# Excluded Studies

## Excluded Studies

### Excluded at the level of full-text paper

Abbreviations/key to reasons for exclusion from analysis

cct | no randomized controlled trial
csf | CSF administered in at least one epo arm but not in control arm
data | not sufficient data available
iron | iron administered in at least one epo arm but not in control arm
low | epo dose <300 IU/kg bodyweight per week (should be specified)
mds | myelodysplastic syndrome
none | no chemo/radiotherapy
other | study objective other than a comparison of erythropoiesis-stimulating products, doses, or comparison to control; additional text provided
sct | high-dose therapy plus autologous stem cell transplantation
surg | pre- or perioperative epo administration (should be specified)
ten | ≤10 patients in at least one study arm
dup | duplicate publication
exKQ1 | excluded -- Key Question 1
exKQ2 | excluded -- Key Question 2
exKQ3 | excluded -- Key Question 3
exKQ4 | excluded -- Key Question 4

plus additional free text explanations

Excluded Studies

Aapro MS, Cella D, Zagari M. Age, anemia, and fatigue. Semin Oncol 2002; 29(3 Suppl 8):55-9.exKQ1: related to Littlewood 2001

Abels R. Erythropoietin for anemia in cancer patients. Eur J Cancer 1993; 29a(Suppl 2):2-8.exKQ1: none; cct; exKQ4: data; exKQ2

Abels R. Recombinant human erythropoietin in the treatment of the anaemia of cancer. Acta Haematol 1992; 87(Suppl 1):4-11.exKQ1; exKQ2: dup Abels 1993; none; cct; exKQ4: data (no statistical methods reported)

Abels RI, Larholt K, Krantz KD, et al. Recombinant human erythropoietin (r-HuEPO) for the treatment of the anemia of cancer. Murphy MJ, editor. Alpha Medical Press, 121–141. 1991. Symp. Dayton 1991 Proc Beijing Symp, AlphaMed Press. Blood cell growth factors: present a future use in hematology and oncology. exKQ4: related to Case 1993 and Henry 1995

Adamson JW, Ludwig H. Predicting the hematopoietic response to recombinant human erythropoietin (epoetin alfa) in the treatment of the anemia of cancer. Oncology 1999; 56(1):46-53.exKQ4: review

Adamson JW. Epoetin alfa: into the new millennium. Semin Oncol 1998; 25(3 Suppl 7):76-9.exKQ4: review

Agoram B, Rossi G, Heatherington AC. Three-times-weekly administration of darbepoetin alfa appears to be as effective as 100 (mu)g once a week in chemotherapy-induced anemia: Results of a clinical trial simulation. J Support Oncol 2005; 3(2 Suppl. 1):26–27.exKQ2 ; clinical trial simulation

Ardizzoni A, Cafferata MA, Rosso R. Epoietin alfa in lung cancer. Tumori 1998; 84(6 Suppl 1):20–6.exKQ4: review

Ariganello O, Mancuso A, Di Molfetta M, et al. A new induction schedule of epoetin alfa 40.000 IU in anemic patients with advanced lung cancer. Lung Cancer 2004; 46(1):119-24.exKQ2; cct

Arslan M, Evrensel T, Kurt E, et al. Comparison of clinical outcomes of different erythropoietin usage strategies. Tumori 2004; 90(4):394–398.exKQ3: cct; exKQ4: data and no control for potential biases

Auerbach M, Ballard H, Trout JR, et al. Intravenous iron optimizes the response to recombinant human erythropoietin in cancer patients with chemotherapy-related anemia: a multicenter, open-label, randomized trial. J Clin Oncol 2004; 22(7):1301–1307.other; different iron dosages tested, all patients received erythropoietin; exKQ4

Aziz K, Hashem T, Mobarek N, et al. Does recombinant human erythropoietin improve the outcome of radiation therapy in head and neck cancer patients. Proceedings of ASTRO Abstract #2274. 2001. cct; personal communication with author suggests that allocation was not concealed exKQ4

Balducci L. Anemia, cancer, and aging. Cancer Control 2003; 10(6):478-86.exKQ4: review article

Bamias A, Aravantinos G, Kalofonos C, et al. Prevention of anemia in patients with solid tumors receiving platinum-based chemotherapy by recombinant human erythropoietin (rHuEpo): A prospective, open label, randomized trial by the Hellenic Cooperative Oncology Group. Oncology 2003; 64(2):102–110.exKQ4: data (only transfusion requirements and Hb change reported)

Barbui T, Romero M, Delaini F, et al. Prospective clinical and epidemiological evaluation of rHuEPO in the routine care of a network of hematological centers. Blood 104 (11), 407–408. 4-12-2004. 46th annual meeting of American Society of Hematology December 4–7 2004 San Diego, CA. Abstract # 5290. exKQ4: data

Beggs VL, Disalvo WM, Meyer LP, et al. Fatigue and plasma cytokines in a randomized double-blind placebo-controlled trial of epoetin alfa in patients undergoing combined modality therapy for unresectable non-small cell lung cancer (NSCLC). Proc Am Soc Clin Oncol 22, 733. 3-6-2003. 39th ASCO annual meeting May 31-June 3, 2003 Chicago, IL. Abstract # 2948. ten

Beguin Y. Prediction of response and other improvements on the limitations of recombinant human erythropoietin therapy in anemic cancer patients. Haematologica 2002; 87(11):1209-21.exKQ4: review article

Beguin Y. Prediction of response to optimize outcome of treatment with erythropoietin. Semin Oncol 1998; 25(3 Suppl 7):27–34.exKQ4: review

Beguin Y. Prediction of response to treatment with recombinant human erythropoietin in anaemia associated with cancer. Med Oncol 1998; 15 Suppl 1:38–46.exKQ4: review article

Beguin Y, Glaspy J, Henry DH, et al. Prediction of hemoglobin non-response in studies of darbepoetin alfa compared with epoetin alfa to treat chemotherapy-induced anemia. Proc Am Soc Clin Oncol 22, 896. 31-5-2003. ASCO annual meeting May 31- June 3 2003 Chicago, IL. Abstract #3605. exKQ4: data (no definition of response reported)

Beguin Y, Loo M, R’Zik S, et al. Early prediction of response to recombinant human erythropoietin in patients with the anemia of renal failure by serum transferrin receptor and fibrinogen. Blood 1993; 82(7):2010–2016.exKQ4: nephrology

Bessho M, Hirashima K, Asano S, et al. Treatment of the anemia of aplastic anemia patients with recombinant human erythropoietin in combination with granulocyte colony-stimulating factor: a multicenter randomized controlled study. Multicenter Study Group. Eur J Haematol 1997; 58(4):265-72.exKQ1: other aplastic anemia exKQ4

Bindi M, Montemaggi M, Sabatino M, et al. Reticulocytes can represent an early indicator of the erythropoietic response to darbepoetin alfa in the anemia by chemotherapy. J Clin Oncol 22[14S]. 5-6-2004. 40th ASCO annual meeting June 5–8 2004 New Orleans, LA. Abstract # 8245. exKQ4: data (Hb); exKQ1: data; relevant outcomes not reported

Blayney D, Fesen M, Mirtsching BC, et al. Every-2-week darbepoetin alfa improves hemoglobin in anemic patients with cancer undergoing chemotherapy: A stratified analysis by tumor type. Blood 102 (11). 6-12-2003. 45th annual meeting American society of Hematology December 6–9 2003 San Diego, CA. Abstract # 3779. exKQ1: data; exKQ4: data (tumor type)

Blohmer JU, Wurschmidt F, Petry U, et al. Results with sequential adjuvant chemo-radiotherapy. Ann Oncol 15 (Suppl. 3). 29-10-2004. the 29th European Society for Medical Oncology Congress 29 October- 2 November 2004 Vienna, Austria Abstract # 447PD. exKQ1: iron ; exKQ4

Bokemeyer C, Aapro MS, Courdi A, et al. EORTC guidelines for the use of erythropoietic proteins in anaemic patients with cancer. Eur J Cancer 2004; 40(15):2201-16.exKQ4: review article

Borota R, Borota J, Belic A, et al. Clinical use of erythropoietin. Med Pregl 1996; 49(9–10):369-76.exKQ4: review

Bosze P, Mayer A, Thurzo L, et al. Recombinant human erythropoietin in the treatment of anemic patients undergoing chemotherapy for cancer. Orv Hetil 1995; 136(47):2567-72.exKQ4: data

Braga M, Gianotti L, Gentilini O, et al. Erythropoiesis after therapy with recombinant human erythropoietin: a dose-response study in anemic cancer surgery patients. Vox Sang 1999; 76(1):38–42.exKQ2: surg, ten

Brinkmann K, Fridman M, Tannous RE, et al. Analysis of the effectiveness of epoetin alfa in clinical practice: results of a retrospective chart review. Blood 100 (11), 499b. 6-12-2002. 44th annual meeting of American society of hematology Dec 6–10 2002 Philadelphia, PA. Abstract 5583. exKQ4: data

Buyukpamukcu M, Varan A, Kutluk T, et al. Is epoetin alfa a treatment option for chemotherapy-related anemia in children? Med Pediatr Oncol 2002; 39(4):455–458.exKQ1: cct; follow up publication to Varan 1999; communication with authors suggest that the allocation was not concealed exKQ4

Canon J. Final results of a randomized, double-blind, active-controlled trial of darbepoetin alfa administered once every 3 weeks (Q3W) for the treatment of anemia in patients receiving multicycle chemotherapy. Journal of Clinical Oncology in Print. 15-5-2005. Proceedings of the 41th Annual Meeting of the American Society of Oncology;13–17 May, 2005; Orlando FL; J Clin Oncol; Abstract 8284. exKQ2: data

Casadevall N, Durieux P, Dubois S, et al. Health, economic, and quality-of-life effects of erythropoietin and granulocyte colony-stimulating factor for the treatment of myelodysplastic syndromes: a randomized, controlled trial. Blood 2004; 104(2):321–327.exKQ1: csf; exKQ4

Casas F, Vinolas N, Farrus B, et al. Karnofsky (KPS) score benefit of erythropoietin (Epo) in lung cancer (LC) patients (pts) undergoing concurrent chemoradiation therapy (Ch-RT). Proc Am Soc Clin Oncol 18. 15-5-1999. 35th ASCO annual meeting May 15–18 1999 Atlanta, GA. Abstract # 1875. exKQ4: data

Cascinu S, Del Ferro E, Fedeli A, et al. Recombinant human erythropoietin treatment in elderly cancer patients with cisplatin-associated anemia. Oncology 1995; 52(5):422-6.exKQ4: data

Cazzola M. Mechanisms of anaemia in patients with malignancy: implications for the clinical use of recombinant human erythropoietin. Med Oncol 2000; (17) Suppl 1:11-6.exKQ4: review

Cazzola M, Coiffier B, Beguin Y. Once-weekly epoetin beta (NeoRecormon®) 30 000 IU is as effective and safe as a three-times weekly regimen for the treatment of anemia in patients with lymphoid malignancies: results of the NOW (NeoRecormon® Once Weekly) Study. Blood 100 (11), 312b. 6-12-2002. 44th annual meeting of the American Society of Hematology Dec 6–10 2002 Philadelphia, PA. Abstract # 4790. exKQ4: exKQ2: data (related to Cazzola 2003)

Cazzola M, Ponchio L, Beguin Y, et al. Subcutaneous erythropoietin for treatment of refractory anemia in hematologic disorders. Results of a phase I/II clinical trial. Blood 1992; 79:29–37.exKQ4: none (more than 50% received no chemotherapy)

Cazzola M, Ponchio L, Pedrotti C, et al. Prediction of response to recombinant human erythropoietin (rHuEpo) in anemia of malignancy. Haematologica 1996; 81:434-41.exKQ4: unclear if patients were treated with chemo- or radiotherapy (“refractory anemia associated with various disorders”; no further details reported)

Chan AT, Leung WT, Lin J, et al. Recombinant human erythropoietin for anaemia in Chinese cancer patients on chemotherapy. Clin Oncol (R Coll Radiol) 1995; 7(4):272.exKQ1: ten

Charu V, Belani CP, Gill AN, et al. A controlled, randomized, open-label study to evaluate the effect of ever-2-week darbepoetin alfa for anemia of cancer. J Clin Oncol 2004; 22 (14S):Abstract #8084.exKQ4: data; exKQ2: none go2

Cheer SM, Wagstaff AJ. Epoetin beta: a review of its clinical use in the treatment of anaemia in patients with cancer. Drugs 2004; 64(3):323-46.exKQ4: review article

Cortes J, O’Brien S, Quintas-Cardama A, Ault P, Giles F, Shan J et al. phase chronic myelogenous leukemia (CML)Recombinant human erythropoietin (rHuEPO) is effective for the treatment of anemia associated with imatinib therapy in patients (pts) with chronic. Blood 102 (11), 911a. 6-12-2003. Annual meeting of ASH Dec 6–9 2003 San Diego, CA. Abstract # 3390. exKQ4: data

Cortes J, O’Brien S, Quintas A, et al. Erythropoietin is effective in improving the anemia induced by imatinib mesylate therapy in patients with chronic myeloid leukemia in chronic phase. Cancer 2004; 100(11):2396–2402.exKQ4: data

Couture F, Turner AR, Melosky B, et al. Prior red blood cell transfusions in cancer patients increase the risk of subsequent transfusions with or without recombinant human erythropoietin management. Oncologist 2005; 10(1):63–71.exKQ4: data (predictors for transfusion)

Crawford J, Blackwell S, Shoemaker D, et al. Prevention of chemotherapy-related anemia by recombinant human erythropoietin (EPO) in patients with small cell lung cancer receiving cyclophosphamide, doxorubicin, and etoposide (CAE) chemotherapy with G-CSF support. Lung Cancer 1997; 18 (Suppl 1):205.exKQ1: data

Crawford J, Robert F, Perry M, et al. Epoetin alfa 40,000 u once weekly maintains hemoglobin in advanced non-small-cell lung cancer patients receiving first-line chemotherapy. Proc Am Soc Clin Oncol 22, 628. 31-5-2003. Proc Am Soc Clin Oncol May 31- June 3 2003 annual meeting Chicago, IL. Abstract 2527.exKQ4 no data available

Dammacco F, Silvestris F, Castoldi GL, et al. The effectiveness and tolerability of epoetin alfa in patients with multiple myeloma refractory to chemotherapy. Int J Clin Lab Res 1998; 28:127-34.exKQ4: data; exKQ1: dup Dammacco 2001

Daneryd P, Svanberg E, Körner U, et al. Protection of metabolic and exercise capacity in unselected weight-losing cancer patients following treatment with recombinant erythropoietin: a randomized prospective study. Cancer Res 1998; 58:5374-9.exKQ1: other Epo not given to all patients in the experimental arm, only to anemic patients exKQ4

de Campos E, Radford J, Steward W, et al. Clinical and in vitro effects of recombinant human erythropoietin in patients receiving intensive chemotherapy for small-cell lung cancer. J Clin Oncol 1995 Jul;13(7):1623-31. exKQ1: exKQ2 dup related Thatcher 1998 exKQ4

Del Mastro L, Gennari A, Donati S. Chemotherapy of non-small-cell lung cancer: role of erythropoietin in the management of anemia. Ann Oncol 1999; 10 Suppl 5:91-4.exKQ4: review

Demetri GD. Anaemia and its functional consequences in cancer patients: current challenges in management and prospects for improving therapy. Br J Cancer 2001; 84 Suppl 1:31-7.exKQ4: review article

Demetri G, Dale DC, Aapro MS, et al. Epoetin alfa improves hemoglobin and quality of life in anemic geriatric cancer patients >/= 60 years receiving chemotherapy. Blood 102 (11). 5-12-2003. 45th annual meeting of American Society of Hematology Dec 6–9 2003 San Diego, CA. Abstract 4368.exKQ4: possible duplication (Demetri 1998) and no meaningful data reported

Demetri GD, Kris M, Wade J, et al. Quality-of-life benefit in chemotherapy patients treated with epoetin alfa is independent of disease response or tumor type: Results from a prospective community oncology study. J Clin Oncol 1998; 16:3412-25.exKQ1: cct; community study

Draisci M, Morra E, Carpani G, et al. 20 Q-abnormality: a factor predictive of response to recombinant erythropoietin therapy in myelodysplastic syndromes? Blood 94 (Suppl. 1), 308a. 3-12-1999. 41st annual meeting of American Society of Hematology Dec 3–7 1999 New Orleans, LA. Abstract # 1379. exKQ4: mds

Duhrsen U. The clinical value of erythropoietin in patients with cancer. Drugs 2002; 62(14):2013-23.exKQ4: review article

Dusenbery KE, McGuire WA, Holt PJ, et al. Erythropoietin increases hemoglobin during radiation therapy for cervical cancer. Int J Radiat Oncol Biol Phys 1994; 29(5):1079-84.exKQ1: cct; exKQ4

Eagleton HJ, Littlewood TJ. Update on the clinical use and misuse of erythropoietin. Curr Hematol Rep 2003; 2(2):109-15.exKQ4: review

Egerer G, Harter C, Karthaus M, Ho AD, Goldschmidt H. Use of erythropoietin in patients with multiple myeloma. Onkologie 2003; 26(1):80-4.exKQ4: review article

Fairclough DL, Gagnon DD, Zagari MJ, et al. Evaluation of quality of life in a clinical trial with nonrandom dropout: the effect of epoetin alfa in anemic cancer patients. Qual Life Res 2003; 12(8):1013-27.exKQ1: related to Littlewood 2001

Fallowfield L, Gagnon D, Zagari M, et al. Multivariate regression analyses of data from a randomised, double-blind, placebo-controlled study confirm quality of life benefit of epoetin alfa in patients receiving non-platinum chemotherapy. Br J Cancer 2002; 87(12):1341-53.exKQ1: related to Littlewood 2001

Faust E. A phase III, double-blind, placebo-controlled, randomized study of novel erythropoiesis stimulating protein (Aranespo) in patients undergoing platinum-treatment for lung cancer. Proc Am Soc Clin Oncol 20. 12-5-2001. 37th annual meeting of ASCO May 12–15 2001 San Francisco, CA. Abstract #1293.exKQ4: data

Gabrilove JL, Cleeland CS, Livingston RB, et al. Clinical evaluation of once-weekly dosing of epoetin alfa in chemotherapy patients: improvements in hemoglobin and quality of life are similar to three-times-weekly dosing. J Clin Oncol 2001; 19(11):2875-82.exKQ1: cct; community study; exKQ4: data

Gamucci T, Thorel MF, Frasca AM, et al. Erythropoietin for the prevention of anaemia in neoplastic patients treated with cisplatin. Eur J Cancer 1993; 29a(Suppl. 2):13-4.exKQ1: data; interim analysis, exKQ4

Garton JP, Gertz MA, Witzig TE, et al. Epoetin alfa for the treatment of the anemia of multiple myeloma. Arch Intern Med 1995; 155:2069-74.exKQ1: ten

Gebbia V, Gebbia N, Testa A, et al. Subcutaneous recombinant human erythropoietin prevents chemotherapy-related anemia in patients with advanced cancer. Int J Oncol 1992; 1:341-5.exKQ1: ten exKQ4

Glaser C, Millesi W, Wanschitz F, et al. R-HuErythropoietin treatment increases efficacy of neo-adjuvant radiochemotherapy and improves cancer free survival of patient with oral squamous cell carcinoma: a 17 months follow-up. ASCO. 15-5-1999. 35th annual meeting ASCO May 15-18 1999 Atlanta, GA. Abstract 1543. exKQ1: cct

Glaser CM, Millesi W, Kornek GV, et al. Impact of hemoglobin level and use of recombinant erythropoietin on efficacy of preoperative chemoradiation therapy for squamous cell carcinoma of the oral cavity and oropharynx. Int J Radiat Oncol Biol Phys 2001; 50(3):705-15.exKQ1: cct exKQ4

Glaspy J, Applebaum S, Henry D, et al. Darbepoetin alfa 6.75mcg every 3 weeks (Q3W) may be synchronized with Q3W chemotherapy to alleviate anemia in cancer patients. Ann Oncol 2004;15(suppl 3), 219–220. The 29th European Society for Medical Oncology Congress, October 29-November 2, 2004; Vienna, Austria. Abstract 833. exKQ2: data

Glaspy J, Bukowski R, Steinberg D, et al. Impact of therapy with epoetin alfa on clinical outcomes in patients with nonmyeloid malignancies during cancer chemotherapy in community oncology practice. J Clin Oncol 1997; 15:1218-34.exKQ1: exKQ2: cct; community study

Glaspy J, Degos L, Dicato M, et al. Comparable efficacy of epoetin alfa for anemic cancer patients receiving platinum- and nonplatinum-based chemotherapy: a retrospective subanalysis of two large, community-based trials. Oncologist 2002; 7(2):126-35.exKQ4: data; exKQ2 :cct

Glaspy J, Demetri G, Cremieux P. Does baseline endogenous erythropoietin level impact hemoglobin (Hb) response to r-HuEPO in cancer patients? Blood 94 (Supp 1), 15b. 7-12-1999. 41st ASH annual meeting Dec 3–7 1999 New Orleans, LA. Abstract 3210. exKQ4: related to Glaspy 1997 and Demetri 1998

Glaspy J, Henry D, Patel R, et al. Effects of chemotherapy on endogenous erythropoietin levels and the pharmacokinetics and erythropoietic response of darbepoetin alfa: A randomised clinical trial of synchronous versus asynchronous dosing of darbepoetin alfa. Eur J Cancer 2005; 41(8):1140–1149.exKQ2 : data

Glaspy J, Jadeja JS, Justice G, et al. A dose-finding and safety study of novel erythropoiesis stimulating protein (NESP) for the treatment of anaemia in patients receiving multicycle chemotherapy. Br J Cancer 2001; 84 Suppl 1:17–23.exKQ1: dose finding study; exKQ2: cct exKQ4

Glossmann JP, Engert A, Wassmer G, et al. Recombinant human erythropoietin, epoetin beta, in patients with relapsed lymphoma treated with aggressive sequential salvage chemotherapy--results of a randomized trial. Ann Hematol 2003; 82(8):469–475.exKQ1: sct; exKQ4

Gonzalez-Baron M, Morales S, Alberola V, et al. Factors predictive of response to epoetin alfa treatment. Proc Am Soc Clin Oncol 19. 20-5-2000. 36th annual meeting ASCO May 20–23 2000 New Orleans, LA. Abstract 2522. exKQ4: related to Gonzalez 1999

Goram AL. Factors and predictors of response with epoetin alfa for chemotherapy-related anemia. J Pharm Technol 2000; 16(6):227–235.exKQ4: review

Hedenus M, Adriansson M, San Miguel J, et al. Efficacy and safety of darbepoetin alfa in anaemic patients with lymphoproliferative malignancies: a randomized, double-blind, placebo-controlled study. Br J Haematol 2003; 122(3):394–403.exKQ4: data (although statistical methods are described they do not match with the results)

Hedenus M, Glaspy J, Dewey C, et al., the NESP990114 and 980290 Study Groups. Dose response of darbepoetin alfa is similar in anemic patients with solid tumors or lymphoproliferative malignancies. Blood 98 (11), 297a. 7-12-2001. 43rd annual meeting of American Society of Hematology Dec 7–11 2001 Orlando, FL. Abstract # 1255. exKQ4: comparison of different studies

Hedenus M, Vansteenkiste J, Poulsen E, et al. Darbepoetin alfa as a treatment for chemotherapy-induced anemia: an integrated analysis of data from multiple studies. Blood 100 (11), 17b–18b. 6-12-2002. 44th annual meeting of American Society of Hematology Dec 6–10 2002 Philadelphia, PA. Abstract 3520. exKQ4: data

Hellström Lindberg E, Ahlgren T, et al. Treatment of anemia in myelodysplastic syndromes with granulocyte colony-stimulating factor plus erythropoietin: results from a randomized phase II study and long-term follow-up of 71 patients. Blood 1998; 92(1):68–75.exKQ1: mds; csf exKQ4

Hellstrom-Lindberg E, Negrin R, Stein R, et al. Erythroid response to treatment with G-CSF plus erythropoietin for the anaemia of patients with myelodysplastic syndromes: proposal for a predictive model. Br J Haematol 1997; 99(2):344-51.exKQ4: mds

Henke M, Guttenberger R, Barke A, et al. Erythropoietin for patients undergoing radiotherapy: a pilot study. Radiotherapy and Oncology 1999; 50(2):185-90.exKQ4: data; exKQ2 data

Henry DH, Abels RI. Recombinant human erythropoietin in the treatment of cancer and chemotherapy-induced anemia: results of double-blind and open-label follow-up studies. Semin Oncol 1994; 21(2 (Suppl 3):21-8.exKQ4: related to Case 1993 and Henry 1995

Henry DH, Thatcher N. Patient selection and predicting response to recombinant human erythropoietin in anemic cancer patients. Semin Hematol 1996; 33(1 Suppl 1):2–5.exKQ4: review

Italian Cooperative Study Group. A randomized double-blind placebo-controlled study with subcutaneous recombinant human erythropoietin in patients with low-risk myelodysplastic syndromes. Br J Haematol 1998; 103:1070-4.exKQ1: mds; exKQ4: mds

Jitnuyanont A. Impact of therapy with recombinant human erythropoietin (r-HuEPO) and quality-of-life in anemic cancer patients. Intern Med J Thailand 2001; 17(4):283–290.exKQ4: data, exKQ1: ten

Kallich JD, Tchekmedyian NS, Damiano AM, et al. Psychological outcomes associated with anemia-related fatigue in cancer patients. Oncology (Huntingt) 2002; 16(9 Suppl 10):117-24.exKQ1: related to Vansteenkiste 2002

Kotasek D, Canon JL, San Miguel J, et al. Correction/maintenance dosing (front loading) of darbepoetin alfa: Final results from a randomized phase III active-controlled trial. J Support Oncol 2005; 3(2 Suppl. 1):16–17.exKQ2 : related to Kotasek 2004

Kotasek D, Steger G, Faught W, et al. Darbepoetin alfa administered every 3 weeks alleviates anaemia in patients with solid tumours receiving chemotherapy; results of a double-blind, placebo-controlled, randomised study. Eur J Cancer 2003; 39(14):2026–2034.in4: exKQ4: data

Kurz C, Marth C, Windbichler G, et al. Erythropoietin treatment under polychemotherapy in patients with gynecologic malignancies: a prospective, randomized, double-blind placebo-controlled multicenter study. Gynecologic Oncology 1997; 65(3):461-6.exKQ4: data (statistical methods)

Lavey RS, Dempsey WH. Erythropoietin increases hemoglobin in cancer patients during radiation therapy. Int J Radiat Oncol Biol Phys 1993; 27:1147-52.exKQ4: data (outcome); exKQ1: cct, dup Lavey 2004

Lavey RS, Liu PY, Greer BE, et al. Recombinant human erythropoietin as an adjunct to radiation therapy and cisplatin for stage IIB-IVA carcinoma of the cervix: a Southwest Oncology Group study. Gynecol Oncol 2004; 95(1):145-51.exKQ4: data, exKQ1: cct, dup Lavey 1993

Leitgeb C, Pecherstorfer M, Fritz E, et al. Quality of life in chronic anaemia of cancer during treatment with recombinant human erythropoietin. Cancer 1994; 73:2535-42.exKQ4: data; exKQ1: cct

Leon P, Jimenez M, Barona P, et al. Recombinant human erythropoietin for the treatment of anemia in children with solid malignant tumors. Med Pediatr Oncol 1998; 30(2):110-6.exKQ4: data; exKQ1: cct

Littlewood TJ. Efficacy and quality of life outcomes of epoetin-alpha in a double-blind, placebo-controlled, multicentre study of cancer patients receiving non-platinum-containing chemotherapy. Front Radiat Ther Oncol 2002; 37:34-7.exKQ1: related to Littlewood 2001

Littlewood TJ, Bajetta E, Nortier JW, et al. Effects of epoetin alfa on hematologic parameters and quality of life in cancer patients receiving nonplatinum chemotherapy: results of a randomized, double-blind, placebo-controlled trial. J Clin Oncol 2001; 19(11):2865-74.exKQ4: data ;exKQ2 :data for 2 doses

Littlewood TJ, Bajetta E, Rapoport B, et al. Early administration of epoetin alfa optimizes anemia management with respect to hematologic and quality of life (QOL) outcomes in anemic cancer patients (pts) undergoing chemotherapy. Blood 100 (11). 6-12-2002. 44th annual meeting of the American Society of Hematology Dec 6–10 2002 Philadelphia, PA. Abstract 3524. exKQ4: data; exKQ2: data

Littlewood TJ, Nortier J, Rapoport B, et al. Epoetin alfa corrects anemia and improves quality of life in patients with hematologic malignancies receiving non-platinum chemotherapy. Hematol Oncol 2003; 21(4):169–180.exKQ4: data, exKQ1: related to Littlewood 2001

Ludwig H, Chott A, Fritz E, et al. Increase of bone marrow cellularity during erythropoietin treatment in myeloma. Stem Cells 1995; 13 Suppl 2:77–87.exKQ4: unclear if patients received chemo-/radiotherapy

Ludwig H, Sundal E, Pecherstorfer M, et al. Recombinant human erythropoietin for the correction of cancer associated anemia with and without concomitant cytotoxic chemotherapy. Cancer 1995; 76(11):2319-29.exKQ1: cct

MacDougall IC. Could anti-inflammatory cytokine therapy improve poor treatment outcomes in dialysis patients? Nephrol Dial Transplant 2004; 19 Suppl 5:73–78.exKQ4: nephrology

MacDougall IC, Cooper AC. Erythropoietin resistance: the role of inflammation and pro-inflammatory cytokines. Nephrol Dial Transplant 2002; 17 Suppl 11:39–43.exKQ4: nephrology

Maisnar V, Chroust K. Treatment of associated anemia in different hematological disorders with epoetin alpha. Neoplasma 2004; 51(5):379-84.exKQ4: data

Malik IA, Khan ZK, Hakimali A, et al. The effect of subcutaneous recombinant human erythropoietin (r-HuEPO) on anemia in cancer patients receiving platinum-based chemotherapy. J Pakistan Med Assoc 1998; 48(5):127-31.exKQ1: cct exKQ4

Malyszko J, Zbroch E, Wolczynski S, et al. Leptin and serum erythropoietin in hemodialyzed and peritoneally dialyzed uremic patients during rHuEPO therapy. Am J Nephrol 2000; 20(3):180-6.exKQ4: nephrology

Mangiameli A, Spina S, Iannetti E, et al. [Erythropoietin and cisplatin-induced neuropathies in cancer patients]. [Italian]. Clinica Terapeutica 2002; 153(3):177–180.exKQ1: ten exKQ4

Mantovani G, Ghiani M, Curreli L, et al. Assessment of the efficacy of two dosages and schedules of human recombinant erythropoietin in the prevention and correction of cisplatin-induced anemia in cancer patients. Oncol Rep 1999; 6(2):421-6.exKQ2 ; ten

Mantovani L, Lentini G, Hentschel B, et al. Treatment of anaemia in myelodysplastic syndromes with prolonged administration of recombinant human granulocyte colony-stimulating factor and erythropoietin. Br J Haematol 2000; 109(2):367–375.exKQ1: cct exKQ4

Marinaccio M, Mele E, Giotta F, et al. Pretreatment normalization of mild anemia with epoetin alfa: Impact on the outcome in epithelial ovarian cancer patients. Proc Am Soc Clin Oncol 22, 486. 31-5-2003. 39th ASCO annual meeting May 31 - June 3 2003 Chicago, IL. Abstract 1952. exKQ1: surg exKQ4

Markman M, Reichman B, Hakes T, et al. The use of recombinant human erythropoietin to prevent carboplatin-induced anemia. Gynecol Oncol 1993; 49(2):172-6.exKQ1: cct exKQ4

Martin SC, Gagnon DD, Zhang L, et al. Cost-utility analysis of survival with epoetin-alfa versus placebo in stage IV breast cancer. Pharmacoeconomics 2003; 21(16):1153–1169.exKQ1: related to Littlewood 2001

Mirtsching B, Charu V, Vadhan-Raj S, et al. Every-2-week darbepoetin alfa is comparable to rHuEPO in treating chemotherapy-induced anemia. Results of a combined analysis. Oncology (Huntingt) 2002; 16(10 Suppl 11):31-6.exKQ4: data

Mittelman M. The implications of anemia in multiple myeloma. Clin Lymphoma 2003; 4 Suppl 1:23-9.exKQ4: review

Mittelman M, Floru S, Djaldetti M. Subcutaneous erythropoietin for treatment of refractory anemia in hematologic disorders. Blood 1992; 80(3):841–843.exKQ4: data

Moebus V, Bastert G, Kreienberg R, et al. Epoetin alpha prevents anemia and transfusions of rbcs in patients receiving dose-dense sequential chemotherapy. Proceedings of ASCO. 12-5-2001. Annual meeting of ASCO May 12–15 2001 San Francisco, CA. Abstract # 36. exKQ1: iron exKQ4

Musto P, Matera R, Minervini MM, et al. Low serum levels of tumor necrosis factor and interleukin-1 beta in myelodysplastic syndromes responsive to recombinant erythropoietin. Haematologica 1994; 79(3):265-8.exKQ4: mds

Nguyen TV, Trinh GN. Clinical evaluation of once-weekly and three-times-weekly dosings of epoetin alfa in chemotherapy patients: problems of study design and interpretation. J Clin Oncol 2002; 20(3):878.exKQ2

Osterborg A, Brandberg Y, Molostova V, et al. Randomized, Double-Blind, Placebo-Controlled Trial of Recombinant Human Erythropoietin, Epoetin Beta, in Hematologic Malignancies. J Clin Oncol 2002; 20(10):2486-94.exKQ4: data (predictors for transfusion-free survival); dup Osterborg 2005

Pangalis GA, Poziopoulos C, Angelopoulou MK, et al. Effective treatment of disease-related anaemia in B-chronic lymphocytic leukaemia patients with recombinant human erythropoietin. Br J Haematol 1995; 89(3):627–629.exKQ4: data; exKQ1: data

Pangalis GA, Siakantaris MP, Angelopoulou MK, et al. Downstaging Rai stage III B-chronic lymphocytic leukemia patients with the administration of recombinant human erythropoietin. Haematologica 2002; 87(5):500-6.exKQ4: none

Patton J, Kuzur M, Liggett W, et al. Epoetin alfa 60,000 u once weekly followed by 120,000 u every 3 weeks increases and maintains hemoglobin levels in anemic cancer patients undergoing chemotherapy. Oncologist 2004; 9(1):90–96.exKQ2 :cct

Patton J, Reeves T, Wallace J. Effectiveness of darbepoetin alfa versus epoetin alfa in patients with chemotherapy-induced anemia treated in clinical practice. Oncologist 2004; 9(4):451–458.exKQ1: chart review

Pecorelli S. The Italian gynecological consensus statement on the use of epoetin alfa in the management of anemia. Semin Oncol 2002; 29(3 Suppl 8):13-5.exKQ4: review article

Pierelli L, Perillo A, Greggi S, et al. Erythropoietin addition to granulocyte colony-stimulating factor abrogates life-threatening neutropenia and increases peripheral-blood progenitor-cell mobilization after epirubucin, paclitaxel and cisplatin combination chemotherapy: results of a randomized comparison. J Clin Oncol 1999; 17(4):1288-95.exKQ1: data exKQ4

Pirker R, Vansteenkiste J, Gateley J, et al. A phase 3, double-blind, placebo-controlled, randomized study of novel erythropoiesis stimulating protein (NESP) in patients undergoing platinum treatment for lung cancer. Proc Am Soc Clin Oncol 20, Abstract # 1572. 12-5-2001. 37th annual meeting of ASCO May 12–15 2001 San Francisco, CA. Abstract 1572. exKQ4: data; exKQ1: related to Vansteenkiste 2002

Pirker R, Vansteenkiste J, Tomita D, et al. Exploratory analysis of the effect of baseline hemoglobin (Hb) on response to darbepoetin alfa in a phase 3 study of in lung cancer patients (pts). Ann Oncol 13 (Suppl 5), 177 (Abstract #651P). 18-10-2002. 27th ESMO Congress, Nice, France, 18–22 October 2002. exKQ4: data

Ponchio L, Beguin Y, Farina G, et al. Evaluation of erythroid marrow response to recombinant human erythropoietin in patients with cancer anaemia. Haematologica 1992; 77(6):494–501.exKQ4: data

Porter JC, Leahey A, Polise K, et al. Recombinant human erythropoietin reduces the need for erythrocyte and platelet transfusions in pediatric patients with sarcoma: A randomized, double-blind, placebo-controlled trial. J Pediatrics 1996; 129(5):656-60.exKQ1: ten exKQ4

Prozanto P, Cortesi E, van der Rijt K, et al. Early intervention with epoetin alfa in breast cancer (BC) patients (pts) undergoing chemotherapy (CT): results of a randomized, multicenter, phase IIIb study (EPO-INT-47 Study Group). Annals of Oncology 13 Suppl 5, 168. 18-10-2002. 27th annual meeting of the European Society for Medical oncology Oct 18 –22 2002 Nice, France Abstract 6200. go1 exKQ4

Quirt I, Robeson C, Lau CY, et al. Epoetin alfa in patients not on chemotherapy - Canadian data. Semin Oncol 2002; 29(3 Suppl 8):75–80.exKQ4: none

Rearden TP, Charu V, Saidman B, et al. Results of a randomized study of every three-week dosing (Q3W) of darbepoetin alfa for chemotherapy-induced anemia (CIA). Blood 102[11]. 6-12-2003. Proceedings of the 45th Annual Meeting of the American Society of Hematology; December 6–9;2003; San Diego, CA. Abstract 3783. exKQ4: epo for Hb maintenance; exKQ3 interim results related to Rearden T 2004

Reed N, Morere JF. Optimising anaemia management with epoetin beta. Oncology 2004; 67 Suppl 1:12-6.exKQ2 ; related to Cazzolla 2003

Remacha A, Arrizabalaga B, Villegas A, et al. Characteristics of a subgroup of responders to erythropoietin plus granulocyte colony-stimulating factor in myelodysplastic syndromes. Blood 94 (Suppl. 1), 308a. 3-12-1999. 41st Annual Meeting of American Society of Hematology Dec 3–7 1999 New Orleans, LA. Abstract # 1378. exKQ4: mds

Remacha AF, Arrizabalaga B, Villegas A, et al. Erythropoietin plus granulocyte colony-stimulating factor in the treatment of myelodysplastic syndromes. Identification of a subgroup of responders. The Spanish Erythropathology Group. Haematologica 1999; 84(12):1058-64.exKQ4: mds

Richart JM, Petruska PJ, Klebert KS, et al. A phase III trial of epoetin alfa: early vs late administration in patients treated with chemotherapy. Blood 2002; 100:175b. Proceedings of the 44th Annual Meeting of the American Society of Hematology; December 6–10, 2002; Philadelphia, PA. Abstract 4199. Interim analysis.

Rosberg J, Cremieux PY, McKeown SR, et al. Benefits of early hemoglobin response to epoetin alfa in elderly patients with chemotherapy-related anemia. Blood 104 (11), 609a. 4-12-2004. 46th annual meeting of the American Society of Hematology Dec 4–7 2004 San Diego California Abstract # 2216. exKQ4: data

Rosberg J, Lefebvre P, Fastenau J, et al. Clinical significance of a >/= 1 gram/deciliter (g/dL) rise in hemoglobin (Hb) at week 4 (early response) or at week 8 during epoetin alfa (EPO) treatment. Blood 102 (11). 6-12-2003. 45th annual meeting of American Society of Hematology Dec 6–9 2003 San Diego California Abstract # 2777. exKQ4: data

Rose EH, Abels RI, Nelson RA, et al. The use of r-HuEpo in the treatment of anaemia related to myelodysplasia (MDS). Br J Haematol 1995; 89(4):831-7.exKQ4: mds

Rosen FR, Haraf DJ, Kies MS, et al. Multicenter randomized phase II study of paclitaxel (1-hour infusion), fluorouracil, hydroxyurea, and concomitant twice daily radiation with or without erythropoietin for advanced head and neck cancer. Clin Cancer Res 2003; 9(5):1689–1697.exKQ4: data; exKQ1: iron

Samol J, Littlewood TJ. The efficacy of rHuEPO in cancer-related anaemia. Br J Haematol 2003; 121(1):3–11.exKQ4: review

Samper OP, Rodriguez PA, Martin DM, et al. Treatment of anemia in patients under radiotherapy with subcutaneous epoetenium alpha 10,000 iu three times a week and 40,000 iu once a week. Oncologia (Madrid) 2002; 25(8):40–46.exKQ2: cct exKQ4

San Miguel JF, Garcia-Sanz R. Recombinant human erythropoietin in the anaemia of multiple myeloma and non-Hodgkin’s lymphoma. Med Oncol 1998; 15 Suppl 1:29–34.exKQ2 :cct

Sato T, Maekawa T, Watanabe S, et al. Erythroid progenitors differentiate and mature in response to endogenous erythropoietin. J Clin Invest 2000; 106(2):263-70.exKQ4: laboratory study

Schwartzberg L, Yee L, Senecal F, et al. Darbepoetin alfa (DA) 200 mcg every 2 weeks (Q2W) vs epoetin alfa (Epo) 40,000 U weekly (QW) in anemic patients (pts) receiving chemotherapy (ctx). Journal of Clinical Oncology 22 (14S), Abstract #8063. 5-6-2004. 40th Proceedings of ASCO June 5–8 2004 New Orleans, Louisiana. exKQ4: data

Scott SN, Boeve TJ, McCulloch TM, et al. The effects of epoetin alfa on transfusion requirements in head and neck cancer patients: a prospective, randomized, placebo-controlled study. Laryngoscope 2002; 112(7 Pt 1):1221–1229.exKQ1: surg exKQ4

Shasha D, George MJ, Harrison LB. Once-weekly dosing of epoetin-alpha increases hemoglobin and improves quality of life in anemic cancer patients receiving radiation therapy either concomitantly or sequentially with chemotherapy. Cancer 2003; 98(5):1072–1079.exKQ4: data; exKQ1: cct; community study

Siakantaris MP, Angelopoulou MK, Vassilakopoulos TP, et al. Correction of disease related anaemia of B-chronic lymphoproliferative disorders by recombinant human erythropoietin: maintenance is necessary to sustain response. Leuk Lymphoma 2000; 40(1–2):141-7.exKQ4: none

Silvestris F, Romito A, Fanelli P, et al. Long-term therapy with recombinant human erythropoietin (rHu-EPO) in progressing multiple myeloma. Ann Hematol 1995; 70:313-8.exKQ4: data

Smith RE, Tchekmedyian NS, Chan D, et al. A dose- and schedule-finding study of darbepoetin alpha for the treatment of chronic anaemia of cancer. Br J Cancer 2003; 88(12):1851–1858.exKQ1; exKQ2: none; exKQ4

Stasi R, Brunetti M, Bussa S, et al. Response to recombinant human erythropoietin in patients with myelodysplastic syndromes. Clin Cancer Res 1997; 3(5):733-9.exKQ4: exKQ1 mds

Stasi R, Pagano A, Terzoli E, et al. Recombinant human granulocyte-macrophage colony-stimulating factor plus erythropoietin for the treatment of cytopenias in patients with myelodysplastic syndromes. Br J Haematol 1999; 105(1):141-8.exKQ4: mds

Stein RS, Abels RI, Krantz SB. Pharmacologic doses of recombinant human erythropoietin in the treatment of myelodysplastic syndromes. Blood 1991; 78(7):1658-63.exKQ1: ten, mds

Stone RM, Bernstein SH, Demetri G, et al. Therapy with recombinant human erythropoietin in patients with myelodysplastic syndromes. Leuk Res 1994; 18(10):769-76.exKQ4: mds

Straus DJ. Epoetin alfa therapy for patients with hematologic malignancies and mild anemia. Clin Lymphoma 2003; 4 Suppl 1:S13–S17.exKQ3 review

Straus DJ, Turner RR, Testa MA, et al. Epoetin alfa treatment improves quality of life and increases hemoglobin levels during chemotherapy for lymphoma, chronic lymphocytic leukemia (CLL), and multiple myeloma (MM) patients with mild-to-moderate anemia. Blood 100, 220a-221a. 6-12-2002. 44th Annual Meeting of the American Society of Hematology; December 6–10, 2002; Philadelphia, PA. Abstract 828. exKQ3: interim results related to Straus 2003

Sweeney PJ, Nicolae D, Ignacio L et al. Effect of subcutaneous recombinant human erythropoietin in cancer patients receiving radiotherapy: final report of a randomized, open-labelled, phase II trial. Br J Cancer 1998; 77(11):1996–2002.exKQ4: data; exKQ1: iron

Tchekmedyian NS, Kallich J, McDermott A, Fayers P, Erder MH. The relationship between psychologic distress and cancer-related fatigue. Cancer 2003; 98(1):198–203.exKQ1: related to Vansteenkiste 2002; exKQ4

Terpos E, Mougiou A, Kouraklis A, et al. Prolonged administration of erythropoietin increases erythroid response rate in myelodysplastic syndromes: a phase II trial in 281 patients. Br J Haematol 2002; 118(1):174-80.exKQ4: mds

Thompson JA, Gilliland DG, Prchal JT, et al. Effect of recombinant human erythropoietin combined with granulocyte/macrophage colony-stimulating factor in the treatment of patients with myelodysplastic syndrome. Blood 2000; 95:1175-9.exKQ4: mds; exKQ1: mds

Tsukuda M, Yuyama S, Kohno H, et al. Effectiveness of weekly subcutaneous recombinant human erythropoietin administration for chemotherapy-induced anemia. Biotherapy 1998; 11:21-5.exKQ1; exKQ2 :ten exKQ4

Vadhan-Raj S, Hong JJ, Gregory SA, et al. An open-label, randomized study to develop a screening tool for functional capacity in anemic subjects with nonmyeloid malignancies receiving chemotherapy and darbepoetin alfa. Blood 102 (11). 6-12-2003. 45th annual meeting of American Society of Hematology Dec 6–9 2003 San Diego, CA. Abstract 1814. exKQ4: data

Vadhan-Raj S, Mirtsching B, Gregory SA, et al. Baseline covariates of response to darbepoetin alfa (DA) every 2 weeks (Q2W) in patients (pts) with chemotherapy-induced anemia. J Clin Oncol 22 (14S). 5-6-2004. 40th annual meeting of ASCO June 5–8 2004 New Orleans, LA. Abstract 8061. exKQ4: data

Vadhan-Raj S, Skibber JM, Crane C, et al. Randomized, double-blind, placebo-controlled trial of epoetin alfa (Procrit) in patients with rectal and gastric cancer undergoing chemo-radiotherapy (CT/RT) followed by surgery: early termination of the trial due to increased incidence of thrombo-embolic events (TEE). Blood 104[11], 797a. 4-12-2004. 46th annual meeting of the American Society of Hematology Dec 4–7 2004 San Diego, CA. Abstract 2915. exKQ4: data (predictive factors for Hb change)

Vansteenkiste J, Pirker R, Massuti B, et al. Double-blind, placebo-controlled, randomized phase III trial of darbepoetin alfa in lung cancer patients receiving chemotherapy. J Natl Cancer Inst 2002; 94:1211-20.exKQ4: data

Vansteenkiste J, Poulsen E, Rossi G, et al. Darbepoetin alfa: impact on treatment for chemotherapy-induced anemia and considerations in special populations. Oncology (Huntingt) 2002; 16(10 Suppl 11):45–55.exKQ1: related to Vansteenkiste 2002

Vansteenkiste J, Tomita D, Rossi G, et al. Darbepoetin alfa in lung cancer patients on chemotherapy: a retrospective comparison of outcomes in patients with mild versus moderate-to-severe anaemia at baseline. Supportive Care in Cancer 2004; 12(4):253–262.exKQ4: data; exKQ1: dup related to Vansteenkiste 2002

Varan A, Buyukpamukcu M, Kutluk T, et al. Recombinant human erythropoietin treatment for chemotherapy-related anemia in children. Pediatrics 1999; 103(2):161-4.exKQ4: data; exKQ1: cct, communication with authors suggest allocation not concealed, dup Buyukpamukcu 2002

Velilla Millan C, Polo Jaime S, Lopez P, et al. Effect of two administration schedules of erythropoietin upon hemoglobin in breast cancer patients treated with radiation therapy. Oncologia (Spain) 2003; 26(8):45–51.exKQ2: cct

Verma N, Tester W. Alternate week dosing of epoetin alfa - an option for maintenance of hemoglobin in patients who responded to weekly dosing schedule. Blood 102 (11). 6-12-2003. 45th annual meeting of American Society of Hematology Dec 6–9 2003 San Diego, CA. Abstract # 3781. exKQ4: epo used for maintenance

Wagner LM, Billups CA, Furman WL, et al. Combined use of erythropoietin and granulocyte colony- stimulating factor does not decrease blood transfusion requirements during induction therapy for high-risk neuroblastoma: A randomized controlled trial. J Clin Oncol 2004; 22(10):1886–1893.exKQ1: sct; exKQ4

Waltzman RJ. A randomized, active-control, pilot trial of front-loaded dosing regimens of darbepoetin-alfa for the treatment of patients with anemia during chemotherapy for malignant disease. Cancer 2004; 100(7):1545–1546.exKQ1: comment to Glaspy 2003 study

Yilmaz D, Cetingul N, Kantar M, et al. A single institutional experience: is epoetin alpha effective in anemic children with cancer? Pediatr Hematol Oncol 2004; 21(1):1–8.exKQ4: data, exKQ1: cct; exKQ2

Zagari M, Wacholz M, Xiu L. An open-label, controlled, randomized, dose comparison study of epoetin alfa for the treatment of anemia in cancer patients receiving platinum containing chemotherapy. Hematol J 61[4(suppl 2)]. 13-6-2003. 8th Congress of the European Hematology Association June 13–15 2003 Lyon France. Abstract 0177. exKQ2: ten

Zagari MJ, Pallister CJ, Perkins AC, et al. Pre-treatment factors are poor predictors of individual responses to rHuEPO in anemic cancer patients. Blood 100 (11), 13b. 6-12-2002. 44th annual meeting of American Society of Hematology Dec 6–10 2002 Philadelphia, PA. Abstract 3503. exKQ4: data

Ziras N, Rozakou AJ, Potamianou A, et al. Soluble transferrin receptor (sTFR) as a predictor of response to prophylactic epoetin alfa (EPO) treatment in non-anemic cancer patients (pts) under chemotherapy (CT). Preliminary results. Proc Am Soc Clin Oncol 20. 12-5-2001. 37th annual meeting of ASCO May 12–15 2001 San Francisco, CA. Abstract 2987. exKQ4: data and epo used for Hb maintenance