# Evidence Tables

Table C1

KQ1: Number of studies and randomized patients comparing darbepoetin versus epoetin, epoetin versus control, and darbepoetin versus control, summarized by outcomes reported

Outcome | Darbepoetin (1) vs. Epoetin (2) (R=randomized; E=evaluated) | | | | Epoetin (1) vs. Control (2) (R=randomized; E=evaluated) | | | | Darbepoetin (1) vs. Control (2) (R=randomized; E=evaluated)
| #RCTs | Total N | N (1) | N (2) | #RCTs | Total N | N (1) | N (2) | #RCTs | Total N | N (1) | N (2)
Effectiveness Outcomes
hematologic response rates^1^ | 3 | R:645 E:634 | R:404 E:397 | R:241 E:237 | 15 | R:3,508 E:3,293 | R:2,016 E:1,844 | R:1,492 E:1,449 | 3 | R:674 E:659 | R:439 E:427 | R:235 E:232
transfusion rates | 6 | R:2,375 E:2,158 | R:1,322 E:1,169 | R:1,053 E:989 | 34 | R:5,280 E:5,210 | R:2,902 E:2,859 | R:2,378 E:2,351 | 4 | R:994 E:950 | R:598 E:566 | R:396 E:384
tumor response rates | 0 | | | | 5 | R:788 E:688 | R:391 E:345 | R:397 E:343 | 1 | R:320 E:315 | R:159 E:156 | R:161 E:159
overall survival | 1 | R:358 E:358 | R:180 E:180 | R:178 E:178 | 35^2^ | R:6,964 E:6,918 | R:3,850 E:3,825 | R:3,114 E:3,093 | 4 | R:994 E:911 | R:598 E:583 | R:396 E:328
quality of life | 2 | R:1,342 E:810 | R:705 E:433 | R:637 E:377 | 13 | R:2,947 E:2,374 | R:1,558 E:1,274 | R:1,389 E:1,100 | 2 | R:663 E: 558 | R: 332 E: 279 | R:331 E:279
Adverse Events
thromboembolic events | 3 | R:1,896 E:1,879 | R:953 E:948 | R:943 E:931 | 30 | R:6,168 E:6,092 | R:3,395 E:3,355 | R:2,773 E:2,737 | 1 | R:320 E:314 | R:159 E:155 | R:161 E:159
hypertension | 0 | | | | 15 | R:1,975 E:1,949 | R:1,169 E:1,156 | R:806 E:793 | 1 | R:320 E:314 | R:159 E:155 | R:161 E:159
thrombocytopenia/hemorrhage | 0 | | | | 9 | R:1,434 E:1,422 | R:835 E:830 | R:599 E:592 | 0
rash | 0 | | | | 6 | R:533 E:522 | R:317 E:306 | R:216 E:216 | 0
seizures | 1 | R:127 E:127 | R:96 E:96 | R:31 E:31 | 3 | R:389 E:389 | R:198 E:198 | R:191 E:191 | 0
antibodies^3^ | 4 | R:1,967 E:1,967 | R:1,114 E:1,114 | R:853 E:853 | 6 | R:1,305 E:1,305 | R:704 E:704 | R:601 E:601 | 4 | R:994 E:994 | R:598 E:598 | R:396 E:396

1 defined as Hb increase ≥2 g/dL from baseline (see Methods for details)

2 Cazzola 1995 randomized 117 patients to 4 epoetin arms, plus 29 patients to control. Two treatment arms were excluded from all analyses but survival, since epoetin dose was <300 IU/Kg per week. However, Cazzola et al. only reported survival data pooled across all treatment arms, precluding exclusion of the low-dose arms. Thus, Cazzola 1995 randomized 146 patients for survival and 86 for all other outcomes.

3 Reports generally did not specify the number of patients evaluated for antibodies, and included mostly qualitative statements (e.g., “no antibody formation observed”). Absent information, the review assumed all randomized patients were evaluated.

Table C2

KQ1: Epoetin versus Control, Study Characteristics, Part I

study author | n randomized | n randomized in experimental arm | n randomized in control arm | drug | dose | weight based or fix | duration of study drug medication (weeks) | dose adjustment | iron | transfusion trigger | primary and secondary outcomes of the study
Aravantinos 2003 | 47 | 24 | 23 | Epoetin alfa (assume) | 3 × 150 IU/kg/wk sc | weight | NR, approx. >9–12 | decreasing: stopped if Hb >14 g/dl, restarted with 25% reduction when Hb <12.5 g/dl | fix | Hb < 9g/dL or discretion of physician | Hb, Hct, RBCT
Bamias 2003 | 144 | 72 | 72 | Epoetin alfa | 3 × 10,000 IU/wk sc | fixed | 21 to 24 wks (duration of chemo), categorized as >20 | decreasing: if Hb increased by 2 g/dl dose reduced to 50% reduction, stopping: if Hb > 15 g/dL epo stopped and resumed at 50% dose when Hb <13g/dl | NR | discretion of physician | Hb, RBCT (QoL in a subset)
Boogaerts 2003, Coiffier 2001 | 262 | 133 | 129 | Epoetin beta | 3 × 150 IU/kg/wk sc | weight | 12 | Increasing: if Hb increase <0.5 g/dL within 3–4 wks or <1 g/dL within 6–8 wks dose increased to 300 IU/kg. Decreasing: if Hb increase >2 g/dL within 4 wks dose reduced by 50%. If Hb >14 g/dL stopped and reinstated at 50% if Hb <12 g/dL | as necessary | Hb <8.5 g/dL | Hb, RBCT, QoL
Carabantes 1999 | 35 | 20 | 15 | Epoetin alfa | 3 × 150 IU/kg/wk sc | weight | during 6 cycles of CT, cycle length 21–28 days, assumed 18 – 24 wk | increasing: if no response dose increased to 3 × 300 IU/kg/wk | not reported | NR | Hb, RBCT, QoL
Cascinu 1994 | 100 | 50 | 50 | Epoetin alfa | 3 × 100 IU/kg | weight | 9 | decreasing: if Hb >12g/dl stopped until Hb level deceased <10 g/dl | as necessary | Hb <8g/dL or clinical symptoms | Hb, RBCT, AE
Case 1993 | 157 | 81 | 76 | Epoetin alfa | 3 × 150 IU/kg/wk sc | weight | 12 | decreasing: if Hct 38% was reached dose could be reduced to maintain Hct level | as necessary | at discretion of physician | Hb, RBCT, QoL, AE
Cazzola 1995 c | 146 | c: 31, d: 26 (arms a and b excluded) | 29 | Epoetin beta | 7 × 5,000 IU/wk, 7 × 10,000 IU/wk sc | fixed | 8 | decreasing: if Hb increased >2 g/dL OR Hb level >12.5 g/dL dose was reduced from 7× to 3× per week. If Hb >13 g/dl (MM) or >15 g/dL (NHL) drug was stopped | as necessary | at discretion of physician | Hb, RBCT, AE
Chang 2005 | 354 | 176 | 178 | Epoetin alfa | 1 × 40,000 IU/wk sc | fixed | 16, max 28 | Increasing: if at the end of week 4 or 6 Hb had decreased > 2 g/dl dose increased to 60,000 IU Decreasing: If Hb > 14 g/dl stopped until ≤12g/dl, then restart with 75%. If Hb increased > 2 g/dl per month dose reduced by 25% | as necessary | Hb <8g/dL or discretion of physician | QoL, Hb, safety
Dammacco 2001 | 145 | 69 | 76 | Epoetin alfa | 3 × 150 IU/kg/wk sc | weight | 12 | Increasing: if Hb did not increase dose increased to 3 × 300 IU/kg/wk | as necessary | Hb < 7 g/dL or cardiovascular symptoms | Hb, RBCT, QoL, AE
Del Mastro 1997 | 62 | 31 | 31 | Epo, unclear whether alfa or beta | 3 × 150 IU/kg/wk sc | weight | 14 | Stopping: if Hb increased >15g/dl in two consecutive weeks drug was stopped until Hb <13 g/dL | as necessary | Hb < 8g/dL or anemia related symptoms | Hb, RBCT, QoL, AE
Dunphy 1999 | 30 | 15 | 15 | unclear, assume Epoetin alfa as partly sponsored by OrthoBiotech | 3 × 150 IU/kg/wk sc | weight | 6 | Increasing: if Hb fell ≥ 1g/dl during first course, Epo increased to 3 × 300, if Hb fell >1g/dl during second course, Epo increased to 3 × 450 | fix | Hb < 8g/dL or cardiovascular symptoms | Hb, RBCT
EPO-CAN-15 | 106 | 53 | 53 | Epoetin alfa | 1 × 40,000 IU/wk sc | fixed | 12–24 | Administered if Hb <14 g/dl, increase to 60,000 if Hb < 14 after 3 wks, stopping: if Hb > 16 stop until Hb < 14, then resume at lower dose | not reported | NR | progression free survival, tumour response, overall survival, local disease progression, Hb
EPO-CAN-20 | 66 | assume 33 | assume 33 | Epoetin alfa | 1 × 40,000 IU/wk sc | fixed | 12 | Initiate if Hb <12 g/dl, if after 4 wks Hb increase < 1 g/dL increase 60,000; if Hb 14 stop until Hb 12 g/dL, resume at 75% | not reported | NR | NR
EPO-GBR-7 | 301 | assume 151 | assume 150 assume | Epoetin alfa | if hb < 12.5 then 3 × 10,000 IU (25% of patients) ;if hb > 12.5 then 3 × 4,000 IU (75% of patients) sc | fixed, dependent on Hb | through the end of radiotherapy, not categorized | Titration: to achieve and maintain Hb 12.5 g/dl to 15 g/dl, initiate at Hb level 15g/dL | not reported | NR | local disease free survival, QoL
GOG-0191 | 113 | 58 | 55 | Epoetin alfa | 1 × 40,000 IU/wk sc | fixed | NR | Titration to maintain >13 g/dl, initiate at Hb level 12 g/dl, stop if Hb > 14 g/dL for 2 weeks or more, reinstate if Hb < 13 g/dL at same dose | not reported | NR | Hb, survival, progression free survival, local tumor control, quality of life
Henke 2003 | 351 | 180 | 171 | Epoetin beta | 3 × 300 IU/kg/wk sc | weight | 7–9, median duration of epo tx: 42.5 days | Stopping: stop if Hb level >14g/dL (women) or 15g/dL (men), or if Hb increase >2g/dL/wk, resumed if Hb fell below target | as necessary | NR | progression free survival, survival, tumour response, Hb, AE
Henry 1995 | 132 | 67 | 65 | Epoetin alfa | 3 × 150 IU/kg/wk sc | weight | 12 | Decreasing: if Hct 38% was reached drug stopped until Hct < 38% | as necessary | at discretion of physician (result: epo Hct 24.7%, control Hct 25.45) | Hb, RBCT, QoL, AE
Henze 2002 | 232 | assume 116 | assume 116 | Epoetin alfa | 1 × 600 or 900 IU/kg/wk (sc (?)) | weight | 20 | NR | NR | NR | transfusion rates, volume of transfusion, Hb change
Huddart 2002 | 90 | assume 45 | assume 45 | Epoetin alfa | 3 × 10,000 IU/wk sc | fixed | given for 4–6 cycles of chemotherapy plus 4 wks, max 28 wks | Increasing to 3 × 20,000 IU/wk depending on response | NR | NR | Hb response, Hb change, transfusion, QoL (FACT An)
Iconomou 2003 | 122 | 61 | 61 | Epoetin alfa | 3 × 10,000 IU/wk sc | fixed | 12 | Increasing: if Hb increase < 1 g/dL dose increased to 3 × 20,000 IU; decreasing: if Hb increased >2g/dL dose reduced by 25% | fix | Hb 7.5 g/dL or discretion of physician | QoL, Hb change, transfusion requirement, outpatients setting
INT-1 | 246 | 80 (150 IU/kg) + 85 (300 IU/kg) | 81 | Epoetin alfa | a: 3 × 150 (n=85); b: 3 × 300 IU/kg (n=80) sc | weight | 1 month post chemotherapy, categorized as unclear | increasing: if reticulocyte after 4 weeks < 40,000 double dose (for 150 arm), stopping: if Hb > 14 g/dL stop until Hb < 12.5 g/dL then restart at 75% | NR | NR | RBCT
INT-3 | 201 | 136 | 65 | Epoetin alfa | 3 × 150– 300 IU/kg sc | weight | 12 | increasing: if reticulocyte after 4 weeks < 40,000 double dose, stopping: if Hb > 14 g/dL (w) or > 16 g/dL (m) stop until Hb < 12 g/dL (w) or 14 g/dL (m) then restart at 75% | NR | MR | RBCT
Janinis 2003 | 372 | assume 186 | assume 186 | Epoetin alfa | 3 × 10,000 IU/wk sc | fixed | NR | NR | fix | NR | QoL, RBCT, tumor response, “clinical benefit ratio”
Kunikane 2001 a, b | 72 | assume 48 | assume 24 | Epoetin beta | a: 3 × 100 IU/kg/wk, b:3 × 200 IU/kg/wk sc | weight | 6 | stopping: if Hb >16 g/L (men) or >14 g/dL (women) drug was stopped | not reported | NR | Hb, pts RBCT,
Kurz 1997 | 35 | 23 | 12 | Epoetin alfa | 3 × 150 IU/kg/wk sc | weight | 12 | increasing: if Hb increase < 1 g/dL after 4 weeks dose increased to 3 × 300 IU | as necessary (for non- responder s), before categorize d as fix | Hb < 8 g/dL or clinical symptoms | Hb, RBCT
Leyland-Jones 2003 | 939 | 469 | 470 | Epoetin alfa | 1× 40,000 IU/wk sc | fixed | median duration 52 weeks | increasing: if Hb increase <10.5 g/dL after 4 wks drug increased to 60,000 IU/wk, decreasing: if Hb level >14 g/dL or increase > 2 g/dL drug withheld | NR | NR | Survival, QoL, hematological effects, transfusions, time to progression, AE
Littlewood 2001 | 375 | 251 | 124 | Epoetin alfa | 3 × 150 IU/kg/wk sc | weight | 28 | stopping: if Hb level increased to >15 g/dL drug was stopped and restarted if Hb 12 g/dL | as necessary | Hb < 8 g/dL or clinical symptoms | Hb, RBCT, QoL, AE, after protocol amendment also survival
Machtay 2004 | 148 | assume 74 | assume 74 | Epoetin alfa | 1× 40,000 IU/wk sc | fixed | 9–10, categorized as 6–9 | decreasing: if Hb ≥ 16 g/dL (men) or >14 g/dL (women) drug stopped, if Hb <13.5 g/dL (men) or <12.5 d/dL (women) dosing resumed at a dose reduction of 30,000 IU | not reported | NR | 1 year local progression free survival, survival, Hb, toxicity, patterns of failure
N93-004 | 224 | 109 | 115 | Epoetin alfa | 3 × 150 IU/kg/wk sc | weight | 12 (assumed as drug given during 3 × 3 wks chemo plus 3 wks) | decreasing: dose withheld if Hb >16 g/dL and restarted at 50% if Hb <14 g/dL | not reported | NR | Tumour response, overall survival, Hb, transfusion rate
Oberhoff 1998 | 218 | 114 | 104 | Epoetin beta | 7 × 5,000IU/wk sc | fixed | 12 | not reported | as necessary | discretion of physician | Hb, RBCT, AE
O’Shaughnessy 2005 | 100 | 51 | 49 | Epoetin alfa | 1 × 40,000 IU/wk sc | fixed | 12 | Increasing, decreasing: If Hb increased < 1 g/dl (for baseline Hb 9–12 g/dL) OR < 2 (for baseline Hb 12–14) within 4 wks, drug increased to 60,000 IU; decreasing: If Hb > 15 g/dl drug stopped and reinstated at 85% if Hb < 13g/dl. If Hb increased > 1.3 g/dl in 2 wks dose reduction at physician’s discretion. | as necessary | if Hb < 8 g/dL and patient received RBC excluded from study | cognitive function, QoL
Osterborg 1996 a,b | 144 | 95 | 49 | Epoetin beta | a: 7 × 10,000 IU/wk sc, b: titration | fixed, titration | 24 | increasing: if no signs of response within 4 weeks, dose increased to 300; decreasing: if Hb increase >2 g/dL per 4 weeks dose reduced by 50%. If Hb level >14 g/dL study drug was stopped, if Hb level <13 g/dL reinstated at 50% | not reported | Hb < 10 g/dL | Hb, RBCT, AE
Osterborg 2002, Osterborg 2005 | 349 | 173 | 176 | Epoetin beta | 3 × 150 IU/kg/wk sc | weight | 16 | increasing: if no signs of response within 4 weeks, dose increased to 300; decreasing: if Hb increase >2 g/dL per 4 weeks dose reduced by 50%. If Hb level >14 g/dL study drug was stopped, if Hb level <13 g/dL reinstated at 50% | as necessary | Hb < 8.5 g/dL or medically indicated | Hb, RBCT, AE
P-174 | 45 | assume 33 | assume 12 | Epoetin alfa | 3 × 150 IU/kg/wk sc | weight | 12 | epoetin alfa dose titrated to maintain Hct between 38%–40% | not reported | | Hb
Quirt 1996 | 56 | assume 28 | assume 28 | Epoetin alfa | 3 × 150 IU/kg/wk sc | weight | 16 | increasing: if Hb increase <1 g/dL within 4 wks drug increased to 300 IU/kg | not reported | NR | Hb, RBCT, QoL
Razzouk 2004 | 224 | 113 | 111 | Epoetin alfa | 1 × 600 IU/kg/wk U IV | weight | 16 | increasing: if Hb increase <1 g/dL within 4 wks drug increased to 900 IU/kg, maximal 60,000 IU iv qw; decreasing: if Hb > 15 g/dL drug withheld, restarted if Hb < 13 g/dL with 25% dose reduction | as necessary | NR | Hb, QoL
Rose 1994 | 221 | 142 | 79 | Epoetin alfa | 3 × 150 IU/kg/wk sc | weight | 12 | epoetin alfa dose titrated to maintain Hct between 38%–40% | as necessary | NR | HR, RBCT, QoL
Rosenzweig 2004 | 27 | 14 | 13 | Epoetin alfa | 1 × 40,000 IU/wk sc | fixed | 12 | Increasing: if Hb increased <1 g/dL after 4 weeks, drug increased to 1 × 60,000 IU/wk, if Hb increase < 1 g/dL after 8 weeks, drug discontinued | NR | at discretion of physician | fatigue, QoL
Savonije 2004 | 315 | 211 | 104 | Epoetin alfa | 3 × 10,000 IU/wk sc | fixed | 14 | Increasing: if Hb increase <1 g/dL after 4 wks drug increased to 20,000 IU tiw; decreasing: if Hb > 14 g/dL drug withheld until Hb < 13 g/dL, resumed at 10,000 IU twice weekly | not reported | NR | Hb, transfusion requirements, QoL
Silvestris 1995 | 54 | 30 | 24 | Epoetin alfa | 3 × 150 IU/kg/wk sc | weight | 24 | Increasing: dose was increased after the 6th week of treatment | fix | NR | Hb, AE
Ten Bokkel 1998 a, b | 122 | 88 | 34 | Epoetin beta | a: 3 × 150 IU/kg/wk, b: 3 × 300 IU/kg/wk sc | weight | through duration of chemotherapy plus 3–24, categorized as more than 20 weeks | Decreasing: if Hb increased ≥2 g/dL dose was reduced by 50%. If Hb level >15g/dl drug stopped until Hb <14g/dl | as necessary | usually if Hb < 9.7 g/dl | RBCT, transfusion, AE
Thatcher 1999 a, b | 130 | 86 | 44 | Epoetin alfa | a: 3 × 150 IU/kg/wk, b: 3 × 300 IU/kg/wk sc | weight | 26 | Decreasing: if Hb exceeded 15 g/dl drug stopped and restarted with 50% if Hb <13 g/dL | as necessary | Hb ≤ 10 g/dL | Hb, RBCT, QoL, AE
Thomas 2002 | 130 | 65 | 65 | Epoetin alfa | 3 × 10,000 IU/wk sc | fixed | not clearly reported, outcomes assessed at 12 weeks | NR | not reported | at discretion of physician | Hb, QoL, RBCT
Throuvalas 2000 | 55 | assume 28 | assume 27 | unclear, Epoetin alfa or beta | 5 × 10,000 IU sc | fixed | during chemotherapy, 5–6 weeks | NR | as necessary | Hb < 9.0 g/dl | Hb, RBCT
Vadhan-Raj 2004 | 60 | 29 | 31 | Epoetin alfa | 1 × 40,000 IU/wk sc | fixed | 16 wks or up to 4 wks post surgery, categorized as 16 weeks | Increasing: if Hb level ≤13 g/dL after 4 wks increase to 60,000 IU/wk; decreasing: if Hb level ≥15 g/dL withheld and resumed if Hb ≤14 g/dl at 50% dose. | not reported | NR | Hb response, transfusions, local tumour response, pathological post-surgery response, QoL, safety
Welch 1995 | 30 | 15 | 15 | Epoetin alfa | 3 × 300 IU/kg/wk sc | weight | 24 | Decreasing: if Hb > 15 g/dl drug stopped until Hb between 12 –14 g/dl, drug reinstated at 50% dose reduction | as necessary | discretion of physician | Hb, RBCT, AE
Witzig 2005 | 344 | 174 | 170 | Epoetin alfa | 1 × 40,000 IU/wk sc | fixed | 16 | Increasing: if Hb increase < 1 g/dL after 4 weeks dose increased to 60,000 IU; if Hb level >15g/dL for two weeks, drug stopped and restarted with 75% when Hb <13 g/dl | fix | at discretion of physician | QoL, transfusions, Hb change
Wurnig 1996 | 30 | 16 | 14 | Epoetin alfa | 2 × 600 IU/kg/wk IV | weight | 20 | Maintaining: epo was started if Hb <11 g/dl and discontinued if Hb >13.5 g/dl | no | Hb level 8.5 g/dL | Hb, RBCT, AE

Table C3

KQ1: Epoetin versus Control, Study Characteristics, Part II

study author | n randomized | cancer details | cancer category | therapy | Hb eligibility criteria | Hb base- line EPO arm [mean g/dl (SD)] | Control arm mean baseline HB (SD) | Hb category | AGE; EPO arm, as reported (mean, SD) range if not reported otherwise | AGE; control arm, as reported (mean or median, SD), range | age category (children, adults, elderly (>65)
Aravantinos 2003 | 47 | ovarian, lung, stomach, other | solid | Platinum based chemotherapy | Hb <10.5 g/dL | 9.8 (+/−0.5) | 9.32 (+/−0.8) | 10 | 59 (18–76) | 64 (23–75) | adults
Bamias 2003 | 144 | ovarian, NSCLC, SCLC, other | solid | Platinum based chemotherapy | Hb <13 g/dL | 11.5 (range 11.1, 11.9) | 11.5 (range 11.2, 11.8) | 10–12 | 60 (18–77) | 62 (19–80) | adults
Boogaerts 2003, Coiffier 2001 | 262 | MM, NHL, CLL, Ovarian, bone, GI, respir, other | mixed | Chemotherapy, platinum & non platinum, details not reported but interpreted as such as some solid cancers which are usually treated with platinum are included | Hb ≤ 11 g/dl | 9.0 (range 5–13) | 9.2 (range 5–12) | 10 | 62 (24–68) | 62 (24–85) | adults
Carabantes 1999 | 35 | SCLC, ovarian | solid | Platinum based chemotherapy | Hb ≤ 11.5 g/dl | 10.5 (+/−0.8) | 10.5 (+/−0.8) | 10–12 | NR | NR | adults
Cascinu 1994 | 100 | stomach, ovarian, melanoma, head neck, lung, breast | solid | Platinum based chemotherapy, some, additional radiotherapy, categorized as chemo-platinum all | Hb ≤9 g/dl | 8.63 (+/−0.62) | 8.73 (+/−0.52) | 10 | median 58 (44–72) | median 57 (45–68) | adults
Case 1993 | 157 | solid and hemato-logical tumors | mixed | Chemotherapy without platinum | Hb ≤ 10.5 g/dl | 9.29 (SD 1.14) | 9.57 (SD 1.04) | 10 | 64 (27–92) | 64 (30–88) | adults
Cazzola 1995 c | 146 | MM, NHL | hemato- logical | Chemotherapy without platinum, some (22%) patients did not receive chemotherapy, categorized as platinum free chemotherapy | Hb ≤ 11 g/dl INDEPENDENT OF TRANSFUSION | c: 9.4 (SD 1.9); d: 9.4 (SD 1.0) | 9.5 (SD 1.1) | 10 | c: median 31 (42–85); d: median 63 (28–80) | median 68 (28–82) | adults
Chang 2005 | 354 | Breast cancer, stage I–IV | solid | Chemotherapy without platinum | Hb <12g/dL | 11.2 (SD 0.9) | 11.3 (SD 0.8) | 10–12 | 50.4 (SD 11.1, R 27–78) | 50.1 (SD 10, R 31–85) | adults
Dammacco 2001 | 145 | MM, NHL | hemato- logical | Chemotherapy, platinum & non platinum | Hb ≤ 10 g/dl | 8.67 (SD 0.9) | 8.34 (SD 1.4) | 10 | 60.6 (SD 8.3), range 39–74 | 65 (SD 8.8), range 47–85 | adults
Del Mastro 1997 | 62 | breast, stage II | solid | Chemotherapy without platinum | Hb ≥12g/dL | 13.00 (0.7) | 13.1 (0.6) | 12 | median 54 (31–66) | median 56 (29–68) | adults
Dunphy 1999 | 30 | head neck, SCLC, stage III/IV | solid | Platinum based chemotherapy | NR | 14.1 (2.1) | 14.1 (1.6) | 12 | median 59 (42–76) | median 67 (32–82) | adults
EPO-CAN-15 | 106 | limited disease SCLC | solid | Platinum based chemotherapy plus radiotherapy, categorized as chemo_radio | NR | NR | NR | NR (no assumption possible) | NR | NR | adults
EPO-CAN-20 | 66 | advanced SCLC | solid | Radiotherapy +/− non platinum based chemotherapy, categorized as chemo-radiotherapy only | Hb ≤ 12 g/dl | NR | NR | NR (no assumption possible) | NR | NR | adults
EPO-GBR-7 | 301 | head and neck, stage I’–IV | solid | Radiotherapy | Hb ≤ 15 g/dl | 13.4 (SD 1.2) | 13.5 (SD 1.3) | 12 | 59.8 (SD 10.8) | 60.2 (SD 10.6) | adults
GOG-0191 | 113 | cervix carcinoma | solid | Platinum based chemotherapy plus radiotherapy, categorized as chemo_radio | Hb ≤ 14 g/dl | NR | NR | NR (no assumption possible) | NR | NR | adults
Henke 2003 | 351 | advanced (stage III, IV) head and neck | solid | Radiotherapy after surgical resection, 22% (78/351) of patients radiotherapy only | <13 g/dL (men), <12 g/dL (women) | median 11.7 (8.5 –14.4) | median 11.8 (6.9 – 14.6) | 10–12 | median 58 (25–81) | median 57 (36–87) | adults
Henry 1995 | 132 | solid and hematological tumors | mixed | Platinum based chemotherapy | Hb ≤ 10.5 g/dl | 9.68 (SD 1.28) | 9.27 (SD 1.49) | 10 | 60 (20–84) | 60 (34–83)* | adults
Henze 2002 | 232 | ALL (37%) and non-ALL malignancies | mixed | Chemotherapy, some non-ALL patients underwent also surgery, categorized as unclear | NR | NR | NR | NR (no assumption possible) | NR | NR | children
Huddart 2002 | 90 | solid tumours, no details given | solid | Platinum based chemotherapy | Hb <10.5 g/dL | NR | NR | NR (no assumption possible) | NR | NR | adults
Iconomou 2003 | 122 | lung, breast, colorectal, ovarian, unknown primary, kidney, stomach, other | solid | Chemotherapy, platinum & non platinum (51/122 (42%) received platinum) | Hb ≤ 11.0g/dL | 10.1 (+/−SD 0.6) | 10.1 (+/−SD 0.4) | 10–12 | 60.6 (SD 10.7), range 33 – 85 | 62.6 (SD 10.3), range 34–80 | adults
INT-1 | 246 | ovarian | solid | Platinum-based chemotherapy | Hb ≤ 11 g/dl | NR | NR | NR (no assumption possible) | NR | NR | adults
INT-3 | 201 | mixed | mixed | Chemotherapy unclear | Hb ≤ 12 g/dl | NR | NR | NR (no assumption possible) | NR | NR | adults
Janinis 2003 | 372 | solid and hematological malignancies | mixed | Chemotherapy, platinum & non platinum (129/372 (35%) received platinum) | Hb ≤ 11.0 g/dL | median 10.5 | median 10.5 | 10–12 | NR | NR | adults
Kunikane 2001 a, b | 72 | SCLC | solid | Platinum based chemotherapy | Hb 9–13 g/dl | a: 12.3 (SD 1.2), b: 12.3 (SD 1.4) | 12.0 (SD 0.9) | 12 | a: 62.7 (SD 8.7), b: 62.7 (SD 4.8) | 59.5 (SD 9.9) | adults
Kurz 1997 | 35 | solid tumours; ovarian, uterus, cervix | solid | Platinum based chemotherapy, 6/35 (17%) did not receive platinum, categorized as platinum | Hb ≤ 11 g/dl | 9.88 (SD 0.8) | 9.85 (SD 0.6) | 10 | 54.4 (SD 9.7) | 52.7 (SD 7.5) | adults
Leyland-Jones 2003 | 939 | metastatic breast cancer | solid | Chemotherapy without platinum | Hb 13 g/dL, no upper of lower limit on Hb for inclusion | median 12.8 | median 12.8 | 12 | 55.8 (SD 11.13) | 55.1 (SD 10.49) | adults
Littlewood 2001 | 375 | NHL, MM, breast, HD, CLL, GI, other | mixed | Chemotherapy without platinum | Hb ≤10.5 g/dl OR 10.5–12 AND decrease of ≥1.5 g/dL per cycle | 9.9 (SD 1.13) | 9.7 (SD 1.13) | 10 | 58.3 (SD 14.8), range 18.7–84.9 | 59.5 (SD 13.9), range 21.1–88.6 | adults
Machtay 2004 | 148 | head and neck non-metastatic, not resected | solid | Radiotherapy, advanced stages received in addition platinum based chemotherapy, categorized as radiotherapy | Hb 9–13.5 g/dL (men), 9–12.5 g/dL (women) | 12.0 | 12.2 | 12 | NR | NR | adults
N93-004 | 224 | SCLC, limited and extended disease | solid | Platinum based chemotherapy | Hb ≤ 14 g/dl | NR | NR | NR (no assumption possible) | NR | NR | adults
Oberhoff 1998 | 218 | solid tumours; ovarian, breast, lung, GU, GI, other | solid | Chemotherapy, platinum & non platinum | Hb ≤ 11 g/dl OR ≤ 13 g/dl AND decrease of ≥1.5 g/dL per CT cycle | median 9.6 | median 10.3 | 10 | 52, range 20–85 | 57, range 19–73 | adults
O’Shaughnessy 2005 | 100 | breast cancer, stages I-IIIB | solid | Chemotherapy without platinum | Hb 9–14 g/dl | 12.8 (SD 1.0) | 13.0 (SD 1.0) | 12 | 53.3 (SD 9.7) | 54.3 (SD 12.0) | adults
Osterborg 1996 a,b | 144 | MM, NHL, CLL | hematological | Chemotherapy without platinum, 6/59 (10%) did not receive chemotherapy, study categorized as chemotherapy non platinum category | Hb ≤ 10 g/dl | a: median 8.0 (range 6.2–10.1), b: median 8.0 (range 5.5–10.3) | median 8.1 (range 5.2–9.8) | 10 | a: 66(43–84), b: 65 (38–82) | 64 (36–83) | adults
Osterborg 2002, Osterborg 2005 | 349 | MM, NHL, CLL | hematological | Chemotherapy without platinum | Hb ≤ 10 g/dl | 9.2 (SD 1.1) | 9.3 (SD 1.0) | 10 | 63 (32–86) | 64 (28–83) | adults
P-174 | 45 | CLL | hematological | Chemotherapy (NR, but for some patients reported in Pangalis 1995), categorized as ‘unclear’ | Hct < 32% | NR | NR | NR (no assumption possible) | NR | | adults
Quirt 1996 | 56 | lymphoma, solid tumours | mixed | Chemotherapy, unclear if platinum included or not, categorized as ‘unclear’ OK | Hb drop of 1.5 g/dL | 10.9 | 10.7 | 10–12 | NR | NR | adults
Razzouk 2004 | 224 | solid tumours, Hodgkin’s disease, non-Hodgkin’s disease, ALL | mixed | Chemotherapy ’unclear’ | Hb ≤ 12 g/dl | 9.8 (SD 1.3) | 9.5 (SD 1.0) | 10 | 12.4 (SD 3.6) | 10.8 (SD 4.0) | children
Rose 1994 | 221 | CLL, stage III, IV | hematological | Chemotherapy (only 162/221 (73%) received CT), categorized as chemotherapy without platinum | Hct ≤ 32% | 9.1 (1.3) | 9.3 (1.2) | 10 | 68.3 (SD 10) | 68.1 (9.3) | adults
Rosenzweig 2004 | 27 | metastatic breast cancer | solid | Chemotherapy, 14/27 (52%) did not receive chemotherapy, categorized as ‘unclear’ | Hb <12g/dL | NR | NR | NR (no assumption possible) | 55.9 (+/−11.7) | 53.9 (+/− 14.2) | adults
Savonije 2004 | 315 | solid tumors | solid | Platinum based chemotherapy | Hb <12.1 g/dL | 10.7 (SD 1.0) | 10.8 (SD 1.0) | 10–12 | 56.9 (SD 10.9) | 57.7 (SD 9.5) | adults
Silvestris 1995 | 54 | MM | hematological | Chemotherapy | Hb 8 ≤ g/dl | NR | NR | NR (no assumption possible) | NR | adults | adults
Ten Bokkel 1998 a, b | 122 | ovarian (stage II-IV) | solid | Platinum based chemotherapy | Hb ≤ 13 g/dl | a: 12.0 (1.3–12.6, SD 0.88), b:11.6 (10.5–12.2, SD 1.34) | 11.8 (10.6–12.5, SD 1.19) | 10–12 | a: 58.81, b: 60.97 | 58.83 | adults
Thatcher 1999 a, b | 130 | SCLC | solid | Platinum based chemotherapy (89% of patients) | Hb ≥ 10.5 g/dl | a: 13.4 (SD 1.3), b: 13.5 (SD 1.3) | 13.4 (SD 1.3) | 12 | a: 59 (43–72), b: 58.5 (30–72) | 60 (39–74) | adults
Thomas 2002 | 130 | NR | unclear | Chemotherapy, categorized as ‘unclear’ | (Hb inclusion criteria level: < 12g/dL) | 10.59 (SD 1.05) | 10.59 (SD 1.05) | 10–12 | NR | NR | adults
Throuvalas 2000 | 55 | cervix and bladder carcinoma | solid | Platinum based chemotherapy plus radiotherapy, categorized as chemo_radio therapy | Hb 10–13 g/dl | 11.5 (SD 0.6) | 11.1 (0.5) | 10–12 | 54 (36–75) | 58 (35–75) | adults
Vadhan-Raj 2004 | 60 | gastric or rectal ca | solid | combined chemo-radio therapy without platinum, categorized as chemo_radio | Hb 10–15 g/dl | median 13 | median 13 | 12 | NR | NR | adults
Welch 1995 | 30 | ovarian, stage II-IV | solid | Platinum based chemotherapy | normal Hb | 13 | 12.8 | 12 | NR | NR | adults
Witzig 2005 | 344 | lung, breast, other | solid | Chemotherapy, platinum & non platinum, some radiotherapy, 56/330 (175) received platinum | Hb ≤ 11.5 g/dl (men), Hb ≤ 10.5 g/dl (women) | 9.5, range 6.0–11.4 | 9.4, range 6.9–11.4 | 10 | 63.6 (SD 11.89), range 20–88 | 63.7 (SD 13.00), range 24–86 | adults
Wurnig 1996 | 30 | various malignant one tumours | solid | Chemotherapy, platinum & non platinum, 21/35 (60%) received platinum | Hb 11 g/dl | 11.0 (SD 1.5) | 10.5 (SD 0.75) | 10–12 | NR | NR | adults

Table C4

KQ1: Darbepoetin versus Control, Study Characteristics, Part I

study author | n randomized | n randomized in experimental arm | n randomized in control arm | drug | dose | weight based or fix | duration of study drug medication (weeks) | dose adjustment | iron | transfusion trigger | primary and secondary outcomes of the study
Hedenus 2002 a,b,c | 66 | all 55, a: 11, b:22, c:22 | 11 | Darb-epoetin alfa | a: 1.0, b: 2.25, c: 4.0 μg/kg qw sc | weight | 12 | Decreasing: if Hb increase >2 g/dL in 4 wks drug reduced by 50%, if Hb level >15 g/dL (men) or 14 g/dL (women) drug stopped and reinstated at 50% if Hb <13 g/dL | as necessary | Hb <8g/dL | dose response relationship Hb response, Hb change, transfusion
Hedenus 2003 | 349 | 176 | 173 | Darb-epoetin alfa | 2.25 μg/kg/ qw sc | weight | 12 | Increasing: if Hb increase <1.0 g/dL within 4 wks of treatment dose was doubled. Decreasing: if Hb increase >15 g/dL (men) or >14g/dL (women) drug stopped until Hb <13 g/dL and reinstated at 50% | as necessary | Hb <8g/dL or discretion of physician | Hb response, transfusion, Hb change, QoL
Kotasek 2003 a,b,c,d,e,f | 259 | 208 | 51 | Darb-epoetin alfa | a: 4.5 μg/kg Q3W, b:6.75 μg/kg Q3W, c: 9 μg/kg Q3W, d:12 μg/kg Q3W, e:13.5 μg/kg Q3W, f:15 μg/kg Q3W sc | weight | 12 | Increasing not allowed, decreasing: if Hb increased >15 g/dL (men) or >14 g/dl (women) drug stopped and reinstated at a lower dose level if Hb <13 g/dL | NR | NR | Safety, antibodies, Hb response, Hb change, transfusions, QoL
Vanstee nkiste 2002 | 320 | 159 | 161 | Darb-epoetin alfa | 2.25 mcg/kg qw sc | weight | 12 | Increasing: if Hb increase < 1 g/dL within 6 wks dose doubled to 4.5 μg/kg/wk. Decreasing: If Hb >15 g/dl (men) or >14 g/dl (women) drug stopped, reinstated at 50% if Hb <13 g/dl | NR | Hb < 8g/dL or at discretion of physician | transfusion, number of RBCTs, Hb response, AE, overall survival, progression free survival, QoL, hospitalization

Table C5

KQ1: Darbepoetin versus Control, Study Characteristics, Part II

study author | n randomized | cancer details | cancer category | therapy | Hb eligibility criteria | Hb baseline EPO arm [mean g/dl (SD)] | Control arm mean baseline HB (SD) | hb category | AGE; darbepo arm, as reported (mean, SD) range if not reported otherwise | AGE; control arm, as reported (mean or median, SD), range | age category (children, adults, elderly (>65)
Hedenus 2002 a,b,c | 66 | lymphoma, HD, NHL, CLL, MM | hematological | Chemotherapy without platinum | Hb ≤ 11.0 g/dL | a: 9.7 (SD 0.8), b: 9.4 (SD 1.3), c: 9.7 (SD 0.9) | 9.5 (SD 2.0) | 10 | a: median 64 (26 to 80), b: median 69 (20 to 84), c: median 70 (52- | median 63 (25–80) | adults
Hedenus 2003 | 349 | lymphoma: HD, NHL, MM | hematological | NR, assumed to be chemotherapy without platinum | Hb ≤ 11.0 g/dL | 9.59 (SD 1.22) | 9.5 (SD 1.21) | 10 | 64.8 (SD 13.8) | 64.6 (SD 12.2) | adults
Kotasek 2003 a,b,c,d,e,f | 259 | breast, gyne, gastrointestinal, lung, other | solid | Chemotherapy, not reported if with or without platinum, interpreted as some patients receiving platinum as some of solid cancers included are usually treated with platinum | Hb ≤ 11.0 g/dL | 9.93 (SD 1.0) | 9.87 (SD 1.12) | 10 | 58.3 (SD 11.9) | 56.2 (SD 12.4) | adults
Vansteenkiste 2002 | 320 | SCLC, and non-SCLC | solid | Platinum based chemotherapy | Hb ≤ 11.0 g/dL | 10.28 (SD 1.08) | 9.93 (SD 1.01) | 10–12 | 61.6 (SD 9.2) | 61.3 (SD 8.8) | adults

Table C6

KQ1: Darbepoetin versus Epoetin, Study Characteristics, Part I

study author | # randomized | design | drug | Darbepoetin dose per week | Epoetin dose per week | weight based or fix | duration of medication(weeks) | Dose adjustment Darbepoetin | Dose adjustment Epoetin | iron | transfusion trigger | primary and secondary outcomes of the study
Alexopoulos 2004 | 50 | compare effectiveness, RCT | Darbepoetin versus epoetin alfa | 1 × 150 μg qw | 10,000 IU tiw | darb fixed, epo fixed | 12 | Increasing: if Hb increase < 1.5 g/dL at 4 wks drug increased to 300 μg qw | Increasing: if Hb increase < 1.5 g/dL at 4 wks drug increased to 20,000 IU tiw | NR | NR | Hb, RBCT,
Glaspy 2002, Part A | 269 | sequential dose finding study | Darbepoetin versus epoetin alfa | a: 0.5; b: 1.0; c: 1.5; d: 2.25; e: 4.5; f: 6.0 and g: 8.0 μg/kg qw | 150 IU/kg tiw | darb weight based, epo weight based | 12 | no dose adjustment | Increasing: if Hb increase < 1.0 g/dL at wk 8 EPO increased to 300 IU/kg tiw | NR | NR | safety, Hb, RBCT, QoL
Glaspy 2002, Part B | 160 | parallel dose finding study | Darbepoetin versus epoetin alfa | a: 3.0; b: 5.0; c: 7.0 and d: 9.0 μg/kg q2w | 40,000 IU qw | darb weight based, epo fixed | 12 | no dose adjustment | Increasing: if Hb increase < 1.0 g/dL at wk 6 EPO increased to 60,000 IU qw | NR | NR | safety, Hb, RBCT, QoL
Glaspy 2003 a–c | 127 | pilot front loading study | Darbepoetin versus epoetin alfa | a: 4 × 4.5 μg/kg qw until Hb ≤ 12 g/d/L, then 1.5 μg/kg qw up to wk 12; b: 4 × 4.5 μg/kg qw, then 8 × 2.25 μg/dL; c: 4 × 4.5 μg/kg qw, then 8 × 3 μg/dL qw | 40,000 IU qw | darb weight based, epo fixed | 12 | drug was withheld if Hb level > 15.0 g/dL (men) or 14 g/dL (women), if Hb ≤ 13 g/dL drug reinstated at 75%; no other dose adjustment | Increasing: if Hb increase < 1.0 g/dL at wk 6 EPO increased to 60,000 IU qw; decreasing: drug was withheld if Hb level > 15.0 g/dL (men) or 14 g/dL (women), if Hb ≤ 13 g/dL drug reinstated at 75% | NR | Hb ≤ 8 g/dL or as medically indicated | Hb, time to response, safety, QoL
Glaspy 2005 * | 1220 | phase 3, non-inferiority trial | Darbepoetin versus epoetin alfa | 1 × 200 μg q2w | 40,000 IU qw | darb fixed, epo fixed | 12 or 16 | remain at randomized dose OR dose may be increased to 300 μg q2w | remain at randomized dose OR dose may be increased to 60,000 IU qw | NR | NR | RBCT, safety, Hb response, change, QoL
Schwartzberg 2004, a–c | 318 | to validate patient questionnaire | Darbepoetin versus epoetin alfa | 200 mg q2w | 40,000 IU qw | darb fixed, epo fixed | 16 | Increasing: if Hb increase ≤ 1.0 g/dL at wk 4 Darb increased to 300μg q2w; Stopping: drug was withheld if Hb level > 13.0 g/dL and reinstated at the previous dose if Hb ≤ 13 g/dL. | Increasing: if Hb increase ≤ 1.0 g/dL at wk 4 EPO increased to 60,000 IU qw; Stopping: drug was withheld if Hb level > 13.0 g/dL and reinstated at the previous dose if Hb ≤ 13 g/dL. | NR | NR | validate patient satisfaction questionnaire, efficacy (Hb, Hct, RBCT), safety
Waltzman 2005 | 358 | effectiveness study to compare Hb response rates | Darbepoetin versus epoetin alfa | 200 mg q2w | 40,000 IU qw | darb fixed, epo fixed | 12 to 16 | Increasing: if Hb increase < 1.0 g/dL at wk 6 Darb increased to 300μg q2w; Decreasing: if Hb rise > 1.0 g/dL in 2 wks dose decreased by 25%; Stopping: drug was withheld if Hb level > 13.0 g/dL resumed at 25% dose reduction when Hb < 12 g/dL. | Increasing: if Hb increase < 1.0 g/dL at wk 4 EPO increased to 60,000 IU qw; Decreasing: if Hb rise > 1.0 g/dL in 2 wks dose decreased by 25%; Stopping: drug was withheld if Hb level > 13.0 g/dL, resumed at 25% dose reduction when Hb < 12 g/dL. | NR | NR | Hb response, RBCTs, change, QoL

* study was amended from 12 to 16 weeks to allow dose titrations to occur by physician discretion, to increase sample size, to modify secondary Hb efficacy endpoint

Table C7

KQ1: Darbepoetin versus Epoetin, Study Characteristics, Part II

study author | n randomized | cancer details | cancer category | therapy | Hb eligibility criteria | Hb baseline Darb arm [mean g/dl (SD)] | Hb baseline EPO arm [mean g/dl (SD)] | Hb category | Age Darb arm [mean (SD)] if not stated otherwise | Age EPO arm [mean (SD)] if not stated otherwise | age category (children, adults, elderly (>65)
Alexopoulos 2004 | 50 | non- hematolo gical tumors | solid | NR | Hb ≤11 g/dL OR Hb decrease ≥ 1.5 g/dL during CT | 10.2 (+/−0.87) | 9.81 (+/− 1.02) | 10 | NR | NR | adults
Glaspy 2002, Part A | 269 | Breast, GI, lung, other | solid | chemotherapy | Hb ≤11 g/dL | 9.91 (SD 0.94) | 10.02 (SD 0.88) | 10–12 | 61.9 (SD 11.9) | 57.8 (SD 14.5) | adults
Glaspy 2002, Part B | 160 | breast, GI, lung, other | solid | chemotherapy | Hb ≤11 g/dL | 9.82 (SD 0.95) | 9.73 (SD 1.17) | 10 | 64.3 (SD 12.0) | 63.9 (SD 12.3) | adults
Glaspy 2003 a–c | 127 | breast, lung, GI, gyne, GU, other cancers | solid | chemotherapy | Hb ≤11 g/dL | a: 9.54 (SD 1.12); b: 9.90 (SD 1.02); c: 9.90 (SD 0.99) | 9.84 (SD 0.83) | 10 | a: 60.5 (SD 14.1); b: 66.4 (SD 12.7); c: 62.7 (SD 13.2) | 63.5 (SD 8.7) | adults
Glaspy 2005 | 1220 | lung, breast, GI, gyne, lymphopr oliferative (7.5%), other cancers | solid or mixed | some (42%) platinum based chemotherapy | Hb ≤11 g/dL | 10.18 (SD 0.90) | 10.21 (SD 0.89) | 10–12 | 63.2 (SD 12.4) | 63.7 (SD 11.6) | adults
Schwartzberg 2004, a–c | 318 | a: breast cancer, b: lung cancer (stage IIIb, IV), c: gynecolog ical cancers | solid | chemotherapy, some platinum (41%) | Hb ≤ 11 g/dL | 10.4 (SD 0.8) | 10.4 (SD | 10–12 | 58.7 (SD | 61.7 (SD | adults
Waltzman 2005 | 358 | lung, breast, other | solid | chemotherapy, some platinum (40.5%) | Hb ≤ 11 g/dL | 10.02 (SD 0.84) | 10.14 (SD 0.75) | 10–12 | 63.4 (SD 11.8) | 62.1 (SD 11.8) | adults

Table C8

KQ1: Epoetin versus Control, Study Quality

study author | random | allocation | blinding | placebo | ITT or 10% | similar | high or low quality | publication
Aravantinos 2003 | unclear | unclear | no | no placebo | yes | yes | low | full text publication
Bamias 2003 | unclear | unclear | no | no placebo | yes, exception TR, QoL | control group had statistically significant lower EPO levels at baseline (EPO: 24,8 (16.6–37), control: 12.5 (8.7–18), mU/ml, geometric mean, p=0.012) | low | full text publication
Boogaerts 2003, Coiffier 2001 | yes | yes | no | no placebo | yes | more patients in control (80%) had CT before study compared to EPO (68%), p=0.025 | low | full text publication, abstract publication, unpublished data, FDA documents
Carabantes 1999 | unclear | unclear | no | no placebo | yes, exception QoL | yes | low | abstract
Cascinu 1994 | yes | yes, sealed envelopes | double | Placebo | yes | yes | high | full text publication, unpublished data
Case 1993 | yes | yes | double | Placebo | yes | yes, no details for cancer stage available | high | full text publication, unpublished data, FDA documents
Cazzola 1995 c | yes | unclear | no | no placebo | yes | yes | low | full text publication, unpublished data, FDA documents
Chang 2005 | unclear | unclear | no | no placebo | yes | patients with metastatic disease appear to have lower baseline Hb at entry and significantly higher level of serum ferritin, more cycles of chemotherapy were given in the epo arm (mean 5.0 vs 4.6, p=0.058) | low | full text publication
Dammacco 2001 | yes | unclear | double | Placebo | yes, exception: Hb response | yes | high, low for Hb response | full text publication, unpublished data, FDA documents
Del Mastro 1997 | yes | yes | no | no placebo | yes | yes | low | full text publication, unpublished data
Dunphy 1999 | unclear | unclear | no | no placebo | yes | gender was not distributed equally, more male patients in EPO arm (80% vs 47%, p0.003) | low | full text publication
EPO-CAN-15 | unclear | unclear | double | Placebo | yes | unclear | high | FDA documents
EPO-CAN-20 | unclear | unclear | double | Placebo | yes | unclear | high | FDA documents
EPO-GBR-7 | unclear | unclear | no | no placebo | yes, not TVE and TR | more subjects in the EPO arm had tumour stage IV (39% vs 36%) | low | FDA documents
GOG-0191 | unclear | unclear | no | no placebo | yes | unclear | low | FDA documents
Henke 2003 | unclear | unclear | double | Placebo | yes | more smokers (66% vs 53%) in the EPO group; more stage IV patients in the EPO hypopharynx subgroup (85% vs 70%) | high | full text publication, FDA documents
Henry 1995 | yes | yes | double | Placebo | yes | yes, no details for cancer stage available | high | full text publication, unpublished data, FDA documents
Henze 2002 | unclear | unclear | no | no placebo | unclear | unclear, non-ALL patients underwent surgery, this might have biased the transfusion outcome | low | abstract
Huddart 2002 | unclear | unclear | no | no placebo | unclear | unclear | low | abstract
Iconomou 2003 | yes (was performed by a telephone call to the registry of the department of medicine) | yes (was performed by a telephone call to the registry of the department of medicine) | no | no placebo | yes | yes (“Univariate analyses revealed no _significant differences at baseline between groups for any of the demographic and clinical characteristics […].”) | low | full text publication
INT-1 | unclear | unclear | double | Placebo | yes | unclear | high | FDA documents
INT-3 | unclear | unclear | double | Placebo | yes | unclear | high | FDA documents
Janinis 2003 | unclear | unclear | no | no placebo | unclear | yes (“Both groups were well balanced for performance status, gender, age, and tumor type.”) | low | abstract
Kunikane 2001 a, b | yes, centrally randomized | yes, centrally randomized | double | Placebo | no | yes | low | full text publication
Kurz 1997 | yes | yes | double | Placebo | yes | yes | high | full text publication, unpublished data
Leyland-Jones 2003 | unclear | unclear | double | Placebo | yes | EPO patients were more likely to have adverse factors such as advanced age, lower performance status, greater extent of disease at baseline, and more risk factors for TVE’s (based on retrospective chart review) | high | full text publication, FDA documents
Littlewood 2001 | yes | yes | double | Placebo | yes | yes | high | full text publication, unpublished data, FDA documents
Machtay 2004 | unclear | unclear | no | no placebo | yes | unclear | low | abstract, FDA documents
N93-004 | unclear | unclear | double | Placebo | yes | slightly higher proportion of patients in the EPO arm had extensive SCLC than in the placebo arm (66% vs 59%) | high | FDA documents
Oberhoff 1998 | yes | yes | no | no placebo | yes | yes | low | full text publication, unpublished data, FDA documents
O’Shaughnessy 2005 | yes, computer generated randomization schedule’ | unclear | double | Placebo | yes | yes | high | full text publication
Osterborg 1996 a,b | yes | yes | no | no placebo | yes | yes | low | full text publication, unpublished data, FDA documents
Osterborg 2002, Osterborg 2005 | yes | yes | double | Placebo | yes | yes | high | full text publication, unpublished data, FDA documents
P-174 | unclear | unclear | double | Placebo | yes | unclear | high | FDA documents
Quirt 1996 | unclear | unclear | double | Placebo | yes | unclear | high | abstract
Razzouk 2004 | unclear | unclear | double | Placebo | yes | unclear | high | abstract
Rose 1994 | yes | unclear | double | Placebo | yes | yes | high | abstract, unpublished data, FDA documents
Rosenzweig 2004 | unclear | yes (using sequential, opaque, sealed envelopes with the order unknown to the investigator) | no | no placebo | yes | yes | low | full text publication, FDA documents
Savonije 2004 | unclear | unclear | no | no placebo | yes | significantly more patients with metastatic disease in EPO group | low | abstract
Silvestris 1995 | unclear | unclear | no | no placebo | no, not sure | unclear | low | full text publication
Ten Bokkel 1998 a, b | yes | yes | no | no placebo | yes, exception TR | yes | low | full text publication, unpublished data, FDA documents
Thatcher 1999 a, b | yes | yes | no | no placebo | yes | yes | low | full text publication, unpublished data, FDA documents
Thomas 2002 | unclear | unclear | no | no placebo | yes | yes (“At baseline, groups balanced for Hb, demographics, CT and disease related variables.”) | low | abstract
Throuvalas 2000 | yes | yes | no | no placebo | yes | yes | low | abstract, unpublished data
Vadhan-Raj 2004 | unclear | unclear | double | Placebo | yes | unclear | high | abstract, FDA documents
Welch 1995 | unclear | unclear | no | no placebo | yes | yes | low | full text publication
Witzig 2005 | unclear | unclear | double | Placebo | yes (not QoL) | yes | high, low for QoL | full text publication, FDA documents
Wurnig 1996 | yes (computer- generated randomization code) | unclear | double | Placebo | yes | unclear | high | full text publication

Table C9

KQ1: Darbepoetin versus Control, Study Quality

study author | random | allocation | blinding | placebo | ITT or 10% | similar | high or low quality | publication
Hedenus 2002 a,b,c | yes (central randomization service) | yes (central randomization service) | double | Placebo | yes | yes | high | full text publication
Hedenus 2003 | yes (central randomization service) | yes (central randomization service) | double | Placebo | yes | more patients with indolent lymphoma were randomized to placebo and more patients with higher stage of disease were randomized to Aranesp | high | full text publication, FDA documents
Kotasek 2003 a,b,c,d,e,f | unclear | unclear | double | Placebo | yes for safety, not for transfusion | slightly higher proportion of patients in the 12 μg group had breast cancer (61%) compared with the other groups, which ranged from 15 to 38%. The 12 μg group had also a slightly higher mean hb at baseline (10.4 g/d, compared with the other groups (9.7 to 10.2). | high, low for transfusion | full text publication
Vansteenkiste 2002 | yes, central randomization service | yes, central randomization service | double | Placebo | yes (not QoL) | yes | high, low for QoL | full text publication, FDA documents

Table C10

KQ1: Darbepoetin versus Epoetin, Study Quality

study author | random | allocation | blinding | placebo | ITT or 10% | similar | high or low quality | publication
Alexopoulos 2004 | unclear | unclear | no | no placebo | ITT | yes | low | abstract
Glaspy 2002 | unclear | unclear | no | no placebo | ITT or 10% | yes | low | full text
Glaspy 2003 a–c | unclear | unclear | no | no placebo | ITT or 10% | exception: lower mean baseline Hb and lower baseline serum erythropoietin concentration in darb group a and a larger proportion of women in the darb cohorts | low | full text
Glaspy 2005 | unclear | unclear | no | no placebo | ITT or 10%, not for QoL | yes | low | abstract
Schwartzberg 2004 | unclear | unclear | no | no placebo | ITT or 10% | yes | low | full text
Waltzman 2005 | unclear | unclear | no | no placebo | ITT or 10%, more pts excluded for QoL | exception: higher percentage of patients received nonplatinum based CT in the EPO group | low | abstract

Table C11

KQ1 Outcome I. Hematologic response: Epoetin versus Control

study author | Hb response definition | Epo n | Epo N | Proportion (%) | Control n | Control N | Proportion (%) | Comments
Hb at baseline < 10 g/dL
Boogaerts 2003 | Hb increase of 2 g/dL during the treatment phase without transfusion requirements after the initial 4 treatment weeks | 63 | 133 | 47.37% | 17 | 129 | 13.18%
Case 1993 | Hct increase of 6% from baseline independent of transfusion | 46 | 79 | 58.23% | 10 | 74 | 13.51%
Cazzola 1995 c | Hb increase of 2 g/dL independent of transfusion | 19 | 31 | 61.29% | 2 | 29 | 6.90% | data submitted for Cochrane Review
Cazzola 1995 d | | 16 | 26 | 61.54% | | | | data submitted for Cochrane Review
Dammacco 2001 | Hb increase of 2 g/dL independent of transfusion | 38 | 66 | 57.58% | 6 | 66 | 9.09% | data were included in Cochrane Review as Coiffier 2001
Henry 1995 | Hct increase of 6% from baseline independent of transfusion | 31 | 64 | 48.44% | 4 | 61 | 6.56% | Hct definition
Littlewood 2001 | Hb increase of 2 g/dL independent of transfusion in the previous 28 days | 172 | 244 | 70.49% | 22 | 115 | 19.13% | efficacy population: patients on study at least 28 days
Oberhoff 1998 | Hb increase of 2 g/dL independent of transfusion | 38 | 114 | 33.33% | 7 | 104 | 6.73% | at week 12, data submitted for Cochrane Review
Osterborg 1996 a | Hb increase of 2 g/dL independent of transfusion | 21 | 47 | 44.68% | 8 | 49 | 16.33% | data submitted for Cochrane Review
Osterborg 1996 b | | 23 | 48 | 47.92%
Osterborg 2002 | Hb increase of 2 g/dL independent of transfusion within 6 weeks | 114 | 170 | 67.06% | 46 | 173 | 26.59% | at end of week 16
Witzig 2004 | Hb increase of 2 g/dL from baseline | 120 | 165 | 72.73% | 52 | 164 | 31.71% | unclear if independent of transfusion
Rose 1994 | Hb increase of ≥ 6% of Hct unrelated to transfusion | 67 | 142 | 47.18% | 13 | 79 | 16.46% | Hct definitions, data submitted for Cochrane Review
Hb at baseline 10 to 12 g/dL
Bamias 2003 | Hb increase of 2 g/dl | 15 | 72 | 20.83% | 2 | 72 | 2.78% | unclear if independent of transfusion
Chang 2004 | Hb increase of 2 g/dl independent of transfusion in the previous 28 days | 115 | 175 | 65.71% | 11 | 175 | 6.29% | Hb response was evaluated retrospectively
Iconomou 2003 | Hb increase of 2 g/dl | 25 | 57 | 43.86% | 7 | 55 | 12.73% | after 12 wks of treatment, unclear if independent of transfusion
Savonije 2004 | Hb increase of 2 g/dl independent of transfusion in the previous 28 days | 146 | 211 | 69.19% | 32 | 104 | 30.77%

Table C12

KQ1 Outcome I. Hematologic response: Darbepoetin versus Control

Study Author | Treatment n | Treatment N | Treatment Proportion | Control n | Control N | Control Proportion | Hb definition | Comment
Hedenus 2002a | 5 | 11 | 45.45% | 1 | 11 | 9.09% | Hb increase of 2 g/dL independent of transfusion in the previous 28 days | absolute numbers were derived using Kaplan-Meier method; (Arm a 45% N=11, control 10%, N=11)
Hedenus 2002b | 12 | 22 | 54.55% | | | | | arm b: 55%, N=22
Hedenus 2002c | 14 | 22 | 63.64% | | | | | arm c: 62%, N=22
Hedenus 2003 | 104 | 174 | 59.77% | 31 | 170 | 18.24% | Hb increase of 2 g/dL independent of transfusion in the previous 28 days | Derived using Kaplan-Meier method (darb arm response 60%, N=174, control response 18%. N=170)
Kotasek 2003a | 8 | 32 | 25.00% | 7 | 51 | 13.73% | | Derived using Kaplan-Meier method; arm a: 24%, N=32, control 14%, N=51
Kotasek 2003b | 8 | 17 | 47.06% | | | | increase Hb 2 g/dL from baseline during 12 week study in the absence of RBCT in the previous 28 days | c: 50%, N=17
Kotasek 2003c | 23 | 46 | 50.00% | | | | | b: 48%, N=46
Kotasek 2003d | 17 | 28 | 60.71% | | | | | d: 62%, N=28
Kotasek 2003e | 20 | 35 | 57.14% | | | | | e: 58%, N=35
Kotasek 2003f | 20 | 40 | 50.00% | | | | | f: 50%, N=40

Table C13

KQ1 Outcome I. Hematologic response: Darbepoetin versus Epoetin

study author | Hb response definition | Hb response assessed at week | Darb (n) | Darb (N) | Percentage (%) | EPO (n) | EPO (N) | Percentage (%) | Comments
Hb at baseline ≤ 10 g/dL
Glaspy 2003 a | Hb increase of 2 g/dL independent of transfusion in the previous 28 days | 12 | 19 | 32 | 59.38% | 15 | 30 | 50.00% | reported K-M percentages with 95% CI, a: 59% (38; 80), EPO 49% (29; 69)
Glaspy 2003 b | | 12 | 17 | 30 | 56.67% | | | | reported K-M percentages with 95% CI, b: 58% (38; 79)
Glaspy 2003 c | | 12 | 20 | 30 | 66.67% | | | | reported K-M percentages with 95% CI, c: 65% (47; 84)
Glaspy 2002 Part B a | Hb increase of 2 g/dL independent of transfusion in the previous 28 days | 12 | 20 | 33 | 60.61% | 19 | 32 | 59.38% | a: 3 μg/kg q2w Darb, K-M percentages 60% (39; 80), EPO: 60% (40; 79)
Glaspy 2002 Part B b | | 12 | 25 | 31 | 80.65% | | | | b: 5 μg/kg q2w Darb, K-M percentages 79% (56; 100)
Glaspy 2002 Part B c | | 12 | 18 | 32 | 56.25% | | | | c: 7 μg/kg q2w Darb, K-M percentages taken from figure: 55%
Glaspy 2002 Part B d | | 12 | 21 | 32 | 65.63% | | | | d: 9 μg/kg q2w Darb, K-M percentages taken from figure: 67%
Hb at baseline 10–12 g/dL
Waltzman 2005 | Hb increase of ≥ 2 g/dL at week 9 | 9 | 48 | 177 | 27.12% | 78 | 175 | 44.57% | based on patients who received at least 1 dose of study drug and had at least 1 postbaseline hb or transfusion, p<0.001(logistic regression model adjusted for CT)
Waltzman 2005 | Hb increase of ≥ 2 g/dL at week 17 | 17 | 74 | 177 | 41.81% | 101 | 175 | 57.71% | based on patients who received at least 1 dose of study drug and had at least 1 postbaseline hb or transfusion, p=0.004 (logistic regression model adjusted for CT)

Table C14

KQ1 Outcome I. Hematologic response studies omitted from meta-analysis: Epoetin versus Control

study author | Hb response definition | Hb response, comments | Hb response n EPO | Hb response n control
Carabantes 1999 | Hb increase ≥ 1 g/dl OR Hb increase 0.5–1 g/dl and reticulocyte count increase > 40,000/ml after 3–4 weeks | no data reported | NR | NR
Cascinu 1994 | Hb level >10 g/dl after 9 weeks without transfusions | | 41/50 (82%) | 0/50
Del Mastro 1997 | maintain Hb level > 10g/dl | | 31/31 (100%) | 15/31 (48%)
Henke 2003 | Hb target level reached (women: Hb ≥ 14g/dL, men Hb ≥ 15g/dL) | | 148/180 (82%) | 26/171 (15%)
Huddart 2002 | Hb increase of 2 g/dl and/or increase in reticulocyte count >40 × 10^9^ | only % given for response, Epo36%, Control 5.5%, assumed 45 per group (n=90 for total group given in abstract) | 16/45 (36%) | 2/45 (5.5%)
Kurz 1997 | Hb increase of 2 g/dL and/or Hb >12 g/dL | data were included in Cochrane Review but should be excluded | 13/23 (56.5%) | 0/12
Silvestris 1995 | Hb increase of 2 g/dl or not further transfusion | | 21/27 (77.8%) | NR

Table C15

KQ1 Outcome I. Hematologic response study omitted from meta-analysis: Darbepoetin versus Control

Study ID | Treatment n | Treatment N | Treatment Proportion | Control n | Control N | Control Proportion | Hb definition | Comments
Vansteenkiste 2002 | 103 | 156 | 66.03 % | 38 | 158 | 24.05% | Hematological response as defined by Hb increase 2 g/dL OR target Hb 12g/dL | not in MA, absolute numbers were derived using Kaplan-Meier method, darb 66%, N=156, control 24%, N=158

Table C16

KQ1 Outcome I. Hematologic response studies omitted from meta-analysis: Darbepoetin versus Epoetin

study author | Hb response definition | response assessed at week | Darb (n) | Darb (N) | Proportion (%) | EPO (n) | EPO (N) | Proportion (%) | Comments
Schwartzberg 2004 | Hb increase of ≥ 2 g/dL OR Hb level ≥12 g/dL | | 108 | 157 | 68.79% | 112 | 155 | 72.26% | definition did not meet our criteria, percentages reported
Alexopoulos 2004 | Hb increase of 1.5 g/dL over baseline | 4 | 8 | 25 | 32.00% | 3 | 25 | 28.00% | reported percentages, p=NS
Alexopoulos 2004 | | 8 | 11 | 25 | 44.00% | 11 | 25 | 44.00% | reported percentages, p=NS
Glaspy 2005 | achieving Hb target ≥ 11 g/dL | K-M approach | 547 | 606 | 90.26% | 576 | 603 | 95.52% | K-M proportion (95% CI) Darb: 90.3% (87.5; 93.1), EPO: 95.5 (93.6; 97.4)
Additional data
Glaspy 2002 Part A | Hb increase of 2 g/dL independent of transfusion in the previous 28 days | 12 | 3 | 13 | 23.00% | NR | 53 | NR | dosage: 0.5 μg/kg qw Darb; K-M 23% (0; 46)
Glaspy 2002 Part A | | 12 | 22 | 29 | 76.00% | | | | dosage: 4.5 μg/kg qw Darb; K-M 76% (59; 94)

Table C17

KQ1 Outcome I. Hematologic response subgroup analysis: Epoetin versus Control

Study | Subgroups prospectively stratified for | Epo n/N (%) | Control n/N (%) | p-value
Littlewood 2001 | Overall efficacy population | 172/244 (70.5%) | 22/115 (19.1%) | <0.001
Littlewood 2001 | solid tumors | 87/131 (66.4%) | 13/61 (21%) | NR
Littlewood 2001 | hematological tumors | 85/113 (75.22%) | 9/543 (16.6%) | NR
Littlewood 2001 | Hb ≤ 10.5 | 139/293 (47.4%) | 22/100 (22%) | NR
Littlewood 2001 | Hb > 10.5 | 33/41 (80.5%) | 0/15 (0%) | NR
Osterborg 2002 | All | 114/170 (67%) | 46/173 (27%) | <0.001
Osterborg 2002 | MM | 44/58 (76%) | 17/58 (29%) | <0.001
Osterborg 2002 | NHL | 33/53 (62%) | 12/49 (24%) | <0.001

Osterborg 1996 | | Dose titration Epo | Dose titration Epo | Fixed dose Epo | Fixed dose Epo | Controls | Controls
| | Responder/Treated | Response rate (K-M est) | Responder/Treated | Response rate (K-M est) | Responder/Treated | Response rate (K-M est)
| MM | 13/22 | 70%^*^ | 12/23 | 64% | 4/20 | 21%
| NHL | 10/22 | 52% | 7/15 | 54% | 4/19 | 28%
| Chemotherapy yes | 22/38 | 63%^*^ | 18/34 | 63%^*^ | 7/35 | 24%
| Chemotherapy no | 1/6 | 20% | 1/4 | 33% | 1/4 | 25%

* p<0.05 compared with controls

Table C18

KQ1 Outcome I. Hematologic response subgroup analysis: Darbepoetin versus Control

Study | Subgroups prospectively stratified for | Epo n/N (%) | Control n/N (%) | p-value
Hedenus 2003 | lymphoma | 64% (55/86) | 13% (11/84) | <0.001
Hedenus 2003 | myeloma | 56% (49/88) | 22% (20/86) | <0.001

Table C19

KQ1 Outcome I. Hematologic response subgroup analysis: Darbepoetin versus Epoetin

Study | Subgroups prospectively stratified for | Darb n/N (%) | Epo n/N (%) | p-value
Schwartzberg 2004 | Overall population | 108/157 (69%) | 122/155 (72%) | NR
Schwartzberg 2004 | Lung cancer | 63/72 (88%) | 56/69 (81%) | NR
Schwartzberg 2004 | Breast cancer | 25/51 (49%) | 30/51 (59%) | NR
Schwartzberg 2004 | Gynecological cancers | 21/34 (62%) | 26/35 (74%) | NR
Schwartzberg 2004 | Hb < 10.5 | 21/38 (55%) | 18/38 (47%) | NR
Schwartzberg 2004 | Hb ≥ 10.5 | 88/119 (74%) | 94/117 (80%) | NR

Table C20

KQ1 Outcome II. Transfusion: Epoetin versus Control

Study ID | Treatment n | Treatment N | Proportion (%) | Control n | Control N | Proportion (%) | Comments
Baseline Hb below < 10g/dL
Aravantinos 2003 | 9 | 24 | 37.50 | 23 | 23 | 100.00
Boogaerts 2003 | 43 | 133 | 32.33 | 67 | 129 | 51.94
Cascinu 1994 | 10 | 50 | 20.00 | 28 | 50 | 56.00 | data submitted for original Cochrane Review
Case 1993 | 32 | 79 | 40.51 | 36 | 74 | 48.65 | data submitted for original Cochrane Review
Cazzola 1995c | 6 | 31 | 19.35 | 8 | 29 | 27.59
Cazzola 1995d | 4 | 26 | 15.38
Dammacco 2001 | 19 | 69 | 27.54 | 36 | 76 | 47.37
Henry 1995 | 34 | 64 | 53.13 | 42 | 61 | 68.85
Huddart 2002 | 18 | 45 | 40.00 | 32 | 45 | 71.11
Kurz 1997 | 5 | 23 | 21.74 | 8 | 12 | 66.67
Littlewood 2001 | 62 | 251 | 24.70 | 49 | 124 | 39.52
Oberhoff 1998 | 32 | 114 | 28.07 | 44 | 104 | 42.31 | data submitted for original Cochrane Review
Osterborg 1996a | 33 | 47 | 70.21 | 39 | 49 | 79.59 | data submitted for original Cochrane Review
Osterborg 1996b | 39 | 48 | 81.25
Osterborg 2002 | 65 | 169 | 38.46 | 90 | 173 | 52.02 | data submitted for original Cochrane Review
Witzig 2004 | 42 | 166 | 25.30 | 65 | 164 | 39.63
Rose 1994 | 65 | 142 | 45.77 | 47 | 79 | 59.49 | data submitted for original Cochrane Review
Baseline Hb below 10–12g/dL
Bamias 2003 | 11 | 72 | 15.28 | 24 | 72 | 33.33
Chang 2004 | 15 | 175 | 8.57 | 40 | 175 | 22.86
Iconomou 2003 | 9 | 61 | 14.75 | 16 | 61 | 26.23
Ten Bokkel 1998a | 2 | 45 | 4.44 | 13 | 33 | 39.39
Ten Bokkel 1998b | 6 | 42 | 14.29
Thomas 2000 | 7 | 62 | 11.29 | 31 | 65 | 47.69
Wurnig 1996 | 8 | 15 | 53.33 | 14 | 14 | 100.00
Carabantes 1999 | 4 | 20 | 20.00 | 13 | 15 | 86.67
Janinis 2003 | 17 | 186 | 9.14 | 43 | 186 | 23.12
Quirt 1996 | 4 | 27 | 14.81 | 8 | 27 | 29.63
Razzouk 2004 | 72 | 111 | 64.86 | 85 | 111 | 76.58
Savonije 2004 | 76 | 211 | 36.02 | 68 | 104 | 65.38
Throuvalas 2000 | 2 | 28 | 7.14 | 10 | 26 | 38.46
Vadhan-Raj 2004 | 4 | 28 | 14.29 | 10 | 31 | 32.26
Baseline Hb 12g/dL
Del Mastro 1997 | 0 | 31 | 0.00 | 2 | 31 | 6.45
Dunphy 1999 | 2 | 13 | 15.38 | 5 | 14 | 35.71
Kunikane 2001a | 1 | 16 | 6.25 | 0 | 19 | 0.00
Kunikane 2001b | 2 | 18 | 11.11
Thatcher 1999a | 19 | 42 | 45.24 | 26 | 44 | 59.09
Thatcher 1999b | 9 | 44 | 20.45
Welch 1995 | 4 | 15 | 26.67 | 8 | 15 | 53.33
Baseline not reported
Henze 2002 | 72 | 116 | 62.07 | 80 | 116 | 68.97

Table C21

KQ1 Outcome II. Transfusion: Darbepoetin versus Control

Study ID | Dosage | Treatment n | Treatment N | Treatment Percentage | Control n | Control N | Control Percentage | first 4 weeks included in analysis? | Comments
Hedenus 2002a | 1.0 μg/kg qw | 3 | 11 | 27.27% | 5 | 11 | 45.45% | excluding first 4 weeks, counting week 5 to end of treatment | derived from K-M estimates, arm a: 27% (95% CI 1–54), N=11, control: 45% (16–75), N=11
Hedenus 2002b | 2.25 μg/kg qw | 6 | 22 | 27.27% | | | | | 27% (9–46), N=22
Hedenus 2002c | 4.5 μg/kg qw | 3 | 22 | 13.64% | | | | | 15% (0–30), N=22
Hedenus 2003 | 2.25 μg/kg/qw | 52 | 167 | 31.14% | 79 | 165 | | excluding first 4 weeks, counting week 5 to end of treatment (week 13) | derived from K-M estimates, arm a: 31%(95% CI 24–38), N=167; 48% (95% CI 41%–56%), N=165
Kotasek 2003a | 4.5 μg/kg Q3W | 8 | 30 | 26.67% | 23 | 50 | | excluding first 4 weeks, counting week 5 to week 12 | arm a: 25% (9%–41%), N=30; control 46% (32%–61%), N=50
Kotasek 2003b | 6.75 μg/kg Q3W | 5 | 17 | 29.41% | | | | | arm b: 28% (7%–51%), N=17
Kotasek 2003c | 9.0 μg/kg Q3W | 12 | 41 | 29.27% | | | | | arm c: 30% (16%–44%), N=41
Kotasek 2003d | 12.0 μg/kg Q3W | 7 | 27 | 25.93% | | | | | arm d: 26% (7.5%–41%), N=27
Kotasek 2003e | 13.5 μg/kg Q3W | 9 | 35 | 25.71% | | | | | arm e: 27% (11%–40%), N=35
Kotasek 2003f | 15 μg/kg Q3W | 7 | 38 | 18.42% | | | | | arm f: 19% (6%–32%), N=38
Vansteen._FDA report | 2.25 μg/kg qw | 53 | 156 | 33.97% | 89 | 158 | | including first 4 weeks

Table C22

KQ1 Outcome II. Transfusion: Darbepoetin versus Control

Study ID | Darbepoetin (n) | Darbepoetin (N) | Percentage (%) | Epoetin (n) | Epoetin (N) | Percentage (%) | Weeks included | Comments
Baseline Hb below < 10g/dL
Glaspy 2002 Part A, c (1.5 μg/kg/qw) | 9 | 35 | 25.71% | 12 | 53 | 22.64% | 5–13 | K-M percentages reported, a: 26% (9; 43), EPO 23% (10; 36)
Glaspy 2002 Part A, d (2.25 μg/kg/qw) | 8 | 59 | 13.56% | | | | | b: 13% (4; 23)
Glaspy 2002 Part A, e (4.5 μg/kg/qw) | 2 | 29 | 6.90% | | | | | c: 6% (2; 30)
Glaspy 2002 Part B, a (3 μg/kg/q2w) | 1 | 30 | 3.33% | 11 | 30 | 36.67% | 5–13 | K-M percentages reported, a: 4% (0; 11), EPO 36% (10; 87)
Glaspy 2002 Part B, b (5 μg/kg/q2w) | 7 | 30 | 23.33% | | | | | b: 22% (6; 37)
Glaspy 2002 Part B, c (7 μg/kg/q2w) | 7 | 30 | 23.33% | | | | | c: 23% (7; 39)
Glaspy 2002 Part B, d (9 μg/kg/q2w) | 3 | 29 | 10.34% | | | | | d: 11% (0; 23)
Alexopoulos 2004 | 4 | 25 | 16.00% | 3 | 25 | 12.00% | “during study period” | absolute numbers reported, p=NS
Baseline Hb below 10–12 g/dL
Schwartzberg 2004 a (breast cancer) | 4 | 72 | 5.56% | 11 | 69 | 15.94% | 1–16 | percentages reported (a: 6% vs 16%, b: 27% vs 18%, c: 21% vs 17%)
Schwartzberg 2004 b (lung cancer) | 14 | 51 | 27.45% | 9 | 51 | 17.65%
Schwartzberg 2004 c (gynecological) | 7 | 34 | 20.59% | 9 | 51 | 17.65%
Glaspy 2005 | 157 | 582 | 26.98% | 126 | 571 | 22.07% | 5 to end of treatment period (wk 17) | K-M percentages reported, darb: 27%, EPO 22%, adjusted for strata Hb </> 10 g/dl and +/− platinum
Waltzman 2005 | 29 | 163 | 17.79% | 20 | 155 | 12.90% | 5 to end of treatment period (wk 17) | p=0.2936 logistic regression, adjusted for CT

Table C23

KQ1 Outcome II. Transfusion studies omitted from meta-analysis: Epoetin versus Control

Study ID | Epo n/N (%) | Control n/N (%) | Comments
O’Shaugnessy 2005 | −/47 | 4/47 (8.5%) | not in MA, patients receiving transfusion were excluded from study

Table C24

KQ1 Outcome II. Transfusion studies omitted from meta-analysis: Darbepoetin versus Control

Study ID | Treatment n | Treatment N | Treatment Percentage | Control n | Control N | Control Percentage | first 4 weeks included in analysis? | Comment
Vansteenkiste 2002 | 40 | 148 | 27.03% | 77 | 149 | 51.68% | excluding first 4 weeks, counting week 5 to end of treatment | Based on K-M estimates. Darb: 27% (20% to 35%), N=148, control: 52% (44% to 66%), N=149, Difference of 25% (95% CI 14% to 36%) was statistically significant, p<0.001.

Table C25

KQ1 Outcome II. Transfusion subgroup analysis: Epoetin versus Control

Study | Subgroups prospectively | Epo n/N (%) | Control n/N (%) | p-value | comments
| stratified for
Henze 2002 | Overall efficacy population | 72/116 (62%) | 22/115 (19.1%) | p=0.32 | overall n=232, not reported how many patients per group
Henze 2002 | ALL (37%) | 66% | 89% | p=0.03
Henze 2002 | non-ALL | 56% | 60% | p=0.65
Razzouk 2004 | All patients | 72/111 (35%) | 85/111 (23%) | p=0.0536 | p value refers to proportion NOT transfused
Razzouk 2004 | ALL (n=75) | 26/40 (65.0%) | 22/35 (62.9%)
Witzig 2004 | All patients | 42/166 (25.3%) | 65/164 (39.6%) | p=0.005
Witzig 2004 | mild anemia (Hb > 9 g/dL) | 19% | 29%
Witzig 2004 | severe anemia (Hb < 9 g/dL) | 40% | 62%

Table C26

KQ1 Outcome II. Transfusion subgroup analysis: Darbepoetin versus Control

Study | Subgroups prospectively stratified for | Epo % (n/N) | Control % (n/N) | p-value
Hedenus 2003 | Subgroups prospectively stratified for | Epo % (n/N) | Control % (n/N) | p-value
excluding first 4 weeks | lymphoma | 27% | 49% | 0.002
excluding first 4 weeks | myeloma | 35% | 48% | 0.042
including first 4 weeks | lymphoma | NR | NR | 0.011
including first 4 weeks | myeloma | NR | NR | 0.018

Table C27

KQ1 Outcome II. Transfusion subgroup analysis: Darbepoetin versus Epoetin

Study | Subgroups prospectively stratified for | Darbepoetin (n) | Darbepoetin (N) | Proportion (%) | Epoetin (n) | Epoetin (N) | Proportion (%) | Comments
Schwartzberg 2004 | Overall | 25 | 157 | 15.92% | 26 | 155 | 16.77% | weeks 1 to 16, percentages reported
Schwartzberg 2004 | Hb < 10 g/dL | 8 | 38 | 21.05% | 16 | 38 | 42.11%
Schwartzberg 2004 | Hb ≥ 10 g/dL | 17 | 119 | 14.29% | 11 | 117 | 9.40%

Table C28

KQ1 Outcome IV. Survival: Epoetin versus Control

study author | random | eval | method | follow up | events EPO (n/N), reported are deaths if not stated otherwise | events control (n/N), reported are deaths if not stated otherwise | HR (95% CI) | Comments
Littlewood 2001
Littlewood 2001, Martin et al 2003 | 375 | 375 | Kaplan-Meier, unadjusted, p=0.13 | 26 months median fu, 12 months after last subject completed study | 155/251 (62%) | 82/124 (66%) | HR 0.81 (0.62; 1.06) | lost to follow up: Epo 2, placebo 1
Littlewood 2001 | 375 | 375 | Cox- regression, adjusted, p=0.052 | 26 months median fu, 12 months after last subject completed study | 155/251 | 82/124 | HR 1.309 in favor of EPO, equivalent to HR 0.76 (0.58; 1.00) | calculated by GS
Littlewood 2001 | | | median survival | | 17 months | 11 months
Information submitted by OrthoBiotech for Cochrane Review | NR | NR | Cox model, adjusted, p=0.0296 | Nov 15 1998, 3 months after last subject completed study | NR | NR | HR 1.38
Information submitted by OrthoBiotech for Cochrane Review | 375 | 375 | log rank test p=0.128 (unadjusted) | Aug 15 1999; 12 months after last subject completed study | 155/251 | 82/124 | NR
Information submitted by J&J for FDA/ODAC hearing | 375 | 375 | proportions alive at | 12 months | 60% | 40% | HR 1.309, p=0.052, in favor of EPO
Information submitted by J&J for FDA/ODAC hearing | 375 | 375 | Hazard ratio | double-blind study phase plus 30 days | 41/251 | 22/124 | HR 0.81 (0.48; 1.36)
Information submitted by J&J for FDA/ODAC hearing | 375 | 375 | median survival | | 17 months | 11 months
Machtay 2004
Abstract publication 2004 | 135 | 135 | 1-yr actuarial overall survival | 1-year | 70% (assume survival) | 81% (assume survival) | HR 1.57 (0.76; 3.27)
Abstract publication 2004, additional slides | 148 | 141 | deaths within 90 days post study | < 1 year | 9/71 | 6/70 | p=0.59
Abstract publication 2004, additional slides | 148 | 141 | 2- yr overall survival | median f/u 14.5 months, for surviving patients 19.4 months | 27/71 deaths | 21/70 deaths | HR 1.41 (0.8; 2.5), p=0.23
FDA report 2004 | 135 | 117 | NR | 8.7 months | At the interim analysis (at 8.7 months) 22 out of 117 patients had died. The analysis showed no statistically significant differences, but non- significant trends towards lower survival in the epoetin alfa arm.
Information submitted by J&J for FDA/ODAC hearing | 135 | 135 | Proportion | NR | 17/67 (25%) | 12/68 (18%) | NR
Leyland – Jones 2003
Leyland – Jones 2003 | 939 | 939 | Proportion | 4 months | 41 | 16 | NR
Leyland – Jones 2003 | 939 | 939 | Proportion, p=0.0117 | 12 months | 70% (survival) | 76% (survival) | NR
FDA report and information submitted by J&J for FDA/ODAC hearing | 939 | 939 | Proportion | 4 months | 41/469 | 16/470 | NR
FDA report and information submitted by J&J for FDA/ODAC hearing | 939 | 939 | Cox adjusted for metastatic category (ITT) | 12 months | 148/469 | 115/470 | HR 1.37 (1.07; 1,74)
Witzig 2004
Witzig 2004 | 344 | 333 | proportion | died during study period | 13/168 | 8/165 | NR
Witzig 2004 | 344 | 333 | proportion | died within 30 days after the last dose | 31/168 | 22/165 | NR
Information submitted by J&J for FDA/ODAC hearing | 344 | 333 | Hazard ratio | double-blind study phase plus 30 days | 31/168 | 26/165 | HR 1.17 (0.69; 1.97)
Witzig 2004 | 344 | 330 | proportion | follow up 1 year | 105/166 | 103/164 | p=0.53 | HR 1.09 (0.83; 1.43) calculated with p value and events, direction questionable
Witzig 2004 | 344 | 330 | median overall survival | follow up 1 year | 10.4 months | 11.2 months | p=0.53
N93-004
FDA report and information submitted by J&J for FDA/ODAC hearing | 224 | 224 | proportion | 3 years | 100/109 | 101/115 | NR
FDA report and information submitted by J&J for FDA/ODAC hearing | 224 | 224 | median survival (K-M estimate, 95% CI in months) | 3 years | 10.5 (9; 13) | 10.4 (8; 13) | NR
Henke 2003
Henke 2003 | 351 | 351 | Cox model, adjusted for stratum and AJCC stage, ITT | EPO: 605 days, control 928 days | 109/180 | 89/171 | HR 1.39 (1.05–1.84)
Henke 2003 | 351 | 351 | Cox model, adjusted for stratum and AJCC stage, radiotherapy correct | EPO: 605 days, control 928 days | 109/180 | 89/171 | HR 1.22 (0.86–1.73)
Henke 2003 | 351 | 351 | Cox model, adjusted for stratum and AJCC stage, per protocol | EPO: 605 days, control 928 days | 109/180 | 89/171 | HR 1.13 (0.78–1.64)
Information submitted by Roche for FDA/ODAC hearing | 351 | 351 | adjusted Cox regression, p=0.023, adjusted by stratum and TNM staging | EPO: 605 days, control 928 days | 109/180 | 89/171 | HR 1.39 (1.05–1.84) | censored: EPO 71, control 82
Information submitted by Roche for FDA/ODAC hearing | 351 | 351 | log rank test, p=0.0901, not adjusted | EPO: 605 days, control 928 days | 109/180 | 89/171 | HR 1.27 (0.96–1.68), calculated | censored: EPO 71, control 82
Österborg 2002
Österborg 2002 | 349 | 343 | proportion | deaths during 16 weeks of study | 21/170 | 19/173 | -
Österborg 2002 | 349 | 343 | proportion | deaths during 16 weeks of study and follow up | 28/170 | 22/173 | -
IPD data submitted by Roche 2002 | 349 | 343 | Hazard ratio | median observation time 113 days | 21/170 | 19/173 | HR 1.13 (0.61; 2.09)
Information submitted by Roche for FDA/ODAC hearing | 349 | 343 | Cox regression | deaths until day 28 after end of treatment | NR | NR | HR 1.29 (0.71; 2.35)
Information submitted by Roche for FDA/ODAC hearing | 349 | 343 | logrank test p=0.76 | median survival (months): EPO 17.4, control 18.3 | 110/170 | 109/173 | HR 1.04 (0.80; 1.36), calculated by JB | censored: EPO 60, control 64
Österborg 2005 | 349 | 343 | | min follow up 17.5 months, median time for patients being censored EPO 27.8 months. Control 27.5 months; median survival (months): EPO 17.4 (95% CI 15.0; 20.5), control 18.3 (95% CI 16.0–22.3), log-rank test: p=0.76 | 110/170 | 109/173 | HR 1.04 (0.80; 1.36), reported | censored: EPO 60, control 64
Cazzola 1995
Cazzola 1995 | 146 | 146 | Proportion | NR | 4/117 | 3/29 | NR
IPD data submitted by Roche 2002 | 146 | 146 | IPD based hazard ratio | median observation time 57 days | 2/117 | 1/29 | HR 0.06 (0.00; 3.53)
Information submitted by Roche for FDA/ODAC hearing | 146 | 146 | Cox regression | deaths until day 28 after end of treatment | NR | NR | HR 0.37 (0.06; 2.25)
Coiffier 2001; Boogaerts 2003
Boogaerts 2003 | 262 | 262 | NR | NR | NR | NR | NR
IPD data submitted by Roche 2002 | 262 | 262 | IPD based hazard ratio | median observation time 85 days | 8/133 | 8/129 | HR 1.02 (0.38; 2.72)
Roche submission 2004 | 262 | 259 | Cox regression | deaths until day 28 after end of treatment | NR | NR | HR 1.02 (0.42; 2.46)
Oberhoff 1998
Oberhoff 1998 | 218 | 218 | Proportion | during controlled treatment phase | 8/114 | 14/104 | NR
IPD data submitted by Roche 2002 | 218 | 218 | IPD based hazard ratio | median observation time 85 days | 5/114 | 12/104 | HR 0.38 (0.15; 0.99)
Information submitted by Roche for FDA/ODAC hearing | 218 | 218 | Cox regression | deaths until day 28 after end of treatment | NR | NR | HR 0.61 (0.24; 1.55)
Ten Bokkel 1998
Ten Bokkel 1998 | 122 | 120 | Proportion | during study or subsequent follow up | 6/87 | 2/33 | NR
IPD data submitted by Roche 2002 | 122 | 120 | IPD based hazard ratio | median observation time 169.5 days | 4/87 | 2/33 | HR 0.80 (0.14; 4.70)
Information submitted by Roche for FDA/ODAC hearing | 122 | 116 | Cox regression | median observation time 169.5 days | NR | NR | HR 1.01 (0.19; 5.25)
Österborg 1996 a, b
Österborg 1996 a | 144 | 144 | Proportion | deaths during study period | 15/47 | 14/49 | NR
Österborg 1996 b | 144 | 144 | Proportion | deaths during study period | 11/48 | 14/49 | NR
IPD data submitted by Roche 2002 (a) | 144 | 144 | IPD based hazard ratio | median observation time 168.5 days | 15/47 | 12/49 | HR 1.34 (0.55; 3.30)
IPD data submitted by Roche 2002 (b) | 144 | 144 | IPD based hazard ratio | median observation time 168.5 days | 10/48 | 12/49 | HR 0.78 (0.27; 2.25)
Information submitted by Roche for FDA/ODAC hearing | 144 | 144 | Cox regression | deaths until day 28 after end of treatment | NR | NR | HR 1.02 (0.51; 2.05)
Rose 1994
only unpublished data (extracted from CSR by JB)* | | 221 | Proportion | simple binary approach | 11/142 | 4/79 | 1.52 (0.51; 4.53)
Information submitted by J&J for FDA/ODAC hearing | | 221 | Hazard ratio | double-blind study phase plus 30 days | 16/142 | 6/79 | HR 1.68 (0.66; 4.30)
Case 1993
unpublished data | | 157 | Proportion | simple binary approach | 10/81 | 9/76 | 1.05 (0.40; 2.73)
Information submitted by J&J for FDA/ODAC hearing | | 157 | Hazard ratio | double-blind study phase plus 30 days | 10/81 | 9/76 | HR 1.08 (0.44; 2.67)
Dammacco 2001
published and unpublished data identical | | 145 | Proportion | simple binary approach | 1/69 | 7/76 | 0.23 (0.05; 0.94)
Information submitted by J&J for FDA/ODAC hearing | | 145 | Hazard ratio | double-blind study phase plus 30 days | 1/69 | 7/76 | HR 0.15 (0.02; 1.20)
Henry 1995
only unpublished data | | 132 | Proportion | simple binary approach | 8/67 | 10/65 | 0.75 (0.28; 2.01)
Information submitted by J&J for FDA/ODAC hearing | | 132 | Hazard ratio | double-blind study phase plus 30 days | 8/67 | 9/65 | HR 0.86 (0.33; 2.22

Table C29

KQ1 Outcome IV. Survival: Darbepoetin versus Control

study author | randomized | evaluated | method | follow up | events EPO (n/N), reported are deaths if not stated otherwise | events control (n/N), reported are deaths if not stated otherwise | HR (95% CI)
Vansteenkiste 2002
Vansteenkiste 2002 | 320 | 314 | unadjusted, simple Peto’s Odds Ratio | | 22/155 | 19/159 | NR
FDA report 2004 | 320 | 314 | Cox model, adjusted for histology | | 65/155 | 78/159 | HR 0.80 (0.58; 1.11)
Information submitted by industry for FDA/ODAC hearing | 320 | 314 | Cox model, adjusted for histology | median follow up 16 months | 100/155 | 119/159 | HR 0.78 (0.60; 1.01)
Hedenus 2003
Hedenus 2003 | 349 | 344 | proportion | during study or within 30 days after study | 10/175 | 4/169 | NR
Information submitted by industry for FDA/ODAC hearing | 349 | 344 | Hazard ratio; events were counted from K-M curve | median follow up 27 months | 74/175 | 61/169 | HR 1.36 (0.98; 1.90)
Kotasek 2003
Kotasek 2003, only data from publication available | | 198 | number of deaths at end of study reported, simple Peto’s Odds Ratio calculated with RevMan | during study | 7/198 | 3/51 | HR 0.55 (0.11; 2.61)
Hedenus 2002
Hedenus 2002, only data from publication available | | 66 | number of deaths at end of study reported | during study | 0/55 | 0/11 | not estimable

Table C30

KQ1 Outcome IV. Survival subgroup analysis: Epoetin versus Control

Study author | randomized | evaluated | method | follow up | events EPO (n/N), reported are deaths if not stated otherwise | events control (n/N), reported are deaths if not stated otherwise | HR (95% CI) | Comments
Littlewood 2001
Littlewood JCO 2001, Martin et al 2003 | 375 | 375 | Kaplan- Meier, unadjusted, p=0.126 | 26 months median f/u, 12 months after last subject completed study | 155/251 (62%) | 82/124 (66%) | HR 0.76 (0.58; 1.00) | lost to follow up: Epo 2, placebo 1
Littlewood 2001, hematological malignancies | 173 | 173 | Proportion | 26 months median f/u | dead: 54/115 | dead: 30/58 | NR | lost to follow up: Epo 1, placebo 0
| | | | | alive: 60/115 | alive: 28/58
Littlewood 2001, solid tumors | 202 | 202 | Proportion | 26 months median f/u | dead: 101/136 | dead: 52/66 | NR | lost to follow up: Epo 1, placebo 1
| | | | | alive: 34/136 | alive: 13/66
Martin et al 2003, breast cancer stage IV | | 55 | Proportion | assumed: 26 months median f/u | dead: 22/36 (61%) | dead: 16/19 (84%) | NR, K-M curve in paper | lost to follow up: Epo 0, placebo 0
| | | | | alive: 14/36 (39%) | alive: 3/16 (16%)

Table C31

KQ1 Outcome IV. Survival subgroup analysis: Darbepoetin versus Control

Study | Subgroups prospectively stratified for | Darbepo n/N | Control n/N | p-value
Hedenus 2003
report submitted by pharmaceutical company for FDA/ODAC hearing May 2004 | aggressive NHL | 8/17 | 9/16 | “similar results”
report submitted by pharmaceutical company for FDA/ODAC hearing May 2004 | indolent NHL | 7/20 | 9/29 | “similar results”
report submitted by pharmaceutical company for FDA/ODAC hearing May 2004 | MM | 45/90 | 34/83 | “similar results”
report submitted by pharmaceutical company for FDA/ODAC hearing May 2004 | CLL | 14/29 | 9/26 | “similar results”
Vansteenkiste 2002
report submitted by pharmaceutical company for FDA/ODAC hearing May 2004 | non SCLC | K-M curve available | K-M curve available | difference between SCLC and non SCLC was not statistically significant
report submitted by pharmaceutical company for FDA/ODAC hearing May 2004 | SCLC | 28/47 | 35/45

Table C32

KQ1 Outcome IV Survival: Selected characteristics of studies that reported survival outcomes and binary outcomes for survival and thromboembolic events.

Citation | Pub date | N random | Type of malig | Malignancy details | Baseline Hb | Target Hb | | Standard Epo dose^*,*^ | Control death rate | HR for death | | RR for thrombo- embolic event
Citation | Pub date | N random | Type of malig | Malignancy details | Baseline Hb | Lo | Hi | Standard Epo dose^*,*^ | Control death rate | <1 | >1 | <1 | >1
Case-J&J (2002) | 1993 | 157 | mixed | mixed | 9.43 | 12.5 | 12.5 | 31,500 | 11.8 | | ✓ | ✓
Rose-J&J (2002) | 1994 | 221 | hematol | CLL, stage III, IV | 9.2 | | | 31,500 | 7.6 | | ✓ | | ✓
Cascinu | 1994 | 100 | solid | stomach, ov, melanoma, H&N, lung, breast | 8.68 | 10 | 12 | 31,500 | 0
Cazzola-Roche (2002) | 1995 | 146 | hematol | malignant lymphoma (MM, NHL) | 9.4 | 12.5 | 14 | 52,500 | 3.4 | ✓
Henry | 1995 | 132 | mixed | mixed | 9.5 | 12.5 | 12.5 | 31,500 | 15.4 | ✓ | | ✓
Österborg-Roche (2002) | 1996 | 144 | hematol | malignant lymphoma (MM, NHL, CLL) | 8 | 11 | 15 | 70,000 | 24.5 | | ✓ | | ✓
Del Mastro | 1997 | 62 | solid | breast cancer, stage II | 13.05 | 13 | 15 | 31,500 | 9.7 | ✓
Kurz | 1997 | 35 | solid | ov, uterus, cervical ca | 9.9 | | | 31,500 | 0
Oberhoff-Roche (2002) | 1998 | 218 | solid | ovarian, breast, lung, GU, GI, other | 9.95 | | | 35,000 | 11.5 | ✓
Ten Bokkel-Roche (2002) | 1998 | 120 | solid | ovarian, stage II–IV | 11.8 | | | 47,250 | 6.1 | | ✓ | | ✓
Thatcher, a | 1999 | 64 | solid | SCLC | 13.4 | 13 | 15 | 33,075 | 4.5 | ✓
Thatcher, b | 1999 | 66 | solid | SCLC | 13.4 | | | 33,075 | 9.1 | | ✓ | | ✓
Dunphy | 1999 | 30 | solid | H&N, SCLC, stage III/IV | 14.1 | | | 31,500 | 6.7 | ✓
Throuvalas | 2000 | 55 | solid | cervix and bladder ca | 11.3 | | | 50,000 | 3.7 | ✓ | | | ✓
Littlewood^*^ | 2001 | 375 | mixed | NHL, MM, breast, HD, CLL, GI, other | 9.8 | 12 | 15 | 31,500 | 66.1 | ✓ | | | ✓
Coiffier-Roche (2002) | 2001 | 262 | mixed | MM, NHL, CLL, ov, bone, GI, respir, other | 9.1 | 12 | 14 | 31,500 | 6.2 | | ✓
Dammacco-J&J (2002) | 2001 | 145 | hematol | lymphoma (MM, NHL) | 8.5 | | | 31,500 | 9.2 | ✓ | | | ✓
Österborg | 2002 | 343 | hematol | malignant lymphoma (MM, NHL, CLL) | 9.25 | 13 | 14 | 31,500 | 63.0 | | ✓ | | ✓
Leyland Jones^*^ | 2003 | 939 | solid | metastatic breast cancer | 12.8 | 10.5 | 14 | 40000 | 24.5 | | ✓ | | ✓
Henke-Roche^*^ | 2003 | 351 | solid | H&N, stage III, IV | 11.75 | 14 | 15 | 63000 | 52.0 | | ✓ | | ✓
Bamias | 2003 | 144 | solid | ovarian, NSCLC, SCLC, | 11.5 | 13 | | 30,000 | 5.6 | | ✓ | ✓
Machtay^*^ | 2004 | 141 | solid | H&N non-metastatic, non resected | ? 10–12 | 13 | 15 | 40,000 | 30.0 | | ✓ | | ✓
Witzig | 2004 | 330 | solid | lung, breast ca, other | 9.45 | 13 | 15 | 40,000 | 62.8 | | ✓ | | ✓
N93-004^*^ | 2004 | 224 | solid | SCLC, limited and extended disease | ? >12 | 14 | 16 | 31,500 | 87.8 | | ✓ | ✓
Int-1 | 2004 | 244 | solid | ovarian cancer | | | | 47,250 | 2.5 | | ✓ | | ✓
Int-3 | 2004 | 200 | mixed | (no details given) | | | | 47,250 | 4.6 | | ✓ | | ✓
P-174 | 2004 | 45 | hematol | CLL | | | | 31,500 | 8.3 | ✓
Chang | 2004 | 254 | solid | breast, stage I–IV | 11.25 | 12 | 14 | 40,000 | 15.2 | ✓ | | | ✓
EPO-CAN-15 | 2004 | 106 | solid | limited disease SCLC | ? >12 | 14 | | 40,000 | 18.9 | | ✓ | | ✓
EPO-CAN-20 | 2004 | 62 | solid | SCLC | | 12 | | 40,000 | 64.5 | | ✓ | ✓
EPO-GBR-07^*^ | 2004 | 300 | solid | H&N, stage I–IV | 13.45 | 12.5 | 15 | 37,500 | 33.6 | | ✓ | | ✓
GOG-191^*^ | 2004 | 113 | solid | cervical cancer | ? >12 | 13 | | 40,000 | 16.4 | ✓ | | | ✓
Vadhan-Raj | 2004 | 59 | solid | gastric or rectal cancer | 13 | 14 | 15 | 40,000 | 3.2 | ✓ | | | ✓
Savonije | 2004 | 315 | solid | solid tumors | 10.75 | | | | 5.8 | ✓
Razzouk | 2004 | 222 | mixed | solid tumors, Hodgkin’s, non- Hodgkin’s | ? 10–12 | | | 42,000 | 1.8 | ✓
O’Shaughnessy | 2005 | 94 | solid | breast ca, stages I–IIIB | 13.9 | 13 | 15 | 40,000 | 0 | | ✓

* Study identified survival as a primary or secondary outcome.

Table C33

KQ1 Outcome V. Tumor Response: Epoetin versus Control

Study ID | Outcome | Response definition | Intervention (Events/sample size) | Control (Events/sample size) | Intervention: other reported measurements | Control: other reported measurements (EPO) | Relative Risk or Hazard Ratio (95% CI) | P-Value | Comments
EPO-GBR-7 | Complete response at week 12 | NR | 108/114 (95%) | 106/111 (95%) | NR | NR | NR | NR | J&J report
EPO-GBR-7 | Overall response (complete and partial response) at week 12 | NR | 113/114 (99%) | 110/111 (99%) | NR | NR | NR | NR | J&J report
N93 004 limited and extensive disease | Complete response after 3 cycles of chemotherapy (primary endpoint) | Complete response: absence of detectable tumor | 18/109 (17%) | 16/115 (14%) | NR | NR | NR | NS | J&J report
N93 004 limited and extensive disease | Overall response (CR plus PR) 3 cycles of chemotherapy | CR plus PR | 79/109 (72%) | 77/115 (67%) | Tumor response rate 73% (64%; 81%) | Tumor response rate 67% (58%; 76%) | NR | NS | J&J report
N93 004 limited and extensive SCLC | Complete response after last cycle of chemotherapy (secondary endpoint) | CR | 20/109 (18%) | 21/115 (18%) | NR | NR | NR | NR | J&J report
N93 004 limited and extensive SCLC | Overall response after last cycle of chemotherapy (secondary endpoint) | CR plus PR | 65/109 (60%) | 64/115 (56%) | NR | NR | NR | Difference (Epo minus placebo) 4 (−9; 17) | J&J report
N93 004 extensive SCLC | Overall response (CR plus PR) 3 cycles of chemotherapy | CR plus PR | 53/72 | 41/68 | | | NR | Difference (Epo minus placebo) 13 (−2; 29) | J&J report
N93 004 limited SCLC | Overall response (CR plus PR) 3 cycles of chemotherapy | CR plus PR | 26/37 | 36/47 | | | NR | Difference (Epo minus placebo) − 6 (−25; 13) | J&J report
N93 004 extensive SCLC | Overall response after last cycle of chemotherapy (secondary endpoint) | CR plus PR | 38/72 | 35/68 | Tumor response rate 53% (41%; 64%) | Tumor response rate 51% (40%; 63%) | NR | Difference (Epo minus placebo) 1 (−15; 18) | J&J report
N93 004 limited SCLC | Overall response after last cycle of chemotherapy (secondary endpoint) | CR plus PR | 27/37 | 29/47 | Tumor response rate 73% (59%; 87%) | Tumor response rate 62% (48%; 76%) | NR | Difference (Epo minus placebo) 11 (−9; 31) | J&J report
Vadhan-Raj 2004 | Tumor response | no definition given | 14/22 | 14/22 | NR | NR | NR | P=0.777 | Machtay 2004, “The tumour response for rectal cancer at MDACC site was similar between both treatment groups with 14/22 (63.6%) in each treatment group (p=0.777)”; Abstract, no definition for tumour response given, analysis not based on ITT population.
Throuvalas 2000 | Complete response | WHO criteria | 22/28 | 18/26 | NR | NR | NR | NR | Throuvalas 2000 and personal communication
Machtay 2004 | Complete response | no definition given | 73% (52/71) | 74% (52/70) | NR | NR | NR | p=0.99 | Abstract slides, no definition given

Table C34

KQ1 Outcome V. Tumor Response: Darbepoetin versus Control

Study ID | Outcome | Intervention Events/sample size | Control Events/sample size | Hazard ratio (95% CI) | P value | Source & comments
Vansteenkiste 2002 | Number progressed during study or follow up | 94/155 | 110/159 | - 1) HR 0.70 (0.53; 0.92); - 2) HR 0.71 (0.54, 0.94) | NR | FDA report, 12 months median follow up;; - 1) Cox proportional hazard, treatment group as independent variable; - 2) adjusted for tumor type and region
Vansteenkiste 2002 | Progression free survival (disease progression or death) | 131/155 | 145/159 | HR 0.81 (0.64; 1.03) | NR | Amgen presentation (FDA ODAC), adjusted for histology, 24 months follow up

Table C35

KQ1 Outcome V. Other Tumor Outcomes: Epoetin versus Control

Author | Outcome | Intervention: Events/sample size | Control: Events/sample size | Relative Risk or Hazard Ratio (95% CI) | p-value | comments
Henke 2003 Stratum I | locoregional tumor progression or death | 47/102 | 41/94 | | | Kaplan Meier estimate, median locoregional progression-free survival in days:EPO: 1,049d, control 1,152d; p=0.9
Henke 2003 Stratum II | locoregional tumor progression or death | 30/39 | 16/38 | | | Kaplan Meier estimate, median locoregional progression-free survival in days: EPO 377d, control 1,791d p=0.001
Henke 2003 Stratum III | locoregional tumor progression or death | 39/39 | 35/39 | | | Kaplan Meier estimate, median locoregional progression-free survival in days: EPO 141d, control 207d, p=0.006
Henke 2003 | locoregional tumor progression or death | 116/180 | 92/171 | RR 1.62 (1.22; 2.14) | p = 0.0008 | ITT population, adjusted for stratum and American Joint Committee on Cancer Stage, 79 and 64 pts respectively were censored. Kaplan Meier estimate, median locoregional progression-free survival in days: EPO 406d, control 745 d, p=0.04
Henke 2003 | time to locoregional tumour progression and survival | NR | NR | RR 1.69 (1.16; 2.47) | P= 0.007 | Full text publication, ITT population, adjusted for stratum and American Joint Committee on Cancer stage. Tumour progression was assumed when tumour size increased by more than 25%.
EPO-GBR-7 | 2 years disease free survival | 52/56 (93%) | 45/53 (85%) | NR | NR | J&J report, only 109 patients evaluated
EPO-GBR-7 | 3 years disease free survival | 13/18 (72%) | 17/21 (81%) | NR | NR | J&J report, only 39 patients evaluated
Machtay 2004 | 1 year progression free survival | 60% (40/67) | 65% (44/68) | LR 1.10 (0.65; 1.89) | p=0.65 | data taken from abstract
Machtay 2004 | time to locoregional failure | 29/71 (failures) | 28/70 (failures) | NR | p=0.72 | data taken from abstract slides
Machtay 2004 | local regional failure free survival | 36/71 (failures) | 33/70 (failures) | NR | p=0.46 | data taken from abstract slides
GOG 0191 | Progression free survival, not reported when assessed | 85% (49/58) | 82% (45/55) | NR | NR | J&J presentation, FDA, ODAC
EPO-CAN-15 | Median time to progression | 467 days | 419 days | NR | NR | J&J presentation, FDA, ODAC

Table C36

KQ1 Outcome V. Other Chemotherapy Details: Epoetin versus Control

Study | cancer details | chemotherapy category | details on therapy | duration of therapy | when and how tumor response assessed | further comments
EPO-CAN-15 | limited disease SCLC | Chemo - plat all + radio, categorized as chemo_radio | “combined modality chemoradiation therapy” | not reported | not reported
EPO-GBR-7 | head and neck, stage I-IV | radiotherapy | radiotherapy with curative intent | not reported | Local tumor evidence was assessed at weeks 1,4,8 after radiotherapy and years 1, 2, 3, and 5 during follow-up
GOG-0191 | cervical carcinoma | chemo-plat all + radio, categorized as chemo_radio | concurrent radiation and cisplatin | not reported | not reported
N93-004 | SCLC, limited and extensive disease | Platinum based chemotherapy, first line therapy | etoposide plus cisplatin, no details on dosages reported | not reported | The optimal method for assessing tumor response in each patient was determined by the investigator. | TR was assessed at baseline, after the third cycle of chemotherapy, at end of study or the termination visit. The same imaging or measurement method and indicator lesions were to be used for each assessment.
Vadhan-Raj 2004, PR00-03-006 | gastric or rectal ca | chemo-radio non-plat, categorized as chemo_radio | fluoropyrimidine concurrent with radiation | not reported
Henke 2003 | advanced (stage III, IV) head and neck | Radiotherapy after surgical resection, 22% (78/351) of patients radiotherapy only | 60 Gy (range 56 to 64 Gy) to regions for R0 or R1; 70 Gy (range 66–74 Gy) to regions for R2 (macroscopically incompletely respected tumour) or primary definitive treatment. The spinal cord was shielded after 30–36 Gy. | Five fractions of 2.0 Gy per week or five fractions of 1.8 Gy per week.
Throuvalas 2000 | cervix and bladder carcinoma | Chemo – plat all + radio, categorized as chemo_radio therapy | carboplatin 90mg/m^2^ plus radiotherapy 2 Gy/day to the pelvis | 5–6 weeks | 2 months post therapy and confirmed one month later
Machtay 2004 | head and neck non-metastatic, non resected | categorized as chemo_radio, but unclear if only radiotherapy | radiotherapy (66–72 Gy), unclear whether patients received also cisplatin | not reported | median follow up 12 months

Table C37

KQ1 Outcome VI. Thromboembolic complications: Epoetin versus Control

Study ID
Hb </= 10 g/dL | Treatment n | Treatment N | Percentage % | Control n | Control N | Percentage %
Cascinu 1994 | 0 | 50 | 0.00% | 0 | 50 | 0.00%
Case J&J | 2 | 81 | 2.47% | 3 | 76 | 3.95%
Dammacco J&J | 5 | 69 | 7.25% | 1 | 76 | 1.32%
Henry J&J | 6 | 67 | 8.96% | 8 | 65 | 12.31%
Littlewood J&J | 14 | 251 | 5.58% | 5 | 124 | 4.03%
Osterborg 1996a | 2 | 47 | 4.26% | 0 | 25 | 0.00%
Osterborg 1996b | 1 | 48 | 2.08% | 0 | 24 | 0.00%
Osterborg 2002 | 1 | 170 | 0.59% | 0 | 173 | 0.00%
Razzouk 2004 | 6 | 112 | 5.36% | 2 | 110 | 1.82%
Rose J&J | 9 | 142 | 6.34% | 2 | 79 | 2.53%
Witzig J&J | 9 | 168 | 5.36% | 6 | 165 | 3.64%
Hb 10 to 12 g/dL | Treatment n | Treatment N | Percentage % | Control n | Control N | Percentage %
Bamias 2003 | 0 | 72 | 0.00% | 1 | 72 | 1.39%
Chang 2005 | 19 | 175 | 10.86% | 14 | 175 | 8.00%
Henke 2003 | | | | | | 3.51%
Roche | 10 | 180 | 5.56% | 6 | 171
Savonije 2004 | 9 | 211 | 4.27% | 1 | 104 | 0.96%
Ten Bokkel 1998a | 2 | 45 | 4.44% | 0 | 17 | 0.00%
Ten Bokkel 1998b | 4 | 42 | 9.52% | 0 | 16 | 0.00%
Throuvalas 2000 | 1 | 28 | 3.57% | 0 | 26 | 0.00%
Vadhan-Raj FDA | 7 | 29 | 24.14% | 2 | 31 | 6.45%
Hb > 12 g/dL | Treatment n | Treatment N | Percentage % | Control n | Control N | Percentage %
EPO-GBR-7 FDA | 5 | 151 | 3.31% | 1 | 149 | 0.67%
Leyland-Jones J&J | 36 | 448 | 8.04% | 25 | 456 | 5.48%
Machtay 2004 | 2 | 71 | 2.82% | 0 | 70 | 0.00%
Thatcher 1999a | 0 | 42 | 0.00% | 0 | 22 | 0.00%
Thatcher 1999b | 2 | 44 | 4.55% | 0 | 22 | 0.00%
Welch 1995 | 1 | 15 | 6.67% | 0 | 15 | 0.00%
unclear | Treatment n | Treatment N | Percentage % | Control n | Control N | Percentage %
EPO-CAN-15 FDA | 16 | 53 | 30.19% | 2 | 53 | 3.77%
EPO-CAN-20 J&J | 1 | 31 | 3.23% | 2 | 31 | 6.45%
GOG-0191 FDA | 9 | 58 | 15.52% | 3 | 55 | 5.45%
INT-1 J&J | 3 | 164 | 1.83% | 1 | 80 | 1.25%
INT-3 J&J | 8 | 135 | 5.93% | 1 | 65 | 1.54%
N93 004 FDA | 24 | 109 | 22.02% | 26 | 115 | 22.61%
P-174 J&J | 0 | 33 | 0.00% | 0 | 12 | 0.00%
Rosenzweig 2004 | 4 | 14 | 28.57% | 0 | 13 | 0.00%

Table C38

KQ1 Outcome VI. Thromboembolism data sources: Epoetin versus Control

Study | Full text/abstract | | FDA report | | J&J report | | Roche report | | Clinical study report
| EPO event/sample size | Control event/sample size | EPO event/sample size | Control event/sample size | EPO event/sample size | Control event/sample size | EPO event/sample size | Control event/sample size | EPO event/sample size | Control event/sample size
EPO-CAN-15 | - | - | 16/53 | 2/53 | 16/53 | 2/53 | - | -
EPO-CAN-20 | - | - | “low rates in both arms” | | 1/31 | 2/31 | - | -
GBR-07 | - | - | 5 (3%) denominator not reported but assumed to be 151 | 1 (1%) denominator not reported but assumed to be 149 | 4/133 (n should be 151) | 2/149
GOG-191 | - | - | 9/58 | 3/55 | 10/58 | 5/55
Henke | 20/180 (including hypertension) | 9/171 (including hypertension) | - | - | - | - | 10/180 | 6/171
Leyland-Jones | 1% (5/469) | 0.2% (1/470) | 11/469 (death due to TE) | 2/470 (death due to TE) | 36/448 | 25/456
Machtay | 1/67, slides: 2/71 | 0/68, slides: 0/70 | - | - | 1/67 | 0/68 | - | -
N93004 | - | - | 24/109 | 26/115 | 12/109 | 11/115 | - | -
Witzig | 8/168 | 5/165 | - | - | 9/168 | 6/165
Vadhan-Raj | 6/28 | 1/31 | 7/29 | 2/31 | 6/28 | 1/31
Littlewood | - | - | - | - | 14/251 | 5/124 | - | - | 17/251 | 8/124
Case | 4/81 | 4/76 | | | 2/81 | 3/76
Henry | 6/67 | 2/65 | | | 6/67 | 8/65

Table C39

KQ1 Outcome VII. Other adverse events -- Hypertension: Epoetin versus Control

Study ID | Treatment n | Treatment N | Percentage | Control n | Control N | Percentage | Definition of Hypertension
Bamias 2003 | 2 | 72 | 2.78% | 0 | 72 | 0.00% | not reported or available from detailed results
Cascinu 1994 | 0 | 50 | 0.00% | 0 | 50 | 0.00% | not reported or available from detailed results
Case 1993 | 4 | 81 | 4.94% | 2 | 76 | 2.63% | not reported or available from detailed results
Dammacco 2001 | 3 | 69 | 4.35% | 1 | 76 | 1.32% | not reported or available from detailed results
Henry 1995 | 2 | 67 | 2.99% | 4 | 65 | 6.15% | not reported or available from detailed results
Iconomou 2003 | 0 | 61 | 0.00% | 0 | 61 | 0.00% | not reported or available from detailed results
Kunikane 2001a | 3 | 22 | 13.64% | 4 | 17 | 23.53% | WHO grade ≥1; grade 1 = asymptomatic, transient ↑ >20 mm Hg or to >150/100; defined in published report
Kunikane 2001b | 2 | 21 | 9.52% | | | | WHO grade ≥1; grade 1 = asymptomatic, transient ↑ >20 mm Hg or to >150/100; defined in published report
Littlewood 2001 | 9 | 251 | 3.59% | 1 | 124 | 0.81% | not reported or available from detailed results
Osterborg 1996a | 4 | 47 | 8.51% | 1 | 49 | 2.04% | not reported or available from detailed results
Osterborg 1996b | 5 | 48 | 10.42% | | | | not reported or available from detailed results
Rosenzweig 2004 | 1 | 14 | 7.14% | 0 | 13 | 0.00% | not reported or available from detailed results
Silvestris 1995 | 4 | 30 | 13.33% | 0 | 24 | 0.00% | not reported or available from detailed results
Ten Bokkel 1998a | 4 | 43 | 9.30% | 1 | 28 | 3.57% | systolic >180 mm Hg & >30 mm ↑ from baseline or diastolic >100 mm & 15 mm ↑ from baseline; defined in published report
Ten Bokkel 1998b | 7 | 37 | 18.92% | | | | systolic >180 mm Hg & >30 mm ↑ from baseline or diastolic >100 mm & 15 mm ↑ from baseline; defined in published report
Thatcher 1999a | 2 | 42 | 4.76% | 0 | 44 | 0.00% | systolic >180 mm Hg or diastolic >105 mm; from detailed results in published report; unknown whether any patients had systolic pressure >120 but <180
Thatcher 1999b | 1 | 44 | 2.27% | | | | systolic >180 mm Hg or diastolic >105 mm; from detailed results in published report; unknown whether any patients had systolic pressure >120 but <180
Welch 1995 | 2 | 15 | 13.33% | 0 | 15 | 0.00% | systolic >140 mmHg; from detailed results in published report
Rose 1994 | 86 | 142 | 60.56% | 50 | 79 | 63.29% | systolic >140 mm Hg or diastolic >95 mmHg; from trial sponsor’s clinical study report
Alternative data
Dammacco 2001 | 43 | 69 | 62.32% | 36 | 76 | 47.37% | systolic >150 mmHg or diastolic >100 mmHg; data from trial sponsor’s clinical study report
Rose 1994 | 80 | 142 | 56.34% | 47 | 79 | 59.49 | systolic >140 mm Hg; from trial sponsor’s clinical study report
Rose 1994 | 6 | 142 | 4.23% | 3 | 79 | 3.80% | diastolic >95 mmHg; data from trial sponsor’s clinical study report

Table C40

KQ1 Outcome VII. Other adverse events -- Thrombocytopenia: Epoetin versus Control

Study ID | Treatment n | Treatment N | Percentage (%) | Control n | Control N | Percentage (%)
Bamias 2003 | 2 | 72 | 2.78% | 0 | 72 | 0.00%
Boogaerts 2003 | 8 | 133 | 6.02% | 13 | 129 | 10.08%
Cascinu 1994 | 0 | 50 | 0.00% | 0 | 50 | 0.00%
Dammacco 2001 | 5 | 69 | 7.25% | 5 | 76 | 6.58%
Del Mastro 1997 | 4 | 31 | 12.90% | 4 | 31 | 12.90%
Kunikane 2001a | 12 | 22 | 54.55% | 3 | 17 | 17.65%
Kunikane 2001b | 7 | 21 | 33.33%
Littlewood 2001 | 18 | 251 | 7.17% | 9 | 124 | 7.26%
Osterborg 1996a | 3 | 47 | 6.38% | 2 | 49 | 4.08%
Osterborg 1996b | 0 | 48 | 0.00%
Thatcher 1999a | 11 | 42 | 26.19% | 9 | 44 | 20.45%
Thatcher 1999b | 9 | 44 | 20.45%

Table C41

KQ1 Outcome VII. Other adverse events -- Rash: Epoetin versus Control

Study ID | Treatment n | Treatment N | Proportion | Control n | Control N | Proportion
Del Mastro 1997 | 2 | 31 | 6.45% | 0 | 31 | 0.00%
Henry 1995 | 7 | 67 | 10.45% | 2 | 65 | 3.08%
Kurz 1997 | 0 | 12 | 0.00% | 0 | 12 | 0.00%
Osterborg 1996a | 1 | 47 | 2.13% | 0 | 49 | 0.00%
Osterborg 1996b | 1 | 48 | 2.08% | 0
Thatcher 1999a | 5 | 42 | 11.90% | 4 | 44 | 9.09%
Thatcher 1999b | 1 | 44 | 2.27%
Welch 1995 | 1 | 15 | 6.67% | 0 | 15 | 0.00%

Table C42

KQ1 Outcome VII. Other adverse events -- Seizures: Epoetin versus Control

Study ID | Treatment n | Treatment N | Proportion | Control n | Control N | Proportion
Cascinu 1994 | 0 | 50 | 0.00% | 0 | 50 | 0.00%
Case 1993 | 2 | 81 | 2.47% | 2 | 76 | 2.63%
Henry 1995 | 3 | 67 | 4.48% | 2 | 65 | 3.08%

Table C43

KQ2: Study Characteristics, Part I

study author | participants randomized | Drug | Intervention (Early) | Control Late | weight based or fix | Maximum duration of EPO medication (weeks) | dose adjustment | iron | transfusion trigger (when transfusion assessed) | publication | primary and secondary outcomes of the study
KQ2 Comparison I. Different Weight-Based Doses
Kunikane 2001 | 72 Evaluable: A) 16 B) 18 0: 19 | Epoetin beta | A) 100 IU/Kg tiw B) 200 IU/kg tiw | Placebo | Weight | 8 | Stopping: if Hb >16 g/L (men) or >14 g/dl (women) drug was stopped | NR | NR | Full-text | Hb, Transfusions
Ten Bokkel 1998 | 122 A) 45 B) 42 o) 33 | Epoetin beta | A) 150 IU/kg tiw B) 300 IU/kg tiw | No Placebo | Weight | Through duration of chemo plus 3–24 weeks depending duration of chemo | Decreasing: if Hb increased ≥2 g/dl dose was reduced by 50%. If Hb level >15g/dl. Drug stopped until Hb <14g/dl | As necessary | Usually if Hb < 9.7 g/dl | Full-text, unpublished | RBCT, TR, AE
Thatcher 1999 | 130 A) 44 B) 42 o) 44 | Epoetin alfa | A) 150 IU/kg tiw B) 300 IU/kg tiw | No Placebo | Weight | 26 | Decreasing: if Hb exceeded 15 g/dl Drug stopped and restarted with 50% if Hb <13 g/dl. | As necessary | Usually if Hb ≤ 10 g/dl | Full-text, unpublished | Hb, RBCT, QoL, AE
Glaspy 2002 | 160 A) 33 B) 31 C) 32 D) 32 Epo: 32 | Darbepoetin alfa | A) 3,0 μg/kg Q2W B) 5,0 μg/kg Q2W C) 7,0 μg/kg Q2W D) 9,0 μg/kg Q2W | 40000 iU Epo alfa | Darb weight based, Epoetin fixed | 12 | Only Epoetin Increasing: if Hb increase < 1.0 g/dl at wk 6 EPO increased to 60,000 IU QW | NR | NR | Full-text | Hb response, Hb change, transfusions, QoL, Safety, Antibodies
Hedenus 2002 | 66 A) 11 B) 22 C) 22 O: 11 | Darbepoetin | A) 1.0 μg/kg QW B) 2.25 μg/kg QW C) 4.5 μg/kg QW | Placebo | Weight | 12 | Decreasing: if Hb increase >2 g/dl in 4 wks drug reduced by 50%, if Hb level >15 g/dl (men) or 14 g/dl (women) drug stopped and reinstated at 50% if Hb <13 g/dl | As necessary | Hb <8g/dL | Full-text | Dose response Hb response, Hb change, RBC transfusion
Kotasek 2003 | 259 A) 32 B) 17 C) 46 D) 28 E) 35 F) 40 O: 51 | Darbepoetin | A) 4.5 μg/kg Q3W B) 6.75 μg/kg Q3W C) 9 μg/kg Q3W D) 12 μg/kg Q3W E) 13.5 μg/kg Q3W F) 15 μg/kg Q3W | Placebo | Weight | 12 | Increasing not allowed, decreasing: if Hb increased >15 g/dl (men) or >14 g/dl (women) drug stopped and reinstated at a lower dose level if Hb <13 g/dl | NR | NR | Full-text | Hb response, Hb change, transfusions, QoL, Safety, Antibodies
KQ2 Comparison II. Different Fixed Doses
Cazzola 1995 | 146 Treatment: A) 31 B) 29 C) 31 D) 26 0: 29 | Epoetin beta | A) 1000 daily B) 2000 daily C) 5000 daily D) 10000 daily | No treatment | Fix | 8 | Decreasing: if Hb increased >2 g/dl OR Hb level >12.5 g/dl dose was reduced from 7x to 3x per week. If Hb >13 g/dl (MM) or >15 g/dl (NHL) drug was stopped | If serum iron or transferrin saturation below normal limit => Iron (oral) | At discretion of physician | Full-text | HR, Hb, RBCT, AE
Glimelius 1998 | 84 A) 41 B) 43 | Epoetin alfa | 10000 tiw | 2000 tiw | FIX | 18 | Not allowed. Stop if Hb > 14,5 g/dl | As Necessary | If Hb < 8,5 mg/dl at discretion of physician | Full-text | Increase Baseline HB Level (Response defined as increase over baseline by greater than 1 g/dl. Failure decrease >1 g/dl) or need of RBC transfusions Safety QoL
Johansson 2001 | 180 A) 90 B) 90 | Epoetin beta | 5000 tiw | 1000 tiw | FIX | 12 | Dose doubled in high dose group if Hb increased<1,5 after week4 or <2 after week8. In both if Hb >14 treatment withdrawn until Hb <13. Then twice a week. | Fix 200 mg/d oral | By investigators physicians | Paper | Hb Response defined as increase ≥ 1,5 g/dl and also ≥2 g/dl. Hb level (after w 4/8/12) Patients required Transfusion Transfused Volume Adverse events / Safety QoL (EORTC QoL30)
Ollson 2002 | 180 A) 90 B) 90 | Epoetin beta | 5000 tiw. | 1000 tiw | FIX | 24 | Increase in high dose group if Hb increased<1 g/dl after week4 or <2 after week8. In both if H >15 treatment withdrawn until Hb <14. Then twice a week. If Hb >14 D. twice /w | Regardless S-ferritin − 200-mg/d oral. | By investigators physicians | Paper | Hb Response defined as increase ≥ 2 g/dl ;also for I > 1g/dl. Hb mean level (after w 4/8/12/16/20/24) Need for transfusion Safety QoL (EORTC QoL30)
Sakai 2004 | 86 A) 28 B) 29 C) 29 | Epoetin beta | A) 9000 QW B) 18000 QW C) 36000.QW | No placebo | FIX | 12 | Withheld if Hb >14g/dl (restarted if Hb <12) | Oral fix | NR | Abstract | Increase in Hb concentration at last evaluation Percentage Hb > 2/gdl Transfusion requirements Adverse effects QoL (Fact-An)
KQ2 Comparison III. Weight-Based versus Fixed-Dose Regimens
Granetto 2003 | 546 A) 268 B) 264 | Epoetin alfa | 10000 tiw (If patient weight: <45 kg => 5000 tiw, if >100kg => 15000 tiw) | 150/ kg tiw | FIX vs. weight | 12 | I: Double Dose after 1^st^ chemotherapy Hb increase <1 or Reticulocyte <40000/μl D) by 25% if Hb increase ≥2/m Stop by Hb >14 until <12 than reinstated with 75 % Dose. | If transferrin saturation < 20% | Hb < 8g/dl | Paper | Transfusion (RBC or whole blood) requirements over days 29–84 (proportion of pt) Change in Hb Level from baseline Proportion of patients who responded to Epoetin (complete if Hb ≥2 g/dl without transfusion after 4 w; partial HB change 0–2 g7dl without transfusion 4w) CLAS / LASA
Hesketh 2004 | 243 | Darbep oetin | 325 μg Q1W | 4,5 μg /kg Q1W | FIX vs. weight | 16 | After correction of Anemia ≥12 g/dl reduction to Q3W = Maintain Phase Therapy withheld if Hb>15(men) or >14(women) Reinstated with 200μg / 3μg/kg if Hb <13. | By investigat ors physician | By investigators physicians Recommenda tion Hb < 8g/dl | Paper | Hem. response defined as increase ≥ 2 g/dl or a concentration ≥ 12 g/dl in absence of RBC transfusion within previous 28 d Time required to achieve Hb Response Transfusion (RBC) requirements from week 5 (proportion of pt) RBC units Safety
KQ2 Comparison IV. More-versus Less-Frequent Dosing
Cazzola 2003 | 241 A) 119 B) 122 | Epoetin beta | 30000 QW | 10000 tiw | FIX | 16 | Double Dose if Hb Increase ≤ 0,5 g/dl. After week 4 or RBCT. Decrease (50%Dose) if Hb Increase ≥2 g/dl. Stop if Hb >14 reinstated with 50% reduced Dose if Hb <13. | Iron (I.V.) if transferrin saturation < 20%. | If necessary Hb< 8,5g/dl | Paper | Time-adjusted Hb between w5 and w16 (Hb AUC) if HRBC transfused adjusted results obtained. Hb Response ≥2 g/dl vs. baseline without transfusion Portion of pat correct anemia ≥11 or ≥12 Severe anemia ≥8, 5 Transfusion free Transfusion requirements Survival Adverse effects
Steensma 2005 | 365 A) 183 B) 182 | Epoetin | After period of fix treatment with 3 x 40000 IU Epo then 120000 Epo Q3W | After period of fix treatment with 3 x 40000 IU continuing Epo 40000 Epo QW | FIX | 21 weeks (incl 3 week same qw treatment) | NR | 325 mg oral qw FIX | NR | Abstract | Proportion of pts requiring transfusion. Hb increment from baseline= Response ≥2 g/dl and ≥ 3g/dl vs. baseline Final Hb Survival adverse effects
KQ2 Comparison V. Front-Loaded versus Reduced or Constant Dosing
Glaspy 2003 | 127: A)32 B)32 C)32 Epo:31 | Darbepoetin (control Epoetin) | A) 4.5 μg/kg/w until Hb > 12 g/dl, then 1.5 μg/kg/wk up to week 12 B) 4.5 μg/kg/w, then 8 x 2.25 μg/kg/w C) 4 x 4.5 μg/kg/w, then 8 x 3 μg/kg/Q2W | 40000 iU Epo alfa | Darbepo weight based, Epoetin fixed | 12 | For Darbepo: Withheld if Hb level > 15.0 g/dl (m) or 14 g/dl (w); If Hb < 13 g/dl drug reinstated at 75% Dose. Control (Epo) increasing: if Hb increase < 1.0 g/dl at week 4 EPO increased to 60,000 IU QW | NR | Hb≤8 g/dl | Full-text | Mean change in Hb level Proportion of patients with Hb response ≥2 g/dl vs. baseline without transfusion last 6 weeks Time to Hb response Safety (sum Adverse Events) QoL (FACT-F)
Kotasek 2004 | 727 A) 356 B) 367 | Darbepoetin | 4,5 μg/ kg QW (week 1–4) Q3W (week 5–16) | 2,25 μg/ kg QW | Weight | 16 | Only in Control If Hb response week 6 < 1/gdl or RBC Transfusion dose Doubled. | NR | NR | Abstract (Poster) | Red blood cell transfusion (from Week 5 to end of treatment) or withdrawal from study during the 16-week treatment period (aside from death and disease progression) Proportion of patients receiving transfusion during treatment phase. Time to Hb response Increase in Hb level ≥ 2 g/dl from baseline Safety
KQ2 Comparison VI. Titrated versus Constant Dosing
Österborg 1996 | 144 A) 47 B) 48 o) 49 | Epoetin beta | A) Fix 10000 iU Q7W B) Titration: Stat Dose 2000 iU (for 8w) if then Hb<11g /dl =>5000 Q7W; if week 12 Hb<11 g/dl => 10000 (Q7W) | No Placebo | FIX / vs. Titration | 24 | If Hb > 13 (women) or 14 (men) dose stopped until Hb decrease < 1 g/dl than restarted at reduced frequency. Non responders (Pt with transfusion need after 12w therapy with 10000 Dose) withdrawn | NR | Hb < 10 g/dl | Full-text Unpublished | HR, Hb, RBCT, AE
KQ2 Comparison VII. Intravenous versus Subcutaneous Dosing
Justice 2005 | 120 A) 59 B) 59 | Darbepoetin alfa | 4,5mcg/kg intravenous QW until week6 then Q3W | 4, 5mcg/kg subcutaneous QW until week6 then Q3W | Weight | 18 | Withheld if Hb ≥ 14g/dl (women) 15 (men), reinstated Q3W if HB ≤13g/dl. | At discretion of investigator or study center | If Hb < 8 g/dl or if symptoms of anemia present | Full-text | Hem. Response HB≥12 g/dl or I ≥2 g/dl Reaching Hb Target 11 g/dl Mean change Hb RBC Transfusions Safety

Table C44

KQ2: Study Characteristics, Part II

study author | n randomized | cancer details | cancer category | therapy | Hb eligibility criteria [g/dl] | Hb baseline Early [mean g/dl (SD)] | Hb baseline Late arm [mean g/dl (SD)] | Hb category | Age Early arm [mean (SD)] if not stated otherwise | Age Late arm [mean (SD)] if not stated otherwise | age category (children adults elders (>65)
KQ2 Comparison I. Different Weight-Based Doses
Kunikane 2001 | 72 | Lung | Solid | Platinum based chemotherapy | Hb 9.0–13 g/dl | A) 12,3 (SD1,2) B) 12,3 (SD1,4) | 12,0 (SD 0,9) | 12 | A) 62,7 (SD 8,7) B) 62,7 (SD 4,8) | 59,5 (SD 9,9) | Adults
Ten Bokkel 1998 | 122 | ovarian, stage II–IV | Solid | Platinum based chemotherapy | Hb ≤ 13gdl | Median / Range A) 12.0 (11.3–12.6) B)11.6 (10.5–12.2) | Median / Range 11.8 (10.6–12.5) | A10–12 | A) 58.51 B) 60,97 | 58.83 | Adults
Thatcher 1999 | 130 | SCLC | solid | Platinum based chemotherapy (89% of patients)* | Hb > 10.5 g/dl | A) 13.4 (SD 1.3)* B) 13.5 (SD 1.3)* | 13.4 (SD 1.3)* | 12 | A) 59 (43–72 B) 58.5 (30–72) | 60 (39–74) | Adults
Glaspy 2002 | 160 | Breast, GI, lung, other | Solid | Chemotherapy | Hb <11 g/dl | 9.82 (SD 0.95) 9.8 (SD 1,0) For (A-D reported) | 9.73 (SD 1.17) 9,7 (1,2) | 10 | 64.3 (SD 12.0) For (A-D reported) | 63.9 (SD 12.3) | Adults
Hedenus 2002 | 66 | Malignant lymphoma (HD, NHL, CLL, MM) | Hematological | Chemotherapy | Hb ≤ 11.0 g/dl | A) 9,74 (SD 0,82) B) 9,4 (SD 1,25) C) 9,7 (SD 0,85) | 9.54 (SD 0,95) | 10 | Median/Range A) 63 (25–80) B) 64 (26–80) C) 70 (52–84) | Median 63 (25–80) | Adults
Kotasek 2003 | 259 | Breast, gyne, gastrointestinal, lung, other | Solid | Chemotherapy, not reported if with or without platinum, interpreted as some platinum) | Hb ≤ 11.0 g/dl | 9.93 (SD 1.0) (Reported for A-F, F slightly higher 10,4) | 9.87 (SD 1.12) | 10 | 58.3 (SD 11.9) | 56,2 (SD 12,4) | Adults
KQ2 Comparison II. Different Fixed Doses
Cazzola 1995 | 146 | Malignant lymphoma (MM, NHL) | Hematological | Chemotherapy | Hb ≤ 11 g/dl independent of transfusion | A) 9,3 (SD 0,9) B) 9,4 (SD 0,9) C) 9.4 (SD 1.2) D) 9.4 (SD 1.0) | 9.5 (SD 1.1) | 10 | A) Median 67 (48–82) B) Median 65 (40–82) C) Median 68 (42–85) D) median 63 (28–80) | Median 68 (28–80) | Adults
Glimelius 1998 | 83 | Gastric 20 Pancreatic 10 Biliary 6 Colon 48 | Solid | Chemotherapy | m <13 g/dl w<11,5 g/dl | 10,9 (1,0) | 10,8 (1,0) | 10–12 | Mean 61 31–78 | Mean 61 34–79 | Adults
Johansson 2001 | 180 | Hormone refractory prostate cancer | Solid | Mixed (antitumor not further stated) | Hb ≤ <10,5g/dl | 9,1 (+−0,9) | 9,2 (+− 0,8) | 10 | Mean 71 (+−8) | Mean 72 (+−7) | Categorized as Elderly
Ollson 2002 | 180 | Metastatic breast cancer | Solid | Mixed | Hb ≤ <11,0g/dl | 9,8 (Range 6,4 – 11,0) | 9,9 (Range 7,7 – 11,1) | 10 | 57 (range 35– 83) | 58 (Range 30–82) | Adults
Sakai 2004 | 86 | Lung cancer Malignant Lymphoma | Mixed | Chemotherapy | Hb ≤ <11,0g/dl | NR | NR | 10 | A) 60,5 B) 63,0 C) 61,9 | NR | Adults
KQ2 Comparison III. Weight-Based versus Fixed-Dose Regimens
Granetto 2003 | 546 | Lung: 33,3%/33,3% Gynecological: 29,4%/31,8% Other: 37,3%/34,9% | Solid | Chemotherapy (platinum) | Hb ≤ 10,5 g/dl or on chemotherapy Hb ≥ 12 with but ≥ 10,5 chemotherapy following decrease ≥ 1, 5 | 9,61 (1,02) | 9,65 (1,05) | 10 | Mean 61,8 (SD 10,5) | Mean 61,1 (SD 10,0) | Adults
Hesketh 2004 | 243 | Breast GIT Genitourinary Gynecologic Lung Lymphoproliferative | Mixed | Chemotherapy | Hb ≤ 11g/dl | 10,2 (SD 1,0) | 10,2 (SD 0,9) | A10–12 | Mean 63,2 (SD 13,3) | Mean 60,4 (SD 13,3) | Adults
KQ2 Comparison IV. More- versus Less-Frequent Dosing
Cazzola 2003 | 241 | MM NHL CLL | Hematological | Chemotherapy | 9–11 g/dl | 10,2 (1,0) | 10,1 (1,0) | 10 | 38–82 Median 67 | 33–90 Median 65 | Adults
Steensma 2005 | 365 | NR (Pts eligible if they need not to be receiving active anti-neoplastic therapy) | unclear | 89 % of pts receiving anti- neoplastic therapy. Type unclear | Men <12 g/dl; women <11g/dl | NR | NR | unclear | NR | NR | unclear
KQ2 Comparison V. Front-Loaded versus Reduced or Constant Dosing
Glaspy 2003 | 127 | Breast GiT Lung Others | Solid | Chemotherapy | Hb ≤ 11 g/dl | A) 9,54 (SD1, 12) B) 9,90(SD1, 02) C) 9,90 (SD0, 99) | Epoetin: 9,84 (SD 0,83) | 10 | A) 60,5 (SD 14,1) B) 66,4 (SD 12,7) C) 62,7 (SD 13,2) | Epoetin: 63,5 (SD 8,7) | Adults
Kotasek 2004 | 727 | Hematological Lung Breast Other solid | Mixed | Chemotherapy | Hb ≤ <11,0g/dl | 9,6 (SD1,0) | 9,6 (SD1,0) | 10 | 61,0 (SD13,0) | 61,9 (12,8) | Adults
KQ2 Comparison VI. Titrated versus Constant Dosing
Österborg 1996 | 144 | malignant lymphoma (MM, NHL, CLL) | Hematological | Chemotherapy | Hb ≤ 10gdl | A) median 8.0 (range 6.2–10.1) B) median 8.0 (range 5.5–10.3) | median 8.1 (range 5.2–9.8) | 10 | 66(43–84) 65 (38–82) | 64 (36–83) | Adults
KQ2 Comparison VII. Intravenous versus Subcutaneous Dosing
Justice 2005 | 120 | Lung Breast Gastrointestinal Gynecological Myeloproliferative Other | Mixed | Chemotherapy (50% Platinum) | Hb ≤≤ 11 g/dl | 9,5(SD0,8) | 9,6 (SD 0,9) | 10 | 63,9 (SD13,6) | 63,1 (SD12,6) | Adults

Table C45

KQ2: Study Quality

study author | random | allocation | blinding | placebo | ITT or 10% | similar | high or low quality
KQ2 Comparison I. Different Weight-Based Doses
Kunikane 2001 | yes | yes (central randomization service) | double blind | no placebo | no | yes | low
Ten Bokkel 1998 | yes | yes | open label | no placebo | ITT or 10% | yes | low
Thatcher 1999 | unclear | unclear | open label | no placebo | ITT | yes | low
Glaspy 2002 | unclear | unclear | no | no placebo | ITT or 10% | yes | low
Hedenus 2002 | yes | yes (central randomization service) | double blind | placebo | ITT | yes | high
Kotasek 2003 | unclear | unclear | double blind | placebo | yes for safety, not sure for transfusion | Yes (Except a slightly higher proportion of patients in the 12 μg group had breast cancer (61%) compared with the other groups, which ranged from 15 to 38%. I 12 μg group had also a slightly higher mean Hb at baseline (10.4 g/d, compared with the other groups (9.7 to 10.2). | high
KQ2 Comparison II. Different Fixed Doses
Cazzola 1995 | yes | unclear | no | no placebo | ITT or 10% | yes | low
Glimelius 1998 | yes | unclear | no | no | ITT | yes | low
Johansson 2001 | unclear | unclear | open label | no | ITT | yes | low
Ollson 2002 | yes | yes | open label | no | ITT > 10% | yes | low
Sakai 2004 | unclear | unclear | double blind | no | > 10 % | yes (except reduced serum Epo concentration in 36000 Group. Double serum ferritin in 9000 Group | low
KQ2 Comparison III. Weight-Based versus Fixed-Dose Regimens
Granetto 2003 | unclear | unclear | double blind | no | ITT or > 10 % | yes | low
Hesketh 2004 | yes | unclear | no | no | ITT or 10 % | Yes (at baseline) Therapy decisions about Fe/RBC not reported | low
KQ2 Comparison IV. More- versus Less-Frequent Dosing
Cazzola 2003 | unclear | unclear | no | no | ITT | yes | low
Steensma 2005 | unclear | unclear | No | No | unclear | unclear | low
KQ2 Comparison V. Front-Loaded versus Reduced or Constant Dosing
Glaspy 2003 | unclear | unclear | no | No placebo | ITT or 10% | yes | low
Kotasek 2004 | unclear | unclear | double blind | yes (for schedule) | ITT | yes | low
KQ2 Comparison VI. Titrated versus Constant Dosing
Österborg 1996 | yes | yes | no | no | ITT | yes | low
KQ2 Comparison VII. Intravenous versus Subcutaneous Dosing
Justice 2005 | yes | unclear | open label | no | ITT or <10% | yes | low

Table C46

KQ2: Hematologic Response

study author | Hb response definition | Early (n) | Early (N) | Percentage (%) | Late (n) | Late (N) | Percentage (%) | Comments
KQ2 Comparison I. Different Weight-Based Doses
Glaspy 2002 Group A | Hb increase of 2 g/dl independent of transfusion in the previous 28 days | 20 | 33 | 60.61% | 19 | 32 | 59.38% | A) 3 μg/kg Q2W Darb, K-M percentages 60% (39; 80), EPO: 60% (40; 79)
Glaspy 2002 Group B | | 25 | 31 | 80.65% | | | | B) 5 μg/kg Q2W Darb, K-M percentages 79% (56; 100)
Glaspy 2002 Group C | | 18 | 32 | 56.25% | | | | C) 7 μg/kg Q2W Darb, K-M percentages taken from figure: 55%
Glaspy 2002 Group D | | 21 | 32 | 65.63% | | | | D) 9 μg/kg Q2W Darb, K-M percentages taken from figure: 67%
Hedenus 2002 Group A | Hb increase of 2 g/dL independent of transfusion in the previous 28 days | 5 | 11 | 45.45% | 1 | 11 | 9.09% | Absolute numbers were derived using Kaplan-Meier method; A) 45% N=11, control 10%, N=11
Hedenus 2002 Group B | | 12 | 22 | 54.55% | | | | B) 55%, N=22
Hedenus 2002 Group C | | 14 | 22 | 63.64% | | | | C) 62%, N=22
Kotasek 2003 Group A | Increase ≥ 2 g/dl from baseline, in absence of previous RBCT in previous 28 d | 8 | 32 | 25.00% | 7 | 51 | 13.73% | Derived using Kaplan-Meier method; arm A) 24%, N=32, control 14%, N=51
Kotasek 2003 Group B | | 8 | 17 | 47.06% | | | | B) 48%, N=17
Kotasek 2003 Group C | | 23 | 46 | 50.00% | | | | C) 50%, N=46
Kotasek 2003 Group D | | 17 | 28 | 60.71% | | | | D) 62%, N=28
Kotasek 2003 Group E | | 20 | 35 | 57.14% | | | | E) 58%, N=35
Kotasek 2003 Group F | | 20 | 40 | 50.00% | | | | F) 50%, N=40
KQ2 Comparison II. Different Fixed Doses
Cazzola 1995 Group A | Hb increase of 2 g/dl independent of transfusion | 2 | 31 | 6.45 | 2 | 29 | 7,4 (6,89) | Only % reported
Cazzola 1995 Group B | | 9 | 29 | 31.03 | | | | Only % reported
Cazzola 1995 Group C | | 19 | 31 | 61,29) | | | | Only% reported
Cazzola 1995 Group D | | 16 | 26 | 61.54 | | | | Only % reported
Glimelius 1998 | Hb Response ≥ 2 g/dl vs. baseline without transfusion | 26 | 41 | 63.41 | 11 | 43 | 25.58
Johansson 2001 | HB Response defined as increase ≥ 2 g/dl | 39 | 90 | 43.33 | 23 | 90 | 25.56 | % reported also after week (4/ /8). At week 12 P<0,05
Ollson 2002 | HB Response defined as increase ≥ 2 g/dl | 53 | 90 | 58.88 | 46 | 90 | 51.11 | Estimated from Fig 3 (Proportion after 24 week)
Sakai 2004 Group A | HB Response defined as increase ≥ 2 g/dl | 9 | 22 | 40.9 | | | | Observation period and independence of transfusion not stated.
Sakai 2004 Group B | | 16 | 24 | 66.66
Sakai 2004 Group C | | 18 | 23 | 78.26
KQ2 Comparison III. Weight-Based versus Fixed-Dose Regimens
Granetto 2003 | Complete if increase of Hb ≥ 2 g/dl without transfusion after 4 w | 110 | 218 | 50.46 | 122 | 230 | 53.04 | 22 pt excluded from efficacy evaluation in cause of protocol violations % as reported P0,040; Mantel Hanzel X Test
KQ2 Comparison IV. More- versus Less-Frequent Dosing
Cazzola 2003 | Hb Response ≥ 2 g/dl vs. baseline without transfusion | 85 | 118 | 72.03 | 89 | 119 | 74.78 | % reported.
Steensma 2005 | Hb Increment ≥ 2 g/dl vs. baseline | 109 | 182 | 59.89 | 128 | 183 | 69.95 | % reported for 2 g/dl Hb increment P = 0.04 with or without transfusion not reported
KQ2 Comparison V Front-Loaded versus Reduced or Constant Dosing
Glaspy 2003 Group A | Hb increase of 2 g/dl independent of transfusion | 19 | 32 | 59.38 | 15 | 30 | 50 | Only % reported
Glaspy 2003 Group B | | 17 | 30 | 56.67 | | | | Only % reported
Glaspy 2003 Group C | | 20 | 30 | 66.67 | | | | Only% reported
KQ2 Comparison VI. Titrated versus Constant Dosing
Österborg 1996 Group A | Hb increase of 2 g/dl (Mean over 4 weeks and independence of erythrocyte transfusions during 8 weeks period) | 21 | 44 | 44.68 | 8 | 39 | 16.33 | Dose FIX
Österborg 1996 Group B | | 23 | 38 | 44.92 | | | | Dose Titration

Table C47

KQ2: Studies Not Included for Hematologic Response

study author | Hb response definition | Intervention n | Intervention N | Proportion (%) | Control n | Control N | Proportion (%) | Comments
Hesketh 2004 | HB Response defined as increase ≥ 2 g/dl or a concentration ≥ 12 g/dl in albescence of RBC transfusion within previous 28 d | 10 | 122 | 86 (CI 78–94) | 101 | 120 | 84 (CI 76–92) | KM – estimate Difference in Percentages 2 (CI –8–12)
Justice 2005 | HB response HB≥12 g/dl or I ≥ 2 g/dl | 40 | 59 | 67.78 | 47 | 59 | 79.66 | Estimated by Kaplan Meier method % reported: A 80 (67 to 92) B) 68 (52 to 83)
Additional Data
Granetto 2003 | Complete if increase of Hb ≥ 2 g/dl without transfusion after 4 w | 58 | 105 | 55.24 | 60 | 113 | 53.09 | Weight 45–63 kg
Granetto 2003 | | 32 | 66 | 48.48 | 38 | 70 | 54.28 | Weight 70 –100 kg

Table C48

KQ2: Transfusion Studies

Study ID | Intervention (n) | Intervention (N) | Percentage (%) | Control (n) | Control(N) | Percentage (%) | Comments
KQ2 Comparison I. Different Weight-Based Doses
Kunikane 2001 Group A | 1 | 16 | 6.25 | 0 | 19
Kunikane 2001 Group B | 2 | 18 | 11.11
Ten Bokkel 1998 Group A | 2 | 45 | 4.44 | 13 | 33 | 39.39
Ten Bokkel 1998 Group B | 6 | 42 | 14.29
Thatcher 1999 Group A | 19 | 42 | 45.24 | 26 | 44 | 59.09 | Total number of transfusion significant difference between Group A/B
Thatcher 1999 Group B | 9 | 44 | 20.45
Glaspy 2002 Group A | 1 | 30 | 3.33% | 11 | 30 | 36.67% | K-M percentages reported, A) 4% (0; 11), EPO-control 36% (10; 87)
Glaspy 2002 Group B | 7 | 30 | 23.33% | | | | B) 22% (6; 37)
Glaspy 2002 Group C | 7 | 30 | 23.33% | | | | C) 23% (7; 30)
Glaspy 2002 Group D | 3 | 29 | 10.34% | | | | D) 11% (0; 23)
Hedenus 2002 Group A | 3 | 11 | 27.27% | 5 | 11 | 45.45% | Excluding first 4 weeks, counting week 5 to end of treatment derived from K-M estimates, arm A) 27% (95% CI 1–54), N=11, control: 45% (16–75), N=11
Hedenus 2002 Group B | 6 | 22 | 27.27% | | | | 27% (9–46), N=22
Hedenus 2002 Group C | 3 | 22 | 13.64% | | | | 15% (0–30), N=22
Kotasek 2003 Group A | 8 | 30 | 26.67% | 23 | 50 | 46 | arm A) 25% (9%–41%), N=30; control 46% (32%–61%), N=50
Kotasek 2003 Group B | 5 | 17 | 29.41% | | | | arm B) 28% (7%-51%), N=17
Kotasek 2003 Group C | 12 | 41 | 29.27% | | | | arm C) 30% (16%–44%), N=41
Kotasek 2003 Group D | 7 | 27 | 25.93% | | | | arm D) 26% (7.5%–41%), N=27
Kotasek 2003 Group E | 9 | 35 | 25.71% | | | | arm E) 27% (11%–40%), N=35
Kotasek 2003 Group F | 7 | 38 | 18.42% | | | | arm F 19% (6%–32%), N=38
KQ2 Comparison II. Different Fixed Doses
Cazzola 1995 Group A | 7 | 31 | 22.58 | Placebo 8 | Placebo 29 | 27.59
Cazzola 1995 Group B | 5 | 29 | 17.24
Cazzola 1995 Group C | 6 | 31 | 19.35
Cazzola 1995 Group D | 4 | 26 | 15.38
Glimelius 1998 | 3 | 41 | 7.32 | 5 | 43 | 11.63 | not significant
Johansson 2001 | 36 | 90 | 40.00% | 49 | 90 | 54.44%
Ollson 2002 | 30 | 90 | 33.33 | 32 | 90 | 35.66 | % reported
Sakai 2004 Group A | 5 | 22 | 22.72
Sakai 2004 Group B | 4 | 24 | 16.66
Sakai 2004 Group C | 0 | 23 | 0
KQ2 Comparison III. Weight-Based versus Fixed-Dose Regimens
Granetto 2003 | 37 | 225 | 16.44 | 30 | 238 | 12.61 | Only 463 of 546 patients assed (drop outs in first 4 weeks). Transfusion free % reported - -Kaplan Meier Estimate Log rank p=0,32% RR 1,29 (CI 0,78–2,14)
Hesketh 2004 | 23 | 122 | 18.88 | 19 | 120 | 15.83 | Reported: Fix: 19% (CI:11–27) W: 16% (CI 9–23)
KQ2 Comparison IV. More- versus Less-Frequent Dosing
Cazzola 2003 | 10 | 115 | 9.24 | 16 | 114 | 14.03 | Additional source ASH 2002 Mean Hb in both groups before transfusion 7,4 g/dl P=0,14 Cochrane M.-Haenzel Test adjusted for underlying disease
Steensma 2005 | 29 | 182 | 15.93 | 35 | 183 | 19.13 | % reported; P= 0.51
KQ2 Comparison V. Front-Loaded versus Reduced or Constant Dosing
Kotasek 2004 | 89 | 356 | 25.00% | 88 | 367 | 23.98 | Week 5 to end of treatment estimate from reported %. A) 24% (CI 19; 28); B) 25% (CI 20; 30)
KQ2 Comparison VI. Titrated versus Constant Dosing
Österborg 1996 Group A | 27 | 47 | 56.25 | 40 | 49 | 81.6 | % of transfused patients during m 2 to 6 reported
Österborg 1996 Group B | 31 | 48 | 64.58
KQ2 Comparison VII. Intravenous versus Subcutaneous Dosing
Justice 2005 | 21 | 59 | 35.59 | 19 | 59 | 32.2 | % reported for week 5 up to end. A)32 (CI 18; 45) B) 35 (CI 20; 50)

Table C49

KQ2: Overall Survival

Study author | Randomized | Evaluated | Method | Follow up | Events INTERVENTION (n/N), reported are deaths if not stated otherwise | Events control (n/N), reported are deaths if not stated otherwise | HR (95% CI) | Comments
KQ2 Comparison I. Different Weight-Based Doses
Ten Bokkel 1998 Group A | 45 | | Proportion | During study or subsequent follow up | 1/45 | 2/33
Ten Bokkel 1998 Group B | 42 | | | | 3/42
Thatcher 1999 Group A | | | Proportion | | 1/42 | 3/44
Thatcher 1999 Group B | | | | | 5/44
KQ2 Comparison II. Different Fixed Doses
Cazzola 1995 | 146 | 146 | Proportion | NR | 4/117 | 2/029 | NR | In Full text deaths not reported for the different intervention Groups
Glimelius 1998 | | | | | | | | Death or terminal disease reported
Ollson 2002 | 180 | | Proportion | 24 week | 21 | 19
KQ2 Comparison III. Weight-Based versus Fixed-Dose Regimens
Granetto 2003 | 268/264 | 255/255 | Proportion | | 20/268 | 14/264 | | Not based on Kaplan-Meier estimate
Hesketh 2004 | 243 | | Proportion | 19 week | 13/122 | 11/120 | | Study + 30d observed.
KQ2 Comparison IV. More-versus Less-Frequent Dosing
Steensma 2005 | NR | NR | NR | NR | NR | NR | NR | Only reported slight trend towards the intervention group (120k) p=0,10.
KQ2 Comparison VII. Intravenous versus Subcutaneous Dosing
Justice 2005 | 120 | 118 | Proportion | 18 w + 30d after | 7/59 | 5/59

Table C50

KQ2: Thrombotic Events

Study ID | Intervention n | Intervention N | Percentage (%) | Control n | Control N | Percentage (%) | Definition of TE | Comments
KQ2 Comparison I. Different Weight-Based Doses
Ten Bokkel 1998 Group A | 2 | 45 | 4.44% | 0 | 31 | 0.00% | Cardiovascular events
Ten Bokkel 1998 Group B | 4 | 42 | 9.52% | 0 | | 0.00%
KQ2 Comparison II. Different Fixed Doses
Glimelius 1998 | 6 | 41 | 13.95 | 3 | 43 | 7.32 | NR | ! Deep VT and 1cerebral ischemic attack reported.
Johansson 2001 | 11 | 90 | 12.22 | 4 | 90 | 4.44 | Cardiovascular events | Deep VT 4/1; Mi 2/0; Heart failure 2/1; Atrial fibrillation 1/1; Cerebral bleeding 2/2
KQ2 Comparison III. Weight-Based versus Fixed-Dose Regimens
Granetto 2003 | 5 | 268 | 1.9 | 5 | 264 | 1.9 | No | Only AE related to study drug reported.
KQ2 Comparison IV. More-versus Less-Frequent Dosing
Cazzola 2003 | 18 | 118 | 15.25 | 21 | 119 | 17.65 | Vascular disorders | Part % reported. Recalculated from 85 patients reported adverse events in each group.
KQ2 Comparison VI. Titrated versus Constant Dosing
Österborg 1996 Group A | 1 | 47 | 2.13 | 0 | 49 | 0 | Pulmonary Embolism
Österborg 1996 Group B | 2 | 48 | 4.17

Table C51

KQ2: Rash

Study ID | Treatment n | Treatment N | Percentage | Control n | Control N | Percentage | Definition of Rash | Comments
KQ2 Comparison III. Weight-Based versus Fixed-Dose Regimens
Granetto 2003 | 5 | 268 | 1.9 | 1 | 264 | 0.4 | Skin reactions (incl. pruritus) | Only AE related to study drug reported.
KQ2 Comparison VI. Titrated versus Constant Dosing
Österborg 1996 Group A | 1 | 47 | 2.13 | 0 | 49 | 0 | | Dose FIX
Österborg 1996 Group B | 1 | 48 | 2.08 | | | | | Dose Titration

Table C52

KQ2: Hypertension

Study ID | Treatment n | Treatment N | Percentage | Control n | Control N | Percentage | Definition of Hypertension | Comments
KQ2 Comparison I. Different Weight-Based Doses
Kunikane 2001 Group A | 3 | 22 | 13.64 | 4 | 17 | 23.53 | Grade 1–4 reported not further specified
Kunikane 2001 Group B | 2 | 21 | 9.52 | | | | Grade 1–4 reported not further specified
Ten Bokkel 1998 Group A | 1 | 45 | 2.22 | 1 | 28 | 3.58 | SBP > 180 mmHg with change < 30 mmHg or SBP < 80 mmHg with change of 15 mmHg or DBP: > 100 mmHg with change > 15mmHG
Ten Bokkel 1998 Group B | 3 | 42 | 7.14
KQ2 Comparison II. Different Fixed Doses
Glimelius 1998 | 0 | 41 | 0 | 0 | 43 | | NR
Johansson 2001 | 0 | 90 | 0 | 0 | 90 | 0 | NR
KQ2 Comparison III. Weight-Based versus Fixed-Dose Regimens
Granetto 2003 | 4 | 268 | 1.5 | 3 | 264 | 1.1 | No | Only AE related to study drug reported.
KQ2 Comparison VI. Titrated versus Constant Dosing
Österborg 1996 Group A | 4 | 47 | 8.51 | 1 | 49 | 2.04
Österborg 1996 Group B | 5 | 48 | 10.42

Table C53

KQ3: Study Characteristics, Part I

study author | participants randomized | Drug | Intervention (Early) | Control Late | weight based or fixed | Maximum duration of EPO medication (weeks) | dose adjustment | iron | transfusion trigger (when transfusion assessed) | publication | primary and secondary outcomes of the study
Rearden 2004 | 204 E: 102 L: 102 | Darbepoetin alfa | 300 μg Q3W | Observation until Hb ≤ 10 g/dl then start treatment 300μg Q3W [38 patients, 37.3%] | Fixed | 12 (darbepoetin treatment period); chemotherapy and follow-up continued for 22 weeks | Increase to 500μg/Dose-. for Early: if Hb <10g/dl; for Late: if Hb <9 g/dl or if after 2 consecutives doses of DA Hb <10 g/dl | NR | NR | Abstract + slides | proportions with: Hb drop below 10 g/dl by week 12; Hb drop during therapy; RBC transfused during therapy; also, mean Hb over time; mean change in FACT-Fatigue subscale score; proportion maintaining Hb 11.0 to 13.0 (target)
Straus 2003 | 269 E: 135 L: 134 | Epoetin alfa | 40000 IU QW | Observation until Hb ≤9 g/dl after 2nd chemotherapy cycle, then start treatment: 40,000 IU QW [29 pt (19.4%)] | Fixed | 16 | Increased to 60000 in either group if after 4w of Epo treatment Hb I ≤1g/dl | NR | NR | Abstract + poster copy | Hb response; RBC transfusions, QoL; Safety Health Care utilization Work/Productivity
Crawford 2003 | 216 E: 109 L: 107 | Epoetin alfa | 40000 IU QW | Observation until Hb ≤ 10 g/dl, then start treatment at 40,000 IU QW (44% of controls had Hb<10 g/dL and received late epoetin) | Fixed | 16 | Increased to 60,000 IU QW if ≥2 g/dL Hb decrease; dose withheld if Hb >15 g/dL twice consecutively; re-start with dose decreased by 20,000 IU weekly when Hb ≤13 g/dL | as needed (ferritin <100 ng/mL or Tsat<20%) | NR | Abstract + slides (presented as poster) | Hb changes over time; proportion transfused; RBC units/patient; QoL changes with Fact-An, LASA, BFI; tumor size; survival; adverse events; lab tests; blood pressure

Table C54

KQ3: Study Characteristics, Part II

study author | n randomized | cancer details | cancer category | therapy | Hb eligibility criteria [g/dl] | Hb baseline Early [mean g/dl (SD)] | Hb baseline Late arm [mean g/dl (SD)] | Hb category | Age Early arm [mean (SD)] if not stated otherwise | Age Late arm [mean (SD)] if not stated otherwise | age category (children adults elders (>65)
Rearden 2004 | 204 | Breast; Lung; GiT; Genitourinary; Lymphoid; Gyne; Other | Mixed | chemotherapy | ≥10,5 and ≤12,0 | 11,1 (SD 0,7) | 11,2 (SD 0,6) | 12 | 63,2 (SD 10,9) | 63,7 (SD 12,2) | Adults
Straus 2003 | 269 | NHL; MM; Hodgkin; CL | Hematological | chemotherapy with cycles week (1;2;3;4) | Hb > 10 g/dl and Hb ≤12,0 g/dl | 11,1(SE 0,7) | 11,2 (SE 0,7) | 12 | 59,0 (SD14,0) n=126 | 60,5 (SD14,9) n = 122 | Adults
Crawford 2003 | 216 | Lung cancer (non-small cell) | Solid | chemotherapy with platinum, 78–80% of each arm | Hb ≥11 g/dL and <15 g/dL | 13,1 (SD 1,0) | 13,0 (SD 1,2) | >12 | 62,3 (SD 11,0) | 62,7 (SD 10,6) | adults

Table C55

KQ3: Study Quality

study author | random | allocation | blinding | placebo | ITT or 10% | similar | high or low quality
Rearden 2004 | unclear | unclear | no | no placebo | ITT | yes | low
Straus 2003 | unclear | unclear | no | no placebo | ITT | yes | low
Crawford 2003 | unclear | unclear | no | no placebo | ITT | yes | Low

Table C56

KQ3. Hematologic Response

study author | Hb response definition | Early (n) | Early (N) | Percentage (%) | Late (n) | Late (N) | Percentage (%) | Comments
Rearden 2004 | Hb Increase ≥ 2 g/dl | 19 | 94 | 20,2 | 16 | 86 | 18,6 | Data presented by Charu-2004

Table C57

KQ3: Study Not Included for Hematologic Response

study author | Hb response definition | Early | Late | Comments
Straus 2003 | Hb increase ≥ 2 g/dl OR Hb increase Hb ≥ 12 g/dl | 70,4% (95 Pt) | 25,4% (34 Pt) | P < 0,001 (ITT)
Crawford 2003 | Proportion maintaining Hb ≥10 g/dL and not transfused | 82% | 56% | P = 0,0001

Table C58

KQ3: Transfusion

Study ID | time of measurement | Intervention (n) | Intervention (N) | Percentage (%) | Control (n) | Control(N) | Percentage (%) | Comments
Rearden 2004 | 12 weeks | 14 | 99 | 14% (CI 7;20) | 22 | 102 | 22% (CI 13;30)
Rearden 2004 | 22 weeks | 17 | 99 | 17,2 | 27 | 102 | 26,5 | P=0,11
Straus 2003 | 16 weeks | 24 | 135 | 17,8 | 35 | 134 | 26,1 | P=0,11
Crawford 2003 | 16 weeks | 13 | 106 | 12,3 | 22 | 105 | 21,0 | P=0,089

Table C59

KQ3: Thrombotic Events

Study ID | Intervention n | Intervention N | Percentage (%) | Control n | Control N | Percentage (%) | Definition of TE | Comments
Rearden 2004 | 99 | 2 | 2 | 102 | 0 | 0 | 1 atrial fibrillation 1 deep venous thrombosis | The other adverse events possibility related to study drug 9/5 not specified. described
Straus 2003 | 135 | 15 | 11.1 | 134 | 4 | 3 | Thrombovascular events | In Early 2 TVE’s (moderate thrombosis and severe deep thromophlebitis) were assed related to epo, in Late no.
Crawford | NR | | NR | NR | | NR

Table C60

KQ3: QoL data from Straus et al. 2003

Straus 2003 | Baseline Immediate | Change Immediate | Baseline Delayed: | Change: Delayed | p-value
FACT-G
- FACT –G Physical well being | 20.9 (n=117) | 1.0 (n=118) | 20.9 (n=112) | −0.33 (n=112) | 0.007
- FACT –G Functional well being | 17.6 (n=118) | 0.43 (n=119) | 18.3 (n=114) | − 1.03 (n=113) | 0. 024
FACT – anemia subscale
- FACT – fatigue subscale | 34.0 (n=118) | 1.45 (n=119) | 34.3 (n=112) | − 1.68 (n=112) | 0.005
- Total of FACT anemia subscale | 55.0 (n=118) | 1.92 (n=118) | 55.2 (n=112) | − 1.71 (n=112) | 0.008

Table C61

KQ3: QoL data from Rearden et al. 2004

Rearden 2004 | Baseline Immediate | Change (week 13) Immediate | Change (week 22) Immediate | Baseline Delayed: | Change (week 13) Delayed | Change (week 22) Delayed | comments
- FACT – fatigue subscale | | n=86 | n=72 | | n=72 | n=52
- FACT – fatigue subscale | 31.6 (SD11.7) | 1.5 (CI 4.0; −0.9) | 1.5 (CI 4.4; −1.4) | 27.7 (SD 12.8) | −0.8 (CI 2.1; −3.6) | 1.8 (CI 5.7; −1.9) | Fact F baseline data from Charu et al. 2004

Table C62

KQ4: Study Characteristics, Part I

Study Author | Trial Design | Study Type | Objective | EPO Tx Length (wks) | Source | No. of Patients in Study | Hb Response N Resp/N Eval (%) | No. Pts. With Dose Change | Definition of Hb Response | Comment
Miller 1992 | Phase I/II | I | Determine association of pretreatment variables with HR | | Full text | 21 | 12/21 (57%) | NR/NA | Hb > 10 g/dL after 3–4 weeks independent of transfusion | Different response criterion; unclear if all possible predictive factors that had been tested are reported
Case 1993 | RCT | I | Use a linear model approach to determine the effect of various baseline parameters on response efficacy | 12 | Full text | 157 (81 rec’d Epo) | 46/79 (58%) | NR | Hct increase ≥ 6% from baseline independent of transfusion | Patients probably included in Henry 1995
Cascinu 1994 | RCT | I | Determine the association of pretreatment erythropoietin levels with response to epo treatment | 9 | Full text | 100 (50 rec’d Epo) | 29/50 (58%) after 3 wks 37/50 (74%) after 6 wks 41/50 (82%) after 9 wks | NR | Hb increase to > 10 g/dL after 3, 6, and 9 weeks | Different response criterion
Ludwig 1994 | Prospective cohort study | I | Investigate the power of hematological and humoral factors to predict response to epo | ≥12 | Full text | 80 | 38/80 (48%) | 9/38 (24%) of responders | Hb increase ≥ 2 g/dL within 12 weeks and no transfusion within weeks 3–12 | Unclear if patients received chemoradiotherapy
Cazzola 1995 | RCT | I | Identify predictors of response to epo | 8 | Full text | 146 (117 rec’d Epo) | After 8 weeks: 5,000 IU: 61% 10,000 IU: 62% | NR | Hb increase ≥ 2 g/dL between baseline and two time points independent of transfusion in the previous 6 wks (unclear if different definition used for predictive factors study: “cumulative response rates after 8 weeks of treatment”) | Two additional dose-levels were investigated (1000 IU and 2000 IU) but excluded for predictive factors study
Garton 1995 | RCT | I | Determine differences between responders and non-responders (not explicitly stated) | 6 | Full text | 10 | 9/20 (45%) including all pts 6/10 (60%) including only patients receiving Epo in the first part of the study | 7/9 responders received 3 × 300 IU/kg/wk | Hct ≥ 38% after 12 weeks of epo | Different response definition; unclear what kind of chemo- or radiotherapy patients received
Henry 1995 | RCT | I | Re-analysis of data to predict responsiveness to Epo | 12 | Full text (letter) | NR | 77/143 (54%; only patients receiving chemotherapy) | NR | Hct increase ≥ 6% after 12 weeks from baseline independent of transfusion | Only results for patients receiving chemotherapy reported here
Ludwig 1995 | Prospective cohort study | I | Determine the association of baseline erythropoietin levels and changes over time with HR | 12 | Full text | 102 | 35/68 (51%; only patients receiving chemotherapy) | NR | Hb increase ≥ 2 g/dL independent of transfusion
Osterborg 1996 | RCT | I | Identify prognostic factors for HR | 24 | Full text | 121 (77 rec’d Epo) | 60% | NR | Hb increase ≥ 2 g/dL (mean over 4 wks) independent of transfusion (8 wk period)
Kasper 1997 | Prospective cohort study | I | Compare baseline parameters of responders and non-responders (not explicitly stated) | ≥12 | Full text | 60 | 23/48 (48%) | 59/60 (98%) not reported separately for predictive factors analysis | Hb increase > 2g/dL from baseline independent of transfusion
Glaspy 1997 | Prospective cohort study | I | Determine the association of baseline erythropoietin level with change in hemoglobin level during epo therapy | Unclear (1047 patients received 4 months) | Full text | 2342 (2030 evaluable) | 53% | NR | Different definitions used for different analyses; not all definitions reported | Recommended that epo not be started unless erythropoietin level at baseline < 200 IU/L; collection of baseline data (e.g. erythropoietin level) optional; different response definition
Musto 1997 | Prospective cohort study | I | Evaluate the role of interleukin-1, interleukin-6, tumor necrosis factor and other non-invasive factors in erythropoiesis | 8 | Full text | 40 (40 rec’d Epo) | 13/37 (35%) | NR/NA | Complete interruption of transfusions and stable Hb > 8 g/dL | Different response definition
Demetri 1998 | Prospective cohort study | I | Determine the association of baseline erythropoietin levels and response (not explicitly stated) | 16 | Full text | 2370 (2289 evaluable) | 1406/2289 (61%) | NR | Hb increase ≥ 2 g/dL or Hb ≥ 12 g/dL | Different response criterion; unclear if absence of transfusion required; response definition probably not used for predictive factors study; statistical methods inadequately described
Fjornes 1998 | Prospective cohort study | I | Develop prediction criteria for efficacy of epo therapy | 12 | Full text | 22 (22 rec’d Epo) | 10/22 (45%) | NR | No transfusions required, no decrease in Hb level, or improved performance status with decreased clinical symptoms of anemia (3 criteria “very good response”, 2 criteria “good response”, 1 criterion “moderate response”) | Different response criterion
Glimelius 1998 | RCT | I | Determine the association of baseline erythropoietin levels and response (not explicitly stated) | 18 | Full text | 100 | 2000 IU: 30% 10000 IU: 73% | NA | Hb increase ≥ 1.0 g/dL independent of RBCT | Different response definition
Oberhoff 1998 | RCT | I | Identify subgroups of patients that exhibit the greatest epo benefit | 12 | Full text | 189 (101 in Epo-arm) | 38% | NR/NA | Hb increase ≥ 2 g/dL in a 4 wk interval and maintained independent of transfusion in that interval or the previous 4 wks | Transferrin saturation mentioned as possible predictive factor in methods section but not reported in results
Gonzalez 1999 | Prospective cohort study | I | | NR | Abstract | | 40/79 (51%) type I 23/79 (29%) type II | NR | Hb increase ≥ 1 g/dL after 4 weeks (type I); Hb increase ≥ 1 g/dL after 8 weeks (on double epo dose) (type II) | Different response criterion; unclear if absence of transfusion required
González-Barón 2002 | Prospective cohort study | I | Identify factors that might predict HR to epo | 1 month after end of chemotherapy (median 2.9 cycles) | Full text | 117 | 63% | NR | Hb increase ≥ 2 g/dL during the treatment phase | Unclear if absence of transfusion required
Hedenus 2002 | RCT | I | Use logistic regression model to assess the treatment effect of darbepoetin alfa and other parameters | 12 | Full text | 66 (55 rec’d Epo) | 1.0 μg/kg: 45%; 2.25 μg/kg: 55%; 4.5 μg/kg: 62% | Epo stopped temporarily in 3 patients; no details reported | Hb increase ≥ 2 g/dL independent of transfusion in the previous 4 wks
Boogaerts 2003 | RCT | I | Determine the association between endogenous erythropoietin level and HR to epo | 12 | Full text | 262 (133 rec’d Epo) | 63/133 (47%) | NR | Hb increase ≥ 2 g/dL during the treatment phase without transfusion after the initial 4 treatment wks | Statistical methods inadequately described
Cazzola 2003 | RCT | I | Identify predictors of response to epo | 16 | Full text | 241 (241 rec’d Epo) | tiw: 75% qw: 72% | NR | Hb increase ≥ 2 g/dL from baseline independent of transfusion in the previous 6 wks | Additional inclusion criterion: serum epo level ≤ 100 IU/L; unclear if all possible factors analyzed were reported
Chang 2004 | RCT | I | Exploratory analysis to determine which baseline parameters were significant predictors of HR | 16 or 4 wks after end of chemotx (max 28 weeks) | Full text | 354 | 52% | NR | Calculated average Hb from wks 4 to 12 ≥ 12 g/dL | Statistical methods inadequately described; unclear if absence of transfusion required; different response criterion
Katodritou 2004 | Prospective cohort study | I | Evaluate both traditional and novel predictive factors for predicting response to Epo treatment | ≥6 (responders continued as needed; non-responders plus iron for additional 4 weeks) | Abstract | NA | 20/32 (63%) | NR/NA | Hb increase ≥ 2 g/dL after 6 wks; Patients with iron plus epo: Hb increase ≥ 1 g/dL after 4 weeks | Unclear if absence of transfusion required; 20/32 (63%) responders, 12/32 (38%) non-responders (8/9 iron+Epo responded)
Witzig 2004 | RCT | II | Test a modified version of a specific algorithm (Ludwig 1994) to predict HR | 16 | Full text | 344 (174 in Epo-arm) | 73% | Dose escalation: 42.8% | Hb increase ≥ 2 g/dL | Different response criterion (HR not independent of transfusion); statistical methods not described
Littlewood 2003 | 4 RCT | I | Determine the relationship between a large number of pre- and early treatment factors and HR | NR | Full text | 604 | 382/561 (68%) | NR | Hb increase ≥ 2 g/dL or Hct increase ≥ 6% | Unclear if absence of transfusion required; no study analyzed here reported elsewhere in table
McKenzie 2004 | 3 multicenter clinical trials | I | Evaluate whether patients with early Hb increase had better outcomes compared with late/non-responders | NR | Abstract | Study 1: 2964; study 2: 681; study 3: 2289 | NR | NR | Hb increase ≥ 2 g/dL independent of transfusion | Patients probably already included in Glaspy 1997 and Demetri 1998

Table C63

KQ4: Study Characteristics, Part II

Study Author | Drug | Dose per week | Dose Change | Transfusion trigger | Out-comes Reported | Malignancy type | Cancer Tx | Hb required at enrollment | Baseline Hb g/dL (SD) | Age (Med. Range)
Miller 1992 | Epoetin beta | 5 × 25, 50, 10, or 200 IU/kg/wk | NR | NR | HR, Hb, RBCT, AE | Solid tumors | chemotx (all platinum) | < 11 g/dL while receiving chemo; > 11 g/dL if prior to chemo | 10.0 g/dL (9.3) | Mean 51 yrs (SD 6)
Case 1993 | Epoetin alfa | 3 × 150 IU/kg/wk | Decreasing: if Hct 38–40%; epo dose titrated to maintain Hct | Discretion of treating physician | HR, RBCT, HRQOL, AE | Malignancy (excluding primary myeloid malignancies and acute leukemias) | chemotx | ≤ 10.5 g/dL | Hct 28.5% (Hb not reported) | 64 yrs (27–92)
Cascinu 1994 | Epoetin alfa | 3 × 100 IU/kg/wk | Decreasing: if Hb > 12 g/dL; epo stopped until Hb <10 g/dL | Hb < 8 g/dL or clinical symptoms | HR, Hb, RBCT, AE | Stomach, ovarian, melanoma, head neck, lung, breast | chemotx (platinum all); some radiotherapy | ≤ 9 g/dL | 8.6 g/dL (0.6) | 58 yrs (44–72)
Ludwig 1994 | Epoetin alfa | 3 × 150 IU/kg/wk | Increasing/decreasing: if Hb increase < 2 g/dL after 6 wks epo 3 × 300 IU/kg/wk; epo titrated to maintain Hb in normal range | NR | Not applicable | Multiple myeloma, breast, other hematologic malignancies and solid tumors | Unclear | < 11 g/dL | Median 9.5 g/dL (range 5.3–10.9) | 62 yrs (32–82)
Cazzola 1995 | Epoetin beta | 7 × 5,000 or 10000 IU/wk (see comment) | Decreasing: if Hb increase > 2 g/dL or Hb > 12.5 g/dL epo 3 x per week; epo stopped if Hb > 13 g/dL (MM) or > 15 g/dL (NHL) | Discretion of treating physician | HR, Hb, RBCT, AE | Multiple myeloma, non-Hodgkin lymphoma (excluding high-grade NHL) | chemotx (116/146 (79%) of patients) | ≤ 11 g/dL (independent of transfusion) | 5000 IU: 9.4 g/dL (1.2); 10000 IU: 9.4 g/dL (1.0) | 5000 IU: 68 yrs (42–85); 10000 IU: 63 yrs (28–80)
Garton 1995 | Epoetin alfa | 3 × 150 IU/kg/wk | Increasing: if Hct < 38% after 6 wks Epo 3 × 300 IU/kg/wk for6 more wks | NR | HR | Multiple myeloma | chemotx | Hct ≤ 30% (unrelated to recent bleeding) | Hct 29% (Hb not reported) | NR
Henry 1995 | NR | 3 × 150 IU/kg/wk | NR | NR | HR, RBCT, HRQOL, AE | Hematologic malignancies, prostate, breast, GI-tract, lung, other solid tumors | chemotx | ≤ 10.5 g/dL or Hct ≤ 32% (from Abeles 1993) | Hct 29.1 % (including pts not receiving chemotx; from Abeles 1993) | NR
Ludwig 1995 | NR | 3 × 150 IU/kg/wk | Increasing/decreasing: if Hb increase ≤ 2 g/dL epo 300 IU/kg; if Hb > 12 g/dL epo dose reduced at discretion of treating physician | If clinical symptoms required immediate medical attention | HR, RBCT, performance status, AE | Breast, multiple myeloma, other solid tumors, other hematological malignancies (including CLL) | chemotx (68/94 (72%) of patients; 15/68 (22%) platinum) | < 11 g/dL | 9.2 g/dL (1.1; only pts receiving chemotx) | 57 yrs (33–86; only patients receiving chemotx)
Osterborg 1996 | Epoetin beta | 7 × 10,000 IU/wk or titration (7 × 2,000 IU/wk week 1–8; 7 × 5,000 IU/wk week 9–12; 7 × 10,000 IU/wk week 13–24) | Decreasing: if Hb 11–13 g/dL (no RBCT) epo 5 or 3 times per week; epo stopped if Hb > 13 g/dL (women) or > 14 g/dL (men) until Hb ≤ 10 g/dL (reduced frequency) | Hb < 10 g/dL | HR, RBCT, AE | Multiple myeloma, low-grade NHL | chemotx (69/77 (90%) of patients receiving Epo) | ≤ 10 g/dL | Fixed dose: median 8.0 g/dL (range 6.2–10.1); titration: median 8.0 g/dL (range 5.2–9.8) | Fixed dose: 66 yrs (43–84); titration: 64 yrs (36–83)
Kasper 1997 | NR | 7 × 2,000 IU/wk | Increasing/decreasing: if Hb increase ≤ 2 g/dL after 4 wks epo 7 × 5,000 IU/wk; if Hb increase ≤ 2 g/dL after 8 wks Epo 7 × 10,000 IU/wk; if Hb ≥ 14 g/dL epo 5 ×/wk or 3 ×/wk; epo stopped if no HR after 12 wks, stable Hb, or Hb >16 g/dL | NR | HR | Hematologic malignancies (including CLL and MDS), solid tumors | chemotx (85% of patients) | < 10 g/dL | 9.2 g/dL (0.1) | 53 yrs (18–71)
Glaspy 1997 | Epoetin alfa | 3 × 150 IU/kg/wk | Increasing/decreasing: if response not satisfactory to treating physician epo 3 × 300 IU/kg/wk; if Hct increase > 4% during 2-wk period epo reduced 25%; epo stopped if Hct > 40% until Hct ≤ 38% (epo reduced 25%) | NR | HR, HRQOL, RBCT | Hematologic malignancies (excluding myeloid malignancies), lung, breast, gynecologic malignancies, other solid tumors | chemotx (40% platinum-based) | Anemia (no further details reported) | 9.2 g/dL (1.3) | Mean 62.2 yrs (SD 13.3)
Musto 1997 | Epoetin alfa | 3 × 10,000 IU/wk | NR | NR | HR | Multiple myeloma | chemotx | ≤ 8 g/dL (transfusion required) | Median 7.1 g/dL (range 3.5–8) | 64.2 yrs (42–78)
Demetri 1998 | Epoetin alfa | 3 × 10,000 IU/wk | Increasing/decreasing: if Hb increase after 4 wks <1 g/dL epo 3 × 20,000 IU/wk; if Hb increase > 1 g/dL within 2-wk period epo dose reduced; epo stopped if Hb > 13 g/dL until ≤ 12 g/dL (epo dose reduced by 25% and titrated to maintain Hb level) or if Hb increase after 8 wks < 1 g/dL | Discretion of treating physician | HR, Harold, RBCT | Lung, hematologic malignancies (excluding myeloid malignancies), breast, gynecologic malignancies, other solid tumors | chemotx (21% platinum) | ≤ 11 g/dL | 9.3 g/dL (1.0) | Mean 63 yrs (SD 13)
Fjornes 1998 | Epoetin alfa | 3 × 10000 IU/wk | Increasing/decreasing: if Hb after 4 weeks decreased from baseline, stable/decreased performance status, or stable/increased clinical symptoms of anemia Epo 3 × 20,000 IU/wk; Epo stopped if transfusion required for decreasing Hb levels and worsened performance status | Hb < 8.5 g/dL and clinical signs of anemic hypoxia | HR, Hb, RBCT | Lung, sarcoma, breast, neuroectodermal | chemotx (platinum all) | < 11 g/dL | Median 8.1 g/dL (range 5.9–10.9) | 71 yrs (48–94)
Glimelius 1998 | Epoetin beta | 3 × 2,000 or 10,000 IU/kg/wk | Not allowed; epo stopped if Hb > 14.5 g/dL | If Hb < 8.5 g/dL at discretion of physician | HR, RBCT, HRQoL, AE | Colorectal, other GI-tract malignancies | chemotx (16/100 (16%) patients received no chemotx) | Men: ≤ 13 g/dL (chemo) and ≤ 11.5 g/dL (no chemo); women: ≤ 11.5 g/dL (chemo) and ≤ 10.5 g/dL (no chemo) | 2,000 IU (chemo): 10.8 g/dL (1.0); 2,000 IU (no chemo): 9.7 g/dL (0.9); 10,000 IU (chemo): 10.9 g/dL (1.0); 10,000 IU (no chemo): 9.9 g/dL (0.7) | 2000 IU (chemo): Mean 61 yrs (range 34–79); 2000 IU (no chemo): Mean 63 yrs (range 46–80); 10000 IU (chemo): Mean 61 yrs (range 31–78); 10000 IU (no chemo): Mean 64 yrs (range 53–75)
Oberhoff 1998 | Epoetin beta | 7 × 5,000 IU/wk | NR | NR | RBCT, HR, AE | Gynecological malignancies, breast, lung, urinary tract cancer, other solid tumors | chemotx (>50% platinum) | ≤ 11 g/dL | Median 9.6 g/dL | 53 yrs (20–77)
Gonzalez 1999 | Epoetin alfa | 3 × 150 IU/kg/wk | Increasing: if Hb increase after 4 wks < 1 g/dL epo 3 × 300 IU/kg/wk | NR | Not applicable (predictive factors = study objective | Solid tumors | chemotx (platinum all) | ≤ 11 g/dL | NR | NR
González-Barón 2002 | Epoetin alfa | 3 × 150 IU/kg/wk | No dose adjustment in first 4 wks according to HR (no details reported) | NR | Not applicable | Lung, ovarian, other | chemotx (platinum all) | ≤ 10.5 g/dL | NR | Mean 54.8 yrs
Hedenus 2002 | Darb-epoetin alfa | 1 × 1.0, 2.25, or 4.5 μg/kg/wk | Decreasing: if Hb increase during 28d period (plus absence of RBCT) ≥ 2 g/dL epo reduced by 50%; epo stopped if Hb > 15 g/dL (men) or 14 g/dL (women) until Hb ≤ 13 g/dL (epo dose reduced by 50%) | Hb ≤ 8 g/dL | HR, Hb, RBCT, AE | Multiple myeloma, lymphoma (including CLL but excluding high-grade NHL) | chemotx | 11 g/dL | 1.0 μg/kg: 9.7 g/dL (0.8); 2.25 μg/kg: 9.4 g/dL (1.3); 4.5 μg/kg: 9.7 (0.9) | 1.0 μg/kg: 64 yrs (26–80); 2.25 μg/kg: 69 yrs (20–84); 4.5 μg/kg: 70 yrs (52–84)
Boogaerts 2003 | Epoetin beta | 3 × 150 IU/kg/wk | Increasing/decreasing: if Hb increase within 3–4 wks < 0.5 g/dL or < 1 g/dL within 6–8 wks epo 3 × 300 IU/kg/wk; if Hb increase within 4 wks > 2 g/dL epo dose reduced 50%; epo stopped if Hb > 14 g/dL until Hb < 12 g/dL (epo dose reduced 50%) | Hb < 8.5 g/dL | HR, Hb, RBCT, QoL | Multiple myeloma, lymphoma (including CLL), ovarian, sarcoma, colorectal, lung, other solid tumors | chemotx (platinum some; assumed) | ≤ 11 g/dL | Median 9.0 g/dL (range 5–13) | 62 yrs (24–85)
Cazzola 2003 | Epoetin beta | 3 × 10,000 IU/wk (tiw) or 1 × 30,000 IU/wk (qw) | Increasing/decreasing: if no response after 4 wks epo dose doubled; if Hb increase ≥ 2 g/dL epo dose reduced by 50%; epo stopped if Hb > 14 g/dL until Hb < 13 g/dL (epo dose reduced by 50%) | Hb < 8.5 g/dL unless clinically indicated | Hb AUC5-16, HR, Hb, RBCT, several other efficacy parameters | Multiple myeloma, lymphoma (including CLL) | chemotx (32/237 (14%) of patients received no chemotx) | 9–11 g/dL | tiw: 10.1 (1.0); qw: 10.2 (1.0) | tiw: 65 yrs (33–90); qw: 67 yrs (38–82)
Chang 2004 | Epoetin alfa | 1 × 40,000 IU/wk | Increasing/decreasing: if Hb after 4 or 6 wks decreased > 2 g/dL epo 1 × 60,000 IU/wk; if Hb increase > 2 g/dL/month epo reduced 25% (to maintain Hb increase at < 2 g/dL/mo); epo stopped if Hb > 14 g/dL until Hb ≤ 12 g/dL (epo dose reduced 25%) | Discretion of treating physician (not recommended unless Hb < 8 g/dL) | HRQoL, AE | Breast | chemotx | ≤ 12 g/dL | 11.2 g/dL (0.9) | Mean 50.4 yrs (SD 11.1)
Katodritou 2004 | NR | 30,000 IU/wk | NR | NR | Not applicable (predictive factors = study objective) | Multiple myeloma, lymphoma | NR | NR | NR | NR
Witzig 2004 | Epoetin alfa | 1 × 40,000 IU/wk | Increasing: if Hb increase < 1 g/dL after 4 wks epo 1 × 60,000 IU/wk; epo stopped if Hb > 15 g/dL for two wks until Hb < 13 g/dL (epo dose reduced 25%) | At discretion of physician | HRQoL, RBCT, Hb | Lung, breast cancer, other | chemotx (some platinum); some radiotherapy | ≤ 11.5 g/dL (men); ≤ 10.5 g/dL (women) | 9.5 g/dL (range 6.0–11.4) | 63.6 (11.89)
Littlewood 2003 | NR | 3 × 150 IU/kg/wk | Increasing (3 studies): if Hb increase < 1 g/dL after 4 wks epo 3 × 300 IU/kg/wk; Decreasing (1 study):epo titrated to achieve Hct 38–40% | NR | NR | Breast cancer (23%), multiple myeloma (20%), lymphoma (16%), other | NR (probably > 50% chemotx) | NR | NR | Median 62 yrs (range 18–92)
McKenzie 2004 | NR | Study 1 and 2: 40,000 IU/wk; study 3: 3 × 10,000 IU/wk | Study 1 and 2: escalation to 60,000 IU/wk possible; study 3: escalation to 3 × 20,000 IU/wk possible | NR | NR | Nonmyeloid malignancies | chemotx; some radiotherapy | ≤ 11 g/dL | NR | NR

Table C64

KQ4: Study Quality, Part I

study author | | Type of predictive factors study | | Refutable hypotheses reported | | Objective prospectively defined | | Inclusion criteria defined for predictive factors study | | Sample size calculation (method) | | Number and characteristics of excluded patients reported | | Missing data handling reported, including losses to follow-up reported | | Internal validation (method) | | F/U at least four weeks | | Selection process of possible predictive factors explained and adequate | | Cut-off values for continuous variables explained and adequate | | Performance measures reported (Sens., Spec., +LR, −LR) | | Method of statistical analysis
Miller 1992 | | I | | No | | Yes | | Unclear | | No | | Unclear (probably no patients excluded but no explicit statement) | | No | | No | | Yes | | No | | No/not applicable (unclear if cut-offs were used) | | No | | Univariate logistic regression models
Case 1993 | | I | | No | | Yes | | Yes | | No | | Partially (2 excluded for analysis) | | No | | No | | Yes | | No | | Not applicable | | No | | Multivariate linear regression
Cascinu 1994 | | I | | No | | Yes | | Unclear | | No | | Unclear (probably no patients excluded but no explicit statement) | | No | | No | | Yes | | No | | No | | No | | Univariate logistic regression
Ludwig 1994 | | | | No | | Yes | | Unclear | | No | | Unclear (probably no patients excluded but no explicit statement) | | Unclear | | Yes (sample was split in a training and verification group; patients were ordered chronologic ally (?) and alternately assigned to one of the two groups) | | Yes | | No | | Yes (various percentiles were tested with stepwise discriminant analysis) | | No | | Point-biserial correlation to estimate correlation of baseline parameters and HR; stepwise discriminant analysis (selection criterion for variables/cu t-offs: likelihood ratio approach (measured by statistically significant Wilks’ lambda)); Cox’s maximum likelihood multivariate logistic regression for defining the algorithm
Cazzola 1995 | | I | | Yes | | Yes | | Unclear | | No | | No | | Partially (lost to follow-up because of death, AE, or non-response: coded as non-response; other losses to follow-up: censored) | | No | | Yes | | No | | Yes (using repeated log-rank tests cut-off values were chosen that divided patients into groups with high or low probability of response (>/= 10 patients in group) | | Partially (for algorithm) | | Time to response: Kaplan-Meier; univariate methods (repeated log-rank tests for optimal cut-offs); classification and regression tree method; Cox proportional-hazard model (if two or more factors were found)
Garton 1995 | | I | | No | | No | | Unclear | | No | | Partially (4 excluded for analysis | | No | | No | | Yes | | No | | Not applicable | | No | | Univariate methods (Student’s t-test)
Henry 1995 | I | | No | | Yes | | Unclear | | No | | No | | No (seems some patients were lost to follow-up for early changes: 2 weeks 132 patients included; 4 weeks 127 patients included) | | No | | Yes | | Partially | | Partially | | No | | Descriptive statistics
Ludwig 1995 | I | | No | | Yes | | Yes (baseline erythropoiet in level available) | | No | | Partially (48 excluded for analysis | | No | | No | | Yes | | No | | No | | No | | Not reported (odds ratio and 95%-CI reported in results)
Osterborg 1996 | | I | | No | | Yes | | No | | No | | No | | No | | No | | Yes | | No | | Univariate analysis: not applicable; multivariate analysis: partially (several analysis performed with different cut-offs but unclear how the optimal one was chosen) | | No | | Univariate and multivariate Cox’s regression model
Glaspy 1997 | | I | | No | | Partially | | No | | No | | No | | No | | No | | Yes | | Yes (literature reference) | | Not applicable | | No | | Simple linear correlation using regression analysis
Kasper 1997 | | I | | No | | Partially | | No | | No | | Yes (12 excluded for analysis) | | Yes (simple exclusion from analysis) | | No | | Yes | | No | | No/not applicable (unclear if cut-offs were used) | | Partially | | Univariate methods (Student’s t-test, Mann-Whitney U-Wilcoxon rank sum test (according to the results only t-test was used)
Musto 1997 | | I | | No | | Yes | | Yes | | No | | Yes (3 excluded for analysis) | | Partially | | No | | Yes | | Partially | | Partially (medians were chosen as cut-offs) | | No | | Univariate methods (chi-square test)
Demetri 1998 | | I | | No | | Unclear | | Yes | | No | | Partially (1317 excluded for analysis of baseline erythropoiet in level) | | Yes (simple exclusion from analysis) | | No | | Yes | | No | | Not applicable | | No | | Descriptive statistics (early changes) and regression analysis (baseline erythropoiet in level)
Fjornes 1998 | | I | | No | | Yes | | Unclear | | No | | Unclear (probably no patients excluded but no explicit statement) | | No | | No | | Yes | | No | | Not applicable | | No | | Univariate methods (Mann-Whitney U-test)
Glimelius 1998 | | I | | No | | Unclear | | Unclear | | No | | No | | No | | No | | Yes | | Yes (literature reference) | | No (apparently various cut-offs were used for Epo O/P ratio and at least one cut-off was used for baseline erythropoiet in level) | | No | | Univariate methods (Student’s t-test and chi-square test)
Oberhoff 1998 | | I | | No | | Yes | | No | | No | | No | | Unclear | | No | | Yes | | No | | No | | No | | Unclear
Gonzalez 1999 | | I | | No | | Yes | | No | | No | | Partially (26 excluded for analysis) | | No | | No | | Yes | | No | | No/not applicable (unclear if cut-offs were used) | | No | | Not reported
González-Barón 2002 | | I | | No | | Yes | | Yes (at least 4 weeks on Epo treatment; however patients were also excluded for other reasons: receiving RBCT during first 4 weeks, death caused by malignancy, fewer than 3 chemothera py cycles, no follow-up data for the first 4 weeks) | | No (post-hoc ’power-analysis’ using 95%-confidence intervals reported) | | Partially (27 excluded for analysis) | | Yes (last observation carried forward) | | Yes (six samples (using 45 (50% of the whole sample) randomly selected case; however, no results of this validation are reported) | | Yes | | No | | Unclear | | Yes | | Univariate analysis; point-biserial correlation to estimate correlation of baseline parameters and early changes and HR; stepwise discriminant analysis (selection criterion for variables: likelihood ratio approach (measured by statistically significant Wilks’ lambda)); logistic regression models (cut-off values were chosen based on the maximum verisimilitude method)
Hedenus 2002 | | I | | No | | Yes | | Yes | | No | | Partially (unclear if 2 excluded for analysis) | | No | | No | | Yes | | No | | No | | No | | Multiple logistic regression
Boogaerts 2003 | | I | | No | | Yes | | Yes | | No | | Partially (30 withdrawn during study) | | No | | No | | Yes | | Partially | | No (paper cited for justification described different cut-off values/used no cut-off values | | No | | Odds ratios and relative risks (no further details reported, e.g. statistical tests used)
Cazzola 2003 | | I | | No | | Yes | | Unclear | | No | | Unclear | | Partially (8 patients were excluded from the primary ITT analysis; however, it is unclear which population was used for the predictive factors analysis | | No | | Yes | | No | | Unclear | | No | | Cox proportional-hazard model
Chang 2004 | | I | | No | | Yes | | Unclear | | No | | Unclear | | No | | No | | Yes | | No | | No/not applicable (unclear if cut-offs were used) | | No | | Multivariate logistic regression
Katodritou 2004 | | I | | No | | Yes | | Yes | | No | | Unclear (probably no patients excluded but no explicit statement) | | No | | No | | Yes | | Partially | | No/not applicable (unclear if cut-offs were used) | | Yes | | Univariate and multivariate methods (no further details reported); ROC curve to determine optimal cut-offs for factors significant in multivariate analysis
Witzig 2004 | | II | | No | | Yes | | No | | No | | No | | No | | No | | Yes | | Partially | | Partially | | Partially | | Descriptive and univariate (tests used not reported)
Littlewood 2003 | | I | | No | | Yes | | Partially (data suitable for evaluation available) | | No | | No | | No | | No | | Yes | | Yes (factors addressed in previous studies) | | Unclear (some cut- offs chosen based on previous studies, some cut- offs chosen based on multiple testing but no selection criteria reported) | | Yes | | Stepwise logistic regression analysis for selecting significant variables; univariate methods (chi-square test)
McKenzie 2004 | | I | | No | | Yes | | No | | No | | No | | No | | No | | Yes | | No | | Not applicable | | No | | Univariate methods (no details reported)

Table C65

KQ4: Study Quality, Part II

| | | Multivariable analysis
study author | Prognostic variables fully defined | CIs reported | Statistical package used | Coding of variables reported | Problem with overfitting | Conformity of linearity for ranked variables reported | Tests of interaction performed
Miller 1992 | No | No | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Case 1993 | Yes | No | Not reported | Not applicable | Probable | Not applicable | Not reported
Cascinu 1994 | Yes | No | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Ludwig 1994 | Yes | Yes (odds ratios) | No | Not applicable | Probably | Not applicable | Not reported
Cazzola 1995 | Yes | No | SAS | Not applicable | Probable | Not applicable | Not reported
Garton 1995 | Yes | No | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Henry 1995 | Yes | No | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Ludwig 1995 | Yes | Yes | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Osterborg 1996 | Yes | No | No | Univariate analysis: yes; multivariate analysis: not applicable | Unlikely | Not applicable | Not reported
Glaspy 1997 | Yes | No | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Kasper 1997 | Yes | No | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Musto 1997 | Yes | No | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Demetri 1998 | Yes | No | Yes (SAS) | Unclear | Unclear | Unclear | Unclear
Fjornes 1998 | Yes | No | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Glimelius 1998 | Yes | No | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Oberhoff 1998 | Yes | No | Not applicable/reported | Not applicable/reported | Not applicable/reported | Not applicable/reported | Not applicable/reported
Gonzalez 1999 | Yes | No | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
González-Barón 2002 | Yes | No | No | Not applicable | Probable | Not applicable | Not reported
Hedenus 2002 | Yes | No | Not reported | Yes | Probable | Not applicable | Not reported
Boogaerts 2003 | Yes | Yes | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Cazzola 2003 | Yes | Yes | Not reported | Not applicable | Unlikely | Not applicable | Not reported
Chang 2004 | Yes | No | Not reported | Not applicable | Probable | Not applicable | Not reported
Katodritou 2004 | Yes | No | Not reported | Not reported | Not reported | Not reported | Not reported
Witzig 2004 | Yes | No | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable
Littlewood 2003 | Yes | No | Yes (SAS) | Not applicable | Probable | Not applicable | Not reported
McKenzie 2004 | Yes | No | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable

Table C66

KQ4: Serum O/P Ratio

study author | Cut-off value (value) | N patients responded above cut-off | N patients responded below cut-off | Result (serum epo) (e.g. likelihood ratio) | Result (O/P ratio) (e.g. likelihood ratio) | Comments
Miller 1992 | No | Not applicable | Not applicable | Ability to respond independent of baseline erythropoietin level (p = 0.71) | Not reported/assessed | Different response criterion
Case 1993 | No | Not applicable | Not applicable | Response to Epo independent of baseline erythropoietin level | Not reported/assessed | Epo level one of various covariates in a multivariate linear regression model; no further details reported (e.g. p- value)
Cascinu 1994 | No | Not applicable | Not applicable | Response to Epo independent of baseline erythropoietin level (p = 0.27) | Not reported/assessed | No further details reported
Ludwig 1994 | Unclear | Not reported/applicable | Not reported/applicable | Baseline erythropoietin level correlated significantly with responders (r = −0.23; p < 0.05) and discriminated significantly between responders and non- responders (R^2^ = 0.074; p < 0.05) | Not reported/assessed
Cazzola 1995 | Yes (baseline erythropoietin level 50 IU/l or 70 IU/l; baseline erythropoietin O/P ratio 0.8 or 0.9) | Baseline erythropoietin level > 50 IU/l: 25%; baseline erythropoietin level > 70 IU/l: 18%; O/P ratio > 0.8: 31%; O/P ratio > 0.9: 27% | Baseline erythropoietin level ≤50 IU/l: 78%; baseline erythropoietin level ≤70 IU/l: 73%; O/P ratio ≤0.8: 75%; O/P ratio ≤0.9: 70% | Not reported | Not reported | Absolute numbers could not be calculated due to losses to follow-up (unclear enumerator) performance measures were therefore not calculated; > 50 IU/l versus ≤50 IU/l: p = 0.0014 (CART, adjusted); > 70 IU/l versus ≤70 IU/l: p = 0.0089 (CART, adjusted); > 0.8 versus ≤0.8: p = 0.0050 (CART, adjusted); > 0.9 versus ≤0.9: p = 0.0390 (CART, adjusted); according to Cox model epo level independent significant factor (≤ 50 IU/l or O/P ratio ≤0.8 more likely to respond); response definition used unclear
Garton 1995 | No | Not applicable (11/20 responder) | Not applicable | Mean erythropoietin level did not differ between responders and non-responders (p = 0.23) | Not reported/assessed | Very few patients
Henry 1995 | Yes (baseline erythropoietin level 50 IU/l) | Baseline erythropoietin level ≥100 IU/l: 29/64 (45%) | Baseline erythropoietin level < 100 IU/l: 48/79 (61%) | Specificity: 35/66 (53%); sensitivity 48/77 (62%); +LR: 1.3; −LR: 0.7 [test positive: Epo < 100 IU/l; target: response] | Not reported/assessed | Performance measures (“Result”) calculated by S.T.; only patients receiving chemotherapy reported here
Ludwig 1995 | Yes (baseline erythropoietin level 100 IU/l) | Not reported | Not reported | Responders had more often baseline erythropoietin levels < 100 IU/l compared to non-responders (odds ratio: 0.69; 95%-CI: 0.26–1.80) | Not reported/assessed
Osterborg 1996 | Univariate analysis: no; multivariate analysis: yes (baseline erythropoietin O/P ratio 0.9) | O/P ratio ≥0.9: 10% (titration); 41% (fixed dose) | O/P ratio < 0.9: 79% (titration); 60% (fixed dose) | In a further analysis optimal cut-offs for response and non- response were explored (Kaplan Meier estimates): baseline erythropoietin level < 50 IU/l: 76% responded; baseline erythropoietin level ≥400 IU/l: 9% responded | Univariate analysis: hazard ratio 0.84 (p-value < 0.01); multivariate analysis: O/P ratio only significant factor; in a further analysis optimal cut-offs for response and non- response were explored (Kaplan-Meier estimates): O/P ratio < 0.6: 89% responded; O/P ratio ≥1.2: 10% responded | Absolute numbers could not be calculated due to losses to follow-up (unclear enumerator) performance measures were therefore not calculated; unclear what criteria were applied to find optimal cut-offs in the additional exploratory analysis (“further analysis” in “Results”)
Glaspy 1997 | No | Not applicable | Not applicable | No correlation between response and baseline erythropoietin level (p = 0.294; r = 0.020) | Not reported/assessed | No definition of hemoglobin response given; patients with baseline erythropoietin level > 200 IU/l had significant Hb increase from baseline to final evaluation (mean: 8.4 g/dl to 10.2 g/dl; p-value ≤? 0.001)
Kasper 1997 | Partially (sub- analysis for baseline erythropoietin level 100 IU/l | Baseline erythropoietin level ≥100 IU/l: 27% | Baseline erythropoietin level < 100 IU/l: 59% | Mean erythropoietin level at baseline: responder: 102.7 IU/l versus non-responder: 284.4 IU/l; p-value = 0.052 | | Absolute numbers could not be calculated due to missing data performance measures were therefore not calculated
Musto 1997 | Yes (baseline erythropoietin O/P ratio 0.8) | O/P ratio ≥0.8: 1/18 (6%) | O/P ratio < 0.8: 12/19 (63%) | Not reported/assessed | Specificity: 7/24 (71%); sensitivity: 12/13 (92%); +LR: 3.2; −LR: 0.1 [positive test: O/P ratio < 0.8; target: response] | Performance measures (“Result”) calculated by S.T.; ≥0.8 versus < 0.8: p < 0.001
Demetri 1998 | No | Not applicable | Not applicable | No correlation between baseline erythropoietin level and change in hemoglobin (r = 0.017) | Not reported/assessed | Unclear what is meant by “change in hemoglobin level”; statistical methods described only inadequately
Fjornes 1998 | No | Not applicable | Not applicable | Responder: median 59.0 IU/l (range 17–85); Non-responder: median 105.0 (range 74–214); p-value: 0.002 | Not reported/assessed
Glimelius 1998 | Partially (sub- analysis for baseline erythropoietin level 50 IU/l and baseline erythropoietin O/P ratio 0.8 and various others; data for these not shown) | Baseline erythropoietin level > 50 IU/l: not reported; O/P ratio ≥0.8: 26/46 (57%) | Baseline erythropoietin level < 50 IU/l: not reported; O/P ratio < 0.8: 15/31 (48%) | Average erythropoietin levels at baseline did not differ between responders and non- responders; difference between patients with epo > 50 IU/l and epo < 50 IU/l not significant | Specificity: 16/36 (44%); sensitivity: 26/41 (63%); +LR: 1.1; −LR: 0.8 [test positive: O/P ratio ≥0.8; target: response] | Performance measures (“Result”) calculated by S.T.; ≥0.8 versus < 0.8: not statistically different (no further details reported); various Epo O/P ratios tested with no statistically significant difference (no further details reported)
Oberhoff 1998 | Yes (baseline erythropoietin level 50 IU/l and baseline erythropoietin O/P ratio 0.9) | Baseline erythropoietin level > 50 IU/l: 50%; O/P ratio > 0.9: 47% | Baseline erythropoietin level ≤50 IU/l: 46%; O/P ratio ≤0.9: 46% | No correlation between baseline erythropoietin level and HR | No correlation between Epo O/P ratio and HR | Absolute numbers could not be calculated due to losses to follow-up (unclear enumerator) performance measures were therefore not calculated; No further details reported (e.g., p- values)
González- Barón 2002 | No | Not applicable | Not applicable | Baseline erythropoietin level not significant different between responders (mean 69.1 IU/l) and non- responders (84.0 IU/l): p = n.s. and did not discriminate significantly between responders and non- responders | Not reported/assessed | No further details reported (e.g. p-value)
Hedenus 2002 | Yes (baseline erythropoietin level 100 IU/l) | Not reported | Not reported | No statistically significant association between baseline erythropoietin level and hematologic response | Not reported/assessed | Epo level one of various covariates in a multiple logistic regression model
Boogaerts 2003 | Yes (baseline erythropoietin level 50 IU/l; baseline erythropoietin O/P ratio 0.9) | Not reported for baseline erythropoietin level; O/P ratio ≥0.9 only predictive for patients with solid tumors: 27% | Not reported for baseline erythropoietin level; O/P ratio < 0.9 only predictive for patients with solid tumors: 52% | Baseline erythropoietin levels < 50 IU/l predictive for response: OR 2.5 (95%-CI: 1.2–5.1) | O/P ratio < 0.9 only predictive for patients with solid tumors: RR 1.9 (95%-CI: 1.0–3.7), p < 0.001 | No further details reported; absolute numbers could not be calculated due to missing data
Cazzola 2003 | Unclear | Not applicable/reported | Not applicable/reported | Baseline erythropoietin level predictive for response: HR 0.99 (95%-CI: 0.98–1.0), p = 0.002 | Not reported/assessed | Unclear if cut-off values were used; unclear if lower levels predict for response or non-response or higher levels predict for response or non-response (discussion indicates that lower levels predict for response)
Littlewood 2003 | Yes (baseline erythropoietin level 100, 200, 300, or 500 IU/l) | > 100 IU/l: 80/145 (55%); > 200 IU/l: 29/52 (56%); 12/24% (50%); 5/12 (42%) | ≤100 IU/l: 239/324 (74%); 290/417 (70%); 307/445 (69%); 314/457 (69%) | Baseline erythropoietin level ≤100 IU/l statistically related to HR in logistic regression model (p = 0.0037); specificity: 65/150 (43%); sensitivity: 239/319 (75%); +LR: 1.3; −LR: 0.6 [test positive: erythropoietin ≤100 IU/l; target: response] | See below | Performance measures only calculated by S.T. for the most significant cut-off (100 IU/l; authors report predictive values (positive and negative) although described as specificity and sensitivity); ≤100 IU/l versus > 100 IU/l: p < 0.001 (univariate analysis); ≤200 IU/l versus > 200 IU/l: p = 0.045 (univariate analysis); ≤300 IU/l versus > 300 IU/l: p = 0.052 (univariate analysis); ≤500 IU/l versus > 500 IU/l: p = 0.047 (univariate analysis)
Littlewood 2003 | Yes (baseline erythropoietin O/P ratio 0.9) | O/P ratio > 0.9: 137/209 (66%) | O/P ratio ≤0.9: 125/180 (69%) | See above | Baseline erythropoietin O/P ratio ≤0.9 not statistically related to HR in logistic regression model | ≤ 0.9 versus > 0.9: p = 0.414 (univariate analysis)
Katodritou 2004 | Not reported | Not reported | Not reported | No statistically significant difference between responders and non-responders | Not reported/assessed | Univariate analysis; no further details reported (e.g. p-value)
Witzig 2004 | Yes (baseline erythropoietin level 44 IU/l; 44–86 IU/l; 86 IU/l) | Data not interpretable (table labeled not unambiguously) | Data not interpretable (table labeled not unambiguously) | No difference in HR with respect to baseline erythropoietin level; p = 0.26 | Not reported/assessed | Patients with HR independent of RBCT

Table C67

KQ4: Ferritin, Iron, Transferrin

study author | Cut-off value (value) | N patients responded above cut-off | N patients responded below cut-off | Result [ferritin] (e.g. likelihood ratio) | Result [iron] (e.g. likelihood ratio) | Result [transferrin] (e.g. likelihood ratio) | Result [transferrin saturation] (e.g. likelihood ratio) | Comments
Miller 1992 | No | Not applicable | Not applicable | Ability to respond independent of baseline ferritin level (p = 0.96) | Not reported/assessed | Not reported/assessed | Not reported/assessed | Different response criterion
Ludwig 1994 | Yes (not reported) | Not applicable (see “Results”) | Not applicable (see “Results”) | Baseline ferritin level did not significantly correlate with HR | Baseline iron level did not significantly correlate with HR | Baseline transferrin level did not significantly correlate with HR | Not reported/assessed | Point-biserial correlation
Cazzola 1995 | Yes (transferrin saturation 40%) | 27% | 37% | Not reported | Not reported | Not reported | > 40% versus ≤40%: p = 0.5720 (univariate, adjusted) | Absolute numbers could not be calculated due to losses to follow-up (unclear enumerator) performance measures were therefore not calculated
Henry 1995 | Yes (ferritin 400 ng/ml) | Ferritin ≥400 ng/ml: 31/69 (45%) | Ferritin < 400 ng/ml: 46/74 (62%) | Specificity: 38/66 (58%); Sensitivity: 46/77 (60%); +LR: 1.4; −LR: 0.7 [test positive: ferritin < 400 ng/ml; target: response] | Not reported/assessed | Not reported/assessed | Not reported/assessed | Performance measures (“Result”) calculated by S.T.; only patients receiving chemotherapy reported here
Henry 1995 | Yes (ferritin 500 ng/ml) | Ferritin ≥500 ng/ml: 25/62 (40%) | Ferritin < 500 ng/ml: 52/81 (61%) | Specificity: 37/66 (56%); sensitivity: 52/77 (68%); +LR: 1.5; −LR: 0.6 [test positive: ferritin < 500 ng/ml; target: response] | Not reported/assessed | Not reported/assessed | Not reported/assessed | Performance measures (“Result”) calculated by S.T.; only patients receiving chemotherapy reported here
Osterborg 1996 | No | Not applicable | Not applicable | Not reported/assessed | Not reported/assessed | Not reported/assessed | No significant predictor for HR: hazard ratio 0.92 (p-value = 0.15) | Univariate Cox’s regression analysis
Kasper 1997 | No | Not applicable | Not applicable | No significant difference between responder and non- responder | No significant difference between responder and non-responder | No significant difference between responder and non-responder | Not reported/assessed | No further details reported (e.g. p-value)
Fjornes 1998 | No | Not applicable | Not applicable | No significant difference between responders and non-responders | No significant difference between responder and non-responder | Not reported/assessed | Not reported/assessed | No further details reported (e.g. p-value)
Gonzalez 1999 | Not reported | Not reported | Not reported | No significant difference between responders and non-responders | Not reported/assessed | No significant difference between responders and non-responders | Not reported/assessed | No further details reported (e.g. p-value)
González-Barón 2002 | No | Not applicable | Not applicable | Baseline ferritin level not significant different between responders (mean 354.8 ng/ml) and non-responders (382.5 ng/ml): p = n.s. and did not discriminate significantly between responders and non-responders | Baseline serum iron level not significant different between responders (mean 79.7) and non-responders (101.4): p = n.s. and did not discriminate significantly between responders and non-responders | Baseline transferrin level not significant different between responders (mean 255.3) and non-responders (253.7): p = n.s. and did not discriminate significantly between responders and non-responders | Baseline transferrin saturation index not significant different between responders (mean 39.5) and non-responders (26.1): p = n.s. and did not discriminate significantly between responders and non-responders | No further details reported (e.g. p-value)
Littlewood 2003 | Yes (ferritin 400 ng/ml) | Ferritin > 400 ng/ml: 144/231 (62%) | Ferritin ≤ 400 ng/ml: 223/310 (72%) | Baseline ferritin level ≤ 400 ng/ml statistically related to HR in logistic regression model (p = 0.0002); specificity: 87/174 (50%); sensitivity: 223/367 (61%); +LR: 1.2; −LR: 0.8 [test positive: ferritin ≤ 400 ng/ml; target: response] | Not reported/assessed | Not reported/assessed | See below | ≤ 400 ng/ml versus > 400 ng/ml: p = 0.018 (univariate analysis)
Littlewood 2003 | Yes (transferrin saturation 20% or 40%) | Transferrin saturation > 20%: 179/262 (68%); transferrin saturation > 40%: 58/102 (57%); | Transferrin saturation ≤ 20%: 115/172 (67%); transferrin saturation ≤ 40%: 236/332 (71%); | See above | Not reported/assessed | Not reported/assessed | Baseline transferrin saturation (≤ 40% or > 20%) not statistically related to HR in logistic regression model | ≤ 20% versus > 20%: p = 0.75 (univariate analysis); ≥ 40% versus > 40%: p = 0.007 (univariate analysis)
Chang 2004 | No | Not applicable | Not applicable | No significant predictor of response | Not reported/assessed | Not reported/assessed | Not reported/assessed | No further details reported (e.g. p-value)
Katodritou 2004 | Not reported | Not reported | Not reported | No significant difference between responders and non-responders | Not reported/assessed | Not reported/assessed | Not reported/assessed | Univariate analysis; no further details reported (e.g. p-value)

Table C68

KQ4: sTFR

study author | Cut-off value (value) | N patients responded above cut-off | N patients responded below cut-off | Result (serum sTFR) (e.g. likelihood ratio) | Result (O/P ratio) (e.g. likelihood ratio) | Comments
Ludwig 1994 | Yes (not reported) | Not applicable (see “Results”) | Not applicable (see “Results”) | Baseline sTFR level did not significantly correlate with HR | Not reported/assessed | Point-biserial correlation
Musto 1997 | Yes (O/P ratio 0.8) | O/P ratio ≥ 0.8 1/4 (25%) | O/P ratio < 0.8: 12/33 (36%) | Not reported/assessed | Specificity: 3/24 (13%); sensitivity: 12/13 (92%); +LR: 1.1; −LR: 0.6 [positive test: O/P ratio < 0.8; target: response] | Performance measures (“Result”) calculated by S.T.; < 0.8 versus ≥ 0.8: p > 0.05
Katodritou 2004 | Not reported | Not reported | Not reported | No significant difference between responders and non-responders | Not reported/assessed | Univariate analysis; no further details reported (e.g. p-value)

Table C69

KQ4: Blood count

study author | Cut-off value (value) | Type of cells | N patients responded above cut-off | N patients responded below cut-off | Result (e.g. likelihood ratio) | Comments
Miller 1992 | No | Leukocytes | Not applicable | Not applicable | Ability to respond independent of baseline erythrocyte count (p = 0.66) | Different response criterion
Ludwig 1994 | Yes (not reported) | Leukocytes | Not applicable (see “Results”) | Not applicable (see “Results”) | Baseline leukocyte count did not significantly correlate with HR | Point-biserial correlation
Littlewood 2003 | Yes (2000/μl) | Leukocytes | Leukocytes > 2000/μl: 366/532 (69%) | Leukocytes ≤ 2000/μl: 16/28 (57%) | Baseline leukocyte count not statistically related to HR in logistic regression model | ≤ 2000/μl versus > 2000/μl: p = 0.197 (univariate analysis)
Cazzola 1995 | Yes (2000/μl) | Neutrophils | Neutrophils > 2000/μl: 37% | Neutrophils ≤ 2000/μl: 26% | Not reported | Absolute numbers could not be calculated due to losses to follow-up (unclear enumerator) performance measures were therefore not calculated; > 2000/μl versus ≤ 2000/μl: p = 1.0 (univariate, adjusted); according to Cox model neutrophils independent significant factor (neutrophils > 1600/μl more likely to respond)
Osterborg 1996 | No | Neutrophils | Not applicable | Not applicable | No significant predictor of HR: hazard ratio 1.0 (p-value = 0.43) | Univariate Cox’s regression analysis
Chang 2004 | No | Neutrophils | Not applicable | Not applicable | No significant predictor of HR | No further details reported (e.g. p-value)
Miller 1992 | No | Platelets | Not applicable | Not applicable | Ability to respond independent of baseline platelet count (p = 0.71) | Different response criterion
Cazzola 1995 | Yes (100000/μl) | Platelets | Platelets > 100000/μl: 38% | Platelets ≤ 100000/μl: 13% | Not reported | Absolute numbers could not be calculated due to losses to follow-up (unclear enumerator) performance measures were therefore not calculated; > 100000/μl versus ≤ 100000/μl: p = 0.0374 (univariate, adjusted)
Ludwig 1994 | Yes (not reported) | Platelets | Not applicable (see “Results”) | Not applicable (see “Results”) | Baseline platelet count did not significantly correlate with HR | Point-biserial correlation
Osterborg 1996 | No (univariate and multivariate analysis) | Platelets | Platelets ≥ 100000/μl: titration 72%; fixed dose 68% | Platelets < 100000/μl: titration 39%; fixed dose 50% | Hazard ratio 1.2 (p-value < 0.01) (higher platelet count predicting HR) | Absolute numbers could not be calculated due to losses to follow-up (unclear enumerator) performance measures were therefore not calculated; baseline platelet count was only a significant predictor in univariate analysis not in multivariate analysis
Kasper 1997 | No | Platelets | Not applicable | Not applicable | Baseline platelet count did not significantly correlate with HR | There was a significant increase in reticulocytes in the first and second week in responders (p = 0.009). However, no comparison to non-responders reported
Chang 2004 | No | Platelets | Not applicable | Not applicable | No significant predictor of HR | No further details reported (e.g. p-value)
Ludwig 1994 | Yes (not reported) | Reticulocytes | Not applicable (see “Results”) | Not applicable (see “Results”) | Baseline reticulocytes count did not significantly correlate with HR | Point-biserial correlation
Garton 1995 | No | Reticulocytes | Not applicable (11/20 responded | Not applicable | Mean reticulocyte counts did not differ between responders and non-responders (p = 0.06) | Very few patients
Fjornes 1998 | No | Reticulocytes | Not applicable | Not applicable | No significant difference between responders and non-responders | No further details reported (e.g. p-value)
González-Barón 2002 | No | Reticulocytes | Not applicable | Not applicable | Baseline reticulocyte count not significant different between responders (mean 2.7%) and non-responders (2.4%): p = n.s. and did not discriminate significantly between responders and non-responders | No further details reported (e.g. p-value)
Littlewood 2003 | Yes (2.5%) | Reticulocytes | Reticulocytes > 2.5%: 117/177 (66%) | Reticulocytes ≤ 2.5%: 251/367 (68%) | Baseline reticulocyte count not statistically related to HR in logistic regression model | ≤ 2.5% versus > 2.5%: p = 0.593 (univariate analysis)
Katodritou 2004 | Not reported | Reticulocytes | Not applicable/reported | Not applicable/reported | No significant difference between responders and non-responders | Univariate analysis; no further details reported (e.g. p-value)

Table C70

KQ4: Creatinine Clearance

study author | Cut-off value (value) | N patients responded above cut-off | N patients responded below cut-off | Result [creatinine clearance] (e.g. likelihood ratio) | Result [serum creatinine] (e.g. likelihood ratio) | Comments
Cazzola 1995 | Yes (0.9 mg/dl) | 29% | 43% | Not reported/assessed | > 0.9 mg/dl versus ≤ 0.9 mg/dl: p = 0.7190 (univariate, adjusted) | Absolute numbers could not be calculated due to losses to follow-up (unclear enumerator) performance measures were therefore not calculated
Osterborg 1996 | No | Not applicable | Not applicable | Not reported/assessed | No significant predictor of HR: hazard ratio 0.99 (p-value = 0.92) | Univariate Cox’s regression analysis
Musto 1997 | Not reported | Not applicable/reported | Not applicable/reported | Not reported/assessed | Not reported/assessed | Presence of renal failure did not affect response to Epo
Fjornes 1998 | No | Not applicable | Not applicable | Responder: median 47 ml/min (range 28–104); Non-responder: median 91 ml/min (range 59–123); p-value: 0.02 | Responder: median 140.5 μmol/l (range 92–225); Non-responder: median 78.0 μmol/l (range 57–97); p-value: 0.002
Cazzola 2003 | Unclear | Not reported | Not reported | Not reported/assessed | HR 1.0 (95%-CI: 1.0–1.0), p = 0.89 | Unclear if cut-off values were used

Table C71

KQ4: Other Baseline Parameters

study author | Parameter | Parameter | Parameter | Parameter | Parameter | Parameter | Parameter | Parameter | Comments
Ludwig 1994 | C-reactive protein did not significantly correlate with HR | Interleukin-1 beta did not significantly correlate with HR | Interleukin-6 did not significantly correlate with HR | Tumor necrosis factor-alfa or -beta did not significantly correlate with HR | Neopterin did not significantly correlate with HR | Alfa1-antitrypsin did not significantly correlate with HR | Interferon-gamma did not significantly correlate with HR | Stem cell factor did not significantly correlate with HR | Point-biserial correlation
Musto 1997 | Number of circulating BFU-E (median in this study = 19): BFU-E > 19: 6/9 (67%) responded; BFU-E < 19: 2/12 (17%) responded; p-value < 0.01 | Interleukin-1 (median in this study = 110 pg/ml): IL-1 < 110 pg/ml: 10/16 (63%); IL-1 > 110 pg/ml: 3/21 (14%); p-value < 0.001 | Interleukin-6 (median in this study = 63 IU/ml): IL-6 < 63 IU/ml versus IL-6 > 63 not statistically significant (no further details reported) | Tumor necrosis factor (median in this study = 50 pg/ml): TNF < 50 pg/ml: 11/18 (61%); TNF > 50 pg/ml: 2/19 (11%); p-value < 0.001
Gonzalez 1999 | “hemogram”: no significant difference between responders and non-responders | “chemistry”: no significant difference between responders and non-responders | | | | | | | No further details reported (e.g. p-value)
Katodritou 2004 | Percentage of hypochromic erythrocytes (HYPO%): HYPO% Specificity 7/12 (60%); Sensitivity 20/20 (100%) | | | | | | | | Multivariate analysis; cut-offs determined by ROC curve; no further details reported (e.g. p-values); absolute values derived from percentages (see brackets)

Table C72

KQ4: Early Changes

Study author | Comments | Parameter | Parameter | Parameter | Parameter | Parameter | Parameter | Parameter | Parameter | Parameter | Parameter
Ludwig 1994 | Multivariate logistic regression | | | Response probable: serum ferritin level (absolute) < 400 ng/ml after 2 weeks: 34/47 (72%) responded; response not probable: serum ferritin level (absolute) ≥ 400 ng/ml after 2 weeks: 4/33 (12%) responded; Specificity 29/42 (69%); Sensitivity 34/38 (89%); +LR 2.9; −LR 0.2 [positive test: ferritin < 400 ng/ml; target: response]
Ludwig 1994 | point-biserial correlation | Hb increase ≥ 0.5 g/dl after 2 weeks: r = −0.55; p < 0.01 | Serum erythropoietin increase after 2 weeks (no cut-off reported): r = −0.28; p < 0.01 | Serum ferritin increase after 2 weeks (no cut-off reported): r = −0.32; p < 0.01 | Serum neopterin increase after 2 weeks (no cut-off reported): r = −0.32; p < 0.01 | Serum C-reactive protein increase after 2 weeks (no cut-off reported): r = −0.38; p < 0.01 | Serum sTFR increase after 2 weeks (no cut-off reported): r = 0.34; p < 0.01 | Serum transferrin increase after 2 weeks (no cut-off reported): r = 0.33; p < 0.01 | Serum iron increase after 2 weeks (no cut-off reported): r = −0.33; p < 0.01 | Hct increase after 2 weeks (no cut-off reported): r = 0.32; p < 0.01 | Erythrocyte count increase after 2 weeks (no cut-off reported): r = 0.28; p < 0.05
Ludwig 1994 | point-biserial correlation, continued | Reticulocyte count increase after 2 weeks (no cut-off reported): r = 0.28; p < 0.05 | Alfa1-antitrypsin increase after 2 weeks (no cut-off reported): r = −0.23; p < 0.05 | Interleukin-1 beta increase after 2 weeks (no cut-off reported) did not significantly correlate with HR | Tumor necrosis factors-alfa and -beta increase after 2 weeks (no cut-off reported) did not significantly correlate with HR | Interleukin-6 increase after 2 weeks (no cut-off reported) did not significantly correlate with HR | Interferon-gamma increase after 2 weeks (no cut-off reported) did not significantly correlate with HR | Stem cell factor increase after 2 weeks (no cut-off reported) did not significantly correlate with HR | Leukocyte increase after 2 weeks (no cut-off reported) did not significantly correlate with HR | Platelets increase after 2 weeks (no cut-off reported) did not significantly correlate with HR
Ludwig 1994 | Stepwise discriminant analysis | Hb increase ≥ 0.5 g/dl after 2 weeks: R^2^ = 0.39; p < 0.001 | Serum erythropoietin level (absolute) after 2 weeks: R^2^ = 0.151; p < 0.01 | Serum ferritin level (absolute) after 2 weeks: R^2^ = 0.14; p < 0.02
Henry 1995 | Due to losses to follow-up/missing data performance measures (spec., sens., +LR, −LR) could not be calculated; only patients receiving chemotherapy reported here | Hb increase ≥ 0.5 g/dl after 2 weeks: 34/53 (64%) | Reticulocyte count increase ≥ 40000/μl after 2 weeks: 24/41 (59%) responded | | Hb increase ≥ 1 g/dl after 4 weeks: 51/70 (73%) responded | Reticulocyte count increase ≥ 40000/μl after 4 weeks: 33/46 (72%) responded
Glaspy 1997 | Hb response definition for this analysis: increase in Hb ≥ 2 g/dl over the course of Epo treatment; performance measures (Sens., Spec., +LR, −LR) calculated by S.T. | | | | Hb increase ≥ 1 g/dl after 4 weeks: 792/1054 (75%) responded; Hb increase < 1 g/dl: 284/962 (30%) responded; specificity 678/940 (72%); sensitivity 792/1076 (74%); +LR 2.6; −LR 0.4 [positive test: Hb↑ ≥ 1 g/dl; target: response]
Demetri 1998 | No further details reported; 44% of patients with increase < 1 g/dl achieved Hb response | | | | Hb increase ≥ 1 g/dl after 4 weeks: 81% responded
Glimelius 1998 | Performance measures (Sens., Spec., +LR, −LR) calculated by S.T.; p-values reported separately for different treatment arms: 2000 IU/l: 10/17 versus 5/17 (p < 0.05) and 10000 IU/l: 20/21 versus 10/16 (p < 0.05) | | Hb increase > 0.5 g/dl after 2 or 3 weeks: 30/38 (79%) responded; Hb increase ≤ 0.5 g/dl after 2 or 3 weeks: 15/33 (45%) responded; specificity: 18/26 (69%); sensitivity 30/45 (67%); +LR 2.2; −LR 0.5 [test positive: Hb increase > 0.5 g/dl; target: response]
González-Barón 2002 | Since a large amount of possible factors (early changes) were tested only significant factors in the discriminant analysis are described in detail here; no further details are given for Hb increase therefore, no performance measures (Sens., Spec., +LR, −LR) could be calculated | Factors at 2 weeks which did not significantly discriminate between responders and non-responders: RBC (absolute and increase), Hct (absolute and increase), reticulocytes (absolute and increase), serum iron (absolute and increase), ferritin (absolute and increase), transferrin (absolute and increase), transferrin saturation (absolute and increase), erythropoietin level (absolute and increase) | Factors at 4 weeks which did not significantly discriminate between responders and non-responders: RBC (absolute and increase), Hct (absolute and increase), reticulocytes (absolute and increase), serum iron (absolute and increase), ferritin (absolute and increase), transferrin (absolute and increase), transferrin saturation (absolute and increase), erythropoietin level (absolute and increase) | Discriminatory analysis and logistic regression showed that Hb (absolute) at 4 weeks and Hb increase at 4 (using a cut-off of 0.5 g/dl) weeks were the best variables in predicting response; response probable: Hb increase ≥ 0.5 g/dl after 4 weeks: predictive power 89%; response not probable: Hb increase < 0.5 g/dl after 4 weeks: predictive power 71%
Littlewood 2003 | Performance measures (Sens., Spec., +LR, −LR) calculated by S.T. only for the most significant factors (Hb increase 0.3 G7dl after 2 weeks and 1 g/dl after 4 weeks) | Hb increase > 0.3 g/dl after 2 weeks: 141/186 (76%) responded; Hb increase ≤ 0.3 g/dl after 2 weeks: 149/247 (60%) responded; > 0.3 versus ≤ 0.3: p < 0.001; specificity: 98/143 (69%); sensitivity: 141/290 (49%); +LR: 1.5; −LR: 0.7 [positive test: Hb > 0.3 g/dl; target: response] | Hb increase > 0.5 g/dl after 2 weeks: 117/152 (77%) responded; Hb increase ≤ 0.5 g/dl after 2 weeks: 173/281 (62%) responded; > 0.5 versus ≤ 0.5: p = 0.001 | Transferrin saturation (absolute) > 20% after 2 weeks: 34/48 (71%) responded; transferrin saturation ≤ 20% after 2 weeks: 41/60 (68%) responded; > 20% versus ≤ 20%: p = 0.779 | Transferrin saturation (absolute) > 40% after 2 weeks: 10/13 (77%) responded; transferrin saturation ≤ 40% after 2 weeks: 65/95 (68%) responded; > 40% versus ≤ 40%: p = 0.553 | Transferrin saturation increase > 20% after 2 weeks: 3/5 (60%) responded; transferrin saturation increase ≤ 20% after 2 weeks: 69/97 (71%) responded; > 20% versus ≤ 20%: p = 0.976 | Transferrin saturation increase > 25% after 2 weeks: 2/3 (67%) responded; transferrin saturation increase ≤ 25% after 2 weeks: 70/99 (71%) responded; > 25% versus ≤ 25%: p = 1.0 | Ferritin level (absolute) > 400 ng/ml after 2 weeks: 27/47 (57%) responded; ferritin level (absolute) ≤ 400 ng/ml after 2 weeks: 52/69 (75%) responded; > 400 ng/ml versus ≤ 400 ng/ml: p = 0.042 | Reticulocytes increase > 0.8% after 2 weeks: 134/185 (72%) responded; reticulocytes increase ≤ 0.8% after 2 weeks: 128/210 (61%); > 0.8% versus ≤ 0.8%: p = 0.016 | Hb increase > 1.0 g/dl after 4 weeks: 219/250 (88%) responded; Hb increase ≤ 1.0 g/dl after 4 weeks: 151/288 (52%) responded; > 1.0 versus ≤ 1.0: p < 0.001; specificity: 137/168 (82%); sensitivity: 219/370 (59%); +LR: 3.2; −LR: 0.5 [positive test: Hb > 1.0 g/dl; target: response] | Transferrin saturation (absolute) > 20% after 4 weeks: 83/129 (64%) responded; transferrin saturation ≤ 20% after 4 weeks: 98/134 (73%) responded; > 20% versus ≤ 20%: p = 0.124
Littlewood 2003, continued | Performance measures (Sens., Spec., +LR, −LR) calculated by S.T. only for the most significant factors (Hb increase 0.3 G7dl after 2 weeks and 1 g/dl after 4 weeks) | Transferrin saturation (absolute) > 40% after 4 weeks: 19/39 (49%) responded; transferrin saturation ≤ 40% after 4 weeks: 162/224 (72%) responded; > 40% versus ≤ 40%: p = 0.003 | Transferrin saturation increase > 20% after 4 weeks: 9/18 (50%) responded; transferrin saturation increase ≤ 20% after 4 weeks: 157/221 (71%) responded; > 20% versus ≤ 20%: p = 0.062 | Transferrin saturation increase > 25% after 4 weeks: 4/12 (33%) responded; transferrin saturation increase ≤ 25% after 4 weeks: 162/227 (71%) responded; > 25% versus ≤ 25%: p = 0.014 | Reticulocytes increase > 0.8% after 4 weeks: 182/249 (73%) responded; reticulocytes increase ≤ 0.8% after 4 weeks: 156/246 (63%); > 0.8% versus ≤ 0.8%: p = 0.021 | Transferrin saturation (absolute) > 40% after 4 weeks: 19/39 (49%) responded; transferrin saturation ≤ 40% after 4 weeks: 162/224 (72%) responded; > 40% versus ≤ 40%: p = 0.003
Cazzola 2003 | Unclear how cut-off value was determined | | | Hb increase ≥ 0.1 g/dl after 3 weeks: HR 1.1 (95%-CI: 1.0–1.1), p < 0.00001
Cazzola 2003 | Unclear how cut-off values were determined | sTFR increase after 2–3 weeks > 15% versus ≤ 15%: HR 1.6 (95%-CI: 1.1-2-3), p = 0.007 | sTFR increase after 2–3 weeks > 20% versus ≤ 20%: HR 1.6 (95%-CI: 1.2-2-3), p = 0.003 | sTFR increase after 2–3 weeks > 25% versus ≤ 25%: HR 1.7 (95%-CI: 1.2-2-3), p = 0.001
Katodritou 2004 | Multivariate analysis; cut-offs determined by ROC curve; no further details reported (e.g. p-values); absolute values derived from percentages (see brackets) | Increment of reticulocyte hemoglobin at 2 weeks (retics-Ht wk2) compared to baseline (retics-Ht wk0): retics-Ht wk2/retics-Ht wk0 ≥ 1.5: Specificity 10/12 (80%); Sensitivity 20/20 (100%)
McKenzie 2004 | Patients probably already included in Glaspy 1997 and Demetri 1998 | | | | Hb increase ≥ 1 after 4 weeks versus Hb increase < 1 after 4 weeks: Study 1: 84% vs. 47%; Study 2: 79% vs. 49%; Study 3: 80% vs. 44%; (p < 0.0001 for all)
Witzig 2004 | Absolute values and performance measures (Sens., Spec., +LR, −LR) calculated by S.T. (for percentages used see brackets) | Serum ferritin level (absolute) < 400 ng/ml after 2 weeks: 50/65 (77%) responded; serum ferritin level (absolute) ≥ 400 ng/ml after 2 weeks: 16/41 (39%) responded; Specificity 25/40 (63%); Sensitivity 50/66 (76%); +LR 2.0; −LR 0.4 | | | Hb increase ≥ 1 g/dl after 4 weeks: 48/62 (77%) responded; Hb increase < 1 g/dl after 4 weeks: 32/52 (62%) responded; Specificity 20/34 (59%); Sensitivity 48/80 (60%); +LR 1.5; −LR 0.7

Table C73

KQ4: Algorithms

study author | Algorithm | Result (e.g. likelihood ratio) | Comment
Ludwig 1994 | Response not probable: baseline erythropoietin level ≥ 100 IU/l and Hb increase after 2 weeks < 0.5 g/dl; response probable: baseline erythropoietin level < 100 IU/l and/or Hb increase after 2 weeks ≥ 0.5 g/dl | Epo ≥ 100 IU/l and Hb↑ < 0.5 g/dl: 29/31 (94%) not responded; Epo < 100 IU/l and/or Hb↑ ≥ 0.5 g/dl: 9/45 (20%) not responded; Specificity: 36/38 (95%); Sensitivity: 29/38 (76%); +LR 14.5; −LR 0.3 [test positive: Epo ≥ 100 IU/l and Hb↑ < 0.5 g/dl; target: non-response] | Odds ratio 58.0 (95%-CI: 16.3–206.8; p < 0.000000001); multivariate logistic regression
Ludwig 1994 | Response probable: baseline erythropoietin level < 100 IU/l and Hb increase > 0.5 g/dl after 4 weeks; response not probable: baseline erythropoietin level ≥ 100 IU/l and/or Hb increase ≤ 0.5 g/dl after 4 weeks | Epo < 100 IU/l and Hbc ≥ 0.5 g/dl: 15/15 (100%) responded; Epo ≥ 100 IU/l and/or Hb↑ < 0.5 g/dl: 23/61 (38%) responded; Specificity: 38/38 (100%); Sensitivity: 15/38 (39%); +LR not applicable; −LR 0.6 [test positive: Epo < 100 IU/l and Hbc ≥ 0.5 g/dl; target: response] | Odds ratio 50.8 (95%-CI: 2.9–889.1; p < 0.000001); multivariate logistic regression
Cazzola 1995 | Step 1: baseline erythropoietin level ≤ 50 IU/L or erythropoietin O/P ratio ≤ 0.9 response probable if at least one criterion fulfilled. Step 2: after 2 weeks increase of Hb ≥ 0.3 g/dl response probable | Step 1: Epo ≤ 50 IU/l or O/P ratio ≤ 0.9: 30/40 responded; Epo > 50 IU/l or O/P ratio > 0.9: 1/8 responded; specificity 7/17 (41%); sensitivity 30/31 (97%); +LR 1.6; −LR 0.08 [positive test: Epo ≤ 50 IU/l or O/P ratio ≤ 0.9; target: response]; Step 2: Hb↑ ≥ 0.3 g/dl: 30/34 responded; Hb↑ ≤ 0.3 g/dl: 0/6 responded; specificity 6/10 (60%); sensitivity 30/30 (100%); +LR 2.5; −LR not applicable [positive test: Hb↑ ≤ 0.3 g/dl; target: response] | Unclear why increase in Hb at 2 weeks was chosen and how cut-off value was determined; authors report predictive values (positive and negative) although described as specificity and sensitivity; performance measures (“Result”) calculated by S.T.
Henry 1995 | Response probable: Hb increase ≥ 0.5 g/dl and reticulocytes increase ≥ 40000/μl after 2 weeks | Hb↑ ≥ 0.5 g/dl + ret.↑ ≥ 40000/μl: 14/21 (67%) responded; Hb↑ < 0.5 g/dl and/or ret.↑ < 40000/μl: 59/111 (53%) responded; specificity: 52/59 (88%); sensitivity: 14/73 (19%); +LR: 1.6; −LR: 0.9 [positive test: Hb↑ ≥ 0.5 g/dl + ret.↑ ≥ 40000/μl; target: response] | Performance measures (“Result”) calculated by S.T.
Henry 1995 | Response not probable: Hb increase < 0.5 g/dl and reticulocytes increase < 40000/μl after 2 weeks | Hb↑ < 0.5 g/dl + ret.↑ < 40000/μl: 32/62 (52%) not responded; Hb↑ ≥ 0.5 g/dl and/or ret.↑ ≥ 40000/μl: 27/70 (39%) not responded; specificity: 43/75 (57%); sensitivity: 30/57 (53%); +LR: 1.2; −LR: 0.8 [positive test: Hb↑ < 0.5 g/dl + ret.↑ < 40000/μl; target: non response] | Performance measures (“Result”) calculated by S.T.
Henry 1995 | Response probable: Hb increase ≥ 1 g/dl and reticulocytes increase ≥ 40000/μl after 4 weeks | Hb↑ ≥ 1 g/dl + ret.↑ ≥ 40000/μl: 27/32 (84%) responded; Hb↑ < 1 g/dl and/or ret.↑ < 40000/μl: 44/95 (46%) responded; specificity: 51/56 (91%); sensitivity: 27/71 (38%); +LR: 4.3; −LR: 0.7 [positive test: Hb↑ ≥ 0.5 g/dl + ret.↑ ≥ 40000/μl; target: response] | Performance measures (“Result”) calculated by S.T.
Henry 1995 | Response not probable: Hb increase < 1 g/dl and reticulocytes increase < 40000/μl after 4 weeks | Hb↑ < 1 g/dl + ret.↑ < 40000/μl: 29/45 (64%) not responded; Hb↑ ≥ 1 g/dl and/or ret.↑ ≥ 40000/μl: 27/82 (33%) not responded; specificity: 55/71 (77%); sensitivity: 29/56 (52%); +LR: 2.3; −LR: 0.6 [positive test: Hb↑ < 0.5 g/dl + ret.↑ < 40000/μl; target: non response] | Performance measures (“Result”) calculated by S.T.
Glaspy 1997 | Response probable: Hb increase after 4 weeks ≥ 1 g/dl and no RBCT requirement during first 4 weeks | Hb↑ ≥ 1 g/dl + no RBCT: 664/817 (81%) responded; Hb↑ < 1 g/dl and/or RBCT: 412/1199 (34%) responded; specificity: 787/940 (84%); sensitivity: 664/1076 (62%); +LR: 3.8; −LR: 0.5 [positive test: Hb↑ ≥ 1 g/dl + no RBCT; target: response] | Performance measures (“Result”) calculated by S.T.
Glaspy 1997 | Response not probable: Hb increase < 1 g/dl and RBCT requirement during first 4 weeks | Hb↑ < 1 g/dl + RBCT: 160/205 (78%) not responded; Hb↑ ≥ 1 g/dl and/or no RBCT: 780/1811 (43%) not responded; specificity: 1031/1076 (96%); sensitivity: 160/940 (17%); +LR: 4.1; −LR: 0.9 [positive test: Hb↑ < 1 g/dl + RBCT; target: non-response] | Performance measures (“Result”) calculated by S.T.
Fjornes 1998 | Response probable: baseline erythropoietin level < 75 IU/l and serum creatinine > ULN and creatinine clearance < 60 ml/min; response not probable: baseline erythropoietin level ≥ 75 IU/l and serum creatinine ≤ ULN and creatinine clearance ≥ 60 ml/min | Epo < 75 IU/l and Crea < 60ml/min: 8/8 responded; Epo ≥ 75 IU/l and/or Crea ≥ 60 ml/min: 2/14 responded; Specificity 12/12 (100%); Sensitivity 8/10 (80%); +LR not applicable; −LR 0.2 [positive test: Epo < 75 IU/l and Crea < 60ml/min; target: response] | No details reported regarding derivation of the model (e.g. derivation of cut-off values); performance measures (“Result”) calculated by S.T.
Littlewood 2003 | Algorithms incorporating two or three factors (baseline parameters plus early changes) were essentially no better than single factors, i.e. change in Hb after 4 weeks | | Data not reported here (12 algorithms tested/reported in Littlewood 2003)
Witzig 2004 | Response not probable: erythropoietin level ≥ 100 IU/l and Hb increase after 4 weeks < 0.5 g/dl; response probable: erythropoietin level < 100 IU/l and/or Hb increase after 4 weeks ≥ 0.5 g/dl | Epo ≥ 100 IU/l and Hb↑ < 0.5 g/dl: 6/12 (50%) not responded; Epo < 100 IU/l and/or Hb↑ ≥ 0.5 g/dl: 26/92 (28%) not responded; Specificity: 66/72 (92%); Sensitivity: 6/32 (19%); +LR 2.3; −LR 0.9 [positive test: Epo ≥ 100 IU/l and Hb↑ < 0.5 g/dl; target: non-response] | This is a slightly modified version of the algorithm described by Ludwig 1994 (changes at 4 weeks instead of 2 weeks); performance measures (“Result”) calculated by S.T.; HR not independent of RBCT
Witzig 2004 | Response probable: erythropoietin level < 100 IU/l and Hb increase ≥ 0.5 g/dl after 4 weeks; response not probable: erythropoietin level ≥ 100 IU/l and/or Hb increase < 0.5 g/dl after 4 weeks | Epo < 100 IU/l and Hb↑ ≥ 0.5 g/dl: 43/51 (84%) responded; Epo ≥ 100 IU/l and/or Hb↑ < 0.5 g/dl: 29/53 (55%) responded; Specificity: 24/32 (75%); Sensitivity: 43/72 (60%); +LR 2.4; −LR 0.5 [positive test: Epo < 100 IU/l and Hb↑ ≥ 0.5 g/dl; target: response] | This is a slightly modified version of the algorithm described by Ludwig 1994 (changes at 4 weeks instead of 2 weeks); performance measures (“Result”) calculated by S.T.; HR not independent of RBCT