# Sample Data Abstraction Forms

## KQ1 Sample Data Abstraction Forms

I. Study Eligibility

first author, year:

Reviewer:

TYPE OF STUDY 1. Is the study described as randomised? NB: Answer ‘no’ if the study is in cross over or quasi randomised design | Yes OR Unclear Go to Next question | No Exclude
PARTICIPANTS IN THE STUDY 2. Did the participants in the study have a previous treated or untreated malignant disease? | Yes OR Unclear Go to Next question | No Exclude
3. Were the participants anaemic or at risk for anaemia from chemotherapy and/or radiotherapy or their malignant disease? | Yes OR Unclear Go to Next question | No Exclude
INTERVENTIONS IN THE STUDY 4. Was one group given Epoetin alfa or Epoetin beta subcutaneously or intravenously (not orally) in a dose of at least 300U /kg /week for at least four weeks? | Yes OR Unclear Go to Next question | No Exclude
5. Did the control group receive the same care (e.g., chemotherapy and supportive therapies) with or without placebo? | Yes OR Unclear Go to Next question | No Exclude
OUTCOMES IN THE STUDY 6. Did the study document hematologic response? Or Did the study document number of patients or red blood cell units transfused? Or Did the study document QUALITY of life? | Yes OR Unclear Go to Next question | No Exclude
Final Decision 1x ‘no’ ⇒ exclude 1x ‘unclear’ ⇒ unclear | Include Unclear | Exclude

## Inclusion/exclusion criteria

- Include
  Randomized controlled trials (RCTs).

- Exclude
  Non-randomized studies, in particular quasi-randomized such as where allocation is based on date of birth or day of the month.
  RCTs with 10 or fewer subjects in any study arm at randomization.

### Population

- Include
  Age
  Participants of every age will be included.
  Careful note will be made as to whether included studies have children (persons <18 years) amongst their study populations.

- Include
  Disease
  Participants diagnosed with malignant disease, using clinical and histological/cytological criteria irrespective of type or stage of the disease or previous therapy will be included.

- Include
  Level of hemoglobin/anemia and nature of anemia
  All participants with anemia or at risk of anemia from chemotherapy, and/or radiotherapy or the underlying malignant disease will be included. Other causes of anemia such as hemolysis, iron deficiency and occult bleeding should have been excluded in participants to included studies. Studies where the mean or median hemoglobin is >13 g/dl will be excluded.

- Exclude
  Studies where erythropoietin is being given in the context of myeloablative chemotherapy ahead of bone marrow or peripheral blood stem cell transplantation will be excluded.

- Exclude
  Studies where erythropoietin is being given for short-term preoperative treatment to correct anemia or to support collection of autologous blood prior to cancer surgery will also excluded.

### Intervention

Epoetin alfa and epoetin beta and darbepoetin alfa based therapies at doses and duration indicated in their license/approval.

### Comparator

Any comparator will be acceptable, provided the only difference in initial treatment between treatment and control arms is the use of erythropoietin.

The most common comparator anticipated will be no erythropoietin followed by best standard care where red blood cell (RBC) transfusion will be given when a study participant’s hemoglobin falls to an unacceptably low level (often 10g/dl). Ideally a protocol for when blood should be instigated should be described. The same rules on rescue RBC transfusion should also apply in the erythropoietin arm.

Concomitant supportive treatments such as G-CSF or iron supplementation will be allowed provided they have been applied equally in each arm of the study. Their presence/absence will be carefully recorded. Studies where concomitant supportive treatments are just applied in one or the other arm alone will be excluded.

### Outcomes

Outcomes sought from studies that meet the inclusion criteria are as follows:

- Hematologic response to treatment [Hb increase of 2g/dL or Hct increase of 6%]
- Need for blood transfusion after treatment
- Health-related quality of life
- Fatigue
- Survival
- Tumor response
- Adverse events/toxicity [thrombotic events, hypertension, hemorrhage/thrombocytopenia, rash/irritation/pruritus, seizures]
- Patient preference

Accurate information on patient preference may be scant in the absence of crossover trials. We are not aware of any in this topic area.

All outcomes will be considered in two groups of time periods: outcomes measured up to 6 months and outcomes measured beyond 6 months.

Extractor initials:

Section 1: Paper details

Date:

Section 1. Paper details.

Paper title:
Ref manager number and initials:
First Author:
Authors contact address (if available)
Publication year
Full text article or only published as an abstract
Number of trials included in this paper: (if more than one, complete separate extraction forms for each, and add letters A, B, C, etc to the paper name)
Papers of other trials with which this may link: (if other papers report further results of this trial, incorporate them onto this form, and note what has been here)
Trial design: Singlecentre or multicentre
Source of participants (inpatients or outpatients)
Method of recruitment:
Dates for recruitment:
Funding: pharmaceutical or not (give details);
In industry submission?
In Cochrane Review? If yes is it an included study, an excluded study or ongoing trial?

Aim of study:

Details of comparisons evaluated in this trial:

| X = yes | comments
Epoetin versus placebo
Epoetin versus no treatment
Epo versus standard care
Epo versus administration
Epo versus brand
Epo versus dose
| x = yes | comments
Epoetin plus RBC Transfusions in all arms
Epoetin plus iron suppl. in all arms
Epoetin plus G-CSF in all arms
Epoetin plus other

Eligibility criteria – describe in text box below:

Exclusion criteria - describe in box below:

How was epo deficiency derived? ie tested for epo or diagnosed by elimination of other causes of anaemia?

Staging evaluation:

Histology/Cytology Yes or no
Describe
Was compliance assessed?
If so describe:

Section 2: Outcomes sought

Outcomes
Primary
Secondary
QoL

Describe statistics used:

Any power calculations and if so for what?

Time periods of surveillance – describe

Maximum duration of surveillance:

Notes:

Dichotomous data: N/n: number of events/total number of patients

Continuous data: N/n/SD: treatment mean of outcome parameter/total number of patients in group/treatment standard deviation of outcome parameter.

Section 3. Intervention

| Intervention | Control | | comments
| Group 1[n=] (%) | Group [n=](%)
Intervention/control
Epo Dose IU/kg
Epo dose frequency
Epo dose per week IU/kg
Duration of epo treatment (weeks)
Dosing regimen*
Route (s.c or iv)
RBC transfusion trigger ? if so what ?
iron supplementation? if so describe

*Dosing regimen:

Fixed (F): all patients were given continuously the same dose of Epoetin

Decreasing (D): patients with a defined response were given a reduced amount of Epoetin

Increasing (I): patients showing no response within a specified period of time were given an increased dose of Epoetin

Notes: e.g. describe dosing regime:

1. Chemotherapy:

Chemotherapy regime describe:

Cycles repeated (days):

Times:

Adjustments:

Notes:

(if stated add the number of pts on each chemo regime)

{describe} | | Intervention {} | Control {} | comments
Please give numbers and percentages | | Group 1 [n=] (%) | Group [n=] (%) | Group 2 [n=] (%)
Chemo agents (list) ↓ | Dose/route/time schedule

2. Radiotherapy:

Radiotherapy regimen

Radiation repeated every days

Times:

Adjustments:

Notes:

(if stated add the number of pts on each chemo regime)

{describe} | | Intervention {} | Control {} | comments
Please give numbers and percentages | | Group 1 [n=] (%) | Group [n=] (%)
Radiotherapy regime (list) ↓ | Dose/route/time schedule

Section 4. Results - Patient Characteristics

Comment: number of patients evaluated usually varies in each outcome

Number of patients recruited for this study:
Number of patients randomised:
Number of patients evaluated:
Number of patients recruited for QoL:
Number of patients evaluated in QoL

{} | Intervention {} Group 1 [n=] (%) | Control {} Group [n=] (%) | comments
Total Patients randomised
Total Patients evaluated
Total Patients not evaluated
Exclusions Reasons:
Withdrawals reasons:
Lost to follow up reasons:

Were the withdrawals and losses to follow up less than 10% of the study population?:

Characteristics at baseline: Comment: this was designed to fit also studies with several treatment arms add extra columns if need be.

{describe} | Intervention {} | Control {} | comments
Please give numbers and percentages | Group 1 [n=] (%) | Group [n=] (%)
Age (state if mean; median; range)
Gender M/F | / | / | /
Disease category-/Solid or haem
List diseases ↓
Disease Stage
I
II
III
IV
Bone Marrow Involvement
Performance status (Karnofsky, etc
0
1
2
3
4
No. with previous epo therapy (describe if details given)
No. with previous transfusion
n = transfusion at baseline (give Hb value for pts with previous transfusion)
Hb baseline (all patients)
Hb baseline (no prior transfusion/n patients)
HKT baseline
serum EPO, no. pts tested
serum EPO baseline
serum iron baseline
serum ferritin baseline

Are these characteristics roughly balanced between the groups?:

Section 4. Results – Outcomes

Maximum duration of surveillance:
Describe surveillance: ie time on epo, time after trial stopped

dichotomous data: N/n : number of events/total number of patients in group

continuous data: N/n/SD : treatment mean of outcome parameter/total number of patients in group/treatment standard deviation of outcome parameter

Haematologic response:

| Definition
complete response
partial response
no response

{describe} | Intervention {} | Control {} | comments
| Group 1 [n=] (%) | Group [n=] (%)
overall response
complete response
partial response
no response

Data extracted from which text, table, figure?

Expert statistical attention needed?

Notes:

Haemoglobin:

{describe} | Intervention {} | Control {} | comments
| Group 1 [n=] (%) | Group [n=] (%)
Hb (g/dl) Baseline
Hb (g/dl) Finish of epo therapy(put time point in brackets)
Hb (g/dl) Endpoint (put time point in brackets)
Hb change (g/dl) if stated in the paper (put time point in brackets) {SD}
Other time points

Data extracted from which text, table, figure?

Expert statistical attention needed?

Notes:

Haematocrit:

{describe} | Intervention {} | Control {} | comments
| Group 1 [n=] (%) | Group [n=] (%)
Hematocrit Baseline
Hematocrit Finish of epo therapy(put time point in brackets)
Hematocrit Endpoint (put time point in brackets)
Hematocrit Change if stated in the paper (put time point in brackets) {SD}
Other time points

Data extracted from which text, table, figure?

Expert statistical attention needed?

Notes:

Transfusion:

{describe} | Intervention {} | Control {} | comments
| Group 1 [n=] (%) | Group [n=] (%)
Number of Patients transfused
Number of RBC-units transfused
Number of RBC-units transfused per patient
Number of RBC-units transfused/patient/4weeks

Data extracted from which text, table, figure?

Expert statistical attention needed?

Notes:

Quality of Life/Performance status

Quality of life outcomes

{describe} | Intervention {} | Control {} | p-value | comments
| Group 1 [n=] (%) | Group [n=] (%)
QoL Baseline
FACT G – 27 items
Domain 1
Domain 2
Domain 3
Domain 4
FACT F – 13 items
QOL Score - endpoint
FACT G – 27 items
Domain 1
Domain 2
Domain 3
Domain 4
FACT F – 13 items
QOL Score - overall
FACT G – 27 items
Domain 1
Domain 2
Domain 3
Domain 4
FACT F – 13 items
Performance
Score
Endpoint
Performance
Score
Change

Data extracted from which text, table, figure?

Expert statistical attention needed?

Notes:

Tumour response

Reported?:

| Definition
CR complete response
PR partial response
NR no response
When was tumour response assessed, ie at end of study, at n weeks?
How was tumour response assessed? clinical exam, radiotherapy, computer tomography, other?

{describe} | Intervention {} Group 1 [n=] (%) | Control {} Group [n=] (%) | Comments, p-value
CR
PR
NR

Data extracted from which text, table, figure?

Expert statistical attention needed?

Notes:

Mortality Reported?:

{describe} Cause of death | Intervention {} Group 1 [n=] (%) | Control {} Group [n=] (%) | Comments, p-value

Data extracted from which text, table, figure?

Expert statistical attention needed?

Notes:

Adverse events:

document during which period the adverse events occurred: during study period, after completion of study

{describe} | Intervention {} | Control {} | Comments, p-value
| Group 1 [n=] (%) | Group [n=] (%)
Hypertension (definition)
Rash/Irritation
Pruritis
Mortality
Thrombotic Event (Definition)
Seizure
Haemorrhage/Thrombopenia
Fatigue: Definition:
EPO Antibodies

Other adverse events:

{describe} | Intervention {} Group 1 [n=] (%) | Control {} Group [n=] (%) | Comments, p-value

Data extracted from which text, table, figure?

Expert statistical attention needed?

Notes:

Survival

Reported?:

Main results | HR | CI | p | Comments (inc details)
Unadjusted (logrank or M-H)
Stratified
Cox model

Other data | Group 1 | Group 2 | Total | Comments (inc details)
Number of events
Number analysed
Median survival
Follow-up (min/max/median)
Proportions alive at t
Kaplan Meier curves?
Other survival curves?

Summary data estimates
Method | O-E | V | Favours… | Comments (inc details)

*complete one sheet for each comparison between groups

Comments

Section 5 - Study validity form

TREATMENT ALLOCATION | Yes | No | Unclear | Comments
1. Was allocation truly random? Yes: random numbers, coin toss, shuffle etc No: for patient number, date of birth, alternate Unclear: if the method of randomisation was not stated or unclear
2. Was the treatment allocation concealed? Yes: central allocation at trials office or pharmacy, sequentially numbered or coded vials, other methods where the trialist allocating treatment could not be aware of the treatment Inadequate: allocation was alternate (by patient, day of the week, admission on ward, etc) or based on information, such as date of birth, already known to the trialist) Unclear: insufficient information given
SIMILARITY OF GROUPS
3.Were the patients characteristics at baseline similar in all groups?
IMPLEMENTATION OF MASKING
4. Was the treatment allocation masked from the participants? (either stated explicitly, or an identical placebo is used)
5. Was the treatment allocation masked from the clinicians?
COMPLETENESS OF THE TRIAL
6. Were the number of withdrawals, drop outs and lost to follow up in each group stated? NB: Yes, if there have not been any drop outs or lost to follow up
7. Did the analysis include an intention-to- treat analysis and were there less than 10% of patients per study arm excluded?

KQ2 and KQ3 Sample Data Abstraction Forms

Paper details

Paper title:
Ref manager number and initials
First Author:
Authors contact address (if available)
Publication year
Full text article or only published as an abstract
Number of trials included in this paper:
Papers of other trials with which this may link: (if other papers report further results of this trial, incorporate them onto this form, and note what has been here)
: Singlecentre or multicentre
Source of participants (inpatients or outpatients)
Method of recruitment:
Dates for recruitment:
Funding: pharmaceutical or not (give details);
In industry submission?

Outcomes sought

Aim of study:

To demonstrate superiority of correction/maintenance vs standard-weekly dose based on proportion of patients requiring:
Outcomes | •
Secondary
QoL

Patient eligibility criteria

Patient exclusion criteria - describe in box below:

Describe statistics used:

Any power calculations and if so for what?/Other comments

Section 3. Intervention

Sample | Intervention | Control | comments
Intervention/control
Pat randomized
Initiating Darbepoetin
Single Dose IU
dose frequency
Dose per week
Duration of epo treatment (weeks)
Dosing regimen*
Route (s.c or iv)
Cumulative Dose Median/trial
RBC transfusion trigger ? if so what ?
iron supplementation? if so describe

*Dosing regimen:

Fixed (F):all patients were given continuously the same dose of Epoetin

Decreasing (D): patients with a defined response were given a reduced amount of Epoetin

Increasing (I): patients showing no response within a specified period of time were given an increased dose of Epoetin

Notes: e.g. describe dosing regime:

Time periods of surveillance – describe

Screening
Random test period
Test/treatment:
Observation period

Maximum duration of surveillance:

Quality Assessment

Remarks

Characteristics of included studies

study author | participants randomised | drug | Intervention Front Loading | Control Continious dose | weight based or fix | Maximum duration of EPO medication (weeks) | dose adjustment | iron | transfusion trigger (when transfusion assessed) | publication | primary and secondary outcomes of the study
Sample

study author | n randomised | cancer details | cancer category | therapy | Hb eligibility criteria | Hb baseline High | Hb baseline low) | hb category | In arm age reported (mean, SD) range if not reported otherwise | control arm age reported (mean or median, SD), range | age category (children, adults, eldery (>65)
Sample

study author | Random | allocation | blinding | placebo | ITT or 10% | similar | high or low quality
Sample

Hematologic Response

Definition as protocol

study author | Hb response definition | Intervention n | Intervention N | Proportion (%) | Control n | Control N | Proportion (%) | Comments

Other definitions

study author | Hb response definition | | Hb response n Intervention | | Hb response Control | | Hb response, comments
Sample | Mean Hb end of treatment | | 11,5 (CI 11,4 11,6) | | 11,7 (11,6 ; 11,8) | | In Poster
Sample

Subgroups:

Participants receiving red blood cell transfusions

Study ID | Intervention n | Intervention N | Proportion (%) | Control n | Control N | Proportion (%) | Comments
Sample

Subgroups:

Quality of Life (QoL):

Only Graph on copy similar increase FACT AN F Subscale score

| Baseline Intervention | Change Intervention | Baseline Control: | Change: Control | p-value | comments
??
??

Tumor response

For Q3 not regularly assed and also not reported.

Overall survival

study author | randomized | Evaluated | method | follow up | events INTERVENTION (n/N), reported are deaths if not stated otherwise | events control (n/N), reported are deaths if not stated otherwise | HR (95% CI) | Comments
Sample

Adverse effects

Thromboembolic

Baseline HB:

Target Hb:

Intervention Hb

Study ID | Intervention n | Intervention N | Percentage (%) | Control n | Control N | Percentage (%) | Definition of | Comments
Sample

Hypertension

Study ID | Treatment n | Treatment N | Percentage | Control n | Control N | Percentage | Definition of Hypertension | Comments
Sample

Rash

Study ID | Treatment n | Treatment N | Percentage | Control n | Control N | Percentage | Definition of | Comments
Sample

Seizures

Study ID | Treatment n | Treatment N | Percentage | Control n | Control N | Percentage | Definition of | Comments
Sample

Cost

Not/reported

KQ4 Sample Data Abstraction Forms

KQ4 Sample Abstraction Forms, Study Characteristics, Part I

Study author | Type of underlying study (basic population) | Type of predictive factors study | Objective as defined by study authors | Drug | Dose per week | Duration of EPO medication | Dose adjustment | Transfusion trigger | Type of publication | Outcomes of the underlying study | Cancer details

KQ4 Sample Abstraction Forms, Study Characteristics, Part II

Underlying therapy | N of patients in underlying study (randomized or included if no randomization) | N of patients analyzed for predictive factors | Hb eligibility criteria | Hb baseline [mean g/dl (SD) if not stated otherwise] | Age [median (range) if not stated otherwise] | HR overall (patients treated with Epo) | Number of patients with Epo dose adjustment | Hb response definition | Comment | Related publications | Checked

KQ4 Sample Abstraction Forms, Study Quality, Part I

study author | Type of predictive factors study | Refutable hypotheses reported | Objective prospectively defined | Inclusion criteria defined for predictive factors study | Sample size calculation (method) | Number and characteristics of excluded patients reported | Missing data handling reported, including losses to follow-up reported | Internal validation (method) | Follow- up at least four weeks | Selection process of possible predictive factors explained and adequate

KQ4 Sample Abstraction Forms, Study Quality, Part II

Cut-off values for continuous variables explained and adequate | Performance measures reported (Sens., Spec., +LR, −LR) | Method of statistical analysis | Prognostic variables fully defined | Confidence intervals reported | Multivariable analysis
Cut-off values for continuous variables explained and adequate | Performance measures reported (Sens., Spec., +LR, −LR) | Method of statistical analysis | Prognostic variables fully defined | Confidence intervals reported | Statistical package used | Coding of variables reported | Problem with overfitting | Conformity of linearity for ranked variables reported | Tests of interaction performed

KQ4 Sample Abstraction Forms, Serum Epo, O/P level

study author | Cut-off value (value) | N patients responded above cut-off | N patients responded below cut-off | Result (serum epo) (e.g. likelihood ratio) | Result (O/P ratio) (e.g. likelihood ratio) | Comments | Conclusions

KQ4 Sample Abstraction Forms, Ferritin, Iron, Transferrin

study author | Cut-off value (value) | N patients responded above cut-off | N patients responded below cut-off | Result [ferritin] (e.g. likelihood ratio) | Result [iron] (e.g. likelihood ratio) | Result [transferrin] (e.g. likelihood ratio) | Result [transferrin saturation] (e.g. likelihood ratio) | Comments | Conclusions

KQ4 Sample Abstraction Forms, Soluble Transferrin Receptor (sTFR)

study author | Cut-off value (value) | N patients responded above cut-off | N patients responded below cut-off | Result (serum sTFR) (e.g. likelihood ratio) | Result (O/P ratio) (e.g. likelihood ratio) | Comments | Conclusions

KQ4 Sample Abstraction Forms, Blood Count (ex. Hb or RBC)

study author | Cut-off value (value) | Type of cells | N patients responded above cut-off | N patients responded below cut-off | Result (e.g. likelihood ratio) | Comments | Conclusions

KQ4 Sample Abstraction Forms, Creatinine Clearance

study author | Cut-off value (value) | N patients responded above cut-off | N patients responded below cut- off | Result [creatinine clearance] (e.g. likelihood ratio) | Result [serum creatinine] (e.g. likelihood ratio) | Comments | Conclusions

KQ4 Sample Abstraction Forms, Other Baseline Parameters

study author | Parameter | Parameter | Parameter | Parameter | Parameter | Parameter | Parameter | Comments | Conclusions

KQ4 Sample Abstraction Forms, Early Changes

study author | Comments | Parameter | Parameter | Parameter | Parameter | Parameter | Parameter | Parameter

KQ4 Sample Abstraction Forms, Algorithms

study author | Algorithm | Result (e.g. likelihood ratio) | Comment

KQ4 Sample Abstraction Forms, Overview, Part I

| | | Association? | | Cut-Offs
Study Author | Comment | Patients in predictive factor study | Pos? | Neg? | Pos? | Neg? | O/P | Reference to? | Pos? | Neg? | Ferritin | Pos? | Neg? | Iron | Pos? | Neg?

KQ4 Sample Abstraction Forms, Overview, Part II

Transferrin | Pos? | Neg? | Transferrin Saturation | Pos? | Neg? | sTFR | Pos? | Neg? | Reticulocytes | Pos? | Neg? | Leukocytes | Pos? | Neg?

KQ4 Sample Abstraction Forms, Overview, Part III

Platelets | Pos? | Neg? | Neutrophils | Pos? | Neg? | Creatinine | Pos? | Creatinine clearance | Pos? | Interleukin-1 | Pos? | Interleukin-6 | Pos? | TNF | Pos? | Others

KQ4 Sample Abstraction Forms, Overview, Part IV

Hb increase after 2–3 weeks | Pos? | Hb increase after 4 weeks | Pos? | Serum ferritin absolute after 2 weeks | Pos? | Reticulocyte increase after 2 weeks | Pos?

KQ4 Sample Abstraction Forms, Sample Sizes, Part I

EPO | | O/P | | Ferritin | | Cell sounts | | Creatinine | | HB after 2–3 weeks
Sample size | N studies | Sample size | N studies | Sample size | N studies | Sample size | N studies | Sample size | N studies | Sample size | N studies

KQ4 Sample Abstraction Forms, Sample Sizes, Part II

Hb after 4 weeks | | Ret after 4 weeks | | Ferritin after 2 weeks | | Other early | | Algorithm
Sample size | N studies | Sample size | N studies | Sample size | N studies | Sample size | N studies | Sample size | N studies