# Exact Search Strings

## Exact Search Strings

MEDLINE searches refined (performed 3/11/2005)

1. Search (“Erythropoietin”[MeSH] OR “Erythropoietin, Recombinant”[MeSH] OR “Epoetin Alfa”[MeSH] OR “epoetin beta”[Substance Name])
2. Search erythropoietin OR epoetin* OR epo OR eprex OR neorecormon OR aranesp OR procrit
3. 1 OR 2
4. Search “Neoplasms”[MeSH] OR “Carcinoma”[MeSH] OR malignan* OR cancer* OR oncolog* OR myelodysplas* OR tumor* OR tumour* OR neoplas* OR carcinom*
5. 3 AND 4
6. Search (“Randomized Controlled Trial”[Publication Type] OR “Controlled Clinical Trial” [Publication Type] OR “Randomized Controlled Trials”[MeSH]) OR “Random Allocation”[MeSH] OR “Double-Blind Method”[MeSH] OR “Single-Blind Method”[MeSH]
7. Search “Clinical Trial”[Publication Type] OR “Clinical Trials”[MeSH] OR “clinical trial”
8. Search ((singl* OR doubl* OR trebl* OR tripl*) AND (mask* OR blind*))
9. Search “Placebos”[MeSH] OR placebo* OR random*
10. Search “Research Design”[MeSH:NoExp] OR “Comparative Study”[MeSH] OR “Evaluation Studies”[MeSH] OR “Follow-Up Studies”[MeSH]
11. Search “Prospective Studies”[MeSH] OR control* OR prospectiv* OR volunteer*
12. 6 OR 7 OR 8 OR 9 OR 10 OR 11
13. 5 AND 12
14. 13 AND PY=1998–2005 NOT (animals NOT humans)
15. Search “darbepoetin alfa”[Substance Name] OR aranesp OR darbepoetin
16. 15 AND 4
17. 16 AND 12
  This set was not restricted
18. Search “Epidemiologic Studies” [MeSH] OR “Incidence” [MeSH] OR predict* OR prognos* OR course* OR model* OR respon*
19. 5 AND 18
20. 16 AND 18
21. 19 OR 20
22. 21 AND PY=1998–2005 NOT (animals NOT humans)

EMBASE revised search (performed 4/7/2005)

1. ‘erythropoietin’/exp OR ‘erythropoietin, recombinant’/exp OR ‘epoetin alfa’/exp OR ‘epoetin beta’/exp AND [humans]/lim AND [1998–2005]/py
2. erythropoietin OR epoetin* OR eprex OR neocormon OR aranesp OR procrit OR darbepoetin* AND [humans]/lim AND [1998–2005]/py
3. deleted
4. ‘neoplasms’/exp OR ‘carcinoma’/exp AND [humans]/lim AND [1998–2005]/py
5. malignan* OR cancer* OR oncolog* OR myelodysplas* OR tumor* OR tumour* OR neoplas* OR carcinoma* AND [humans]/lim AND [1998–2005]/py
6. #1 OR #2
7. #4 OR #5
8. #6 AND #7
9. ‘clinical trial’:it OR ‘randomized controlled trial’:it AND [1998–2005]/py
10. ‘randomized controlled trials’/exp OR ‘random allocation’/exp OR ‘double-blind method’/exp OR ‘single-blind method’/exp OR ‘clinical trials’/exp OR ‘research design’/exp OR ‘placebos’/exp AND [humans]/lim AND [1998–2005]/py
11. deleted
12. (singl* OR doubl* OR trebl* OR tripl*) AND (mask* OR blind*) AND [humans]/lim AND [1998–2005]/py
13. placebo* OR random* OR control* OR prospectiv* OR volunteer* AND [humans]/lim AND [1998–2005]/py
14. ‘comparative study’/exp OR ‘evaluation studies’/exp OR ‘follow-up studies’/exp OR ‘prospective studies’/exp AND [humans]/lim AND [1998–2005]/py
15. #9 OR #10 OR #12 OR #13 OR #14
16. #8 AND #15
17. #16/EMBASE
18. ‘epidemiologic studies’/exp OR ‘incidence’/exp AND [humans]/lim AND [1998–2005]/py
19. predict* OR prognos* OR course* OR model* OR respon* AND [humans]/lim AND [1998–2005]/py
20. #18 OR #19
21. #8 AND #20
22. #21/EMBASE