# Appendixes

Appendix A Exact Search Strings

Appendix B Sample Data Abstraction Forms

Appendix C Evidence Tables

Appendix D Excluded Studies

Appendix E Technical Expert Panel (TEP) and Peer Reviewers

Appendix F Statistical Heterogeneity

Appendix G Clinical Trials

Appendix H Community Studies