# Technical Expert Panel

Kenneth R. DeVault, M.D., FACG

Director of Gastrointestinal Research

Division of Gastroenterology & Hepatology

Department of Internal Medicine

Mayo Clinic Jacksonville

Jacksonville, FL

Ronald Hinder, M.D., Ph.D.

Professor and Chairman

Department of Surgery

Mayo Clinic College of Medicine

Mayo Clinic Jacksonville

Ponte Vedra Beach, FL

Peter J. Kahrilas, M.D.

Professor, Division of Gastroenterology

Northwestern University

Chicago, IL

Joel Richter, M.D., FACP, MACG

The Richard L. Evans Chair, Department of Medicine

Gastroenterology Section

Temple University Hospital

Philadelphia, PA

Richard Sampliner, M.D.

Professor of Medicine

Department of Medicine

University of Arizona

Tucson, AZ

Nick Shaheen, M.D., M.P.H.

Associate Professor of Medicine and Epidemiology

Director of the Center for Esophageal Diseases & Swallowing

University of North Carolina

Chapel Hill, NC