# Results

Our literature search yielded 3,532 citations of primary studies on GERD published from 2004 to August 2010, 107 citations of systematic reviews on extraesophageal GERD, and 250 citations of primary studies on PPI use (GERD and non-GERD indications) and fracture risk. In addition, we performed a Medline search (from 2002 to 2009) for all RCTs of GERD therapy in patients with asthma to update a previously published systematic review that examined the effect of PPI treatment on asthma in RCTs,12 which yielded 277 abstracts. We identified 541 of these (530 primary studies, 23 systematic reviews, 14 primary studies on PPI use and fracture risk, and 8 RCTs on GERD therapy in patients with asthma) as potentially relevant and retrieved them for further evaluation. A total of 144 publications on GERD, five systematic reviews on extraesophageal GERD, and nine primary studies on PPI use and fracture risk were finally included in the present review. Figure 2 summarizes the study selection flow.

Figure 2 Study selection flow

Citations identified consisted of the following: 3,532 identified in MEDLINE for primary studies on gastroesophageal reflux disease (GERD) published between 2004 and August 2010; 107 identified in MEDLINE, Cochrane Database of Systematic Reviews, the ACP Journal Club, the DARE, and the CRD HTA for systematic review articles on extraesophageal GERD published up to October 2009; 250 identified in MEDLINE for primary studies on proton pump inhibitor (PPI) use and fracture risk published up to May 2010; 277 identified in MEDLINE for randomized controlled trials (RCTs) of GERD therapy in patients with asthma published between 2002 and 2009. Abstracts for 3,625 failed to meet criteria. Of 541 receiving full-text review, 530 were primary studies on GERD, 23 were systematic reviews on extraesophageal GERD, 14 were primary studies on PPI use and fracture risk, and 8 were RCTs of GERD therapy in patients with asthma. Of these articles, 375 failed to meet criteria. That left 166 articles that qualified for inclusion: 144 primary studies on GERD, 5 systematic reviews on extraesophageal GERD, 9 primary studies on PPI use and fracture risk, and 8 RCTs of GERD therapy in patients with asthma.

## Key Question 1 What is the evidence of the comparative effectiveness of medical, surgical, and other newer forms of treatments for improving objective and subjective outcomes in patients with chronic gastroesophageal reflux disease (GERD)? Is there evidence that effectiveness varies by specific techniques/procedures or medications? Objective outcomes include esophagitis healing, ambulatory pH, other indicators of reflux, need for medication, health care utilization, and incidence of esophageal stricture, Barrett's esophagus, or esophageal adenocarcinoma. Subjective outcomes include symptom frequency and severity, sleep/productivity, and overall quality of life

### Key Question 1A Medical Vs. Surgical Treatments

#### Synopsis

The 2005 AHRQ Comparative Effectiveness Review (CER), based on findings from 3 RCTs, indicated medical therapy with PPIs and antireflux surgery to be similarly effective in improving GERD-related symptoms and decreasing esophageal acid exposure, with 10 to 65 percent of surgical patients requiring ongoing medical therapy post-procedure. In the present update, the addition of long-term followup data in two of the previously reviewed studies and data from two new RCTs indicate that patients who underwent antireflux surgery experienced a greater improvement in heartburn and regurgitation at followup compared with patients who received medical treatment alone. The patients who had antireflux surgery had increased incidence of dysphagia and postprandial bloating. It was also found that fundoplication decreased, but did not eliminate, the use of antireflux medications at followup. These findings should be interpreted with caution as the reviewed studies with long followup (7 to 12 years) had high proportions of patient dropouts (33 to 58 percent). The strength of evidence was rated moderate.

#### Detailed Analysis

Four RCTs and three nonrandomized trials (Grant 2008^13^ utilized both randomized and non-randomized study designs) produced 8 publications comparing medical with surgical treatments for GERD.13-20 Two of these publications, Lundell's 2007^15^ and 2009^17^ papers, present 7- and 12-year followup data for the SOPRAN study originally reported in the 2005 CER (note: for studies presenting data from multiple time intervals, we present results from the most recent followup, e.g., 12-year followup from the SOPRAN study). Lundell's16 and Atwood's14 2008 analyses report 3-year followup data on outcomes from the LOTUS trial. Mehta 2006^18^ reports 6.9 year (median) followup data from the Mahon study,21 while Grant 2008^13^ and Anvari 2006 report 1-year followup data.20 The four RCTs—the SOPRAN,15,17 LOTUS,14,16 Grant 2008,^13^ and Anvari 2006^20^ studies—enrolled a total of 1325 patients, of which, 944 reported information at the final followup period. Mehta 2006^18^ included 67 percent (145/217) of the patients from the Mahon study21 at long-term followup. Olberg 2005, the only pure non-randomized study, enrolled 746 patients, 358 of whom reported followup data at a mean of 75 months.19 All RCTs identified in the present review had methodological limitations including issues concerning possible selection bias,13 small sample size,20 and a large proportion of patient dropouts.15,17

As in the 2005 CER, the studies in this review included patient populations with varying clinical characteristics and response to medical treatments at baseline. SOPRAN enrolled only patients with baseline esophagitis, without restriction on the degree of severity, while patients included in the LOTUS trial had no higher than grade B (Los Angeles classification) esophagitis at randomization (although some patients with Barrett's esophagus were included).

Treatments across studies also varied. SOPRAN patients underwent open fundoplication; LOTUS patients laparoscopic fundoplication; and the Olberg 2005 study included patients who had open or laparoscopic fundoplication procedures.19 Patients in the Mehta 2006 study were given the option of laparoscopic surgery if unsatisfied with initial PPI treatment.18 Patients in the medical treatment groups received esomeprazole in the LOTUS trial, or omeprazole in the SOPRAN study, while patients in the Grant 2008 study13 and Anvari 2006 study received individualized medical management based on symptom response.20 The Olberg 2005 study used nonoperated matched controls with some receiving PPI and/or H2RA treatment. Overall, four studies assessed laparoscopic fundoplication versus PPI,13,14,16,18,20 one study examined open fundoplication versus PPI,15,17 and one study assessed a sample of patients receiving surgery (laparoscopic and open) versus matched control.19 The strength of evidence for this body of data was rated moderate due to large dropout rates for studies with long followup as well as varied individual study quality, followup time periods, interventions used and outcomes assessed.

Findings from both the RCTs and non-randomized comparisons have been organized by the following outcomes of interest: (1) Change in symptoms, quality of life (QOL) and patient satisfaction; (2) Change in medication usage status; (3) Change in pH study results; and (4) Remission rates. Details of these outcomes are presented in the tables that follow.

##### Change in Symptoms, Quality of Life (QOL) and Patient Satisfaction

(Table 1)

Table 1 Medical vs. surgical treatments for GERD: Change in symptoms, QOL, and satisfaction

Author Year Study Intervention | N enrolled N with f/u data | Follow-up duration | Quality | Results
RCTs
Lundell 2008^16^ [18469091] LOTUS Trial LAS vs. EsOME | 554 412 | 3 y | B | Heartburn LAS: Decrease across 3 yr study period EsOME: Similar levels across 3 yr study period More pts reported mild heartburn in EsOME group at f/u (p<0.001; inversely related to dose) Regurg LAS: Decrease across 3 yr study period EsOME: Similar levels across 3 yr study period GSRS reflux: Greater improvement in mean scores for LAS (p<0.001) QOLRAD: Greater improvement in mean scores for LAS (p<0.001 for all dimensions)
Attwood 2008^14^ [18709511] LOTUS Trial Non-BE Cohort LAS vs. EsOME | 554 412 | 3 y | B | GSRS: mean scores similar for all dimensions for both groups across 3 yr study period (normal values, differences NS) QOLRAD: mean scores similar for all dimensions for both groups across 3 yr study period (normal values, differences NS)
Grant 2008^13^ [19074946] Randomized Cohort LAS vs. Medical treatment^a^ | 357 299 | 12 mo | B | SF-36: Improvements in mean f/u scores for LAS group—largest difference observed in general health and bodily pain dimensions EQ-5D: Improvements in mean f/u scores for LAS group—some evidence of attenuation at 12 mo f/u REFLUX QoL: Significant improvements in mean f/u scores for LAS group (p<0.001)
Anvari 2006^20^ [17227922] RCT LAS vs. Medical | 104 96 | 12 mo | B | GERSS: better in LAS (P=0.002) SF-36: similar in PCS and MCS SF-36 Gen Health subscore: better in LAS (P=0.005) EQ-5D: similar in both
Lundell 2007/2009^15,17^ [17256807/19490952] SOPRAN study 12-year f/u Cohort OAS vs. OME | 310 218, 7-yr f/u 137, 12-yr f/u | 12 y | C Large dropout | Heartburn: More common in OME (HR=1.73, 95%CI 1.6-1.9) Regurg: More common in OME (HR=2.38, 95% CI 2.1-2.7) GSRS: mean total scores similar—troubled to a minor extent by GI sx—w/normal values across f/u PGWB: mean total scores similar w/ normal values across f/u
Non-randomized studies
Mehta 2006^18^ [17114017] LAS vs. PPI vs. PPI / LAS^b^ | 217 145 | Median: 6.9 y (range, 4.3-8.3 y) | C Large dropout | DeMeester Symptom Score: Significant improvements in mean 12 mo f/u scores for all groups (p<0.01) Pts opting for LAS after 12 mo PPI demonstrated further significant score improvement at long-term f/u (p<0.01) Satisfaction Scores** LAS, PPI/LAS: >80% very satisfied w/symptom control; 88% would undergo surgery if they had it to do over again PPI: 59% very satisfied, 41% moderately satisfied Significant association b/w tx group and scores (x^2^ = 15.7; p<0.01)
Grant 2008^13^ [19074946] Non-randomized Cohort LAS vs. Medical treatment^a^ | 453 299 | 12 mo | B | REFLUX QoL: Improvements in mean f/u scores favored LAS group vs. Med Tx group EQ-5D: Improvements in mean f/u scores favored LAS group vs. Med Tx group
Olberg 2005^19^ [15932167] OAS/LAS vs. Matched nonoperated pt with GERD Matched-pair f/u study | 746 358 | Mean: 75.25 mo | B | GSRS reflux domain: OAS/LAS Mean scores demonstrate significantly fewer reflux symptoms at f/u (p<0.001) PGWB: No consistent significant differences b/w groups at f/u

EsOME = Esomeprazole; OME = Omeprazole; PPI = Proton pump inhibitor; LAS = Laparoscopic antireflux surgery; OAS = Open Anti-Reflux Surgery; QoL = Quality of Life; GSRS = Gastrointestinal Symptom Rating Scale; QOLRAD = Quality of Life in Reflux & Dyspepsia; gastroesophageal reflux score (GERSS); PGWB = Psychological General Well-Being Index

a Patients allocated to medical treatment had their treatment reviewed and adjusted as needed by local gastroenterologist to be “best medical management” based on the Genval workshop report

b Long-term (median 6.9 yr f/u) satisfaction rating: 1 (not at all) – 3 (very much)

The six included studies (Table 1) utilized a variety of methods to capture outcomes, including patient report of heartburn, regurgitation and satisfaction, and structured scales such as the Gastrointestinal Symptom Rating Scale (GSRS), Quality of Life in Reflux and Dyspepsia, SF-36, EQ-5D, REFLUX Quality of Life (QOL), gastroesophageal reflux score (GERSS), DeMeester Symptom Score, and the Psychological General Well-Being Index (PGWB). Lundell 2008 (LOTUS trial) reported decreases in both heartburn and regurgitation in the surgery group (approximately 30 percent with these symptoms at randomization compared to less than 10 percent at followup) while the medical group reported that the proportion of patients with complaints of heartburn largely stayed the same (approximately 30 percent at both randomization and followup) and the proportion of patients with regurgitation decreased from approximately 25 percent at randomization to 15 percent at followup, but no significance testing was reported (N.B., these proportions were estimated from Figure 4 in the paper).16 Additionally, more medically treated patients reported mild heartburn, compared to those receiving surgery, at 3-year followup (P<0.001).16 Patients in surgical groups demonstrated significantly greater improvement in mean QOLRAD and GSRS reflux domain scores (P<0.001 for both scores); however, they also experienced some mild dysphagia post-surgery—very few (<10%) medically treated patients had dysphagia (P<0.001).16 In contrast, Attwood 2008, also reporting results from the LOTUS trial but with analysis stratified into patients with and without Barrett's esophagus, did not find a significant difference in GSRS or QOLRAD between surgery or medical treatments in those subgroups.14

Grant 2008 reported improvements in SF-36, EQ-5D and REFLUX QOL mean scores for the surgical group, with the latter score attaining significance (P<0.001).13 No significant differences were detected between groups for “difficulty swallowing” at 12-month followup.13 Anvari 2006 similarly reported greater improvements in GERSS (P=0.002) and the SF-36 General Health subscore (P=0.005) in the surgical group compared with the medical group at 1 year.20 Twelve year followup data from the SOPRAN study demonstrated more heartburn and regurgitation in the medical treatment group, with mean GSRS and PGWB scores remaining similar (in normal range) across followup.15,17 These data also indicated that dysphagia was significantly more common after surgery compared with medical treatments (estimated HR 1.7, 95%CI 1.5, 1.9). Mehta 2006,^18^ in a non-randomized long-term followup (patients in the medical treatment arm were offered surgery after the original trial ended at 12 months) of the Mahon RCT,21 reported similar significant (P <0.01) DeMeester Symptom Score improvements in all treatment groups; patients opting for surgery after medical treatment demonstrated continued significant (P<0.01) improvement. Additionally, a greater proportion of surgical patients reported being “very satisfied” with symptom control compared to medically treated patients, with a significant (P<0.01) association between treatment group and symptom score. In the Grant 2008 study, the non-randomized patient-preference cohort demonstrated similar, though less marked, results to the randomized cohort, with improvements in QOL scores favoring the surgical groups.13 The Olberg 2005 publication also reported symptom scores significantly (P<0.001) favoring surgery with fewer reflux symptoms noted on the GSRS at followup.19 No significant differences between treatment groups were evident using the PGWB scale.19

##### Change in Medication Usage Status

(Table 2)

Table 2 Medical vs. surgical treatments for GERD: Change in medication usage status

Author Year Study Intervention | N enrolled N with f/u data | Follow-up duration | Quality | Results
RCTs
Grant 2008^13^ [19074946] Randomized Cohort LAS vs. Medical treatment^a^ | 357 299 | 12 mo | B | At 12 mo f/u, 38% (59/154) of randomized LAS pts were on antireflux medication compared to 90% (147/164) of randomized med tx pts For those randomized to LAS pts who had surgery, use of antireflux medication dropped to 14% (14/104) at 12 mo f/u
Anvari 2006^20^ [17227922] RCT LAS vs. Medical | 104 96 | 12 mo | B | 0% of LAS on PPIs 100% of medical treatment on PPIs
Lundell 2007/2009^15,17^ [17256807/19490952] SOPRAN study 12-year f/u Cohort OAS vs. OME | 310 218, 7-yr f/u 137, 12-yr f/u | 12 y | C Large dropout | Across f/u, 14% (12/155) OME pts referred for fundoplication; 36% (52/144) OAS pts treated w/OME or other PPI for > 8 weeks w/slow but steady increase over time
Non-randomized studies
Grant 2008^13^ [19074946] Non-randomized Cohort LAS vs. Medical treatment^a^ | 453 299 | 12 mo | B | At 12 mo f/u, 20% (46/230) of preference LAS pts were on antireflux medication compared to 93% (165/178) of preference med tx pts
Olberg 2005^19^ [15932167] OAS/LAS vs. Matched non-operated pt with GERD Matched-pair f/u study | 746 358 | Mean: 75.25 mo | B | Significant difference in antireflux drug use at f/u w/less use by OAS/LAS group (p<0.001)

EsOME= Esomeprazole; OME=Omeprazole; PPI=Proton pump inhibitor; LAS=Laparoscopic antireflux surgery; OAS=Open Anti-Reflux Surgery

a Patients allocated to medical treatment had their treatment reviewed and adjusted as needed by local gastroenterologist to be “best medical management” based on the Genval workshop report

Four studies (Table 2) reported a change in medication usage outcomes.13,15,17,19 Grant 2008 reports similar trends, for both randomized and non-randomized cohorts, with the RCT demonstrating a lower percentage of patients on antireflux medication at 12-month followup in the surgery groups versus patients being treated medically (38% vs. 90%, no P value).13 Anvari 2006 reported that none of the surgically treated patients were taking PPIs or other anti-secretory medications at 1-year followup.20 Long-term follow up in the SOPRAN study demonstrated slow but constant increase in treatment with omeprazole or other PPIs for patients in the surgery group (29% were treated for 1 year or longer).15,17 Olberg reported a significant decrease in antireflux medication use at followup favoring the surgery group (PPI use the previous week: 9.4% vs. 49.4%, P<0.001).19

##### Change in pH Study Results

(Table 3)

Table 3 Medical vs. surgical treatments for GERD: Change in pH study results

Author Year Study Intervention | N enrolled N with f/u data | Follow-up duration | Quality | Results
RCTs
Attwood 2008^14^ [18709511] LOTUS Trial Non-BE Cohort LAS vs. EsOME | 554 412 | 3 y | B | Δ total acid exposure time from baseline favoring LAS: LAS- 13.2%, to a median of 0.4% EsOME-7.4%, to a median of 4.9% (p=0.002)
Anvari 2006^20^ [17227922] RCT LAS vs. Medical | 104 96 | 12 mo | B | %time pH<4: diff between groups: 3.63 (in favor of LAS), P=0.004

EsOME=Esomeprazole; LAS=Laparoscopic antireflux surgery

Two studies (Table 3) reported a difference in pH study results.14,20 Attwood 2008 noted a significant improvement (P= 0.002) in total acid exposure for non-Barrett's esophagus LOTUS trial patients undergoing laparoscopic fundoplication versus patients treated with esomeprazole.14 Anvari 2006 reported that surgically treated patients (off PPIs) had a significantly lower mean time of pH<4 compared with medically treated patients (on PPIs) at 1-year followup (mean difference 3.63%, P=0.0042).20

##### Remission Rates

(Table 4)

Table 4 Medical vs. surgical treatments for GERD: Remission rates

Author Year Study Intervention | N enrolled N with f/u data | Follow-up duration | Quality | Results
RCTs
Lundell 2008^16^ [18469091] LOTUS Trial LAS vs. EsOME | 554 412 | 3 y | B | Remission^a^ rate: No significant difference b/w groups at 3 yr follow up
Lundell, 2007/2009^15,17^ [17256807/19490952] SOPRAN study 12-year f/u Cohort OAS vs. OME | 310 218, 7-yr f/u 137, 12-yr f/u | 12 y | C Large dropout | Remission^b^ rate: Greater sustained remission in OAS group (p = 0.002; For dose adjustment of OME: p = .022)

EsOME=Esomeprazole; OME=Omeprazole; LAS=Laparoscopic antireflux surgery; OAS=Open Anti-Reflux Surgery

a EsOME arm: relapse (failed remission) defined as need for escalation in treatment, despite dosage adjustment, for control of reflux; LAS arm: relapse (failed remission) defined as need for escalation in treatment for control of reflux; post-op complaints requiring medical action, peri-op death, post-op death within 30-days post surgery, dysphagia requiring further treatment, or any other requirement to reoperate for sx control

b Relapse (failed remission) defined as presence of at least one of the following criteria: (i) moderate or severe heartburn or acid regurgitation during the previous 7 days before a hospital visit; (ii) oesophagitis of at least grade 2; (iii) moderate or severe dysphagia or symptoms of odynophagia in combination with mild heartburn or acid regurgitation; (iv) requirement for OME treatment for more than 8 weeks after antireflux surgery to control reflux symptoms, or need for reoperation; (v) after randomization to OME, being considered by the physician to require antireflux surgery to control symptoms; (vi) patient opting for antireflux surgery during the course of the study for any reason, despite randomization to OME. Outcome was also analyzed after a dose adjustment to either 40 or 60 mg OME in patients who had a relapse of symptoms with 20 mg daily.

Both the LOTUS trial14,16 and SOPRAN study15,17 (Table 4) reported on remission rates of patients undergoing surgery versus those treated medically. In the LOTUS trial, no significant differences in remission were observed between treatment groups at 3-year followup.14,16 However, the criteria for remission differed between the surgical and medical groups. The SOPRAN study, in contrast, defined remission consistently between surgical and medical groups.15,17 In this study, the open fundoplication surgery group demonstrated significantly greater sustained remission of GERD symptoms relative to the medication group at 12-year followup (53% vs. 40%, P=0.022).

### Key Question 1B Surgical Vs. Endoscopic Treatments

#### Synopsis

The 2005 CER did not find any studies that compared surgical treatment and endoscopic treatment. The present report identified one small study of laparoscopic total fundoplication versus EndoCinch™. This study found that laparoscopic total fundoplication was more effective than EndoCinch™ in improving GERD symptoms and 24-hour pH study. The strength of evidence was rated insufficient.

#### Detailed Analysis

(Table 5)

Table 5 Comparative studies evaluating surgical vs. endoscopic treatments for GERD

Author Year | Study design | Intervention | Enroll/Final | Objective Outcomes | | | Subjective Outcomes | | Quality Comments
Author Year | Follow-up Duration | Intervention | Enroll/Final | Off PPI | Off All Meds | Diagnostic tests^a^ | Symptom improved | Quality of life | Quality Comments
Mahmood 2006^22^ [16542276] | nRCT 1 y | EndoCinch | 27/27 | 63% | nd | LES pressure 9.7 ± 0.9 % time pH<4 8.5 ± 1.1% Both groups had significant improvement in DeMeester score, but was sig better in LNF group (p<0.01) | Both groups had significant improvement in heartburn symptom score, but was sig better in LNF group (p=0.04) Regurg frequency significantly improved in both groups and there was no difference between group (p=0.21) | QOLRAD significantly improved in both groups and there was no difference between group (p=0.11) | C Small sample size
| | Laparoscopic total fundoplication (LNF) | 24/24 | 87% | nd | LES pressure 16.0 ± 1.3 % time pH<4 0.9 ± 0.3% | | QOLRAD significantly improved in both groups and there was no difference between group (p=0.11) | C Small sample size

LES=lower esophageal sphincter, QOLRAD=GERD-specific quality-of-life questionnaire

Quality of Life in Reflux and Dyspepsia (QOLRAD) questionnaire: Disease-specific questionnaire covering 5 dimensions: emotional distress, sleep disturbance, problems with food/drink, limitations in physical and social functioning and lack of vitality. Responses are rated on a 7-grade Likert scale (lower score indicating a more severe impact on daily functioning) Scores of the 5 dimensions were calculated by taking the mean of single items: emotion (five items), sleep (five items), food (six items), physical (five items) and vitality (three items).

a mean± SE

One C-rated non-randomized comparative study (Table 5) followed 41 patients who had either EndoCinch™ or laparoscopic total fundoplication (LNF).22 Although both EndoCinch™ and LNF groups had significant improvement in GERD symptoms and 24-hour pH study measures over the follow-up period, patients in the LNF had significantly better improvement in heartburn score (P = 0.04), DeMeester score (P < 0.01), and the percentage of time of pH < 4 (P < 0.01). No significant difference in regurgitation score and QOLRAD was observed. At 1 year, the proportions of PPI users in the EndoCinch™ and LNF groups were 37 percent and 13 percent, respectively (P value not reported).

### Key Question 1C Medical Vs. Endoscopic Treatments

The 2005 CER did not find any studies that compared medical treatment and endoscopic treatment; neither did this update. The strength of evidence was rated insufficient.

### Key Question 1D Medical Treatment

#### Synopsis

In the 2005 CER,1 comparisons of PPIs to H2RAs found PPIs to be superior to H2RAs in resolution of GERD symptoms at 4 weeks and healing of esophagitis at 8 weeks. There were no significant differences between omeprazole, lansoprazole, pantoprazole, and rabeprazole for relief of symptoms at 8 weeks and no significant difference between esomeprazole 40 mg with lansoprazole 30 mg and pantoprazole 40 mg for symptoms relief at 4 weeks. Similarly, no difference was observed in the comparison of esomeprazole 20 mg with omeprazole 20 mg in relief of symptoms at 4 weeks. However, esomeprazole 40 mg was significantly favored for symptom relief at 4 weeks compared to omeprazole 20 mg. The previous report relied on three unbiased and valid meta-analyses of randomized controlled trials comparing different medications.

In the present, updated review, results from 39 additional primary studies—all relevant RCTs reported since the publication of the 2005 CER—were included. The data from these studies does not alter the conclusions drawn about the comparison between different medical treatment in the previous report. The strength of evidence for all the findings in the comparative medical treatment of GERD was rated moderate. In addition to the PPIs mentioned in the previous report, the present report also includes studies that examined dexlansoprazole. A majority (24/39 trials, 62 percent) of the studies identified in this update were rated B.

##### Key Points for Comparisons of Medical Treatment

We focused on five main comparisons:

1. Comparisons between PPIs and H2RAs
2. Comparisons between different PPIs
3. Comparisons between different dosages and dosing regimens of commonly used PPIs
4. Comparisons between once daily and on-demand dosing regimens of commonly used PPIs
5. Comparisons between PPIs and over-the-counter dosages of PPIs (omeprazole 20 mg, lansoprazole 15 mg)

Key findings within the five comparison groups are summarized as follows:

1. Comparisons between PPIs and H2RAs
  - PPIs (esomeprazole 20 mg taken once daily or on-demand, lansoprazole 15 mg taken once daily and omeprazole 20 mg taken once daily) were superior to H2RAs (ranitidine 150 mg and famotidine 20 mg, both taken twice daily) for resolution of GERD symptoms at 6 months.
    ◦ Lansoprazole 15 mg, taken once daily, was more effective than ranitidine 150 mg taken twice daily for healing of esophagitis at 1 year.
    ◦ Esomeprazole 20 mg, taken once daily or on-demand, was more effective than ranitidine 150 mg taken twice daily for prevention of symptom relapse at 6 months.
    ◦ Maintenance treatment (≥ 6 months) with PPIs (esomeprazole 20 mg taken once daily or on-demand, lansoprazole 15 mg taken once daily) appears to be more efficacious than maintenance treatment with H2RA (ranitidine 150 mg taken twice daily) in symptom remission.
    ◦ Patients on esomeprazole 20 mg taken once daily were more likely to be satisfied with their study medication than patients on ranitidine 150 mg taken twice daily.
  ◦ In maintenance treatment, patients taking lansoprazole 15 mg are likely to stay longer on their treatment as compared to ranitidine 150 mg taken twice daily and thus tend to have a longer median time to relapse of symptoms.
    ◦ Studies with larger sample sizes suggested PPIs to be more efficacious than H2RAs with respect to GERD symptoms, while smaller studies tend to show them to have equivalent effects.
2. Comparisons between different PPIs
  - No consistent comparative difference in symptom relief was observed between esomeprazole (20 to 40 mg), lansoprazole (15 to 30 mg), pantoprazole (20 to 40 mg), or rabeprazole (10 to 20 mg) over a period ranging from 4 weeks to 6 months.
    ◦ There is some evidence that rabeprazole 10 mg may provide better symptom relief than esomeprazole 40 mg at 4 weeks, and also that pantoprazole 20 mg provides better control of heartburn than esomeprazole 20 mg over 24 weeks.
    ◦ Results from three acute treatment trials showed similar esophagitis healing rates for both pantoprazole 40 mg and esomeprazole 40 mg as demonstrated by endoscopy, with the rates increasing with trial duration from 8 to 12 weeks, and being equivalent over 6 months
3. Comparisons between different dosages and dosing regimens of commonly used PPIs
  - No consistent difference in doses and dosing regiments with different PPIs in relation to symptom resolution and esophagitis healing rates.
    ◦ There was no significant difference in symptom resolution rates at 4 weeks between esomeprazole 20 mg taken once a day and esomeprazole 40 mg taken once a day.
    ◦ There was no significant difference in sleep quality at 4 weeks, in patients with GERD and sleep disturbances, between esomeprazole 20 mg and 40 mg, both taken once a day.
    ◦ In two studies of 4 weeks and 6 months duration, dexlansoprazole 30 mg showed better heartburn control than dexlansoprazole 60 mg doses, although this effect was not statistically significant.
    ◦ A significantly higher rate of healing of esophagitis at 4 weeks was observed with esomeprazole 40 mg taken once a day as compared to esomeprazole 20 mg taken once a day. This was supported by finding a significantly higher percentage of time being exposed to pH>4 (which indicates better acid control) in subjects taking esomeprazole 40 mg once a day as compared to esomeprazole 20 mg taken once a day.
4. Comparisons between once daily and on-demand dosing regimens of commonly used PPIs
  - Continuous daily intake of esomeprazole 20 mg appears to provide better symptom control and quality of life relative to on-demand dosing over a period of 6 months.
    ◦ Continuous daily intake of esomeprazole 20 mg appears to provide significantly better endoscopic remission as compared to on-demand dosing over a period of 6 months.
    ◦ Continuous daily intake of rabeprazole 20 mg appears to provide better symptom control and quality of life relative to on-demand dosing over a period of 6 months.
5. Comparisons between PPIs and over-the-counter dosages of PPIs (omeprazole 20 mg, lansoprazole 15 mg)
  - No consistent comparative difference in symptom relief and esophagitis healing rates was observed between esomeprazole (20 to 40 mg), lansoprazole 30 mg, pantoprazole 40 mg or rabeprazole 20 mg with omeprazole 20 mg or lansoprazole 15 mg over a period ranging from 4 weeks to 1 year.
    ◦ When comparing different PPIs with over-the-counter dosages of omeprazole (20 mg), it was observed that pantoprazole 40 mg and rabeprazole 20 mg provide significantly better symptom relief and healing of esophagitis at 8 weeks.
    ◦ Esomeprazole 20 mg provides better endoscopic remission rates as compared to over-the-counter dosages of lansoprazole (15 mg) over 6 months.

#### Detailed Analysis

Data from 39 primary studies were analyzed. All were randomized control trials published between 2005 and 2010. The results are applicable to adults diagnosed with GERD and some degree of esophagitis

Overall, 31,539 subjects were enrolled, with data from 28,230 subjects available for follow up. Of the 39 studies, 6 (15 percent) were of quality A, 24 (62 percent) of quality B, and 9 (23 percent) were of quality C quality. The sample size ranged from 43 to 6,017 subjects. Followup duration ranged from 28 days to 1 year. All subjects were adult patients with GERD.

Comparisons were stratified into 5 categories: a) Comparisons between different PPIs and H2RAs - 4 studies from five published articles23-27 b) Comparisons between different PPIs – 10 studies.28-37 c) Comparisons between different dosages and dosing regimens of commonly used PPIs – 12 studies.38-48 d) Comparisons between once daily and on-demand dosing regimens of commonly used PPIs – 5 studies49-54 e) Comparisons between PPIs and over-the-counter dosages of omeprazole – 8 studies.55-62

PPIs included esomeprazole, lansoprazole, omeprazole, pantoprazole, rabeprazole, and dexlansoprazole. No standard dose was defined, with the exception of the category for comparison of various PPIs with the over the counter dose of omeprazole (20 mg) and lansoprazole (15 mg). The dosages used in the trials in this category are approved for over-the-counter use by the U.S. Food and Drug Administration (FDA). H2RAs included famotidine and ranitidine.

##### Comparison of Proton Pump Inhibitors With H_2_ Receptor Antagonists

Four RCTs23-27 enrolled a total of 2,268 GERD patients with followup information available from 2,141 subjects. One trial reported outcome data in 2 published articles.23,24 One of the articles mainly reported effectiveness and costs outcomes23 while the other reported quality of life and patient satisfaction outcomes.24 Patients took various PPIs – esomeprazole 20 mg taken once daily or on-demand, lansoprazole 15 mg taken once daily and omeprazole 20 mg taken once daily, and also two H2RAs – famotidine 20 mg and ranitidine 150 mg, both twice daily. Sample sizes, based on availability of followup data, ranged from 51 to 1797. Three quarters (3 of 4 trials; 75 percent) of the studies in this category of comparisons were graded B. The remaining trial26 was graded C.

The findings from these studies have been organized by the following outcomes of interest: symptom assessment; quality of life (QOL); esophagitis healing; and relapse rates and medication use, time to recurrence and patient satisfaction, which are more general measures of treatment efficacy. The details of these outcomes are presented in the Evidence Tables while key points are summarized below. Adverse effects are presented under Key Question 3.

###### Symptom Assessment

(Table 6)

Table 6 Comparison of PPI with H2 receptor antagonist: Symptom assessment

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
Norman 2005^23^ [15924594] / Hansen 2006^24^ [16409423] a | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) vs RAN 150 mg (BD) | 1902 (1648 / 1797) | ↑ % of patients w/o heartburn for EsOME 20 mg QD (72.2%) vs EsOME 20 mg O-D (45.1%) and RAN (32.5%), P<0.01.^23^ ↑ % of patients w/o acid regurg for EsOME 20 mg QD (78%) vs EsOME 20 mg O-D (62%) & RAN (45.7%), NS.23 ↑ improvement in symptoms^b^ for both EsOME 20 mg QD (80.2%) & EsOME 20 mg O-D (77.8%) vs RAN (47%), P<0.001.^24^ | B
Norman 2005^23^ [15924594] / Hansen 2006^24^ [16409423] a | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) vs RAN 150 mg (BD) | 6 mo | | B
Peura 2009^27^ [18726153] | LAN 15 mg (QD) vs RAN 150 mg (BD) | 206 (195) | ↑ % asymptomatic at 1 y for LAN (56%) vs RAN (15%), P<0.001 | B
Peura 2009^27^ [18726153] | LAN 15 mg (QD) vs RAN 150 mg (BD) | 1 y | ↑ % asymptomatic at 1 y for LAN (56%) vs RAN (15%), P<0.001 | B
Wada 2005^25^ [15943840] | OME 20 mg (QD) vs FAM 20 mg (BD) | 54 (51) | Improvement in GSRS^c^ total score for OME (2.04 to 1.80), NS; Significant improvement in GSRS total score for FAM (2.56 to 2.13, P<0.05); ↑ % total nighttime heartburn free rate for OME (75%) vs FAM (43.8%), NS. | B
Wada 2005^25^ [15943840] | OME 20 mg (QD) vs FAM 20 mg (BD) | 8 wk | | B
Fujiwara 2005^26^ [15943841] | OME 20 mg (QD) vs FAM 20 mg (BD) | 106 (98) | No differences in efficacy between FAM (23/48 (47.9%) w/complete remission) and OME (28/50 (56%) w/complete remission), P=0.385 Similar complete relief for OME (56%) & FAM (47.9%), P=0.423. | C Study methods not reported
Fujiwara 2005^26^ [15943841] | OME 20 mg (QD) vs FAM 20 mg (BD) | 4 wk | No differences in efficacy between FAM (23/48 (47.9%) w/complete remission) and OME (28/50 (56%) w/complete remission), P=0.385 Similar complete relief for OME (56%) & FAM (47.9%), P=0.423. | C Study methods not reported

a Hansen 2006^24^ was a separate publication from the same trial that primarily reported on quality of life, but included data on symptoms.

b Measured by Overall Treatment Evaluation (OTE) questionnaire which asks about change in symptoms and rates the reported change (better/worse) on a 7-point Likert scale.

c Interview-based rating scale consisting of 15 items for assessment of gastrointestinal symptoms, combined to give scores for the symptoms of reflux, indigestion, pain, diarrhea, and constipation. The GSRS has a scale from 1-7, with 1 indicating no symptoms and 7 indicating severe symptoms. The scores are averages out for the total score 63.

Out of four trials assessing efficacy, two compared omeprazole with famotidine, one compared esomeprazole with ranitidine and one compared lansoprazole with ranitidine. All but one trial27 included symptomatic treatment-naïve patients.

One large study with 1902 enrolled participants compared esomeprazole 20 mg taken on demand and 20 mg taken once a day with ranitidine 150 mg taken twice a day for a period of 6 months.23,24 The study found that esomeprazole 20 mg taken once a day significantly improved all symptoms in 80.2 percent of subjects (as compared to 77.8 percent of subjects taking esomeprazole 20 mg on-demand or 47% of subjects taking ranitidine 150 mg twice a day, P<0.001.^24^ It also found that 72.2 percent of the subjects had no heartburn (significantly higher than 45.1 percent of subjects taking esomeprazole 20 mg on-demand or 32.5% of subjects taking ranitidine 150 mg twice a day, P<0.01).23 In addition, the study reported that a higher proportion of patients experienced relief from acid regurgitation when taking esomeprazole 20 mg once a day (78 percent) than when taking esomeprazole 20 mg on demand (62 percent) or ranitidine 150 mg twice a day (46 percent), although this effect was not statistically significant.23 In a 1 year trial on 206 patients with erosive esophagitis, Peura et al., reported that a significantly higher proportion (56 percent) of participants remained asymptomatic on lansoprazole 15 mg taken once a day compared to ranitidine 150 mg twice a day (15 percent) over 1 year (P<0.001).27 In other findings, omeprazole and famotidine were shown to be comparative in efficacy in two trials,25,26 where similar rates of complete relief were seen in 54 patients over a 4 week treatment period26 and no significant differences were observed in GSRS total score in 106 patients randomized to both treatments over an 8 week treatment period.25

In summary, analysis of these trials indicates that the larger studies suggested PPIs to be more efficacious than H2RAs in resolution of symptoms, while smaller studies tended to show them to have equivalent effects on GERD symptoms. In addition, all the maintenance treatment studies23,24,27 showed PPIs to be more efficacious than H2RAs while the acute treatment studies25,26 showed no difference between the two classes of drugs.

###### Quality of Life

(Table 7)

Table 7 Comparison of PPI with H2 receptor antagonist or different H2 receptor antagonists: Quality of life

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
Wada 2005^25^ [15943840] | OME 20 mg (QD) vs FAM 20 mg (BD) | 54 (51) | SF-36: Significant improvement from baseline for OME in domains of general health, vitality and mental health (P<0.05) & Significant improvement from baseline for FAM in domain of mental health (P<0.05). | B
Wada 2005^25^ [15943840] | OME 20 mg (QD) vs FAM 20 mg (BD) | 8 wk | | B
Hansen 2006^24^ [16409423] | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) vs RAN 150 mg (BD) | 1902 (1797) | QOLRAD^a^: EsOME 20 mg QD & EsOME 20 mg O-D > RAN in all dimensions (emotional, sleep, food, physical, vitality); P< 0.005. EsOME 20 mg QD > EsOME 20 mg O-D in 4 dimensions (Emotional, sleep, food, vitality), P< 0.005. EsOME 20 mg O-D > EsOME 20 mg QD in physical activity, P< 0.005. | B
Hansen 2006^24^ [16409423] | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) vs RAN 150 mg (BD) | 6 mo | | B
Fujiwara 2005^26^ [15943841] | OME 20 mg (QD) vs FAM 20 mg (BD) | 106 (98) | SF-36^b^ (all scales): No significant differences between FAM & OME in changes from baseline. GSRS (total & all dimensions): No significant differences between FAM & OME. | C Study methods not reported
Fujiwara 2005^26^ [15943841] | OME 20 mg (QD) vs FAM 20 mg (BD) | 4 wk | SF-36^b^ (all scales): No significant differences between FAM & OME in changes from baseline. GSRS (total & all dimensions): No significant differences between FAM & OME. | C Study methods not reported

a Quality of Life in Reflux and Dyspepsia (QOLRAD) questionnaire: Disease-specific questionnaire covering 5 dimensions with 7-grade Likert scale (lower score indicating a more severe impact on daily functioning).

b SF-36 contains 8 scales and 2 summary scores. SF-36 Japanese version 1.2 was used in this study. Range of scores was 0 -100; higher scores indicate better functioning and well-being.

Three of the four included trials also reported quality of life outcomes.24-26 In two of these trials,25,26 the efficacies of omeprazole 20 mg once a day and ranitidine 20 mg twice a day were compared using the SF-36 quality of life scale. Both the studies reported significant improvement in SF-36 in each of the two treatment arms, in the absence of reported raw scores. However, neither study reported a significant difference in the change in scores from baseline between the two treatment arms. A large trial comparing different dosing regimens of esomeprazole (20 mg once a day or on demand) with ranitidine 150 mg twice a day24 noted significant improvements in Quality of Life in Reflux and Dyspepsia (QOLRAD) scores in all dimensions (emotional, sleep, food, physical and vitality) in both of the esomeprazole arms versus ranitidine (P<0.005). As for the esomeprazole arms, esomeprazole once a day significantly increased quality of life scores in the domains of emotion, sleep, food, and vitality (P<0.005) compared to the on-demand regimen, while on-demand dosing significantly improved physical activity compared to esomeprazole once a day (P<0.005).

###### Esophagitis Healing

(Table 8)

Table 8 Comparison of PPI with H2 receptor antagonist: Esophagitis healing

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
Peura 2009^27^ [18726153] | LAN 15 mg (QD) vs RAN 150 mg (BD) | 206 (195) | ↑ healing rate^a^ at 1 y w/LAN (67%) vs RAN (13%), P<0.001 | B
Peura 2009^27^ [18726153] | LAN 15 mg (QD) vs RAN 150 mg (BD) | 1 y | ↑ healing rate^a^ at 1 y w/LAN (67%) vs RAN (13%), P<0.001 | B

a Defined as absence of endoscopic recurrence of erosive esophagitis (≥ Grade 2 on the modified Hetzel–Dent grading scale 64).

Only one trial27 assessed esophagitis healing rates. This study, graded B, enrolled 206 adult subjects with GERD and endoscopically proven erosive esophagitis and randomized them to either lansoprazole 15 mg once a day or ranitidine 150 mg twice a day. At the end of 1 year of therapy, a significantly higher proportion of patients on lansoprazole (67 percent) were confirmed as healed as compared to ranitidine (13 percent), P<0.001.

###### Relapse Rate and Medication Use, Time to Recurrence and Patient Satisfaction

(Table 9)

Table 9 Comparison of PPI with H2 receptor antagonist: Relapse rate, patient satisfaction, time to recurrence, and medication use

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
Norman 2005^23^ [15924594] / Hansen 2006^24^ [16409423] | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) vs RAN 150 mg (BD) | 1902 (Norman 2005 :1648 / Hansen 2005: 1797) | ↑ % of patients w/1 relapse in RAN (34.4%) vs EsOME 20 mg QD (7%) & EsOME 20 mg O-D (10.9%), P<0.0001^23^ ↑ satisfaction w/study medication for EsOME 20 mg QD (82.2%) vs EsOME 20 mg O-D (75.4%) & RAN (33.5%) P<0.01 for EsOME 20 mg QD vs EsOME 20 mg O-D; P<0.0001 for EsOME 20 mg QD vs RAN; P<0.0001 for EsOME 20 mg O-D vs RAN.24 | B
Norman 2005^23^ [15924594] / Hansen 2006^24^ [16409423] | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) vs RAN 150 mg (BD) | 6 mo | | B
Peura 2009^27^ [18726153] | LAN 15 mg (QD) vs RAN 150 mg (BD) | 206 (195) | Improved median time to recurrence of day and night heartburn w/LAN (92 d) vs RAN (36 d). ↑ number of days on maintenance therapy w/LAN (mean 236.9 days) vs RAN (mean 88.7 days), P<0.05. | B
Peura 2009^27^ [18726153] | LAN 15 mg (QD) vs RAN 150 mg (BD) | 1 y | Improved median time to recurrence of day and night heartburn w/LAN (92 d) vs RAN (36 d). ↑ number of days on maintenance therapy w/LAN (mean 236.9 days) vs RAN (mean 88.7 days), P<0.05. | B

One trial analyzed the number of relapses (resulting in change of medication) and satisfaction with study medication23,24 with different dosing regimens of esomeprazole 20 mg (once a day and on-demand) versus ranitidine 150 mg (twice a day). Over a period of 6 months, a significantly higher proportion of subjects with a relapse in symptoms, and hence needing a change in their medication, were observed in the ranitidine group (34.4 percent) as compared to the once a day (7 percent) and on-demand groups (10.9 percent) of esomeprazole (P<0.0001). This is also reflected in the increased level of satisfaction as measured on a Likert scale, with esomeprazole 20 mg once a day (82.2 percent) rated significantly higher than on-demand dosing (75.4 percent), and both in turn significantly higher than ranitidine (33.5 percent). With a 1 year followup, PPIs were also observed to have a longer median time to recurrence of symptoms, as seen with lansoprazole 15 mg (92 days) versus ranitidine (36 days).27 However, this effect may be due to subjects on lansoprazole remaining on therapy significantly longer (236.9 days) than patients treated with ranitidine (88.7 days), P<0.05. Both these trials were for maintenance treatment of GERD.

##### Comparison of Different Proton Pump Inhibitors

Ten RCTs28-37 enrolled a total of 11,055 GERD patients, with followup information available from 10,186 subjects. Although two of the studies29,34 present results from two phases of the same multi-center RCT (EXPO study), they are considered separately, as the drug dosages differed between the two phases. Patients took various PPIs—esomeprazole (20 to 40 mg), lansoprazole (15 to 30 mg), pantoprazole (20 to 40 mg) and rabeprazole (10 to 20 mg). Sample sizes, based on availability of followup data, ranged from 127 to 3,151. Most of the studies (9 of 10 trials, 90 percent) in this category of comparisons were graded B.

The findings from these studies have been organized by the following outcomes of interest: symptom assessment; quality of life (QOL); endoscopic esophagitis healing; and antacid medication use. The details of these outcomes are presented in the Evidence Tables while key points are summarized below. Adverse effects are presented under Key Question 3.

###### Symptom Assessment

(Table 10)

Table 10 Comparison of different PPIs: Symptom assessment

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
Goh 2007^28^ [17301646] | PAN 20 mg (QD) vs EsOME 20 mg (QD) | 1316 (ITT–1303 / PP-1005) | Same mean sum score of GI symptoms^a^ (0.1) for PAN 20 mg (QD) & EsOME 20 mg (QD), NS. | A
Goh 2007^28^ [17301646] | PAN 20 mg (QD) vs EsOME 20 mg (QD) | 6 mo | Same mean sum score of GI symptoms^a^ (0.1) for PAN 20 mg (QD) & EsOME 20 mg (QD), NS. | A
Labenz 2009^29^ [19222417] | PAN 40 mg (QD) vs EsOME 40 mg (QD) | 3151 (3151) | Heartburn resolution was similar in PAN (66.9%) & EsOME (72.5%) arms. | B
Labenz 2009^29^ [19222417] | PAN 40 mg (QD) vs EsOME 40 mg (QD) | 4 wk | Heartburn resolution was similar in PAN (66.9%) & EsOME (72.5%) arms. | B
Labenz 2009^34^ [19298581]^b^ | PAN 20 mg (QD) vs EsOME 20 mg (QD) | 2766 (2766) | Heartburn relapse was higher in PAN (17.4%) vs EsOME (9.8%). | B
Labenz 2009^34^ [19298581]^b^ | PAN 20 mg (QD) vs EsOME 20 mg (QD) | 6 mo | Heartburn relapse was higher in PAN (17.4%) vs EsOME (9.8%). | B
Eggleston 2009^36^ [19210493] | RAB 20 mg (QD) vs EsOME 20 mg (QD) vs EsOME 40 mg (QD) | 1392 (1201) | Similar rates of complete resolution of heartburn in RAB (58.4%), EsOME 40 mg QD (64.4%), & EsOME 20 mg QD (60.6%), P=0.184 Similar rates of complete resolution of regurg in RAB (60.6%), EsOME 40 mg QD (60.3%) & EsOME 20 mg QD (60.1%), P=0.363. | B
Eggleston 2009^36^ [19210493] | RAB 20 mg (QD) vs EsOME 20 mg (QD) vs EsOME 40 mg (QD) | 4 wk | | B
Glatzel 2007^30^ [17489035] | PAN 40 mg (QD) vs EsOME 40 mg (QD) | 585 (ITT – 561/PP- 476) | PAN non-inferior to EsOME (97.5% CI upper bound of PAN score w/in non-inferiority margin – Δ1.73). Median 3-day mean ReQuest GI score^c^ similar for PAN (0.24) & EsOME (0.31), Higher rates of symptom relapse post Tx in EsOME (61%) vs PAN (51.1%), P=0.0216. | B
Glatzel 2007^30^ [17489035] | PAN 40 mg (QD) vs EsOME 40 mg (QD) | 4 wk | | B
Bardhan 2007^31^ [17539986] | PAN 40 mg (QD) vs EsOME 40 mg (QD) | 582 (418) | Same rates of complete endoscopic & symptomatic remission with PAN (76%) & EsOME (76%) in ITT population, & slightly higher rates in per protocol population (PAN: 93%, EsOME: 90%) Comparable rates of symptom relief in PAN (79%) & EsOME: (77%) which is also seen in per protocol population (PAN: 95%, EsOME: 92%) | B
Bardhan 2007^31^ [17539986] | PAN 40 mg (QD) vs EsOME 40 mg (QD) | 12 wk | | B
Fass 2006^35^ [16431305] | LAN 30 mg (BD) vs EsOME 40 mg (QD) | 328 (282) | LAN non-inferior to EsOME (lower limit of the 90%CI > -10). Similar % of heartburn free days (EsOME: 54.4%, LAN: 57.5%), % of epigastric pain free days (EsOME: 65%, LAN: 66.9%) & % of acid regurg free days (EsOME: 60.3%, LAN: 65.3%) NS differences in change in heartburn, epigastric pain & acid regurg from baseline to end of study in both groups. | B
Fass 2006^35^ [16431305] | LAN 30 mg (BD) vs EsOME 40 mg (QD) | 8 wk | | B
Scholten 2007^32^ [17358101] | PAN 20 mg (O-D) vs EsOME 20 mg (O-D) | 236 (199) | Lower mean intensity of heartburn^d^ in PAN (1.12) vs EsOME (1.32), P=0.012. Mean intensity of acid eructation: NS | B
Scholten 2007^32^ [17358101] | PAN 20 mg (O-D) vs EsOME 20 mg (O-D) | 24 wk | Lower mean intensity of heartburn^d^ in PAN (1.12) vs EsOME (1.32), P=0.012. Mean intensity of acid eructation: NS | B
Vcev 2006^33^ [17058517] | PAN 40 mg (QD) vs EsOME 40 mg (QD) | 180 (176) | Similar heartburn-free days for EsOME (70.2%) & PAN (69.8%). | B
Vcev 2006^33^ [17058517] | PAN 40 mg (QD) vs EsOME 40 mg (QD) | 8 wk | Similar heartburn-free days for EsOME (70.2%) & PAN (69.8%). | B
Fock 2005^37^ [15918196] | RAB 10 mg (QD) vs EsOME 20 mg (QD) | 134 (127) | NS differences in Time to first 24-hr heartburn & regurg free interval (RAB<EsOME), Time to first 48-hr heartburn (RAB>EsOME)& regurg free interval(RAB<EsOME) Among pts w/both heartburn & acid regurg, satisfactory symptom relief ↑ in RAB (92.5%) vs EsOME (79.4%), P< 0.05 NS difference in patient-perceived symptom improvement (RAB: 96.4%, EsOME: 87.9%). RAB led to a more rapid resolution of heartburn (8.5 days vs. 9 days for EsOME, P=0.265) and acid regurgitation (6 days vs. 7.5 days for EsOME, P=0.405) | B
Fock 2005^37^ [15918196] | RAB 10 mg (QD) vs EsOME 20 mg (QD) | 4 wk | | B

a Symptoms included heartburn, acid regurgitation, dysphagia, epigastric pain/discomfort, retrosternal tightness, burping/belching, nausea/vomiting, fullness, lower abdominal pain, and flatulence. The intensity of symptoms was scored as none (0), mild (1), moderate (2), and severe (3) by investigators.

b Maintenance phase study of Labenz 2009 [19222417] (which is the healing/active phase study).

c ReQuest-GI comprises 4 dimensions of acid complaints, upper abdominal stomach complaints, lower abdominal/digestive complaints and nausea. Each dimension's score is a product of its intensity and frequency. The ReQuest-GI score is sum of the weighted scores of its four dimensions.

d Intensity of heartburn on a 4-point scale.

All trials were conducted on adult GERD patients. Seven out of 10 trials (70 percent) compared varying dosages of pantoprazole and esomeprazole.28-34 Other comparisons included rabeprazole versus esomeprazole,36,37 and lansoprazole versus esomeprazole,35 Two trials included participants based on clinical symptoms alone, without assessing the presence of esophagitis.35,36 In the other eight trials, participants had esophagitis at presentation28-34 or it had been ruled out by an endoscopic examination.37

The results from the acute phase of the EXPO study showed similar heartburn resolution rates for both pantoprazole 40 mg (67 percent) and esomeprazole 40 mg (73 percent) at 4 weeks.29 Maintenance therapy with 20 mg doses of the same drugs over 6 months did not significantly alter the results, with pantoprazole (17.4 percent) showing a slightly higher heartburn resolution rate as compared to esomeprazole (9.8 percent). Both studies did not report tests of significance. One non-inferiority trial30 demonstrated that pantoprazole 40 mg and esomeprazole 40 mg both had similar median post treatment ReQuest GI subscale scores (PAN0.24, EsOME 0.31) after 4 weeks. The same study also reported that esomeprazole had significantly higher rates of symptom relapse post treatment (61 percent) as compared to pantoprazole (51.1 percent), P=0.0216. Two additional studies reported results with 8 week33 and 12 week31 followup. At 8 weeks, the proportion of patients with heartburn free days was similar for esomeprazole (70.2 percent) and for pantoprazole (69.8 percent).33 At 12 weeks, the endoscopic and symptomatic relapse rates were the same for both the arms (76 percent).31 However, in another study with a followup of 24 weeks, patients on pantoprazole 20 mg showed a significantly lower mean intensity of heartburn (1.12) as compared to esomeprazole 20 mg (1.32), P=0.012.^32^

Results from a non-inferiority trial comparing lansoprazole 30 mg twice a day to esomeprazole 40 mg once a day showed similar percentages of patients who experienced days without symptoms of heartburn (EsOME: 54.4 percent, LAN: 57.5 percent), epigastric pain, (EsOME: 65 percent, LAN: 66.9 percent) and acid regurgitation (EsOME: 60.3 percent, LAN: 65.3 percent).35

Two 4-week studies compared the efficacy of rabeprazole and esomeprazole.36,37 One, a three-arm study comparing two doses of esomeprazole (20 and 40 mg) with 20 mg of rabeprazole, showed similar rates of complete resolution of heartburn (rabeprazole = 58.4 percent, esomeprazole 40 mg = 64.4 percent, esomeprazole 20 mg = 60.6 percent, P=0.184) and acid regurgitation (rabeprazole = 60.6 percent, esomeprazole 40 mg = 60.3 percent, esomeprazole 20 mg = 60.1 percent, P=0.363) in all three arms.36 The second evaluated rabeprazole 10 mg versus esomeprazole 20 mg and found that rabeprazole led to a more rapid resolution of heartburn (8.5 days vs. 9 days for esomeprazole, P=0.265) and acid regurgitation (6 days vs. 7.5 days for esomeprazole, P=0.405), though this finding was not significant.37

###### Quality of Life

(Table 11)

Table 11 Comparison of different PPIs: Quality of life

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
Eggleston 2009^36^ [19210493] | RAB 20 mg (QD) vs EsOME 20 mg (QD) vs EsOME 40 mg (QD) | 1392 (1201) | SF-36^a^ (all domains): ↑ from baseline for all PPI groups, P<0.05; Greatest improvements: Bodily pain, Role-physical, Role-emotional NS differences between Tx groups | B
Eggleston 2009^36^ [19210493] | RAB 20 mg (QD) vs EsOME 20 mg (QD) vs EsOME 40 mg (QD) | 4 wk | SF-36^a^ (all domains): ↑ from baseline for all PPI groups, P<0.05; Greatest improvements: Bodily pain, Role-physical, Role-emotional NS differences between Tx groups | B

a SF-36 contains 8 scales and 2 summary scores with a range of scores from 0 -100; higher scores indicate better functioning and well-being.

Of the 11 reviewed trials, only one reported quality of life outcomes.36 In this study, graded B, 1,392 patients were randomized to esomeprazole 20 mg, esomeprazole 40 mg, or rabeprazole 20 mg, once daily. An increase in the SF-36 quality of life was observed for all domains in all 3 arms (P<0.05), although the mean change was not significantly different between groups. Across all groups, the greatest improvements were seen in the bodily pain, role physical, and role emotional domains.

###### Endoscopic Esophagitis Healing

(Table 12)

Table 12 Comparison of different PPIs: Endoscopic esophagitis healing

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
Goh 2007^28^ [17301646] | PAN 20 mg (QD) vs EsOME 20 mg (QD) | 1316 (ITT– 1303 / PP-1005) | Equal rates of endoscopic & symptomatic remission^a^ for PAN (93%) and EsOME (93%) (ITT analysis: PAN (84%) and EsOME (85%)). | A
Goh 2007^28^ [17301646] | PAN 20 mg (QD) vs EsOME 20 mg (QD) | 6 mo | Equal rates of endoscopic & symptomatic remission^a^ for PAN (93%) and EsOME (93%) (ITT analysis: PAN (84%) and EsOME (85%)). | A
Bardhan 2007^31^ [17539986] | PAN 40 mg (QD) vs EsOME 40 mg (QD) | 582 (418) | Similar rates for endoscopic healing for PAN (98%) and EsOME (94%) (ITT analysis: PAN (91%) and EsOME (88%)). | B
Bardhan 2007^31^ [17539986] | PAN 40 mg (QD) vs EsOME 40 mg (QD) | 12 wk | Similar rates for endoscopic healing for PAN (98%) and EsOME (94%) (ITT analysis: PAN (91%) and EsOME (88%)). | B
Vcev 2006^33^ [17058517] | PAN 40 mg (QD) vs EsOME 40 mg (QD) | 180 (176) | Similar healing rates of erosive oesophagitis w/EsOME (92.2%) & PAN (91.1%). | B
Vcev 2006^33^ [17058517] | PAN 40 mg (QD) vs EsOME 40 mg (QD) | 8 wk | Similar healing rates of erosive oesophagitis w/EsOME (92.2%) & PAN (91.1%). | B

a Combined symptomatic and endoscopic remission was defined as the absence of endoscopic findings (GERD Los Angeles grades A-D) and 'no' or 'mild' heartburn and acid regurgitation. Symptomatic non-relapse was defined as 'no' or 'mild' symptom severity for the variables of heartburn and acid regurgitation.

Three of 10 trials28,31,33 reported endoscopic healing results. All the three compared the efficacy of pantoprazole and esomeprazole in endoscopic healing.28,31,33 Results from two acute treatment trials showed similar esophagitis healing rates for both pantoprazole 40 mg (91.1 to 98 percent of participants) and esomeprazole 40 mg (92.2 to 94 percent of participants) as demonstrated by endoscopy, with the rates increasing with trial duration from 8 to 12 weeks.31,33 In a third trial with six months followup, the rates of endoscopic and symptomatic remission were equivalent (93 percent of participants) for both treatment groups.28

###### Antacid Medication Use

(Table 13)

Table 13 Comparison of different PPIs: Antacid medication use

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
Scholten 2007^32^ [17358101] | PAN 20 mg (O-D) vs EsOME 20 mg (O-D) | 236 (199) | ↑ average daily antacid use w/PAN (0.31 tablets/d) vs EsOME (0.23 tablets/d). | B
Scholten 2007^32^ [17358101] | PAN 20 mg (O-D) vs EsOME 20 mg (O-D) | 24 wk | ↑ average daily antacid use w/PAN (0.31 tablets/d) vs EsOME (0.23 tablets/d). | B

One trial compared the efficacy of pantoprazole 20 mg with esomeprazole 20 mg, both taken on-demand (i.e. as and when necessary), on the use of antacids as a rescue medication among symptomatic GERD patients over 24 weeks.32 The average daily antacid use was found to be higher among participants taking pantoprazole (0.31 tablets/day) than esomeprazole (0.23 tablets/day), though the statistical significance was not reported.

##### Comparison of Different Dosages as Well as Different Dosing Regimens of the Same Proton Pump Inhibitors

Twelve RCTs38-48,54 enrolled a total of 4,599 GERD patients with followup data available from 3,830 subjects. Dosages and dosing regimens were compared among a number of PPIs including esomeprazole, pantoprazole, lanzoprazole, and dexlansoprazole. Sample sizes, based on availability of followup data, ranged from 43 to 873. Three trials compared esomeprazole at different dosages, 38-40 one trial compared different dosing regimens of esomeprazole,41 two trials compared different dosing regimens of lansoprazole,42,54 three trials compared different dosing regimens of dexlansoprazole,43-45 and three trials compared different dosages of pantoprazole.46-48 The dosing regimens used were a once daily regimen or an intermittent course therapy (a four week course only when symptomatic). One 4-week trial compared empirical treatment with a specified dose of esomeprazole (40 mg) to a treatment dose based on results of a screening endoscopy (20 or 40 mg).38 2 out of 12 trials (16.7 percent) was graded A, 4 out of 12 trials (33.3 percent) were graded B, and 6 out of 12 trials (50 percent) were graded C.

The findings from these studies have been organized by the following outcomes of interest: symptom assessment; quality of life (QOL); esophagitis healing; acid control, and antacid medication use and treatment satisfaction. Comparisons of dosages and dosing regimens of the same PPI are assessed separately within each outcome. Details of these outcomes are presented in the Evidence Tables while key points are summarized below. Adverse effects are presented under Key Question 3.

###### Symptom Assessment

(Table 14)

Table 14 Comparison of different dosages as well as different dosing regimens of the same PPIs: Symptom assessment

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
EsOME – Different Dosages
Johnson 2005^39^ [16128933] | EsOME 20 mg (QD) vs EsOME 40 mg (QD) vs Placebo | 675 (642) | Relief of nighttime heartburn symptoms w/ESOME 40 mg QD (53.1%), ESOME 20 mg QD (50.5%) vs placebo (12.7%), P<0.0001 | B
Johnson 2005^39^ [16128933] | EsOME 20 mg (QD) vs EsOME 40 mg (QD) vs Placebo | 4 wk | Relief of nighttime heartburn symptoms w/ESOME 40 mg QD (53.1%), ESOME 20 mg QD (50.5%) vs placebo (12.7%), P<0.0001 | B
Giannini 2008^38^ [18289194] | EsOME 40 mg (QD) vs EsOME 20 / 40 mg (QD, determined by endoscopy) | 612 (551) | Response to empirical Tx^a^ (EsOME 40 mg, QD) – 71.8% was similar to endoscopy-based Tx (EsOME 20 / 40 mg, QD)- 68.3% at 24 wk (P=0.389) | B
Giannini 2008^38^ [18289194] | EsOME 40 mg (QD) vs EsOME 20 / 40 mg (QD, determined by endoscopy) | 24 wk | Response to empirical Tx^a^ (EsOME 40 mg, QD) – 71.8% was similar to endoscopy-based Tx (EsOME 20 / 40 mg, QD)- 68.3% at 24 wk (P=0.389) | B
LAN – Different Dosing Regimens
Cibor 2006^54^ [17357336] | LAN 30 mg (O-D) vs LAN 15 mg (QD) vs LAN 30 mg 4-wk course (intermittent therapy) | 65 (60) | ↓ intensity of symptoms^b^ for LAN 30 mg O-D and LAN 15 mg QD as compared to LAN 30 mg intermittent Tx, P<0.05 | B
Cibor 2006^54^ [17357336] | LAN 30 mg (O-D) vs LAN 15 mg (QD) vs LAN 30 mg 4-wk course (intermittent therapy) | 12 mo | ↓ intensity of symptoms^b^ for LAN 30 mg O-D and LAN 15 mg QD as compared to LAN 30 mg intermittent Tx, P<0.05 | B
Mine 2005^42^ [16105122] | LAN 15 mg (QD) for 16 wk (No step group) vs LAN 30 mg (QD) for 8 wk, followed by FAM 20 mg (BD) for 8 wk (Step down to FAM group) vs LAN 30 mg (QD) or 8 wk followed by LAN 15 mg (QD) for 8 wk (Step down to LAN group) | 43 (43) | Heartburn, regurg and dysphagia disappeared in no step and step down to LAN groups (1 patient in no step had residual heartburn and 1 person in step down to LAN had residual regurg) but remained to some degree in step down to FAM group. | C Poor description of methods, small sample size
Mine 2005^42^ [16105122] | | 16 wk | | C Poor description of methods, small sample size
DexLAN – Different Dosages
Fass 2009^43^ [19392864] | DexLAN 30 mg (QD) vs DexLAN 60 mg (QD) vs Placebo | 947 (873) | The median % of 24-h heartburn-free days was significantly greater in both the DexLAN 30 mg (54.9%) and DexLAN 60 mg (50%) as compared w/placebo (18.5%), P<0.00001 ↓ symptom scores for DexLAN 30 mg and DexLAN 60 mg vs placebo, P< 0.005 | A
Fass 2009^43^ [19392864] | DexLAN 30 mg (QD) vs DexLAN 60 mg (QD) vs Placebo | 4 wk | | A
Metz 2009^44^ [19210298] | DexLAN 30 mg (QD) vs DexLAN 60 mg (QD) vs Placebo | 445 (221) | ↑ proportion of patients w/no heartburn in DexLAN 60 mg (63%) and DexLAN 30 mg (67%) as compared to placebo (17%), P<0.0025 | C 50% loss to follow-up
Metz 2009^44^ [19210298] | DexLAN 30 mg (QD) vs DexLAN 60 mg (QD) vs Placebo | 6 mo | ↑ proportion of patients w/no heartburn in DexLAN 60 mg (63%) and DexLAN 30 mg (67%) as compared to placebo (17%), P<0.0025 | C 50% loss to follow-up
Howden 2009^45^ [19681809] | DexLAN 60 mg (QD) vs DexLAN 90 mg (QD) vs Placebo | 451 (230) | ↑ proportion of patients w/no heartburn in DexLAN 60 mg (95.8%) and DexLAN 90 mg (94.4%) as compared to placebo (19.2%), P<0.00001 | C 88% loss to follow-up in the placebo group
Howden 2009^45^ [19681809] | DexLAN 60 mg (QD) vs DexLAN 90 mg (QD) vs Placebo | 6 mo | ↑ proportion of patients w/no heartburn in DexLAN 60 mg (95.8%) and DexLAN 90 mg (94.4%) as compared to placebo (19.2%), P<0.00001 | C 88% loss to follow-up in the placebo group
PAN – Different Dosages
Pai 2006^46^ [17009401] | S-PAN (20 mg QD) vs racemic PAN (40 mg QD) | 369 (369) | ↓ in all symptom scores (heartburn, regurg, bloating, dyphagia, nausea) in both groups ↑ proportion of patients w/relief from heartburn & acid regurg w/s-PAN 20 mg QD (85.5% & 92.9%, respectively) than w/racemic PAN 40 mg QD (74.4% & 82.4%, respectively), P=0.01 & P=0.004, respectively | C no power calculations, baseline characteristics not adequately reported, poor diagnostic quality
Pai 2006^46^ [17009401] | S-PAN (20 mg QD) vs racemic PAN (40 mg QD) | 28 d | | C no power calculations, baseline characteristics not adequately reported, poor diagnostic quality
Scholten 2005^47^ [16113546] | PAN 40 mg (O-D) vs PAN 20 mg (O-D) vs Placebo | 548 (465) | ↓ perceived average daily symptom load (heartburn, epigastric pain, acid regurg) for PAN 40 mg O-D (2.71) and PAN 20 mg O-D (2.91) vs placebo (3.93), P<0.001 | C Poor description of methods
Scholten 2005^47^ [16113546] | PAN 40 mg (O-D) vs PAN 20 mg (O-D) vs Placebo | 28 wk | ↓ perceived average daily symptom load (heartburn, epigastric pain, acid regurg) for PAN 40 mg O-D (2.71) and PAN 20 mg O-D (2.91) vs placebo (3.93), P<0.001 | C Poor description of methods
PAN – Different Dosing Regimens
Chen 2010^48^ [19904250] | PAN 40 mg (BD) vs PAN 40 mg (O-D) vs Placebo | 200(200) | ↑ sustained symptomatic response at 8 weeks for PAN 40 mg BD (86%) vs PAN 40 mg OD (70%), P=0.01 | A
Chen 2010^48^ [19904250] | PAN 40 mg (BD) vs PAN 40 mg (O-D) vs Placebo | 8 wk | ↑ sustained symptomatic response at 8 weeks for PAN 40 mg BD (86%) vs PAN 40 mg OD (70%), P=0.01 | A

a Responders classified by symptom score. A responder at the 24-wk period was a patient whose sum of symptom scores over the last 7 days before the visit was 0 or 1.

b Intensity of symptoms was rated each time using the Visual-Analog Scale (VAS) from 0-10 points.

###### Esomeprazole—Comparison of Dosages

Two trials compared esomeprazole 20 mg with esomeprazole 40 mg, enrolling 1,287 subjects with followup data available on 1,213 subjects.38,39 The trials included patients who either had a history of erosive esophagitis39 or who had undergone a period of treatment with PPIs before entering the trial.38 One, a three-arm trial conducted over 4 weeks, indicated significantly better relief of nighttime heartburn symptoms in subjects taking either 20 mg (50.5 percent) or 40 mg (53.1 percent) esomeprazole as compared to placebo (12.7 percent), P<0.0001.^39^ In the other, a 24 week trial, treatment response (a patient was considered a responder if the sum of symptom scores over the previous 7 days was either 0 or 1) was observed in 71.8 percent of the group treated empirically and in 68.3 percent of the group whose treatment was determined by endoscopy (P=0.389).38

###### Lansoprazole—Comparison of Different Dosing Regimens

Two separate trials evaluated different dosing regimens of lansoprazole for its effect on GERD symptoms. In one three-arm trial of 65 participants conducted over 1 year, lansoprazole 15 mg once a day was compared to on-demand lansoprazole 30 mg as well as a 30 mg intermittent therapy course (where recurrence of any symptoms was followed by a full 4-week course of lansoprazole 30 mg).54 In this trial, both the daily and on-demand regimens were shown to significantly decrease the intensity of symptoms as compared to the intermittent therapy (P<0.05), though no statistical difference was observed between these two arms.54 In another trial, a three-arm comparison employed 43 participants over 16 weeks to evaluate three different treatment strategies: a once a day dose of lansoprazole 15 mg for the duration of the study (no step group), 30 mg a day stepped down to 15 mg a day halfway through the study (step down to lansoprazole group), and 30 mg a day with a substitution with famotidine 20 mg twice a day halfway through the study (step down to famotidine group).42 Heartburn, acid regurgitation and dysphagia symptoms disappeared in the no step and step down to lansoprazole groups, with the exception of one patient in each group (one patient in the no step group had residual heartburn and one person in the step down to lansoprazole group had residual regurgitation). The step down to famotidine group continued to experience residual symptoms.

###### Dexlansoprazole—Comparison of Dosages

Two three-arm trials compared dexlansoprazole 30 mg and dexlansoprazole 60 mg doses with a placebo.43,44 In the first, a quality A study with 947 enrolled subjects, the median proportion of participants with 24-hour heartburn free days after a 4-week treatment period was found to be significantly higher in the dexlansoprazole 30 mg (54.9 percent) and dexlansoprazole 60 mg (50 percent) groups as compared to placebo (18.5 percent).43 Although the 30 mg dosage showed somewhat better results than the higher dosage, these differences were not statistically significant. Similar findings were reported by the second, smaller study of 445 subjects over 6 months; the proportion of participants with no heartburn was significantly higher with dexlansoprazole 30 mg (67 percent) and dexlansoprazole 60 mg (63 percent), as compared to placebo (17 percent, P<0.0025).44

A third study, comparing dexlansoprazole 60 mg and dexlansoprazole 90 mg doses with a placebo in 451 subjects, reported a significantly higher proportion of patients without heartburn in the 60 mg (95.8 percent) and 90 mg (94.4 percent) groups, as compared to placebo (19.2 percent, P<0.0001).45

###### Pantoprazole—Comparison of Dosages

One study compared the pure S-isomer of pantoprazole 20 mg with a racemic mixture of S- and R-isomers of pantoprazole 40 mg over a 4-week treatment period.46 In the s-isomer, lower dosage group, a significantly higher proportion of patients experienced relief from heartburn (85.5 percent) as compared to the racemic mixture (74.4 percent, P=0.01). Similarly, a significantly higher proportion of patients experienced relief from acid regurgitation in the s-isomer group (92.2 percent) as compared to the racemic mixture (82.4 percent, P=0.004). Another study, enrolling 548 participants, compared 20 and 40 mg doses of pantoprazole on an on-demand regimen with placebo.47 The perceived average daily symptom load (comprising heartburn, epigastric pain and acid regurgitation) was significantly lower for the 40 mg (2.71) and 20 mg on-demand groups (2.91) as compared to placebo (3.93), P<0.001.

###### Pantoprazole—Comparison of Different Dosing Regimens

One trial, comparing pantoprazole 40 mg twice daily and pantoprazole 40 mg once daily with a placebo in 200 overweight or obese subjects over a 8-week treatment period, reported a significantly higher proportion of patients with a sustained symptomatic response in the pantoprazole 40 mg twice daily group (86 percent) as compared to pantoprazole 40 mg once daily group (70 percent, P=0.01). 48

###### Quality of Life

(Table 15)

Table 15 Comparison of different dosages as well as different dosing regimens of the same PPIs: Quality of life

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
EsOME – Different Dosages
Johnson 2005^39^ [16128933] | EsOME 20 mg (QD) vs EsOME 40 mg (QD) vs Placebo | 675 (642) | ↑ rates of complete resolution and relief of GERD-associated sleep disturbances in EsOME 40 mg QD & 20 mg QD groups vs. placebo (P<0.0001) ↑ in good sleep quality (PSQI ≤ 5)^a^ with EsOME 40 mg (46%), EsOME 20 mg (57%) vs. placebo (36%), P<0.001 Greater improvement in global PSQI score (better sleep) with EsOME 40 mg (-3.64) and EsOME 20 mg (-4.00) vs. placebo (-2.19), P<0.0001 | B
Johnson 2005^39^ [16128933] | EsOME 20 mg (QD) vs EsOME 40 mg (QD) vs Placebo | 4 wk | | B
Giannini 2008^38^ [18289194] | EsOME 40 mg (QD) vs EsOME 20 / 40 mg (QD, determined by endoscopy) | 612 (551) | QOLRAD^b^: No difference in emotional, sleep, food/drink, vitality, physical / social components | B
Giannini 2008^38^ [18289194] | EsOME 40 mg (QD) vs EsOME 20 / 40 mg (QD, determined by endoscopy) | 4 wk | QOLRAD^b^: No difference in emotional, sleep, food/drink, vitality, physical / social components | B
DexLAN – Different Dosages
Metz 2009^44^ [19210298] | DexLAN 30 mg (QD) vs DexLAN 60 mg (QD) vs Placebo | 445 (221) | ↑ (improvement) PAGI-QoL^c^ for DexLAN 60 mg QD and DexLAN 90 mg QD vs placebo, P<0.0025 | C 50% loss to follow-up
Metz 2009^44^ [19210298] | DexLAN 30 mg (QD) vs DexLAN 60 mg (QD) vs Placebo | 6 mo | ↑ (improvement) PAGI-QoL^c^ for DexLAN 60 mg QD and DexLAN 90 mg QD vs placebo, P<0.0025 | C 50% loss to follow-up
Howden 2009^45^ [19681809] | DexLAN 60 mg (QD) vs DexLAN 90 mg (QD) vs Placebo | 451 (230) | Higher mean change(improvement) in total PAGI-QoL^c^ scores for DexLAN 60 mg QD and DexLAN 90 mg QD vs the placebo, P<0.0025 (except in relationship sub-scale). DexLAN 60 mg and DexLAN 90 mg maintained their PAGI-QoL while the placebo group reported a deterioration in QOL | C 88% loss to follow-up in the placebo group
Howden 2009^45^ [19681809] | DexLAN 60 mg (QD) vs DexLAN 90 mg (QD) vs Placebo | 6 mo | | C 88% loss to follow-up in the placebo group

a Pittsburgh Sleep Quality Index (PSQI): 19-item questionnaire of sleep quality with 7 component scores with each component score ranged from 0 (best) −3 (worst) to get a global PSQI score range from 0 - 21. A global score >5 indicates poor sleep quality.

b Quality of Life in Reflux and Dyspepsia (QOLRAD) 25 items questionnaire of five dimensions with each item scored on a 7-grade Likert scale; lower values indicate more severe impact on daily functioning.

c Patient assessment of upper gastrointestinal disorders – quality of life questionnaire (PAGIQOL): 30-item questionnaire about the quality of life. The range for total PAGI-QOL is 0-5, with lower scores indicating better health.

###### Esomeprazole—Comparison of Dosages

Two trials compared quality of life with esomeprazole 20 mg versus esomeprazole 40 mg, enrolling a total of 1,287 subjects, with followup data on 1,193 subjects.38,39 One was a placebo-controlled three-arm trial lasting for 4 weeks, with treatment administered once daily, and included subjects with GERD as well as sleep disturbances.39 The effect of different dosages of esomeprazole was evaluated on sleep outcomes measured subjectively as well as with the Pittsburgh sleep quality index (PSQI). Using a PSQI score of 5 or less as an indicator of good sleep quality, a significantly higher proportion of participants using esomeprazole 20 mg (57 percent) and 40 mg (46 percent) reported good sleep quality as compared to placebo (36 percent), P<0.01 for EsOME groups versus placebo. A significantly higher fall in PSQI score was also observed in the 20 mg group (-4.00) and the 40 mg groups (-3.64) as compared to the placebo (-2.19), P<0.0001. A fall in the PSQI global score is indicative of better sleep. In the other trial, lasting 24 weeks, no significant difference in the QOLRAD quality of life score was observed between the group treated empirically with esomeprazole 40 mg and the group whose treatment dosage (20 or 40 mg) was determined by endoscopy.38

###### Rabeprazole—Comparison of Different Dosing Regimens

A trial comparing rabeprazole 20 mg on-demand with rabeprazole 20 mg taken once a day for 6 months assessed quality of life in 268 enrolled subjects and reported that self-reported quality of life significantly improved in the group taking rabeprazole 20 mg once a day and significantly decreased in the rabeprazole 20 mg on-demand group (P<0.05). The difference in change from baseline between the groups was also significant (P<0.05).52

###### Dexlansoprazole—Comparison of Dosages

A three-arm trial of 445 subjects compared Patient Assessment of Upper Gastrointestinal Disorders Quality-of-Life (PAGI-QoL) scores for groups receiving dexlansoprazole 30 mg or dexlansoprazole 60 mg doses with a placebo.44 This study showed that there was a significant improvement in PAGI-QoL in both the 30 mg as well as the 60 mg group as compared to placebo, P<0.0025. In another three-arm trial (451 subjects) comparing PAGI-QoL in groups taking dexlansoprazole 60 mg, dexlansoprazole 90 mg, or a placebo, over 6 months, a higher mean change for PAGI-QoL scores from baseline was observed in both the 60 mg and 90 mg groups when compared to placebo, P<0.0025.^45^

###### Esophagitis Healing

(Table 16)

Table 16 Comparison of different dosages as well as different dosing regimens of the same PPIs: Esophagitis healing

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
EsOME – Different Dosages
Katz 2007^40^ [17305763] | EsOME 10 mg (QD) vs EsOME 40 mg (QD) | 169 (103) | ↑ healing of esophagitis in EsOME 40 mg (86%) as compared to EsOME 10 mg (55%) | C 39% drop-out rates
Katz 2007^40^ [17305763] | EsOME 10 mg (QD) vs EsOME 40 mg (QD) | 4 wk | ↑ healing of esophagitis in EsOME 40 mg (86%) as compared to EsOME 10 mg (55%) | C 39% drop-out rates
LAN – Different Dosing Regimen
Mine 2005^42^ [16105122] | LAN 15 mg (QD) for 16 wk (No step group) vs LAN 30 mg (QD) for 8 wk, followed by FAM 20 mg (BD) for 8 wk (Step down to FAM group) vs LAN 30 mg (QD) or 8 wk followed by LAN 15 mg (QD) for 8 wk (Step down to LAN group) | 43 (43) | Esophagitis healing was seen in all groups (NS) | C Poor description of methods, small sample size
Mine 2005^42^ [16105122] | | 16 wk | Esophagitis healing was seen in all groups (NS) | C Poor description of methods, small sample size
DexLAN – Different Dosages
Metz 2009^44^ [19210298] | DexLAN 30 mg (QD) vs DexLAN 60 mg (QD) vs Placebo | 445 (221) | ↑ esophagitis healing in DexLAN 60 mg (82.5%) & DexLAN 30 mg (74.9%) vs placebo (27.2%), P<0.00001 | C 50% loss to follow-up
Metz 2009^44^ [19210298] | DexLAN 30 mg (QD) vs DexLAN 60 mg (QD) vs Placebo | 6 mo | ↑ esophagitis healing in DexLAN 60 mg (82.5%) & DexLAN 30 mg (74.9%) vs placebo (27.2%), P<0.00001 | C 50% loss to follow-up
Howden 2009^45^ [19681809] | DexLAN 60 mg (QD) vs DexLAN 90 mg (QD) vs Placebo | 451 (230) | ↑ esophagitis healing in DexLAN 60 mg (86.6%) & DexLAN 90 mg (82.1%) vs placebo (25.7%), P<0.00001 | C 88% loss to follow-up in the placebo group
Howden 2009^45^ [19681809] | DexLAN 60 mg (QD) vs DexLAN 90 mg (QD) vs Placebo | 6 mo | ↑ esophagitis healing in DexLAN 60 mg (86.6%) & DexLAN 90 mg (82.1%) vs placebo (25.7%), P<0.00001 | C 88% loss to follow-up in the placebo group
PAN – Different Dosages
Pai 2006^46^ [17009401] | S-PAN 20 mg (QD) vs racemic PAN 40 mg (QD) | 369 (369) | NS differences in healing of esophagitis and erosions between the groups | C No power calculations, baseline characteristics not adequately reported, poor diagnostic quality
Pai 2006^46^ [17009401] | S-PAN 20 mg (QD) vs racemic PAN 40 mg (QD) | 28 d | NS differences in healing of esophagitis and erosions between the groups | C No power calculations, baseline characteristics not adequately reported, poor diagnostic quality

###### Esomeprazole—Comparison of Dosages

One trial compared a once daily dose of esomeprazole 10 mg with esomeprazole 40 mg in 106 patients over a period of 4 weeks.40 A higher proportion of subjects in the 40 mg group (86 percent) had their esophagitis healed as compared to the 10 mg group (55 percent). This trial was graded C.

###### Lansoprazole—Comparison of Different Dosing Regimens

In a trial of 43 participants, graded C, lasting 16 weeks, three different treatment strategies were evaluated: a once a day dose of lansoprazole 15 mg for the duration of the study (no step group), 30 mg a day stepped down to 15 mg a day halfway through the study (step down to lansoprazole group), and 30 mg a day with a substitution with famotidine 20 mg twice a day halfway through the study (step down to famotidine group).42 Esophagitis healing was seen in all arms, with no significant difference between the three groups.

###### Dexlansoprazole—Comparison of Dosages

In one three-arm 6-month trial of 445 subjects comparing esophagitis healing rates in patients taking dexlansoprazole 30 mg, dexlansoprazole 60 mg doses, or a placebo, significantly higher rates of esophagitis healing were observed in the 60 mg (82.5 percent) and 30 mg groups (74.9 percent) as compared to the placebo group (27.2 percent), P<0.00001.^44^ Similarly, in another three-arm 6-month trial of 451 subjects comparing esophagitis healing rates in patients taking dexlansoprazole 60 mg, dexlansoprazole 90 mg, or a placebo, higher rates of esophagitis healing were seen in the 60 mg group (86.6 percent) and the 90 mg group (82.1 percent) as compared to the placebo group (25.7 percent), P<0.00001.^45^

###### Pantoprazole—Comparison of Dosages

One study, graded C, compared pure s-isomer of pantoprazole 20 mg with a racemic mixture of S- and R-isomers of pantoprazole 40 mg over a 4 week treatment period and found no difference in the healing of esophagitis and esophageal erosions between the groups.46

###### Acid Control

(Table 17)

Table 17 Comparison of different dosages as well as different dosing regimens of the same PPIs: Acid control

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
EsOME – Different Dosages
Katz 2007^40^ [17305763] | EsOME 10 mg (QD) vs EsOME 40 mg (QD) | 169 (103) | ↑ acid control (Percent of time w/pH >4 after 5 days of Tx) in EsOME 40 mg (72%) vs EsOME 10 mg (41%) | C 39% dropout rates
Katz 2007^40^ [17305763] | EsOME 10 mg (QD) vs EsOME 40 mg (QD) | 4 wk | ↑ acid control (Percent of time w/pH >4 after 5 days of Tx) in EsOME 40 mg (72%) vs EsOME 10 mg (41%) | C 39% dropout rates
EsOME – Different Dosing Regimen
Vasiliadis 2010^41^ [19809412] | EsOME 40 mg (QD) vs EsOME 40 mg (BD) vs EsOME 40 mg (Once every other day) | 75 (73) | Abnormal acid exposure (≥4% of total time w/Ph<4) in EsOME 40 mg taken once every other day (7%) and not in EsOME 40 mg BD (0.7%) & EsOME 40 mg QD (1.5%). Abnormal De Meester score (≥ 14.7) in EsOME 40 mg taken once every other day (29.4) and not in EsOME 40 mg QD (6.4) & EsOME 40 mg BD (3.9). | B
Vasiliadis 2010^41^ [19809412] | EsOME 40 mg (QD) vs EsOME 40 mg (BD) vs EsOME 40 mg (Once every other day) | 30 d | | B

###### Esomeprazole—Comparison of Dosages

One trial in 106 patients over a period of 4 weeks compared acid control in a parallel trial, with one arm taking a once a day dosage of esomeprazole 10 mg and the other arm taking a dose of once a day esomeprazole 40 mg.40 Acid control was reported as the percentage time with pH > 4 after 5 days of treatment, with higher values indicating better control. Subjects in the 40 mg group spent a higher proportion of time being exposed to pH > 4 (72 percent) as compared to the 10 mg group (41 percent), indicating that the 40 mg dose gives better acid control. This trial was graded C.

###### Esomeprazole—Comparison of Different Dosing Regimens

A three-arm trial assessed acid control over 1 month in 75 people taking esomeprazole 40 mg once a day, esomeprazole 40 mg twice a day and esomeprazole 40 mg once every other day.41 Acid control was evaluated via two indicators: abnormal acid exposure (defined as ≥ 4 percent of total time with pH < 4) and abnormal DeMeester score (≥ 14.7). Abnormal acid exposure was observed in the esomeprazole 40 mg once every other day group (> 7 percent of total time with pH <4) but not in the esomeprazole 40 mg once a day (> 1.5 percent of total time with pH <4) or esomeprazole 40 mg twice a day (> 0.7 percent of total time with pH <4) groups. An abnormal DeMeester score was also observed in the group receiving esomeprazole 40 mg once every other day (29.4) but not in the esomeprazole 40 mg once a day (6.4) or esomeprazole 40 mg twice a day (3.9) groups. This trial was graded B.

###### Antacid Medication Use and Treatment Satisfaction

(Table 18)

Table 18 Comparison of different dosages as well as different dosing regimens of the same PPIs: Antacid medication use and treatment satisfaction

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
EsOME – Different Dosages
Johnson 2005^39^ [16128933] | EsOME 20 mg (QD) vs EsOME 40 mg (QD) vs Placebo | 675 (642) | Lower use of daily antacid rescue tablets in EsOME 40 mg QD (1.0 ± 1.45 tablets/day) and EsOME 20 mg QD (0.9 ± 1.41 tablets/day) vs. placebo (1.7 ± 1.61 tablets/day), P<0.001 | B
Johnson 2005^39^ [16128933] | EsOME 20 mg (QD) vs EsOME 40 mg (QD) vs Placebo | 4 wk | Lower use of daily antacid rescue tablets in EsOME 40 mg QD (1.0 ± 1.45 tablets/day) and EsOME 20 mg QD (0.9 ± 1.41 tablets/day) vs. placebo (1.7 ± 1.61 tablets/day), P<0.001 | B
LAN – Different Dosing Regimen
Cibor 2006^54^ [17357336] | LAN 30 mg (O-D) vs LAN 15 mg (QD) vs LAN 30 mg 4-wk course (intermittent therapy) | 65 (60) | Satisfaction^a^: ↑ % of patients completely satisfied w/Tx in LAN 30 mg O-D group (90%) and LAN 15 mg QD (95%) vs LAN 30 mg intermittent Tx (85%), P<0.05 | B
Cibor 2006^54^ [17357336] | LAN 30 mg (O-D) vs LAN 15 mg (QD) vs LAN 30 mg 4-wk course (intermittent therapy) | 12 mo | Satisfaction^a^: ↑ % of patients completely satisfied w/Tx in LAN 30 mg O-D group (90%) and LAN 15 mg QD (95%) vs LAN 30 mg intermittent Tx (85%), P<0.05 | B
DexLAN – Different Dosages
Fass 2009^43^ [19392864] | DexLAN 30 mg (QD) vs DexLAN 60 mg (QD) vs Placebo | 947 (873) | ↑ % of days w/o rescue medication in DexLAN MR 30 mg (63%) and 60 mg (63%) groups vs placebo (37.3%), P<0.00001 | A
Fass 2009^43^ [19392864] | DexLAN 30 mg (QD) vs DexLAN 60 mg (QD) vs Placebo | 4 wk | ↑ % of days w/o rescue medication in DexLAN MR 30 mg (63%) and 60 mg (63%) groups vs placebo (37.3%), P<0.00001 | A
PAN – Different Dosages
Scholten 2005^47^ [16113546] | PAN 40 mg (O-D) vs PAN 20 mg (O-D) vs Placebo | 548 (465) | Lower average daily antacids intake w/PAN 40 mg O-D (0.33 ± 0.52 tablets/day) and PAN 20 mg O-D (0.45 ± 0.79 tablets/day) vs placebo (0.68 ± 0.77 tablets/day), P=0.0034 | C Poor description of methods
Scholten 2005^47^ [16113546] | PAN 40 mg (O-D) vs PAN 20 mg (O-D) vs Placebo | 28 wk | Lower average daily antacids intake w/PAN 40 mg O-D (0.33 ± 0.52 tablets/day) and PAN 20 mg O-D (0.45 ± 0.79 tablets/day) vs placebo (0.68 ± 0.77 tablets/day), P=0.0034 | C Poor description of methods

a Satisfaction was measured on a 4-point Verbal Rating Scale (VRS; 0 – completely dissatisfied from treatment, 1 – rather dissatisfied, 2 – rather satisfied, 3 – completely satisfied).

###### Esomeprazole—Comparison of Dosages

A three-arm trial for 4 weeks evaluated consumption of rescue antacid medication in 675 participants taking either esomeprazole 20 mg or 40 mg once a day, or placebo.39 The average daily use of antacids was observed to be significantly lower in the esomeprazole 40 mg (1.0 tablets/day) and 20 mg groups (0.9 tablets/day) as compared to placebo (1.7 tablets/day), P<0.001.

###### Lansoprazole—Comparison of Different Dosing Regimens

In a three-arm trial of 65 participants conducted over 1 year, lansoprazole 15 mg once a day was compared to on-demand lansoprazole 30 mg as well as a 30 mg intermittent therapy course (where recurrence of any symptoms was followed by a full 4-week course of lansoprazole 30 mg).54 Patient satisfaction with treatment was recorded at the end of the trial as a measure of efficacy. A significantly higher level of satisfaction was observed in the lansoprazole 30 mg on-demand group (90 percent) and the lansoprazole 15 mg once a day group (95 percent) when compared to the intermittent treatment group (85 percent), P<0.05.

###### Dexlansoprazole—Comparison of Different Dosages

A quality A study with 947 subjects evaluated rescue medication use with respect to 3 treatment arms: dexlansoprazole 30 mg, dexlansoprazole 60 mg, and a placebo.43 Both treatment groups reported a higher percentage of days without rescue medication (63 percent for both 30 mg and 60 mg groups) versus placebo (37.3 percent), P<0.00001.

###### Pantoprazole—Comparison of Dosages

A study of 548 participants compared 20 and 40 mg doses of pantoprazole on an on-demand regimen with a placebo.47 a significantly lower average of daily antacids intake was observed with pantoprazole 40 mg on-demand (0.33 tablets/day) and pantoprazole 20 mg on-demand (0.45 tablets/day) versus placebo (0.68 tablets/day), P=0.0034.

##### Comparison of Once Daily and On-Demand Dosing Regimens of Commonly Used PPIs

Five RCTs49-53 enrolled a total of 8,849 GERD patients with followup data available from 7,905 subjects. Sample sizes, based on availability of followup data, ranged from 132 to 5,265. Three studies compared esomeprazole 20 mg taken once a day with esomeprazole 20 mg taken on demand,49-51 one study compared rabeprazole 20 mg taken once a day with rabeprazole 20 mg taken on demand52 and one study compared rabeprazole 10 mg taken once a day with rabeprazole 10 mg taken on demand.53

The findings from these studies have been organized by the following outcomes of interest: symptom assessment; quality of life (QOL) and esophagitis healing. Details of these outcomes are presented in the Evidence Tables while key points are summarized below. Adverse effects are presented under Key Question 3.

###### Symptom Assessment

(Table 19)

Table 19 Comparisons between once daily and on-demand dosing regimens of commonly used PPIs: Symptom assessment

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
EsOME – Different Dosing Regimen
Szucs 2009^50^ [18783388] | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) | 1935 (1904) | ↑ proportion of patient w/o symptoms (heartburn & regurg) in EsOME 20 mg QD (86%) vs EsOME 20 mg O-D (80%), P<0.01 | B
Szucs 2009^50^ [18783388] | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) | 6 mo | ↑ proportion of patient w/o symptoms (heartburn & regurg) in EsOME 20 mg QD (86%) vs EsOME 20 mg O-D (80%), P<0.01 | B
Sjosted 2005^49^ [16091055] | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) | 477 (370) | No difference for overall symptomatic relapse between EsOME 20 mg QD (5.0%) and EsOME 20 mg O-D (5.7%), P=0.77 | B
Sjosted 2005^49^ [16091055] | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) | 6 mo | No difference for overall symptomatic relapse between EsOME 20 mg QD (5.0%) and EsOME 20 mg O-D (5.7%), P=0.77 | B
RAB – Different Dosing Regimen
Morgan 2007^52^ [18080054] | RAB 20 mg (O-D) vs RAB 20 mg (QD) | 268 (234) | ↑ % of heartburn-free days w/RAB 20 mg QD (90.3%) vs RAB 20 mg O-D (64.6%), P<0.0001 | B
Morgan 2007^52^ [18080054] | RAB 20 mg (O-D) vs RAB 20 mg (QD) | 6 mo | ↑ % of heartburn-free days w/RAB 20 mg QD (90.3%) vs RAB 20 mg O-D (64.6%), P<0.0001 | B
Bour 2005^53^ [15801915] | RAB 10 mg (O-D) vs RAB 10 mg (QD) | 152 (132) | ↑ % of patients w/symptoms relief w/RAB 10 mg QD (86.4%) vs RAB 10 mg O-D (74.6%), P= 0.065 ↑ recurrence rate at the end of Tx w/RAB 10 mg O-D (21.1%) vs. RAB 10 mg QD (13.6%), P=0.065 | B
Bour 2005^53^ [15801915] | RAB 10 mg (O-D) vs RAB 10 mg (QD) | 6 mo | ↑ % of patients w/symptoms relief w/RAB 10 mg QD (86.4%) vs RAB 10 mg O-D (74.6%), P= 0.065 ↑ recurrence rate at the end of Tx w/RAB 10 mg O-D (21.1%) vs. RAB 10 mg QD (13.6%), P=0.065 | B

###### Esomeprazole—Comparison of on-demand with once daily dosing regimens

Two trials, 6 months in duration and with 2,412 enrolled subjects (2274 in followup), compared esomeprazole 20 mg on-demand with esomeprazole 20 mg taken once daily.49,50 The larger study, with 1,935 enrolled participants, reported a significantly higher proportion of patients experiencing complete relief from symptoms with the once a day dose (86 percent) as compared to the on-demand dose (80 percent, P<0.01).50 The other, smaller study with 477 participants revealed no significant differences in the proportion of symptom-free patients assigned to the on-demand (94.3 percent) or once a day regimens (95 percent, P=0.77).49

###### Rabeprazole—Comparison of On-Demand With Once Daily Dosing Regimens

Two trials, 6 months in duration, were reviewed. One compared rabeprazole 20 mg on-demand with rabeprazole 20 mg taken once a day52 and another compared rabeprazole 10 mg on-demand with rabeprazole 10 mg taken once a day.53 These two studies enrolled 420 subjects, with followup data available on 366 subjects. Results indicated that, in the 20 mg comparison, a significantly higher proportion of patients experienced heartburn free days when rabeprazole was taken once a day (90.3 percent) as compared to on-demand (64.6 percent, P<0.0001).52 Similar results were observed with a 10 mg dose, with a higher proportion of patients observed as symptom free when rabeprazole was taken once a day (86.4 percent) as compared to on-demand (74.6 percent). 53 However, this finding was not statistically significant (P=0.065).

###### Quality of Life

(Table 20)

Table 20 Comparisons between once daily and on-demand dosing regimens of commonly used PPIs: Quality of life

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
EsOME – Different Dosing Regimen
Pace 2005^51^ [16098002] | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) | 6017 (5265) | QOLRAD^a^: Improvement in all dimensions w/EsOME 20 mg QD vs EsOME 20 mg O-D, P<0.0001 | C No blinding
Pace 2005^51^ [16098002] | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) | 26 wk | QOLRAD^a^: Improvement in all dimensions w/EsOME 20 mg QD vs EsOME 20 mg O-D, P<0.0001 | C No blinding
RAB – Different Dosing Regimen
Morgan 2007^52^ [18080054] | RAB 20 mg (O-D) vs RAB 20 mg (QD) | 268 (234) | ↑ QoL^b^ in RAB 20 mg QD ↓ QoL in RAB 20 mg O-D (P<0.05). Change in QoL between groups: P<0.05. | B
Morgan 2007^52^ [18080054] | RAB 20 mg (O-D) vs RAB 20 mg (QD) | 6 mo | ↑ QoL^b^ in RAB 20 mg QD ↓ QoL in RAB 20 mg O-D (P<0.05). Change in QoL between groups: P<0.05. | B

a Quality of Life in Reflux and Dyspepsia (QOLRAD) 25 items questionnaire of five dimensions with each item scored on a 7-grade Likert scale; lower values indicate more severe impact on daily functioning.

b Patient assessment of upper gastrointestinal disorders – quality of life questionnaire (PAGIQOL): 30-item questionnaire about the quality of life. The range for total PAGI-QOL is 0-5, with lower scores indicating better health.

###### Esomeprazole—Comparison of On-Demand With Once Daily Dosing Regimens

A large trial, enrolling 6017 participants, with data available from 5,265 participants after a 26 week followup, assessed the quality of life between two groups taking either a once daily 20 mg dose of esomeprazole or esomeprazole 20 mg on demand.51 Using the QOLRAD score, the groups taking a once daily dose were shown to be significantly improved across all dimensions in comparison to those in the on-demand group, P<0.0001.

###### Rabeprazole—Comparison of On-Demand With Once Daily Dosing Regimens

A trial comparing rabeprazole 20 mg on-demand with rabeprazole 20 mg taken once a day for 6 months assessed quality of life in 268 enrolled subjects and reported that self-reported quality of life significantly improved in the group taking rabeprazole 20 mg once a day and significantly decreased in the rabeprazole 20 mg on-demand group (P<0.05). The difference in change from baseline between the groups was also significant (P<0.05)52.

###### Esophagitis Healing

(Table 21)

Table 21 Comparisons between once daily and on-demand dosing regimens of commonly used PPIs: Esophagitis healing

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
EsOME – Different Dosing Regimen
Sjosted 2005^49^ [16091055] | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) | 477 (370) | ↑ proportion of pts in endoscopic remission in EsOME 20 mg QD (81%) vs EsOME 20 mg O-D (58%), P<0.0001 | B
Sjosted 2005^49^ [16091055] | EsOME 20 mg (O-D) vs EsOME 20 mg (QD) | 6 mo | ↑ proportion of pts in endoscopic remission in EsOME 20 mg QD (81%) vs EsOME 20 mg O-D (58%), P<0.0001 | B

###### Esomeprazole—Comparison of On-Demand With Once Daily Dosing Regimens

One trial evaluated endoscopic remission rates over 6 months in subjects taking esomeprazole 20 mg on-demand with esomeprazole 20 mg once a day.49 The study found a significantly higher proportion of patients with endoscopic remission with the once daily dose (81 percent) as compared to the on-demand dose (58 percent), P<0.0001. This trial was graded B.

##### Comparison of PPIs With Over the Counter Doses of Approved PPIs (Omeprazole 20 mg, Lansoprazole 15 mg)

Eight RCTs55-62 enrolled a total of 4,768 GERD patients, with followup data available from 4,168 subjects. Over the Counter Doses of approved PPIs (omeprazole 20 mg, lansoprazole 15 mg) are approved by the U.S. Food and Drug Administration (FDA) for the treatment of frequent heartburn, which is defined as heartburn that occurs two or more days per week. The patients took various PPIs including omeprazole, esomeprazole, rabeprazole, pantoprazole, and lanzoprazole. Sample sizes, based on availability of followup data, ranged from 48 to 1,176. Half of the studies (4 of 8 trials; 50 percent) in this category of comparisons were graded B, 3 trials were graded A (37.5 percent) and 1 study (13.5 percent) was graded C.

The findings from these studies have been organized by the following outcomes of interest: symptom assessment, quality of life, and esophagitis healing. Details of these outcomes are presented in the Evidence Tables while key points are summarized below. Adverse effects are presented under Key Question 3.

###### Symptom Assessment

(Table 22)

Table 22 Comparison of PPI with over the counter doses of approved PPIs (OME 20 mg, LAN 15 mg): Symptom assessment

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
Lightdale 2006^55^ [16773434] | EsOME 20 mg (QD) vs OME 20 mg (QD) | 1176 (1106) | NS differences b/w groups at 4 wk for resolution of heartburn (60.6% EsOME vs 60.5% OME; P=0.995), proportion of heartburn-free day (72.6% EsOME vs 70.9% OME; P = 0.354) or nights (85.7% EsOME vs 83.2% OME, P = 0.069) | A
Lightdale 2006^55^ [16773434] | EsOME 20 mg (QD) vs OME 20 mg (QD) | 8 wk | | A
Schmitt 2006^55^ [16642422] | EsOME 40 mg (QD) vs OME 20 mg (QD) | 1148 (1079) | NS differences b/w groups at 4 wk for investigator-assessed resolution of heartburn (65% EsOME vs 63.1% OME; P=0.48) | A
Schmitt 2006^55^ [16642422] | EsOME 40 mg (QD) vs OME 20 mg (QD) | 4-8 wk | NS differences b/w groups at 4 wk for investigator-assessed resolution of heartburn (65% EsOME vs 63.1% OME; P=0.48) | A
Devault 2006^61^ [16682260] | EsOME 20 mg (QD) vs LAN 15mg (QD) | 1026 (1001) | ↑ endoscopic/symptomatic remission rate^a^ in EsOME (84.8%) vs LAN (75.9), P=0.0007. | B
Devault 2006^61^ [16682260] | EsOME 20 mg (QD) vs LAN 15mg (QD) | 6 mo | ↑ endoscopic/symptomatic remission rate^a^ in EsOME (84.8%) vs LAN (75.9), P=0.0007. | B
Pace 2005^58^ [16024305] | RAB 20 mg (QD) vs OME 20 mg (QD) | 560 (442) | ↓ time to the first day of satisfactory heartburn relief w/RAB (2.8±0.2 d) vs OME (4.7±0.5 d), P= 0.0045 Similar time to complete heartburn relief for RAB (7.2 d) vs OME (8.4 d), NS Similar change in % of patients with good reflux control w/RAB (7% to 90%) vs OME (5.5% to 90.7%). | B
Pace 2005^58^ [16024305] | RAB 20 mg (QD) vs OME 20 mg (QD) | 8 wk | | B
Pilotto 2007^56^ [17724802] | OME 20 mg (QD) vs LAN 30 mg (QD) vs PAN 40 mg (QD) vs RAB 20 mg (QD) | 320 (301) | ↑ rates of disappearance of heartburn with PAN (100%) & RAB (100%) vs OME (86.9%) & LAN (82.4%), P<0.05 for PAN vs OME, RAB vs OME, LAN vs PAN, LAN vs RAB. ↑ rates of disappearance of acid regurg for OME (100%) & PAN (92.2%) vs LAN (75%) & RAB (90.1%), P<0.05 for LAN vs OME, LAN vs PAN, LAN vs RAB. ↑ rates of disappearance of epigastric pain for RAB (100%), PAN (95.2%) & OME (95%) vs LAN (82.6%), P<0.05 for LAN vs OME, LAN vs PAN, LAN vs RAB. | B
Pilotto 2007^56^ [17724802] | OME 20 mg (QD) vs LAN 30 mg (QD) vs PAN 40 mg (QD) vs RAB 20 mg (QD) | 2 mo | | B
Chen 2005^60^ [15918199] | EsOME 40 mg (QD) vs OME 20 mg (QD) | 48 (44) | Similar improvement in heartburn score from baseline for EsOME (-22.3 ± 2.1) and OME (-21.4 ± 2.2), NS | C Small sample size, no power calculation
Chen 2005^60^ [15918199] | EsOME 40 mg (QD) vs OME 20 mg (QD) | 8 wk | Similar improvement in heartburn score from baseline for EsOME (-22.3 ± 2.1) and OME (-21.4 ± 2.2), NS | C Small sample size, no power calculation

a Kaplan-Meier estimate of endoscopic and symptomatic remission rate of erosive esophagitis. Endoscopic/symptomatic remission was defined as no detectable EE and no study discontinuation as a result of reflux symptoms.

All six trials were conducted on adult GERD patients. Three out of the six compared esomeprazole with omeprazole,55,60,62 one compared rabeprazole with omeprazole,58 and one, a four arm trial, compared lansoprazole, pantoprazole, and rabeprazole with omeprazole.56

The remaining trial compared esomeprazole 20 mg with lansoprazole 15 mg over 6 months.

In the first trial, comparing esomeprazole 20 mg versus omeprazole 20 mg over a 8-week period, no significant differences were observed in the resolution of heartburn (60.6 percent esomeprazole vs 60.5 percent omeprazole, P=0.995), proportion of patients with heartburn-free days (72.6 percent esomeprazole vs 70.9 percent omeprazole, P=0.354), or proportion of patients with heartburn free nights (85.7 percent esomeprazole vs 83.2 percent omeprazole, P=0.062) after 4 weeks of treatment.55 Similarly, in another 8-week trial comparing esomeprazole 40 mg with omeprazole 20 mg, no significant differences in investigator-assessed resolution of heartburn (65 percent esomeprazole vs 63.1 percent omeprazole; P=0.48) after 4 weeks of treatment.62 The third 8-week trial, comparing esomeprazole 40 mg versus omeprazole 20 mg also found no significant differences in the change in heartburn score from baseline between the esomeprazole 40 mg group (-22.3) and the omeprazole 20 mg group (-21.4).60

In the 8-week, 560 participant trial comparing rabeprazole 20 mg with omeprazole 20 mg, the time to first day of satisfactory heartburn relief was significantly lower with rabeprazole (2.8 days) compared to omeprazole (4.7 days).58

In the four-arm, 320 participant trial comparing lansoprazole 30 mg, pantoprazole 40 mg, and rabeprazole 20 mg with omeprazole 20 mg,56 100 percent of all participants of the pantoprazole and rabeprazole groups had a complete resolution of heartburn at 2 months, a significantly different result as compared to the omeprazole (87 percent) and lansoprazole (82 percent) groups, P<0.05.

In a large study comparing esomeprazole 20 mg with lansoprazole 15 mg, higher endoscopic and symptomatic remission rates were seen with esomeprazole (84.8 percent) than lansoprazole (75.9 percent), P=0.0007.^61^

###### Quality of Life

(Table 23)

Table 23 Comparison of PPI with over the counter doses of approved PPIs (OME 20 mg, LAN 15 mg): Quality of life

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
Pace 2005^58^ [16024305] | RAB 20 mg (QD) vs OME 20 mg (QD) | 560 (442) | Similar change from baseline in % patients w/very good/good general well being^a^ on RAB (47.6%; 41.7 to 89.3%) & OME (42.8%; 43.5 to 86.3%). | B
Pace 2005^58^ [16024305] | RAB 20 mg (QD) vs OME 20 mg (QD) | 8 wk | Similar change from baseline in % patients w/very good/good general well being^a^ on RAB (47.6%; 41.7 to 89.3%) & OME (42.8%; 43.5 to 86.3%). | B
Tepes 2009^59^ [19453031] | OME 20 mg (O-D) vs OME 10 mg (QD) vs OME 20 mg (QD) | 216 (186) | Similar mean health-related QoL scores^b^ (range 1-10) after Tx period w/OME 20 mg O-D (9.4), OME 10 mg QD (9.7) and OME 20 mg QD (9.8), NS. | B
Tepes 2009^59^ [19453031] | OME 20 mg (O-D) vs OME 10 mg (QD) vs OME 20 mg (QD) | 12 Mo | Similar mean health-related QoL scores^b^ (range 1-10) after Tx period w/OME 20 mg O-D (9.4), OME 10 mg QD (9.7) and OME 20 mg QD (9.8), NS. | B

a General well being was self reported on a 5-point Likert scale: 0 (very good), 1 (good), 2 (fair), 3 (poor) 4 (very poor).

b Health-related quality of life assessed using a visual analogue scale: Range 1 to 10 (1 worst; 10 best)

Two trials reported quality of life and general well-being outcomes.58,59 In one trial, 560 participants randomized to rabeprazole 20 mg or omeprazole 20 mg reported a similar change in proportion of patients with self reported “good” general well-being (47.6 percent of the rabeprazole group and 42.8 percent of the omeprazole group).58

In the other, comparing omeprazole 20 mg on-demand with omeprazole 10 mg once a day and omeprazole 20 mg once a day in 216 participants, all groups reported similar mean health related quality of life scores at the end of the 12-month treatment period (omeprazole 20 mg on-demand: 9.4, omeprazole 10 mg once a day: 9.7, omeprazole 20 mg once a day: 9.8).59

###### Esophagitis Healing

(Table 24)

Table 24 Comparison of PPI with over the counter doses of approved PPIs (OME 20 mg, LAN 15 mg): Esophagitis healing

Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | N_E_ (N_FU_) | Results | Quality
Study Year [UI] | Comparisons: Drug Name Dose (Frequency) | F/U duration | Results | Quality
Lightdale 2006^55^ [16773434] | EsOME 20 mg (QD) vs OME 20 mg (QD) | 1176 (1106) | Similar healing rates for EsOME (90.6%) and OME (88.3%), P=0.621. | A
Lightdale 2006^55^ [16773434] | EsOME 20 mg (QD) vs OME 20 mg (QD) | 8 wk | Similar healing rates for EsOME (90.6%) and OME (88.3%), P=0.621. | A
Schmitt 2006^55^ [16642422] | EsOME 40 mg (QD) vs OME 20 mg (QD) | 1148 (1079) | Similar healing rates for EsOME (68.2%) and OME (66.3%), P=0.385 at 4 weeks; Similar healing rates for EsOME (87%) and OME (85.8%), P=0.552 at 8 weeks | A
Schmitt 2006^55^ [16642422] | EsOME 40 mg (QD) vs OME 20 mg (QD) | 4-8 wk | Similar healing rates for EsOME (68.2%) and OME (66.3%), P=0.385 at 4 weeks; Similar healing rates for EsOME (87%) and OME (85.8%), P=0.552 at 8 weeks | A
Zheng 2009^57^ [19248200] | OME 20 mg (QD) vs LAN 30 mg (QD) vs PAN 40 mg (QD) vs EsOME 40 mg (QD) | 274 (264) | Similar healing rates for OME (87.7%), LAN (89.6%), PAN (91.1%), EsOME (95.4%), NS. | A
Zheng 2009^57^ [19248200] | OME 20 mg (QD) vs LAN 30 mg (QD) vs PAN 40 mg (QD) vs EsOME 40 mg (QD) | 8 wk | Similar healing rates for OME (87.7%), LAN (89.6%), PAN (91.1%), EsOME (95.4%), NS. | A
Devault 2006^61^ [16682260] | EsOME 20 mg (QD) vs LAN 15mg (QD) | 1026 (746) | ↑ rates of endoscopic remission^a^ for EsOME (86.9%) vs LAN (77.8%), P=0.0003. | B
Devault 2006^61^ [16682260] | EsOME 20 mg (QD) vs LAN 15mg (QD) | 6 mo | ↑ rates of endoscopic remission^a^ for EsOME (86.9%) vs LAN (77.8%), P=0.0003. | B
Pace 2005^58^ [16024305] | RAB 20 mg (QD) vs OME 20 mg (QD) | 560 (442) | RAB (97.9%) similar to OME (97.5%) in endoscopic healing. | B
Pace 2005^58^ [16024305] | RAB 20 mg (QD) vs OME 20 mg (QD) | 8 wk | RAB (97.9%) similar to OME (97.5%) in endoscopic healing. | B
Pilotto 2007^56^ [17724802] | OME 20 mg (QD) vs LAN 30 mg (QD) vs PAN 40 mg (QD) vs RAB 20 mg (QD) | 320 (301) | ↑ healing rates for PAN (90%) & RAB (89%) vs OME (75%) & LAN (85%), P<0.05 for PAN vs OME, RAB vs OME. | B
Pilotto 2007^56^ [17724802] | OME 20 mg (QD) vs LAN 30 mg (QD) vs PAN 40 mg (QD) vs RAB 20 mg (QD) | 2 mo | ↑ healing rates for PAN (90%) & RAB (89%) vs OME (75%) & LAN (85%), P<0.05 for PAN vs OME, RAB vs OME. | B
Tepes 2009^59^ [19453031] | OME 20 mg (O-D) vs OME 10 mg (QD) vs OME 20 mg (QD) | 216 (186) | Stratified by baseline esophagitis status:; 1. No esophagitis: ↑ endoscopic remission with OME 10 mg QD (90.5%,) vs OME 20 mg O-D (57.7%), P<0.05 (ITT analysis: OME 10 mg QD (76%,) vs OME 20 mg O-D (48.4%), P<0.05.; 2. Grade A esophagitis: ↑ endoscopic remission with OME 10 mg QD (90.3%,) vs OME 20 mg O-D (65.1%), P<0.01.; 3. Grade B esophagitis: NS difference in endoscopic remission rates. | B
Tepes 2009^59^ [19453031] | OME 20 mg (O-D) vs OME 10 mg (QD) vs OME 20 mg (QD) | 12 Mo | | B
Chen 2005^60^ [15918199] | EsOME 40 mg (QD) vs OME 20 mg (QD) | 48 (44) | ↑ rate of esophagitis healing w/EsOME (72.7%) vs OME (50%), (ITT analysis: EsOME (76.4%) vs OME (45.5%). | C Small sample size, no power calculation
Chen 2005^60^ [15918199] | EsOME 40 mg (QD) vs OME 20 mg (QD) | 8 wk | ↑ rate of esophagitis healing w/EsOME (72.7%) vs OME (50%), (ITT analysis: EsOME (76.4%) vs OME (45.5%). | C Small sample size, no power calculation

a No detectable erosive esophagitis (endoscopic remission)

Eight RCTs55-60,62 reported endoscopic healing results.

Two were 4-arm trials.56,57 One, enrolling 320 participants for a treatment duration of 8 weeks, compared lansoprazole 30 mg, pantoprazole 40 mg, and rabeprazole 20 mg with omeprazole 20 mg and found that pantoprazole and rabeprazole had significantly higher esophagitis healing rates as compared to omeprazole (90 and 89 percent vs. 75 percent, respectively), P<0.05.^56^ Lansoprazole also had a higher esophagitis healing rate (85 percent) but did not attain significance. The other, which used esomeprazole 40 mg instead of rabeprazole as an arm, enrolled 274 participants and reported similar healing rates for omeprazole (87.7 percent), lansoprazole (89.6 percent), pantoprazole (91.1 percent) and esomeprazole (95.4 percent), NS.57

Another study, enrolling 1,176 participants and comparing esomeprazole 20 mg with omeprazole 20 mg over 8 weeks, found similar esophagitis healing rates for esomeprazole (90.6 percent) and omeprazole (88.3 percent), P=0.621^55^. A second trial, enrolling 1,148 participants and comparing esomeprazole 40 mg with omeprazole 20 mg over an 8-week treatment period, also found similar healing rates for esomeprazole (87 percent) and omeprazole (85.8 percent), P=0.552 at 8 weeks.55 A smaller study, enrolling 44 participants, compared esomeprazole 40 mg with omeprazole 20 mg over 8 weeks and found that a higher proportion of participants taking esomeprazole showed esophagitis healing (72.5 percent) as compared to those taking omeprazole (50 percent).60

In another trial, with 560 participants randomized to rabeprazole 20 mg or omeprazole 20 mg, a similar proportion of patients with esophagitis healing among groups was observed (97.5 percent of the rabeprazole group and 97.5 percent of the omeprazole group).58

A trial enrolling 216 subjects and comparing omeprazole 20 mg on demand and omeprazole 10 mg once a day with omeprazole 20 mg once a day, results were stratified by baseline esophagitis status.59 In those subjects with no esophagitis at baseline, a significantly higher proportion of patients with healing of esophagitis in the omeprazole 10 mg once a day group (90.5 percent) was seen as compared to the 20 mg on-demand group (57.7 percent), P<0.05. In those subjects with grade A esophagitis at baseline, a significantly higher proportion of patients with healing of esophagitis was observed in the omeprazole 10 mg once a day group (90.3 percent) as compared to the 20 mg on-demand group (65.1 percent), P<0.01. In those subjects with grade B esophagitis at baseline, no significant difference was seen between the groups at one year.

A large trial of 1026 participants graded B, comparing esomeprazole 20 mg versus lansoprazole 15 mg, showed significantly higher endoscopic remission with esomeprazole (86.9 percent) than with lansoprazole (77.8 percent, P=0.0003).61

### Key Question 1E Surgical Treatments

#### Synopsis

The 2005 CER found little to no difference between laparoscopic total and partial fundoplication, laparoscopic fundoplication with and without division of short gastric vessels, and open total and partial fundoplication in producing symptom relief, QoL improvement, or decreasing usage of antisecretory medications. In the present update, the inclusion of four additional RCTs and seven non-randomized comparative studies did not alter the conclusions of the original report with respect to these comparisons. The strength of evidence was rated moderate.

#### Detailed Analysis

##### Comparative Effectiveness of Surgery

(Table 25)

Table 25 Comparative studies evaluating the long-term outcomes of different types of fundoplication

Author Year | Study design | Enroll/Final | Objective Outcomes | | | Subjective Outcomes | | Quality Comments
Author Year | Follow-up Duration | Enroll/Final | Off PPI | Off all meds | Diagnostic tests | Symptoms | Quality of life | Quality Comments
Laparoscopic total vs partial fundoplication
Shaw 2010^65^ [19789920] | RCT 5.7 y | 50/41 | 85% | nd | nd | Heartburn VAS 1.9 Dysphagia VAS 0.8 Regurgitation VAS 0.5 | nd | A
Shaw 2010^65^ [19789920] | RCT 5.7 y | 50/43 | 90% | nd | nd | Heartburn VAS 0.8 Dysphagia VAS 0.2 Regurgitation VAS 0.1 | nd | A
Nijjar 2010^66^ [20566975] | RCT | 52/48 | nd | nd | nd | Heartburn 27% Dysphagia 41% | Satisfied 92% | A
Nijjar 2010^66^ [20566975] | 5 y | 60/57 | nd | nd | nd | Heartburn 44% Dysphagia 32% | Satisfied 79%
Cai 2008^67^ [18942055] | RCT 10 y | 54/48 | 81% | nd | nd | Heartburn 15% Dysphagia 52% | Satisfied 94% | B
Cai 2008^67^ [18942055] | | 53/41 | 73% | nd | nd | Heartburn 20% Dysphagia 34% | Satisfied 93%
Dallemagne 2006^70^ [16333553] | nRCT 10.3 y | 68/49 | 91% at 5 y 92% at 10 y | nd | Normal barium swallow at 5 y 100% (36/36) | Heartburn 29% Dysphagia 22% GERD-free 93% | GIQLI 115.5 ± 20.8 | B
Dallemagne 2006^70^ [16333553] | nRCT 10.3 y | 32/20 | 91% at 5 y 92% at 10 y | nd | Intrathoracic migration at 5 y 33% (7/21) | Heartburn 35% Dysphagia 25% GERD-free 82% | GIQLI 108.5 ± 27.9 | B
Hafez 2008^71^ [18449599] | nRCT 7.8 y | 89/89 | nd | nd | nd | Insufficient GERD symptom control at 93 mo 14% | nd | B Inconsistent sample size, only p-value reported for multivariate analyses
Hafez 2008^71^ [18449599] | nRCT 7.8 y | 45/45 | nd | nd | nd | Insufficient GERD symptom control at 93 mo 9% | nd | B Inconsistent sample size, only p-value reported for multivariate analyses
Fein 2008^72^ [18766417] | nRCT 5-10 y | 85/74 | 86% | 92% | Esophagitis 4% Hiatal hernia 6% LES pressure 9.1 ± 4.1 LES length 3.5 ± 0.7 (n=48) | Heartburn 30% Regurg 15% Dysphagia 31% | GIQLI 109.8 ± 24.4 | C High loss to f/u, unclear pt flow, retrospective, historical control
| | 32/25 a | 59% | 6% | Esophagitis 0% Hiatal hernia 11% LES pressure 8.9 ± 5.9 LES length 3 ± 0.6 (n=19) | Heartburn 29% Regurg 32% Dysphagia 30% | GIQLI Anterior: 104.1 ± 26.9 Toupet: 115.1 ± 21.0
Pessaux 2005^73^ [16230543] | nRCT 7.1 y | 711/711 | nd | nd | nd | Dysphagia 8% Visick I and II 93% | nd | C Unclear eligibility criteria, incomplete medical f/u exam in some pt
Pessaux 2005^73^ [16230543] | nRCT 7.1 y | 629/629 | nd | nd | nd | Dysphagia 2% Visick I and II 93% | nd | C Unclear eligibility criteria, incomplete medical f/u exam in some pt
Wijnhoven 2008^74^ [18071830] | nRCT 5.9 y | 525/525 | nd | 67% | nd | Heartburn 38% Regurg 38% | nd | C
Wijnhoven 2008^74^ [18071830] | nRCT 5.9 y | 319/319 | nd | 56% b | nd | Heartburn 38% Regurg 38% | nd | C
Laparoscopic total fundoplication with vs without division of short gastric vessels
Yang 2008^69^ [18156921] | RCT 10 y | 50/44 | 91% | nd | nd | Heartburn 11% Regurg 9% | nd | B
Yang 2008^69^ [18156921] | RCT 10 y | 52/44 | 80% | nd | nd | Heartburn 18% Regurg 17% | nd
Mardani 2009^86^ [19016274] | RCT 10 y | 52/42 | nd | 83% | nd | No reflux symptoms 90% Heartburn 10% Regurg 10% GSRS reflux score 1.4 ± 0.7^*^ GSRS dysphagia score 2.0 ± 1.5^*^ | PGWB 100.0 ± 17.2^*^ | C Unclear recruitment criteria
Mardani 2009^86^ [19016274] | RCT 10 y | 47/40 | nd | 83% | nd | No reflux symptoms 78% Heartburn 23% Regurg 18% GSRS reflux score 1.9 ± 1.4^*^ GSRS dysphagia score 2.4 ± 1.6^*^ | PGWB 92.7 ± 21.4^*^
Pessaux 2005^73^ [16230543] | nRCT 7.1 y | 305 | nd | nd | nd | GERD recurrence 13% Dysphagia 9% Visick I and II 91% | nd | C Unclear eligibility criteria, incomplete medical f/u exam in some pt
Pessaux 2005^73^ [16230543] | nRCT 7.1 y | 404 | nd | nd | nd | GERD recurrence 9% Dysphagia 6% Visick I and II 96% | nd | C Unclear eligibility criteria, incomplete medical f/u exam in some pt
Wijnhoven 2008^74^ [18071830] | nRCT 5.9 y | 110 | nd | 61% | nd | Heartburn 38% Regurg 38% | nd | C
Wijnhoven 2008^74^ [18071830] | nRCT 5.9 y | 734 | nd | 63% | nd | Heartburn 38% Regurg 38% | nd | C
Laparoscopic vs open total fundoplication
Draaisma 2006^75^ [16794387]; Broeders 2009^76^ [19801931] | RCT 5.3 y | 98/79 | nd | 72% | % time pH<4 80% (n=10) End expiratory LES 1.7 ± 0.2 (n=48) | Heartburn 41% Regurg 29% Dysphagia 54% Visick I and II 92% (n=79) | General QoL VAS 65.3 (n=79) | C Objective data available in only a subset of pt
Draaisma 2006^75^ [16794387]; Broeders 2009^76^ [19801931] | RCT 5.3 y | 79/69 | nd | 77% | % time pH<4 70% (n=10) End expiratory LES 1.5 ± 0.2 (n=49) | Heartburn 39% Regurg 19% Dysphagia 45% Visick I and II 91% (n=63) | General QoL VAS 61.4 (n=63) | C Objective data available in only a subset of pt
Salminen 2007^77^ [17667497] | RCT 11 y | 55/38 | 74% | 59% | Esophagitis 5% Loose LES 5% | Heartburn/regurg 43% Dysphagia 59% | nd | C Treatment not given as randomized, high dropout, inconsistencies in reported results
Salminen 2007^77^ [17667497] | RCT 11 y | 55/35 | 67% | 60% | Esophagitis 6% Loose LES 26% | Heartburn/regurg 56% Dysphagia 39% | nd | C Treatment not given as randomized, high dropout, inconsistencies in reported results
Trullenque 2005^78^ [16004525] | nRCT 7 y | 75/nd | nd | nd | nd | Heartburn 0% Regurg 0% | nd | C poor reporting of f/u length, dropout and pt characteristics, unclear analysis
Trullenque 2005^78^ [16004525] | nRCT 7 y | 28/nd | nd | nd | nd | Heartburn 1 pt Regurg 0% | nd | C poor reporting of f/u length, dropout and pt characteristics, unclear analysis
Ruiz-Tovar 2010^79^ [19916741] | nRCT ≥ 10 y | total enrolled 174 final lap:78 | 93% | nd | nd | Heartburn or regurg 11% Mild dysphagia 2.6% | nd | C Incomplete reporting
| | final open: 88 | 84% (p<0.05) | nd | nd | Heartburn or regurg 24% Mild dysphagia 3.4%

GIQLI=Gastrointestinal Quality of Life, PGWB=Psychological General Well-Being index, GSRS=Gastrointestinal Symptom Rating Scale

* mean ± SEM

a This group includes 22 patients who underwent anterior fundoplication and 10 patients who underwent Toupet fundoplication

b Compared with patients with total fundoplication, patients with partial fundoplication had a odd ratio of 1.427 (95% CI 1.009-2.019) of postoperative medication use

Seven RCTs (enrolling a total of 807 patients) and eight non-randomized comparative studies (enrolling a total of 3,656 patients) of fundoplication for the treatment of GERD were identified for inclusion in the present update. Five RCTs65-69 and five non-randomized comparative studies70-74 compared two different approaches to laparoscopic fundoplication techniques: total versus partial, and with versus without division of short gastric vessels. Two RCTs75-77 and two non-randomized comparative studies78,79 examined laparoscopic versus open fundoplication.

Mean followup in these studies ranged from 5 to 10.3 years, and sample sizes from 99 to 844. Among RCTs, two were graded A,65,66 two B,67,69 and three C.68,75-77 Among the non-randomized comparative studies, two studies70,71 were graded B and six72-74,77-79 were graded C.

###### Total Vs. Partial Fundoplication

Three RCTs65-67 and five non-randomized comparative studies70-74 compared laparoscopic total versus partial fundoplication. No significant differences in GERD symptoms between groups were observed among any of the studies. One non-randomized comparative study reported that patients who underwent partial fundoplication had an odds ratio of 1.427 (95 percent CI 1.009-2.019) of postoperative medication use compared with patients who had total fundoplication.74 Similarly, another non-randomized comparative study reported a significantly lower proportion of PPI users in the total fundoplication group compared with the partial fundoplication group (total: 14 percent vs. partial: 41 percent, P < 0.01).72 Two non-randomized comparative studies reporting GIQIL scores did not find any significant difference between groups.70,72

###### Total Laparoscopic Fundoplication With Vs. Without Division of Short Gastric Vessel

Two RCTs68,69 and two non-randomized comparative studies73,74 evaluated laparoscopic fundoplication with versus without division of the short gastric vessels. Both RCTs (one69 quality B and one68 quality C) followed patients for 10 years, and did not find differences in medication use, GERD symptoms, or quality of life measures. One of the two non-randomized studies followed 709 patients for 7.1 years and found no significant difference in recurrence of GERD, dysphagia, gas bloat, or Visick grades.73 Similarly, the other non-randomized study, with 844 patients and 5.9 years of follow-up did not find significant differences in the proportion of antireflux medication users between the two groups (with division: 61 percent vs. without division: 63 percent).74

###### Laparoscopic Vs. Open Total Fundoplication

Two RCTs75-77 and two non-randomized comparative studies78,79 compared laparoscopic with open total fundoplication. All four studies were graded C. Both RCTs reported no significant differences in medication use, diagnostic test results, GERD symptoms, or quality of life.75-77 Similarly, One non-randomized comparative study did not find significant differences in GERD symptoms between the two groups.78 In contrast, another non-randomized comparative study reported significantly lower proportions of patients on PPI and occasional heartburn or regurgitation among patients who had laparoscopic procedure, compared with those who had open fundoplication (PPI: 7 percent vs. 16 percent, P < 0.05; occasional symptom: 11 percent vs. 24 percent, P < 0.05).79

##### Long-Term Effectiveness of Surgery

(Table 26)

Table 26 Cohort studies evaluating the long-term outcomes of surgical procedures

Author Year | Study design | Enroll/Final | Objective Outcomes | | | Subjective Outcomes | | Quality Comments
Author Year | Follow-up Duration | Enroll/Final | Off PPI | Off all meds | Diagnostic tests | Symptoms | Quality of life | Quality Comments
Zehetner 2006^80^ [16391962] | Cohort laparoscopic partial fundoplication 5 y | 100/87 | Nd a | nd | %time pH<4 Preoperative: 17.8% (normal value<4%) Postoperative: 0.9% | DeMeester score Preoperative: 4.27 @ 5 y: 0.47 Heartburn @ 5 y: 15% | Satisfaction: 96.6% | B Very small portion of patients for 24-h pH manometry
Rice 2006 81 [16549692] | Cohort laparoscopic partial fundoplication 6.4 y | 117/100 | 5-11 y: 88% | 5-11 y: 78% | nd | Heartburn using the analog scale (postoperative): score of 0 (n=46) score of 1-3 (n=34) score of 4-6 (n=11) score of ≥7 (n=9) less likely to describe dysphagia postoperatively | Overall satisfaction: score of 10 (n=35) score of 7-9 (n=35) score of 4-6 (n=17) score ≤3 (n=3) | C No information on patient characteristics
Biertho 2006^82^ [16823657] | Cohort laparoscopic total fundoplication 5 y | 515/277 | nd | nd | nd | GERD score difference (pre-5yrs): 21.5 (p<0.001) GI score (pre-5yrs): 2.4 (p<0.05) | nd | C High loss to follow-up, no reason provided
Teixeira 2009^83^ [19453033] | Cohort laparoscopic total fundoplication 5.4 y | 168/143 | nd | nd | nd | Average of the difference (pre vs. post, score 0-3), *p<0.001 Heartburn +2.2* Regurgitation +2.0* Dysphagia +0.9* | 56.3 b (preop) | C Retrospective, no adjustment; QoL scale not externally validated; no power calculation
Teixeira 2009^83^ [19453033] | Cohort laparoscopic total fundoplication 5.4 y | 168/143 | nd | nd | nd | Average of the difference (pre vs. post, score 0-3), *p<0.001 Heartburn +2.2* Regurgitation +2.0* Dysphagia +0.9* | 74.0 @ 5 yr Net difference (p<0.001) | C Retrospective, no adjustment; QoL scale not externally validated; no power calculation
Oelschlager 2008^84^ [17970835] | Cohort laparoscopic total or partial fundoplication 5.8 y | 288/288 | nd | At 5 y: 73% | nd | Symptoms improved % (postop) Heartburn (90%), Regurgitation (92%) Dysphagia (75%) | nd | B
Broeders 2010^85^ [20473997] | Cohort total fundoplication 5 y | 338/213 | nd | 81.8% | % total acid exposure at 5 yr: 2.4% (p < 0.001) LES pressure: 1.5 kPa | Heartburn: 35.6% Regurgitation: 27.1% Dysphagia: 51.1% | QoL at 5 y: 63 (P < 0.05) | B, incomplete 5-year follow up data for symptom assessment

a 3.5% of patients needed a regular PPI treatment postoperatively.

b QoL (scale included GI and non-GI symptoms, medication, physical, emotional and psychosocial; maximum score of 96, the higher the score, the better)

Six cohort studies provided long-term outcome (mean 5 to 6.4 years) data on fundoplication.80-85 Sample sizes ranged from 100 to 515. Three80,84,85 were graded B and three were graded C.81-83

Three of the six cohort studies reported significant improvement in GERD symptoms.80,82,83 One study of laparoscopic partial fundoplication reported significant decreases in the percentage of time with pH < 4 after surgical treatment (17.8 percent vs. 0.9 percent, P < 0.0005), as well as significant decreases in DeMeester score (4.3 vs. 0.5, P < 0.0005).80 The proportion of patients who were off all medications at followup was over 70 percent in three studies.81,84,85 Two cohort studies of total fundoplication reported significant improvements in quality of life measure (32-item QoL scale ranging from 0-96 points, 56.3 vs. 74, P < 0.001; 100-point visual analogue scale, 51 vs. 63, P < 0.05).83

### Key Question 1F Endoscopic Treatments

#### Synopsis

The 2005 CER reviewed studies on four endoscopic procedures: EndoCinch™ Suturing System, Stretta^®^, Enteryx™, and the NDO Plicator™. The present report excluded Enteryx and the NDO Plicator because they are no longer available in the U.S.. Stretta was removed from the U.S. market but reintroduced in 2010 by a different manufacturer. Another device, EsophyX™, has been commercialized since the 2005 CER. Thus, we evaluated three endoscopic procedures: the EndoCinch Suturing System, Stretta, and EsophyX.

The EndoCinch Suturing System (Bard, Murray Hill, NJ) places sutures to create a submucosal plication in the gastric cardia. Stretta (Mederi Therapeutics, Greenwich, CT) involves application of radiofrequency energy to the lower esophageal sphincter through a catheter. EsophyX (EndoGastric Solutions, Redmond, WA) plicates the fundus to the anterior and left lateral wall of the distal esophagus slightly below the esophagogastric junction in order to tighten the lower esophageal sphincter.

The effectiveness of the endoscopic procedures for the long-term management of GERD remains substantially uncertain. Similar to the 2005 CER, we found no study of direct comparisons between the different endoscopic treatments in this update. We found little or no difference between EndoCinch and sham, and between Stretta and sham. Five cohort studies assessed the efficacy of EsophyX. The strength of evidence for all the findings was rated either low or insufficient. Better quality studies with longer follow-up are needed to determine the value of endoscopic procedures in the treatment of chronic GERD.

#### Detailed Analysis

In the present update, three RCTs evaluated the efficacy of endoscopic treatments for GERD.87-89 All three studies had short study durations (3 months to 1 year) and small sample sizes (40 to 46 patients).

In addition to RCTs, six cohort studies90-95 of EndoCinch™, five cohort studies96-101 of EsophyX™, and seven cohort studies102-108 of Stretta™ or endoscopic radiofrequency treatment were identified in the present update.

##### The Effectiveness of the EndoCinch Suturing System

(Tables 27 and 28)

Table 27 Comparative studies evaluating endoscopic treatment for GERD

Author Year | Study design | Intervention | Enroll/Final | Objective Outcomes | | | Subjective Outcomes | | Quality Comments
Author Year | Follow-up Duration | Intervention | Enroll/Final | Off PPI | Off All Meds | Diagnostic tests | Symptom improved | Quality of life | Quality Comments
Schwartz 2007^87^ [16763053] a | RCT b 3 mo | EndoCinch™ | 20/20 | 40% of pt reduced PPI use by >95% | nd | % time pH<4 -2.7 ± 4.4 LES pressure 0 ± 0.7 | Heartburn 60% Heartburn score -8.6 ± 9.0 Regurg score -5.2 ±8.3 | In SF-20, there were no sig difference between treatment groups in the change in physical function, social function, and mental health sub-scores. Compared with sham, EndoCinch had sig greater increase in role function and general health sub-scores, and sig greater decrease in bodily pain perception. | A
Schwartz 2007^87^ [16763053] a | RCT b 3 mo | sham | 20/20 | 5% of pt reduced PPI use by >95% | nd | % time pH<4 -1.9 ± 4.6 LES pressure -0.3 ± 0.8 | Heartburn 60% Heartburn score -0.9 ± 4.3 Regurg score -1.1 ± 4.2 | | A
Montgomery 2006^88^ [17101568] | RCT 1 y | EndoCinch | 22/22 | 3 mo: 50% 1 y: 45% | nd | Esophagitis 5% % time pH<4 4.7 (IQR 3.18-7.13) LES length 5cm (IQR 4.0-7.0) LES pressure 9.9 mmHg (IQR 5.9-13.9) | There were no sig differences in GSRS at 1 y between the two groups. | There were no sig differences in SF-36 PCS, and SF-36 MCS at 1 y between the two groups. | B Small sample size without power calculation, unclear sample population
| | sham | 24/21 | 3 mo: 33% 1 y: 24% | nd | Esophagitis 11% % time pH<4 7.4 (IQR 4.03-12.45) LES length 5.5cm (IQR 4.2-6.0) LES pressure 14.0 mmHg (IQR 11.6-19.0) | nd | There were no sig differences in SF-36 PCS, and SF-36 MCS at 1 y between the two groups.
Aziz 2010^109^ [19730952] | RCT 1 y | Stretta® double dose | 12/12 | 50% | nd | LES pressure sig increased and esophagitis grade sig improved in single and double dose group, but not in sham group | HROL score sig improved in single and double dose group, but not in sham group | nd | A
| | Stretta® single dose | 12/12 | 16.7% | nd | LES pressure sig increased and esophagitis grade sig improved in single and double dose group, but not in sham group | HROL score sig improved in single and double dose group, but not in sham group | nd
| | Sham | 12/12 | 0% | nd | LES pressure sig increased and esophagitis grade sig improved in single and double dose group, but not in sham group | HROL score sig improved in single and double dose group, but not in sham group | nd
Coron 2008^89^ [18616516] | RCT 1 y | Stretta® | 23/20 | ITT 17% PP 20% | nd | Esophagitis at 6 mo 53% % time pH<4 at 6 mo 11.4 ± 6.3% | Heartburn score 1.7 ± 0.8 Regurg score 1.2 ± 0.4 Epigastric burning score 1.3 ± 0.6 | SF-36 physical 53 ± 7 SF-36 mental 51 ± 9 REFLUX-QUAL global 84 ± 9 | B Small sample size
| | Control | 20/14 | ITT 0% PP 0% | nd | Esophagitis at 6 mo 54% % time pH<4 at 6 mo 8.8 ±6.1% | Heartburn score 2.3 ± 1.5 Regurg score 1.7 ±1.4 Epigastric burning score 2.0 ± 1.4 | SF-36 physical 40 ± 10 SF-36 mental 50 ± 7 REFLUX-QUAL global 77 ± 18

ITT=intention-to-treat analysis, PP=per-protocol analysis, GLQI=Gastrointestinal Life Quality Index, PCS=physical component score, MCS=mental component score, IQR=interquartile range

SF-36 contains 8 scales - physical functioning (PF), role limitation-physical (RP), bodily pain (BP), general health perceptions (GH), vitality (VT), social functioning (SF), role limitation-emotional (RE), mental health (MH) – and 2 summary scores - the physical component summary score (PCS) and mental component summary score (MCS. SF-36 Japanese version 1.2 was used in this study. Range of scores was 0 -100; higher scores indicate better functioning and well-being.

a Data presented is change from baseline.

b Data presented in this table refers to the first 3 mo of the study where patients were randomized and blinded. After 3 mo, patients in the sham or observation groups were offered the EndoCinch treatment.

Table 28 Cohort studies evaluating endoscopic treatment

Study Year [UI] | N enrolled/N follow-up | Follow-up duration | Results | | | | | | Quality
Study Year [UI] | N enrolled/N follow-up | Excluded ≥ grade 3 esophagitis (y/n) | Change in symptoms | QoL | Esophagitis healing | Medication | pH study | Other | Quality
EndoCinch™
Schiefke 2005^95^ [15888777] | 70/56 Prosp | 18 mo n | heartburn score improved (58.2 vs. 36.8, P=0.001) | nd | Grade 0 (37.1% vs. 45.7%; no P value) | off PPI (0% vs. 6%; no P value) | %time pH <4: 9.1% vs. 8.5% (NS) | | B
Ozawa 2009^93^ [19440812] | 48/48 | 24 mo y | heartburn symptom score improved (14.9±4.6 vs.2.7±2.9, P<0.0001) | nd | Grade 0 (0% vs. 80%) | off PPI (66%) | nd | | B
Domagk 2006^90^ [16542275] | 26/26 RCT a | 6 mo nd | Heartburn severity score 20.9 ± 24.2 | SF-36 physical 50.3 ± 8.1 SF-36 mental 43.5 ± 8.9 GLQI 85.2 ± 14.2 | | Off PPI 77% | Improved esophagitis % % time pH<4 9.6 ± 8.9% LES pressure 38.4 ± 10.4 Modified DeMeester symptom score 2.2 ± 2.4 | | B Small sample size
Paulssen 2008^94^ [18938771] | 119/80 ?Prosp | 41 mo n | heartburn score improved (baseline 21.4±4.72 (SD) vs. final 8.5±8.43, P <0.01); no regurg (baseline 37% vs. final 66%, no P value) | nd | nd | no sig change compared to baseline | %time pH <4: 11.7% vs. 13.5% (NS) | | C Large drop out
Liu 2006^92^ [16484118] | 95/95 Retro | 12 mo y | complete resolution of heartburn and regurg: 72% | nd | nd | nd | nd | | C Retrospective study without adjustment
Liao 2008^91^ [18318824] | 21/20 Prosp | 24 mo y | heartburn score improved (64±25.9 vs. 21.1±26.4, P <0.001); regurg improved (2.4±0.7 vs.1.3±1, P <0.001) | SF-36 general and mental health improved (31.2±14.5 vs. 38.3±15.3, P=0.032; 49.7±19.5 vs. 57±16.4, P=0.03) | nd | nd | nd | | C Small sample
EsophyX™
Cadiere 2008^98^ [18443855] | 86/79 Prosp | 12 mo y | Heartburn eliminated: 61/79 (77%) Regurgitation eliminated: 34/79 (59%) | improved GERD- HRQL of ≥50% 58/79 (73%) | Esophagitis none (17% vs. 45%) | Off PPI (0% vs. 68%) Off any medication (0% vs. 48%) | DeMeester score b (34 vs. 28, p<0.001) Significant increase in LES resting pressure by 53% (p<0.001) | | B
Cadiere 2009^96,97^ [19288158] | 19/14 Prosp | 25 mo y | heartburn resolved: 13/14 (93%) | improved GERD-HRQL of ≥50% 9/14 (64%) | nd | Off PPI: 10/14 (71%) | nd | | C Small sample
Repici 2010^99^ [19902310] | 20/15 | 12 mo n | | improved GERD- HRQL of ≥50% 11/15 (73%) | | Off PPI 7/15 (47%) | LES pressure (NS) | | C Small sample
Testoni 2010^100^ [20091308] | 20/18 | 6 mo n | GERD-HRQL when off PPI (45 ± 20 vs. 16 ± 14, P < 0.001) Number of reflux (63 ± 43 vs. 43 ± 41, P = 0.02) | GERD-QUAL when off PPI (114 ± 29 vs. 74 ± 21, P < 0.001) | Grade 0 (17% vs. 22%, NS) | Off PPI (0% vs. 55.6%) Reduced PPI use: 22% | DeMeester score (20 ± 13 vs. 18 ± 17, NS) LES pressure (8 ± 5 vs. 10 ± 3, NS) | nd | C small sample, short followup
Demyttenaere 2010^101^ [19730949] | 26/22 Prosp | 10 mo y | Improved symptom score (Anvari c) at 3 mo (34±14 vs. 17±15, P=0.002) | Improved GERD-HRQL (Velanovich d) at 3 mo (22±13 vs. 10±7, P=0.0007) | nd | Taking PPIs at 10 mo: (100% vs.68%) | | | C small sample, short followup
Stretta^®^
Reymunde 2007^108^ [17321231] | 83/80 Retro | 48 mo y | GERD symptom score improved (2.7 vs. 0.6,? P<0.05); 69% complete resolution (P <0.001) | GERD QOL improved (2.4 vs. 4.3, P<0.001) | grade A (83.3% vs. 0%) | off meds (0% vs. 86%, P<0.001) | nd | | B
Lutfi 2005^105^ [15624052] | 77/61 Prosp | 26 mo n | nd | improved QOLRAD (3.6±1.1 vs. 5±1.5, P<0.001) | nd | off PPI (26/61; 43%) | 24 had study: acid exposure 7.8±2.6% vs 5.1±3.3%, P=0.001) | | B
Cipolletta 2005^102^ [15868272] | 32/32 Prosp | 12 mo y | heartburn score improved (3.4±0.9 vs. 1.6±1.6, P=0.001) | improved HRQL score (28±7 vs. 16±11.5, P=0.003); SF-36 physical & mental (40±11 vs. 49±11.5, P=0.05; 43±9 vs. 56±11.5, P=0.001) | erosion 25% vs. 12.5% (NS) | daily PPI 100% vs. 19% (NS) | %time <4: 11.7 vs. 8.4 (NS) | | B
Noar 2007^107^ [17321232] | 109/93 Retro | 48 mo y | heartburn score improved (3.6 vs. 1.18, P=0.001) | improved HRQL score (27.8 vs. 7.1, P=0.001) | nd | off PPI (0% vs. 75%, P=0.05) | nd | no dysplasia or adenoCA in 39 pts with Barrett's | C Only pts with long f/u included
Meier 2007^106^ [17613919] | 60/60? Prosp | 12 mo n | heartburn score improved (3.4±1.1 vs. 1.3±1.3, P <0.05) | GERD- HRQL improved (19.2±9 vs. 6.6±7.3; P <0.0001); SF-36 physical & mental improved (P<0.05) | nd | off meds (0% vs. 38%) | DeMeester improved (72.9±63 vs. 35.1±28.6; P=0.003) | | C Heterogeneous sample; no objective testing for GERD
Dundon 2008^103^ [18829607] | 37/32 Retro | 53 mo nd | heartburn score in those who did not require other surgery (2.43 vs. 1.43, NS) | GERD QoL in those who did not require other surgery (3.14 vs. 1.46, NS) | nd | 2/32 (?) completely off meds | nd | | C 53 mo data only on 13 patients
Jeansonne 2009^104^ [19153320] | 68/35 e RCT f | 6 mo nd | Severe heartburn 22% Severe regurg 18.8% Dysphagia 0% | | | 50% off PPI | % time pH < 4 9.1% | | C High dropout, poor GERD diagnostic criteria

a This intervention group is subset of a larger RCT.

b Median.

c Range 0 to 72. Lower score indicates improved symptom score.

d Range 0 to 50. Lower score indicates improved symptom score.

e A total of 51% follow-up rate was reported for this study. Exact numbers of participants followed per group were not reported.

f This intervention group is subset of a larger RCT.

Of the two sham-controlled trials that evaluated EndoCinch, one A-rated study followed 40 patients for 3 months,87 and one B-rated study enrolled 44 patients for 1 year.88 One study reported a significantly greater proportion of patients who stopped or decreased PPI use in the EndoCinch group compared with the sham group at 3 months (65 percent vs. 25 percent, P = 0.01),87 whereas no difference was observed in the other study at both 3 months (50 percent vs. 33 percent, P = NS) and 1 year (45 percent vs. 24 percent, P = NS).88 Compared with sham, patients in the EndoCinch group had significantly better improvement in heartburn score at 3 months (EndoCinch: -8.6 ± 9.0 vs. sham: -0.9 ± 4.3, P < 0.01), but not in regurgitation score (EndoCinch: -5.2 ± 8.3 vs. sham: -1.1 ± 4.2, P = NS).87 Neither trial found significant differences in 24-hour pH study measures and quality of life between EndoCinch and sham.

Of the six cohort studies that evaluated EndoCinch, follow-up durations ranged from 6 to 41 months. Analyzed sample sizes were small, from 20 to 95 patients. Three studies were graded B,90,93,95 and three graded C.91,92,94 Significant improvements in heartburn were found in four studies.91,93-95 Of the two studies that reported quality of life outcome,90,91 one reported significant improvement in SF-36 general and mental scores.91 Two studies reported increased proportion of patients without esophagitis over the follow-up period, but statistical significance were not reported.93,95

##### The Effectiveness of EsophyX

(Table 28)

Of the five cohort studies that evaluated EsophyX, follow-up duration ranged from 6 to 25 months. Apart from one study98 that enrolled 86 patients and was rated B, all other studies96,97,99-101 of EsophyX enrolled 26 or less than patients and were rated C. The proportion of patients who were off PPI at the end of the followup period ranged from 47 to 71 percent.96-101 Improvement of GERD-HRQL was reported by all five studies, of which two found significant results.100,101

##### The Effectiveness of Stretta

(Tables 27 and 28)

Two RCTs evaluated Stretta and followed patients for 1 year.89,109 One A-rated RCT randomized 36 patients into double Stretta procedures, single Stretta procedure, or sham.109 At one-year follow up, the proportions of patients who were off PPI were 50 percent, 17 percent, and 0 percent in the double Stretta group, the single Stretta group, and sham group, respectively.109 Significant improvements were reported in both Stretta groups in GERD HRQL, esophagitis grade, LES basal pressure, and esophageal acid exposure, but no significant change was found in the sham group.109 Another B-rated RCT randomized 43 patients into Stretta procedure or control groups.89 The proportion of patients who stopped or decreased PPI use was significantly greater in the Stretta group compared with the control group at 6 months (78 percent vs. 40 percent, P = 0.01) but it was not significant at 1 year (56 percent vs. 35 percent, P = 0.16). Similarly, there was significant difference in mean regurgitation score (higher is worse) at 6 months (Stretta: 1.3 ± 0.6 vs. control: 2.2 ± 1.3, P = 0.01), but not at 1 year (Stretta: 1.2 ± 0.4 vs. control: 1.7 ± 1.4, P = 0.58). This RCT did not find significant differences in heartburn score, SF-36 and Global REFLUX-QUAL scores, 24-hour pH study measures, and the proportion of patients with esophagitis between the two arms.

Of the seven cohort studies that evaluated Stretta, follow-up durations ranged from 6 months to 4 years. Analyzed sample sizes were relatively small, from 32 to 93 patients. Three studies were graded B,102,105,108 and four graded C.103,104,106,107 Of the six studies that reported changes in GERD symptoms,102-104,106-108 four found significant improvements during the follow-up periods.102,106-108 Also, five studies reported statistically significant improvement in quality of life,102,105-108 and one did not.103 Two studies reported increased proportion of patients without esophagitis during the follow-up period, but statistical significance were not reported.102,108 At the end of the follow-up, the proportion of patients who were off PPI in these seven studies ranged from 6 percent to 86 percent,102-108 but only two studies reported statistical significant difference between baseline and follow-up.107,108

### Key Question 1G Comparative Effectiveness of Treatment for Extraesophageal Manifestation of Gastroesophageal Reflux Disease

#### Synopsis

Key findings from comparative effectiveness of treatment for extraesophageal manifestation of GERD are summarized as follows:

##### Medical Treatment for Extraesophageal Manifestations of GERD

###### Asthma

- A systematic review evaluating the effect of medical treatment did not find consistent effects of PPI or H2RA versus placebo in improving asthma symptoms, nocturnal asthma, use of asthma medications or in objective indicators such as forced expiratory volume in 1 second (FEV1), and morning and evening peak expiratory flow.
- An update to the systematic review did not find evidence from 9 primary RCTs to contradict the conclusions of the systematic review. Studies that used either omeprazole 20 mg in combination with domperidone 10 mg or esomeprazole 40 mg reported an improvement in morning and evening peak expiratory flow rate. Studies using lansoprazole 30 mg or pantoprazole 40 mg did not report an improvement in either asthma symptoms or lung function tests. While rabeprazole 20 mg taken two times a day improved respiratory symptoms during exercise in patients with exercise induced asthma, as compared to a placebo, it did not improve quality of life or pulmonary function tests results.
- An RCT comparing surgery with an H2RA and antacids, and lifestyle modification as a co-intervention in all arms, did not find statistically significant differences in pulmonary function tests among the three groups, though the proportion of patients reporting an improvement ≥ 40 percent in asthma symptom score was significantly higher in the surgery group (75 percent) as compared to the H2RA group (0 percent) and the control group (20 percent) (P<0.05).
- The strength of evidence was rated insufficient.

###### Hoarseness

- Two of the six RCTs in the systematic review assessing the effect of PPI treatment on hoarseness found a significant higher percentage of patients who reporting resolution of hoarseness symptom with PPI treatment, as compared to a placebo.
- The strength of evidence was rated low.

###### Chronic Cough

- A meta-analysis of data from 4 studies in the review demonstrated no significant difference in total resolution of cough between PPIs and placebo, odds ratio 0.46 (95 percent CI: 0.19 to 1.15). A meta-analysis of data from 4 RCTs reporting mean cough scores at the end of the trial in 109 participants found a borderline significant improvement in the mean cough scores at the end of the trial with PPIs as compared to placebo -0.38 units (95 percent CI: -0.77 to 0.00, P=0.05). Another meta-analysis of data from 6 RCTs (161 participants) reporting change in cough scores from the baseline in the same systematic review revealed a significant improvement in cough scores from baseline favoring PPIs as compared to placebo (-0.39 standardized mean difference units; 95 percent CI -0.71 to -0.08).
- The strength of evidence was rated low.

##### Surgical Treatment for Extraesophageal Symptoms

- All of the data on the impact of surgical treatment for GERD on of extraesophageal symptoms come from surgical cohort studies, with a wide variation in the population treated, the severity of the underlying GERD as well as its extraesophageal manifestation, the outcome measures used to assess efficacy, the surgical interventions used, as well as the intensity and duration of followup. Within these parameters, there is an improvement of extraesophageal symptoms with surgical treatment for GERD, with cough (13 to 96 percent in 11 out of 13 studies reporting outcome) and laryngeal symptoms (64 to 94 percent in 5 out of 8 studies reporting outcome) showing a better range of complete resolution of symptoms than asthma (0 to 64 percent in 3 out of 7 studies reporting outcome).
- The strength of evidence was rated insufficient.

#### Detailed Analysis

In this update to the 2005 CER,1 we expanded the population of interest to include patients with both chronic GERD and symptomatic extraesophageal GERD (with a focus on chronic cough, hoarseness/laryngitis and asthma). We included systematic reviews or meta-analyses that synthesized studies focusing exclusively on treatment of patients with chronic GERD, and their impact on extraesophageal GERD (with a focus on chronic cough, hoarseness/laryngitis and asthma). The interventions assessed included both medical (PPI, H2RA, lifestyle modification and patient education) and surgical treatment (fundoplication as well as non-fundoplication repairs).

From the 107 reviews in the search results, 5 systematic reviews qualified for inclusion, which assessed various treatment strategies for chronic cough, hoarseness/laryngitis and asthma.12,110-113 One systematic review focused solely on the efficacy of medical and surgical treatment on asthma;12 one studied the effect of medical and surgical treatment on chronic cough;110 one assessed the effect of surgical and non-surgical treatment on hoarseness/laryngitis,111 and two112,113 included all of the outcomes of interest - chronic cough, hoarseness/laryngitis and asthma.

In addition to reviewing the systematic review on the efficacy of medical and surgical treatment modalities on asthma,12 we conducted an update by searching for primary studies on the same topic published since 2002—including a period of 9 months prior to the date of the last search listed in the Gibson review to make sure we did not miss any studies.

On closer examination of the studies included in the qualified systematic reviews, it was noticed that all of the studies from the systematic review by Hungin 2005^112^ were already included in the later reviews that assessed the same outcomes – asthma,12 chronic cough,110 and hoarseness/laryngitis.111 Furthermore, the quality of Hungin 2005 was assessed to be inferior to the other reviews (e.g., no assessment of the quality of the included primary studies). Therefore, Hungin 2005 was excluded in this report.

All of the systematic reviews included studies on adults but two also included studies on both adults and children.12,110 However, data on children were excluded from our analyses.

When the systematic reviews included both RCTs and observational studies, their results are reported separately.

The quality of the systematic reviews were assessed by the AMSTAR checklist.10 The quality of the systematic reviews of RCTs on asthma outcomes,12 hoarseness/laryngitis outcome,111 and chronic cough outcomes110 was adequate. The quality of the systematic review of surgical cohort studies on all outcomes113 was suboptimal: data on study design details, independent reviews, list of excluded studies, study quality and publication bias assessment were not provided.

##### Medical Treatment for Extraesophageal Manifestations of GERD

###### Asthma

###### Synopsis

One systematic review that was included in this analysis evaluated the effect of PPI treatment on asthma with data from RCTs.12 In addition, an update to this review found 9 primary RCTs of medical GERD therapy in patients with asthma.

Medical treatment does not show a consistent effect on asthma symptoms, nocturnal asthma, use of asthma medications, and objective lung function indicators, including Forced Expiratory Volume in 1 second (FEV1), morning peak expiratory flow and evening peak expiratory flow. Studies that used either omeprazole 20 mg in combination with domperidone 10 mg or esomeprazole 40 mg reported an improvement in morning and evening peak expiratory flow rate. Studies using lansoprazole 30 mg or pantoprazole 40 mg did not report an improvement in either asthma symptoms or lung function tests. While rabeprazole 20 mg taken two times a day improved respiratory symptoms during exercise in patients with exercise induced asthma, as compared to a placebo, it did not improve quality of life or pulmonary function tests results.

###### Detailed Presentation

(Table 29 and 30)

Table 29 Treatment of GERD and its effect on asthma: Data from systematic reviews

Author Year | Gibson 2003^12^
Design | A systematic review of GERD treatment for asthma in adults and children
Population | Patients with asthma – adults (1 study of H2RA vs placebo included children and adolescents between 10-20 years of age).
Intervention (Exposure) and Comparator | 1. H2 antagonist - ranitidine and cimetidine; 2. Proton Pump Inhibitor (Only Omeprazole in varying doses - 20 mg, 40 mg, 80 mg and 160 mg; 3. Conservative anti-reflux therapy: raising the head of the bed, drinking warm water after meals, not eating for 3 hours prior to bed time, anti-reflux medication as required, avoid use of aspirin and anticholinergic preparations and avoidance of procedures increasing intra-abdominal pressure; 4. Surgery
Results | - Database search yielded 262 abstracts, 22 full-text articles and 1 abstract were retrieved. Of these, 12 RCTs were included.; - 9 cross-over trials and 3 parallel design, quality of studies (7 A studies, 4 B studies, and one C study), types of interventions: proton pump inhibitors (6 studies), histamine antagonists (5 studies), surgery (1 study), conservative management (1 study). With exception of 1 RCT comparing H2 antagonist with placebo who studied children and adolescents (aged 10-20 years old), all other RCTs investigated adults.; - 9 of 12 studies failed to show a significant improvement in asthma symptoms.; - Meta-analysis model and heterogeneity (if applicable):; ◦ H2 antagonist, Proton Pump inhibitor, conservative or surgical therapy vs. placebo on FEV1: No effect of treatment; ◦ H2 antagonist or Proton Pump inhibitor vs. placebo on morning peak expiratory flow, Fixed effect model, mean difference [95% CI]: 5.28 [-35.43, 44.72] Heterogeneity: Chi^2^ = 0.3, df=2 (P=0.86); I^2^=0.0%; ◦ H2 antagonist or Proton Pump inhibitor vs. placebo on evening peak expiratory flow, Fixed effect model, mean difference [95% CI]: 7.03 [ -25.88, 39.95 ] Heterogeneity: Chi^2^ = 0.02, df=2 (P=0.99); I^2^=0.0%; ◦ H2 antagonist vs. placebo on nocturnal symptoms score (including a study on adolescents), Fixed effect model, mean difference [95% CI]: -0.16 [ -0.42, 0.11 ] Heterogeneity: Chi^2^ = 0.97, df=3, (P=0.81); I^2^=0.0%; ◦ Proton Pump inhibitor vs. placebo, Outcome: puffs per day, Fixed effect model, mean difference [95% CI]: -0.52 [-1.7, 0.67] Heterogeneity: Chi^2^ = 0.59, df=2, (P=0.74); I^2^=0.0%
Comments | The duration of medical treatments was short in the most studies. Insufficient sample size in the pooled studies. One study included children and adolescents aged from 10 to 20 years.
AMSTAR
A priori design? | Y | Study quality assessment performed? | Y
Two independent reviewers? | Y | Study quality appropriately used in analysis? | N
Comprehensive literature search? | Y | Appropriate statistical synthesis? | Y
All publication types and languages included? | Y | Publication bias assessed? | N
Included and excluded studies listed? | Y | Conflicts of interest stated? | Y
Study characteristics provided? | Y

Author Year [PMID] | Iqbal 2008^113^ [19105666]
Design | A systematic review of retrospective and prospective studies, including RCTs, of surgical fundoplication in the treatment of the symptoms of extraesophageal reflux (EER).
Population | Adults
Intervention (Exposure) and Comparator | Surgery / fundoplication, vs. placebo/medical therapy
Results | Seven studies, 350 patients – 1 RCT, four prospective studies, 2 retrospective studies; In 3 out of 7 studies, 0 to 64 percent of the participants reported a complete resolution of asthma symptoms. In 6 studies, 15 to 84 percent of the participants reported a partial resolution of asthma symptoms after surgery.
Comments | Included both prospective and retrospective studies; only 1 RCT for asthma; no quantitative analysis; quality of studies was not assessed
AMSTAR
A priori design? | N | Study quality assessment performed? | N
Two independent reviewers? | N | Study quality appropriately used in analysis? | n/a
Comprehensive literature search? | Y | Appropriate statistical synthesis? | n/a
All publication types and languages included? | N | Publication bias assessed? | N
Included and excluded studies listed? | N | Conflicts of interest stated? | Y
Study characteristics provided? | Y

Table 30 Treatment of GERD and its effect on asthma: RCTs published between 2002-2010

Author year [PMID] | Interventions | N_E_/N_F/U_ | F/U | Symptoms | Quality of Life | Pulmonary function tests | Asthma Medication use | Quality
Kiljander, 2006^116^ [20110554] | Esomeprazole 40 mg once daily vs Esomeprazole 40 mg twice daily vs placebo | 961/828 | 26 wk | No significant difference in total asthma symptom score between EsOME 40 mg once or twice daily vs. placebo | Significant improvement in Asthma Quality of Life Questionnaire (AQLQ) score in EsOME 40 mg once daily (mean change in score=0.8) and 40 mg twice daily(mean change in score=1.0) vs placebo (mean change in score=0.5), P<0.001 | No significant net difference in morning peak expiratory flow (L/min) between EsOME 40 mg once daily vs. placebo (net difference: +3.5 (95% CI: -3.2, 10.2), NS & EsOME 40 mg twice daily vs. placebo (net difference: +5.5 (95% CI: -1.2, 12.2), NS; Significantly higher net difference in FEV1(L/min) between EsOME 40 mg once daily vs. placebo (net difference: +0.09 (95% CI: 0.03, 0.15), P<0.0001 & EsOME 40 mg twice daily vs. placebo (net difference: 0.12 (95% CI: 0.06, 0.12), P<0.0042 | No significant difference in use of rescue bronchodilators between EsOME 40 mg once and twice daily vs. placebo | A
Littner 2005^117^ [16162697] | Lansoprazole 30 mg vs. placebo | 343/173 | 24 wk | No significant difference in overall asthma symptom score between LAN (1.57± 0.56 to 1.21 ± 0.58) vs. placebo (1.56 ± 0.55 to 1.35 ± 0.65), NS | | No significant net difference in morning peak expiratory flow (L/min) between LAN vs. placebo (net difference: -5; 95 percent CI: -28, 18), NS; No significant net difference in evening peak expiratory flow (L/min) between LAN vs. placebo (net difference: -8; 95 percent CI: -32, 16), NS; | No significant difference in albuterol use (puffs/d) between LAN (4.3 ± 2.6 to 3.3 ± 2.6) vs. placebo (4.5 ± 3.1 to 3.6 ± 3.0), NS | B
Sharma 2007^119^ [17461474] | Omeprazole 20 mg /d + Domperidone 10 mg three times/d vs. placebo | 204/198 | 16 wk | Significant change in daytime asthma score between OME (17.4% decrease) vs. placebo (8.94% decrease), P=0.0001 Significant change in nighttime asthma score between OME (19.6% decrease) vs. placebo (5.4% decrease), P=0.0001 | | Significant higher net difference in morning peak expiratory flow (L/min) between OME vs. placebo (net difference: 22; 95 percent CI: 10, 34), P=0.004; difference in evening peak expiratory flow (L/min) between OME vs. placebo (net difference: 29; 95 percent CI: 14, 44), P=0.002; Significant change in post-bronchodilator FEV1 with OME (11.1% increase) vs. placebo (3.78% increase), P=0.0013 | Significant decrease in albuterol use OME (23.2% decrease) vs. placebo (3.08% decrease), P=0.0001 | B
Dos Santos 2007^114^ [17724529] | Pantoprazole 40 mg/d vs. Placebo | 49/44 | 90 d | No significant difference in diurnal asthma symptom score between PAN (69.2 ± 29 to 58.9 ± 23) vs. placebo (68.8 ± 26 to 64.92 ± 4), P=0.11 No significant difference in nocturnal asthma symptom score between PAN (66.92 ± 7 to 57.9 ± 23) vs. placebo (66 ± 25 to 63.42 ± 6), P=0.16; | Significant improvement in total quality of life score between PAN (61.61 ± 5 to 48.7 ± 12) vs. placebo (63.8 ± 13 to 61.8 ± 13), P=0.001 | No significant net difference in morning peak expiratory flow (L/min) between PAN vs. placebo (net difference: 16; 95 percent CI: -45, 77), NS; No significant net difference in evening peak expiratory flow (L/min) between PAN vs. placebo (net difference: 8; 95 percent CI: -54, 70), NS | | B
Shimizu 2006^120^ [16778364] | Lansoprazole 30 mg/d vs. Roxatidine 150 mg/d | 30/30 | 2 mo | Significant difference in change from baseline in Asthma Control Questionnaire score in LAN (14.4 ± 4.2 to 9.4 ± 4.2), P<0.05 vs. no significant change in ROX (12.3 ± 2.1 to 9.0 ± 3.1), NS | | No significant net difference in morning peak expiratory flow (L/min) between LAN vs. ROX (net difference: 17; 95 percent CI: -21, 55), NS; | | B
Kiljander 2006^116^ [16357331] | Esomeprazole 40 mg/d vs. placebo | 770/624 | 16 wk | | | Significant higher net difference in morning peak expiratory flow (L/min) between EsOME vs. placebo (net difference: 8.7; 95 percent CI: 0.8, 17), P=0.03; Significant higher net difference in evening peak expiratory flow (L/min) between EsOME vs. placebo (net difference: 10.2; 95 percent CI: 2.3, 18), P=0.012 | | C no blinding, no details on method of randomization
Sontag 2003^121^ [12809818] | Nissen Fundoplication [surgical group] vs. Ranitidine 150 mg three times/d [medical group] vs Antacids as needed [control group]. Lifestyle modifications (Avoidance of tight garments, eating after supper, eating fatty foods, and reclining after meals with eating smaller, more frequent meals, elevating head of bed by 6 inches) was a co-intervention in all arms. | 75/62 | 2 y | Overall asthma symptom score (≥40% improvement from baseline) significantly better in the surgical (75 percent) vs. medical (0 percent) / control (20 percent) P<0.05 | | No statistically significant difference in peak expiratory flow rate between the 3 groups, although trend toward improvement in surgical group compared to combined medical and control groups | No significant difference in requirement for bronchodilators or corticosteroids | C No blinding, subjective nature of symptom assessment
Peterson 2009^118^ [18688720] | Rabeprazole 20 mg one – two times /d vs. placebo | 37/31 | 10 wk | Significant improvement in respiratory symptoms during exercise w/ patients taking RAB (70 percent) vs patients taking placebo (25 percent), P=0.03 | No significant change in SF-36 scores w/ RAB vs placebo (P= 0.97,) or mini-Asthma quality of life questionnaire score (P=0.21) | No significant difference in pulmonary function tests (FEV1, FVC, and FEV1/FVC) between the RAB vs placebo. | | C Small sample size, no detail of randomization
Jiang 2003^115^ [12717871] | Omeprazole 20 mg /d & Domperidone 10 mg three times/d + anti-asthmatics (Salbutamol 200 mg four times /d & budesonide 400 mg twice a day) vs. anti-asthmatics | 30/30 | 6 wk | | | Significant higher net difference in bronchial hyperreactivity (measured by PC-20 (g/L) OME & domperidone with asthma medication vs. only asthma medication (net difference: 0.54; 95 percent CI: 0.42,0.66), P<0.0001 | | C, No blinding, No details of method of randomization

One systematic review was included in this analysis. The systematic review evaluated the effect of PPI treatment on asthma with data from RCTs.12 The last search date for this review was September 21, 2002. Since recent RCTs have evaluated the impact of PPI on asthma in GERD patients, an update search was carried out to identify all RCTs of GERD therapy in patients with asthma. In the update search, the time period of search was limited from 2002 – 2009. A total of 277 abstracts were screened, and 8 RCTs qualified for inclusion. An update to our search found 1 study that fulfilled our inclusion criteria, bringing the total number of eligible studies to 9 RCTs.

In the systematic review by Gibson 2009,^12^ 12 RCTs were included in the review.(Table 29) Nine were crossover studies and 3 were parallel arm studies. One study compared the effect of H2RA versus placebo on asthma in children and adolescents in the age group of 10 to 20 years. The omeprazole was the only PPIs used in these studies, in varying doses - 20 mg, 40 mg, 80 mg and 160 mg doses. H2RAs including ranitidine and cimetidine, non-pharmacological conservative reflux therapy, and surgical therapy (posterior gastropexy) were other interventions that were used. 10 of the 12 studies compared either PPI or H2RAs to control therapy, while of the remaining two, one study compared non-pharmacological conservative reflux therapy to a control and another study compared a H2RA to a placebo or surgery. The sample size in the 12 trials ranged from 11 to 90, totaling 432 participants. The range of followup was 1 to 4.5 months. In the 11 trials conducted on adults, the mean age was 48 years (range 22-80 years). Outcome measures reported were lung function, symptoms and use of asthma medications.

Medical treatment did not consistently improve asthma symptoms, nocturnal asthma, use of asthma medications and objective lung functions. Nine out of 12 RCTs did not report a significant improvement in asthma symptoms. Three out of 6 trials that reported nocturnal asthma symptoms scores did not report significant improvement between the treatment arm and the placebo arm. Four out of 7 trials that reported beta-agonists use in puffs per day did not find statistically significant reduction in beta-agonist use. There was no significant improvement in FEV1 in groups using proton pump inhibitors, histamine antagonists, conservative therapy or surgical treatment. Using morning peak expiratory flow as an outcome, a meta-analysis of 3 studies (184 participants) showed no effect of PPI or H2RA over placebo (Mean difference: 5.28 L/min (95 percent CI: -35.43, 44.72)). Sub-group analysis of the same outcome in studies using PPI (3 studies, 88 participants) and H2RA (1 study, 96 participants) did not show significant differences between the drug and the placebo. With evening peak expiratory flow as an outcome, data from 3 studies (154 participants) showed no effect of PPI or H2RA over placebo (Mean difference: 7.03 L/min (95 percent CI: -25.88, 39.95)). Sub-group analysis of the same outcome in studies using PPI (2 studies, 58 participants) and H2RA (1 study, 96 participants) did not show significant differences between the drug and the placebo. Similar non-significant effects were seen with nocturnal symptoms score (Mean difference: -0.16 (95 percent CI: -0.42, 0.11)) and puffs of asthma medication per day (Mean difference: 0.52 puffs per day (95 percent CI: -1.7, 0.67)). Sub-group analysis of nocturnal symptoms score and puffs of asthma medication per day did not show significant differences between using PPI or H2RA as treatment versus the placebo.

In the update search, 9 RCTs were included for analysis.114-116,116-121 The characteristics and results from the 8 studies are outlined in Table 30. The studies enrolled a total of 1538 adult participants and followup data were available from 1192 participants. Five RCTs compared PPIs – lansoprazole 30 mg, omeprazole 20 mg, pantoprazole 40 mg, esomeprazole 40 mg, rabeprazole 20 mg - with placebo,114,116-119 one compared a PPI (lansoprazole 30 mg/d) with an H2RA (Roxatidine 150 mg/d,120 one compared a PPI (omeprazole 20 mg) and antiemetic agent (Domperidone 10 mg three times a day) taken alongside anti-asthma medication with only anti-asthma medication,115 and one study was a 3-arm comparison of surgery and with an H2RA (ranitidine 150 mg three time/d) and antacids.121 Of the 8 trials, the quality of 4 was graded as B and the 4 remaining trials were graded as C.

In the six RCTs comparing PPIs with placebo,114,116,116-119 the sample size of the trials ranged from 30 to 828. Of the 5 trials reporting the effect of PPIs therapy versus placebo on asthma symptoms, 3 trials114,117,122 did not find any significant improvement in asthma symptom score with PPI therapy, while three others118,119 found a significant improvement. In addition, 6 trials reported objective measures of pulmonary function, including FEV1 and, morning and evening peak expiratory flow. Two trials116,119 reported significantly higher net difference (i.e., difference in change from baseline between the intervention and control groups) with PPI therapy but 4 trials114,117,118,122 did not find any significant differences in pulmonary function tests between PPI and placebo therapy, though one trial did show a significantly higher net difference in FEV1(L/min) between esomeprazole 40 mg once daily versus placebo (net difference: +0.09 (95% CI: 0.03, 0.15, P<0.0001) and esomeprazole 40 mg twice daily versus placebo (net difference: 0.12 (95% CI: 0.06, 0.12, P<0.0042).122 Interestingly, one of the trials with rabeprazole 20 mg versus placebo, conducted in subjects with exercise triggered asthma, did not find a significant difference in pulmonary function tests while showing a significant improvement in asthma symptoms.118 Two trials reported on use of albuterol in addition to GERD therapy.117,119. One trial comparing lansoprazole 30 mg versus placebo over 24 weeks did not find any significant difference in albuterol use (measured in puffs per day)117 while another found a significant decrease in albuterol use with omeprazole (20 mg taken twice a day) and Domperidone (10 mg taken three times a day), as compared to a placebo.119 A third trial assessed the use of rescue medication in three groups (esomeprazole 40 mg once daily versus esomeprazole 40 mg twice daily versus a placebo) and found no significant differences in the use of rescue medication.122

In an RCT comparing lansoprazole 30 mg per day with Roxatidine 150 mg per day, there was a significant decrease in asthma symptoms in the people taking lanzoprazole 30 mg (P<0.05), while no significant difference in change in asthma scores from baseline was found in people taking roxatidine 150 mg.120 Change in results of the pulmonary function test in both the groups were not significantly different. This RCT was graded B.

Another RCT, comparing a combination of omeprazole (20 mg taken once daily), domperidone (10 mg taken thrice daily) and anti-asthmatic medication (salbutamol 200 mg four times a day and budesonide 400 mg twice a day) with only anti-asthmatic medication in 30 subjects over 6 weeks found significantly higher net difference in bronchial hyperreactivity (measured by PC-20 in g/L: the amount of methacholine that causes a 20% reduction in FEV1) in the group taking omeprazole and domperidone with asthma medication as compared to only asthma medication (net difference: 0.54; 95 percent CI: 0.42,0.66), P<0.0001.^115^

In a 3-arm RCT, graded C, comparing surgery with an H2RA and antacids, lifestyle modification (including avoidance of tight garments, no eating after supper, avoiding eating fatty foods, and not reclining after meals, coupled with eating smaller, more frequent meals and elevating head of bed by 6 inches) was used as a co-intervention in all arms. There was statistically significant difference in pulmonary function test results among the three groups.121 Overall clinical improvement was significantly better in surgical group (12/16; 75 percent) as compared with medical (2/22, 9 percent) and control groups (1/24, 4 percent), P<0.01. Overall asthma symptom score (≥40% improvement from baseline) was significantly better in the surgical (75 percent) versus medical (0 percent) /control (20 percent) groups, (P<0.05).

In summary, medical treatment does not show a consistent effect on asthma symptoms, nocturnal asthma, use of asthma medications, and objective lung function indicators, including Forced Expiratory Volume in 1 second (FEV1), morning peak expiratory flow and evening peak expiratory flow. Studies that used either omeprazole 20 mg in combination with domperidone 10 mg or esomeprazole 40 mg reported an improvement in morning and evening peak expiratory flow rate. Studies using lansoprazole 30 mg or pantoprazole 40 mg did not report an improvement in either asthma symptoms or lung function tests. While rabeprazole 20 mg taken two times a day improved respiratory symptoms during exercise in patients with exercise induced asthma, as compared to a placebo, it did not improve quality of life or pulmonary function tests results.

###### Hoarseness/Laryngitis

###### Synopsis

One systematic review was included in this analysis, evaluating the effect of RCTs of PPI treatment versus a placebo on hoarseness.111

Most of the RCTs (4/6, 67 percent) did not show a significant difference in resolution of hoarseness between the PPI and placebo arms.111 The remaining 2 RCTs found a significant higher percentage of patients who reporting resolution of hoarseness symptom with PPI treatment, as compared to a placebo. The RCTs that included participants complaining of hoarseness could not objectively demonstrate reflux from the same participants using pH studies.

###### Detailed Presentation

(Table 31)

Table 31 Treatment of GERD and its effect on extraesophageal symptoms: Hoarseness and laryngitis

Author Year [PMID] | Hopkins 2009 [16437513]111
Design | Randomized and quasi-randomized, controlled, double-blinded trials, controlled clinical trials (trials using a control group but no adequate randomisation procedure) and quasi-randomized trials of anti-reflux therapy for adult patients with hoarseness in the absence of other identifiable causes, irrespective of diagnosis of laryngopharyngeal reflux and GERD.
Population | All adult (aged 18 or over) patients with hoarseness (dysphonia), regardless of GERD diagnosis, and who have undergone laryngoscopy to exclude other identifiable causes of hoarseness including malignancy, vocal cord paralysis and vocal cord nodules.
Intervention (Exposure) and Comparator | Non-surgical:; a. Lifestyle modification and patient education; b. Drugs: Proton pump inhibitors (PPIs), Antacids, H2-receptor antagonists, Prokinetic agents, Erythromycin; Surgical:; a. Fundoplication repair - Nissen, Rossetti, Toupet partial fundoplication, Bore partial fundoplication, Collis gastroplasty followed by fundoplication; b. Non-fundoplication repairs: Hill repair (gastropexy), Belsey Mark IV
Results | 302 studies of hoarseness; 6 RCTs comparing gastric acid suppression with PPI vs placebo; no randomized trials of other methods of anti-reflux treatment. In all 6 RCT, 275 patients (sample size ranged from 15-145 participants) randomized to PPI or placebo. f/u ranged from 2 months - 3 months. Quality of outcome assessment (i.e. hoarseness) was not adequate as symptoms used for inclusion into the studies did not correlate with the results from the pH studies within these studies. The studies also used different and invalidated instruments to measure the outcome of interest, making inter-study comparisons invalid. 4 of 6 studies included in the review could not find a significant difference in resolution of symptoms/hoarseness between the PPI and placebo groups; Authors state that excluded studies indicate a placebo effect (data not shown).
Comments | The SR was limited by the quality of the studies available in the literature. The outcome of interest, hoarseness, could not be ascertained reliably in all the RCTs that were screened.
AMSTAR
A priori design? | Y | Study quality assessment performed? | Y
Two independent reviewers? | Y | Study quality appropriately used in analysis? | N/A
Comprehensive literature search? | Y | Appropriate statistical synthesis? | N/A
All publication types and languages included? | nd | Publication bias assessed? | nd
Included and excluded studies listed? | Y | Conflicts of interest stated? | Y
Study characteristics provided? | N

Author Year [PMID] | Iqbal 2008 [19105666]113
Design | A systematic review of retrospective and prospective studies, including RCTs, of surgical fundoplication in the treatment of the symptoms of extraesophageal reflux (EER).
Population | Adults
Intervention (Exposure) and Comparator | Surgery / fundoplication; no comparator
Results | Laryngeal symptoms: 8 published observational cohort studies (case series); 4/8 were prospective studies; f/u ranged from 6 - 65 months a. Interventions included: Nissen fundoplication, Toupet fundoplication, laparoscopic Nissen fundoplication, Collis Nissen fundoplication, Belsey Mark IV repair. Complete resolution of symptoms: 5/8 studies Complete/ partial relief of symptoms: 65–94% of participants. Good pre-operative response to antacid medication predicted good response to surgery (2 studies)
Comments | Included both prospective and retrospective studies; no quantitative analysis; quality of studies was not assessed
AMSTAR
A priori design? | N | Study quality assessment performed? | N
Two independent reviewers? | N | Study quality appropriately used in analysis? | n/a
Comprehensive literature search? | Y | Appropriate statistical synthesis? | n/a
All publication types and languages included? | Y | Publication bias assessed? | N
Included and excluded studies listed? | N | Conflicts of interest stated? | Y
Study characteristics provided? | Y

a One study had a f/u range of 6-108 months

One systematic review was included in this analysis, evaluating the effect of RCTs of PPI treatment versus a placebo on hoarseness.111

The search strategy for the systematic review of RCTs111 included all controlled trials of anti-reflux therapy for adult patients presenting with hoarseness, irrespective of the objective diagnosis of laryngopharyngeal reflux and GERD. The databases searched included Cochrane ENT Group Specialised Register, Cochrane Central Register of Controlled Trials (The Cochrane Library, Issue 3, 2005), Medline (1951 to 2005), EMBASE (1974 to 2005), CINAHL (1982 to 2005), Biological Abstracts and review articles. The search was last updated on 15 November 2005. The interventions included in the search were non-surgical (including lifestyle modification and patient education, and drugs like PPIs, H2RAs, prokinetic agents and erythromycin) and surgical (including fundoplication repair - Nissen, Rossetti, Toupet partial fundoplication, Bore partial fundoplication, Collis gastroplasty followed by fundoplication – and non-fundoplication repairs - Hill repair (gastropexy), Belsey Mark IV). Only data from medical treatment is included in this analysis.

The sample size in the 6 trials that were included ranged from 15 to 145, totaling 275 participants randomized to either a PPI or a placebo. The range of followup was 2 to 3 months. The PPIs were all administered in a twice a day dose frequency. The various doses used included lansoprazole 30mg, omeprazole 40 mg, esomeprazole 40 mg, pantoprazole 40 mg and rabeprazole 20 mg. Most of the RCTs (4/6, 67 percent) did not show a significant difference in the resolution of hoarseness between the PPI and placebo arms. There were many issues with the primary studies included in the review. Even though the presenting symptom in these studies was hoarseness, the pH studies conducted in 4 of 6 trials could not objectively demonstrate GERD in the patients within the studies. Therefore, whether the efficacy of GERD treatment could be adequately evaluated was debatable. In addition, the symptom questionnaire varied across the 6 studies, so an inter-study comparison of resolution of hoarseness was not possible. The authors concluded that the sample sizes of these studies were not large enough to have the power to detect significantly different effects between the PPIs and the placebo. In addition, they hypothesized that the treatment period of 2 to 3 months may not have been adequate to demonstrate the effect on laryngeal symptoms.

###### Chronic Cough

###### Synopsis

One systematic reviews of RCTs that evaluated the effect of PPI treatment on non-specific dry cough of ≥ 3 weeks duration was included in this analysis.110

Meta-analysis of 4 RCTs (191 participants) included in the systematic review did not find a significant difference between PPIs and placebo in total resolution of cough, reporting an odds ratio of 0.46 (95 percent CI: 0.19 to 1.15). Another meta-analysis of data from 6 RCTs (161 participants) reporting change in clough scores from the baseline in the same systematic review revealed a significant improvement in cough scores from baseline favoring PPIs as compared to placebo (-0.39 standardized mean difference units; 95 percent CI -0.71 to -0.08).

###### Detailed Presentation

(Table 32)

Table 32 Treatment of GERD and its effect on extraesophageal symptoms: Chronic cough

Author Year | Chang 2009 110
Design | RCTs on GERD treatment for chronic cough (non-specific dry cough ≥ 3 weeks duration unrelated to underlying respiratory disease (COPD, asthma or cystic fibrosis) or secondary to medication use).
Population | Adults and pediatric patients with chronic cough
Intervention (Exposure) and Comparator | Intervention; 1. Anti reflux conservative measures; 2. H2 receptor antagonists; 3. Proton pump inhibitors; 4. Surgical therapy; Control- placebo
Results | 18 articles, 13 on adults, 5 on pediatric population. 10 parallel studies, 3 crossover studies (with a washout periods of two weeks). Meta-analysis model and heterogeneity (if applicable); - PPI vs. placebo (Adults >18 years) for failure to cure based on clinical features (still coughing at end of trial or reporting period).; ◦ Random effects model, Pooled OR 0.46 (95 percent CI 0.19 to1.15) [Heterogeneity:- Tau^2-^=0.00, Chi^2^ = 1.14, df=3 (P=0.77); I^2^=0 percent]; - PPI vs. placebo (Adults >18 years) for mean cough scores at end of intervention.; ◦ Random effects model, Pooled OR -0.38 (95 percent CI -0.77 to 0.00) [Heterogeneity:- Chi^2^ = 1.98, df=3 (P=0.58); I^2^=0 percent]; - PPI vs. placebo (Adults >18 years), for change in cough scores (end-beginning of intervention); data from parallel group / crossover studies:; ◦ SMD effect estimate -0.39 (95 percent CI -0.71 to -0.08) [Heterogeneity:- Chi^2^ = 5.68, df=5 (P=0.34); I^2^=12 percent]; ◦ Only Crossover studies; standardized scale; fixed effects model. SMD effect estimate -0.41 (95 percent CI -0.75 to -0.07). [Heterogeneity:- Chi^2^ = 0.10, df=1 (P=0.76); I^2^=0 percent]; ◦ Crossover studies; Absolute scores; fixed effects model. SD effect estimate -0.29 (95 percent CI -0.62 to -0.04). [Heterogeneity:- Chi^2^ = 0.38, df=1 (P=0.54); I^2^= 0 percent]; Meta-analysis revealed no significant difference in cure of cough between PPIs and placebo. Meta-analysis revealed significant improvement on cough outcomes at end of trial and in change in cough scores (both in overall scores as well as in data from crossover trials).
Comments | 1. Small number of studies and select availability of unpublished articles therefore potential for publication bias.; 2. Lack of validated scales and objective data on cough.; 3. lack of allocation concealment data due to clinical heterogeneity of participants and medications; 4. Most studies did not use the GORD criteria specified by guidelines of American and European Gastroenterology Associations.
AMSTAR
A priori design? | Yes | Study quality assessment performed? | Yes
Two independent reviewers? | Yes | Study quality appropriately used in analysis? | Yes
Comprehensive literature search? | Yes | Appropriate statistical synthesis? | Yes
All publication types and languages included? | Yes | Publication bias assessed? | Yes
Included and excluded studies listed? | Yes | Conflicts of interest stated? | Yes
Study characteristics provided? | Yes

Author Year [PMID] | Iqbal 2008 [19105666]113
Design | Retrospective and prospective studies of surgical fundoplication in the treatment of the symptoms of extraesophageal reflux.
Population | Adults
Intervention (Exposure) and Comparator | Surgery / fundoplication
Results | 13 studies suggested that 60–100 percent of patients improve after surgery. Surgery in cough was still less successful than surgery for classical GERD.
Comments | Included both prospective and retrospective studies; no quantitative analysis; quality of studies was not assessed
AMSTAR
A priori design? | N | Study quality assessment performed? | N
Two independent reviewers? | N | Study quality appropriately used in analysis? | n/a
Comprehensive literature search? | Y | Appropriate statistical synthesis? | n/a
All publication types and languages included? | N | Publication bias assessed? | N
Included and excluded studies listed? | N | Conflicts of interest stated? | Y
Study characteristics provided? | Y

One systematic review of RCTs evaluating the effect of PPI treatment on non-specific dry cough of ≥ 3 weeks duration was included.110

The search strategy for the systematic review of RCTs110 included all RCTs of GERD treatment with cough as an outcome, where cough was unrelated to a respiratory disorder (e.g., cystic fibrosis, asthma, chronic obstructive airway disease, suppurative lung disease) or to medication use (e.g., ACE inhibitor). The following databases were searched: The Cochrane Controlled Trials Register (CENTRAL) including Airways Collaborative Review Group Specialised Trials Register, Medline (1951 to 2009) and EMBASE 1997 to 2009). The search was last updated in April 2009. The interventions included in the search were anti-reflux conservative measures, H2RA, PPI and surgical therapy. Only data from the medical treatment is presented. The primary outcome that was assessed was the failure to cure (defined as the proportions of participants who were not cured or not substantially improved at follow up). Other outcomes included cough scores and change in cough scores from baseline.

The review contained results from 18 studies. Five of the 18 studies were in a pediatric age group population and thus excluded from this analysis. Out of 13 studies, 10 were parallel arm studies and 3 were crossover studies. The PPIs used were of varying doses and frequencies and included omeprazole, esomeprazole, lansoprazole, pantoprazole and rabeprazole. H2RAs like ranitidine, cisapride, and lifestyle modifications were other interventions that were used. The sample size in the 13 trials that were assessed ranged from 17 to146, totaling 476 participants. The range of followup was 2 to 4 months. Outcome measures were subjective cough scales that had not been validated. Objective outcomes were not used in any of the trials.

Meta-analysis of 4 RCTs (191 participants) included in the systematic review did not find a significant difference between PPIs and placebo in total resolution of cough, reporting an odds ratio of 0.46 (95 percent CI: 0.19 to 1.15). Data from 4 studies (109 participants) reporting mean cough scores found a borderline significant difference in the mean cough scores at the end of the trial in comparisons of PPI versus placebo (Mean difference: -0.38 units (95 percent CI: -0.77 to 0.00, P=0.05)). Another meta-analysis of data from 6 RCTs (161 participants) reporting change in cough scores from the baseline in the same systematic review revealed a significant improvement in cough scores from baseline favoring PPIs as compared to placebo (-0.39 standardized mean difference units; 95 percent CI -0.71 to -0.08). There was evidence of heterogeneity (I^2^=12 percent) between studies in this analysis.

A subgroup analysis was done comparing the differential effect when omeprazole was the PPI used, and when other PPIs were used. A meta-analysis of data from 2 studies (51 participants) revealed a significant difference in the change in cough scores from baseline in comparisons of Omeprazole versus placebo: -0.71 SMD (95 percent CI -1.29 to -0.14). There was no significant difference when other PPIs (lansoprazole, pantoprazole and rabeprazole) were compared with placebo (-0.26 SMD (95 percent CI -0.64 to 0.11)). However, there was a considerable subjectivity in the assessment of outcomes across trials, which can lead to biased results when combining the results to get a summary effect.

##### Surgical Treatment for Extraesophageal Manifestations of GERD

###### Synopsis

Data from one systematic review was included in this report. The review evaluated the effect of anti-reflux surgical treatment on asthma, hoarseness/laryngitis and chronic cough with results from single-arm surgical cohort studies.113

Data from surgical studies showed an improvement in the percentage of participants with resolution of asthma in 7 studies. With followup ranging from 6 to 65 months, the range of participants reporting either a partial or complete resolution of symptoms after surgery was 0 to 64 percent. Improvement in the percentage of participants with resolution of laryngeal symptoms was seen in 8 studies. With followup ranging from 6 to 65 months, the range of participants reporting either a partial or complete resolution of symptoms after surgery was 65 to 94 percent.

In addition, improvement in the percentage of participants with chronic cough was seen in 13 studies. With followup ranging from 3.2 to 65 months, the range of participants reporting either a partial or complete resolution of symptoms after surgery was 60 to 100 percent.

###### Detailed Presentation

###### Asthma

(Table 29)

The search strategy for the systematic review of surgical case series included all retrospective and prospective studies, including RCTs, of surgical fundoplication in the treatment of the symptoms of extraesophageal reflux.113 The search period ranged from January 1991 to December 2006. Non-surgical interventions were excluded. 25 studies evaluating surgical fundoplication for treating extraesophageal symptoms were screened. Of the 25 studies, 24 of those were case series, of which 10 were prospective and 14 were retrospective. One study was a RCT comparing medical and surgical therapy in asthmatics, which has been discussed under the section on Asthma.121 Overall, 7 studies reported asthma outcomes for patients receiving fundoplication, 13 studies had data on chronic cough outcomes, and eight studies reported laryngeal symptoms.

Out of the 24 case series that assessed the role of surgical fundoplication in treating all symptoms of extraesophageal reflux, 7 studies had asthma as an outcome. One study was an RCT comparing Nissen fundoplication with medical therapy121 that was included in the update to the review by Gibson 2009.^12^ Of the remaining 6 studies, 4 of the 6 studies (67 percent) were prospective cohort studies. The sample size in the 7 included studies ranged from 13 to 135, totaling 350 participants, on whom any one of the following surgical procedures was done: Nissen fundoplication, Toupet fundoplication, laparoscopic Nissen fundoplication, Collis Nissen fundoplication, Belsey Mark IV repair. The range of followup was 6 to 65 months. The various scoring methods were used for symptom evaluation were Asthma symptom score, medication frequency score and Likert scale. Quality of life was assessed in some studies before and after surgery, using the SF-36 medical outcomes survey.

In 3 out of 7 studies, 0 to 64 percent of the participants reported a complete resolution of asthma symptoms. In 6 studies, 15 to 84 percent of the participants reported a partial resolution of asthma symptoms after surgery.

###### Hoarseness/Laryngitis

(Table 31)

Eight case-series studies had laryngeal manifestations as outcomes. Four of the 8 studies were prospective, and the rest were retrospective. The sample size in the 8 included studies ranged from 9 to 86, totaling 272 participants, on whom any one of the following surgical procedures was done: Nissen fundoplication, Toupet fundoplication, laparoscopic Nissen fundoplication, Collis Nissen fundoplication, Belsey Mark IV repair. The range of followup was 6 to 65 months. The various scoring methods were used for symptom evaluation were Reflux Symptom Index scale, Reflux Finding Scores, Likert scale, and the Medication Frequency Score. Quality of life was assessed in some studies before and after surgery, using the Gastrointestinal Quality of Life Index (GIQLI).

All the studies showed an improvement in laryngeal symptoms. In 5 out of 8 studies, 65 to 94 percent of the participants reported a complete resolution of symptoms after undergoing surgery. In 3 studies, 74 to 83 percent of the participants reported a partial resolution of symptoms after surgery.

###### Chronic Cough

(Table 32)

Thirteen studies with surgical case series presented chronic cough as an outcome. Five of the 13 studies (38 percent) were prospective, and the rest were retrospective. The sample size in the 13 included studies ranged from 11 – 354, totaling 1057 participants, on whom any one of the following surgical procedures was done: Nissen fundoplication, Toupet fundoplication, laparoscopic Nissen fundoplication, Collis Nissen fundoplication, Belsey Mark IV repair. The range of followup was 3.2 - 65 months. The various scoring methods were used for symptom evaluation were symptom scales and Likert scale. Quality of life was assessed in some studies before and after surgery, using the Gastrointestinal Quality of Life Index (GIQLI) and other quality of life questionnaires.

All the studies showed an improvement in chronic cough symptoms. In 11 out of 13 studies, 13 to 96 percent of the participants reported a complete resolution of chronic cough after undergoing surgery. In 9 studies, 60 to 100 percent of the participants reported a partial resolution of cough after surgery.

## Key Question 2 Is there evidence that effectiveness of medical, surgical, and newer forms of treatment varies for specific patient subgroups? What are the characteristics of patients who have undergone these therapies, including the nature of previous medical therapy, severity of symptoms, age, sex, weight, and other demographic and medical factors? What are the provider characteristics for procedures, including provider volume and setting (e.g., academic vs. community)?

### Synopsis

The 2005 CER identified a number of patient characteristics and baseline clinical factors that may influence the effectiveness of medical, surgical, or endoscopic treatment; however, the quality and consistency of these primary data were mixed and the strength of the identified associations remained unclear. Fifty additional studies were included in this update: 16 medical, 30 surgical, three endoscopic, and one medical versus surgical. For medical treatment, 17 percent (1/6) of RCTs and 40 percent (4/10) of cohort studies were rated C. For surgical treatment, the majority (77 percent) of studies were rated C. For endoscopic treatment, all three studies were rated C. The findings in this update are in general agreement with those from the 2005 report. In addition, the studies included in this update are similarly plagued with a number of methodological issues. The strength of evidence for factors that influenced the comparative effectiveness of surgical versus medical treatment was rated insufficient; for outcome of medical therapy was rated moderate; for outcome of surgical treatment was rated low; and for outcome of endoscopic treatment is also rated low.

Key findings:

- One study showed that there was no significant difference in the effectiveness of surgical versus medical treatment between patients with or without Barrett's esophagus. The strength of evidence was rated insufficient.
- Results from RCTs comparing different PPIs, or dosages and dosing regimens of PPIs showed mixed findings regarding the impacts of esophagitis severity at baseline on healing rates.
- Cohort studies found that sex was not significant modifying factors of medical treatment outcomes.
- Cohort studies consistently showed that obesity, presence of baseline typical GERD symptoms, and more severe esophagitis at baseline were significantly associated with worse medical treatment outcomes, but the associations between age and medical treatment outcomes were inconsistent.
- For surgical treatment, the following patient characteristics were inconsistently associated with worse surgical outcome: per year increase in patient's age, morbid obesity, female sex, presence of baseline symptoms, and esophagitis and hiatal hernia more than 3 centimeter at baseline.
- Preoperative esophageal motility did not significantly impact the effect of Nissen or Toupet laparoscopic fundoplication on dysphagia, recurrence of reflux, and 24-hour pH-metry and manometry outcomes 2 years after surgery.

### Detailed Analysis

No study examined the influences of provider characteristics on medical or surgical treatment outcomes, including provider volume and setting (e.g., academic versus community). For endoscopic treatment, one small study observed a learning curve in performance of a new endoscopic treatment device (EsophyX) comparing the technical procedure parameters in 17 patients.97

We first summarized the findings from a study that evaluated patient characteristics or clinical factors as modifying factors of comparative effectiveness of surgical versus medical treatment, followed by the findings from studies that evaluated patient characteristics or clinical factors as modifying factors of the outcomes of medical, surgical, or endoscopic treatment in this order.

#### Factors That Influenced the Comparative Effectiveness of Surgical Vs. Medical Treatment

One B-quality study, the Long-Term Usage of Acid Suppression Versus Antireflux Surgery (LOTUS) trial, was identified as comparing treatment outcomes in patients with versus those without Barrett's esophagus, randomized to laparoscopic antireflux surgery (LARS) or esomeprazole treatment.14 There were no major differences in demographics, disease specific characteristics, or allocation to treatment between patients with (n=60) and without (n=494) Barrett's esophagus. The study did not find significant differences in therapeutic outcomes (GI Symptom Rating Scale or quality of life) between the two groups after 3 years of followup.

#### Factors That Influenced the Outcome of Medical Therapy

Sixteen studies published after the 2005 CER evaluated whether baseline patient characteristics or clinical factors could differentially affect the outcomes of medical treatment (PPIs or H2RAs). Six were RCTs that also examined whether the treatment outcomes differ by patients' baseline esophagitis severity,33,44,49,55,56,61 and 10 were cohort studies that examined patients characteristics or clinical factors as modifying factors of medical treatment outcomes.29,34,64,123-129 Of the six RCTs, four compared effects of different PPIs,33,55,56,61 one compared different dosing regiments of PPI,49 and one compared different dosages of PPI.44 In this section, we first summarized findings from the RCTs, followed by the findings from cohort studies.

##### RCTs Comparing Different Proton Pump Inhibitors

(Table 33)

Table 33 Summary of studies that evaluated patient characteristics as modifying factors in randomized controlled trials comparing effects of different proton pump inhibitors

Author year [UI] Duration | Comparisons: Drug Name Dose (Frequency) | N analyzed | Potential modifying factor: outcome | P between treatments | Quality Comments
Outcome: healing rate of oesophagitis
Lightdale 2006^55^ [16773434] 8 weeks | Esomeprazole 20 mg (once daily) | 587 | LA grade A: 95% LA grade B: 85% LA grade C: 78% LA grade D: 73% | nd | A
Lightdale 2006^55^ [16773434] 8 weeks | Omeprazole 20 mg (once daily) | 588 | LA grade A: 88% LA grade B: 85% LA grade C: 73% LA grade D: 69% | nd | A
Schmitt 2006^130^ [16642422] 8 weeks | Esomeprazole 40 mg (once daily) | 576 | LA grade A: 88% LA grade B: 85% LA grade C: 91% LA grade D: 80% LA grade C/D: 88% | 0.032 (Breslow-Day test^a^) | A
Schmitt 2006^130^ [16642422] 8 weeks | Omeprazole 20 mg (once daily) | 572 | LA grade A: 91% LA grade B: 88% LA grade C: 82% LA grade D: 65% LA grade C/D: 78% | 0.032 (Breslow-Day test^a^) | A
Pilotto 2007^56^ [17724802] 2 months | Omeprazole 20 mg (once daily) | 74 | SM grade I: 82% SM grade II: 82% SM grade III-IV: 79% | SM grade I: 0.012 SM grade II: NS SM grade III-IV: NS | B Unclear outcome definition
Pilotto 2007^56^ [17724802] 2 months | Lansoprazole 30 mg (once daily) | 75 | SM grade I: 100% SM grade II: 97% SM grade III-IV: 71% | SM grade I: 0.012 SM grade II: NS SM grade III-IV: NS | B Unclear outcome definition
Pilotto 2007^56^ [17724802] 2 months | Pantoprazole 40 mg (once daily) | 77 | SM grade I: 100% SM grade II: 90% SM grade III-IV: 94% | SM grade I: 0.012 SM grade II: NS SM grade III-IV: NS | B Unclear outcome definition
Pilotto 2007^56^ [17724802] 2 months | Rabeprazole 20 mg (once daily) | 75 | SM grade I: 100% SM grade II: 96% SM grade III-IV: 84% | SM grade I: 0.012 SM grade II: NS SM grade III-IV: NS | B Unclear outcome definition
Vcev 2006^33^ [17058517] 4 weeks | Esomeprazole 40 mg (once daily) | 70 | LA grade A: 84% LA grade B: 78% LA grade C: 62% | LA grade A: NS LA grade B: <0.05 LA grade C: <0.01 | C Unclear outcome definition; only 75% patients in the analysis
Vcev 2006^33^ [17058517] 4 weeks | Pantoprazole 40 mg (once daily) | 65 | LA grade A: 83% LA grade B: 72% LA grade C: 50% | LA grade A: NS LA grade B: <0.05 LA grade C: <0.01 | C Unclear outcome definition; only 75% patients in the analysis
Outcome: endoscopic/symptom atic remission rate
Devault 2006^61^ [16682260] 6 months | Esomeprazole 20 mg (once daily) | 501 | LA grade A/B: 88% LA grade C/D: 79% | nd | B Large dropout
Devault 2006^61^ [16682260] 6 months | Lansoprazole 15 mg (once daily) | 500 | LA grade A/B: 81% LA grade C/D: 70% | nd | B Large dropout

SM=Savary-Miller classification (grade I: non-confluent erosions; grade II: confluent erosions; grade III: lesions extending to the entire circumference of the lower esophagus; and grade IV: deep ulcer or esophagitis with complications, i.e. stenosis and/or hemorrhagic lesions.)

a Breslow-Day test was performed to assess for heterogeneity in the treatment effect across baseline severity grades (<0.10 indicating significant heterogeneity)

Five RCTs (2 rated A, 2 rated B, and 1 rated C) compared effects of different PPIs and reported the treatment outcomes by baseline esophagitis severity.33,55,56,61,130 The PPI treatment comparisons were different across studies, and the treatment durations ranged from 1 to 6 months. Four of the five RCTs used the Los Angeles (LA) classification for the severity of esophagitis,33,55,61,130 while the remaining RCT used Savary-Miller classification.56

Overall, two of the five RCTs found that the healing rates were similar between PPI treatment groups regardless of the baseline esophagitis severity, and the other three RCTs found opposite findings with regards to the effects of different PPIs by baseline esophagitis severity. Specifically, one RCT found that the healing rate was only significantly different between PPI treatment groups in patients with grade I (less severe) esophagitis (Savary-Miller classification), another RCT found that healing rate was only significantly different between PPI treatment groups in patients with grade C (more severe) esophagitis, and the last one RCT found that healing rate generally decreased in both groups as the baseline erosive severity (LA classification) increased.

One A-quality RCT compared the effects of esomeprazole (20 mg/day) with that of omeprazole (20 mg/day) in a total of 1175 patients with erosive esophagitis and reported the cumulative healing rates by baseline severity grades.55 The cumulative healing rates were similar between esomeprazole and omeprazole groups in patients with LA grade A (95 vs. 88 percent, respectively), grade B (85 vs. 85 percent, respectively), grade C (79 vs. 73 percent, respectively), or grade D (73 vs. 69 percent, respectively). The authors also reported that “sex, age (<65 vs. ≥65 years), race, and H. pylori status had no meaningful effect on treatment outcome in either group”.

One A-quality RCT compared the effects of esomeprazole (40 mg/day) with that of omeprazole (20 mg/day) in a total of 1148 patients with erosive esophagitis and reported the cumulative healing rates by baseline severity grades. The study found that healing rate generally decreased in both groups as the baseline erosive severity (LA grades A to D) increased (P = 0.03 by Breslow-Day test for heterogeneity in treatment effect across the baseline erosive severity), although this decrease was less pronounced with esomeprazole.

One B-quality RCT compared effects of omeprazole (20 mg/day) with that of lansoprazole (15 mg/day) and reported the cumulative endoscopic or symptomatic remission rates by patients' baseline severity of esophagitis over 6 months of treatment.61 When patients were divided into two groups based on their baseline LA grades, the cumulative endoscopic or symptomatic remission rates were similar between omeprazole and lansoprazole groups in patients with LA grades A or B (88 vs. 81 percent, respectively) and in those with LA grade C or D (79 vs. 70 percent, respectively).

One B-quality RCT compared effects of four PPIs (omeprazole, lansoprazole, pantoprazole, rabeprazole) in elderly patients with esophagitis, and analyzed the healing rates by the baseline severity of esophagitis.56 The healing rate was significantly lower in patients with grade I (less severe) esophagitis treated with omeprazole (20 mg/day) than in patients treated with lansoprazole (30 mg/day), pantoprazole (40 mg/day), or rabeprazole (20 mg/day) (81.8 vs. 100, 100 and 100 percent, respectively, P = 0.012). In patients with grade II, III, or IV esophagitis, there was no significant differences in the healing rates between the four PPIs.

The C-quality RCT found that esomeprazole (40 mg/day) was more effective than pantoprazole (40 mg/day) in healing erosive esophagitis among patients with more severe (LA grade B or C) esophagitis at baseline.33 The healing rates of erosive esophagitis after 4 weeks treatment of esomeprazole and pantoprazole were 84 and 83 percent (P=NS) respectively among patients with LA grade A at baseline, 78 and 72 percent (P<0.05) respectively among patients with LA grade B at baseline, and were 62 and 50 percent (P<0.01) respectively among patients with LA grade C at baseline. However, these results were based on only 75 percent of treated patients.

##### RCTs Comparing Different Dosages and Dosing Regimens of Proton Pump Inhibitors

(Table 34)

Table 34 Summary of studies that evaluated patient characteristics as modifying factors in randomized controlled trials comparing different dosages and dosing regimens of commonly used proton pump inhibitors

Author year [UI] Duration | Comparisons: Drug Name Dose (Frequency) | N analyzed | Potential modifying factor: outcome | P between | Quality Comments
Outcome: endoscopic remission rate
Sjostedt 2005^49^ [16091055] 6 months | Esomeprazole 20 mg (once daily) | 241 | LA grade A: 7% LA grade B: 10% LA grade C: 10% LA grade D: 20% | LA grade A: 0.03 LA grade B: <0.001 LA grade C: 0.0002 LA grade D: 0.09 | B More patients receive on-demand treatment withdrew due to relapse
Sjostedt 2005^49^ [16091055] 6 months | Esomeprazole 20 mg (on-demand) | 229 | LA grade A: 22% LA grade B: 35% LA grade C: 49% LA grade D: 56% | LA grade A: 0.03 LA grade B: <0.001 LA grade C: 0.0002 LA grade D: 0.09 | B More patients receive on-demand treatment withdrew due to relapse
Outcome: esophagitis healing rate
Metz 2009^44^ [19210298] 6 months | Dexlansoprazole 30 mg (once daily) | 137 | LA grade A/B: 80% LA grade C/D: 63% | nd | B
Metz 2009^44^ [19210298] 6 months | Dexlansoprazole 60 mg (once daily) | 153 | LA grade A/B: 82% LA grade C/D: 85% | nd | B

SM=Savary-Miller classification (grade I: non-confluent erosions; grade II: confluent erosions; grade III: lesions extending to the entire circumference of the lower esophagus; and grade IV: deep ulcer or esophagitis with complications, i.e. stenosis and/or hemorrhagic lesions.)

We identified one RCT comparing different dosing regimen of PPI and one RCT comparing different dosages of PPI, and both RCTs reported the treatment outcomes by baseline esophagitis severity.44,49 Both RCTs used LA classification for the severity of esophagitis, and both were rated B quality.

One B-quality RCT compared effects of esomeprazole (20 mg/day) once daily with that of esomeprazole (20 mg/day) on-demand and examined the endoscopic remission rates by patients' baseline severity of esophagitis over the 6 months of treatment.49 The endoscopic remission rates were significantly higher in patients who received esomeprazole on-demand treatment than in those who received esomeprazole once daily regardless of the baseline severity (LA grades A to D). Overall, patients with more severe grades had more frequent endoscopic remission (P=0.0017). The endoscopic remission rates ranged from 7 to 20 percent in esomeprazole once daily group; and it ranged from 22 to 56 percent in esomeprazole on-demand group for patients with LA grades A to D.

One B-quality RCT compared the effects of two different dosages dexlansoprazole (30 or 60 mg/day) and reported the cumulative healing rates by patients' baseline severity of esophagitis over the 6 months of treatment.44 Only patients with healed erosive esophagitis from previous healing studies were enrolled in this RCT. The maintained healing rates at were similar in the dexlansoprazole 30- and 60-mg treatment groups among patients with baseline grade A or B (80 vs. 82 percent, respectively). However, for patients with LA grades C and D at baseline, the maintained healing rates were lower in patients who received lower dose of dexlansoprazole than in patients who received higher dose of dexlansoprazole (63 vs. 85 percent, respectively).

##### Cohort Studies of Medical Treatment

(Table 35)

Table 35 Summary of studies that evaluated patient characteristics as modifying factors of medical treatment outcome

Potential modifying factor | Number of Studies (quality) Total patients (range) | Outcomes
Potential modifying factor | Number of Studies (quality) Total patients (range)
Potential modifying factor | Number of Studies (quality) Total patients (range) | Medications
Potential modifying factor | Number of Studies (quality) Total patients (range) | Symptoms a | Off PPIs | Off all meds | Quality of life | Global Success/ Failure b
Older age (≥65 years old) | 5 (3 B;29,34,127 2 C123,126) 14,645 c (424 to 6215) | Labenz, 2009 [19222417]; Labenz, 2009 [19298581]: 1 yr increase in age adj. OR of heartburn resolution 1.01 (95%CI 1.007, 1.019); 1.02 (95%CI 1.01, 1.03) d | Nocon, 2007 [17311605]: 1 yr increase in age OR 0.97 (95%CI 0.96, 0.98) | | | Malfertheiner, 2005 [15888776]: No diff e DeVault, 2007 [17760655]: No diff
Male sex | 5 (3 B;29,34,127 2 C126,128) 14,400^f^ (179 to 6215) | Labenz, 2009 [19222417]; Labenz, 2009 [19298581]: adj. OR 1.35 (95%CI 1.14, 1.59); No diff g Calleja, 2005 [15810621]: No diff | Nocon, 2007 [17311605]: No diff | | | Malfertheiner, 2005 [15888776]: No diff
Increase BMI or weight | 6 (5 B; 29,34,125,127,129 1C126) 14,711^h^ (113 to 6215) | Sheu, 2007 [17850409]: BMI≥25 vs. <25 adj. OR of SSR 0.90 (95%CI 0.89, 0.95)^I^ Labenz, 2009 [19222417]; Labenz, 2009 [19298581]: No diff; BMI≥30 vs. <30 adj. OR of heartburn resolution 0.76 (95%CI 0.60, 0.93)^j^ | Nocon, 2007 [17311605]: 1 yr increase in BMI OR 0.96 (95% 0.94, 0.99) | | | Sheu, 2007 [17850409]: BMI≥25 vs. <25 adj. OR of ODT failure 2.9 (95%CI 2.3, 3.5) BMI≥25 vs. <25 adj. OR of complete healing 0.43 (95%CI 0.29, 0.53) Malfertheiner, 2005 [15888776]: No diff k
Hiatal hernia | 1 (1 B129) 113 | | | | | Sheu, 2008 [18702650]: No diff (multivariate analysis)
Baseline symptoms | 4 (3 B;29,34,125 1C126) 8383^l^ (377 to 4855) | Sheu, 2007 [17850409]: heartburn severity adj. OR of SSR 0.93 (95%CI 0.89, 0.99); No diff m Labenz, 2009 [19222417]; Labenz, 2009 [19298581]: regurgitation adj. OR of heartburn resolution 0.77 (95%CI 0.61, 0.98); heartburn severity adj. OR of heartburn resolution 0.72 (95%CI 0.57, 0.91)^n^ | Nocon, 2007 [17311605]: 1 unit increase in baseline symptom score OR 0.96 (95%CI 0.95, 0.97) | | | Sheu, 2007 [17850409]: No diff^o^
Esophagitis (any severity) | 6 (4 B;59,124,127,131 2 C64,126) 8538 (45 to 4855) | Xirouchakis, 2009 [18600453]: No diff^p^ | Xirouchakis, 2009 [18600453]: more rabeprazole use among Hill IV group than Hill II or Hill III groups (P=0.02; P=0.001, respectively) Nocon, 2007 [17311605]: mild vs. non-erosive OR 0.51 (95%CI 0.22, 0.61); severe vs. non-erosive OR 0.27 (95%CI 0.20, 0.38) | | | Hamamoto, 2005 [15683433]: LA grade B vs. A non-remission rate 30% vs. 63%, P=0.02; LA grade C/D vs. A non-remission rate 15% vs. 63%, P=0.002 Tepes, 2009 [19453031]: No diff Malfertheiner, 2005 [15888776]: LA grade C/D vs. A/B healing rate 76.9% vs. 90.3%, P<0.001^q^ Kovacs, 2009 [19267194]: healed vs. unhealed EE^r^ OR of recurrence 0.46, (95% CI 0.22, 0.97)

ODT=On-demand therapy; SSR=sustained symptomatic response defined as free from symptoms for the last 7 days

a Symptoms include dysphagia.

b Individual study's definition of success or failure defined by multiple variables.

c Two studies analyzed the same patients: one study analyzed 3151 patients during active treatment (4 weeks), while another stud analyzed 2766 patients during maintenance phase (6 months).

d Odds ratio (95%CI) in active treatment (4 weeks) / maintenance phase (6 months).

e Comparison: age ≥60 vs. <60.

f Two studies analyzed the same patients: one study analyzed 3151 patients during active treatment (4 weeks), while another stud analyzed 2766 patients during maintenance phase (6 months).

g Odds ratio (95%CI) in active treatment (4 weeks) / maintenance phase (6 months).

h Two studies analyzed the same patients: one study analyzed 3151 patients during active treatment (4 weeks), while another stud analyzed 2766 patients during maintenance phase (6 months).

i Rate of sustained symptomatic response: symptoms of both acid regurgitation and heartburn for the last 7 continuous days in any week and thereafter of the active-phase therapy.

j Odds ratio (95%CI) in active treatment (4 weeks) / maintenance phase (6 months).

k Comparison: BMI ≥30 vs. <30.

l Two studies analyzed the same patients: one study analyzed 3151 patients during active treatment (4 weeks), while another stud analyzed 2766 patients during maintenance phase (6 months).

m Comparison: acid regurgitation severity.

n Comparison: severe vs. moderate heartburn.

o Outcome: on-demand therapy failure until the fourth month.

p Comparison: Hill's grading II, III, or IV.

q Erosive reflux patients only.

r Healed erosive esophagitis (EE) was defined by a esophagitis grading scale of 0 to 1; unhealed EE was defined by a esophagitis grading scale of 2 to 4.

Ten cohort studies that examined patients characteristics or clinical factors as modifying factors of medical treatment outcomes.29,34,64,123-129 Medical treatment used in these studies include esomeprazole, pantoprazole, lansoprazole, rabeprazole, and nizatidine. As a particular study may have analyzed more than one factor, several studies appear multiple times in the present analyses. Of the 10 analyzed publications, five studies were on age,29,34,123,126,127 five on sex,29,34,126-128, six on BMI or obesity,29,34,125-127,129, one on severity of acid reflux,125, one on hiatal hernia,129, four on baseline symptoms,29,34,125,126, and six on esophagitis.59,64,124,126,127,131

Overall, cohort studies found that sex was not significant modifying factors of medical treatment outcomes. Moreover, the studies found that obesity, baseline typical GERD symptoms, and severe esophagitis were significantly associated with worse medical treatment outcomes, but the associations between age and medical treatment outcomes were inconsistent. Study results are summarized below.

###### Age

Five studies (with a total of 14,645 patients) examined the influence of age on medical treatment outcomes. 29,34,123,126,127 Three were rated B and two were rated C Sample sizes ranged from 424 to 6,215.

Two studies found that there was no significant difference in medical outcome between older (≥65 or ≥60 years of age) and younger patients.123,127 Three studies (two graded B and one C) found that a per-year increase in patient age was significantly associated with better medical outcomes. 29,34,126 Specifically, two B-quality studies examined factors associated with heartburn resolution in the Expo RCT (mean age 51 years old): one for the findings during the active phase of treatment (esomeprazole or pantoprazole 40 mg/day for 4 weeks),29 and one for the findings during the maintenance phase of treatment (esomeprazole or pantoprazole 20 mg/day for 6 months).34 Multivariate analyses showed that a per-year increase in patient age remained a significant predictor of odds of freedom from heartburn relapse during active phase of treatment (adjusted OR 1.01 [95 percent CI 1.01, 1.02]) and during maintenance phase of treatment (adjusted OR 1.02 [95 percent CI 1.01, 1.03]). One C-quality study analyzed data from a 10-year cohort study including 6215 patients (mean age 54 years old) and showed that a per-year increase in patient age was significantly associated with a reduced risk of continuous use of PPI (OR 0.97 [95 percent CI 0.96, 0.98]).

###### Sex

Five studies (with a total of 14,400 patients) examined the influence of sex on medical outcomes.29,34,126-128 Three studies were quality B and two were quality C. Sample sizes ranged from 179 to 6,215. All five studies did not find a significant association between sex and medical outcomes.

###### Increase BMI or Overweight

Six studies (with a total of 14,711 patients) examined the influence of body mass index (BMI, kg/m^2^) or obesity status on medical outcomes.29,34,125-127,129 Five studies were quality B and four were quality C. Sample sizes ranged from 113 to 6,215.

Only one study did not find significant association between obesity (BMI ≥30) and medical outcomes,127 the other five studies consistently showed that overweight or obesity was significantly associated with worse medical outcomes, such as symptom relapse, continual use of PPIs, or treatment failure.29,34,125,126,129

###### Hiatal Hernia

One B-quality study (113 patients) 129 did not find significant association between presence of hiatal hernia at baseline and medical outcomes.

###### Baseline Symptoms

Four studies (a total of 8,383 patients) examined the influence of baseline symptoms on medical outcomes. 29,34,125,126 Three studies was rated quality B and one was rated quality C. Sample sizes ranged from 377 to 4,855.

All four studies consistently showed that more severe baseline symptoms (e.g., heartburn, regurgitation, or symptom score) was significantly associated with worse medical outcomes, such as symptom relapse and continual use of PPIs. 29,34,125,126 One of the four studies, however, reported that baseline heartburn severity was not significantly associated with the failure of on-demand treatment although it was significantly associated with an increased risk of symptom relapse during the active treatment period (adjusted OR 1.08 [95 percent CI 1.01, 1.12]).125

###### Esophagitis

Six studies (a total of 8538 patients) examined the influence of baseline status of esophagitis on medical outcomes. 59,64,124,126,127,131 Four studies were rated quality B and two were rated quality C. Sample sizes ranged from 45 to 4,855.

One study did not find a significant association between baseline esophagitis and medical outcomes. 59 Five studies consistently showed that more severe esophagitis (based on Hill criteria, LA grades or other esophagitis severity scales) was significantly associated with worse medical outcomes, such as continual use of PPIs, or treatment failure.64,124,126,127,131 One of the five studies, however, reported that more severe esophagitis (based on Hill criteria) was not significantly associated with total symptom score although it was significantly associated with more PPI use.124

#### Factors That Influenced the Outcome of Fundoplication

(Table 36)

Table 36 Summary of studies that evaluated patient characteristics as modifying factors of fundoplication outcome

Potential modifying factor | Number of Studies (Quality) Total patients (range) | Outcomes
Potential modifying factor | Number of Studies (Quality) Total patients (range)
Potential modifying factor | Number of Studies (Quality) Total patients (range) | Medications
Potential modifying factor | Number of Studies (Quality) Total patients (range) | Symptoms a | pH | Off PPIs | Off all meds | Quality of life | Global Success/ Failure b
Older age (≥65 years old) | 9 (3 B;71,84,146 6 C74,83,134,137,151,153) 3750 (82 to 1340) | Brehant, 2006 [16504893]: No diff Cowgill, 2006 [16986386]: No diff c Tedesce, 2006 [16549695]: No diff Hafez, 2008 [18449599]: No diff d Wang, 2008 [18368318]: No diff Pizza, 2007 [17278197]:^e^ No diff | Pizza, 2007 [17278197]:^f^ No diff^g^ | | Wijnhoven, 2008 [18071830]: 1 y increased in age OR: 0.97 (95%CI 0.95, 0.98) | Brehant, 2006 [16504893]: No diff Wang, 2008 [18368318]: No diff Teixeira, 2009 [19453033]: No diff^h^ | Brehant, 2006 [16504893]: No diff Oelschlager, 2008 [17970835]: 1 y increased in age adj. OR of operation failure 1.03 (95%CI, 1.01, 1.58)^i^
Male sex | 6 (1 B;71 5 C74,83,84,139,145) 1701 (102 to 844) | Hafez, 2008 [18449599]: No diff | | | Wijnhoven, 2008 [18071830]: No diff | Teixeira, 2009 [19453033]: No diff Gee, 2008 [18490558]: No diff | Manning, 2006 [16872031]: Male:female ratio sig. lower in poor outcome group^j^ (0.8 vs. 2.6, P=0.001) Oelschlager, 2008 [17970835]: adj. OR of operation failure OR 0.52 (95%CI: 0.29, 0.94)
Increase BMI or weight | 6 (2 B;136,138 4 C132,139,140,145) 1261 (91 to 481) | D'Alessio, 2005 [16137590]: No diff^k^ Anvari, 2006 [16341568]: BMI≥35 vs. <30 net ∆ in reflux symptom score: +5.64 (95%CI 1.04, 10.24)^l^ Chisholm, 2009 [19259752]: No diff | Anvari, 2006 [16341568]: No diff^m^ | | | Gee, 2008 [18490558]: sig. worse HRQL (P<0.05)^n^ | Iqbal, 2006 [16368486]: No diff Manning, 2006 [16872031]: No diff
Psychological | 2 (2 C141,156) 82 (32; 50) | Kalinowska, 2006 [17427490]: No diff Yano, 2009 [19207552]: No diff | | Yano, 2009 [19207552]: No diff | | Kalinowska, 2006 [17427490]: No diff Yano, 2009 [19207552]: No diff
Baseline symptoms | 4 (1 B;84 3 C74,82,143) 1678 (31 to 844) | Biertho, 2006 [16823657]: No diff Lee, 2009 [19259354]: No diff | | | Wijnhoven, 2008 [18071830]: heartburn OR: 0.15 (95%CI 0.10, 0.22); regurgitation OR: 0.60 (95%CI 0.42, 0.87) | | Oelschlager, 2008 [17970835]: adj. OR of operation failure 2.17 (95%CI: 1.18, 3.98)^o^
Preoperative good response to acid-suppression therapy | 2 (1 B;155 1 C140) 415 (91; 324) | Wilkerson, 2005 [16025197]: No diff | | | | | Iqbal, 2006 [16368486]: No diff^p^ Wilkerson, 2005 [16025197]: good vs. poor responders +4% good surgery outcome (Visick I or II), P=0.08
Esophagitis | 8 (1 B85; 7 C83,140,142-145,152) 995 (31 to 178) | Broeders, 2010 [20473997]: No diff, non-erosive vs. erosive Thibault, 2006 [16907894]: Non-erosive vs. erosive 50% vs. 29% daily symptoms, P=0.03 Lord, 2009 [19050984]: No diff^q^ Lee, 2009 [19259354]: No diff | Broeders, 2010 [20473997]: No diff, non-erosive vs. erosive | Broeders, 2010 [20473997]: No diff, non-erosive vs. erosive | Thibault, 2006 [16907894]: Non-erosive vs. erosive 39% vs. 25%, P=0.08 | Broeders, 2010 [20473997]: No diff, non-erosive vs. erosive Kamolz, 2005 [15959712]: Esophagitis positive vs. negative net ∆ GI QoL: -12.4 (nd), P<0.05 Thibault, 2006 [16907894]: No diff Teixeira, 2009 [19453033]: No diff | Iqbal, 2006 [16368486]: No diff Manning, 2006 [16872031]: grade III/ IV vs. I/II No diff
Severity of acid reflux | 1 (1 B71) 133 | Hafez, 2008 [18449599]: DeMeester score ≥50 sig. predicting time until recurrence of reflux symptom (P=0.04^s^)
Preoperative LES incompetence or low LES | 1 (1 C149) 351 | Riedl, 2009 [19370381]: No diff | Riedl, 2009 [19370381]: No diff | | | Riedl, 2009 [19370381]: No diff
Esophageal dysmotility | 4 (1 A,150 2 B,133,147 1 C148) 819 (98 to 400) | Strate, 2008 [18027055]: No diff Ravi, 2005 [16105534]: No diff Pizza, 2008 [18197944]:^t^ No diff Booth, 2008 [18076018]: No diff | Strate, 2008 [18027055]: No diff^u^ Ravi, 2005 [16105534]: No diff Pizza, 2008 [18197944]:^v^ No diff^w^ | | | Ravi, 2005 [16105534]: No diff
Hiatal hernia | 4 (4 C83,140,143,145) 367 (31 to 143) | Lee, 2009 [19259354]: No diff | | | | Teixeira, 2009 [19453033]: No diff | Iqbal, 2006 [16368486]: hernia size >3 cm adj. OR of failure: 3.17 (95%CI 1.04, 9.69); P=0.04 Manning, 2006 [16872031]: No diff
Reflux patterns (upright, bipositional, or supine) | 2 (2 C135,154) 382 (148; 234) | Wayman, 2007 [17377929]: No diff Broeders, 2009 [19491839]: No diff | Broeders, 2009 [19491839]: No diff | Broeders, 2009 [19491839]: No diff | | Broeders, 2009 [19491839]: No diff

HRQoL=health-related quality of life

a Symptoms include dysphagia.

b Individual study's definition of success or failure defined by multiple variables.

c Comparison: ≥70 vs. <60 years old

d Comparison: >54 vs. ≤54 years old

e Pizza, 2007 and Pizza, 2008 are the same study but examining different predictor

f Pizza, 2007 and Pizza, 2008 are the same study but examining different predictor

g Based on 50% patients at 1-year follow-up

h Comparison: >45 vs. ≤45 years old

I Operation success was defined as complete resolution, meaning a complete absence of the presenting symptom at the time of the study.

j Poor outcome group included all patients whose outcomes were the same or worse than pre-op and those who were not happy with the results of the operation.

k Comparison: BMI < 25, 25-30, vs. > 30 kg/m2.

l Higher symptom score indicates worse outcome

m Comparison: BMI≥35 vs. <30 kg/m2

n Comparison: BMI≥35 vs. 25-29.9, or 30-34.9 kg/m2

o Comparison: baseline dysphasia vs. no dysphasia symptom

p Odds ratio of treatment failure: 0.69 (95%CI 0.48, 1.0); P=0.05 but good response to PPI was not a significant predictor for treatment failure in multivariate model

q Comparison: mild vs. non-erosive vs. severe esophagitis

r Comparison: non-erosive vs. erosive esophagitis

s Multivariate Cox regression after adjusting for operation method (Nissen vs. Toupet) and other risk factors

t Pizza, 2007 and Pizza, 2008 are the same study but examining different predictor

u 24-pH monitoring data only available for 144 (out of 200) patients

v Pizza, 2007 and Pizza, 2008 are the same study but examining different predictor

w Based on 68% patients at 1-year follow-

Thirty studies published after the 2005 CER evaluated whether preoperative patient characteristics or baseline clinical factors could differentially affect the outcomes of fundoplication. 71,74,82-84,132-156 Surgical outcomes of interest included typical GERD symptoms (e.g., dysphagia, heartburn, and regurgitation), pH status, whether the patients were off PPIs or all medications, quality of life, and global success or failure (definitions of success or failure varied across studies). As a particular study may have analyzed more than one factor, several studies appear multiple times in the present analyses. Of the 30 analyzed publications, nine studies were on age, 71,74,83,84,134,137,146,151,153 six on sex, 71,74,83,84,139,145 six on BMI or obesity, 132,136,138-140,145 two on psychological profile, 141,156 four on baseline symptoms, 74,82,84,143 two on preoperative response to acid-suppression therapy, 140,155 seven on esophagitis, 83,140,142-145,152 one on esophageal pH, 71 one on LES competence, 149 four on esophageal motility, 133,147,148,150 four on hiatal hernia, 83,140,143,145 and two on reflux patterns. 135,154

Overall, firm conclusions are difficult to make concerning patient characteristics or baseline clinical factors as modifiers of fundoplication outcomes as many of the included studies were retrospective analyses relying on pre-existing patient records and/or self-reported outcomes with missing data, a lack of adjustment for potential confounding in the statistical analyses, or selection bias. Study results are summarized below.

##### Age

Nine studies (with a total of 3,750 patients) examined the influence of age on surgical outcomes. 71,74,83,84,134,137,146,151,153 Of these, three were rated B and six were rated C. Sample sizes ranged from 82 to 1,340.

Seven studies found that a patient's age was not significantly associated with surgical outcomes, or that there was no significant difference in surgical outcomes between older (≥65 years of age was the most commonly used cutoff) and younger patients. 71,83,134,137,146,151,153 Two studies (one graded B and one C) found that a per-year increase in patient's age was significantly associated with worse surgical outcomes. 74,84 Specifically, the B-quality study (mean age: 47 years) conducted a multivariate analysis and showed that a per-year increase in patient's age remained a significant predictor for operation failure (success was defined as complete absence of the presenting symptom at the time of postoperative evaluation) after controlling for type of surgery (Nissen vs. Toupet) and other risk factors (adjusted OR 1.03 [95 percent CI, 1.01, 1.58]).84 The C-quality study (mean age: 58 years) found that a per-year increase in patient age was a significant predictor for anti-reflux medication use after surgery (OR 1.04 [95 percent CI 1.02, 1.05]).74

##### Sex

Six studies (with a total of 1,701 patients) examined the influence of sex on surgical outcomes.71,74,83,84,139,145 One study was quality B and five were quality C. Sample sizes ranged from 102 to 844.

Four studies did not find a significant association between sex and surgical outcomes.71,74,83,139 Two studies (one B, one C) found that male sex was significantly associated with better surgical outcomes.84,145 Specifically, the B-quality study conducted a multivariate analysis and showed that being male was significantly associated with a reduced risk of operation failure (success was defined as complete absence of the presenting symptom at the time of postoperative evaluation) after controlling for the type of surgery (Nissen vs. Toupet) other risk factors (adjusted OR 0.52 [95 percent CI, 0.29, 0.94]).84 The C-quality study found that the male-to-female ratio was significantly lower in the poor outcome group (including patients whose outcomes were the same or worse than pre-op and those who were not happy with the results of the operation) than in the good outcome group (0.8 vs. 2.6, P=0.001).145

##### Increase BMI or Overweight

Six studies (with a total of 1,261 patients) examined the influence of body mass index (BMI, kg/m^2^) or obesity status on surgical outcomes.132,136,138-140,145 Two studies were quality B and four were quality C. Sample sizes ranged from 91 to 481.

Four studies did not find a significant association between BMI or obesity status and surgical outcomes.136,138,140,145 Two studies (both C-quality) found that higher BMI or obesity was significantly associated with worse surgical outcomes.132,139 Specifically, one study compared the surgical outcomes in patients with a BMI of 35 or more (mean BMI 38.4) with patients who had a BMI less than 30 (mean BMI 24.2).132 This study found that morbidly obese patients reported significantly higher reflux symptom scores (indicates a worse outcome) 6 months postoperatively compared with patients who were of normal weight (P<0.0001); however, the difference in reflux symptom score was not associated with a significant difference in acid reflux as measured by 24-hour pH study. The other study also found that morbidly obese patients reported a significantly higher GERD-HRQL scores (indicating a worse outcome) than patients in the lower BMI groups (BMI 25-29.9, or 30-34.9).139

##### Psychological Profile

Two C-quality studies (with a total of 82 patients) examined the influence of psychological profile on surgical outcomes.141,156 One found that postoperative GERD symptoms and quality of life were not significantly different between patients with (n=28) and without (n=22) conversion disorder as diagnosed by the Minnesota Multiphasic Personality Inventory.141 The other reported similar findings having compared patients with (n=7) and without (n=25) depression documented by preoperative history and treatment with one or more antidepressants.156 Additionally, this study also did not find a significant difference in postoperative PPI use between patients with and without depression.

##### Baseline Symptoms

Four studies (with a total of 1,679 patients) examined the influence of baseline symptoms on surgical outcomes.74,82,84,143 One study was quality B and three were quality C. Sample sizes ranged from 31 to 844.

Two C-quality studies did not find significant associations between preoperative non-specific gastrointestinal symptoms or typical GERD symptoms and postoperative symptom outcomes.82,143 The other two studies (one B, one C) reported that preoperative typical GERD symptoms were significantly associated with poorer surgical outcomes. Specially, the B-quality study conducted a multivariate analysis and showed that preoperative dysphagia remained a significant predictor of operation failure (success was defined as complete absence of the presenting symptom at the time of postoperative evaluation) after controlling for type of surgery (Nissen vs. Toupet) and other risk factors (adjusted OR 2.17 [95 percent CI, 1.18, 3.98]).84 The C-quality study found that preoperative heartburn and regurgitation were significantly associated with anti-reflux medication use after surgery (OR 6.5 [95 percent CI 4.5, 9.5] and OR 1.7 [95 percent CI 1.2, 2.4], respectively).74

##### Preoperative Response to Acid-Suppression Therapy

Two studies (with a total of 415 patients) examined the influence of preoperative response to acid suppression treatment on surgical outcomes.140,155 One, a B-quality prospective study, found that a borderline significantly higher proportion of good responders to preoperative PPIs reported an excellent or good outcome with surgery (Visick I or II) compared to poor responders (218/233 [94 percent] vs. 79/91 [87 percent]; P=0.08).155 The other, a C-quality retrospective case-control study, found that preoperative good response to PPIs was associated with a reduced risk of treatment failure (OR 0.69 [95 percent CI, 0.48, 1.0]) in a univariate, but not in a multivariate analysis.140

##### Esophagitis

Eight studies (with a total of 995 patients) examined the influence of baseline status of esophagitis on surgical outcomes.83,85,140,142-145,152 One study was quality B and the other seven studies were quality C. Sample sizes ranged from 31 to 178.

Findings were mixed among the evaluated studies. Three reported no significant differences in surgical outcomes between patients with and without esophagitis at baseline,83,140,143 and two did not find a significant difference in surgical outcomes comparing patients with mild esophagitis at baseline to those with non-erosive or severe esophagitis at baseline.144,145 One study find that, at 5 years, relief of reflux symptoms was similar, PPI use showed a similar reduction and quality of life score improved equally between patients with non-erosive esophagitis at baseline to those with erosive esophagitis at baseline. Another study did not find a significant difference in quality of life outcomes comparing patients with non-erosive esophagitis at baseline to those with erosive esophagitis at baseline. However, this study found a borderline significant effect in the rate of postoperative anti-reflux medication use (39 percent vs. 25 percent, respectively; P=0.08) and a significantly higher rate of postoperative symptoms (50 percent vs. 29 percent, respectively; P=0.03) between these two groups (non-erosive vs. erosive).152 The eight study found that patients with esophagitis reported a significantly lower gastrointestinal quality of life than patients without esophagitis at baseline (P<0.05).142

##### Esophageal pH

One B-quality study conducted a multivariate analysis to examine the potential risk factors for recurrence of reflux symptoms among 133 patients who underwent partial or total fundoplication.71 The study found that a DeMeester score greater or equal to 50 was the only significant predictor for recurrence of reflux symptoms in the multivariate model, which considered operation method (Nissen vs. Toupet) and other risk factors (P=0.04).

##### LES Competence/Pressure

One C-quality retrospective study aimed to examine the associations between preoperative LES manometry data and 1-year postsurgical outcomes among 351 patients.149 Patients were grouped based on the main variables (i.e., intraabdominal length and lower esophageal sphincter pressure) representing LES competence in esophageal manometry. The results demonstrated that the preoperative manometric character of the LES was not significantly associated with either subjective or objective outcomes after laparoscopic antireflux surgery.

##### Esophageal Motility

Four studies (with a total of 819 patients) examined the influence of esophageal dysmotility on surgical outcomes.133,147,148,150 One study was quality A, two quality B, and one quality C. Sample sizes ranged from 98 to 400.

The A-quality RCT randomized 200 patients (100 with normal and 100 with abnormal esophageal motility) to either Nissen or Toupet laparoscopic fundoplication.150 Two-year outcomes were assessed. The results indicated that preoperative esophageal motility did not significantly impact the effect of Nissen or Toupet laparoscopic fundoplication on dysphagia, recurrence of reflux and 24-hour pH-metry and manometry outcomes. The other three studies (2 B- and 1 C-quality) also did not find a significant association between esophageal motility and surgical outcomes.133,147,148

##### Hiatal Hernia

Four studies (with a total of 367 patients) examined the influence of hiatal hernia on surgical outcomes.83,140,143,145 All four studies were rated C. Sample sizes ranged from 31 to 143.

Three studies did not find a significant relationship between the presence of hiatal hernia and surgical outcomes.83,143,145 The remaining study indicated that a hernia size greater than 3 cm was significantly associated with an increased risk of surgical failure in the multivariate analysis (adjusted OR 3.17 [95 percent CI, 1.04, 9.69]).140

##### Reflux Patterns (Upright, Bipositional, or Supine)

Two C-quality studies (with a total of 382 patients) examined the influence of reflux patterns on surgical outcomes.135,154 Both found that reflux patterns were not significantly associated with surgical outcomes, including quality of life, reduction of symptoms, use of PPIs, or total acid exposure.

#### Factors That Influenced the Outcome of Endoscopic Treatment

Three C-quality studies examined the potential modifying factors of endoscopic treatment.92,97,100 One prospective study, did not find a significant difference between men and women (80 vs. 79 percent) in GERD symptom improvement or resolution after endoluminal gastroplication (EndoCinch™).92 Another study investigated the proportion of patients for complete cessation of PPI use at 6 months after transoral incisionless fundoplication with the EsophyX™ device.100 They found that more patients with less severe esophagitis at baseline (base on Hill's grades) stopped PPI use than patients with more severe esophagitis (72 vs. 0 percent, respectively; P=0.02). The third study reported a learning curve in endoscopic transoral fundoplication device performance (EsophyX™) comparing the technical procedure parameters (e.g., procedure time and number of devices used) and found improvements in the last 10 treated patients compared with the first seven treated patients.97

## Key Question 3 What are the short-term and long-term adverse events associated with specific medical, surgical, and newer forms of therapies for GERD? Does the incidence of adverse events vary with duration of followup, specific surgical intervention, or patient characteristics?

### Synopsis

One RCT reported that the rate of serious adverse events was higher in patients who underwent fundoplication compared with those who had medical treatment but this was not statistically significant (P=0.06). Most common adverse events reported with PPIs included diarrhea, nausea or vomiting, abdominal pain, dyspepsia, or headache. These occurred in fewer than 2 percent of patients. Serious complications possibly associated with PPI use previously reported in our 2005 CER included enteric infections (Camyplobacter and Clostridium difficile) and pneumonia. An increased risk of bone fracture is now added to this list, although the strength of association is uncertain. Common adverse events reported in patients who underwent fundoplication included bloating (up to 85 percent) and dysphagia (up to 23 percent). Reoperation rates ranged from 3 to 35 percent. Common adverse events after endoscopic suturing included chest or abdominal pain (up to 24 percent), bleeding (up to 11 percent), dysphagia (up to 50 percent), and bloating (up to 19 percent). None of these quantitative estimates are reliable because of a lack of standard definition and uniform system of reporting. The strength of evidence was rated low.

### Detailed Analysis

#### Adverse Events Comparing Different Treatments

(Table 37)

Table 37 Adverse events in RCTs comparing medical to surgical treatments

Author year [UI] Trail Name Follow-up duration | Treatment | Death | Other reported adverse events | P value between groups
Lundell 2008^16^ [18469091] LOTUS 3 years | Esomeprazole 20 mg/d | 1/266 (0.4%) a | Any serious adverse events: 42/266 (14.3%); - Myocardial infarction: 1/266 (0.4%); - Injury, poisoning, procedural: 2/266 (0.8%); - GI disorders: 5/266 (1.9%); - Musculoskeletal/connective tissue: 8/266 (3.0%); - Infections and infestations: 6/266 (2.3%); - General disorders: 4/266 (1.5%); - Cardiac disorders: 3/266 (1.1%); - Neoplasms, benign/malignant: 6/266 (2.3%); - Reproductive system including breast: 4/266 (1.5%); - Respiratory, thoracic, mediastinal: 1/266 (0.4%); - Vascular disorders: 3/266 (1.1%); - Hepatobiliary disorders: 0/266 (0%) | nd^b^
Lundell 2008^16^ [18469091] LOTUS 3 years | Laparoscopic antireflux surgery | 0/288 | Any serious adverse events: 55/248 (21%); - Myocardial infarction: 1/248 (0.4%); - Injury, poisoning, procedural: 15/248 (6.0%); - GI disorders: 12/248 (4.8%); - Musculoskeletal/connective tissue: 2/248 (0.8%); - Infections and infestations: 3/248 (1.2%); - General disorders: 5/248 (2.0%); - Cardiac disorders: 4/248 (1.6%); - Neoplasms, benign/malignant: 2/248 (0.8%); - Reproductive system including breast: 1/248 (0.4%); - Respiratory, thoracic, mediastinal: 5/248 (2.0%); - Vascular disorders: 3/248 (1.2%); - Hepatobiliary disorders: 3/248 (1.2%)
Lundell 2006^157^ [16480403]; Lundell 2007^15^ [17256807]; Lundell 2009^c,17^ [19490952] SOPRAN 12 years | Omeprazole 20-40 mg/d | 0% 7 year 8/154^d^ (5.2%) 12 year | 7 year follow up; - Gastritis: 17/96 (17.7%); - Atrophic gastritis: 5/96 (5.2%); - Argyrophil cell hyperplasia: 14/96 (14.6%); 12 year follow up; - Esophageal cancer: 0/78 (0%); - Non-fatal heart attacks: 9/78 (11.5%) | nd^e^
Lundell 2006^157^ [16480403]; Lundell 2007^15^ [17256807]; Lundell 2009^c,17^ [19490952] SOPRAN 12 years | Open antireflux surgery: Nissen (primarily) | 1/144 (0.7%)^f^ 7 year 2/144^g^ (1.4%) 12 year | 7 year follow up; - Gastritis: 16/72 (22.2%); - Atrophic gastritis: 3/72 (4.2%); - Argyrophil cell hyperplasia: 4/72 (5.6%); 12 year follow up; - Esophageal cancer: 1/59^h^ (1.7%); - Non-fatal myocardial infarction: 2/59 (3.4%) | nd^e^

n/a=not applicable; GI=gastrointestinal

a One patient died from pneumonia

b Estimated by chi-square testing: Significantly more patients withdrew from the study due to adverse events in esomeprazole than in surgery group (P=0.03). Marginal significant for any serious adverse events (P=0.06) between esomeprazole and surgery groups.

c The FDA concluded that there are baseline differences between surgical and medical treatment groups (e.g., age, history of previous myocardial infarction).

d Patients died of heart-related causes. These data were from FDA database, and claimed that FDA concluded that baseline differences and other confounding factors (eg, withdrawal from the surgical group and/or receiving both therapies) could have biased the safety data.

e Estimated by chi-square testing: Significantly more patients withdrew from the study due to adverse events in omeprazole than in surgery group (P=0.04). Not significant for gastritis and atrophic gastritis, and marginally significant for argyrophil cell hyperplasia (P=0.06) between omeprazole and surgery groups.

f One patient, who had an uneventful post-operative course, died 3 months after the operation due to myocardial infarction.

g Patients died of heart-related causes. These data were from FDA database, and claimed that FDA concluded that baseline differences and other confounding factors (eg, withdrawal from the surgical group and/or receiving both therapies) could have biased the safety data.

h Barrett's diagnosed at baseline endoscopy

We identified two RCTs (published in 4 publications) that compared the adverse events associated with medical treatment to those associated with surgical treatment.15-17,157 We did not identify any study that directly compared the adverse events between medical treatment and endoscopic treatment, or between endoscopic treatment and surgical treatment.

One death (from pneumonia) was reported in the medical treatment arm in one RCT;16 another death was reported in the surgical treatment arm in another RCT.157 In followup publications of the later RCT, that investigators found that fatal outcome and heart-related cause of adverse events were more common in the medical treatment group than in the surgical treatment group.15,17 However, these data were from FDA database, and claimed that FDA concluded that baseline differences and other confounding factors (eg, withdrawal from the surgical group and/or receiving both therapies) could have biased the safety data; thus were not considered in this review. The summary findings from these two RCTs are described below.

One study (published in 3 publications) examined the long-term (7 and 12 years) gastric mucosa, esophageal cancer, and myocardial infarction outcomes in an RCT comparing medical with surgical treatment.15,17,157 The original RCT randomized 310 patients to either omeprazole (n=154) or antireflux surgery (n=155) treatment group. No death was observed in patients who were randomized to omeprazole treatment. One patient (0.69 percent), who was randomized to antireflux surgery group and had an uneventful post-operative course, died 3 months after the operation due to myocardial infarction. Eleven (7 percent) and three (2 percent) patients withdrew from the study due to unacceptable adverse events in the omeprazole and antireflux surgery group, respectively. Only 168 patients (96 in omeprazole and 72 in antireflux surgery group) had gastric mucosa outcomes after 7 years of followup. There were no significant differences in the rates of gastritis (17.7 vs. 22.2 percent), atrophic gastritis (5.2 vs. 4.2 percent), or argyrophil cell hyperplasia (14.6 vs. 5.6 percent) between the two groups (omeprazole vs. antireflux surgery, respectively) after 7 years of followup. At 12 years of followup, there was one case of esophageal cancer in the antireflux surgical treatment group but none in the omeprazole group.

Another study investigated serious adverse events comparing medical with surgical treatment in patients with GERD during the 3 years of followup.16 The original RCT randomized 554 patients to either esomeprazole (n=266) or laparoscopic antireflux surgery group (n=288). One death (0.4 percent) was reported in the esomeprazole treatment group, but no death was observed in the antireflux surgery group. There were significantly more patients withdrew from the study due to adverse events in esomeprazole than in surgery group (P=0.03). Overall rates of serious adverse events were lower in patients who received the esomeprazole treatment than in patients who had antireflux surgery (14 vs. 21 percent, respectively; P=0.06). Specific serious adverse event include myocardial infarction, injury, infections, infestations, neoplasms and gastrointestinal, musculoskeletal, connective tissue, cardiac, reproductive system (including breast), respiratory, thoracic, mediastinal vascular or hepatobiliary disorders.

#### Adverse Events Associated With Medical Treatment

##### Adverse Events Reported in Postmarketing Surveillance Studies

One postmarketing surveillance study analyzed the safety profile of esomeprazole in 11,595 patients (median age 56 years old; 46 percent male) had a record of receiving prescriptions for esomeprazole between September 2000 and April 2001.^158^ Thirty-six percent of these patients reported GERD as their primary indication for the use of esomeprazole. The top ranked adverse events include diarrhea, nausea or vomiting, abdominal pain, dyspepsia, headache or migraine, lower/upper respiratory tract infection, intolerance, general discomfort, and joint pain in descending order. The incidence densities (number of event per 1000 patient-month) for these adverse events were from 2.65 to 1.9 per 1000 patient-months. Furthermore, there were 101 “medically important events” cases probably or possibly related to esomeprazole based primarily on followup information obtained from clinicians. These events were reported in 71 patients (0.61 percent). There were a total of 1,331 “medically important events” involved 11 system organ classes (SOCs): immunological (9 events), cardiovascular (122 events), eye (36 events), central or peripheral nervous system (198 events), alimentary (480 events), skin (134 events), musculoskeletal (185 events), psychiatric (2 events), ear (17 events), respiratory (144 events), and metabolic and endocrine (12 events). There were 223 deaths (1.9%) reported, of which 57 cases with no information on the cause of death. The causes of death for the other 166 patients were mostly cancer (60 percent), or cardiovascular cause (20 percent).

Another postmarketing study analyzed the safety profile of rabeprazole (20 mg/day) in an open label, community-based interventional study.159 During the 8-week followup, the most commonly reported adverse events among 2,579 GERD patients include abdominal pain (1.2 percent), chest pain (0.5 percent); diarrhea (1.5 percent); dizziness (0.7 percent); dyspepsia (0.6 percent); belching (0.5 percent); headache (1.6 percent); nausea (1.0 percent); rash (0.5 percent), and upper respiratory tract infection (0.5 percent)

##### Adverse Events Reported in Randomized, Controlled Trials

(Table 38)

Table 38 Adverse events reported in randomized controlled trials of PPIs or H2RA

Author, year [UI] Medical treatment (sample size) Duration | Common adverse events^a^ | Death | “Serious” adverse events
Bardhan 2007^31^ [17539986]; - Pantoprazole 40mg (n=289); - Esomeprazole 40mg (n=293); 3 months | 0.5% to 1.2% | nd | “Serious adverse events” not related to study medications; - Pantoprazole: 2/289 (0.7%); - Esomeprazole: 7/293 (2.4%)
Chen 2005^60^ [15918199]; - Esomeprazole 40mg (n=25); - Omeprazole 20mg (n=23); 1 month | 0% to 13% Similar for all treatment groups | nd | nd
Devault 2006^61^ [16682260]; - Esomeprazole 20mg/day (n=510); - Lansoprazole 15mg/day (n=514); 6 months | 5.8% to 8% Similar for all treatment groups | nd | “Serious adverse events” not related to study medications; - Esomeprazole: 10/510 (2%); - Lansoprazole: 5/514 (1%)
Devault 2007^123^ [17760655]; - Pantoprazole 10/20/40mg/day (n=254); - Nizatidine 150mg twice/day (n=82); - Placebo once daily (n=82); 2 months | 50% to 59% Similar for all treatment groups | nd | nd
Eggleston 2009^36^ [19210493]; - Rabeprazole 20mg (n=464); - Esomeprazole 20mg (n=459); - Esomeprazole 40mg (n=469); 1 month | 2.1% to 18.5% | nd | nd
Fass 2006^35^ [15918196]; - Lansoprazole 30 mg twice/day (n=167); - Esomeprazole 40 mg/day (n=159); 2 months | 0% to 7.2% | nd | nd
Fass 2009^43^ [19392864]; - Dexlansoprazole 30 mg/day (n=315); - Dexlansoprazole 60 mg/day (n=315); - Placebo (n=317); 1 month | ≥ 5% Similar for all treatment groups | nd | “Serious adverse events” not related to study medications; - Dexlansoprazole 30 mg: 2/315 (0.6%); - Dexlansoprazole 60 mg: 1/315 (0.3%); - Placebo: 1/317 (0.3%)
Fock 2005^37^ [15918196]; - Rabeprazole 10 mg/day (n=63); - Esomeprazole 20 mg/day (n=66); 1 month | 18.2% to 22% Similar for all treatment groups | nd | Elevation of ALT^b^; - Rabeprazole: 1/63 (1.6%); - Esomeprazole: 4/66 (6.1%); Elevation of AST; - Rabeprazole: 1/63 (1.6%); - Esomeprazole: 2/66 (3%)
Glatzel 2007^30^ [17489035]; - Pantoprazole 40 mg/day (n=284); - Esomeprazole 40 mg/day (n=277); 1 month | 1.2% Similar for all treatment groups | nd | “Serious adverse events” not related to study medications; - Pantoprazole: 1/284 (0.4%); - Esomeprazole: 2/277 (0.7%)
Goh 2007^28^ [17301646] Acute phase (4-8 weeks):; - Pantoprazole 40 mg/day (n=1268); Maintenance phase (6 months); - Pantoprazole 20 mg/day (n=636); - Esomeprazole 20 mg/day (n=667); 6 months | Considered by investigators to be related to study medication: 0.9% to 3% | Deaths unrelated to treatment: 2/1303 (0.2%) | “Serious adverse events” not related to study medications; - Pantoprazole: 1.4%; - Esomeprazole: 2.5%; Serious adverse event (loss of consciousness) attributable to esomeprazole: 1/1303 (0.08%)
Howden 2009^45^ [19681809]; - Dexlansoprazole 60 mg/day (n=159); - Dexlansoprazole 90 mg/day (n=152); - Placebo (n=140); 1 month | 0% to 7% Significantly greater in Dexlansoprazole 60 mg (P<0.01) and 90 mg (P=0.003) than placebo | 0% | “Serious adverse events” not related to study medications; - Dexlansoprazole 60 mg: 2/159 (1.3%); - Dexlansoprazole 90 mg: 5/152 (3.3%)
Johnson 2005^39^ [16128933]; - Esomeprazole 20 mg/day (n=220); - Esomeprazole 40 mg/day (n=226); 1 month | 1.3% to 5% Similar for all treatment groups | nd | Nd
Katz 2007^40^ [17305763]; - Esomeprazole 10 mg/day (n=80); - Esomeprazole 40 mg/day (n=89); 1 month | 2% | nd | nd
Lightdale 2006^55^ [16773434]; - Esomeprazole 20 mg/day (n=585); - Omeprazole 20 mg/day (n=588); 2 months | 1.5% to 9.9 Similar for all treatment groups | nd | “Serious adverse events” not related to study medications; - Esomeprazole: 1/585 (0.2%); - Omeprazole: 6/588 (1%)
Metz 2009^44^ [19210298]; - Dexlansoprazole MR 30 mg/day; - Dexlansoprazole MR 60 mg/day; 6 months | 2.1% to 10.8% Similar for all treatment groups | nd | No oesophageal ulcers and perforation
Mine 2005^42^ [16105122]; - 15 mg of lansoprazole once daily for 16 weeks (n=14); - 30 mg of lansoprazole once daily for 8 weeks followed by another 8-week treatment with 20 mg of famotidine twice daily (n=14); - 30 mg of lansoprazole once daily for 8 weeks followed by another 8-week treatment with 15 mg of lansoprazole once daily (n=15); 4 months | 0% (No side effects reported) | nd | nd
Morgan 2007^52^ [18080054]; - Rabeprazole 20mg/day (n=137); - Rabeprazole 20mg on-demand (n=131); 6 months | <3% to 8.8% | nd | 1 (0.3%) memory impairment was categorized as possibly related to study medication 6 (2.2%) serious adverse events not related to study medications: post-op tonsillectomy hemorrhage, malignant melanoma, atrial fibrillation, headache, skin cancer, intestinal infection
Norman 2005^23^ [15924594]; - Esomeprazole 20 mg on-demand; - Esomeprazole 20 mg/day; - Ranitidine 150 mg/day; 6 months | 0.5% to 2% Similar for all treatment groups | nd | nd
Pace 2005^58^ [16024305] Acute phase (4-8 weeks):; - Rabeprazole 20 mg/day (n=283); - Omeprazole 20 mg/day (n=277); Maintenance phase (48 weeks); - Rabeprazole 10 mg 1-2 times/day (n=502); 48 weeks | Acute Phase: Omeprazole (13/272, 4.8%) > Rabeprazole (4/277), P=0.0241 Long-term Phase: 1% to 2% | nd | Acute Phase: “Serious adverse events” not related to study medications Omeprazole: 3/272 (1.1%) Maintenance Phase: “Serious adverse events” Rabeprazole: 12/502 (2.4%)
Pai 2006^46^ [17009401]; - S- Pantoprazole 20 mg/day (n=187); - Racemic Pantoprazole 40 mg/day (n=182); 1 month | 0% (“none of the patients in either groups reported adverse events”) | nd | nd
Peura 2009^27^ [18726153]; - Lansoprazole 15 mg/day (n=100); - Ranitidine 150 mg/day (n=100); 12 months | 5% to 6% | nd | “Serious adverse events” not related to study medications; - Lansoprazole: 9/100 (9%); - Ranitidine: 1/100 (1%)
Pilotto 2007^56^ [17724802]; - Omeprazole 20 mg/day (n=80); - Lansoprazole 30 mg/day (n=80); - Pantoprazole 40 mg/day (n=80); - Rabeprazole 20 mg/day (n=80); 2 months | 0.1% | nd | nd
Scholten 2007^32^ [17358101] Acute phase (4 weeks):; - Pantoprazole 20 mg on-demand (n=236); Long-term phase (6 months); - Pantoprazole 20 mg on-demand (n=100); - Esomeprazole 20 mg on-demand (n=100); 6 months | Acute Phase: 0.8% Long-term Phase: 1% to 6% | nd | “Serious adverse events” not related to study medications; - Pantoprazole: 2/100 (2%); - Esomeprazole: 2/100 (2%)
Sjostedt 2005^49^ [16091055]; - Esomeprazole 20 mg/day (n=243); - Esomeprazole 20mg on-demand (n=234); 6 months | 0.4% to 2.9% Similar for all treatment groups | 20 mg/day: 1/243 (0.4%)^c^ 20 mg on-demand: 0 | “Serious adverse events”; - 20 mg/day: 9/243 (3.7%); - 20 mg on demand: 7/234 (3.0%)
Tepes 2009^59^ [19453031]; - Omeprazole 10mg/day (n=94); - Omeprazole 20 mg/day (n=102); - Omeprazole 20mg on-demand (n=20); 12 months | 0.8% to 2.5% | nd | nd
Vasiliadis 2010^41^ [19809412]; - Esomeprazole 40mg twice daily (n=25); - Esomeprazole 40mg once daily (n=25); - Esomeprazole 40mg every other day (n=25); 1 month | 0% (No adverse events reported) | nd | nd
Vcev 2006^33^ [17058517]; - Esomeprazole 40 mg/day (n=90); - Pantoprazole 40 mg/day (n=90); 1 month | 11% to 12% Similar for all treatment groups | nd | nd
Schmitt 2006^62^ [16642422]; - Esomeprazole 40 mg/day (n=576); - Omeprazole 20 mg/day (n=572); 1-2 months | 1.2% to 10.2% Similar for all treatment groups | nd | nd

ALT= alanine aminotransferase; AST= aspartate aminotransferase

a diarrhea, nausea or vomiting, abdominal pain, dyspepsia, headache or migraine, respiratory track infection intolerance, general discomfort, joint pain, gastritis, dizziness, rash, chest pain, and nausea

b Investigators stated that ALT and AST changes were not clinically significant

c This death was not considered to be due to esomeprazole treatment.

A total of 28 RCTs of PPIs or H_2_RAs reported adverse events in trial participants.23,27,28,30-33,35-37,39-46,49,52,55,56,58-62,123 The durations of these RCTs ranged from 1 to 12 months. The common adverse events reported in these RCTs were similar to those reported in the postmarketing surveillance studies (see the section above), and none reported a significant difference in the common adverse events between different medical treatment. One RCT reported that there were significantly more common adverse events in patients received dexlansoprazole (60 or 90 mg/day) than in those who received placebo,160 but another RCT comparing dexlansoprazole (30 or 60 mg/day) to placebo did not find significant differences in common adverse events between groups.43

Of the 28 RCTs, two RCTs reported a total of three deaths among 1,546 patients.28,49 These deaths were thought not related to study medications by the investigators. Eleven RCTs reported “serious adverse events” (not defined) ranged from 0.3 to 9 percents.27,28,30-32,43,45,49,55,58,61 These “serious” adverse events were also thought not related to study medications by the investigators. One RCT reported 2 to 6 percent of patients had elevated liver function test results after PPI treatment, although the investigators stated that these changes were not clinically significant.37 Another RCT reported 1 case (0.3 percent) of memory impairment that was thought possibly related to rabeprazole treatment.52 No other RCTs reported serious adverse events after PPI or H_2_RA treatment.

##### Use of PPIs or H2RAs and Fracture Risk

(Table 39)

Table 39 Observational studies that examined the relationships between the use of PPIs or H2RAs and fracture risk

Author year [UI] | Study design country | Population (N) | Outcomes | Adjusted OR (95% CI)
Cohort studies
Gray 2010^162^ [20458083] | WHI observational study and clinical trials U.S. | 50-79 y Postmenopausal women | 7.8 y follow-up
Gray 2010^162^ [20458083] | WHI observational study and clinical trials U.S. | | • Risk of hip fracture of PPI use | HR 1.0 (0.71, 1.40)
Gray 2010^162^ [20458083] | WHI observational study and clinical trials U.S. | 161806 | • Risk of clinical spine fracture of PPI use | HR 1.47 (1.18, 1.82)
Gray 2010^162^ [20458083] | WHI observational study and clinical trials U.S. | 161806 | • Risk of forearm or wrist of PPI use | HR 1.26 (1.05, 1.51)
Gray 2010^162^ [20458083] | WHI observational study and clinical trials U.S. | 161806 | • Risk of total fracture PPI use | HR 1.25 (1.15, 1.36)
Gray 2010^162^ [20458083] | WHI observational study and clinical trials U.S. | 161806 | • Risk of hip fracture of H_2_RA use | HR 1.07 (0.87, 1.30)
Gray 2010^162^ [20458083] | WHI observational study and clinical trials U.S. | 161806 | • Risk of clinical spine fracture of H_2_RA use | HR 1.02 (0.87, 1.20)
Gray 2010^162^ [20458083] | WHI observational study and clinical trials U.S. | 161806 | • Risk of forearm or wrist of H_2_RA use | HR 1.05 (0.93, 1.19)
Gray 2010^162^ [20458083] | WHI observational study and clinical trials U.S. | 161806 | • Risk of total fracture of H_2_RA use | HR 1.08 (1.02, 1.14)
Yu 2008^161^ [18813868] | Cohort study U.S. | 79 y Men & Women | 7.6 y follow-up
Yu 2008^161^ [18813868] | Cohort study U.S. | | • Risk of non-spine fracture of PPI use (Women) | HR 1.34 (1.10, 1.64)
Yu 2008^161^ [18813868] | Cohort study U.S. | 11094 | • Risk of non-spine fracture of PPI use (Men) | HR 1.21 (0.91, 1.62)
Yu 2008^161^ [18813868] | Cohort study U.S. | 11094 | • Risk of hip fracture of PPI use (Women) | HR 1.16 (0.80, 1.67)
Yu 2008^161^ [18813868] | Cohort study U.S. | 11094 | • Risk of hip spine fracture of PPI use (Men) | HR 0.62 (0.26, 1.44)
Yu 2008^161^ [18813868] | Cohort study U.S. | 11094 | • Risk of non-spine fracture of H_2_RA use (Women) | HR 1.08 (0.90, 1.31)
Yu 2008^161^ [18813868] | Cohort study U.S. | 11094 | • Risk of non-spine fracture of H_2_RA use (Men) | HR 0.88 (0.58, 1.35)
Yu 2008^161^ [18813868] | Cohort study U.S. | 11094 | • Risk of hip fracture of H_2_RA use (Women) | HR 1.27 (0.92, 1.75)
Yu 2008^161^ [18813868] | Cohort study U.S. | 11094 | • Risk of hip spine fracture of H_2_RA use (Men) | HR 1.22 (0.54, 2.76)
Case control studies
Grisso 1997^163^ [9143208] | Case-control U.S. | >45 y Men | • Risk of hip spine fracture of H_2_RA use (users vs. non-users) | 2.5 (1.4, 4.6)
Grisso 1997^163^ [9143208] | Case-control U.S. | | • Risk of hip spine fracture of H_2_RA use (users vs. non-users) | 2.5 (1.4, 4.6)
Grisso 1997^163^ [9143208] | Case-control U.S. | (cases, 356) (controls, 402) | • Risk of hip spine fracture of H_2_RA use (users vs. non-users) | 2.5 (1.4, 4.6)
Yang 2006^164^ [17190895] | Nested case-control UK | >50 y Men & Women | • Risk of hip fracture with PPI therapy > 1year | 1.44 (1.30, 1.59)
Yang 2006^164^ [17190895] | Nested case-control UK | | Risk of hip fracture with > 1.75 average daily-dose PPI | 2.65 (1.80, 3.90
Yang 2006^164^ [17190895] | Nested case-control UK | (cases, 13556) (controls, 135386) | Risk of hip fracture with > 1.75 average daily-dose PPI | 2.65 (1.80, 3.90
Vestergaard 2006^165^ [16927047] | Case-control Denmark | Mean age: 43.3 y Men & Women | • Risk of any fracture with PPI use within last year | 1.18 (1.12, 1.43)
Vestergaard 2006^165^ [16927047] | Case-control Denmark | | • Risk of hip fracture with PPI use within last year | 1.45 (1.28, 1.65)
Vestergaard 2006^165^ [16927047] | Case-control Denmark | (cases, 124655) (controls, 373962) | • Risk of spine fracture with PPI use within last year | 1.60 (1.25, 2.04)
Targownik 2008^166^ [18695179] | Case-control Canada | >50 y Men & Women | • Risk of hip fracture after 5+ years of PPI use | 1.62 (1.02, 2.58)
Targownik 2008^166^ [18695179] | Case-control Canada | | • Risk of hip fracture after 7+ years of PPI use | 4.55 (1.68, 12.29)
Targownik 2008^166^ [18695179] | Case-control Canada | (cases, 15792) (controls, 47289) | • Risk of any osteoporosis-related fracture after 7+ years of PPI use | 1.92 (1.16, 3.18)
Kaye 2008^167^ [18657011] | Nested case-control study UK | 50-79 y Men & Women | • Risk of hip fracture after 2+ years of PPI use | RR 0.9 (0.7, 1.1)
Kaye 2008^167^ [18657011] | Nested case-control study UK | | • Risk of hip fracture after 2+ years of PPI use | RR 0.9 (0.7, 1.1)
Kaye 2008^167^ [18657011] | Nested case-control study UK | (cases, 4414) (controls, 10923) | • Risk of hip fracture after 2+ years of PPI use | RR 0.9 (0.7, 1.1)
Roux 2009^168^ [19023510] | Case-control Europe | 65.8 y Postmenopausal women | • Risk of vertebral fracture after 6 years of PPI use | 3.50 (1.14, 8.44)^a^
Roux 2009^168^ [19023510] | Case-control Europe | | • Risk of vertebral fracture after 6 years of PPI use | 3.50 (1.14, 8.44)^a^
Roux 2009^168^ [19023510] | Case-control Europe | 1211 | • Risk of vertebral fracture after 6 years of PPI use | 3.50 (1.14, 8.44)^a^
Corley 2010^169^ [20353792] | Case-control U.S. | ≥ 18 y Men & Women | • Risk of hip fracture after 4-5.9 years of PPI use | 1.21 (1.10, 1.33)
Corley 2010^169^ [20353792] | Case-control U.S. | | • Risk of hip fracture after 6-7.9 years of PPI use | 1.33 (1.19, 1.49)
Corley 2010^169^ [20353792] | Case-control U.S. | (cases, 33752) (controls, 130471) | • Risk of hip fracture after 8-9.9 years of PPI use | 1.33 (1.12, 1.57)
Corley 2010^169^ [20353792] | Case-control U.S. | (cases, 33752) (controls, 130471) | • Risk of hip fracture after 10+ years of PPI use | 1.85 (1.41, 2.43)

WHI=Women's Health Initiative

a Adjusted for current use of thiazide diuretics, corticosteroids, thyroid hormone supplementation, calcium, vitamin D, and hormone replacement therapy (HRT)

We identified nine observational studies (7 case-control and 2 cohort studies) that examined the relationships between the use of PPIs or H2RA and fracture risk.161-169 We did not identify a RCT that specifically focused on fracture risk, and none of the RCTs that reported adverse events of medical therapy included fractures as an outcome..(see Key Question 1D)

The nine observational studies enrolled older men and/or women (>45 years old). The total number of fracture cases ranged from 356 to 124,655 in case-control studies.163-169 The total sample sizes were 11,094 and 161,806 in the two cohort studies in U.S..161,162 Both had about 8 years of followup duration. All studies performed multivariate analyses to adjust for potential confounding factors, but the factors included in the analyses varied across studies. The summary findings from these nine observational studies are summarized in Table 39. Below are the key findings:

- Two cohort studies in the U.S. found mixed results on the relationships between the use of PPIs or H_2_RAs and fracture risk during the 8 years of followup.161,162 Findings from one cohort study suggest that men and women, and different types of medical treatment (i.e., PPIs or H_2_RAs) may have different strengths of association with fracture risk. Specifically, non-spine fracture risk was higher with PPI use than with H_2_RA use, but the hip fracture risk was similar between PPI and H_2_RA.
- Six (86%) of the seven case-control studies reported an increased risk of fractures with the use of PPIs.164-169 Exposure to PPIs ranged from 1 to 12 years, depending on the study.
- Three case-control studies found an increased risk of hip fracture with a longer duration of PPI use.164,166,169

In summary, the available data suggest a possible association between the use of PPI for more than 1 year and an increased risk of fractures in older adults. However, all of the available data are based on observational studies and the mechanisms leading to an increased fracture risk are unknown. Thus, the magnitude of risk remains unclear and the association could in part be due to residual confounding.

##### Drug Interaction

Another potential serious complication recognized since our 2005 report was a drug interaction between clopidogrel and PPIs, potentially leading to an increased risk of cardiovascular events. As a result, the Food and Drug Administration issued a warning in late 2009 about the interaction,170 although the importance of this interaction on clinical endpoints remains unsettled. Our search strategy did not focus on the clopidogrel PPI drug interaction since most such studies were based on observational data and a detailed review was beyond the scope of this update. Only one of the studies included in our review specifically addressed the issue of drug interactions with PPIs and that study did not find a drug interaction between PPIs and concomitant medications (medication not specified).128

#### Adverse Events Associated With Surgical Treatment

We identified 38 studies published after the 2005 CER and reported intraoperative complications or adverse events occurring past 30 days after anti-reflux surgical procedures.18-20,67-70,72-78,80,81,83,84,133,139,143,145-147,150,153,171-181 Anti-reflux surgical procedures of interest include total or partial (Nissen or Toupet) fundoplication. Because one study may have reported more than one adverse event; it could appear multiple times in our analyses. The reported intraoperative complications include mortality,78,80,143,146,172,179,180 reoperation,80,81,179 conversion,78,80,143 gastrointestinal injury/perforation,19,73,132,142,143,146,175,176,179 pneumothorax,19,73 splenic injury,175 bleeding,19,73,78,146,176,177,181 pulmonary event,19,73,177 infection/fever, 19,73,177 dysphagia,78,150 and pain/discomfort.177 The reported adverse events occurring past 30 days after anti-reflux surgical procedures include mortality,19,20,67,70,73,81,83,134,138,146,153,171,175-177 reoperation,19,69,70,74-81,84,139,150,171,172,176-178,180 bleeding,18,134,174 pulmonary event,83,134,138,171,180 gastrointestinal event,18,67,72,78,80,84,86,133,134,138,146,150,174,175,179,180 infection/fever,20,79,134,138,153,171,174,180,182 dysphagia,18,20,70,72,73,78,80,83,84,142,146,150,153,173,176,177,179,182 bloating,20,67,70,72,73,78,84,133,142,146,150,177,179 and pain.20,72,74,79,133,146,179

##### Intra- and Perioperative Complications After Surgical Procedures

Four studies reported no deaths,78,143,146,179 but one study reported 0.8 percent of thirty-day all-cause mortality for Laparoscopic Nissen Fundoplication(LNF).180 No deaths were reported for Open Nissen Fundoplication(ONF),78 Laparoscopic Toupet Fundoplication(LTF),80 and Laparoscopic Nissen/Toupet Fundoplication (LNF/LTF) respectively.172 One study reported 0.8 percent of reoperation for LNF.179 Re-operation rates ranged from 0 to 1.8 percent for LTF.80,81 One study reported no gastrointestinal perforation for ONF.19 Gastrointestinal perforation rates ranged: from 0 to 3.2 percent for LNF143,175,176 and from 0.1 to 0.5 percent for LNF/LTF.19,73 Bleeding event rate ranged: from 0 to 3.6 percent for ONF;19,78 from 0.5 to 1.8 percent for LNF78,146,176,177,181 and from 0 to 1.5 percent for LNF/LTF.19,73 Dysphagia event rate ranged from 2.7 to 23 percent for LNF.78,150 The incidence of dysphagia was 7.1 percent for ONF78 and 10 percent for LTF respectively.150 More detailed information about intra- and perioperative complications can be found in Table 40.

Table 40 Intraoperative complications (and those occurring within 30 days) for surgical procedures

| | Surgical
| Open Nissen Fundoplication | Laparoscopic Nissen Fundoplication | Laparoscopic Toupet Fundoplication | Laparoscopic Nissen Fundoplication /Laparoscopic Toupet Fundoplication
Mortality event rate78,80,143,146,172,179,180 | [underlined: Trullenque, 2005 [16004525]] 0/28 (0%) | [underlined: del Genio, 2007 [17426906]] 0/380 (0%) [underlined: Cowgill, 2007 [17879678]] 2/239 (0.8%) [underlined: Trullenque, 2005 [16004525]] 0/75 (0%) [underlined: Pizza, 2007 [17278197]] 0/420 (0%) [underlined: Lee, 2009 [19259354]] 0/31 (0%) | [underlined: Zehetner, 2006 [16391962]] 0/100 (0%) | [underlined: Gill, 2007 [17436134]] 0/400 (0%)
Re-operation event rate80,81,179 | | [underlined: del Genio, 2007 [17426906]] 3/380 (0.8%) | [underlined: Zehetner, 2006 [16391962]] 0/100 (0%) [underlined: Rice, 2006 [16549692]] 2/113 (1.8%)
Conversion event rate78,80,143 | [underlined: Trullenque, 2005 [16004525]] 0/28 (0%) | [underlined: Trullenque, 2005 [16004525]] 1/75 (1.3%) [underlined: Lee, 2009 [19259354]] 0/31 (0%) | [underlined: Zehetner, 2006 [16391962]] 0/100 (0%)
Gastrointestinal injury/perforation event rate19,73,132,142,143,146,175,176,179 | [underlined: Olberg, 2005 [15932167]] Gastric perforation: 0/158 (0%) | [underlined: Zacharoulis, 2006 [17024541]]; - Esophageal perforation: 3/808 (0.4%); - Stomach perforation: 4/808 (0.5%); [underlined: Csendes, 2005 [16137596]]; - Esophageal or gastric perforation: 0/225 (0%); [underlined: Lee, 2009 [19259354]]; - Gastric perforation: 1/31 (3.2%); [underlined: del Genio, 2007 [17426906]]; - Mucosal tear: 1/380 (0.3%); [underlined: Pizza, 2007 [17278197]]; - Mucosal tear: 1/420 (0.2%); [underlined: Anvari, 2006 [16341568]]; - Acute trans-hiatal herniation of the wrap 1/70 (1.4%); [underlined: Kamolz, 2005 [15959712]]; - Severe flatulence 9/178 (5.3%); - Severe diarrhea 6/178 (3.6%) | | [underlined: Olberg, 2005 [15932167]] Gastric perforation: 1/215 (0.5%) [underlined: Pessaux, 2005 [16230543]]; - Gastric perforation: 1/1340 (0.1%); - Esophageal perforation: 4/1340 (0.3%); - Paraesophageal herniation: 2/1340 (0.1%); - Persistent esogastric perforation: 2/1340 (0.1%)
Pneumothorax event rate19,73 | [underlined: Olberg, 2005 [15932167]]; - Pneumothorax: 0/158 (0%) | | | [underlined: Pessaux, 2005 [16230543]]; - Pneumothorax: 4/1340 (0.3%)
Splenic injury event rate175 | | [underlined: Csendes, 2005 [16137596]]; - Splenectomy: 0/225 (0%)
Bleeding event rate19,73,78,146,176,177,181 | [underlined: Trullenque, 2005 [16004525]]; - Abdominal hemorrhage: 1/28 (3.6%); [underlined: Olberg, 2005 [15932167]]; - Intraabd. Bleeding: 2/158 (1.3%); - Bleeding, transfusion: 0/158 (0%) | [underlined: Zacharoulis, 2006 [17024541]] 4/808 (0.5%) [underlined: Salminen, 2006 [16921296]] 8/444 (1.8%) [underlined: Jensen, 2009] [18855057] 1/113 (0.9%) [underlined: Trullenque, 2005 [16004525]]; - Abdominal hematoma: 1/75 (1.3%); [underlined: Pizza, 2007 [17278197]]; - Bleeding, 3/420 (0.7%) | | [underlined: Pessaux, 2005 [16230543]]; - Bleeding: 20/1340 (1.5%); - Hematoma: 5/1340 (0.4%); [underlined: Olberg, 2005 [15932167]]; - Intraabd. Bleeding: 0/215 (0%); - Bleeding, transfusion: 2/215 (0.9%)
Pulmonary event rate19,73,177 | [underlined: Olberg, 2005 [15932167]]; - Pulmonary embolism: 0/158 (0%) | [underlined: Salminen, 2006 [16921296]]; - Pneumonia: 1/444 (0.2%) | | [underlined: Pessaux, 2005 [16230543]]; - Venous thrombosis or pulmonary embolism: 2/1340 (0.1%); - Pleural effusion: 5/1340 (0.4%); - Pneumonia: 11/1340 (0.8%)
Infection/fever event rate19,73,177 | [underlined: Olberg, 2005 [15932167]]; - Lung infection: 4/158 (2.5%); - Wound infection: 2/158 (1.3%) | [underlined: Salminen, 2006 [16921296]] 4/444 (0.9%) | | [underlined: Pessaux, 2005 [16230543]]; - Urinary infection: 3/1340 (0.2%); - Wound infection: 3/1340 (0.2%); - Abdominal abscess: 1/1340 (0.1%); [underlined: Olberg, 2005 [15932167]]; - Lung infection: 8/215 (3.7%); - Wound infection: 0/215 (0%)
Dysphagia event rate78,150 | [underlined: Trullenque, 2005 [16004525]]; - Solid-induced dysphagia: 2/28 (7.1%) | [underlined: Trullenque, 2005 [16004525]]; - Solid-induced dysphagia: 2/75 (2.7%); [underlined: Strate, 2008 [18027055]] 23/100 (23%) | [underlined: Strate, 2008 [18027055]] 10/100 (10%)
Pain/discomfort event rate177 | | [underlined: Salminen, 2006 [16921296]]; - Port sign pain: 1/444 (0.2%)
Other event rate19,73,78,143,177 | [underlined: Trullenque, 2005 [16004525]]; - Hemothorax: 1/28 (3.6%); - Surgical wound complication: 3/28 (10.7%); [underlined: Olberg, 2005 [15932167]]; - Pneumothorax: 0/158 (0%); - Crural rupture: 1/158 (0.6%); - Pulmonary embolism: 0/158 (0%); - Acute paraesoph. Herniation: 0/158 (0%) | [underlined: Salminen, 2006 [16921296]]; - Urinary retention: 4/444 (0.9%); - Neural injury of the diaphragm: 1/444 (0.2%); - Wrap herniation (early): 1/444 (0.2%); [underlined: Trullenque, 2005 [16004525]]; - Wound complication: 2/75 (2.7%); - Subcutaneous emphysemas: 3/75 (4.0%); [underlined: Lee, 2009 [19259354]]; - Atelectasis and prolonged ileus: 2/31 (6.5%); - Subcutaneous emphysemas: 2/31 (6.5%) | | [underlined: Pessaux, 2005 [16230543]]; - Cardiac arrhythmia: 1/1340 (0.1%); [underlined: Olberg, 2005 [15932167]]; - Pneomothorax: 6/215 (2.8%); - Crural rupture: 0/215 (0%); - Pulmonary embolism: 1/215 (0.5%); - Acute paraesoph. Herniation: 3/215 (1.4%)

##### Complications Occurring More Than 30 Days After Surgical Procedures

One study reported 0.6 percent of all-cause mortality for ONF.19 Mortality event rate ranged: from 0 to 8.8 percent for LNF;20,67,70,83,138,146,175-177 from 3.1 to 15.1 percent for LTF67,70,81 and from 0 to 0.9 percent for LNF/LTF.19,73,134,153,171 Reoperation rate ranged: from 3.2 to 34.8 percent for ONF;19,75-77 from 0 to 15 percent for LNF;69,70,75-79,150,176-178,180 from 4 to 9.4 percent for LTF70,80,81,150 and from 0.8 to 8 percent for LNF/LTF.19,74,84,139,171,172 Dysphagia event rate ranged: from 0 to 4.4 percent for ONF;78,176,182 from 1.3 to 30.6 percent for LNF;18,20,70,72,78,83,142,146,177,179 from 2 to 28.0 percent for LTF;70,72,80 and from 2 to 13.5 percent for LNF/LTF.73,84,150,153,173 One study reported no bloating for ONF.78 Bloating event rate ranged; from 1 to 84.9 percent for LNF;20,67,70,72,78,133,142,146,177,179 from 46 to 70 percent for LTF;67,70,72,133 and from 7.5 to 53 percent for LNF/LTF.73,84,150 There was only one study include both open and laparoscopic Rossetti Nissen fundoplication and this study reported 22.4 percent of esophageal dysmotility.148 More detailed information about complications occurred more than 30 days after surgical procedures can be found in Table 41.

Table 41 Complications occurring more than 30 days after surgical procedures

| | Surgical
| Open Nissen Fundoplication | Laparoscopic Nissen Fundoplication | Laparoscopic Toupet Fundoplication | Laparoscopic Nissen Fundoplication /Laparoscopic Toupet Fundoplication
Mortality event rate19,20,67,70,73,81,83,134,138,146,153,171,175-177 | [underlined: Olberg, 2005 [15932167]] 1/158 (0.6%) | [underlined: Csendes, 2005 [16137596]] 0/225 (0%) [underlined: Zacharoulis, 2006 [17024541]] 13/808 (1.6%) [underlined: Salminen, 2006 [16921296]] 4/468 (0.9%) [underlined: Dallemagne, 2006 [16333553]] 6/68 (8.8%) [underlined: Cai, 2008 [18942055]] 3/54 (5.6%) [underlined: Pizza, 2007 [17278197]] 2/65 (3%) [underlined: Teixeria, 2009 [19453033]]; - Operation mortality: 0/143 (0%); [underlined: Dalessio, 2005 [16137590]] 0/257 (0%) [underlined: Anvari, 2006 [17227922]] 0/52 (0%) | [underlined: Dallemagne, 2006 [16333553]] 1/32 (3.1%) [underlined: Cai, 2008 [18942055]] 8/53 (15.1%) [underlined: Rice, 2006 [16549692]] 12/113 (11%) | [underlined: Rosenthal, 2006 [17243869]] 0/186 (0%) [underlined: Pessaux, 2005 [16230543]] 0/1340 (0%) [underlined: Wang, 2008 [18368318]] 0/231 (0%) [underlined: Brehant, 2006 [16504893]] 3/2684 (0.1%) [underlined: Olberg, 2005 [15932167]] 2/215 (0.9%)
Re-operation event rate19,69,70,74-81,84,139,150,171,172,176-178,180 | [underlined: Draaisma, 2006 [16794387]; Broeders, 2009 [19801931]] 24/69 (34.8%) [underlined: Salminen, 2007 [17667497]] 3/35 (8.6%) [underlined: Olberg, 2005 [15932167]] 5/158 (3.2%) [underlined: Ruiz-Tovar, 2010 [19916741]] 1/88 (1.1%) | [underlined: Dallemagne, 2006 [16333553]] 1/68 (1.5%) [underlined: Draaisma, 2006 [16794387]; Broeders, 2009 [19801931]] 12/79 (15.2%) [underlined: Trullenque, 2005 [16004525]] 0/75 (0%) [underlined: Yang, 2008 [18156921]] 13/88 (14.8%) [underlined: Zacharoulis, 2006 [17024541]] 12/808 (1.5%) [underlined: Salminen, 2006 [16921296]] 9/468 (1.9%) [underlined: Morgenthal, 2007 [17562117]] 18/166 (10.8%) [underlined: Cowgill, 2007 [17879678]] 28/239 (12%) [underlined: Salminen, 2007 [17667497]] 3/38 (7.9%) [underlined: Strate, 2008 [18027055]]15/100 (15%) [underlined: Ruiz-Tovar, 2010 [19916741]] 2/78 (2.6%) | [underlined: Dallemagne, 2006 [16333553]] 3/32 (9.4%) [underlined: Zehetner, 2006 [16391962]] 5/100 (5%) [underlined: Rice, 2006 [16549692]] 8/113 (7.1%) [underlined: Strate, 2008 [18027055]] 4/100 (4%) | [underlined: Gill, 2007 [17436134]] 3/400 (0.8%, ≤ 3mo) 21/400 (5.3%, > 3mo) [underlined: Wijnhoven, 2008 [18071830]] 70/844 (8%) [underlined: Rosenthal, 2006 [17243869]] 6/186 (3%) [underlined: Oelschlager, 2008 [17970835]] 10/288 (3%) [underlined: Gee, 2008 [18490558]] 2/173 (1.2%) [underlined: Olberg, 2005 [15932167]] 17/215 (7.0%)
Bleeding event rate18,134,174 | [underlined: Huttl, 2005 [16211438]]; - Bleeding (without spleen): 5/1062 (0.5%) | [underlined: Mehta, 2006 [17114017]]; - Splenic bleeding: 2/91 (2.2%) | [underlined: Huttl, 2005 [16211438]]; - Bleeding (without spleen): 1/470 (0.2%) | [underlined: Brehant, 2006 [16504893]]; - Bleeding: 10/2684 (0.4%)
Pulmonary event rate83,134,138,171,180 | | [underlined: Cowgill, 2007 [17879678]]; - Postpneumonic empyema: 1/239 (0.4%); - Atelectasis: 1/239 (0.4%); [underlined: Teixeria, 2009 [19453033]]; - Respiratory complications: 6/143 (4.2%); [underlined: Dalessio, 2005 [16137590]]; - Pleural effusion: 1/257 (0.4%) | | [underlined: Rosenthal, 2006 [17243869]] 3/186 (1.6%) [underlined: Brehant, 2006 [16504893]]; - Pulmonary infection: 25/2684 (0.9%); - Pleural effusion: 12/2684 (0.4%); - Pulmonary embolism: 7/2684 (0.3%)
Gastrointestinal event rate18,67,72,78,80,84,86,133,134,138,146,150,174,175,179,180 | [underlined: Trullenque, 2005 [16004525]]; - Early satiety: 0/28 (0%); - Diarrhea: 0/28 (0%); [underlined: Huttl, 2005 [16211438]]; - Esophageal perforation: 6/1062 (0.6%); - Injuries of the stomach wall: 6/1062 (0.6%); [underlined: Cowgill, 2007 [17879678]]; - Early postoperative gastroesophageal junction edema: 4/239 (1.7%); - Gastric/esophageal leak: 3/239 (1.3%); - Gastrotomy/esophagotomy: 2/239 (0.8%); - Ileus: 1/239 (0.4%); [underlined: Csendes, 2005 [16137596]]; - Necrosis: 0/225 (0%) | [underlined: del Genio, 2007 [17426906]]; - Hyperflautulence: 7/368 (1.9%); - Early satiety: 14/368 (3.8%); [underlined: Booth, 2008 [18076018]]; - Restriction in belching: 26/59 (44%); - Unable to belch: 8/59 (14%); - Increased flatus: 44/59 (75%); - Diarrhoea: 4/59 (7%); [underlined: Cai, 2008 [18942055]]; - Able to belch normally: 24/48 (50%); [underlined: Trullenque, 2005 [16004525]]; - Early satiety: 1/75 (1.3%); - Diarrhea: 2/75 (2.7%); [underlined: Mardani, 2009 [19016274]]; - Ability to belch: 43/82 (52.4%); [underlined: Pizza, 2007 [17278197]]; - Early satiety: 11/400 (2.8%); - Hyperflatulence: 7/400 (1.8%); [underlined: Strate, 2008 [18027055]]; - Inability to belch: 25/100 (25%); [underlined: Trullenque, 2005 [16004525]]; - Hindered vomiting and burping 15/75 (20.0%) | [underlined: Booth, 2008 [18076018]]; - Restriction in belching: 21/58 (36%); - Unable to belch: 3/58 (5%); - Increased flatus: 39/58 (67%); - Diarrhoea: 6/58 (10%); [underlined: Cai, 2008 [18942055]]; - Able to belch normally: 27/41 (66%); [underlined: Zehetner, 2006 [16391962]]; - Early satiety: 35/87 (41%); - Burp impossibility: 28/87 (33%); - Flatulence: 8/87 (10%); - Diarrhea: 9/87 (11%); [underlined: Huttl, 2005 [16211438]]; - Esophageal perforation: 2/470 (0.4%); - Injuries of the stomach wall: 1/470 (0.2%); [underlined: Strate, 2008 [18027055]]; - Inability to belch: 13/100 (13%); [underlined: Fein, 2008 [18766417] Vomiting: 6/25 (24%)] | [underlined: Oelschlager, 2008 [17970835]]; - New or increased diarrhea: 32/288 (11%); [underlined: Brehant, 2006 [16504893]]; - Esophagus injury: 10/2684 (0.4%)
| | [underlined: Fein, 2008 [18766417]]; - Vomiting: 13/74 (18.8%); [underlined: Mardani, 2009 [19016274]]; - Ability to vomit: 12/82 (14.6%); [underlined: Dalessio, 2005 [16137590]]; - Ileus: 1/257 (0.4%); - Small bowel perforation: 1/257 (0.4%); [underlined: Mehta, 2006 [17114017]]; - Inadvertent Esophageal injury: 2/91 (2.2%)
Infection/fever event rate20,79,134,138,153,171,174,180,182 | [underlined: Ruiz-Tovar, 2010 [19916741]]; - [underlined: Wound infection: 1/88 (1.1%)] | [underlined: Huttl, 2005 [16211438]]; - Wound infections: 9/1062 (0.85%); - Intraabdominal infections: 2/1062 (0.2%); [underlined: Jensen, 2009 [18855057]]; - Wound infection: 2/113 (1.8%); [underlined: Cowgill, 2007 [17879678]]; - Superficial wound infection: 2/239 (0.8%); [underlined: Dalessio, 2005 [16137590]]; - Urinary tract infection: 2/257 (0.8%); - Pneumonia: 1/257 (0.4%); [underlined: Anvari, 2006 [17227922]]; - Fever 2/52 (3.8%) | [underlined: Huttl,2005 [16211438]]; - Wound infections: 0/470 (0%); - Intraabdominal infections: 0/470 (0%) | [underlined: Rosenthal, 2006 [17243869]]; - Urinary tract infection: 3/186 (1.6%); [underlined: Wang, 2008 [18368318]]; - Pneumonia 2/33 (6.1%); [underlined: Brehant, 2006 [16504893]]; - Wound infection: 14/2684 (0.5%)
Dysphagia event rate18,20,70,72,73,78,80,83,84,142,146,150,153,173,176,177,179,182 | [underlined: Trullenque, 2005 [16004525]] 0/28 (0%) [underlined: Zacharoulis, 2006 [17024541]] 15/808 (1.9%) [underlined: Jensen, 2009 [18855057]] 5/113 (4.4%) | [underlined: Salminen, 2006 [16921296]] 97/439 (22.1%) [underlined: del Genio, 2007 [17426906]] 13/368 (3.5%) [underlined: Dallemagne, 2006 [16333553]] 11/49 (22.4%) [underlined: Trullenque, 2005 [16004525]] 1/75 (1.3%) [underlined: Fein, 2008 [18766417]] 22/74 (30.6%) [underlined: Pizza, 2007 [17278197]] 13/400 (3.3%) [underlined: Teixeria, 2009 [19453033]]; - Serious dysphagia: 6/143 (4.2%); [underlined: Kamolz, 2005 [15959712]] 21/178 (11.8%) [underlined: Mehta, 2006 [17114017]] 4/91 (4.4%) [underlined: Anvari, 2006 [17227922]] 4/52 (7.7%) | [underlined: Dallemagne, 2006 [16333553]] 5/20 (25.0%) [underlined: Fein, 2008 [18766417]] 7/25 (28.0%) [underlined: Zehetner, 2006 [16391962]]; - Mild dysphagia: 1/87 (2%) | [underlined: Pessaux, 2005 [16230543]] 68/1340 (5.1%) [underlined: Fumagalli, 2008 [18430108]] 25/259 (9.1%) [underlined: Oelschlager, 2008 [17970835]] 7/288 (2%) [underlined: Strate, 2008 [18027055]]; - Moderate to severe dysphagia: 27/200 (13.5%); [underlined: Wang, 2008 [18368318]]; - Dysphagia+vomiting: 1/33 (3.0%)
Bloating event rate20,67,70,72,73,78,84,133,142,146,150,177,179 | [underlined: Trullenque, 2005 [16004525]]; - Gas bloat: 0/28 (0%); - Meteorism: 0/28 (0%) | [underlined: Salminen, 2006 [16921296]]; - Bloating/flatulence: 320/441 (72.6%); [underlined: del Genio, 2007 [17426906]] 9/368 (2.4%) [underlined: Dallemagne, 2006 [16333553]]; - Abdominal bloating: 40/49 (81.6%); - Gas: 22/49 (44.9%); [underlined: Cai, 2008 [18942055]]; - Abdominal bloating: 14/48 (29%); [underlined: Trullenque, 2005 [16004525]]; - Gas bloat: 1/75 (1.3%); - Meteorism: 4/75 (5.3%); [underlined: Booth, 2008 [18076018]]; - Postprandial fullness: 37/59 (63%); [underlined: Fein, 2008 [18766417]]; - Bloating: 62/74 (84.9%); - Epigastric fullness 44/74: (60.3%); [underlined: Pizza, 2007 [17278197]]; - Bloating: 4/400 (1.0%); [underlined: Kamolz, 2005 [15959712]]; - Bloating 14/178 (7.9%); [underlined: Anvari, 2006 [17227922]]; - Postprandial bloating 7/52 (13.5%) | [underlined: Dallemagne, 2006 [16333553]]; - Abdominal bloating: 14/20 (70.0%); - Gas: 15/20 (75.0%); [underlined: Cai, 2008 [18942055]]; - Abdominal bloating: 19/41 (46%); [underlined: Fein, 2008 [18766417]]; - Bloating: 16/25 (64%); - Epigastric fullness: 15/25 (60%); [underlined: Booth, 2008 [18076018]]; - Postprandial fullness: 37/58 (64%) | [underlined: Pessaux, 2005 [16230543]]; - Gas bloat syndrome: 101/1340 (7.5%); [underlined: Oelschlager, 2008 [17970835]]; - Bloating: 27/288 (9%); [underlined: Strate, 2008 [18027055]]; - Gas bloating: 106/200 (53%)
Pain event rate20,72,74,79,133,146,179 | | [underlined: del Genio, 2007 [17426906]]; - Chest pain: 2/368 (0.5%); [underlined: Booth, 2008 [18076018]]; - Abdominal pain: 13/59 (22%); [underlined: Fein, 2008 [18766417]]; - Epigastric pain; 32/74 (43.8%); - Chest pain: 28/74 (38.4%); [underlined: Pizza, 2007 [17278197]]; - Chest pain: 0/400 (0%); [underlined: Anvari, 2006 [17227922]] Abdominal pain: 2/52 (3.8%) | [underlined: Booth, 2008 [18076018]]; - Abdominal pain: 15/58 (26%); [underlined: Fein, 2008 [18766417]]; - Epigastric pain: 13/25 (52%); - Chest pain: 12/25 (48%) | [underlined: Wijnhoven, 2008 [18071830]]; - Chest pain: 332/833 (39.9%)
Other78,83,84,134,145,150,174-177 | [underlined: Trullenque, 2005 [16004525]]; - Hindered vomiting and burping: 1/28 (3.6%); - Hiccup: 0/28 (0%); [underlined: Huttl, 2005 [16211438]]; - Injuries of the spleen: 4/1062 (0.4%); - Injuries of the pleura with thoracic drain: 5/1062 (0.5%); - Injuries of the pleura without drain: 19/1062 (1.8%); [underlined: Csendes, 2005 [16137596]]; - Conversions: 3/225 (1.3%); - Necrosis: 0/225 (0%); [underlined: Zacharoulis, 2006 [17024541]]; - Intrathoracic wrap migration: 11/808 (1.4%); [underlined: Salminen, 2006 [16921296]]; - Conversion: 10/468 (2.1%); - Difficulties with swallowing: 47/468 (10.0%) | [underlined: Trullenque, 2005 [16004525]]; - Hiccup: 1/75 (1.3%); [underlined: Manning, 2006 [16872031]]; - Conversion: 2/124 (2%); [underlined: Strate, 2008 [18027055]]; - Conversion: 6/100 (6%); [underlined: Teixeria, 2009 [19453033]]; - Conversion: 4/143 (2.7%) | | [underlined: Oelschlager, 2008 [17970835]]; - New or increased diarrhea: 32/288 (11%); [underlined: Brehant, 2006 [16504893]]; - Pneumothorax: 6/2684 (0.2%); - Esophagus injury: 10/2684 (0.4%); - Arterial hypertension: 6/2684 (0.2%); - Acute coronary syndrome: 5/2684 (0.2%); - Postoperative ileus: 7/2684 (0.3%); - Acute pancreatitis: 1/2684 (0.04%); - Subcutaneous emphysema: 3/2684 (0.1%); - Pulmonary embolism: 7/2684 (0.3%); - Pyrexia: 7/2684 (0.3%)
Other19,70,73,138,153,171,174,180,181 | [underlined: Jensen, 2009 [18855057]]; - Conversions: 0/113 (0%); - Readmission to hospital: 4/113 (3.5%); [underlined: Cowgill, 2007 [17879678]]; - Conversion: 35/239 (15%); - Dysrhythmia: 3/239 (1.3%); - Urinary retention: 3/239 (1.3%); - CO2 pneumothorax: 3/239 (1.3%); - Urinary tract infection: 1/239 (0.4%); - Fascial dehiscence: 1/239 (0.4%); - Intraabdominal abscess: 1/239 (0.4%); - Splenic laceration: 1/239 (0.4%); - Postoperative hemorrhage: 1/239 (0.4%); [underlined: Olberg, 2005 [15932167]]; - Ventral hernia: 2/158 (1.3%); - Port site hernia: 0/158 (0%); - Diaphragmatic hernia: 1/158 (0.6%); - Paraesophageal herniation: 0/158 (0%); - Slipped Nissen: 1/158 (0.6%); - Disrupted Nissen or Toupet: 0/158 (0%) | [underlined: Dallemagne, 2006 [16333553]]; - Conversions: 0/68 (0%); [underlined: Dalessio, 2005 [16137590]]; - Urinary retention: 5/257 (1.9%); - Uncomplicated CO2 pneumothorax: 4/257 (1.6%); - Atelectasis: 4/257 (1.6%); - Atrial fibrillation: 2/257 (0.8%); - Myocardial infarctions: 0/257 (0%); - Strokes: 0/257 (0%); - Pulmonary emboli: 0/257 (0%) | [underlined: Huttl, 2005 [16211438]]; - Injuries of the spleen: 4/470 (0.85%); - Injuries of the pleura with thoracic drain: 2/470 (0.4%); - Injuries of the pleura without drain: 3/470 (0.6%); [underlined: Dallemagne, 2006 [16333553]]; - Conversions: 0/32 (0%) | [underlined: Rosenthal, 2006 [17243869]]; - Neuropsychiatric: 2/186 (1.1%); - Cardiac: 1/186 (0.5%); - Endocrinological: 1/186 (0.5%); [underlined: Pessaux, 2005 [16230543],]; - Conversions: 112/1340 (8.4%); [underlined: Wang, 2008 [18368318]]; - Subcutaneous emphysema: 1/198 (0.5%); [underlined: Olberg, 2005 [15932167]]; - Ventral hernia: 0/215 (0%); - Port site hernia: 13/215 (6.0%); - Diaphragmatic hernia: 0/215 (0%); - Paraesophageal herniation: 9/215 (4.2%); - Slipped Nissen: 6/215 (2.8%); - Disrupted Nissen or Toupet: 3/215 (1.4%)
Other18,20,79,142 | [underlined: Ruiz-Tovar, 2010 [19916741]]; - [underlined: Splenic lacerations: 2/88 (2.3%)]; - [underlined: Evisceration: 1/88 (1.1%)] | [underlined: Kalmoz, 2005 [15959712]]; - Early satiety 11/178 (6.1%); - Hiccups 12/178 (6.7%); - Severe weight loss (>5Kg) 12/178 (6.7%); [underlined: Mehta, 2006 [17114017]]; - Wrap migration: 2/91 (2.2%); - Postoperative sequelae: 0/91 (0%); [underlined: Anvari, 2006 [17227922]]; - Dilation of the wrap 2/52 (3.8%); - Delayed oral intake 3/52 (5.8%); [underlined: Ruiz-Tovar, 2010 [19916741]]; - Conversions: 3/78 (4%)

#### Adverse Events Associated With Endoscopic Treatment

For endoscopic studies, we identified 13 studies published after the 2005 CER.87,89-91,94,97-99,101,105,183,184 Endoscopic treatment include EndoCinch, Stretta, or EsophyX. Intraoperative complications include dysphagia97,98 and bleeding.98,184 Complications occurring more than 30 days after endoscopic procedures include death,109 reoperation,90 bleeding,101 infection/fever,94,109 dysphagia,87,91,105 bloating87,91,105 and pain.87,91,109

##### Intra- and Perioperative Complications After Endoscopic Procedures

All-cause mortality rate was not reported for EndoCinch, Stretta, and EsophyX. Dysphagia event rate ranged from 0 to 4 percent for EsophyX.97,98 One study reported 11.1 percent of bleeding within 30 days after EndoCinch and another study reported 6 percent of bleeding for EsophyX.98,184 More detailed information about intra- and perioperative complications for endoscopic procedures can be found in Table 42.

Table 42 Intraoperative complications (and those occurring within 30 days) for endoscopic procedures

| Endoscopic
| Endocinch™ | Stretta™ | EsophyX
Mortality event rate | ND | ND | ND
Dysphagia event rate97,98 | | | [underlined: Cadiere, 2008 [18443855]] 3/86 (4%) [underlined: Cadiere, 2008 [18071818]] 0/17 (0%)
Bleeding event rate98,184 | [underlined: Mosler, 2008 [18629586]] 2/18 (11.1%) | | [underlined: Cadiere, 2008 [18443855]]; - Application site bleeding: 5/86 (6%)
Other event rate97-99,105 | | [underlined: Lutfi, 2005] [underlined: [15624052]]; - Transient gastroparesis: 1/77 (1.3%) | [underlined: Cadiere, 2008 [18443855]]; - Musculoskeletal pain: 8/86 (9%); - Perforation: 2/86 (2%); - Abdominal pain upper: 8/86 (9%); - Pharyngolaryngeal pain: 6/86 (7%); - Nausea: 6/86 (7%); - Epigastric pain: 4/86 (5%); - Pyrexia: 3/86 (4%); - Diarrhea: 2/86 (2%); - Vomiting: 2/86 (2%); [underlined: Repici, 2010 [19902310]]; - Hematemesis: 2/20 (10%); [underlined: Cadiere, 2008 [18071818]]; - Bloating: 3/17 (18%); - Diarrhea: 0/17 (0%); - Difficulty swallowing: 2/17 (12%); - Epigastric pain: 1/17 (6%); - Eructation: 6/17 (35%); - Fever: 0/17 (0%); - Flatulence: 1/17 (6%); - Globus: 0/17 (0%); - Hematemesis: 0/17 (0%); - Left shoulder pain: 0/17 (0%); - Nausea: 0/17 (0%); - Pharynx irritation: 3/17 (18%); - Vomiting: 1/17 (6%)

##### Complications Occurring More Than 30 Days After Endoscopic Procedures

There are no data on all-cause mortality for EndoCinch and EsophyX, and one study reported no death for Stretta.109 One study reported 30.4 percent of reoperation for EndoCinch.90 Dysphagia rate ranged from 14.3 to 50 percent for EndoCinch and 0 to 12.5 percent for Stretta.87,91,105,109 Bloating rate ranged from 10 to 19 percent and pain event rate ranged from 5 to 23.8 percent for EndoCinch.87,91 Mild postprocedure chest pain rate was 54.2 percent and abdominal pain was 8.3 percent for Stretta.109 More detailed information about complications occurring more than 30 days after endoscopic procedures can be found in Table 43.

Table 43 Complications occurring more than 30 days after endoscopic procedures

| Endoscopic
| Endocinch™ | Stretta™ | EsophyX
Mortality event rate109 | nd | [underlined: Aziz, 2010 [19730952]] 0/24 (0%) | nd
Re-operation event rate90 | [underlined: Domagk, 2006 [16542275]] 7/23 (30.4%)
Bleeding event rate91,101 | [underlined: Liao, 2008 [18318824]]; - Delayed bleeding with hematemesis: 1/21 (4.8%) | | [underlined: Demyttenaere, 2010 [19730949]] 2/26 (7.7%)
Infection/fever event rate94,109 | [underlined: Paulssen, 2008 [18938771]]; - Oesophageal fungal infections: 2/119 (1.6%) | [underlined: Aziz, 2010 [19730952]]; - Mild fever: 2/24 (8.3%); - Pneumonia: 1/24 (4.2%)
Dysphagia event rate87,91,105,109 | [underlined: Schwartz, 2007 [16763053]]; - Dysphagia <7 days: 10/20 (50%); [underlined: Liao, 2008 [18318824]]; - Minor dysphasia 3/21 (14.3%) | [underlined: Lutfi, 2005 [15624052]]; - Dysphagia: 0/77 (0%); Aziz, 2010 [19730952]; - Transient dysphagia: 3/24 (12.5%)
Bloating event rate87,91,105 | [underlined: Schwartz, 2007 [16763053]]; - Bloating: 2/20 (10%); [underlined: Liao, 2008 [18318824]]; - [underlined: Bloating 4/21 (19.0%)] | [underlined: Lutfi, 2005 [15624052]]; - Severe gas bloat: 0/77 (0%)
Pain event rate87,91,109 | [underlined: Schwartz, 2007 [16763053]]; - Abdominal pain: 1/20 (5%); [underlined: Liao, 2008 [18318824]]; - Abdominal pain: 5/21 (23.8%) | [underlined: Aziz, 2010 [19730952]]; - Mild postprocedure chest pain: 13/24 (54.2%); - Abdominal pain: 2/24 (8.3%)
Other event rate87,89,91,94,98,101,105,109 | [underlined: Schwartz, 2007 [16763053]]; - Sore throat: 8/20 (40%); - Chest soreness: 6/20 (30%); - Belching: 1/20 (5%); - Early satiety: 1/20 (5%); - Hiccups: 1/20 (5%); - Sedation-related: 0/20 (0%); [underlined: Paulssen, 2008 [18938771]]; - Suture removal due to difficulty in swallowing: 1/119 (1%); [underlined: Liao, 2008 [18318824]]; - Sore throat: 13/21 (61.9%); - Vomiting: 2/21 (9.5%) | [underlined: Lutfi, 2005 [15624052]]; - Stricture: 0/77 (0%); [underlined: Coron, 2008 [18616516]]; - Severe complication: 0/23 (0%)^a^; [underlined: Aziz, 2010 [19730952]]; - Transient nausea/vomiting: 3/24 (12.5%); - Pleural effusion: 1/24 (4.2%); - Mucosal lacerations: 2/24 (8.3%); - Prolonged gastroparesis: 2/24 (8.3%); - Perforation: 0/24 (0%) | [underlined: Cadiere, 2008 [18443855]]; - Abdominal pain upper: 1/86 (1%); - Nausea: 1/86 (1%); [underlined: Demyttenaere, 2010 [19730949]]; - Esophageal perforation: 0/26 (0%)

a No detailed information about complication

#### Adverse Events Reported in FDA/MAUDE (Manufacturer and User Facility Device Experience) Database

A total of 38 events were reported for the three devices between 2000 and 2010 (Table 44). Almost half of these adverse events required hospitalization (47 percent), while nearly a fifth (18 percent) required surgery. Four deaths were noted, all within the radiofrequency ablation therapy group. Bleeding requiring blood transfusions was observed in 3 patients. A list of the reported adverse events is compiled in a second table (Table 45).

Table 44 Devices and adverse events from the MAUDE database

Therapy | Device name | Manufacturer | Time Period | No. of Adverse events
Radiofrequency ablation | Stretta® | Curon Medical Inc., Fremont, CA Curon Medical Inc., Sunnyvale, CA | 2000-2007 | 29
Endoluminal Suture | EndoCinch® | CR BARD/BARD Endoscopic Technologies, Billerica, MA Davol INC. (Subsidiary of CR BARD), Warwick RI | 2001-2010 | 5
Endoluminal Suture | Esophyx® | Endogastric Solutions, Redmond, WA Redmond Inc., Redmond, WA | 2009-2010 | 4

Table 45 List of adverse events from the MAUDE database

Device | Adverse events
Stretta | 1. Death; 2. Device malfunction; 3. Gastrointestinal perforation; 4. Perioperative bloating; 5. Perioperative pain in stomach and abdomen; 6. Perioperative gas and belching; 7. Gastroparesis; 8. Cutaneous burn; 9. Perioperative chest pain; 10. Gastrointestinal injury; 11. Cardiac arrhythmia; 12. Pneumonia; 13. Pleural effusion; 14. Post operative infection; 15. Esophageal leak; 16. Esophageal necrosis; 17. Bleeding; 18. Esophageal ulcer
EndoCinch | 1. Bleeding; 2. Suture site ulcer; 3. Ulcer at incision site; 4. Operator error /device malfunction
Esophyx | 1. Device malfunction; 2. Infection and abscess