# Remaining Issues and Future Research Needs

- Longer term followup is necessary to determine the efficacy of laparoscopic fundoplication versus medical treatments. One available study reviewed reported 3-year interim data; that study is still ongoing.16
- Higher quality studies are necessary to determine the role and value of endoscopic procedures in the treatment of patients with GERD.
- Retrospective analyses exploring potential modifiers of treatment outcomes need to carefully consider confounders and perform appropriate adjustments.
- Comparative studies are needed to determine the optimal treatment(s) for patients who did not respond to medication.
- There is a lack of consensus among the clinical practitioners around the issue of selecting the best diagnostic method to use, and its timing, in identifying acid and non-acid reflux during symptomatic episodes. The role of newer methods like impedance monitoring need to be examined for their impact in the areas of diagnosis and treatment.
- There is a need to focus on less frequently reported outcomes like refractory esophageal and GERD-related extraesophageal symptoms, as well as different dosing regimens like twice daily usage.
- The potential necessity of life-long medical therapy raises the possibility of unidentified long-term safety issues. Therefore, a systematic monitoring of long-term safety data on PPIs should be put in place, as well as better baseline reporting of patient characteristics and potential confounders. Both could help ferret out any possible association between treatment and adverse events. Administrative databases can provide additional data in addressing long-term safety issues.
- Future studies on extraesophageal manifestations manifestation of GERD should target populations with reflux-triggered symptoms to assess the impact of treatment strategies. There is a need to develop tests or biomarkers that can correctly identify individuals with reflux-triggered symptoms.
- A systematic review of the literature examining potential drug interactions and adverse events associated with concomitant use of clopidogrel and PPIs is outside the scope of this update. In the absence of this information, we echo recent FDA statements urging healthcare providers and patients to carefully balance risks with indications of co-therapy.