# References

1 Ip S, Bonis P, Tatsioni A, et al. Comparative Effectiveness of Management Strategies for Gastroesophageal Reflux Disease, Comparative Effectiveness Review No. 1. Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No 290-02-0022. Rockville, MD. Agency for Healthcare Research and Quality. December. 2005. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm.
2 Vakil N, van Zanten SV, Kahrilas P, et al. The Montreal definition and classification of gastroesophageal reflux disease: a global evidence-based consensus. Am J Gastroenterol. 2006;101(8):1900-1920. [pmid: 16928254].
3 Brook RA, Wahlqvist P, Kleinman NL, et al. Cost of gastro-oesophageal reflux disease to the employer: a perspective from the United States. Aliment Pharmacol Ther. 2007;26(6):889-898. [pmid: 17767473].
4 Forgacs I, Loganayagam A. Overprescribing proton pump inhibitors. BMJ. 2008;336(7634):2-3. [pmid: 18174564].
5 Ip S, Tatsioni A, Conant A, et al. Predictors of clinical outcomes following fundoplication for gastroesophageal reflux disease remain insufficiently defined: a systematic review. Am J Gastroenterol. 2009;104(3):752-758. [pmid: 19262527].
6 U.S.Food and Drug Administration. http:,www.fda.gov/cdrh/maude.html (http://www.fda.gov/cdrh/maude.html). Manufacturer and User Facility Device experience Database - (MAUDE). Internet website. 2005.
7 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews. Version 1.0. Available at http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftmethodsGuide.pdf. 2007.
8 Altman DG, Schulz KF, Moher D, et al. The revised CONSORT statement for reporting randomized trials: explanation and elaboration. [see comment]. [Review] [204 refs]. Annals of Internal Medicine. 2001;134(8):663-694. [pmid: 11304107].
9 Moher D, Schulz KF, Altman D, CONSORT GROUP (Consolidated Standards of Reporting Trials). The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. [see comment]. [Review] [30 refs]. JAMA. 2001;285(15):1987-1991. 2001. [pmid: 11308435].
10 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
11 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. [see comment]. [Review] [49 refs]. Lancet. 1999;354(9193):1896-1900. [pmid: 10584742].
12 Gibson PG, Henry R, Coughlan JJ. Gastro-oesophageal reflux treatment for asthma in adults and children [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;(3).
13 Grant AM, Wileman SM, Ramsay CR, et al. Minimal access surgery compared with medical management for chronic gastro-oesophageal reflux disease: UK collaborative randomised trial. [see comment]. BMJ. 2008;337:a2664. [pmid: 19074946].
14 Attwood SE, Lundell L, Hatlebakk JG, et al. Medical or surgical management of GERD patients with Barrett's esophagus: the LOTUS trial 3-year experience. J Gastrointest Surg. 2008;12(10):1646-1654. [pmid: 18709511].
15 Lundell L, Miettinen P, Myrvold HE, et al. Seven-year follow-up of a randomized clinical trial comparing proton-pump inhibition with surgical therapy for reflux oesophagitis. [see comment]. British Journal of Surgery. 2007;94(2):198-203. [pmid: 17256807].
16 Lundell L, Attwood S, Ell C, et al. Comparing laparoscopic antireflux surgery with esomeprazole in the management of patients with chronic gastro-oesophageal reflux disease: a 3-year interim analysis of the LOTUS trial. Gut. 2008;57(9):1207-1213. [pmid: 18469091].
17 Lundell L, Miettinen P, Myrvold HE, et al. Comparison of outcomes twelve years after antireflux surgery or omeprazole maintenance therapy for reflux esophagitis. Clin Gastroenterol Hepatol. 2009;7(12):1292-1298. [pmid: 19490952].
18 Mehta S, Bennett J, Mahon D, et al. Prospective trial of laparoscopic nissen fundoplication versus proton pump inhibitor therapy for gastroesophageal reflux disease: Seven-year follow-up. Journal of Gastrointestinal Surgery. 2006;10(9):1312-1316. discussion 1316-1317. [pmid: 17114017].
19 Olberg P, Johannessen R, Johnsen G, et al. Long-term outcome of surgically and medically treated patients with gastroesophageal reflux disease: a matched-pair follow-up study. Scandinavian Journal of Gastroenterology. 2005;40(3):264-274. [pmid: 15932167].
20 Anvari M, Allen C, Marshall J, et al. A randomized controlled trial of laparoscopic nissen fundoplication versus proton pump inhibitors for treatment of patients with chronic gastroesophageal reflux disease: One-year follow-up. Surgical Innovation. 2006;13(4):238-249. [pmid: 17227922].
21 Mahon D, Rhodes M, Decadt B, et al. Randomized clinical trial of laparoscopic Nissen fundoplication compared with proton-pump inhibitors for treatment of chronic gastro-oesophageal reflux. [see comment]. British Journal of Surgery. 2005;92(6):695-699. [pmid: 15898130].
22 Mahmood Z, Byrne PJ, McMahon BP, et al. Comparison of transesophageal endoscopic plication (TEP) with laparoscopic Nissen fundoplication (LNF) in the treatment of uncomplicated reflux disease. [see comment]. American Journal of Gastroenterology. 2006;101(3):431-436. [pmid: 16542276].
23 Norman HA, Bergheim R, Fagertun H, et al. A randomised prospective study comparing the effectiveness of esomeprazole treatment strategies in clinical practice for 6 months in the management of patients with symptoms of gastroesophageal reflux disease. [erratum appears in Int J Clin Pract 2005 Nov;59(11):1371]. International Journal of Clinical Practice. 2005;59(6):665-671. [pmid: 15924594].
24 Hansen AN, Bergheim R, Fagertun H, et al. Long-term management of patients with symptoms of gastro-oesophageal reflux disease—a Norwegian randomised prospective study comparing the effects of esomeprazole and ranitidine treatment strategies on health-related quality of life in a general practitioners setting. International Journal of Clinical Practice. 2006;60(1):15-22. [pmid: 16409423].
25 Wada T, Sasaki M, Kataoka H, et al. Efficacy of famotidine and omeprazole in healing symptoms of non-erosive gastrooesophageal reflux disease: randomized-controlled study of gastro-oesophageal reflux disease. Alimentary Pharmacology & Therapeutics. 2005;21(Suppl 2):2-9. [pmid: 15943840].
26 Fujiwara Y, Higuchi K, Nebiki H, et al. Famotidine vs. omeprazole: a prospective randomized multicentre trial to determine efficacy in non-erosive gastro-oesophageal reflux disease. Alimentary Pharmacology & Therapeutics. 2005;21(Suppl 2):10-18. [pmid: 15943841].
27 Peura DA, Freston JW, Haber MM, et al. Lansoprazole for long-term maintenance therapy of erosive esophagitis: double-blind comparison with ranitidine. Digestive Diseases & Sciences. 2009;54(5):955-963. [pmid: 18726153].
28 Goh KL, Benamouzig R, Sander P, et al. Efficacy of pantoprazole 20 mg daily compared with esomeprazole 20 mg daily in the maintenance of healed gastroesophageal reflux disease: a randomized, double-blind comparative trial - the EMANCIPATE study. [see comment]. European Journal of Gastroenterology & Hepatology. 2007;(3):205-211. [pmid: 17301646].
29 Labenz J, Armstrong D, Zetterstrand S, et al. Clinical trial: factors associated with resolution of heartburn in patients with reflux oesophagitis--results from the EXPO study. [see comment]. Alimentary Pharmacology & Therapeutics. 2009;29(9):959-966. [pmid: 19222417].
30 Glatzel D, bdel-Qader M, Gatz G, et al. Pantoprazole 40 mg is as effective as esomeprazole 40 mg to relieve symptoms of gastroesophageal reflux disease after 4 weeks of treatment and superior regarding the prevention of symptomatic relapse. Digestion. 2007;75(Suppl 1):69-78. [pmid: 17489035].
31 Bardhan KD, Achim A, Riddermann T, Pfaffenberger B. A clinical trial comparing pantoprazole and esomeprazole to explore the concept of achieving ‘complete remission’ in gastro-oesophageal reflux disease. Alimentary Pharmacology & Therapeutics. 2007;25(12):1461-1469. [pmid: 17539986].
32 Scholten T, Teutsch I, Bohuschke M, et al. Pantoprazole on-demand effectively treats symptoms in patients with gastrooesophageal reflux disease. Clinical Drug Investigation. 2007;27(4):287-296. [pmid: 17358101].
33 Vcev A, Begic I, Ostojic R, et al. Esomeprazole versus pantoprazole for healing erosive oesophagitis. Collegium Antropologicum. 2006;30(3):519-522. [pmid: 17058517].
34 Labenz J, Armstrong D, Zetterstrand S, et al. Clinical trial: factors associated with freedom from relapse of heartburn in patients with healed reflux oesophagitis— results from the maintenance phase of the EXPO study. Alimentary Pharmacology & Therapeutics. 2009;29(11):1165-1171. [pmid: 19298581].
35 Fass R, Sontag SJ, Traxler B, et al. Treatment of patients with persistent heartburn symptoms: a double-blind, randomized trial. Clinical Gastroenterology & Hepatology. 2006;4(1):50-56. [pmid: 16431305].
36 Eggleston A, Katelaris PH, Nandurkar S, et al. Clinical trial: the treatment of gastrooesophageal reflux disease in primary care--prospective randomized comparison of rabeprazole 20 mg with esomeprazole 20 and 40 mg. Alimentary Pharmacology & Therapeutics. 2009;29(9):967-978. [pmid: 19210493].
37 Fock KM, Teo EK, Ang TL, et al. Rabeprazole vs esomeprazole in non-erosive gastro-esophageal reflux disease: a randomized, double-blind study in urban Asia. World Journal of Gastroenterology. 2005;11(20):3091-3098. [pmid: 15918196].
38 Giannini EG, Zentilin P, Dulbecco P, et al. Management strategy for patients with gastroesophageal reflux disease: a comparison between empirical treatment with esomeprazole and endoscopy-oriented treatment. [see comment]. American Journal of Gastroenterology. 2008;103(2):267-275. [pmid: 18289194].
39 Johnson DA, Orr WC, Crawley JA, et al. Effect of esomeprazole on nighttime heartburn and sleep quality in patients with GERD: a randomized, placebo-controlled trial. American Journal of Gastroenterology. 2005;100(9):1914-1922. [pmid: 16128933].
40 Katz PO, Ginsberg GG, Hoyle PE, et al. Relationship between intragastric acid control and healing status in the treatment of moderate to severe erosive oesophagitis. Alimentary Pharmacology & Therapeutics. 2007;25(5):617-628. [pmid: 17305763].
41 Vasiliadis KV, Viazis N, Vlachogiannakos J, et al. Efficacy of three different dosages of esomeprazole in the long-term management of reflux disease: a prospective, randomized study, using the wireless Bravo pH system. American Journal of Gastroenterology. 2010;105(2):308-313. [pmid: 19809412].
42 Mine S, Iida T, Tabata T, et al. Management of symptoms in step-down therapy of gastroesophageal reflux disease. Journal of Gastroenterology & Hepatology. 2005;(9):1365-1370. [pmid: 16105122].
43 Fass R, Chey WD, Zakko SF, et al. Clinical trial: the effects of the proton pump inhibitor dexlansoprazole MR on daytime and nighttime heartburn in patients with non-erosive reflux disease. Alimentary Pharmacology & Therapeutics. 2009;29(12):1261-1272. [pmid: 19392864].
44 Metz DC, H C, P M, L. Clinical trial: Dexlansoprazole MR, a proton pump inhibitor with dual delayed-release technology, effectively controls symptoms and prevents relapse in patients with healed erosive oesophagitis. Alimentary Pharmacology and Therapeutics. 2009;(7):742-754. [pmid: 19210298].
45 Howden CW, Larsen LM, Perez MC, et al. Clinical trial: efficacy and safety of dexlansoprazole MR 60 and 90 mg in healed erosive oesophagitis - maintenance of healing and symptom relief. Alimentary Pharmacology & Therapeutics. 2009;30(9):895-907. [pmid: 19681809].
46 Pai VG, Pai NV, Thacker HP, et al. Comparative clinical trial of S-pantoprazole versus racemic pantoprazole in the treatment of gastro-esophageal reflux disease. World Journal of Gastroenterology. 2006;12(37):6017-6020. [pmid: 17009401].
47 Scholten T, Dekkers CP, Schutze K, et al. On-demand therapy with pantoprazole 20 mg as effective long-term management of reflux disease in patients with mild GERD: the ORION trial. Digestion. 2005;72(2-3):76-85. [pmid: 16113546].
48 Chen WY, Chang WL, Tsai YC, et al. Double-dosed pantoprazole accelerates the sustained symptomatic response in overweight and obese patients with reflux esophagitis in Los Angeles grades A and B 130. American Journal of Gastroenterology. 2010;105(5):1046-1052. [pmid: 19904250].
49 Sjostedt S, Befrits R, Sylvan A, et al. Daily treatment with esomeprazole is superior to that taken on-demand for maintenance of healed erosive oesophagitis. Alimentary Pharmacology & Therapeutics. 2005;22(3):183-191. [pmid: 16091055].
50 Szucs T. Cost analysis of long-term treatment of patients with symptomatic gastroesophageal reflux disease (GERD) with esomeprazole on-demand treatment or esomeprazole continuous treatment: An open, randomized, multicenter study in Switzerland. Value in Health. 2009;(2):273-281. [pmid: 18783388].
51 Pace F, Negrini C, Wiklund I, et al. Quality of life in acute and maintenance treatment of non-erosive and mild erosive gastro-oesophageal reflux disease. Alimentary Pharmacology & Therapeutics. 2005;22(4):349-356. [pmid: 16098002].
52 Morgan DG, O'Mahony MF, O'Mahony WF, et al. Maintenance treatment of gastroesophageal reflux disease: an evaluation of continuous and on-demand therapy with rabeprazole 20 mg. Canadian Journal of Gastroenterology. 2007;21(12):820-826. [pmid: 18080054].
53 Bour B, Staub JL, Chousterman M, et al. Long-term treatment of gastro-oesophageal reflux disease patients with frequent symptomatic relapses using rabeprazole: on-demand treatment compared with continuous treatment. Alimentary Pharmacology & Therapeutics. 2005;21(7):805-812. [pmid: 15801915].
54 Cibor D, Ciecko-Michalska I, Owczarek D, et al. Optimal maintenance therapy in patients with non-erosive reflux disease reporting mild reflux symptoms—a pilot study. Advances in Medical Sciences. 2006;51:336-339. [pmid: 17357336].
55 Lightdale CJ, Schmitt C, Hwang C, et al. A multicenter, randomized, double-blind, 8-week comparative trial of low-dose esomeprazole (20 mg) and standard-dose omeprazole (20 mg) in patients with erosive esophagitis. [erratum appears in Dig Dis Sci 2006 May;51(5):851 Note: dosage error in text]. Digestive Diseases & Sciences. 2006;51(5):852-857. [pmid: 16773434].
56 Pilotto A, Franceschi M, Leandro G, et al. Comparison of four proton pump inhibitors for the short-term treatment of esophagitis in elderly patients. World Journal of Gastroenterology. 2007;13(33):4467-4472. [pmid: 17724802].
57 Zheng RN. Comparative study of omeprazole, lansoprazole, pantoprazole and esomeprazole for symptom relief in patients with reflux esophagitis. World Journal of Gastroenterology. 2009;15(8):990. [pmid: 19248200].
58 Pace F, Annese V, Prada A, et al. Rabeprazole is equivalent to omeprazole in the treatment of erosive gastro-oesophageal reflux disease. A randomised, double-blind, comparative study of rabeprazole and omeprazole 20 mg in acute treatment of reflux oesophagitis, followed by a maintenance open-label, low-dose therapy with rabeprazole. Digestive & Liver Disease. 2005;37(10):741-750. [pmid: 16024305].
59 Tepes B, Stabuc B, Kocijancic B, et al. Maintenance therapy of gastroesophageal reflux disease patients with omeprazole. Hepato-Gastroenterology. Feb. 2009;56(89):67-74. [pmid: 19453031].
60 Chen CY, Lu CL, Luo JC, et al. Esomeprazole tablet vs omeprazole capsule in treating erosive esophagitis. World Journal of Gastroenterology. 2005;11(20):3112-3117. [pmid: 15918199].
61 Devault KR, Johanson JF, Johnson DA, et al. Maintenance of healed erosive esophagitis: a randomized six-month comparison of esomeprazole twenty milligrams with lansoprazole fifteen milligrams. Clinical Gastroenterology & Hepatology. 2006;4(7):852-859. [pmid: 16682260].
62 Schmitt C, Lightdale CJ, Hwang C, et al. A multicenter, randomized, double-blind, 8-week comparative trial of standard doses of esomeprazole (40 mg) and omeprazole (20 mg) for the treatment of erosive esophagitis. Digestive Diseases & Sciences. 2006;51(5):844-850. [pmid: 16642422].
63 Svedlund J, Sjodin I, Dotevall G. GSRS—a clinical rating scale for gastrointestinal symptoms in patients with irritable bowel syndrome and peptic ulcer disease. Dig Dis Sci. 1988;33(2):129-134. [pmid: 3123181].
64 Kovacs TO, Lee CQ, Chiu YL, et al. Intravenous and oral lansoprazole are equivalent in suppressing stimulated acid output in patient volunteers with erosive oesophagitis. Aliment Pharmacol Ther. 2004;20(8):883-889. [pmid: 15479360].
65 Shaw JM, Bornman PC, Callanan MD, et al. Long-term outcome of laparoscopic Nissen and laparoscopic Toupet fundoplication for gastroesophageal reflux disease: a prospective, randomized trial. Surgical Endoscopy. 2010;24(4):924-932. [pmid: 19789920].
66 Nijjar RS, Watson DI, Jamieson GG, et al. Five-year follow-up of a multicenter, double-blind randomized clinical trial of laparoscopic Nissen vs anterior 90 degrees partial fundoplication 58. Archives of Surgery. 2010;145(6):552-557. [pmid: 20566975].
67 Cai W, Watson DI, Lally CJ, et al. Ten-year clinical outcome of a prospective randomized clinical trial of laparoscopic Nissen versus anterior 180(degrees) partial fundoplication. British Journal of Surgery. 2008;95(12):1501-1505. [pmid: 18942055].
68 Mardani J. Ten-year results of a randomized clinical trial of laparoscopic total fundoplication with or without division of the short gastric vessels. The British journal of surgery. 2009;(1):61-65. [pmid: 19016274].
69 Yang H, Watson DI, Lally CJ, et al. Randomized trial of division versus nondivision of the short gastric vessels during laparoscopic Nissen fundoplication: 10-year outcomes. Annals of Surgery. 2008;247(1):38-42. [pmid: 18156921].
70 Dallemagne B, Weerts J, Markiewicz S, et al. Clinical results of laparoscopic fundoplication at ten years after surgery. Surgical Endoscopy. 2006;(1):159-165. [pmid: 16333553].
71 Hafez J, Wrba F, Lenglinger J, et al. Fundoplication for gastroesophageal reflux and factors associated with the outcome 6 to 10 years after the operation: multivariate analysis of prognostic factors using the propensity score. Surgical Endoscopy. 2008;22(8):1763-1768. [pmid: 18449599].
72 Fein M, Bueter M, Thalheimer A, et al. Ten-year outcome of laparoscopic antireflux surgery. Journal of Gastrointestinal Surgery. 2008;12(11):1893-1899. [pmid: 18766417].
73 Pessaux P, Arnaud JP, Delattre JF, et al. Laparoscopic antireflux surgery: five-year results and beyond in 1340 patients. Archives of Surgery. 2005;140(10):946-951. [pmid: 16230543].
74 Wijnhoven BP, Lally CJ, Kelly JJ, et al. Use of antireflux medication after antireflux surgery. Journal of Gastrointestinal Surgery. 2008;12(3):510-517. [pmid: 18071830].
75 Draaisma WA, Rijnhart-De Jong HG, Broeders IA, et al. Five-year subjective and objective results of laparoscopic and conventional Nissen fundoplication: a randomized trial. Annals of Surgery. 2006;244(1):34-41. [pmid: 16794387].
76 Broeders JA, Rijnhart-De Jong HG, Draaisma WA, et al. Ten-year outcome of laparoscopic and conventional nissen fundoplication: randomized clinical trial. Annals of Surgery. 2009;250(5):698-706. [pmid: 19801931].
77 Salminen PT, Hiekkanen HI, Rantala AP, et al. Comparison of long-term outcome of laparoscopic and conventional nissen fundoplication: a prospective randomized study with an 11-year follow-up. Annals of Surgery. 2007;246(2):201-206. [pmid: 17667497].
78 Trullenque JR, Torres ST, Marti ME, et al. Surgery for gastroesophageal reflux disease: a comparative study between the open and laparoscopic approaches. Revista Espanola de Enfermedades Digestivas. 2005;97(5):328-337. [pmid: 16004525].
79 Ruiz-Tovar J, ez-Tabernilla M, Chames A, et al. Clinical outcome at 10 years after laparoscopic versus open Nissen fundoplication 43. Journal of Laparoendoscopic & Advanced Surgical Techniques. Part. 2010;(1):21-23. [pmid: 19916741].
80 Zehetner J, Holzinger F, Breuhahn T, et al. Five-year results of laparoscopic Toupet fundoplication as the primary surgical repair in GERD patients: is it durable?. Surgical Endoscopy. 2006;(2):220-225. [pmid: 16391962].
81 Rice S, Watson DI, Lally CJ, et al. Laparoscopic anterior 180 degrees partial fundoplication: five-year results and beyond. Archives of Surgery. 2006;141(3):271-275. [pmid: 16549692].
82 Biertho L, Sebajang H, Allen C, et al. Does laparoscopic Nissen fundoplication lead to chronic gastrointestinal dysfunction?. Surgical Endoscopy. 2006;(9):1360-1363. [pmid: 16823657].
83 Teixeira JP, Mosquera V, Flores A. Long-term outcomes of quality of life after laparoscopic Nissen fundoplication. Hepato– Gastroenterology. Feb. 2009;56(89):80-84. [pmid: 19453033].
84 Oelschlager BK, Quiroga E, Parra JD, et al. Long-term outcomes after laparoscopic antireflux surgery. [see comment]. American Journal of Gastroenterology. 2008;103(2):280-287. quiz 288. [pmid: 17970835].
85 Broeders JA, Draaisma WA, Bredenoord AJ, et al. Long-term outcome of Nissen fundoplication in non-erosive and erosive gastro-oesophageal reflux disease. British Journal of Surgery. 2010;97(6):845-852. [pmid: 20473997].
86 Mardani J, Lundell L, Lonroth H, et al. Ten-year results of a randomized clinical trial of laparoscopic total fundoplication with or without division of the short gastric vessels. British Journal of Surgery. 2009;96(1):61-65. [pmid: 19016274].
87 Schwartz MP, Wellink H, Gooszen HG, et al. Endoscopic gastroplication for the treatment of gastro-oesophageal reflux disease: a randomised, sham-controlled trial. [see comment]. Gut. 2007;56(1):20-28. [pmid: 16763053].
88 Montgomery M, Hakanson B, Ljungqvist O, et al. Twelve months' follow-up after treatment with the EndoCinch endoscopic technique for gastro-oesophageal reflux disease: a randomized, placebo-controlled study. Scandinavian Journal of Gastroenterology. 2006;41(12):1382-1389. [pmid: 17101568].
89 Coron E, Sebille V, Cadiot G, et al. Clinical trial: Radiofrequency energy delivery in proton pump inhibitor-dependent gastrooesophageal reflux disease patients. Alimentary Pharmacology & Therapeutics. 2008;28(9):1147-1158. [pmid: 18616516].
90 Domagk D, Menzel J, Seidel M, et al. Endoluminal gastroplasty (EndoCinch) versus endoscopic polymer implantation (Enteryx) for treatment of gastroesophageal reflux disease: 6-month results of a prospective, randomized trial. [see comment]. American Journal of Gastroenterology. 2006;101(3):422-430. [pmid: 16542275].
91 Liao CC, Lee CL, Lin BR, et al. Endoluminal gastroplication for the treatment of gastroesophageal reflux disease: a 2-year prospective pilot study from Taiwan. Journal of Gastroenterology & Hepatology. 2008;23(3):398-405. [pmid: 18318824].
92 Liu JJ, Di SV, Ookubo R, et al. Endoscopic treatment of gastroesophageal reflux disease: effect of gender on clinical outcome. Scandinavian Journal of Gastroenterology. 2006;41(2):144-148. [pmid: 16484118].
93 Ozawa S, Kumai K, Higuchi K, et al. Short-term and long-term outcome of endoluminal gastroplication for the treatment of GERD: the first multicenter trial in Japan. Journal of Gastroenterology. 2009;44(7):675-684. [pmid: 19440812].
94 Paulssen EJ, Lindsetmo RO. Long-term outcome of endoluminal gastroplication in the treatment of gastro-oesophageal reflux disease: effect of a second procedure. Scandinavian Journal of Gastroenterology. 2008;43(1):5-12. [pmid: 18938771].
95 Schiefke I, Zabel-Langhennig A, Neumann S, et al. Long term failure of endoscopic gastroplication (EndoCinch). [see comment]. Gut. 2005;54(6):752-758. [pmid: 15888777].
96 Cadiere GB, Van SN, Graves JE, et al. Two-year results of a feasibility study on antireflux transoral incisionless fundoplication using EsophyX. Surgical Endoscopy. 2009;23(5):957-964. [pmid: 19288158].
97 Cadiere GB, Rajan A, Germay O, et al. Endoluminal fundoplication by a transoral device for the treatment of GERD: A feasibility study. Surgical Endoscopy. 2008;22(2):333-342. [pmid: 18071818].
98 Cadiere GB, Buset M, Muls V, et al. Antireflux transoral incisionless fundoplication using EsophyX: 12-month results of a prospective multicenter study. World J Surg. 2008;32(8):1676-1688. [pmid: 18443855].
99 Repici A, Fumagalli U, Malesci A, et al. Endoluminal fundoplication (ELF) for GERD using EsophyX: a 12-month follow-up in a single-center experience. J Gastrointest Surg. 2010;14(1):1-6. [pmid: 19902310].
100 Testoni PA, Corsetti M, Di PS, et al. Effect of transoral incisionless fundoplication on symptoms, PPI use, and ph-impedance refluxes of GERD patients. World J Surg. 2010;34(4):750-757. [pmid: 20091308].
101 Demyttenaere SV, Bergman S, Pham T, et al. Transoral incisionless fundoplication for gastroesophageal reflux disease in an unselected patient population. Surg Endosc. 2010;24(4):854-858. [pmid: 19730949].
102 Cipolletta L, Rotondano G, Dughera L, et al. Delivery of radiofrequency energy to the gastroesophageal junction (Stretta procedure) for the treatment of gastroesophageal reflux disease. Surgical Endoscopy. 2005;(6):849-853. [pmid: 15868272].
103 Dundon JM, Davis SS, Hazey JW, et al. Radiofrequency energy delivery to the lower esophageal sphincter (Stretta procedure) does not provide long-term symptom control. Surgical Innovation. 2008;15(4):297-301. [pmid: 18829607].
104 Jeansonne LO, White BC, Nguyen V, et al. Endoluminal full-thickness plication and radiofrequency treatments for GERD: an outcomes comparison. Archives of Surgery. 2009;144(1):19-24. discussion 24. [pmid: 19153320].
105 Lutfi RE, Torquati A, Kaiser J, et al. Three year's experience with the Stretta procedure: did it really make a difference?. Surgical Endoscopy. 2005;(2):289-295. [pmid: 15624052].
106 Meier PN, Nietzschmann T, Akin I, et al. Improvement of objective GERD parameters after radiofrequency energy delivery: a European study. Scandinavian Journal of Gastroenterology. 2007;42(8):911-916. [pmid: 17613919].
107 Noar MD, Lotfi-Emran S. Sustained improvement in symptoms of GERD and antisecretory drug use: 4-year follow-up of the Stretta procedure. [see comment]. Gastrointestinal Endoscopy. 2007;65(3):367-372. [pmid: 17321232].
108 Reymunde A, Santiago N. Long-term results of radiofrequency energy delivery for the treatment of GERD: sustained improvements in symptoms, quality of life, and drug use at 4-year follow-up. [see comment]. Gastrointestinal Endoscopy. 2007;65(3):361-366. [pmid: 17321231].
109 Aziz AM, El-Khayat HR, Sadek A, et al. A prospective randomized trial of sham, single-dose Stretta, and double-dose Stretta for the treatment of gastroesophageal reflux disease. Surgical Endoscopy. 2010;24(4):818-825. [pmid: 19730952].
110 Chang AB, Lasserson TJ, Gaffney J, et al. Gastro-oesophageal reflux treatment for prolonged non-specific cough in children and adults [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;(3).
111 Hopkins C, Yousaf U, Pedersen M. Acid reflux treatment for hoarseness [Systematic Review]. Cochrane Database of Systematic Reviews. 2009;(3).
112 Hungin AP, Raghunath AS, Wiklund I. Beyond heartburn: a systematic review of the extra-oesophageal spectrum of reflux-induced disease. [Review] [138 refs]. Family Practice. 2005;22(6):591-603. [pmid: 16024554].
113 Iqbal M, Batch AJ, Spychal RT, et al. Outcome of surgical fundoplication for extraesophageal (atypical) manifestations of gastroesophageal reflux disease in adults: a systematic review. [Review] [44 refs]. Journal of Laparoendoscopic & Advanced Surgical Techniques Part A. 2008;18(6):789-796. [pmid: 19105666].
114 dos Santos LH, Ribeiro IO, Sanchez PG, et al. Evaluation of pantoprazol treatment response of patients with asthma and gastroesophageal reflux: a randomized prospective double-blind placebo-controlled study. [see comment]. Jornal Brasileiro De Pneumologia: Publicacao Oficial Da Sociedade Brasileira De Pneumologia E Tisilogia. 2007;33(2):119-127. [pmid: 17724529].
115 Jiang SP, Liang RY, Zeng ZY, et al. Effects of antireflux treatment on bronchial hyper-responsiveness and lung function in asthmatic patients with gastroesophageal reflux disease. World Journal of Gastroenterology. 2003;9(5):1123-1125. [pmid: 12717871].
116 Kiljander TO, Harding SM, Field SK, et al. Effects of esomeprazole 40 mg twice daily on asthma: a randomized placebo-controlled trial. American Journal of Respiratory & Critical Care Medicine. 2006;173(10):1091-1097. [pmid: 16357331].
117 Littner MR, Leung FW, Ballard ED, et al. Effects of 24 weeks of lansoprazole therapy on asthma symptoms, exacerbations, quality of life, and pulmonary function in adult asthmatic patients with acid reflux symptoms. [see comment]. Chest. 2005;128(3):1128-1135. [pmid: 16162697].
118 Peterson KA, Samuelson WM, Ryujin DT, et al. The role of gastroesophageal reflux in exercise-triggered asthma: a randomized controlled trial. Digestive Diseases & Sciences. 2009;54(3):564-571. [pmid: 18688720].
119 Sharma B, Sharma M, Daga MK, et al. Effect of omeprazole and domperidone on adult asthmatics with gastroesophageal reflux. World Journal of Gastroenterology. 2007;13(11):1706-1710. [pmid: 17461474].
120 Shimizu Y, Dobashi K, Kobayashi S, et al. A proton pump inhibitor, lansoprazole, ameliorates asthma symptoms in asthmatic patients with gastroesophageal reflux disease. Tohoku Journal of Experimental Medicine. 2006;209(3):181-189. [pmid: 16778364].
121 Sontag SJ, O'Connell S, Khandelwal S, et al. Asthmatics with gastroesophageal reflux: long term results of a randomized trial of medical and surgical antireflux therapies. [see comment]. American Journal of Gastroenterology. 2003;98(5):987-999. [pmid: 12809818].
122 Kiljander TO, Junghard O, Beckman O, et al. Effect of esomeprazole 40 mg once or twice daily on asthma: a randomized, placebo-controlled study. American Journal of Respiratory & Critical Care Medicine. 2010;181(10):1042-1048. [pmid: 20110554].
123 Devault KR, Morgenstern DM, Lynn RB, et al. Effect of pantoprazole in older patients with erosive esophagitis. Diseases of the Esophagus. 2007;(5):411-415. [pmid: 17760655].
124 Xirouchakis E, Kamberoglou D, Kalos D, et al. The effect of gastroesophageal flap valve appearance on the management of patients with symptoms of gastroesophageal reflux disease. Digestive Diseases & Sciences. 2009;54(2):328-332. [pmid: 18600453].
125 Sheu BS, Cheng HC, Chang WL, et al. The impact of body mass index on the application of on-demand therapy for Los Angeles grades A and B reflux esophagitis. American Journal of Gastroenterology. 2007;102(11):2387-2394. [pmid: 17850409].
126 Nocon M, Labenz J, Jaspersen D, et al. Long-term treatment of patients with gastrooesophageal reflux disease in routine care -results from the ProGERD study. Alimentary Pharmacology & Therapeutics. 2007;25(6):715-22. [pmid: 17311605].
127 Malfertheiner P, Lind T, Willich S, et al. Prognostic influence of Barrett's oesophagus and Helicobacter pylori infection on healing of erosive gastro-oesophageal reflux disease (GORD) and symptom resolution in nonerosive GORD: report from the ProGORD study. [see comment]. Gut. 2005;54(6):746-751. 2005. [pmid: 15888776].
128 Calleja JL, Suarez M, De Tejada AH, et al. Helicobacter pylori infection in patients with erosive esophagitis is associated with rapid heartburn relief and lack of relapse after treatment with pantoprazole. Digestive Diseases & Sciences. 2005;50(3):432-439. [pmid: 15810621].
129 Sheu BS, Chang WL, Cheng HC, et al. Body mass index can determine the healing of reflux esophagitis with Los Angeles Grades C and D by esomeprazole. American Journal of Gastroenterology. 2008;103(9):2209-2214. [pmid: 18702650].
130 Schmitt C, Lightdale CJ, Hwang C, et al. A multicenter, randomized, double-blind, 8-week comparative trial of standard doses of esomeprazole (40 mg) and omeprazole (20 mg) for the treatment of erosive esophagitis. Dig Dis Sci. 2006;51(5):844-850. [pmid: 16642422].
131 Hamamoto N, Hashimoto T, Adachi K, et al. Comparative study of nizatidine and famotidine for maintenance therapy of erosive esophagitis. Journal of Gastroenterology & Hepatology. 2005;(2):281-286. [pmid: 15683433].
132 Anvari M, Bamehriz F. Outcome of laparoscopic Nissen fundoplication in patients with body mass index >or=35. Surgical Endoscopy. 2006;20(2):230-234. [pmid: 16341568].
133 Booth MI, Stratford J, Jones L, et al. Randomized clinical trial of laparoscopic total (Nissen) versus posterior partial (Toupet) fundoplication for gastro-oesophageal reflux disease based on preoperative oesophageal manometry. [see comment]. British Journal of Surgery. 2008;95(1):57-63. [pmid: 18076018].
134 Brehant O, Pessaux P, Arnaud JP, et al. Long-term outcome of laparoscopic antireflux surgery in the elderly. Journal of Gastrointestinal Surgery. 2006;10(3):439-444. [pmid: 16504893].
135 Broeders JA, Draaisma WA, de Vries DR, et al. The preoperative reflux pattern as prognostic indicator for long-term outcome after Nissen fundoplication. American Journal of Gastroenterology. 2009;104(8):1922-1930. [pmid: 19491839].
136 Chisholm JA, Jamieson GG, Lally CJ, et al. The effect of obesity on the outcome of laparoscopic antireflux surgery. Journal of Gastrointestinal Surgery. 2009;13(6):1064-1070. [pmid: 19259752].
137 Cowgill SM, Arnaoutakis D, Villadolid D, et al. Results after laparoscopic fundoplication: does age matter?. American Surgeon. 2006;72(9):778-783. discussion 783-784. [pmid: 16986386].
138 D'Alessio MJ, Arnaoutakis D, Giarelli N, et al. Obesity is not a contraindication to laparoscopic Nissen fundoplication. Journal of Gastrointestinal Surgery. Oct. 2005;9(7):949-954. [pmid: 16137590].
139 Gee DW, Andreoli MT, Rattner DW. Measuring the effectiveness of laparoscopic antireflux surgery: long-term results. Archives of Surgery. 2008;143(5):482-487. [pmid: 18490558].
140 Iqbal A, Kakarlapudi GV, Awad ZT, et al. Assessment of diaphragmatic stressors as risk factors for symptomatic failure of laparoscopic nissen fundoplication. Journal of Gastrointestinal Surgery. 2006;10(1):12-21. [pmid: 16368486].
141 Kalinowska E, Tarnowski W, Bielecki K, et al. Quality of life before and after laparoscopic fundoplication. Does quality of life depend on psychological factors? Preliminary report. Wiadomosci Lekarskie. 2006;59(11-12):772-777. [pmid: 17427490].
142 Kamolz T, Granderath FA, Schweiger UM, et al. Laparoscopic Nissen fundoplication in patients with nonerosive reflux disease. Long-term quality-of-life assessment and surgical outcome. Surgical Endoscopy. 2005;(4):494-500. [pmid: 15959712].
143 Lee SK, Kim EK. Lapsaroscopic Nissen fundoplication in Korean patients with gastroesophageal reflux disease. Yonsei Medical Journal. 2009;50(1):89-94. [pmid: 19259354].
144 Lord RV, DeMeester SR, Peters JH, et al. Hiatal hernia, lower esophageal sphincter incompetence, and effectiveness of Nissen fundoplication in the spectrum of gastroesophageal reflux disease. Journal of Gastrointestinal Surgery. 2009;13(4):602-610. [pmid: 19050984].
145 Manning BJ, Salman R, Gillen P. Laparoscopic Nissen fundoplication: predicting outcome from peri-operative evaluation. Irish Journal of Medical Science. Jun. 2006;175(2):55-58.
146 Pizza F, Rossetti G, Limongelli P, et al. Influence of age on outcome of total laparoscopic fundoplication for gastroesophageal reflux disease. World Journal of Gastroenterology. 2007;13(5):740-747. [pmid: 17278197].
147 Pizza F, Rossetti G, del GG, et al. Influence of esophageal motility on the outcome of laparoscopic total fundoplication. [erratum appears in Dis Esophagus 2008;21(3):279 Note: Rosetti, G [corrected to Rossetti, G]]. Diseases of the Esophagus. 2008;21(1):78-85. [pmid: 18197944].
148 Ravi N, Al-Sarraf N, Moran T, et al. Acid normalization and improved esophageal motility after Nissen fundoplication: equivalent outcomes in patients with normal and ineffective esophageal motility. American Journal of Surgery. 2005;(3):445-450. [pmid: 16105534].
149 Riedl O, Gadenstatter M, Lechner W, et al. Preoperative lower esophageal sphincter manometry data neither impact manifestations of GERD nor outcome after laparoscopic Nissen fundoplication. Journal of Gastrointestinal Surgery. 13(7):1189-1197.
150 Strate U, Emmermann A, Fibbe C, et al. Laparoscopic fundoplication: Nissen versus Toupet two-year outcome of a prospective randomized study of 200 patients regarding preoperative esophageal motility. [see comment]. Surgical Endoscopy. 2008;22(1):21-30. [pmid: 18027055].
151 Tedesco P, Lobo E, Fisichella PM, Way LW, Patti MG. Laparoscopic fundoplication in elderly patients with gastroesophageal reflux disease. Archives of Surgery. 2006;141(3):289-292. discussion 292. [pmid: 16549695].
152 Thibault R, Coron E, Sebille V, et al. Antireflux surgery for non-erosive and erosive reflux disease in community practice. Alimentary Pharmacology & Therapeutics. 2006;24(4):621-632. [pmid: 16907894].
153 Wang W, Huang MT, Wei PL, et al. Laparoscopic antireflux surgery for the elderly: a surgical and quality-of-life study. Surgery Today. 2008;38(4):305-310. [pmid: 18368318].
154 Wayman J, Myers JC, Jamieson GG. Preoperative gastric emptying and patterns of reflux as predictors of outcome after laparoscopic fundoplication. British Journal of Surgery. 2007;94(5):592-598. [pmid: 17377929].
155 Wilkerson PM, Stratford J, Jones L, et al. A poor response to proton pump inhibition is not a contraindication for laparoscopic antireflux surgery for gastro esophageal reflux disease. Surgical Endoscopy. 2005;(9):1272-1277. [pmid: 16025197].
156 Yano F, Sherif AE, Turaga K, et al. Gastrointestinal quality of life in patients after anti reflux surgery. Diseases of the Esophagus. 2009;22(2):177-184. [pmid: 19207552].
157 Lundell L, Havu N, Miettinen P, et al. Changes of gastric mucosal architecture during long-term omeprazole therapy: results of a randomized clinical trial. Alimentary Pharmacology & Therapeutics. 2006;23(5):639-647. [pmid: 16480403].
158 Davies M, Wilton LV, Shakir SA. Safety profile of esomeprazole: results of a prescription-event monitoring study of 11 595 patients in England. Drug Safety. 2008;31(4):313-323. [pmid: 18366242].
159 Cutler A, Robinson M, Murthy A, et al. Rabeprazole 20 mg for erosive esophagitis-associated symptoms in a large, community-based study: additional results. Digestive Diseases & Sciences. 2010;55(2):338-345. [pmid: 19557517].
160 Howden CW, Ballard ED, Koch FK, et al. Control of 24-hour intragastric acidity with morning dosing of immediate-release and delayed-release proton pump inhibitors in patients with GERD. Journal of Clinical Gastroenterology. 2009;43(4):323-326. [pmid: 18758373].
161 Yu EW, Blackwell T, Ensrud KE, et al. Acid-suppressive medications and risk of bone loss and fracture in older adults. Calcified Tissue International. 2008;83(4):251-259. [pmid: 18813868].
162 Gray SL, LaCroix AZ, Larson J, et al. Proton pump inhibitor use, hip fracture, and change in bone mineral density in postmenopausal women: results from the Women's Health Initiative. Arch Intern Med. 2010;170(9):765-771. [pmid: 20458083].
163 Grisso JA, Kelsey JL, O'Brien LA, et al. Risk factors for hip fracture in men. Hip Fracture Study Group. American Journal of Epidemiology. 1997;145(9):786-793. [pmid: 9143208].
164 Yang YX, Lewis JD, Epstein S, et al. Long-term proton pump inhibitor therapy and risk of hip fracture. JAMA. 2006;296(24):2947-2953. [pmid: 17190895].
165 Vestergaard P, Rejnmark L, Mosekilde L. Proton pump inhibitors, histamine H2 receptor antagonists, and other antacid medications and the risk of fracture. Calcified Tissue International. 2006;79(2):76-83. [pmid: 16927047].
166 Targownik LE, Lix LM, Metge CJ, et al. Use of proton pump inhibitors and risk of osteoporosis-related fractures. CMAJ Canadian Medical Association Journal. 2008;179(4):319-326.
167 Kaye JA, Jick H. Proton pump inhibitor use and risk of hip fractures in patients without major risk factors. Pharmacotherapy. 2008;28(8):951-959. [pmid: 18657011].
168 Roux C, Briot K, Gossec L, et al. Increase in vertebral fracture risk in postmenopausal women using omeprazole. Calcified Tissue International. 2009;84(1):13-19. [pmid: 19023510].
169 Corley DA, Kubo A, Zhao W, et al. Proton pump inhibitors and histamine-2 receptor antagonists are associated with hip fractures among at-risk patients. Gastroenterology. 2010;139(1):93-101. [pmid: 20353792].
170 U.S.Food and Drug Administration. Clopidogrel (marketed as Plavix) and Omeprazole (marketed as Prilosec)—Drug Interaction. Available at; http://www.fda.gov/Safety/MedWatch/SafetyInformation/SafetyAlertsforHumanMedical Products/ucm190848.htm. November 17, 2009.
171 Rosenthal R, Peterli R, Guenin MO, et al. Laparoscopic antireflux surgery: long-term outcomes and quality of life. Journal of Laparoendoscopic & Advanced Surgical Techniques Part A. 2006;16(6):557-561. [pmid: 17243869].
172 Gill J, Booth MI, Stratford J, et al. The extended learning curve for laparoscopic fundoplication: a cohort analysis of 400 consecutive cases. Journal of Gastrointestinal Surgery. 2007;11(4):487-492. [pmid: 17436134].
173 Fumagalli U, Bona S, Battafarano F, et al. Persistent dysphagia after laparoscopic fundoplication for gastro-esophageal reflux disease. Diseases of the Esophagus. 2008;21(3):257-261. [pmid: 18430108].
174 Huttl TP, Hohle M, Wichmann MW, et al. Techniques and results of laparoscopic antireflux surgery in Germany. Surgical Endoscopy. 2005;(12):1579-1587. [pmid: 16211438].
175 Csendes A, Burdiles P, Korn O. Laparoscopic Nissen fundoplication: the “right posterior” approach. Journal of Gastrointestinal Surgery. Oct. 2005;9(7):985-991. [pmid: 16137596].
176 Zacharoulis D, O'Boyle CJ, Sedman PC, et al. Laparoscopic fundoplication: a 10-year learning curve. Surgical Endoscopy. 2006;(11):1662-1670. [pmid: 17024541].
177 Salminen PT, Laine SO, Ovaska JT. Late subjective results and symptomatic outcome after laparoscopic fundoplication. Surgical Laparoscopy, Endoscopy & Percutaneous Techniques. 2006;16(4):203-207.
178 Morgenthal CB, Shane MD, Stival A, et al. The durability of laparoscopic Nissen fundoplication: 11-year outcomes. [see comment]. Journal of Gastrointestinal Surgery. 2007;11(6):693-700. [pmid: 17562117].
179 del GG, Rossetti G, Brusciano L, et al. Laparoscopic Nissen-Rossetti fundoplication with routine use of intraoperative endoscopy and manometry: technical aspects of a standardized technique. World Journal of Surgery. 2007;31(5):1099-1106. [pmid: 17426906].
180 Cowgill SM, Gillman R, Kraemer E, et al. Ten-year follow up after laparoscopic Nissen fundoplication for gastroesophageal reflux disease. American Surgeon. 2007;73(8):748-752. discussion 752-753. [pmid: 17879678].
181 Jensen CD, Gilliam AD, Horgan LF, et al. Day-case laparoscopic Nissen fundoplication. Surgical Endoscopy. 2009;23(8):1745-1749. [pmid: 18855057].
182 Jensen CD, Gilliam AD, Horgan LF, et al. Day-case laparoscopic Nissen fundoplication. Surgical Endoscopy. 2009;23(8):1745-1749. [pmid: 18855057].
183 Madan AK, Ternovits CA, Tichansky DS. Emerging endoluminal therapies for gastroesophageal reflux disease: adverse events. American Journal of Surgery. 2006;(1):72-75. [pmid: 16769279].
184 Mosler P, Aziz AM, Hieston K, et al. Evaluation of supplemental cautery during endoluminal gastroplication for the treatment of gastroesophageal reflux disease. Surgical Endoscopy. 2008;22(10):2158-2163. [pmid: 18629586].