# Introduction

The first Comparative Effectiveness Report published by the Agency of Healthcare Quality and Research (AHRQ) focused on gastroesophageal reflux disease (GERD).1 The Key Questions addressed concerned the comparative effectiveness of medical, surgical and endoscopic treatments for improving objective and subjective outcomes in patients with GERD. In addition, the report examined the relative efficacy of these interventions in specific patient subgroups as well as their adverse event profiles.

A number of developments since the final publication of the report in 2005 have necessitated an update. Among them: the publication of approximately 3,000 new studies, the introduction of new drugs, the recognition of new drug safety considerations, and the market withdrawal and introduction of new endoscopic interventions. Also notable was the publication of a new consensus definition of GERD in 2006.^2^

The current report addresses the developments in treatments of GERD in adults. In addition, it has been expanded to include sections on treatments of extraesophageal syndromes, including chronic cough, laryngitis, and asthma, which were considered to be of particular clinical importance by an expert panel.

Despite these developments, many considerations remained unchanged. As with the previous report, definitions of GERD and disease severity among included subjects varied from study to study. For example, many studies defined GERD based on symptomatology, while others incorporated the results of various objective tests such as ambulatory esophageal pH, endoscopic, or acid suppression studies. In this update, the populations evaluated were, therefore, made explicit and outlined in detail.

Similar considerations were made for assessment of outcomes, which included measures of formal or informal assessment of symptoms, use of medications, quality of life instruments, healing of esophagitis, and changes in esophageal pH exposure. The methods by which these outcomes were evaluated varied and not all studies included outcomes of interest. Again, outcomes and their definitions were explicitly reported when making comparisons across studies. The quality of studies was also assessed rigorously and weighed in the formulation of conclusions.

Furthermore, as this report was intended to focus on comparative effectiveness, studies that directly compared treatment options for GERD were prioritized. However, non-comparison studies were also considered in order to fully address particular of the Key Questions, such as those pertaining to adverse events.

GERD continues to be an important disease both in terms of cost and public health. One study of an employed population in the United States estimated that more than 11,000 of 267,000 employees (4%) suffered from GERD, contributing an average incremental cost of $3,355 per employee during a three year observation period—approximately 65% related to prescription drugs.3 At the same time, it is well recognized that some drugs used to treat GERD (such as proton pump inhibitors) are overprescribed.4 The large disease burden, economic impact, and market potential for new drugs and devices explain the continued intense interest in GERD and the development of cost-effective approaches for its diagnosis and management.

The purpose of the current report is to provide a detailed, rigorous, and up-to-date appraisal of the evidence comparing various management strategies for adult patients with GERD. While not intended to make clinical recommendations, its conclusions should have immediate clinical applicability by elucidating the safety and effectiveness of various treatment approaches for subgroups of patients with GERD as well as providing guideline-issuing organizations guidance in the formulation of their recommendations for the management of GERD.