# EPC Program Director

Joseph Lau, M.D.

Tufts Medical Center

Boston, MA