# Discussion

An up-to-date review of the literature has revealed that many of the 2005 CER's original conclusions remain valid. In addition to the reconfirmation of these findings, further data were identified and included in the present report, expanding on these previous results. Notably, we added a section on the treatment of extraesophageal manifestations of GERD, which was not covered in the 2005 review. Furthermore, the present update also reviewed two new PPIs and one new endoscopic procedure. Table 46 summarizes the strength of evidence on treatments for GERD.

Table 46 Strength of evidence

Key question | Strength of evidence | Summary, conclusion, comments
Key question 1. What is the evidence of the comparative effectiveness of medical, surgical and other newer forms of treatments for improving objective and subjective outcomes in patients with chronic gastroesophageal reflux disease (GERD)? Is there evidence that effectiveness varies by specific techniques/procedures or medications? Objective outcomes include esophagitis healing, ambulatory pH, other indicators of reflux, need for medication, healthcare utilization, and incidence of esophageal stricture, Barrett's esophagus, or esophageal adenocarcinoma. Subjective outcomes include symptom frequency and severity, sleep/productivity, and overall quality of life.
Medical vs. surgical treatments | Moderate | - Based on analysis of 4 RCTs and 3 nonrandomized trials with varied:; ◦ Medical (PPI and/or H2RA) vs. surgical (open and/or laparoscopic fundoplication) interventions; ◦ Outcomes of study (GERD symptoms, QoL, satisfaction, medication use, pH study results, remission rates); ◦ Follow-up time period (1 to 12 years); ◦ Study quality (5 B-level, 2 C-level); ◦ Dropout rate for studies with 7 to 12 year followup (33 to 58%); - Patients who underwent antireflux fundoplication surgery experienced a greater improvement in heartburn and regurgitation at followup compared to patients who received medical treatment alone. Surgery was associated with an increased incidence of dysphagia and postprandial bloating. Surgery decreased, but did not eliminate, the use of antireflux medications at followup.
Medical vs. endoscopic treatments | Insufficient | - No study was identified for this comparison.
Surgical vs. endoscopic treatments | Insufficient | - One small non-randomized study reported significantly better improvement in heartburn score and 24-hour pH study in the laparoscopic total fundoplication group, compared with EndoCinch^TM^. There were no significant differences in other outcomes.
Medical treatment comparisons Comparisons between PPIs and H2RAs | Moderate | - PPIs (esomeprazole 20 mg taken once daily or on-demand, lansoprazole 15 mg taken once daily and omeprazole 20 mg taken once daily) were superior to H2RAs (ranitidine 150 mg and famotidine 20 mg, both taken twice daily) for resolution of GERD symptoms at 6 months.; - Data from one RCT reported that lansoprazole 15 mg, taken once daily, was more effective than ranitidine 150 mg taken twice daily for healing of esophagitis at 1 year.; - Data from one RCT reported that esomeprazole 20 mg, taken once daily or on-demand, was more effective than ranitidine 150 mg taken twice daily for prevention of symptom relapse at 6 months.; - Data from two RCTs reported that maintenance treatment (≥ 6 months) with PPIs (esomeprazole 20 mg taken once daily or on-demand, lansoprazole 15 mg taken once daily) appears to be more efficacious than maintenance treatment with H2RA (ranitidine 150 mg taken twice daily) in symptom remission.; - Data from one RCT reported that maintenance treatment, patients taking lansoprazole 15 mg are likely to stay longer on their treatment as compared to ranitidine 150 mg taken twice daily and thus tend to have a longer median time to relapse of symptoms.; - Studies with larger sample sizes suggested PPIs to be more efficacious than H2RAs with respect to GERD symptoms.
Comparisons between different PPIs | Moderate | - Based on analysis of 10 RCTs, no consistent comparative difference in symptom relief and esophagitis healing rates was observed between esomeprazole (20 to 40 mg), lansoprazole (15 to 30 mg), pantoprazole (20 to 40 mg) or rabeprazole (10 to 20 mg) over a period ranging from 4 weeks to 6 months.; - There is some evidence from individual studies that rabeprazole 10 mg may provide better symptom relief than esomeprazole 40 mg at 4 weeks, and also that pantoprazole 20 mg provides better control of heartburn than esomeprazole 40 mg over 24 weeks.; - Results from three acute treatment trials showed similar esophagitis healing rates for both pantoprazole 40 mg and esomeprazole 40 mg as demonstrated by endoscopy, with the rates increasing with trial duration from 8 to 12 weeks, and being equivalent over 6 months.
Comparisons between different dosages and dosing regimens of PPIs | Moderate | - Based on analysis of 12 RCTs, no consistent difference in doses and dosing regiments with different PPIs in relation to symptom resolution and esophagitis healing rates.; - One RCT reported that there was no significant difference in symptom resolution rates at 4 weeks between esomeprazole 20 mg taken once a day and esomeprazole 40 mg taken once a day.; - One RCT reported a significantly higher rate of healing of esophagitis at 4 weeks was observed with esomeprazole 40 mg once a day compared with esomeprazole 20 mg once a day.
Comparisons between once daily and on-demand dosing regimens of PPIs | Moderate | - Three RCTs comparing continuous daily intake of esomeprazole 20 mg appears to provide better symptom control and quality of life relative to on-demand dosing over a period of 6 months.; - One RCT reported that continuous daily intake of esomeprazole 20 mg appears to provide significantly better endoscopic remission compared with on-demand dosing over a period of 6 months.; - Two RCTs reported that continuous daily intake of rabeprazole 20 mg appears to provide better symptom control and quality of life relative to on-demand dosing over a period of 6 months.
Comparisons between PPIs and over-the-counter dosages of PPIs approved for treatment of frequent heartburn (omeprazole 20 mg, lansoprazole 15 mg) | Moderate | - Based on analysis of eight RCTs, no consistent comparative difference in symptom relief and esophagitis healing rates was observed between esomeprazole (20 to 40 mg), lansoprazole 30 mg, pantoprazole 40 mg or rabeprazole 20 mg with omeprazole 20 mg or lansoprazole 15 mg over a period ranging from 4 weeks to 1 year.; - One RCT reported that pantoprazole 40 mg and rabeprazole 20 mg provide significantly better symptom relief and healing of esophagitis than omeprazole 20 mg at 8 weeks.; - One RCT reported that esomeprazole 20 mg provides higher endoscopic remission rates compared with lansoprazole 15 mg over 6 months.
Surgical treatment comparisons Total vs. partial fundoplication | Moderate | - One RCT and five non-randomized comparative studies compared laparoscopic total vs. partial fundoplication.; - No consistent significant differences in GERD symptoms, diagnostic test results, or quality of life were observed between groups.
Fundoplication with vs. without division of short gastric vessel | Moderate | - Two RCTs and two non-randomized comparative studies compared laparoscopic fundoplication with vs. without division of short gastric vessel.; - No significant differences in medication use, GERD symptoms, or quality of life were found between groups.
Laparoscopic vs. open fundoplication | Moderate | - Two RCTs and one non-randomized comparative study compared laparoscopic vs. open fundoplication.; - No significant differences in medication use, GERD symptoms, diagnostic test results, or quality of life were found between groups.
Endoscopic treatments Comparison between endoscopic treatments | Insufficient | - No direct comparisons between the different endoscopic treatments were identified.
EndoCinch™ | Low | - Two sham-controlled studies and six non-comparative cohort studies evaluated the effectiveness of EndoCinch™.; - No consistent differences between EndoCinch™ and sham were reported.; - Significant improvements in heartburn, quality of life, and esophagitis healing were found in some but not all cohort studies.
EsophyX™ | Insufficient | - Five small cohort studies evaluated the effectiveness of EsophyX™.; - The reported proportion of patients who were off PPI at the end of the followup period ranged from 47 to 71 percent.; - Significant improvement of GERD-HRQL was reported by two of five studies.
Stretta™ | Insufficient | - One sham-controlled study and seven non-comparative cohort studies evaluated Stretta™.; - In the RCT, the proportion of patients who stopped or decreased PPI use was significantly greater in the Stretta™ group compared with the control group at 6 months (but it was not significant at 1 year). No significant differences in heartburn symptoms, QoL, acid exposure and esophagitis outcomes were found.; - The majority of cohort studies found significant improvements in GERD symptoms, QoL, and medication use.
Medical treatment for extraesophageal symptoms Asthma | Insufficient | - A systematic review did not find consistent effects of PPI or H2RA (vs. placebo) in improving asthma symptoms, nocturnal asthma, use of asthma medications or FEV1.; - 8 primary RCTs in the update to the systematic review also reported inconsistent effects. Omeprazole 20 mg (combined with domperidone 10 mg) or esomeprazole 40 mg showed an improvement in peak expiratory flow rate. Lansoprazole 30 mg or pantoprazole 40 mg did not show an improvement in asthma symptoms or lung function tests. Rabeprazole 20 mg twice a day improved respiratory symptoms during exercise in patients with exercise induced asthma, as compared to a placebo, but not QoL or pulmonary function measures.
Hoarseness | Low | - Four of six RCTs did not find a significant difference in resolution of hoarseness between PPI and placebo.
Chronic cough | Low | - Meta-analysis of 4 studies (191 participants) showed no significant difference in total resolution of cough between PPIs and placebo, odds ratio 0.46 (95% CI: 0.19 to 1.15). A meta-analysis of data from 4 RCTs reporting mean cough scores at the end of the trial in 109 participants found a borderline significant improvement in the mean cough scores at the end of the trial with PPIs as compared to placebo 0.38 units (95 percent CI: 0.77 to 0.00, P=0.05). Another meta-analysis examining the improvement in cough scores within the same systematic review, however, showed a significant improvement in cough scores from baseline favoring PPIs compared to placebo ( 0.39 standardized mean difference units; 95 percent CI: 0.71 to -0.08).
Surgical Treatment for extraesophageal symptoms | Insufficient | - All of the data on surgical treatment are from cohort studies, with a wide variation in the population treated, the severity of the underlying GERD and its extraesophageal manifestation, the outcome measures, the surgical interventions, the intensity and duration of followup.; - The majority of the cohort studies found that surgery may help improve cough and laryngeal symptoms more so than asthma, but there is a wide range of effect estimates in these studies.
Key Question 2: Is there evidence that the effectiveness of medical, surgical and newer forms of treatments vary for specific patient subgroups? What are the characteristics of patients who have undergone these therapies, including the nature of previous medical therapy, severity of symptoms, age, sex, weight, other demographic and medical factors, or by specific patient subgroups, and provider characteristics for procedures including provider volume and setting (e.g., academic vs. community)?
Factors that influenced the comparative effectiveness of surgical vs. medical treatment | Insufficient | - One study found that there was no significant difference in the effectiveness of medical vs. surgical treatment between patients with and without Barrett's esophagus.
Factors that influenced the outcome of medical therapy | Moderate | - Six RCTs comparing different PPIs, or dosages and dosing regimens of PPIs showed mixed findings regarding the impacts of esophagitis severity at baseline on healing rates.; - Ten cohort studies examined patient characteristics or clinical factors as modifying factors of medical treatment outcomes.; - Sex was not a significant modifying factor of medical treatment outcomes.; - Obesity, presence of baseline typical GERD symptoms, and more severe esophagitis were significantly associated with worse medical treatment outcomes.; - The associations between age and medical treatment outcomes were inconsistent.
Factors that influenced the outcome of surgical treatment | Low | - One RCT found that preoperative esophageal motility did not significantly impact the effect of laparoscopic fundoplication on dysphagia, recurrence of reflux, and acid exposure and manometry outcomes.; - Thirty cohort studies showed the following were inconsistently associated with worse surgical outcome: per year increase in patient's age, morbid obesity, female sex, presence of baseline symptoms or esophagitis, and hiatal hernia greater than 3 cm at baseline.
Factors that influenced the outcome of endoscopic treatment | Low | - Three cohort studies examined different modifying factors of endoscopic treatment:; - One study did not find a significant difference between men and women in symptom improvement.; - One study found more patients with less severe esophagitis at baseline stopped PPI use than patients with more severe esophagitis.; - One study observed a learning curve in performance of a new endoscopic treatment device (EsophyX) comparing the technical procedure parameters.
Key Question 3: What are the short-term and long-term adverse events associated with specific medical, surgical and newer forms of therapies for GERD? Does the incidence of adverse events vary with duration of follow-up, specific surgical intervention, or patient characteristics?
Adverse events | Low | - None of the adverse event quantitative estimates are reliable because of a lack of standard definition and uniform system of reporting.; - One RCT reported that the rate of serious adverse events was higher with surgery than with medical treatment (P=0.06).; - Potential serious complications possibly associated with PPIs included an increased risk of bone fracture, as well as enteric infections and pneumonia previously reported in our 2005 CER.; - Common adverse events reported in patients who underwent fundoplication included bloating and dysphagia.; - Common adverse events after endoscopic suturing included chest or abdominal pain, bleeding, dysphagia, and bloating.

With regard to comparisons between surgery and medical therapy, we found that laparoscopic fundoplication in patients whose GERD symptoms were already well-controlled by medical treatments was at least as effective as continued medical treatment (and in some cases superior) in controlling GERD-related symptoms for the first 1 to 3 years following surgery, provided that the procedure was performed by experienced surgeons in high volume centers.

Bearing these findings in mind, the choice of laparoscopic fundoplication would be mainly targeted at those who wished to avoid the potential burden of lifelong medical treatments. Therefore, it is important to know how well the laparoscopic fundoplication actually succeeds in doing so. Of the three trials on laparoscopic fundoplication versus medical treatment reviewed, one reported that no patients treated with surgery were on medications at 1 year followup;20 one reported 13 percent of the surgically treated patients were on medications at 1 year;13 and one (with a 3 year followup) did not report medication use.16 It appears clear that laparoscopic fundoplication is efficacious in helping patients to decrease the use of antireflux medications in the short term (≤1 year), but the longer term effect is uncertain. Of note, a long-term trial on open fundoplication versus medical treatments found that one-third of the surgically treated patients had received some form of antireflux medication by 12 years.17

Adverse events from surgery must also be considered. Fundoplication is associated with procedural complications like postoperative infections and incisional hernia, and morbidities like dysphagia and postprandial bloating, some of which may require surgical revisions. It would be helpful if one can predict preoperatively who would be at a higher risk of some of these postoperative complications. However, our review did not identify reliable patient or operative predictors of clinical outcome; age, morbid obesity, female sex, baseline symptoms, esophagitis, and hiatal hernia were all inconsistently associated with worse surgical outcomes.

However, medical therapy has also been associated with potentially serious complications. As in our previous review, serious complications reported with the use of PPIs include an increased risk of enteric infections (including Campylobacter and C. difficile) and pneumonia. An observation made since the 2005 review is a possible association between the use of PPIs and an increased risk of fractures.

For patients with GERD symptoms that cannot be adequately managed by standard medical treatments, published evidence to guide the choice of further therapy is not particularly helpful, as the available data are restricted to cohort studies lacking a proper control group. Of note, the two studies reviewed that explicitly included patients with an unsatisfactory response to medical treatments found that GERD symptoms had significantly improved after laparoscopic fundoplication in more than 5 years of followup.80,81

Another important consideration is whether medical therapy or surgery is more effective in preventing long-term complications of GERD such as the development of Barrett's esophagus or esophageal adenocarcinoma. We did not identify sufficient evidence to conclude whether one or the other approach was more effective in preventing these adverse outcomes.

In addition to comparing medical and surgical therapies, our review also evaluated several new studies comparing specific medications, including two new PPIs. No consistent comparative difference in symptom relief was observed between esomeprazole (20 to 40 mg), lansoprazole (15 to 30 mg), pantoprazole (20 to 40 mg), or rabeprazole (10 to 20 mg). However, there is some evidence that rabeprazole 10 mg may provide better symptom relief than esomeprazole 40 mg at 4 weeks, and pantoprazole 40 mg better than esomeprazole 40 mg over 24 weeks.

With respect to dosing intervals, continuous dosing with PPIs was found to be more effective than on-demand dosing. For example, continuous daily intake of esomeprazole 20 mg or rabeprazole 20 mg appeared to provide better symptom control and quality of life relative to on-demand dosing over a period of 6 months. As for comparisons of different PPIs with over-the-counter dosages of omeprazole (20 mg), pantoprazole 40 mg and rabeprazole 20 mg provided significantly better symptom relief and healing of esophagitis at 8 weeks, and esomeprazole 20 mg provided better endoscopic remission rates as compared to over-the-counter dosages of lansoprazole (15 mg) at 6 months. While significant, the observed magnitude of these differences was generally small and the clinical relevance remains uncertain. It is possible that the variations in effectiveness may have been due to the specific doses examined.

As for the three available endoscopic procedures (EndoCinch^TM^, Stretta^TM^, EsophyX^TM^) for the long-term management of GERD, effectiveness remains substantially uncertain. EndoCinch (suturing) and Stretta (radiofrequency ablation) had been previously examined in the 2005 CER; EsophyX (endoscopic fundoplication) is a new introduction. While some clinical benefits were observed in patients who had these procedures, the studies were generally small, of variable quality, and of short duration. In addition, all of these procedures have been associated with complications including dysphagia, infection/fever, and bloating.

For the treatment of patients with extraesophageal manifestations of GERD symptoms, no consistent benefit could be attributed to either medication or surgery. A small RCT found that patients' asthma symptoms improved after antireflux surgery compared to antireflux medical treatments, but these improvements could not be substantiated by objective testing.121 Similarly, some observational studies reported that antireflux surgery could be beneficial for those with asthma, chronic cough, or laryngeal symptoms. Despite the focus in our report on only those patients with asthma, chronic cough, or laryngeal symptoms, we surmise that the considerable clinical heterogeneity within these subgroups precluded the detection of a reliable effect, if one exists. It is recognized that the quality of primary studies in this field is limited. Within these studies, the impact of GERD treatment may be limited, as GERD may not be the cause for symptoms in all of the subjects in the study. The treatment population will include both responders (participants with reflux triggered symptoms) and non-responders (participants whose symptoms are not reflux triggered). This will dilute the overall treatment effect. Without any tests and biomarkers to identify GERD-related symptoms, it is not possible to accurately estimate the potential effects from anti-acid treatments.

We acknowledge the limitations of largely relying on existing systematic reviews to review the evidence for the treatment of patients with extraesophageal manifestations of GERD symptoms; it would not have been feasible to review all the primary literature on this topic within the time period of this report. Even though we have assessed the reporting quality of these systematic reviews, we did not re-analyze the primary studies.

While we have made every attempt to address the Key Questions set out in the present review, the available evidence had several important limitations:

- Studies directly comparing surgery to medical therapy generally had high dropout-rates in long-term followup (e.g., 58 percent of patients were lost to followup at 12 years in a study comparing medical treatment and open fundoplication).
- There was a great deal of variability in the rigor of how the outcomes were evaluated across studies, particularly in subjective endpoints (e.g., some used a validated measure of quality of life, while others used symptom scales whose measurement properties have not been well characterized).
- Most studies were non-randomized or lacked a suitable control group.
- The majority of the included studies had a relatively short followup (typically no longer than 1 year), particularly those concerned with medical treatments.
- Pharmacologically equivalent doses of various PPIs have not been well established (or universally agreed upon), thus clouding interpretation of existing comparative PPI studies.
- Reporting of adverse events was often incomplete and inconsistent across studies; some studies did not report specific adverse events and the definitions of adverse events differed across studies.