# GERD Data Extraction Form

Key Questions 1 and 3

Key Questions 2

## Evidence Table Template of Systematic Review

Evidence table of systematic review

Author Year [PMID]
Design | A systematic review of xxx (key questions or study aim)
Population | Definitions of atypical GERD or symptoms of atypical GERD included
Intervention (Exposure) and Comparator
Results | Describe study selection flow Summarize study characteristics (eg. study design (n=x), quality of studies ‥etc.) Meta-analysis model and heterogeneity (if applicable) Key findings
Comments | Limitations and bias of this systematic review
AMSTAR
| Study quality assessment performed?
Two independent reviewers?
| Appropriate statistical synthesis?
All publication types and languages included?
| Conflicts of interest stated?
Study characteristics provided?