# Excluded Studies

## I Primary Studies on GERD

Author | Title | Source | Reasons for rejection
Abdel-Raouf El-Geidie A; Gadel-Hak N;Fathi O; | Secondary antireflux surgery | Int J Surg. 2009 Feb;7(1):44-9. Epub 2008 Oct 18. | Not relevant, study assesses causes and some outcomes of secondary antireflux surgeries to correct original surgery but purpose wasn't to make comparisons
Agrawal S; Shapey I; Peacock A; Ali A;Super P; | Prospective study of routine day-case laparoscopic modified Lind partial fundoplication | World J Surg. 2009 Jun;33(6):1229-34. | FU < 5 years
Bajbouj M; Becker V; Phillip V; Wilhelm D; Schmid RM; Meining A; | High-dose esomeprazole for treatment of symptomatic refractory gastroesophageal reflux disease--a prospective pH-metry/impedance-controlled study | Digestion. 2009;80(2):112-8. Epub 2009 Jul 27. | Prospective non-comparative medical treatment cohort
Bajbouj M; Reichenberger J; Neu B; Prinz C; Schmid RM; Rosch T; Meining A; | A prospective multicenter clinical and endoscopic follow-up study of patients with gastroesophageal reflux disease | Z Gastroenterol. 2005 Dec;43(12):1303-7. | no intervention of interest
Bataille D; Simoens C; Mendes da CP; | Laparoscopic revision for failed anti-reflux surgery. Preliminary results | Hepatogastroenterology. 2006 Jan-Feb;53(67):86-8. | Previous antireflux surgeries
Bautista JM; Wong WM; Pulliam G; Esquivel RF; Fass R; | The value of ambulatory 24 hr esophageal pH monitoring in clinical practice in patients who were referred with persistent gastroesophageal reflux disease (GERD)-related symptoms while on standard dose anti-reflux medications | Dig Dis Sci. 2005 Oct;50(10):1909-15. | Not relevant, study assesses value of pH testing in failed PPI vs failed H2RA pts
Beaumont H; Boeckxstaens GE; | Does the presence of a hiatal hernia affect the efficacy of the reflux inhibitor baclofen during add-on therapy? | Am J Gastroenterol. 2009 Jul;104(7):1764-71. Epub 2009 Jun 2. | GABA agonist baclofen is not Tx of interest. no comparison of interest; duration <4 weeks
Becker V; Bajbouj M; Waller K; Schmid RM; Meining A; | Clinical trial: persistent gastro-oesophageal reflux symptoms despite standard therapy with proton pump inhibitors - a follow-up study of intraluminal-impedance guided therapy | Aliment Pharmacol Ther. 2007 Nov 15;26(10):1355-60. Epub 2007 Sep 26. | Not relevant, study assesses utility of ph monitoring in identifying pts to modify ppi therapy
Bergman MP; Klinkenberg-Knol EC; Faller G; Aar A; Lakhai W; Vandenbroucke-Grauls CM; Kuipers EJ; Appelmelk BJ; | Long-term acid suppression by omeprazole in gastro-oesophageal reflux disease patients does not lead to anti-gastric autoantibody production | Aliment Pharmacol Ther. 2005 Apr 15;21(8):977-83. | sample size <100 for KQ3
Bergman S; Mikami DJ; Hazey JW; Roland JC; Dettorre R; Melvin WS; | Endolumenal fundoplication with EsophyX: the initial North American experience | Surg Innov. 2008 Sep;15(3):166-70. | N<10
Biertho L; Dallemagne B; Dewandre JM; Jehaes C; Markiewicz S; Monami B; Wahlen C; Weerts J; | Laparoscopic treatment of Barrett's esophagus: long-term results | Surg Endosc. 2007 Jan;21(1):11-5. Epub 2006 Nov 16. | 100% Barrett's
Biertho L; Sebajang H; Anvari M; | Effects of laparoscopic Nissen fundoplication on esophageal motility: long-term results | Surg Endosc. 2006 Apr;20(4):619-23. Epub 2006 Feb 25. | condition excluded in this review
Bigard MA; Genestin E; | Treatment of patients with heartburn without endoscopic evaluation: on-demand treatment after effective continuous administration of lansoprazole 15 mg | Aliment Pharmacol Ther. 2005 Oct 1;22(7):635-43. | PPI vs placebo is excluded
Birk J; Pruitt R; Haber G; Raijman I; Baluyut A; Meiselman M; Sedghi S; | The Plicator procedure for the treatment of gastroesophageal reflux disease: a registry study | Surg Endosc. 2009 Feb;23(2):423-31. Epub 2008 Sep 24. | NDO device excluded
Bjornsson E; Abrahamsson H; Simren M; Mattsson N; Jensen C; Agerforz P; Kilander A; | Discontinuation of proton pump inhibitors in patients on long-term therapy: a double-blind, placebo-controlled trial | Aliment Pharmacol Ther. 2006 Sep 15;24(6):945-54. | discontinuation of PPIs in long-term PPI users
Blazeby JM; Barham CP; Donovan JL; | Commentary: Randomised trials of surgical and non-surgical treatment: a role model for the future.[comment] | BMJ. 2008 Dec 15;337:a2747. doi: 10.1136/bmj.a2747. | commentary
Blondeau K; Mertens V; Vanaudenaerde BA; Verleden GM; Van Raemdonck DE; Sifrim D; Dupont LJ; | Gastro-oesophageal reflux and gastric aspiration in lung transplant patients with or without chronic rejection | Eur Respir J. 2008 Apr;31(4):707-13. Epub 2007 Dec 5. | lung transplant patients
Bochkarev V; Iqbal A; Lee YK; Vitamvas M; Oleynikov D; | One hundred consecutive laparoscopic Nissen's without the use of a bougie | Am J Surg. 2007 Dec;194(6):866-70; discussion 870-1. | follow-up <5 years
Bochkarev V; Lee YK; Vitamvas M; Oleynikov D; | Short esophagus: how much length can we get? | Surg Endosc. 2008 Oct;22(10):2123-7. Epub 2008 Jun 14. | follow-up <5 years; intervention not of interest (extended transhiatal mediastinal dissection to elongate short esophagus)
Bocskei C; Viczian M; Bocskei R; Horvath I; | The influence of gastroesophageal reflux disease and its treatment on asthmatic cough | Lung. 2005 Jan-Feb;183(1):53-62. | atypical GERD
Boddy AP; Mehta S; Bennett J; Lowndes R; Mahon D; Rhodes M; | Postoperative esophageal physiology studies may help to predict long-term symptoms following laparoscopic Nissen fundoplication | Surg Endosc. 2008 May;22(5):1298-302. Epub 2007 Oct 31. | surgical cohort N<100; surgical arm from a RCT (Mahon, 2005 in our 2005 report)
Bogte A; Bredenoord AJ; Smout AJ; | Diagnostic yield of oesophageal pH monitoring in patients with chronic unexplained cough | Scand J Gastroenterol. 2008 Jan;43(1):13-9. | no treatment
Boiron M; Benchellal Z; Huten N; | Study of swallowing sound at the esophagogastric junction before and after fundoplication | J Gastrointest Surg. 2009 Sep;13(9):1570-6. Epub 2009 Jun 3. | < 100 patients and FU < 5 yrs
Bonavina L; Saino GI; Bona D; Lipham J; Ganz RA; Dunn D; DeMeester T; | Magnetic augmentation of the lower esophageal sphincter: results of a feasibility clinical trial | J Gastrointest Surg. 2008 Dec;12(12):2133-40. Epub 2008 Oct 10. | N<100; follow-up <5 year
Bonnet G; Khan MI; Ong L; | Using quality-of-life instruments to measure outcome after laparoscopic fundoplication | N Z Med J. 2005 Jul 29;118(1219):U1594. | surgical cohort N<100
Boolchand V; Faulx A; Das A; Zyzanski S; Isenberg G; Cooper G; Sivak MV; Chak A; | Primary care physician attitudes toward endoscopic screening for GERD symptoms and unsedated esophagoscopy | Gastrointest Endosc. 2006 Feb;63(2):228-33. | not relevant
Bove M; Vieth M; Casselbrant A; Ny L; Lundell L; Ruth M; | Acid challenge to the esophageal mucosa: effects on local nitric oxide formation and its relation to epithelial functions | Dig Dis Sci. 2005 Apr;50(4):640-8. | healthy pts
Bozikas A; Marsman WA; Rosmolen WD; van Baal JW; Kulik W; ten Kate FJ; Krishnadath KK; Bergman JJ; | The effect of oral administration of ursodeoxycholic acid and high-dose proton pump inhibitors on the histology of Barrett's esophagus | Dis Esophagus. 2008;21(4):346-54. | BE pts
Braghetto I; Korn O; Debandi A; Burdiles P; Valladares H; Csendes A; | Laparoscopic cardial calibration and gastropexy for treatment of patients with reflux esophagitis: pathophysiological basis and result | World J Surg. 2005 May;29(5):636-44. | N<100; follow-up <5 year
Braghetto I; Papapietro K; Csendes A; Gutierrez J; Fagalde P; Diaz E; Rodriguez A; Undurraga F; | Nonesophageal side-effects after antireflux surgery plus acid-suppression duodenal diversion surgery in patients with long-segment Barrett's esophagus* | Dis Esophagus. 2005;18(3):140-5. | BE pts
Brandt MG; Darling GE; Miller L; | Symptoms, acid exposure and motility in patients with Barrett's esophagus | Can J Surg. 2004 Feb;47(1):47-51. | no intervention of interest
Bredenoord AJ; | Lesogaberan, a GABA(B) agonist for the potential treatment of gastroesophageal reflux disease | IDrugs. 2009 Sep;12(9):576-84. | GABA agonist not Tx of interest
Bretagne JF; Honnorat C; Richard-Molard B; Soufflet C; Barthelemy P; | Management of gastroesophageal reflux disease by primary care physicians and gastroenterologists: a prospective study of patients' records | Gastroenterol Clin Biol. 2008 Dec;32(12):995-1000. Epub 2008 Oct 28. | not relevant
Bretagne JF; Rey JF; Caekaert A; Barthelemy P; | Routine management of gastro-oesophageal reflux disease by gastroenterologists in France: a prospective observational study | Dig Liver Dis. 2005 Aug;37(8):566-70. | cross-sectional study on prevalence and treatment practices of GERD
Bright T; Watson DI; Tam W; Game PA; Astill D; Ackroyd R; Wijnhoven BP; Devitt PG; Schoeman MN; | Randomized trial of argon plasma coagulation vs. endoscopic surveillance for barrett esophagus after antireflux surgery: late results | Ann Surg. 2007 Dec;246(6):1016-20. | all patients with Barrett's
Byrne JP; Smithers BM; Nathanson LK; Martin I; Ong HS; Gotley DC; | Symptomatic and functional outcome after laparoscopic reoperation for failed antireflux surgery | Br J Surg. 2005 Aug;92(8):996-1001. | intervention not considered in this review
Byrne PJ; Ravi N; Al-Sarraf N; Rowley S; Moran T; Reynolds JV; | The Rossetti-Nissen fundoplication--effective in managing gastro-oesophageal reflux disease | Surgeon. 2008 Feb;6(1):19-24. | follow-up <5 years
Bytzer P; Morocutti A; Kennerly P; Ravic M; Miller N; ROSE T; | Effect of rabeprazole and omeprazole on the onset of gastro-oesophageal reflux disease symptom relief during the first seven days of treatment | Scand J Gastroenterol. 2006 Oct;41(10):1132-40. | RCT <4 wk but had AE data
Cadiere GB; Rajan A; Germay O; Himpens J; | Endoluminal fundoplication by a transoral device for the treatment of GERD: A feasibility study | Surg Endosc. 2008 Feb;22(2):333-42. Epub 2007 Dec 11. | follow up <5 years
Cadiere GB; Rajan A; Rqibate M; Germay O; Dapri G; Himpens J; Gawlicka AK; | Endoluminal fundoplication (ELF)--evolution of EsophyX, a new surgical device for transoral surgery | Minim Invasive Ther Allied Technol. 2006;15(6):348-55. | results published in another paper (Cadiere 2008 18443855)
Cai Q;Barrie M;Olejeme H;Rosenberg MD; | A pilot study of efficacy and safety of continuous intravenous infusion of pantoprazole in the treatment of severe erosive esophagitis | Dig Dis Sci. 2008 Jun;53(6):1500-5. | med vs med < 4 weeks' duration
Calabrese C; Fabbri A; Bortolotti M; Cenacchi G; Carlo S; Zahlane D; Miglioli M;Di FG; | Effect of omeprazole on symptoms and ultrastructural esophageal damage in acid bile reflux | World J Gastroenterol. 2005 Mar 28;11(12):1876-80. | N<100
Calabrese C; Liguori G; Gabusi V; Gionchetti P; Rizzello F; Straforini G; Brugnera R; Di FG; | Ninety-six-hour wireless oesophageal pH monitoring following proton pump inhibitor administration in NERD patients | Aliment Pharmacol Ther. 2008 Jul;28(2):250-5. Epub 2008 May 12. | med vs med < 4 weeks' duration
Calabrese C; Trere D; Liguori G; Gabusi V; Vici M; Cenacchi G; Derenzini M; Di FG; | Esophageal cell proliferation in gastroesophageal reflux disease: clinical-morphological data before and after pantoprazole | World J Gastroenterol. 2009 Feb 28;15(8):936-41. | N<100
Carrau RL; Khidr A; Crawley JA; Hillson EM; Davis JK; Pashos CL; | The impact of laryngopharyngeal reflux on patient-reported quality of life | Laryngoscope. 2004 Apr;114(4):670-4. | not relevant
Casburn-Jones AC; Murray LS; Gillen D; McColl KE; | Endoscopy has minimal impact on mortality from upper gastrointestinal cancer in patients older than 55 years with uncomplicated dyspepsia | Eur J Gastroenterol Hepatol. 2006 Jun;18(6):645-8. | not population of interest
Casson AG; Madani K; Mann S; Zhao R; Reeder B; Lim HJ; | Does previous fundoplication alter the surgical approach to esophageal adenocarcinoma? | Eur J Cardiothorac Surg. 2008 Nov;34(5):1097-101; discussion 1101-2. Epub 2008 Sep 6. | population: patients with esophageal cancer
Castell D; Bagin R; Goldlust B; Major J; Hepburn B; | Comparison of the effects of immediate-release omeprazole powder for oral suspension and pantoprazole delayed-release tablets on nocturnal acid breakthrough in patients with symptomatic gastro-oesophageal reflux disease | Aliment Pharmacol Ther. 2005 Jun 15;21(12):1467-74. | <4 wk dose
Castro FM; Garcia DE; Larraona JL; Rodriguez Hornillo MC; Lamas RE; Nunez HD; Pallares QM; | Efficacy of low-dose lansoprazole in the treatment of non-erosive gastrooesophageal reflux disease. Influence of infection by Helicobacter pylori | Rev Esp Enferm Dig. 2006 Mar;98(3):170-9. | single arm study, Tx for 2 weeks only (<4 wk dose), no adverse events data
Ceccarelli G; Patriti A; Biancafarina A; Spaziani A; Bartoli A; Bellochi R; Casciola L; | Intraoperative and postoperative outcome of robot-assisted and traditional laparoscopic Nissen fundoplication | Eur Surg Res. 2009;43(2):198-203. Epub 2009 Jun 10. | comparison not of interest; follow up <5 years
Celik A; Loux TJ; Harmon CM; Saito JM; Georgeson KE; Barnhart DC; | Revision Nissen fundoplication can be completed laparoscopically with a low rate of complications: a single-institution experience with 72 children | J Pediatr Surg. 2006 Dec;41(12):2081-5. | pediatric patients
Chang EY; Minjarez RC; Kim CY; Seltman AK; Gopal DV; Diggs B; Davila R; Hunter JG; Jobe BA; | Endoscopic ultrasound for the evaluation of Nissen fundoplication integrity: a blinded comparison with conventional testing | Surg Endosc. 2007 Oct;21(10):1719-25. Epub 2007 Mar 8. | not relevant
Chen CL; Orr WC; | Autonomic responses to heartburn induced by esophageal acid infusion | J Gastroenterol Hepatol. 2004 Aug;19(8):922-6. | not relevant
Chen CL; Reif ME; Orr WC; | Effect of laparoscopic Nissen fundoplication on symptoms and gastric myoelectric activity in gastroesophageal reflux disease | J Clin Gastroenterol. 2006 Apr;40(4):301-5. | N<100; follow up <5 years
Chen LQ; Ferraro P; Martin J; Duranceau AC; | Antireflux surgery for Barrett's esophagus: comparative results of the Nissen and Collis-Nissen operations | Dis Esophagus. 2005;18(5):320-8. | comparisons of surgical techniques: N<100
Chin KF; Myers JC; Jamieson GG; Devitt PG; | Symptoms experienced during 24-h pH monitoring and their relationship to outcome after laparoscopic total fundoplication | Dis Esophagus. 2008;21(5):445-51. | predictor not of interest
Cicala M; Gabbrielli A; Emerenziani S; Guarino MP; Ribolsi M; Caviglia R; Costamagna G; | Effect of endoscopic augmentation of the lower oesophageal sphincter (Gatekeeper reflux repair system) on intraoesophageal dynamic characteristics of acid reflux.[see comment] | Gut. 2005 Feb;54(2):183-6. | This technology is not in use in the US
Ciovica R; Gadenstatter M; Klingler A; Lechner W; Riedl O; Schwab GP; | Quality of life in GERD patients: medical treatment vs. antireflux surgery | J Gastrointest Surg. 2006 Jul-Aug;10(7):934-9. | follow up <5 years
Ciovica R; Gadenstatter M; Klingler A; Neumayer C; Schwab GP; | Laparoscopic antireflux surgery provides excellent results and quality of life in gastroesophageal reflux disease patients with respiratory symptoms | J Gastrointest Surg. 2005 May-Jun;9(5):633-7. | Atypical GERD patients
Ciovica R; Riedl O; Neumayer C; Lechner W; Schwab GP; Gadenstatter M; | The use of medication after laparoscopic antireflux surgery | Surg Endosc. 2009 Sep;23(9):1938-46. Epub 2009 Jan 24. | FU < 5 years
Comte L; Vansteelandt S; Tousset E; Baxter G; Vrijens B; | Linear and loglinear structural mean models to evaluate the benefits of an on-demand dosing regimen | Clin Trials. 2009 Oct;6(5):403-15. Epub 2009 Sep 8. | Paper describes various mathematical models; no data on proportion of patients who are GERD and those who are dyspeptic patients, no data on outcomes
Conchillo JM; Schwartz MP; Selimah M; Samsom M; Arts J; Tack J; Sifrim D; Smout AJ; | Role of intra-oesophageal impedance monitoring in the evaluation of endoscopic gastroplication for gastro-oesophageal reflux disease | Aliment Pharmacol Ther. 2007 Jul 1;26(1):61-8. | not relevant - Use of impedance monitoring as an evaluation tool
Contini S; Scarpignato C; | Endoscopic treatment of gastro-oesophageal reflux disease (GORD): a systematic review | Dig Liver Dis. 2003 Nov;35(11):818-38. | SR of enoluminal procedures, all studies included are pre-2005
Cookson R; Flood C; Koo B; Mahon D; Rhodes M; | Short-term cost effectiveness and long-term cost analysis comparing laparoscopic Nissen fundoplication with proton-pump inhibitor maintenance for gastro-oesophageal reflux disease | Br J Surg. 2005 Jun;92(6):700-6. | cost-effectiveness analysis of surgical vs. ppi
Cote GA; Ferreira MR; Rozenberg-Ben-Dror K; Howden CW; | Programme of stepping down from twice daily proton pump inhibitor therapy for symptomatic gastro-oesophageal reflux disease associated with a formulary change at a VA medical center | Aliment Pharmacol Ther. 2007 Mar 15;25(6):709-14. | < 5 years FU
Cowgill SM; Arnaoutakis D; Villadolid D; Rosemurgy AS; | ‘Redo’ fundoplications: satisfactory symptomatic outcomes with higher cost of care | J Surg Res. 2007 Nov;143(1):183-8. | N<100
Csendes A; Bragheto I; Burdiles P; Smok G; Henriquez A; Parada F; | Regression of intestinal metaplasia to cardiac or fundic mucosa in patients with Barrett's esophagus submitted to vagotomy, partial gastrectomy and duodenal diversion. A prospective study of 78 patients with more than 5 years of follow up.[see comment] | Surgery. 2006 Jan;139(1):46-53. | all patients with Barrett's
Csendes A; Burgos AM; Smok G; Burdiles P; Henriquez A; | Effect of gastric bypass on Barrett's esophagus and intestinal metaplasia of the cardia in patients with morbid obesity | J Gastrointest Surg. 2006 Feb;10(2):259-64. | Population (morbidly obese) and intervention (gastric bypass) are not relevant
Dachs R; rby-Stewart A; Graber M; | Choosing one PPI treatment over another | Am Fam Physician. 2007 Nov 1;76(9):1273-4. | review paper
D'Alessio MJ; Rakita S; Bloomston M; Chambers CM; Zervos EE; Goldin SB; Poklepovic J; Boyce HW; Rosemurgy AS; | Esophagography predicts favorable outcomes after laparoscopic Nissen fundoplication for patients with esophageal dysmotility | J Am Coll Surg. 2005 Sep;201(3):335-42. | Makes no distinction b/n GERD and hiatus hernia patients
Dan D; Seetahal S; Naraynsingh V; | Laparoscopic Nissen fundoplication for improved gastrointestinal symptoms and quality of life | West Indian Med J. 2009 Jan;58(1):8-12. | N<100
Davis RE; Iqbal A; Gerhardt JD; Welch RA; Turaga K; Tierney B; Haider M; Filipi CJ; | A long-term comparison of plication configurations for endoluminal gastroplication: circumferential versus helical | J Clin Gastroenterol. 2005 Nov-Dec;39(10):869-76. | surg comparison (circumferential vs. helical) but <50 per arm, <5 y f/u
de Boer W; de WN; Geldof H; Hazelhoff B; Bergmans P; Smout A; Tytgat G; | Does Helicobacter pylori infection influence response rate or speed of symptom control in patients with gastroesophageal reflux disease treated with rabeprazole? | Scand J Gastroenterol. 2006 Oct;41(10):1147-54. | <4 wk Rx
de J; van RB; Timmer R; Gooszen HG; Smout AJ; | The influence of laparoscopic adjustable gastric banding on gastroesophageal reflux | Obes Surg. 2004 Mar;14(3):399-406. | not relevant
de J;van RB;Timmer R;Gooszen HG;Smout AJ; | Effect of laparoscopic gastric banding on esophageal motility | Obes Surg. 2006 Jan;16(1):52-8. | not relevant
De Jonge PJ; Siersema PD; Van Breda SG; Van Zoest KP; Bac DJ; Leeuwenburgh I; Ouwendijk RJ; Van DH; Kusters JG; Kuipers EJ; | Proton pump inhibitor therapy in gastro-oesophageal reflux disease decreases the oesophageal immune response but does not reduce the formation of DNA adducts | Aliment Pharmacol Ther. 2008 Jul;28(1):127-36. Epub 2008 Mar 31. | no outcome of interest (cellular immune response; oxidative DNA damage)
de Souza CM; Ferrari AP; Ciconelli R; Ferraz MB; Moraes-Filho JP; | Evaluation of health-related quality of life in gastroesophageal reflux disease patients before and after treatment with pantoprazole | Dis Esophagus. 2006;19(4):289-93. | not RCT med rx; N<100
del Genio G; Rossetti G; Brusciano L; Maffettone V; Napolitano V; Pizza F; Tolone S; del GA; Di MM; | Laparoscopic Nissen-Rossetti fundoplication is effective to control gastro-oesophageal and pharyngeal reflux detected using 24-hour oesophageal impedance and pH monitoring (MII-pH) | Acta Otorhinolaryngol Ital. 2006 Oct;26(5):287-92. | duplicate publication: same population as del Genio 2007
del Genio G; Tolone S; del GF; Aggarwal R; d'Alessandro A; Allaria A; Rossetti G; Brusciano L; del GA; | Prospective assessment of patient selection for antireflux surgery by combined multichannel intraluminal impedance pH monitoring | J Gastrointest Surg. 2008 Sep;12(9):1491-6. Epub 2008 Jul 9. | Evaluation of the use of multichannel intraluminal impedance pH monitoring (MII-pH) for patient selection in anti-reflux surgery
del Genio G; Tolone S; Rossetti G; Brusciano L; del GF; Pizza F; Russo F; Di MM; Napolitano V; del GA; | Total fundoplication does not obstruct the esophageal secondary peristalsis: investigation with pre- and postoperative 24-hour pH-multichannel intraluminal impedance | Eur Surg Res. 2008;40(2):230-4. Epub 2007 Nov 20. | N<100; follow up <5 years
del Genio G; Tolone S; Rossetti G; Brusciano L; Pizza F; del GF;Russo F;Di MM; Lucido F;Barra L; Maffettone V; Napolitano V; del GA; | Objective assessment of gastroesophageal reflux after extended Heller myotomy and total fundoplication for achalasia with the use of 24-hour combined multichannel intraluminal impedance and pH monitoring (MII-pH) | Dis Esophagus. 2008;21(7):664-7. Epub 2008 Jun 17. | achalasia not considered in this review
Dent J; Kahrilas PJ; Hatlebakk J; Vakil N; Denison H; Franzen S; Lundborg P; | A randomized, comparative trial of a potassium-competitive acid blocker (AZD0865) and esomeprazole for the treatment of patients with nonerosive reflux disease | Am J Gastroenterol. 2008 Jan;103(1):20-6. | AZD0865 was discontinued from clinical development after analysis showed that AZD0865 did not show additional clinical efficacy compared to PPI treatment AZD0865 was being developed for acid related GI disease. Drug was discontinued in 2005. http://www.as
des Varannes SB; Sacher-Huvelin S; Vavasseur F; Masliah C; Le RM; Aygalenq P; Bonnot-Marlier S; Lequeux Y; Galmiche JP; | Rabeprazole test for the diagnosis of gastro-oesophageal reflux disease: results of a study in a primary care setting | World J Gastroenterol. 2006 Apr 28;12(16):2569-73. | not relevant
Dettmar PW; Hampson FC; Jain A; Choubey S; Little SL; Baxter T; | Administration of an alginate based gastric reflux suppressant on the bioavailability of omeprazole.[see comment] | Indian J Med Res. 2006 Apr;123(4):517-24. | Assesses drug interaction between 10 per cent w/v liquid alginate suspension and omeprazole
Dettmar PW; Hampson FC; Taubel J; Lorch U; Johnstone LM; Sykes J; Berry PJ; | The suppression of gastro-oesophageal reflux by alginates | Int J Clin Pract. 2007 Oct;61(10):1654-62. Epub 2007 Aug 6. | not GERD patients
Dettmar PW; Sykes J; Little SL; Bryan J; | Rapid onset of effect of sodium alginate on gastro-oesophageal reflux compared with ranitidine and omeprazole, and relationship between symptoms and reflux episodes | Int J Clin Pract. 2006 Mar;60(3):275-83. | med vs med < 4 weeks' duration
Dickman R; Emmons S; Cui H; Sewell J; Hernandez D; Esquivel RF; Fass R; | The effect of a therapeutic trial of high-dose rabeprazole on symptom response of patients with non-cardiac chest pain: a randomized, double-blind, placebo-controlled, crossover trial | Aliment Pharmacol Ther. 2005 Sep 15;22(6):547-55. | Outcome is Atypical GERD -non-cardiac chest pain
Diculescu M; Iacob R; Chira C; Mihaila D; Iacob S; | Esomeprazole in the treatment of patients with heartburn and other upper gastrointestinal symptoms, referred to primary care -- results of the in-practice evaluation program in Romania.[see comment] | Rom J Gastroenterol. 2005 Mar;14(1):9-14. | med cohort with no AE reported
Dotan E; Katz R; Bratcher J; Wasserman C; Liebman M; Panagopoulos G; Spaccavento C; | The prevalence of pantoprozole associated thrombocytopenia in a community hospital | Expert Opin Pharmacother. 2007 Sep;8(13):2025-8. | no information on patient's diagnoses
Draaisma WA; Ruurda JP; Scheffer RC; Simmermacher RK; Gooszen HG; Rijnhart-De Jong HG; Buskens E; Broeders IA; | Randomized clinical trial of standard laparoscopic versus robot-assisted laparoscopic Nissen fundoplication for gastro-oesophageal reflux disease | Br J Surg. 2006 Nov;93(11):1351-9. | follow up <5 years
Duh MS; Gosselin A; Luo R; Lohoues H; Lewis BE; Crawley JA; | Impact of compliance with proton pump inhibitors on NSAID treatment | Am J Manag Care. 2009 Oct;15(10):681-8. | Cointervention being assessed (NSAID Rx) is not of interest
El-Serag HB; Fitzgerald S; Richardson P; | The extent and determinants of prescribing and adherence with acid-reducing medications: a national claims database study | Am J Gastroenterol. 2009 Sep;104(9):2161-7. Epub 2009 Jun 30. | PPI prescription patterns are not of interest. retrospective cohort study of PI and H2RA prescribing practices and compliance
El-Serag HB; Wieman M; Richardson P; | The use of acid-decreasing medication in veteran patients with gastro-oesophageal reflux disorder with and without Barrett's oesophagus | Aliment Pharmacol Ther. 2008 Jun;27(12):1293-9. Epub 2008 Mar 21. | not relevant; retrospective cohort study on the extent of PPI use in patients with newly diagnosed GERD with and without BO and to examine other potential determinants of PPI use in these patients.
el-Sherif AE; Adusumilli PS; Pettiford BL; d'Amato TA; Schuchert MJ; Clark A; DiRenzo C; Landreneau JP; Luketich JD; Landreneau RJ; | Laparoscopic clam shell partial fundoplication achieves effective reflux control with reduced postoperative dysphagia and gas bloating | Ann Thorac Surg. 2007 Nov;84(5):1704-9. | adverse events: not the primary outcome
Engstrom C; Lonroth H; Mardani J; Lundell L; | An anterior or posterior approach to partial fundoplication? Long-term results of a randomized trial | World J Surg. 2007 Jun;31(6):1221-5; discussion 1226-7. Epub 2007 Apr 24. | no comparions of interest; subjects <100
Engstrom C; Ruth M; Lonroth H; Lundell L; | Manometric characteristics of the gastroesophageal junction after anterior versus posterior partial fundoplication | Dis Esophagus. 2005;18(1):31-6. | N<50; follow-up<5 year
Epstein D; Bojke L; Sculpher MJ; REFLUX trial group; | Laparoscopic fundoplication compared with medical management for gastro-oesophageal reflux disease: cost effectiveness study. | BMJ. 2009 Jul 14;339:b2576. doi: 10.1136/bmj.b2576. | cost-effectiveness analysis
Fallone CA; Guyatt GH; Armstrong D; Wiklund I; Degl'innocenti A; Heels-Ansdell D; Barkun AN; Chiba N; Zanten SJ; El-Dika S; Austin P; Tanser L; Schunemann HJ; | Do physicians correctly assess patient symptom severity in gastro-oesophageal reflux disease? | Aliment Pharmacol Ther. 2004 Nov 15;20(10):1161-9. | not relevant
Farah JF; Grande JC; Goldenberg A; Martinez JC; Lupinacci RA; Matone J; | Randomized trial of total fundoplication and fundal mobilization with or without division of short gastric vessels: a short-term clinical evaluation | Acta Cir Bras. 2007 Nov-Dec;22(6):422-9. | <50 per arm, <5 y f/u
Farup PG HM; Heibert M; Hoeg V; | Alternative vs. conventional treatment given on-demand for gastroesophageal reflux disease: a randomised controlled trial | BMC Complement Altern Med. 2009 Feb 24;9:3. | pectin-based, raft-forming, natural, anti-reflux agent (PRA) is not a medication iof interest
Feng L; Tan CH; Merchant RA; Ng TP; | Association between depressive symptoms and use of HMG-CoA reductase inhibitors (statins), corticosteroids and histamine H(2) receptor antagonists in community-dwelling older persons: cross-sectional analysis of a population-based cohort | Drugs Aging. 2008;25(9):795-805. | not relevant
Fennerty MB; Johnson DA; | Heartburn severity does not predict disease severity in patients with erosive esophagitis | MedGenMed. 2006 Apr 6;8(2):6. | 5 separate RCTs
Foroulis CN; Thorpe JA; | Photodynamic therapy (PDT) in Barrett's esophagus with dysplasia or early cancer | Eur J Cardiothorac Surg. 2006 Jan;29(1):30-4. Epub 2005 Dec 6. | Population: Barrett's esophagus complicated with high-grade dysplasia and/or early esophageal adenocarcinoma
Franke A; Hepp C; Harder H; Beglinger C; Singer MV; | Esomeprazole reduces gastroesophageal reflux after beer consumption in healthy volunteers | Scand J Gastroenterol. 2008;43(12):1425-31. | Population: healthy volunteers without a history of GERD
Frantzides CT; Carlson MA; Zografakis JG; Moore RE; Zeni T; Madan AK; | Postoperative gastrointestinal complaints after laparoscopic Nissen fundoplication | JSLS. 2006 Jan-Mar;10(1):39-42. | follow-up <5 years
Franzen T; Anderberg B; Wiren M; Johansson KE; | Long-term outcome is worse after laparoscopic than after conventional Nissen fundoplication | Scand J Gastroenterol. 2005 Nov;40(11):1261-8. | f/u <5 years
Frazzoni M; Manno M; De ME; Savarino V; | Efficacy in intra-oesophageal acid suppression may decrease after 2-year continuous treatment with proton pump inhibitors | Dig Liver Dis. 2007 May;39(5):415-21. Epub 2007 Mar 26. | patients with Barrett's esophagus or severe reflux oesophagitis
Frazzoni M; Manno M; De ME; Savarino V; | Intra-oesophageal acid suppression in complicated gastro-oesophageal reflux disease: esomeprazole versus lansoprazole | Dig Liver Dis. 2006 Feb;38(2):85-90. Epub 2005 Nov 10. | patients with Barrett's esophagus or ulcerative reflux oesophagitis
Frezza EE; Dissanaike S; Wachtel MS; | Laparoscopic highly selective vagotomy with nissen fundoplication: is there any role? | Surg Laparosc Endosc Percutan Tech. 2007 Oct;17(5):361-4. | N<100; follow-up <5 yr
Fuchs KH; Breithaupt W; Fein M; Maroske J; Hammer I; | Laparoscopic Nissen repair: indications, techniques and long-term benefits | Langenbecks Arch Surg. 2005 Jun;390(3):197-202. Epub 2004 Jul 3. | review
Funch-Jensen P; Bendixen A; Iversen MG; Kehlet H; | Complications and frequency of redo antireflux surgery in Denmark: a nationwide study, 1997-2005 | Surg Endosc. 2008 Mar;22(3):627-30. Epub 2007 Dec 11. | Primary fundoplication group not homogenous GERD population--unable to distinguish b/w surgery for GERD or paraesophageal hernia
Gad El-Hak N; Abo ZM; Aboelenen A; Fouad A; Abd AT; El-Shoubary M; Kandel T; Hamdy E; Abdel WM; Fathy O; El-ebidy G; Sultan A; Elfiky A; Elghwalby N; Ezzat F; | Short gastric vessels division in Laparoscopic Nissen Fundoplication | Hepatogastroenterology. 2005 Nov-Dec;52(66):1742-7. | follow-up <5 years
Garcia Rodriguez LA; Lagergren J; Lindblad M; | Gastric acid suppression and risk of oesophageal and gastric adenocarcinoma: a nested case control study in the UK.[see comment] | Gut. 2006 Nov;55(11):1538-44. Epub 2006 Jun 19. | not population of interest
Garcia Rodriguez LA; Ruigomez A; Panes J; | Use of acid-suppressing drugs and the risk of bacterial gastroenteritis.[see comment] | Clin Gastroenterol Hepatol. 2007 Dec;5(12):1418-23. | not GERD patients
Garg N; Yano F; Filipi CJ; Mittal SK; | Long-term symptomatic outcomes after Collis gastroplasty with fundoplication | Dis Esophagus. 2009;22(6):532-8. Epub 2009 Feb 13. | < 100 patients
Geevasinga N; Coleman PL; Webster AC; Roger SD; | Proton pump inhibitors and acute interstitial nephritis.[see comment] | Clin Gastroenterol Hepatol. 2006 May;4(5):597-604. | not GERD patients
Ghosh A; Halder S; Mandal S; Mandal A; Basu M; Dabholkar P; | Rabeto plus: a valuable drug for managing functional dyspepsia | J Indian Med Assoc. 2008 Nov;106(11):752-4. | Med pre- and post trial, <4wk, itopride is not of interest, not sure what is “rabeto plus”?
Ghoshal UC; Chourasia D; Tripathi S; Misra A; Singh K; | Relationship of severity of gastroesophageal reflux disease with gastric acid secretory profile and esophageal acid exposure during nocturnal acid breakthrough: a study using 24-h dual-channel pH-metry | Scand J Gastroenterol. 2008;43(6):654-61. | not relevant
Gillies RS; Stratford JM; Booth MI; Dehn TC; | Does laparoscopic antireflux surgery improve quality of life in patients whose gastro-oesophageal reflux disease is well controlled with medical therapy? | Eur J Gastroenterol Hepatol. 2008 May;20(5):430-5. | N<100; follow up <5 years
Gisbert JP; Cooper A; Karagiannis D; Hatlebakk J; Agreus L; Jablonowski H; Zapardiel J; | Impact of gastroesophageal reflux disease on patients' daily lives: a European observational study in the primary care setting | Health Qual Life Outcomes. 2009 Jul 2;7:60. | Not relevant; crosssectional study
Goessler A; Huber-Zeyringer A; Hoellwarth ME; | Recurrent gastroesophageal reflux in neurologically impaired patients after fundoplication | Acta Paediatr. 2007 Jan;96(1):87-93. | Population: mentally retarded children
Granderath FA; Granderath UM; Pointner R; | Laparoscopic revisional fundoplication with circular hiatal mesh prosthesis: the long-term results | World J Surg. 2008 Jun;32(6):999-1007. | Population: previous anti-reflux surgery
Granderath FA; Kamolz T; Granderath UM; Pointner R; | Gas-related symptoms after laparoscopic 360 degrees Nissen or 270 degrees Toupet fundoplication in gastrooesophageal reflux disease patients with aerophagia as comorbidity.[see comment] | Dig Liver Dis. 2007 Apr;39(4):312-8. Epub 2007 Feb 15. | no comparator of interest
Granderath FA; Kamolz T; Schweiger UM; Pointner R; | Impact of laparoscopic nissen fundoplication with prosthetic hiatal closure on esophageal body motility: Results of a prospective randomized trial.[see comment][erratum appears in Arch Surg. 2007 Jun;142(6):579] | Arch Surg. 2006 Jul;141(7):625-32. | no intervention of interest: laparoscopic Nissen fundoplication with prosthetic hiatal closure/with simple sutured hiatal closure
Granderath FA; Schweiger UM; Kamolz T; Asche KU; Pointner R; | Laparoscopic Nissen fundoplication with prosthetic hiatal closure reduces postoperative intrathoracic wrap herniation: preliminary results of a prospective randomized functional and clinical study | Arch Surg. 2005 Jan;140(1):40-8. | no intervention of interest: laparoscopic Nissen fundoplication with prosthetic hiatal closure/with simple sutured hiatal closure
Granderath FA; Schweiger UM; Kamolz T; Pointner R; | Dysphagia after laparoscopic antireflux surgery: a problem of hiatal closure more than a problem of the wrap.[see comment] | Surg Endosc. 2005 Nov;19(11):1439-46. Epub 2005 Sep 30. | Identification of the morphologic cause of dysphagia after laparoscopic antireflux surgery
Granderath FA; Schweiger UM; Pointner R; | Laparoscopic antireflux surgery: tailoring the hiatal closure to the size of hiatal surface area.[see comment] | Surg Endosc. 2007 Apr;21(4):542-8. Epub 2006 Nov 14. | Evaluating different methods of crural closure by the size of the hiatal defect
Grant A; Wileman S; Ramsay C; Bojke L; Epstein D; Sculpher M; Macran S; Kilonzo M; Vale L; Francis J; Mowat A; Krukowski Z; Heading R; Thursz M; Russell I; Campbell M; REFLUX trial group; | The effectiveness and cost-effectiveness of minimal access surgery amongst people with gastro-oesophageal reflux disease - a UK collaborative study. The REFLUX trial | Health Technol Assess. 2008 Sep;12(31):1-181, iii-iv. | Duplicate (UI 19074946)
Grigolon A; Cantu P; Savojardo D; Conte D; Penagini R; | Esophageal acid exposure on proton pump inhibitors in unselected asymptomatic gastroesophageal reflux disease patients | J Clin Gastroenterol. 2008 Oct;42(9):969-73. | non-RCT med comparison; N<100
Grotenhuis BA; Wijnhoven BP; Bessell JR; Watson DI; | Laparoscopic antireflux surgery in the elderly | Surg Endosc. 2008 Aug;22(8):1807-12. Epub 2007 Dec 20. | study not specific for adverse events
Guerin E; Betroune K; Closset J; Mehdi A; Lefebvre JC; Houben JJ; Gelin M; Vaneukem P; El N; | Nissen versus Toupet fundoplication: results of a randomized and multicenter trial | Surg Endosc. 2007 Nov;21(11):1985-90. | follow up <5 yr
Guirguis-Blake J; | Medical treatments in the short-term management of reflux esophagitis | Am Fam Physician. 2008 Mar 1;77(5):620. | Cochrane briefs
Gutschow CA; Collet P; Prenzel K; Holscher AH; Schneider PM; | Long-term results and gastroesophageal reflux in a series of laparoscopic adjustable gastric banding | J Gastrointest Surg. 2005 Sep-Oct;9(7):941-8. | The population studied as well as the intervention used is not relevant
Hakanson BS; Thor KB; Thorell A; Ljungqvist O; | Open vs laparoscopic partial posterior fundoplication. A prospective randomized trial | Surg Endosc. 2007 Feb;21(2):289-98. Epub 2006 Nov 21. | follow up <5 yr
Hamamoto N; Hashimoto T; Adachi K; Hirakawa K; Ishihara S;Inoue H; Taniura H; Niigaki M; Sato S; Kushiyama Y; Suetsugu H; Miyake T; Kinoshita Y; | Comparative study of nizatidine and famotidine for maintenance therapy of erosive esophagitis | J Gastroenterol Hepatol. 2005 Feb;20(2):281-6. | H2RA vs H2RA not comparator of interest
Hartmann J; Jacobi CA; Menenakos C; Ismail M; Braumann C; | Surgical treatment of gastroesophageal reflux disease and upside-down stomach using the Da Vinci robotic system. A prospective study | J Gastrointest Surg. 2008 Mar;12(3):504-9. Epub 2007 Nov 20. | system experimental, follow up <5 yr
Hartmann J; Menenakos C; Ordemann J; Nocon M; Raue W; Braumann C; | Long-term results of quality of life after standard laparoscopic vs. robot-assisted laparoscopic fundoplications for gastro-oesophageal reflux disease. A comparative clinical trial | Int J Med Robot. 2009 Mar;5(1):32-7. | system experimental, follow up <5 yr
Hawkey C; Talley NJ; Yeomans ND; Jones R; Sung JJ; Langstrom G; Naesdal J; Scheiman JM; Study Group; | Improvements with esomeprazole in patients with upper gastrointestinal symptoms taking non-steroidal antiinflammatory drugs, including selective COX-2 inhibitors | Am J Gastroenterol. 2005 May;100(5):1028-36. | The study population included people with chronic conditions who were chronic (>7 months) continuous users of NSAID; not GERD patients.
Heemskerk J; van Gemert WG; Greve JW; Bouvy ND; | Robot-assisted versus conventional laparoscopic Nissen fundoplication: a comparative retrospective study on costs and time consumption | Surg Laparosc Endosc Percutan Tech. 2007 Feb;17(1):1-4. | non-RCT surgical tx, N<100
Hogan D; Pratha V; Riff D; Ducker S; Schwartz H; Soffer E; Wang W; Rath N; Comer GM; | Oral pantoprazole in the form of granules or tablets are pharmacodynamically equivalent in suppressing acid output in patients with gastro-oesophageal reflux disease and a history of erosive oesophagitis | Aliment Pharmacol Ther. 2007 Jul 15;26(2):249-56. | no clinical outcome of interest
Hongo M; Kinoshita Y; Haruma K; | A randomized, double-blind, placebo-controlled clinical study of the histamine H2-receptor antagonist famotidine in Japanese patients with nonerosive reflux disease | J Gastroenterol. 2008;43(6):448-56. Epub 2008 Jul 4. | H2RA vs placebo not comparator of interest
Hongo M; Kinoshita Y; Miwa H; Ashida K; | The demographic characteristics and health-related quality of life in a large cohort of reflux esophagitis patients in Japan with reference to the effect of lansoprazole: the REQUEST study | J Gastroenterol. 2008;43(12):920-7. Epub 2008 Dec 24. | Not focused on AE
Horowitz N; Moshkowitz M; Leshno M; Ribak J; Birkenfeld S; Kenet G; Halpern Z; | Clinical trial: evaluation of a clinical decision-support model for upper abdominal complaints in primary-care practice | Aliment Pharmacol Ther. 2007 Nov 1;26(9):1277-83. | study intervention was a medical algorithm, which is not of interest
Horstmann R; Classen C; Rottgermann S; Langer M; Palmes D; | Long-term experience of treating 185 patients with gastroesophageal reflux disease (GERD) by anti-reflux surgery respecting the functional-morphological restoration of the esophagus | Langenbecks Arch Surg. 2006 Feb;391(1):24-31. Epub 2005 Nov 18. | intervention not of interest, f/u<5 yr
Howden CW; Ballard ED; Koch FK; Gautille TC; Bagin RG; | Control of 24-hour intragastric acidity with morning dosing of immediate-release and delayed-release proton pump inhibitors in patients with GERD | J Clin Gastroenterol. 2009 Apr;43(4):323-6. | < 4 weeks duration
Hubbard N; Velanovich V; | Endoscopic endoluminal radiofrequency ablation of Barrett's esophagus in patients with fundoplications | Surg Endosc. 2007 Apr;21(4):625-8. Epub 2007 Feb 16. | patients with fundoplication and Barrett's esophagus
Hughes JD; Tanpurekul W; Keen NC; Ee HC; | Reducing the cost of proton pump inhibitors by adopting best practice | Qual Prim Care. 2009;17(1):15-21. | Descriptive study of prescribing characteristics as well as cost; no data on effect of PPI
Hunt RH ;Armstrong D; Yaghoobi M; James C; Chen Y; Leonard J; Shin JM; Lee E; Tang-Liu D; Sachs G; | Predictable prolonged suppression of gastric acidity with a novel proton pump inhibitor, AGN 201904-Z | Aliment Pharmacol Ther. 2008 Jul;28(2):187-99. Epub 2008 Apr 25. | Not a population of interest - healthy male volunteers
Inamori M; Togawa J; Iwasaki T; Ozawa Y; Kikuchi T; Muramatsu K; Chiguchi G; Matsumoto S; Kawamura H; Abe Y; Kirikoshi H; Kobayashi N; Shimamura T; Kubota K; Sakaguchi T; Saito S; Ueno N; Nakajima A; | Early effects of lafutidine or rabeprazole on intragastric acidity: which drug is more suitable for on-demand use?[see comment] | J Gastroenterol. 2005 May;40(5):453-8. | Population: healthy male volunteers
Jensen CD; Gilliam AD; Horgan LF; Bawa S; Attwood SE; | Day-case laparoscopic Nissen fundoplication | Surg Endosc. 2009 Aug;23(8):1745-9. Epub 2008 Oct 15. | f/u <5 years
Jeske HC; Borovicka J; von GA; Tiefenthaler W; Hohlrieder M; Heidegger T; Benzer A; | Preoperative administration of esomeprazole has no influence on frequency of refluxes | J Clin Anesth. 2008 May;20(3):191-5. | Enrolled healthy volunteers; Not the population of interest
Johnson DA; Stacy T; Ryan M; Wootton T; Willis J; Hornbuckle K; Brooks W; Doviak M; | A comparison of esomeprazole and lansoprazole for control of intragastric pH in patients with symptoms of gastro-oesophageal reflux disease | Aliment Pharmacol Ther. 2005 Jul 15;22(2):129-34. | med vs med < 4 weeks' duration
Johnston MH; Eastone JA; Horwhat JD; Cartledge J; Mathews JS; Foggy JR; | Cryoablation of Barrett's esophagus: a pilot study.[see comment] | Gastrointest Endosc. 2005 Dec;62(6):842-8. | patients with Barrett's esophagus
Jones R; Patrikios T; | The effectiveness of esomeprazole 40 mg in patients with persistent symptoms of gastro-oesophageal reflux disease following treatment with a full dose proton pump inhibitor | Int J Clin Pract. 2008 Dec;62(12):1844-50. | med cohort N<100
Kahrilas PJ; Dent J; Lauritsen K; Malfertheiner P; Denison H; Franzen S; Hasselgren G; | A randomized, comparative study of three doses of AZD0865 and esomeprazole for healing of reflux esophagitis | Clin Gastroenterol Hepatol. 2007 Dec;5(12):1385-91. Epub 2007 Oct 22. | AZD0865 was discontinued from clinical development after analysis showed that AZD0865 did not show additional clinical efficacy compared to PPI treatment AZD0865 was being developed for acid related GI disease. Drug was discontinued in 2005. http://www.as
Kahrilas PJ; Miner P; Johanson J; Mao L; Jokubaitis L; Sloan S; | Efficacy of rabeprazole in the treatment of symptomatic gastroesophageal reflux disease | Dig Dis Sci. 2005 Nov;50(11):2009-18. | PPI vs placebo is excluded
Kaspari S; Kupcinskas L; Heinze H; Berghofer P; | Pantoprazole 20 mg on demand is effective in the long-term management of patients with mild gastro-oesophageal reflux disease | Eur J Gastroenterol Hepatol. 2005 Sep;17(9):935-41. | PPI vs placebo is excluded
Katz PO; Koch FK; Ballard ED; Bagin RG; Gautille TC; Checani GC; Hogan DL; Pratha VS; | Comparison of the effects of immediate-release omeprazole oral suspension, delayed-release lansoprazole capsules and delayed-release esomeprazole capsules on nocturnal gastric acidity after bedtime dosing in patients with night-time GERD symptoms | Aliment Pharmacol Ther. 2007 Jan 15;25(2):197-205. | RCT < 4 wk
Kelly JJ; Watson DI; Chin KF; Devitt PG; Game PA; Jamieson GG; | Laparoscopic Nissen fundoplication: clinical outcomes at 10 years | J Am Coll Surg. 2007 Oct;205(4):570-5. Epub 2007 Aug 23. | f/u <5 years
Keywood C; Wakefield M; Tack J; | A proof-of-concept study evaluating the effect of ADX10059, a metabotropic glutamate receptor-5 negative allosteric modulator, on acid exposure and symptoms in gastro-oesophageal reflux disease | Gut. 2009 Sep;58(9):1192-9. Epub 2009 May 20. | med vs med < 4 weeks' duration
Khajanchee YS; Dunst CM; Swanstrom LL; | Outcomes of Nissen fundoplication in patients with gastroesophageal reflux disease and delayed gastric emptying | Arch Surg. 2009 Sep;144(9):823-8. | follow-up < 5 years
Khan A; Cho I; Traube M; | Patients with throat symptoms on Acid suppressive therapy: do they have reflux? | Dig Dis Sci. 2010 Feb;55(2):346-50. Epub 2009 Mar 3. | Data for our purposes not available?
Khan MA; Smythe A; Globe J; Stoddard CJ; Ackroyd R; | Randomized controlled trial of laparoscopic Nissen versus Lind fundoplication for gastro-oesophageal reflux disease | Scand J Gastroenterol. 2009;44(3):269-75. | follow-up < 5 years
Kim JH; Sinn DH; Son HJ; Kim JJ; Rhee JC; Rhee PL; | Comparison of one-week and two-week empirical trial with a high-dose rabeprazole in non-cardiac chest pain patients | J Gastroenterol Hepatol. 2009 Sep;24(9):1504-9. | No comparator, Trial < 4 weeks, PPI used as diagnositic tool for GERD-related NCCP; Only 38% of pts with GERD
Kinoshita Y; Kobayashi T; Kato M; Asahina K; Haruma K; Shimatani T; Inoue S; Kabemura T; Kurosawa S; Kuwayama H; Ashida K; Hirayama M; Kiyama S; Yamamoto M; Suzuki J; Suzuki H; Matsumoto K; Aoshima M; | The pharmacodynamic effect of omeprazole 10 mg and 20 mg once daily in patients with nonerosive reflux disease in Japan | J Gastroenterol. 2006 Jun;41(6):554-61. | med vs med < 4 weeks' duration
Kornmo TS; Ruud TE; | Long-term results of laparoscopic Nissen fundoplication due to gastroesophageal reflux disease. A ten year follow-up in a low volume center | Scand J Surg. 2008;97(3):227-30. | N<100
Kundhal PS; Harnish JL; Urbach DR; | Effect of surgeon on outcome of antireflux surgery | Surg Endosc. 2007 Jun;21(6):902-6. Epub 2006 Nov 14. | no modifier of interest; N<100
Kunsch S; Neesse A; Linhart T; Steinkamp M; Fensterer H; Adler G; Gress TM; Ellenrieder V; | Impact of pantoprazole on duodeno-gastro-esophageal reflux (DGER) | Z Gastroenterol. 2009 Mar;47(3):277-82. Epub 2009 Mar 11. | condition not considered in this review
Kusano M; Shimoyama Y; Kawamura O; Maeda M; Kuribayashi S; Nagoshi A; Zai H; Moki F; Horikoshi T; Toki M; Sugimoto S; Mori M; | Proton pump inhibitors improve acid-related dyspepsia in gastroesophageal reflux disease patients | Dig Dis Sci. 2007 Jul;52(7):1673-7. Epub 2007 Mar 24. | PPIs (rabeprazole+lansoprazole+o meprazole)
Kusano M; Shirai N; Yamaguchi K; Hongo M; Chiba T; Kinoshita Y; Acid-Related Symptom (ARS) Research Group; | It is possible to classify non-erosive reflux disease (NERD) patients into endoscopically normal groups and minimal change groups by subjective symptoms and responsiveness to rabeprazole -- a report from a study with Japanese patients | Dig Dis Sci. 2008 Dec;53(12):3082-94. Epub 2008 May 9. | classification of non-erosive reflux disease patients
Kushner PR; Snoddy AM; Gilderman L; Peura DA; | Lansoprazole 15 mg once daily for 14 days is effective for treatment of frequent heartburn: results of 2 randomized, placebo-controlled, double-blind studies | Postgrad Med. 2009 Jul;121(4):67-75. | med vs med < 4 weeks' duration
Labenz J; Nocon M; Lind T; Leodolter A; Jaspersen D; Meyer-Sabellek W; Stolte M; Vieth M; Willich SN; Malfertheiner P; | Prospective follow-up data from the ProGERD study suggest that GERD is not a categorial disease.[see comment] | Am J Gastroenterol. 2006 Nov;101(11):2457-62. Epub 2006 Oct 4. | progression or regression of GERD under routine care
Lagergren J; Viklund P; | Is esophageal adenocarcinoma occurring late after antireflux surgery due to persistent postoperative reflux?[see comment] | World J Surg. 2007 Mar;31(3):465-9. | case-contol study of esophageal adenocarcinoma
Lamb PJ; Myers JC; Thompson SK; Jamieson GG; | Laparoscopic fundoplication in patients with a hypertensive lower esophageal sphincter | J Gastrointest Surg. 2009 Jan;13(1):61-5. Epub 2008 Sep 7. | N<100
Lazebnik LB DVKV; | [Efficiency of famotidin in prophylaxis of NSAIDs-induced gastropathy: result of multicenter research ZASLON-1 (protection of gastric mucosa from non-steroidal anti-inflammatory drugs] | Eksp Klin Gastroenterol. 2009;(2):3-9. | Not GERD nor GERD tx (NSAID)? Article in Russian
Lecuyer M; Cousin T; Monnot MN; Coffin B; | Efficacy of an activated charcoal-simethicone combination in dyspeptic syndrome: results of a randomized prospective study in general practice | Gastroenterol Clin Biol. 2009 Jun-Jul;33(6-7):478-84. Epub 2009 Apr 5. | not treatment of interest
Lee ES; Kim N; Lee SH; Park YS; Kim JW; Jeong SH; Lee DH; Jung HC; Song IS; | Comparison of risk factors and clinical responses to proton pump inhibitors in patients with erosive oesophagitis and non-erosive reflux disease | Aliment Pharmacol Ther. 2009 Jul 1;30(2):154-64. Epub 2009 Apr 15. | comparison not of interest-no individual data by drug
Lindeboom MY; Ringers J; Straathof JW; van Rijn PJ; Neijenhuis P; Masclee AA; | The effect of laparoscopic partial fundoplication on dysphagia, esophageal and lower esophageal sphincter motility | Dis Esophagus. 2007;20(1):63-8. | sample size <100 for KQ3
Lippmann QK; Crockett SD; Dellon ES; Shaheen NJ; | Quality of life in GERD and Barrett's esophagus is related to gender and manifestation of disease | Am J Gastroenterol. 2009 Nov;104(11):2695-703. Epub 2009 Sep 15. | No treatments
Lu M; Malladi V; Agha A; Abudayyeh S; Han C; Siepman N; Graham DY; | Failures in a proton pump inhibitor therapeutic substitution program: lessons learned | Dig Dis Sci. 2007 Oct;52(10):2813-20. Epub 2007 Mar 28. | no modifiers of interest: sequence effect (LAN-RAB-LAN-RAB vs. RAB-LAN-RAB-LAN)
Macran S; Wileman S; Barton G; Russell I; REFLUX trial group; | The development of a new measure of quality of life in the management of gastro-oesophageal reflux disease: the Reflux questionnaire | Qual Life Res. 2007 Mar;16(2):331-43. Epub 2006 Oct 11. | development of a new measure of quality of life: the Reflux questionnaire
Mainie I; Tutuian R; Agrawal A; Adams D; Castell DO; | Combined multichannel intraluminal impedance-pH monitoring to select patients with persistent gastro-oesophageal reflux for laparoscopic Nissen fundoplication | Br J Surg. 2006 Dec;93(12):1483-7. | <100 patients, <5yrs FU
Mainie I; Tutuian R; Castell DO; | Addition of a H2 receptor antagonist to PPI improves acid control and decreases nocturnal acid breakthrough | J Clin Gastroenterol. 2008 Jul;42(6):676-9. | non-RCT of med; follow-up<4 wk; no adverse events
Mainie I; Tutuian R; Castell DO; | Comparison between the combined analysis and the DeMeester Score to predict response to PPI therapy | J Clin Gastroenterol. 2006 Aug;40(7):602-5. | predictor not considered in this review
Mainie I; Tutuian R; Shay S; Vela M; Zhang X; Sifrim D; Castell DO; | Acid and non-acid reflux in patients with persistent symptoms despite acid suppressive therapy: a multicentre study using combined ambulatory impedance-pH monitoring.[see comment] | Gut. 2006 Oct;55(10):1398-402. Epub 2006 Mar 23. | Study of association between reflux episodes and GORD symptioms
Mariette C; Piessen G; Balon JM; Guidat A; Lebuffe G; Triboulet JP; | The safety of the same-day discharge for selected patients after laparoscopic fundoplication: a prospective cohort study | Am J Surg. 2007 Sep;194(3):279-82. | sample size <100 for KQ3
Mark LA; Okrainec A; Ferri LE; Feldman LS; Mayrand S; Fried GM; | Comparison of patient-centered outcomes after laparoscopic Nissen fundoplication for gastroesophageal reflux disease or paraesophageal hernia | Surg Endosc. 2008 Feb;22(2):343-7. Epub 2007 Nov 20. | Population not of interest
Masqusi S; Velanovich V; | Pyloroplasty with fundoplication in the treatment of combined gastroesophageal reflux disease and bloating | World J Surg. 2007 Feb;31(2):332-6. | Intervention/Outcome not of interest
Mathavan VK; Yuh JN; Marks JM; | Long-term evaluation of patients undergoing laparoscopic antireflux surgery without bougie placement | J Laparoendosc Adv Surg Tech A. 2009 Feb;19(1):7-12. | follow up less than 5 years
Mathes RW; Malone KE; Daling JR; Porter PL; Li CI; | Relationship between histamine2-receptor antagonist medications and risk of invasive breast cancer | Cancer Epidemiol Biomarkers Prev. 2008 Jan;17(1):67-72. | not population of interest
McGlashan JA; Johnstone LM; Sykes J; Strugala V; Dettmar PW; | The value of a liquid alginate suspension (Gaviscon Advance) in the management of laryngopharyngeal reflux | Eur Arch Otorhinolaryngol. 2009 Feb;266(2):243-51. Epub 2008 May 28. | Atypical GERD outcomes
McVary KT; Roehrborn CG; Kaminetsky JC; Auerbach SM; Wachs B; Young JM; Esler A; Sides GD; Denes BS; | Tadalafil relieves lower urinary tract symptoms secondary to benign prostatic hyperplasia | J Urol. 2007 Apr;177(4):1401-7. | not relevant
Mejia-Rivas MA; Herrera-Lopez A; Hernandez-Calleros J; Herrera MF; Valdovinos MA; | Gastroesophageal reflux disease in morbid obesity: the effect of Roux-en-Y gastric bypass | Obes Surg. 2008 Oct;18(10):1217-24. Epub 2008 May 30. | Intervention (Roux-en-Y Gastric Bypass) is not of intrest
Metz DC; Miner PB; Heuman DM; Chen Y; Sostek M; | Comparison of the effects of intravenously and orally administered esomeprazole on acid output in patients with symptoms of gastro-oesophageal reflux disease | Aliment Pharmacol Ther. 2005 Nov 1;22(9):813-21. | med vs med < 4 weeks' duration
Mickevicius A; Endzinas Z; Kiudelis M; Jonaitis L; Kupcinskas L; Maleckas A; Pundzius J; | Influence of wrap length on the effectiveness of Nissen and Toupet fundoplication: a prospective randomized study | Surg Endosc. 2008 Oct;22(10):2269-76. Epub 2008 Apr 9. | follow-up < 5yrs
Miyamoto M; Haruma K; Kuwabara M; Nagano M; Okamoto T; Tanaka M; | Long-term gastroesophageal reflux disease therapy improves reflux symptoms in elderly patients: five-year prospective study in community medicine | J Gastroenterol Hepatol. 2007 May;22(5):639-44. | < 100 patients
Miyamoto M; Haruma K; Takeuchi K; Kuwabara M; | Frequency scale for symptoms of gastroesophageal reflux disease predicts the need for addition of prokinetics to proton pump inhibitor therapy.[see comment] | J Gastroenterol Hepatol. 2008 May;23(5):746-51. Epub 2007 Nov 19. | < 5 years of follow up
Monnikes H; Bardhan KD; Stanghellini V; Berghofer P; Bethke TD; Armstrong D; | Evaluation of GERD symptoms during therapy. Part II. Psychometric evaluation and validation of the new questionnaire ReQuest in erosive GERD | Digestion. 2004;69(4):238-44. Epub 2004 Jul 12. | duplicate publication with Monnikes 2007 (refID 833)
Monnikes H; Bardhan KD; Stanghellini V; Berghofer P; Bethke TD; Armstrong D; | Evaluation of GERD symptoms during therapy. Part II. Psychometric evaluation and validation of the new questionnaire ReQuest in erosive GERD | Digestion. 2007;75 Suppl 1:41-7. Epub 2007 May 4. | Non-comparative Non-RCT for medical tx
Monnikes H; Pfaffenberger B; Gatz G; Hein J; Bardhan KD; | Novel measurement of rapid treatment success with ReQuest: first and sustained symptom relief as outcome parameters in patients with endoscopy-negative GERD receiving 20 mg pantoprazole or 20 mg esomeprazole | Digestion. 2007;75 Suppl 1:62-8. Epub 2007 May 4. | RCT < 4 wk
Moretzsohn LD; Carvalho EB; Franco JD; Soares MP; Brito EM; Belarmino K; Coelho LG; | Control of esophageal and intragastric pH with compounded and manufactured omeprazole in patients with reflux esophagitis: a pilot study | Can J Clin Pharmacol. 2009 Winter;16(1):e264-72. Epub 2009 Apr 21. | med vs med < 4 weeks' duration. Treatment arms < 10
Morino M; Pellegrino L; Giaccone C; Garrone C; Rebecchi F; | Randomized clinical trial of robot-assisted versus laparoscopic Nissen fundoplication | Br J Surg. 2006 May;93(5):553-8. | no comparison or outcome of interest
Morton JM; Galanko JA; Soper NJ; Low DE; Hunter J; Traverso LW; | NIS vs SAGES: a comparison of national and voluntary databases | Surg Endosc. 2006 Jul;20(7):1124-8. Epub 2006 May 13. | not focused on GERD population
Muller-Stich BP; Koninger J; Muller-Stich BH; Schafer F; Warschkow R; Mehrabi A; Gutt CN; | Laparoscopic mesh-augmented hiatoplasty as a method to treat gastroesophageal reflux without fundoplication: single-center experience with 306 consecutive patients | Am J Surg. 2009 Jul;198(1):17-24. Epub 2009 Jan 29. | follow up < 5 years
Muller-Stich BP; Linke GR; Borovicka J; Marra F; Warschkow R; Lange J; Mehrabi A; Koninger J; Gutt CN; Zerz A; | Laparoscopic mesh-augmented hiatoplasty as a treatment of gastroesophageal reflux disease and hiatal hernias-preliminary clinical and functional results of a prospective case series | Am J Surg. 2008 Jun;195(6):749-56. Epub 2008 Mar 26. | less than 100 patients and follow up < 5 years
Muller-Stich BP; Reiter MA; Mehrabi A; Wente MN; Fischer L; Koninger J; Gutt CN; | No relevant difference in quality of life and functional outcome at 12 months' follow-up-a randomised controlled trial comparing robot-assisted versus conventional laparoscopic Nissen fundoplication | Langenbecks Arch Surg. 2009 May;394(3):441-6. Epub 2009 Jan 23. | no comparisonof interest; follow-up<5 yr
Muller-Stich BP; Reiter MA; Wente MN; Bintintan VV; Koninger J; Buchler MW; Gutt CN; | Robot-assisted versus conventional laparoscopic fundoplication: short-term outcome of a pilot randomized controlled trial | Surg Endosc. 2007 Oct;21(10):1800-5. Epub 2007 Mar 13. | no comparison or outcome of interest
Muro Y; Sugiura K; Nitta Y; Mitsuma T; Hoshino K; Usuda T; Hayashi K; Murase Y; Shimizu M; Matsuo H; | Scoring of reflux symptoms associated with scleroderma and the usefulness of rabeprazole | Clin Exp Rheumatol. 2009 May-Jun;27(3 Suppl 54):15-21. | No comparator-RBZ only
Myers JC; Jamieson GG; Wayman J; King DR; Watson DI; | Esophageal ileus following laparoscopic fundoplication | Dis Esophagus. 2007;20(5):420-7. | sample size <100 for KQ3
Nakadi IE; Melot C; Closset J; DeMoor V; Betroune K; Feron P; Lingier P; Gelin M; | Evaluation of da Vinci Nissen fundoplication clinical results and cost minimization | World J Surg. 2006 Jun;30(6):1050-4. | comparison not of interest; N<100
Nakamura T; Shirakawa K; Masuyama H; Sugaya H; Hiraishi H; Terano A; | Minimal change oesophagitis: a disease with characteristic differences to erosive oesophagitis | Aliment Pharmacol Ther. 2005 Jun;21 Suppl 2:19-26. | no clear definition of symptoms
Neumayer C; Ciovica R; Gadenstatter M; Erd G; Leidl S; Lehr S; Schwab G; | Significant weight loss after laparoscopic Nissen fundoplication | Surg Endosc. 2005 Jan;19(1):15-20. Epub 2004 Nov 18. | follow up < 5 years
Ng FH; Wong SY; Lam KF; Chu WM; Chan P; Ling YH; Kng C; Yuen WC; Lau YK; Kwan A; Wong BC; | Famotidine is inferior to pantoprazole in preventing recurrence of aspirin-related peptic ulcers or erosions | Gastroenterology. 2010 Jan;138(1):82-8. Epub 2009 Nov 11. | Not GERD population
Nojkov B; Rubenstein JH; Adlis SA; Shaw MJ; Saad R; Rai J; Weinman B; Chey WD; | The influence of co-morbid IBS and psychological distress on outcomes and quality of life following PPI therapy in patients with gastro-oesophageal reflux disease | Aliment Pharmacol Ther. 2008 Mar 15;27(6):473-82. Epub 2008 Jan 10. | follow up < 5 years
Oda K;Iwakiri R;Hara M;Watanabe K;Danjo A;Shimoda R;Kikkawa A;Ootani A;Sakata H;Tsunada S;Fujimoto K; | Dysphagia associated with gastroesophageal reflux disease is improved by proton pump inhibitor | Dig Dis Sci. 2005 Oct;50(10):1921-6. | less than 100 patients and follow up < 5 years
Ogut F; Ersin S; Engin EZ; Kirazli T; Midilli R; Unsal G; Bor S; | The effect of laparoscopic Nissen fundoplication on laryngeal findings and voice quality | Surg Endosc. 2007 Apr;21(4):549-54. Epub 2007 Feb 7. | Crosssectional study of Atypical GERD; no intervention
Omura N; Kashiwagi H; Yano F; Tsuboi K; Ishibashi Y; Kawasaki N; Suzuki Y; Yanaga K; | Therapeutic effects of laparoscopic fundoplication for nonerosive gastroesophageal reflux disease | Surg Today. 2006;36(11):954-60. | less than 100 patients and follow up < 5 years
Oridate N; Takeda H; Asaka M; Nishizawa N; Mesuda Y; Mori M; Furuta Y; Fukuda S; | Acid-suppression therapy offers varied laryngopharyngeal and esophageal symptom relief in laryngopharyngeal reflux patients | Dig Dis Sci. 2008 Aug;53(8):2033-8. Epub 2007 Dec 13. | Atypical GERD - LPR - patients
Oridate N; Takeda H; Mesuda Y; Nishizawa N; Furuta Y; Asaka M; Fukuda S; | Evaluation of upper abdominal symptoms using the Frequency Scale for the Symptoms of Gastroesophageal Reflux Disease in patients with laryngopharyngeal reflux symptoms | J Gastroenterol. 2008;43(7):519-23. Epub 2008 Jul 23. | Atypical GERD - LPR - patients
Orr WC; Craddock A; Goodrich S; | Acidic and non-acidic reflux during sleep under conditions of powerful acid suppression | Chest. 2007 Feb;131(2):460-5. | med vs med < 4 weeks' duration
Orr WC; Goodrich S; Robert J; | The effect of acid suppression on sleep patterns and sleep-related gastro-oesophageal reflux.[see comment] | Aliment Pharmacol Ther. 2005 Jan 15;21(2):103-8. | med vs med < 4 weeks' duration
Orr WC; Robert JJ; Houck JR; Giddens CL; Tawk MM; | The effect of acid suppression on upper airway anatomy and obstruction in patients with sleep apnea and gastroesophageal reflux disease | J Clin Sleep Med. 2009 Aug 15;5(4):330-4. | Medical cohort
Ozawa S; Kumai K; Higuchi K; Arakawa T; Kato M; Asaka M; Katada N; Kuwano H; Kitajima M; | Short-term and long-term outcome of endoluminal gastroplication for the treatment of GERD: the first multicenter trial in Japan | J Gastroenterol. 2009;44(7):675-84. Epub 2009 May 14. | N<100; follow-up <5 year
Ozmen V; Oran ES; Gorgun E; Asoglu O; Igci A; Kecer M; Dizdaroglu F; | Histologic and clinical outcome after laparoscopic Nissen fundoplication for gastroesophageal reflux disease and Barrett's esophagus | Surg Endosc. 2006 Feb;20(2):226-9. Epub 2005 Dec 9. | Patients with Barretts Oespphagus
Pace F; Pallotta S; Manes G; de LA; Zentilin P; Russo L; Savarino V; Neri M; Grossi E; Cuomo R; | Outcome of nonerosive gastroesophageal reflux disease patients with pathological acid exposure | World J Gastroenterol. 2009 Dec 7;15(45):5700-5. | no treatment of interest
Pai V, Pai N. | Randomized, double-blind, comparative study of dexrabeprazole 10 mg versus rabeprazole 20 mg in the treatment of gastroesophageal reflux disease. | World J Gastroenterol. 2007 Aug 14;13(30):4100-2. | dexrabeprazole is not approved by FDA
Pandeya N; Webb PM; Sadeghi S; Green AC; Whiteman DC; Australian CS; | Gastro-oesophageal reflux symptoms and the risks of oesophageal cancer: are the effects modified by smoking, NSAIDs or acid suppressants? | Gut. 2010 Jan;59(1):31-8. Epub. | not all GERD pts
Park W; Hicks DM; Khandwala F; Richter JE; Abelson TI; Milstein C; Vaezi MF; | Laryngopharyngeal reflux: prospective cohort study evaluating optimal dose of proton-pump inhibitor therapy and pretherapy predictors of response | Laryngoscope. 2005 Jul;115(7):1230-8. | Pts w. atypical gerd
Peterson KA SWRDYDTKH; | The role of gastroesophageal reflux in exercise-triggered asthma: a randomized controlled trial | Dig Dis Sci. 2009 Mar;54(3):564-71. Epub 2008 Aug 8. | Atypical GERD; included in Asthma update
Pidoto RR; Fama' F; Giacobbe G; Gioffre' Florio MA; Cogliandolo A; | Quality of life and predictors of long-term outcome in patients undergoing open Nissen fundoplication for chronic gastroesophageal reflux | Am J Surg. 2006 Apr;191(4):470-8. | surgical cohort N<100
Pleskow D; Rothstein R; Kozarek R; Haber G; Gostout C; Lembo A; | Endoscopic full-thickness plication for the treatment of GERD: long-term multicenter results | Surg Endosc. 2007 Mar;21(3):439-44. Epub 2006 Dec 16. | NDO device excluded
Pleskow D; Rothstein R; Kozarek R; Haber G; Gostout C; Lo S; Hawes R; Lembo A; | Endoscopic full-thickness plication for the treatment of GERD: Five-year long-term multicenter results | Surg Endosc. 2008 Feb;22(2):326-32. Epub 2007 Nov 20. | NDO device excluded
Pratha V; Hogan DL; Lynn RB; Field B; Metz DC; | Intravenous pantoprazole as initial treatment in patients with gastroesophageal reflux disease and a history of erosive esophagitis: a randomized clinical trial | Dig Dis Sci. 2006 Sep;51(9):1595-601. Epub 2006 Aug 22. | <4 wk Rx
Puhan MA; Guyatt GH; Armstrong D; Wiklund I ;Fallone CA; Heels-Ansdell D; Degl'Innocenti A; Veldhuyzen van Zanten SJ; Tanser L; Barkun AN; Chiba N; Austin P; El-Dika S; Schunemann HJ; | Validation of a symptom diary for patients with gastro-oesophageal reflux disease | Aliment Pharmacol Ther. 2006 Feb 15;23(4):531-41. | explores validity of a symptom diary as HRQL measurement instrument for GERD
Radajewski R; Hazebroek EJ; Berry H; Leibman S; Smith GS; | Short-term symptom and quality-of-life comparison between laparoscopic Nissen and Toupet fundoplications | Dis Esophagus. 2009;22(1):84-8. Epub 2008 Nov 12. | follow up <5 years
Rakita S; Villadolid D; Thomas A; Bloomston M; Albrink M; Goldin S; Rosemurgy A; | Laparoscopic Nissen fundoplication offers high patient satisfaction with relief of extraesophageal symptoms of gastroesophageal reflux disease | Am Surg. 2006 Mar;72(3):207-12. | Pts w. atypical gerd
Rantanen TK; Rasanen JV; Sihvo EI; Ahotupa MO; Farkkila MA; Salo JA; | The impact of antireflux surgery on oxidative stress of esophageal mucosa caused by gastroesophageal reflux disease: 4-yr follow-up study | Am J Gastroenterol. 2006 Feb;101(2):222-8. | follow up <5 years
Rantanen TK; Sihvo EI; Rasanen JV; Salo JA; | Gastroesophageal reflux disease as a cause of death is increasing: analysis of fatal cases after medical and surgical treatment.[see comment] | Am J Gastroenterol. 2007 Feb;102(2):246-53. Epub 2006 Dec 11. | no usable data
Rasanen JV; Sihvo EI; Rantanen TK; Ahotupa MO; Farkkila MA; Harjula A; Salo JA; | Gastroesophageal reflux patients' defective antioxidative capacity in the proximal esophageal mucosa before antireflux surgery and also after 4-year follow-up | Ann Med. 2008;40(1):74-80. | N<100; follow up <5 years
Ravi N; Al-Sarraf N; Balfe P; Byrne PJ; Reynolds JV; | On-table endoscopy following laparoscopic fundoplication | J Gastrointest Surg. 2008 Jun;12(6):991-6. | follow up <5 years
Reichel O; Dressel H; Wiederanders K; Issing WJ; | Double-blind, placebo-controlled trial with esomeprazole for symptoms and signs associated with laryngopharyngeal reflux | Otolaryngol Head Neck Surg. 2008 Sep;139(3):414-20. | Pts w. atypical gerd
Reimer C; Sondergaard B; Hilsted L; Bytzer P; | Proton-pump inhibitor therapy induces acid-related symptoms in healthy volunteers after withdrawal of therapy.[see comment] | Gastroenterology. 2009 Jul;137(1):80-7, 87.e1. Epub 2009 Apr 10. | not population of interest, study looks at healthy subjects randomized to PPI or placebo
Reis GM; Savassi-Rocha PR; Nogueira AM; Lima MJ; de CS; Arantes V; Barros CA; Cancado OL; | Histological esophagitis before and after surgical treatment of morbid obesity (Capella technique): a prospective study | Obes Surg. 2008 Apr;18(4):367-70. Epub 2008 Feb 22. | Gastric bypass for morbid obese with esophagitis
Remak E; Brown RE; Yuen C; Robinson A; | Cost-effectiveness comparison of current proton-pump inhibitors to treat gastro-oesophageal reflux disease in the UK | Curr Med Res Opin. 2005 Oct;21(10):1505-17. | cost-effectiveness analysis
Richter JE; | Con: Impedance-pH testing does not commonly alter management of GERD. [Review] [22 refs] | Am J Gastroenterol. 2009 Nov;104(11):2667-9. | not primary research, a commentary
Riedl O; Gadenstatter M; Lechner W; Schwab G;Marker M; Ciovica R; | Preoperative lower esophageal sphincter manometry data neither impact manifestations of GERD nor outcome after laparoscopic Nissen fundoplication | J Gastrointest Surg. 2009 Jul;13(7):1189-97. Epub 2009 Apr 16. | f/u<5yr for surgical study
Rijnhart-De Jong HG; Draaisma WA; Smout AJ; Broeders IA; Gooszen HG; | The Visick score: a good measure for the overall effect of antireflux surgery? | Scand J Gastroenterol. 2008;43(7):787-93. | no outcomes of interest
Rodriguez LA; Ruigomez A; Wallander MA; Johansson S; | Acid-suppressive drugs and community-acquired pneumonia | Epidemiology. 2009 Nov;20(6):800-6. | Pneumonia not considered atypical GERD
Roman S; Poncet G; Serraj I; Zerbib F; Boulez J; Mion F; | Characterization of reflux events after fundoplication using combined impedance-pH recording | Br J Surg. 2007 Jan;94(1):48-52. | follow up <5 years
Rossi M; Barreca M; de BN; Renzi C; Santi S; Gennai A; Bellini M; Costa F; Conio M; Marchi S; | Efficacy of Nissen fundoplication versus medical therapy in the regression of low-grade dysplasia in patients with Barrett esophagus: a prospective study.[see comment] | Ann Surg. 2006 Jan;243(1):58-63. | population: patients with Barrett esophagus and low-grade dysplasia
Rothstein R; Filipi C; Caca K; Pruitt R; Mergener K; Torquati A; Haber G; Chen Y; Chang K; Wong D; Deviere J; Pleskow D; Lightdale C; Ades A; Kozarek R; Richards W; Lembo A; | Endoscopic full-thickness plication for the treatment of gastroesophageal reflux disease: A randomized, sham-controlled trial | Gastroenterology. 2006 Sep;131(3):704-12. | NDO device excluded. 3 month follow up.
Sala E; Salminen P; Simberg S; Koskenvuo J; Ovaska J; | Laryngopharyngeal reflux disease treated with laparoscopic fundoplication | Dig Dis Sci. 2008 Sep;53(9):2397-404. Epub 2008 Mar 5. | Pts w. atypical gerd
Salminen P; | The laparoscopic Nissen fundoplication--a better operation?. [Review] [33 refs] | Surgeon. 2009 Aug;7(4):224-7. | review article
Salminen P; Sala E; Koskenvuo J; Karvonen J; Ovaska J; | Reflux laryngitis: a feasible indication for laparoscopic antireflux surgery?[see comment] | Surg Laparosc Endosc Percutan Tech. 2007 Apr;17(2):73-8. | atypical GERD
Salyers WJ;Mansour A;El-Haddad B;Golbeck AL;Kallail KJ; | Lifestyle modification counseling in patients with gastroesophageal reflux disease | Gastroenterol Nurs. 2007 Jul-Aug;30(4):302-4. | not relevant, article looks at lifestyle modifications for pts w/ gerd
Sandbu R; Sundbom M; | Nationwide survey of long-term results of laparoscopic antireflux surgery in Sweden | Scand J Gastroenterol. 2010;45(1):15-20. | f/u<5yr for surgical study
Sato K; Umeno H; Chitose S; Nakashima T; | Patterns of laryngopharyngeal and gastroesophageal reflux | J Laryngol Otol Suppl. 2009 May;(31):42-7. | Dx of atypical GERD
Schiefke I;Neumann S; Zabel-Langhennig A; Moessner J; Caca K; | Use of an endoscopic suturing device (the ‘ESD’) to treat patients with gastroesophageal reflux disease, after unsuccessful EndoCinch endoluminal gastroplication: another failure | Endoscopy. 2005 Aug;37(8):700-5. | endoscopic Suturing Device after faliure of EndoCinch
Schiefke I; Rogalski C; Zabel-Langhennig A; Witzigmann H; Mossner J; Hasenclever D; Caca K; | Are endoscopic antireflux therapies cost-effective compared with laparoscopic fundoplication? | Endoscopy. 2005 Mar;37(3):217-22. | Not primary study--cost effective comparison of endoscopic vs. surgery
Schilling D; Kiesslich R; Galle PR; Riemann JF; | Endoluminal therapy of GERD with a new endoscopic suturing device.[see comment] | Gastrointest Endosc. 2005 Jul;62(1):37-43. | surgical cohort; sample size <100 for KQ3
Schmitt C; Lightdale CJ; Hwang C; Hamelin B; | A multicenter, randomized, double-blind, 8-week comparative trial of standard doses of esomeprazole (40 mg) and omeprazole (20 mg) for the treatment of erosive esophagitis | Dig Dis Sci. 2006 May;51(5):844-50. Epub 2006 Apr 27. | < 5 year fu
Schneider JH; Kramer KM; Konigsrainer A; Granderath FA; | The lower esophageal sphincter strength in patients with gastroesophageal reflux before and after laparoscopic Nissen fundoplication | Dis Esophagus. 2007;20(1):58-62. | < 5 year fu
Schneider JM; Brucher BL; Kuper M; Saemann K; Konigsrainer A; Schneider JH; | Multichannel intraluminal impedance measurement of gastroesophageal reflux in patients with different stages of morbid obesity | Obes Surg. 2009 Nov;19(11):1522-9. Epub 2008 Jul 22. | no treatment of interest
Schunemann HJ; Armstrong D; Degl'innocenti A; Wiklund I; Fallone CA; Tanser L; van Zanten SV; Heels-Ansdell D; El-Dika S; Chiba N; Barkun AN; Austin P; Guyatt GH; | A randomized multicenter trial to evaluate simple utility elicitation techniques in patients with gastroesophageal reflux disease | Med Care. 2004 Nov;42(11):1132-42. | not relevant, study involves looking at ways to improve intruments measuring HRQL in GERD pts
Shahani S; Sawant P; Dabholkar P; | Rabeprazole plus domperidone: the answer for gastro-oesophageal reflux disease | J Indian Med Assoc. 2008 Apr;106(4):264, 266, 268. | non comparative study, <100 subjects, 4 weeks duration, no AE
Shaheen NJ; Madanick RD; Alattar M; Morgan DR; Davis PH; Galanko JA; Spacek MB; Vaughn BV; | Gastroesophageal reflux disease as an etiology of sleep disturbance in subjects with insomnia and minimal reflux symptoms: a pilot study of prevalence and response to therapy | Dig Dis Sci. 2008 Jun;53(6):1493-9. | outcome not of interest
Shaheen NJ; Stuart E; Schmitz SM; Mitchell KL; Fried MW; Zacks S; Russo MW; Galanko J; Shrestha R; | Pantoprazole reduces the size of postbanding ulcers after variceal band ligation: a randomized, controlled trial | Hepatology. 2005 Mar;41(3):588-94. | not GERD
Sharma B; Sharma M; Daga MK; Sachdev GK; Bondi E; | Effect of omeprazole and domperidone on adult asthmatics with gastroesophageal reflux | World J Gastroenterol. 2007Mar 21;13(11):1706-10. | atypical GERD (this article is included in atypical GERD asthma update)
Sharma N; Agrawal A; Freeman J; Vela MF; Castell D; | An analysis of persistent symptoms in acid-suppressed patients undergoing impedance-pH monitoring.[see comment] | Clin Gastroenterol Hepatol. 2008 May;6(5):521-4. Epub 2008 Mar 20. | med cohort with no AE reported
Sharma P; Chey W; Hunt R; Laine L; Malfertheiner P; Wani S; | Endoscopy of the esophagus in gastroesophageal reflux disease: are we losing sight of symptoms? Another perspective | Dis Esophagus. 2009;22(5):461-6. Epub 2009 Jan 23. | not primary research, a commentary
Shay S; | A balancing view: Impedance-pH testing in gerd-limited role for now, perhaps more helpful in the future. [Review] [14 refs] | Am J Gastroenterol. 2009 Nov;104(11):2669-70. | not primary research, a commentary
Shim KN; Hong SJ; Sung JK; Park KS; Kim SE; Park HS; Kim YS; Lim SH; Kim CH; Park MJ; Yim JY; Cho KR; Kim D; Park SJ; Jee SR; Kim JI; Park JY; Song GA; Jung HY; Lee YC; Kim JG; Kim JJ; Kim N; Park SH; Jung HC; Chung IS; Study Group of Korean College of Helicobacter and Upper Gastr | Clinical spectrum of reflux esophagitis among 25,536 Koreans who underwent a health check-up: a nationwide multicenter prospective, endoscopy-based study | J Clin Gastroenterol. 2009 Aug;43(7):632-8. | no treatment of interest
Shimatani T; Inoue M; Kuroiwa T; Moriwaki M; Xu J; Ikawa K; Morikawa N; Tazuma S; | Which has superior acid-suppressive effect, 10 mg omeprazole once daily or 20 mg famotidine twice daily? Effects of single or repeated administration in Japanese Helicobacter pylori-negative CYP2C19 extensive metabolizers | Dig Dis Sci. 2007. Feb;52(2):390-5. Epub 2007 Jan 9. | not population of interest
Shimatani T; Inoue M; Kuroiwa T; Xu J; Mieno H; Nakamura M; Tazuma S; | Acid-suppressive effects of rabeprazole, omeprazole, and lansoprazole at reduced and standard doses: a crossover comparative study in homozygous extensive metabolizers of cytochrome P450 2C19 | Clin Pharmacol Ther. 2006 Jan;79(1):144-52. | not population of interest, study compares PPI vs H2RA in healthy subjects with different metabolism genotypes
Shimizu Y; Dobashi K; Kobayashi S; Ohki I; Tokushima M; Kusano M; Kawamura O; Shimoyama Y; Utsugi M; Sunaga N; Ishizuka T; Mori M; | A proton pump inhibitor, lansoprazole, ameliorates asthma symptoms in asthmatic patients with gastroesophageal reflux disease | Tohoku J Exp Med. 2006 Jul;209(3):181-9. | atypical GERD (this article is included in atypical GERD asthma update)
Smythe A; Troy GP; Ackroyd R; Bird NC; | Proton pump inhibitor influence on reflux in Barrett's oesophagus | Eur J Gastroenterol Hepatol. 2008 Sep;20(9):881-7. | 100% Barrett's
Sontag SJ; Sonnenberg A; Schnell TG; Leya J; Metz A; | The long-term natural history of gastroesophageal reflux disease. [see comment] | J Clin Gastroenterol. 2006 May-Jun;40(5):398-404. | no intervention
Spechler SJ; Barker PN; Silberg DG; | Clinical trial: intragastric acid control in patients who have Barrett's oesophagus--comparison of once- and twice-daily regimens of esomeprazole and lansoprazole | Aliment Pharmacol Ther. 2009 Jul 1;30(2):138-45. Epub 2009 Apr 29. | medical tx<4weeks
Spence GM; Watson DI; Jamiesion GG; Lally CJ; Devitt PG; | Single center prospective randomized trial of laparoscopic Nissen versus anterior 90 degrees fundoplication | J Gastrointest Surg. 2006 May;10(5):698-705. | follow-up < 5yrs
Stoltey J; Reeba H; Ullah N; Sabhaie P; Gerson L; | Does Barrett's oesophagus develop over time in patients with chronic gastro-oesophageal reflux disease? | Aliment Pharmacol Ther. 2007 Jan 1;25(1):83-91. | no comparative Rx
Sugimoto M;Furuta T;Shirai N;Kajimura M;Hishida A;Sakurai M;Ohashi K;Ishizaki T; | Different dosage regimens of rabeprazole for nocturnal gastric acid inhibition in relation to cytochrome P450 2C19 genotype status | Clin Pharmacol Ther. 2004 Oct;76(4):290-301. | not population of interest, study looks to develop optimal dosage for rabeprazol in healthy subjects with different metabolism genotypes
Sundstrom A; Blomgren K; Alfredsson L; Wiholm BE; | Acid-suppressing drugs and gastroesophageal reflux disease as risk factors for acute pancreatitis--results from a Swedish Case-Control Study | Pharmacoepidemiol Drug Saf. 2006 Mar;15(3):141-9. | pts w/ acute pancreatitis
Suurna MV; Welge J; Surdulescu V; Kushner J; Steward DL; | Randomized placebo-controlled trial of pantoprazole for daytime sleepiness in GERD and obstructive sleep disordered breathing | Otolaryngol Head Neck Surg. 2008 Aug;139(2):286-90. | not GERD
Swoger J; Ponsky J; Hicks DM; Richter JE; Abelson TI; Milstein C; Qadeer MA; Vaezi MF; | Surgical fundoplication in laryngopharyngeal reflux unresponsive to aggressive acid suppression: a controlled study.[see comment] | Clin Gastroenterol Hepatol. 2006 Apr;4(4):433-41. | atypical GERD
Taghavi SA; Ghasedi M; Saberi-Firoozi M; izadeh-Naeeni M; Bagheri-Lankarani K; Kaviani MJ; Hamidpour L; | Symptom association probability and symptom sensitivity index: preferable but still suboptimal predictors of response to high dose omeprazole | Gut. 2005 Aug;54(8):1067-71. Epub 2005 Apr 21. | < 5 year FU
Tharavej C; Hagen JA; Portale G; Hsieh CC; Gandamihardja TA; Lipham JC; Peters JH; DeMeester SR; Crookes PF; Bremner CG; DeMeester TR; | Bravo capsule induction of esophageal hypercontractility and chest pain | Surg Endosc. 2006 May;20(5):783-6. Epub 2006 Mar 16. | not relevant, not treatment for GERD, study looks at adverse effects of Bravo capsule, a monitoring system measuring esophageal acid exposure
Thompson SK; Cai W; Jamieson GG; Zhang AY; Myers JC; Parr ZE; Watson DI; Persson J; Holtmann G; Devitt PG; | Recurrent symptoms after fundoplication with a negative pH study--recurrent reflux or functional heartburn? | J Gastrointest Surg. 2009 Jan;13(1):54-60. Epub 2008 Aug 20. | Association b/w heartburn and pt characteristics post fundoplicaiton. < 100 patients
Thompson SK; Jamieson GG; Myers JC; Chin KF; Watson DI; Devitt PG; | Recurrent heartburn after laparoscopic fundoplication is not always recurrent reflux | J Gastrointest Surg. 2007 May;11(5):642-7. | N<100; follow-up <5 years
Tibbling L; Johansson M; Mjones AB; Franzen T; | Globus jugularis and dysphagia in patients with hiatus hernia | Eur Arch Otorhinolaryngol. 2010 Feb;267(2):251-4. Epub 2009 Jul 14. | < 100 patients and FU < 5 yrs
Tierney B; Iqbal A; Haider M; Filipi C; | Effects of prior endoluminal gastroplication on subsequent laparoscopic Nissen fundoplication | Surg Endosc. 2007 Feb;21(2):321-3. Epub 2007 Jan 6. | only 6 pts
Tipnis NA; Rhee PL; Mittal RK; | Distension during gastroesophageal reflux: effects of acid inhibition and correlation with symptoms | Am J Physiol Gastrointest Liver Physiol. 2007 Aug;293(2):G469-74. Epub 2007 Jun 7. | effects of esomeprazole on Ger-induced distension of esophagus
Todd JA; Basu KK; de Caestecker JS; | Normalization of oesophageal pH does not guarantee control of duodenogastro-oesophageal reflux in Barrett's oesophagus | Aliment Pharmacol Ther. 2005 Apr 15;21(8):969-75. | BE pts
Torquati A; Lutfi R; Khaitan L; Sharp KW; Richards WO; | Heller myotomy vs Heller myotomy plus Dor fundoplication: cost-utility analysis of a randomized trial | Surg Endosc. 2006 Mar;20(3):389-93. Epub 2006 Jan 25. | Pts w/ achalasia
Toruner M; Bektas M; Cetinkaya H; Soykan I; Ozden A; | The effect of rabeprazole alone or in combination with H2 receptor blocker on intragastric pH: a pilot study | Turk J Gastroenterol. 2004 Dec;15(4):225-8. | not population of interest, study looks at PPI vs. PPI + H2RA in subjects with dyspectic sx
Tosato F; Monsellato I; Marano S; Leonardo G; Portale G; Bezzi M; | Functional evaluation at 1-year follow-up of laparoscopic Nissen-Rossetti fundoplication | J Laparoendosc Adv Surg Tech A. 2009 Jun;19(3):351-4. | 1 yr fu
Tsereteli Z; Sporn E; Astudillo JA; Miedema B; Eubanks WS; Thaler K; | Laparoscopic Nissen fundoplication is a good option in patients with abnormal esophageal motility | Surg Endosc. 2009 Oct;23(10):2292-5. Epub 2009 Jan 27. | surgical study with <100 patients
Tucker LE; Blatt C; Richardson NL; Richardson DT; Cassat JD; Riechers TB; | Laparoscopic Nissen fundoplication in a community hospital: patient satisfaction survey.[see comment] | South Med J. 2005 Apr;98(4):441-3. | no outcomes of interest
Turkcapar A; Kepenekci I; Mahmoud H; Tuzuner A; | Laparoscopic fundoplication with prosthetic hiatal closure.[see comment][erratum appears in World J Surg. 2007 Nov;31(11):2168 Note: Turkcapar, Ahmet [added]; Mahmoud, Hatim [added]; Tuzuner, Acar [added]] | World J Surg. 2007 Nov;31(11):2169-76. Epub 2007 Jul 3. | Comparison of hiatal closure methods with the same procedure (laparoscopic fundoplication) are not interventions of interest in this review
Tutuian R; Mainie I; Agrawal A; Adams D; Castell DO; | Nonacid reflux in patients with chronic cough on acid-suppressive therapy.[see comment] | Chest. 2006 Aug;130(2):386-91. | association of cough and nonacid reflux
Tutuian R; Vela MF; Hill EG; Mainie I; Agrawal A; Castell DO; | Characteristics of symptomatic reflux episodes on Acid suppressive therapy | Am J Gastroenterol. 2008 May;103(5):1090-6. Epub 2008 Apr 28. | Not relevant--examines pt characteristics associated w/ symptomatic and non symptomatic reflux
Vakil N; Guda N; Partington S; | The effect of over-the-counter ranitidine 75 mg on night-time heartburn in patients with erosive oesophagitis on daily proton pump inhibitor maintenance therapy | Aliment Pharmacol Ther. 2006 Mar 1;23(5):649-53. | med vs med < 4 weeks' duration
van Marrewijk CJ MSFGNMdWNMJvO MJJGDKJLR; | Effect and cost-effectiveness of step-up versus step-down treatment with antacids, H2-receptor antagonists, and proton pump inhibitors in patients with new onset dyspepsia (DIAMOND study): a primary-care-based randomised controlled trial | Lancet. 2009 Jan 17;373(9659):215-25. | Dyspepsia is not disease of interest
van Zanten SV; Flook N; Talley NJ; Vakil N; Lauritsen K; Bolling-Sternevald E; Persson T; Bjorck E; Svedberg LE; STARS II Study Group; | One-week acid suppression trial in uninvestigated dyspepsia patients with epigastric pain or burning to predict response to 8 weeks' treatment with esomeprazole: a randomized, placebo-controlled study | Aliment Pharmacol Ther. 2007 Sep 1;26(5):665-72. | Pts w dyspepsia
Varela JE; Hinojosa MW; Nguyen NT; | Laparoscopic fundoplication compared with laparoscopic gastric bypass in morbidly obese patients with gastroesophageal reflux disease | Surg Obes Relat Dis. 2009 Mar-Apr;5(2):139-43. Epub 2008 Sep 4. | follow-up<5 years
Varga G; Kiraly A; Cseke L; Kalmar K; Horvath OP; | Effect of laparoscopic fundoplication on hypertensive lower esophageal sphincter associated with gastroesophageal reflux | J Gastrointest Surg. 2008 Feb;12(2):304-7. Epub 2007 Nov 6. | surgical cohort N<100
Victorzon M; Tolonen P; Vuorialho T; | Laparoscopic floppy Nissen fundoplication for gastro-oesophageal reflux disease is feasible as a day-case procedure | Scand J Surg. 2006;95(3):162-5. | surgical cohort N<100
Vidal O; Lacy AM; Pera M; Valentini M; Bollo J; Lacima G; Grande L; | Long-term control of gastroesophageal reflux disease symptoms after laparoscopic Nissen-Rosetti fundoplication | J Gastrointest Surg. 2006 Jun;10(6):863-9. | follow-up<5 years
Vieth M; Kulig M; Leodolter A; Naucler E; Jaspersen D; Labenz J; Meyer-Sabellek W; Lind T; Willich S; Malfertheiner P; Stolte M; | Histological effects of esomeprazole therapy on the squamous epithelium of the distal oesophagus | Aliment Pharmacol Ther. 2006 Jan 15;23(2):313-9. | no usable data
Violette A; Velanovich V; | Quality of life convergence of laparoscopic and open anti-reflux surgery for gastroesophageal reflux disease | Dis Esophagus. 2007;20(5):416-9. | f/u <5 y
von RD; Brey U; Riecken B; Caca K; | Endoscopic full-thickness plication (Plicator) with two serially placed implants improves esophagitis and reduces PPI use and esophageal acid exposure | Endoscopy. 2008 Mar;40(3):173-8. | NDO device excluded
von RD; Schiefke I; Fuchs KH; Raczynski S; Philipper M; Breithaupt W; Caca K; Neuhaus H; | Endoscopic full-thickness plication for the treatment of GERD by application of multiple Plicator implants: a multicenter study (with video).[see comment] | Gastrointest Endosc. 2008 Nov;68(5):833-44. Epub 2008 Jun 4. | NDO device excluded
von RD; Schiefke I; Fuchs KH; Raczynski S; Philipper M; Breithaupt W; Caca K; Neuhaus H; | Endoscopic full-thickness plication for the treatment of gastroesophageal reflux disease using multiple Plicator implants: 12-month multicenter study results | Surg Endosc. 2009 Aug;23(8):1866-75. Epub 2009 May 14. | NDO device excluded
Wada Y; Ito M; Takata S; Kitamura S; Takamura A; Tatsugami M; Imagawa S; Matsumoto Y; Tanaka S; Yoshihara M; Chayama K; | Little necessity of acid inhibition against proton pump inhibitor rebound effects and prior helicobacter pylori eradication therapy in gastric ulcer patients: a randomized prospective study | Hepatogastroenterology. 2009 May-Jun;56(91-92):624-8. | patients with gastric adenoma or early gastric cancer
Wahlqvist P; Guyatt GH; Armstrong D; Degl'innocenti A; Heels-Ansdell D; EI-Dika S; Wiklund I; Fallone CA; Tanser L; Veldhuyzen van ZS; Austin P; Barkun AN; Chiba N; Schunemann HJ; | The Work Productivity and Activity Impairment Questionnaire for Patients with Gastroesophageal Reflux Disease (WPAI-GERD): responsiveness to change and English language validation | Pharmacoeconomics. 2007;25(5):385-96. | not relevant, primary objectives were test responsiveness of questionnaire in pts w/ gerd treated with PPI. No comparisons made.
Walwaikar PP; Kulkarni SS; Bargaje RS; | Evaluation of new gastrointestinal prokinetic (ENGIP-I) study | J Indian Med Assoc. 2005 Oct;103(10):559-60. | Med pre- and post trial, N<100
Wang R; | Burden of gastroesophageal reflux disease in Shanghai, China | Dig Liver Dis. 2009 Feb;41(2):110-5. Epub 2008 Aug 15. | no intervention
Warrington S; Baisley K; Lee D; Lomax K; Delemos B; Boyce M; Morocutti A; | Pharmacodynamic effects of single doses of rabeprazole 20 mg and pantoprazole 40 mg in patients with GERD and nocturnal heartburn | Aliment Pharmacol Ther. 2007 Feb 15;25(4):511-7. | pharmacodynamic study
Watson DI; Jamieson GG; Bessell JR; Devitt PG; | Laparoscopic fundoplication in patients with an aperistaltic esophagus and gastroesophageal reflux | Dis Esophagus. 2006;19(2):94-8. | aperistaltic esophagus
Wehrli NE; Levine MS; Rubesin SE; Katzka DA; Laufer I; | Secondary achalasia and other esophageal motility disorders after laparoscopic Nissen fundoplication for gastroesophageal reflux disease | AJR Am J Roentgenol. 2007 Dec;189(6):1464-8. | N<100
Weigt J; Monkemuller K; Peitz U; Malfertheiner P; | Multichannel intraluminal impedance and pH-metry for investigation of symptomatic gastroesophageal reflux disease | Dig Dis. 2007;25(3):179-82. | internvention not of interest
Wertheimer AI; Wilson JM; | Comparative drug effects: the case of GERD therapies | Dis Manag. 2007 Feb;10(1):46-50. | no details on intervention
Westbrook JI; Duggan AE; Duggan JM; Westbrook MT; | A 9 year prospective cohort study of endoscoped patients with upper gastrointestinal symptoms | Eur J Epidemiol. 2005;20(7):619-27. | non-specific dx of dyspepsia
Wieslaw T; Adam K; Artur B; Lech B; Krzysztof B; | Nissen fundoplication improves gastric myoelectrical activity characteristics and symptoms in gastroesophageal reflux patients: evaluation in transcutaneous electrogastrography | Surg Endosc. 2008 Jan;22(1):134-40. Epub 2007 May 12. | follow up < 5y
Wijnhoven BP; Watson DI; Devitt PG; Game PA; Jamieson GG; | Laparoscopic Nissen fundoplication with anterior versus posterior hiatal repair: long-term results of a randomized trial | Am J Surg. 2008 Jan;195(1):61-5. | no comparions of interest
Wiklund I; Carlsson R; Carlsson J; Glise H; | Psychological factors as a predictor of treatment response in patients with heartburn: a pooled analysis of clinical trials | Scand J Gastroenterol. 2006 Mar;41(3):288-93. | secondary analysis
Wilder-Smith C; Backlund A; Eckerwall G; Lind T; Fjellman M; Rohss K; | Effect of increasing esomeprazole and pantoprazole doses on acid control in patients with symptoms of gastro-oesophageal reflux disease: a randomized, dose-response study | Clin Drug Investig. 2008;28(6):333-43. | pharmacodynamic study
Wilder-Smith C; Lind T; Lundin C; Naucler E; Nilsson-Pieschl C; Rohss K; | Acid control with esomeprazole and lansoprazole: a comparative dose-response study | Scand J Gastroenterol. 2007 Feb;42(2):157-64. | pharmacodynamic study
Wilder-Smith CH; Wilder-Smith P; Kawakami-Wong H; Voronets J; Osann K; Lussi A; | Quantification of dental erosions in patients with GERD using optical coherence tomography before and after double-blind, randomized treatment with esomeprazole or placebo | Am J Gastroenterol. 2009 Nov;104(11):2788-95. Epub 2009 Aug 4. | no outcome of interest (dental erosion outcomes)
Wilkerson PM; Stratford J; Jones L; Sohanpal J; Booth MI; Dehn TC; | A poor response to proton pump inhibition is not a contraindication for laparoscopic antireflux surgery for gastro esophageal reflux disease | Surg Endosc. 2005 Sep;19(9):1272-7. Epub 2005 Jul 14. | in Ip 2009 SR
Wong AS; Myers JC; Jamieson GG; | Esophageal pH profile following laparoscopic total fundoplication compared to anterior fundoplication | J Gastrointest Surg. 2008 Aug;12(8):1341-5. Epub 2008 Feb 26. | <100 pts @ 5 y f/u
Woodcock SA; Watson DI; Lally C; Archer S; Bessell JR; Booth M; Cade R; Cullingford GL; Devitt PG; Fletcher DR; Hurley J; Jamieson GG; Kiroff G; Martin CJ; Martin IJ; Nathanson LK; Windsor JA; International Society fir Disease of the Esophagus -Australasian Section; | Quality of life following laparoscopic anterior 90 degrees versus Nissen fundoplication: results from a multicenter randomized trial | World J Surg. 2006 Oct;30(10):1856-63. | f/u < 5 y
Wykypiel H; Gadenstaetter M; Klaus A; Klingler P; Wetscher GJ; | Nissen or partial posterior fundoplication: which antireflux procedure has a lower rate of side effects? | Langenbecks Arch Surg. 2005 Apr;390(2):141-7. Epub 2005 Feb 12. | f/u < 5 y
Wykypiel H; Hugl B; Gadenstaetter M; Bonatti H; Bodner J; Wetscher GJ; | Laparoscopic partial posterior (Toupet) fundoplication improves esophageal bolus propagation on scintigraphy | Surg Endosc. 2008 Aug;22(8):1845-51. Epub 2007 Dec 11. | <100 pts; f/u < 5 y
Yang H; Watson DI; Kelly J; Lally CJ; Myers JC; Jamieson GG; | Esophageal manometry and clinical outcome after laparoscopic Nissen fundoplication | J Gastrointest Surg. 2007 Sep;11(9):1126-33. | no analysis of interest
Yang HB SBWSCHCWCW; | H. pylori eradication prevents the progression of gastric intestinal metaplasia in reflux esophagitis patients using long-term esomeprazole | Am J Gastroenterol. 2009 Jul;104(7):1642-9. Epub 2009 May 12. | No treatment of interest (triple therapy)
Yi CH; Chen CL; Kuo TB; Yang CC; | The effect of acid suppression on sleep and cardiac autonomic regulation in GERD | Hepatogastroenterology. 2008 Sep-Oct;55(86-87):1649-52. | PPI vs placebo is excluded
Yoshikawa I; Nagato M; Yamasaki M; Kume K; Otsuki M; | Long-term treatment with proton pump inhibitor is associated with undesired weight gain | World J Gastroenterol. 2009 Oct 14;15(38):4794-8. | <100 patients
Youssef YK; Shekar N; Lutfi R; Richards WO; Torquati A; | Long-term evaluation of patient satisfaction and reflux symptoms after laparoscopic fundoplication with Collis gastroplasty | Surg Endosc. 2006 Nov;20(11):1702-5. Epub 2006 Sep 6. | comparison not of interest
Zaninotto G; Cassaro M; Pennelli G; Battaglia G; Farinati F; Ceolin M; Costantini M; Ruol A; Guirroli E; Rizzetto C; Portale G; Ancona E; Rugge M; | Barrett's epithelium after antireflux surgery.[see comment] | J Gastrointest Surg. 2005 Dec;9(9):1253-60; discussion 1260-1. | 100% Barrett's
Zaninotto G; Portale G; Costantini M; Rizzetto C; Guirroli E; Ceolin M; Salvador R; Rampado S; Prandin O;Ruol A; Ancona E; | Long-term results (6-10 years) of laparoscopic fundoplication | J Gastrointest Surg. 2007 Sep;11(9):1138-45. Epub 2007 Jul 10. | patients with GERD mixed with patients with BE and Hiatal hernia, results are presented together
Zeman Z; Rozsa S; Tihanyi T; Tarko E; | Psychometric documentation of a quality-of-life questionnaire for patients undergoing antireflux surgery (QOLARS) | Surg Endosc. 2005 Feb;19(2):257-61. Epub 2004 Dec 9. | topic not of interest

## II Systematic Reviews on Extra-Esophageal GERD

Author | Title | Source | Reasons for rejection
Calabrese C; Fabbri A; Areni A; Scialpi C; Zahlane D; Di FG; | Asthma and gastroesophageal reflux disease: effect of long-term pantoprazole therapy | World J Gastroenterol. 2005 Dec 28;11(48):7657-60. | non-random selection
Coughlan JL; Gibson PG; Henry RL; | Medical treatment for reflux oesophagitis does not consistently improve asthma control: a systematic review.[see comment]. [Review] [44 refs] | Thorax. 2001 Mar;56(3):198-204. | SR has already been extracted
Gibson PG; Henry RL; Coughlan JL; | Gastro-oesophageal reflux treatment for asthma in adults and children.[update of Cochrane Database Syst Rev. 2000;(2):CD001496; PMID: 10796653]. [Review] [40 refs] | Cochrane Database Syst Rev. 2003;(2):CD001496. | SR has already been included; this update search was conducted to add to this SR
Khoshoo V; Haydel R; | Effect of antireflux treatment on asthma exacerbations in nonatopic children | J Pediatr Gastroenterol Nutr. 2007 Mar;44(3):331-5. | non-random; children
Sopo SM; Radzik D; Calvani M; | Does treatment with proton pump inhibitors for gastroesophageal reflux disease (GERD) improve asthma symptoms in children with asthma and GERD? A systematic review. [Review] [11 refs] | J Investig Allergol Clin Immunol. 2009;19(1):1-5. | pediatric patients
Stordal K; Johannesdottir GB; Bentsen BS; Knudsen PK; Carlsen KC; Closs O; Handeland M; Holm HK; Sandvik L; | Acid suppression does not change respiratory symptoms in children with asthma and gastro-oesophageal reflux disease | Arch Dis Child. 2005 Sep;90(9):956-60. | pediatric patients and adoloscents
Susanto AD; Yanus F; Wiyono WH; Jusuf A; Lelosutan SAR; Prasetyo S; | Improved asthma symptoms and PEFR in moderate persistant asthma patients with GERD. The role of the proton pump inhibitor [Abstract] | Respirology. 2006 Nov;11 Suppl 5:A77-304. | conference proceedings, only abstract available
American Lung Association Asthma Clinical Research Center; Mastronarde JG; Anthonisen NR; Castro M; Holbrook JT; Leone FT; Teague WG; Wise RA; | Efficacy of esomeprazole for treatment of poorly controlled asthma.[see comment] | N Engl J Med. 2009 Apr 9;360(15):1487-99. | GERD dx not part of inclusion criteria--only 7% (29/402) of participants had GERD dx

## III Primary Studies on PPI Use and Fracture Risk

Author | Title | Source | Reasons for rejection
| Do PPIs have long-term side effects? Nexium and the other proton-pump inhibitors are great at reducing stomach acid, but that might have some unintended consequences | Harv Health Lett. 2009 Jan;34(3):4-5. | review
| Proton pump inhibitors and fractures? Beware long-term use | Prescrire Int. 2009 Oct;18(103):21 6. | unlikely to be a primary study
Iwakiri R; Fujimoto K; | Importance of vertebral fracture and body mass index in the pathogenesis of gastroesophageal reflux disease | Intern Med. 2008;47(18):15 51-3. Epub 2008 Sep 16. | review
Richards JB; Goltzman D; | Proton pump inhibitors: balancing the benefits and potential fracture risks | CMAJ. 2008 Aug 12;179(4):306-7. | commentary
Targownik LE; Lix LM; Leung S; Leslie WD; | Proton-pump inhibitor use is not associated with osteoporosis or accelerated bone mineral density loss | Gastroenterolog y. 2010 Mar;138(3):896-904. Epub 2009 Nov 18. | no fracture outcomes
Yoshimura M; Nagahara A; Ohtaka K; Shimada Y; Asaoka D; Kurosawa A; Osada T; Kawabe M; Hojo M; Yoshizawa T; Watanabe S; | Presence of vertebral fractures is highly associated with hiatal hernia and reflux esophagitis in Japanese elderly people | Intern Med. 2008;47(16):14 51-5. Epub 2008 Aug 15. | not related to PPI use