# Search Strategy

## I Primary Studies

Database: Ovid MEDLINE(R) <1996 to October Week 5 2009>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Gastroesophageal Reflux/ (10877)
2. gastro?esophageal reflux.tw. (7093)
3. gastro-esophageal reflux.tw. (474)
4. gastro-oesophageal reflux.tw. (1977)
5. exp esophagitis/ (3248)
6. esophagitis.tw. (3877)
7. oesophagitis.tw. (1161)
8. (GERD or GORD).tw. (3695)
9. bile reflux/ (210)
10. heartburn/ (791)
11. heartburn.tw. (2122)
12. (acid adj5 reflux).tw. (1496)
13. exp dyspepsia/ (3469)
14. dyspep$.tw. (5288)
15. or/1-14 (22229)
16. limit 15 to human (21510)
17. limit 16 to english language (18093)
18. limit 17 to “all adult (19 plus years)” (10095)
19. 17 not 18 (7998)
20. limit 19 to “all child (0 to 18 years)” (2307)
21. 17 not 20 (15786)
22. follow-up studies/ (221986)
23. (follow-up or followup).tw. (287251)
24. exp cohort studies/ (469036)
25. cohort.tw. (108161)
26. exp Case-Control Studies/ (336457)
27. (case adj20 control).tw. (45125)
28. exp Longitudinal Studies/ (410361)
29. longitudinal.tw. (57455)
30. (random$ or rct).tw. (327155)
31. exp Randomized Controlled Trials/ (54377)
32. exp random allocation/ (30873)
33. exp Double-Blind Method/ (57833)
34. exp Single-Blind Method/ (10625)
35. randomized controlled trial.pt. (180083)
36. clinical trial.pt. (250829)
37. controlled clinical trials/ (0)
38. (clin$ adj trial$).tw. (98722)
39. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw. (55283)
40. exp Research Design/ (161832)
41. exp Evaluation Studies/ (123323)
42. exp Prospective Studies/ (188292)
43. exp Comparative Study/ (721897)
44. or/22-41 (1499433)
45. 21 and 44 (7443)
46. limit 45 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index) (379)
47. 45 not 46 (7064)
48. limit 47 to (guideline or meta analysis or practice guideline or “review” or review, academic or “review literature” or review, multicase or “review of reported cases” or review, tutorial) [Limit not valid in Ovid MEDLINE(R); records were retained] (852)
49. 47 not 48 (6212)
50. limit 49 to yr="2004 -Current" (2928)

## II Systematic Reviews

Database: Ovid MEDLINE(R), CDSR, ACP Journal Club, DARE, CLHTA

Search Strategy:

--------------------------------------------------------------------------------

1. exp Gastroesophageal Reflux/ (10807)
2. gastro?esophageal reflux.tw. (7156)
3. gastro-esophageal reflux.tw. (484)
4. gastro-oesophageal reflux.tw. (2047)
5. exp esophagitis/ (3200)
6. esophagitis.tw. (3905)
7. oesophagitis.tw. (1215)
8. (GERD or GORD).tw. (3747)
9. bile reflux/ (207)
10. heartburn/ (773)
11. heartburn.tw. (2194)
12. (acid adj5 reflux).tw. (1532)
13. exp dyspepsia/ (3454)
14. dyspep$.tw. (5509)
15. or/1-14 (22501)
16. limit 15 to human [Limit not valid in CDSR,ACP Journal Club,DARE; records were retained] (21755)
17. limit 16 to english language [Limit not valid in CDSR,ACP Journal Club,DARE; records were retained] (18383)
18. limit 17 to “all adult (19 plus years)” [Limit not valid in CDSR,ACP Journal Club,DARE; records were retained] (10460)
19. 17 not 18 (7923)
20. limit 19 to “all child (0 to 18 years)” [Limit not valid in CDSR,ACP Journal Club,DARE; records were retained] (2275)
21. 17 not 20 (16108)
22. (systematic overview$ or systematic review$).tw. (29771)
23. systematic.tw. (75657)
24. meta analysis.pt. (19604)
25. meta-analys$.mp. [mp=ti, ot, ab, nm, hw, ui, an, tx, kw, sh, ct] (44489)
26. 25 or 22 or 24 or 23 (106759)
27. limit 26 to “review” [Limit not valid in ACP Journal Club,DARE; records were retained] (45706)
28. 27 and 21 (558)
29. atypical.mp. [mp=ti, ot, ab, nm, hw, ui, an, tx, kw, sh, ct] (40208)
30. 28 and 29 (22)
31. cough.mp. [mp=ti, ot, ab, nm, hw, ui, an, tx, kw, sh, ct] (15531)
32. 28 and 31 (46)
33. reflux laryngitis.mp. [mp=ti, ot, ab, nm, hw, ui, an, tx, kw, sh, ct] (50)
34. 33 and 28 (4)
35. asthma.mp. [mp=ti, ot, ab, nm, hw, ui, an, tx, kw, sh, ct] (55294)
36. 35 and 28 (41)
37. chest pain.mp. [mp=ti, ot, ab, nm, hw, ui, an, tx, kw, sh, ct] (12149)
38. 28 and 37 (25)
39. esophageal impedance.mp. [mp=ti, ot, ab, nm, hw, ui, an, tx, kw, sh, ct] (32)
40. impedance.mp. [mp=ti, ot, ab, nm, hw, ui, an, tx, kw, sh, ct] (14376)
41. 39 or 40 (14376)
42. 28 and 41 (7)
43. 42 or 38 or 32 or 34 or 36 or 30 (107)

## III Primary Study Search to Update Systematic Review on the Treatment of Gastroesophageal Reflux Disease and Asthma12

Database: Ovid MEDLINE(R) 1950 to November Week 3 2009; EBM Reviews - Cochrane Central Register of Controlled Trials 4th Qtr 2009

Search Strategy:

1. exp Gastroesophageal Reflux/ (19436)
2. gastro?esophageal reflux.tw. (11324)
3. gastro-esophageal reflux.tw. (865)
4. gastro-oesophageal reflux.tw. (3583)
5. exp esophagitis/ (8814)
6. esophagitis.tw. (7896)
7. oesophagitis.tw. (2773)
8. (GERD or GORD).tw. (4568
9. (“reflux” or “ger” or “gerd” or “acid” or “esophagus”).tw. (1027656)
10. bile reflux/ (651)
11. heartburn/ (1573)
12. heartburn.tw. (3651)
13. (acid adj5 reflux).tw. (2612)
14. exp dyspepsia/ (7196)
15. dyspep$.tw. (10273)
16. or/1-15 (1046853)
17. (“cimetidine” or “ranitidine” or “famotidine” or “nizatidine” or “omeprazole” or “pantoprazole” or “lansoprazole” or “rabeprazole” or “esomeprazole” or “surgery” or “Nissen” or “fundoplication” or “therapy” or “treatment”).tw. (3401111)
18. exp anti-ulcer agents/ (43815)
19. exp histamine H2 antagonists/ (21081)
20. proton pump inhibitor$.tw. (6459)
21. (“prilosec” or “zegerid” or “pepcid” or “tagamet” or “tagemet” or “axid” or “zantac”).mp. (286)
22. exp Digestive System Surgical Procedures/ (231485)
23. (“antireflux surger$” or “anti-reflux surger$” or “Belsey Mark” or “Hill gastropexy” or “Hill posterior” or “Hill repair” or “laproscop$” or “Rosetti” or “Toupet's” or “Woodward” or “Thal fundic” or “Allison's”).tw. (2010)
24. or/17-23 (3561960)
25. asthma.mp. [mp=ti, ot, ab, nm, hw, ui, sh, kw] (127269)
26. randomized controlled trial.pt. (560951)
27. controlled clinical trial.pt. (161290)
28. randomized controlled trials/ (67115)
29. Random Allocation/ (88433)
30. Double-blind Method/ (194574)
31. Single-Blind Method/ (22534)
32. clinical trial.pt. (748591)
33. Clinical Trials.mp. or exp Clinical Trials/ (275706)
34. (clinic$ adj25 trial$).tw. (222717)
35. ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. (219302)
36. Placebos/ (48648)
37. placebo$.tw. (230781)
38. random$.tw. (743435)
39. trial$.tw. (580232)
40. (randomized control trial or clinical control trial).sd. (227662)
41. (latin adj square).tw. (3535)
42. Comparative Study.tw. or Comparative Study.pt. (1641309)
43. exp Evaluation studies/ (149648)
44. Follow-Up Studies/ (437652)
45. Prospective Studies/ (331593)
46. (control$ or prospectiv$ or volunteer$).tw. (2460246)
47. Cross-Over Studies/ (45716)
48. or/26-47 (4912825)
49. 16 and 24 and 25 and 48 (885)
50. remove duplicates from 49 (710)
51. limit 50 to english language [Limit not valid in CCTR; records were retained] (604)
52. limit 51 to humans [Limit not valid in CCTR; records were retained] (568)
53. limit 52 to yr="2002 -Current" (277)

## IV PPI Use (GERD and Non-GERD Indications) and Fracture

Database: Ovid MEDLINE(R), Ovid MEDLINE(R) In-Process

Search Strategy:

--------------------------------------------------------------------------------

1. Bone Density/ (31259)
2. exp Osteoporosis/ (36259)
3. ((bone$ or plate$) adj3 mineral$).tw. (29932)
4. (bone adj2 (loss or turnover or densi$)).tw. (41898)
5. (Skelet$ adj2 (mineral$ or development$)).tw. (3069)
6. mineralization defect$.tw. (202)
7. Mineral$ content$.tw. (6959)
8. BMC.tw. (3768)
9. Osteoporo$.tw. (38113)
10. Osteomalac$.tw. (3663)
11. (Osteopath$ or osteopenia).tw. (8678)
12. Bone Development/ (10526)
13. Osteogenesis/ (14232)
14. fracture$.tw. (133687)
15. Accidental Falls/ (10664)
16. falls.tw. (21363)
17. exp “Bone and Bones”/ (409010)
18. exp PHOTON ABSORPTIOMETRY/ (13051)
19. or/1-18 (581027)
20. exp Gastroesophageal Reflux/ (18164)
21. gastro?esophageal reflux.tw. (10881)
22. gastro-esophageal reflux.tw. (824)
23. gastro-oesophageal reflux.tw. (3010)
24. exp esophagitis/ (8241)
25. esophagitis.tw. (7506)
26. oesophagitis.tw. (2250)
27. (GERD or GORD).tw. (4293)
28. bile reflux/ (632)
29. heartburn/ (1344)
30. heartburn.tw. (3056)
31. (acid adj5 reflux).tw. (2366)
32. exp dyspepsia/ (6415)
33. dyspep$.tw. (8744)
34. or/20-33 (40966)
35. limit 34 to human (37684)
36. limit 35 to english language (29047)
37. limit 36 to “all adult (19 plus years)” (16156)
38. 36 not 37 (12891)
39. limit 38 to “all child (0 to 18 years)” (3847)
40. 36 not 39 (25200)
41. exp anti-ulcer agents/ (36323)
42. exp omeprazole/ (7626)
43. omeprazole.mp. (9064)
44. lansoprazole.mp. (1972)
45. pantoprazole.mp. (1054)
46. rabeprazole.mp. (757)
47. esomeprazole.mp. (595)
48. dexlansoprazole.mp. (24)
49. exp histamine H2 antagonists/ (17528)
50. cimetidine/ (8937)
51. cimetidine.mp. (11917)
52. exp ranitidine/ (4802)
53. ranitidine.mp. (6225)
54. exp famotidine/ (1351)
55. famotidine.mp. (1783)
56. exp nizatidine/ (290)
57. nizatidine.mp. (374)
58. exp domperidone/ (1428)
59. domperidone.mp. (2041)
60. exp metoclopramide/ (4293)
61. metoclopramide.mp. (5860)
62. prokinetic$.tw. (1665)
63. proton pump inhibitor$.tw. (5868)
64. prilosec.mp. (43)
65. zegerid.mp. (5)
66. pepcid.mp. (12)
67. (tagamet or tagemet).mp. (94)
68. axid.mp. (11)
69. (zantac or protonix or nexium or prevacid or aciphex).mp. (111)
70. or/41-69 (53552)
71. 19 and 70 (314)
72. 19 and (40 or 70) (550)
73. limit 72 to (english language and humans) (413)
74. limit 73 to (addresses or bibliography or biography or case reports or letter or news or “review”) (163)
75. 73 not 74 (250)