# Appendixes

Appendix A Search Strategy

Appendix B Excluded Studies

Appendix C GERD Data Extraction Form