# Acknowledgements

The Evidence-based Practice Center thanks James Gaylor for his assistance with article retrieval and Ramon Iovin for editing this report.