# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
ALT: Alanine aminotransferase
AMSTAR: Assessment of multiple systematic reviews
ARS: anti-reflux surgery
BD: Twice daily
BMI: body mass index
CA: carcinoma
CI: Confidence Interval
CONSORT: Consolidated Standards of Reporting Trials
CVD: Cardiovascular disease
d: day, days
DBP: Diastolic blood pressure
DexLAN: Dexlanzoprazole
diff: difference
DM: Diabetes Mellitus
Dx: Diagnosis
ECH: Endocinch
EPC: Evidence-based Practice Center
ERX: Enteryx
EsOME: Esomeprazole
f/u: follow-up
FAM: Famotidine
GERD: gastroesophageal Reflux Disease
GERD-HRQL: Gastroesophageal Reflux Disease-Health-Related Quality-Of-Life
GERSS: Gastroesophageal Reflux Score
GI: gastrointestinal
GSRS: Gastrointestinal Symptoms Rating Scale
H2RA: H2 receptor antagonist
HR: Hazard ratio
ht: Height
HTN: Hypertension
hx: history
IOM: Institute of Medicine
IQR: Interquartile range
IU: International unit
LAN: Lanzoprazole
LAS: laparoscopic anti reflux surgery, laparoscopic fundoplication
LES: lower esophageal sphincter
LNF: laparoscopic Nissen fundoplication, laparoscopic Nissen Rossetti
LOS: length of stay
LPA: laparoscopic partial fundoplication, laparoscopic Toupet
MA: Meta-analysis
MED: all medical interventions
MI: Myocardial infarction
mil: Million
mo: month, months
N: Number of subjects
n: Number of subjects had event(s)
N _E_: N enrolled
NA: not applicable
nd: no data
NDO: NDO plication
N_FU_: N follow up
NIH: National Institutes of Health
NIZ: Nizatidine
nRCT: non-randomized controlled trial
NS: Not significant
OAS: Open anti-reflux surgery
O-D: On-Demand
OME: Omeprazole
OME: omeprazole
ONF: Open Nissen fundoplication, Open total fundoplication, Open Nissen Rossetti
OPA: Open partial fundoplication, Open Toupet
OR: Odds Ratio
P: P value (note upper case P; not lower case p)
P Btw: P value of difference between two interventions
PAGI-QOL: The Patient Assessment of Upper Gastrointestinal Disorders Quality of Life
PAN: Pantoprazole
PGWB: Psychological General Well-Being Index
PI(E)CO: Population, Intervention (or Exposure), Comparison and Outcome
PMID: PubMed (unique) identifier
postop: postoperative
PPI: Proton Pump Inhibitor
PSQI: Pittsburgh Sleep Quality Index
pt: patient, patients
QD: Once daily
QoL: quality-of-life
QOLRAD: GERD-specific quality-of-life questionnaire
RAB: Rabeprazole
RAN: ranitidine
RAN: Ranitidine
RCT: randomized controlled trial
regurg: regurgitation
RR: Relative risk
SBP: Systolic blood pressure
SD: Standard deviation
SE: Standard error
SF-36-M: SF-36 mental
SF-36-P: SF-36 physical
STR: Stretta
STROBE: STrengthening the Reporting of OBservational studies in Epidemiology
Suppl: supplement
sx: symptom
TEP: Technical Expert Panel
TIA: Transient ischemic attach
TOO: Task order officer
Tx: Treatment
UK: United Kingdom
U.S.: United States
vol: volume
vs: versus
w/: with
w/o: without
wk: week, weeks
WMD: Weighted mean difference
wt: weight
XO: crossover design
y: year, years