# Technical Expert Panel

Timothy Beukelman, M.D., M.S.C.E.

University of Alabama at Birmingham

Birmingham, AL

Patti Forest, M.D., M.B.A.

North Carolina Division of Medical Assistance

North Carolina Department of Health and Human Services

Raleigh, NC

Hilary M. Haftel, M.D., M.H.P.E.

University of Michigan Medical School

Ann Arbor, MI

Norman T. Ilowite, M.D.

Children's Hospital at Montefiore and Albert Einstein College of Medicine

Bronx, NY

Elizabeth Mellins, M.D.

Stanford School of Medicine

Stanford, CA

C. Egla Rabinovich, M.D., M.P.H.

Duke University Medical Center

Durham, NC

Carole A. Wallace, M.D.

University of Washington and Seattle Children's Hospital

Seattle, WA