# References

1 Manners PJ, Bower C, Manners PJ, et al. Worldwide prevalence of juvenile arthritis why does it vary so much?. J Rheumatol. 2002;29(7):1520-1530. [pmid: 12136914].
2 Helmick CG, Felson DT, Lawrence RC, et al. Estimates of the prevalence of arthritis and other rheumatic conditions in the United States. Part I. Arthritis Rheum. 2008;58(1):15-25. [pmid: 18163481].
3 Karvonen M, Viik-Kajander M, Moltchanova E, et al. Incidence of childhood type 1 diabetes worldwide. Diabetes Mondiale (DiaMond) Project Group. Diabetes Care. 2000;23(10):1516-1526. [pmid: 11023146].
4 Goldmuntz EA, White PH, Goldmuntz EA, et al. Juvenile idiopathic arthritis: a review for the pediatrician. Pediatr Rev. 2006;27(4):e24-e32. [pmid: 16581950].
5 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0. Draft posted Oct. 2007. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf. July 29, 2010.
6 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Medical Research Methodology. 2006;6:9. [pmid: 16519814].
7 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295].
8 Anonymous. Review Manager (RevMan) [Computer program]. Version 5.0. Copenhagen. The Nordic Cochrane Centre, The Cochrane Collaboration. 2008.
9 Higgins JPT, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-1558. [pmid: 12111919].
10 Higgins JPT, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-560. [pmid: 12958120].
11 Brewer EJ, Giannini EH, Kuzmina N, et al. Penicillamine and hydroxychloroquine in the treatment of severe juvenile rheumatoid arthritis. Results of the U.S.A.-U.S.S.R. double-blind placebo-controlled trial. N Engl J Med. 1986;314(20):1269-1276. [pmid: 3517643].
12 van Kerckhove C, Giannini EH, Lovell DJ. Temporal patterns of response to D-penicillamine, hydroxychloroquine, and placebo in juvenile rheumatoid arthritis patients. Arthritis Rheum. 1988;31(10):1252-1258. [pmid: 3178907].
13 Giannini EH, Brewer EJ, Kuzmina N, et al. Methotrexate in resistant juvenile rheumatoid arthritis. Results of the U.S.A.-U.S.S.R. double-blind, placebo-controlled trial. The Pediatric Rheumatology Collaborative Study Group and The Cooperative Children's Study Group. N Engl J Med. 1992;326(16):1043-1049. [pmid: 1549149].
14 Woo P, Southwood TR, Prieur AM, et al. Randomized, placebo-controlled, crossover trial of low-dose oral methotrexate in children with extended oligoarticular or systemic arthritis. Arthritis Rheum. 2000;43(8):1849-1857. [pmid: 10943876].
15 van Rossum MA, Fiselier TJ, Franssen MJ, et al. Sulfasalazine in the treatment of juvenile chronic arthritis: a randomized, double-blind, placebo-controlled, multicenter study. Dutch Juvenile Chronic Arthritis Study Group. Arthritis Rheum. 1998;41(5):808-816. [pmid: 9588731].
16 Smith JA, Thompson DJ, Whitcup SM, et al. A randomized, placebo-controlled, double-masked clinical trial of etanercept for the treatment of uveitis associated with juvenile idiopathic arthritis. Arthritis Rheum. 2005;53(1):18-23. [pmid: 15696578].
17 Ruperto N, Lovell DJ, Cuttica R, et al. A randomized, placebo-controlled trial of infliximab plus methotrexate for the treatment of polyarticular-course juvenile rheumatoid arthritis. Arthritis Rheum. 2007;56(9):3096-3106. [pmid: 17763439].
18 Kvien TK, Hoyeraal HM, Sandstad B. Azathioprine versus placebo in patients with juvenile rheumatoid arthritis: a single center double blind comparative study. J Rheumatol. 1986;13(1):118-123. [pmid: 3517321].
19 Prieur AM, Piussan C, Manigne P, et al. Evaluation of D-penicillamine in juvenile chronic arthritis. A double-blind, multicenter study. Arthritis Rheum. 1985;28(4):376-382. [pmid: 3885958].
20 Silverman ED, Cawkwell GD, Lovell DJ, et al. Intravenous immunoglobulin in the treatment of systemic juvenile rheumatoid arthritis: a randomized placebo controlled trial. Pediatric Rheumatology Collaborative Study Group. J Rheumatol. 1994;21(12):2353-2358. [pmid: 7699642].
21 Kvien TK, Hoyeraal HM, Sandstad B. Slow acting antirheumatic drugs in patients with juvenile rheumatoid arthritis—evaluated in a randomized, parallel 50-week clinical trial. J Rheumatol. 1985;12(3):533-539. [pmid: 3930720].
22 Oppermann J, Mobius D. Therapeutical and immunological effects of methylprednisolone pulse therapy in comparison with intravenous immunoglobulin. Treatment in patients with juvenile chronic arthritis. Acta Univ Carol Med (Praha). 1994;40(1-4):117-121. [pmid: 9355686].
23 Riddle R, Ryser CN, Morton AA, et al. The impact on health-related quality of life from non-steroidal anti-inflammatory drugs, methotrexate, or steroids in treatment for juvenile idiopathic arthritis. J Pediatr Psychol. 2006;31(3):262-271. [pmid: 15872147].
24 Ruperto N, Lovell DJ, Quartier P, et al. Abatacept in children with juvenile idiopathic arthritis: a randomised, double-blind, placebo-controlled withdrawal trial. Lancet. 2008;372(9636):383-391. [pmid: 18632147].
25 Lovell DJ, Ruperto N, Goodman S, et al. Adalimumab with or without methotrexate in juvenile rheumatoid arthritis. N Engl J Med. 2008;359(8):810-20. [pmid: 18716298].
26 Lovell DJ, Giannini EH, Reiff A, et al. Etanercept in children with polyarticular juvenile rheumatoid arthritis. Pediatric Rheumatology Collaborative Study Group. N Engl J Med. 2000;342(11):763-769. [pmid: 10717011].
27 Lovell DJ, Giannini EH, Reiff A, et al. Long-term efficacy and safety of etanercept in children with polyarticular-course juvenile rheumatoid arthritis: interim results from an ongoing multicenter, open-label, extended-treatment trial. Arthritis Rheum. 2003;48(1):218-226. [pmid: 12528122].
28 Giannini EH, Lovell DJ, Silverman ED, et al. Intravenous immunoglobulin in the treatment of polyarticular juvenile rheumatoid arthritis: a phase I/II study. Pediatric Rheumatology Collaborative Study Group. J Rheumatol. 1996;23(5):919-924. [pmid: 8724309].
29 Yokota S, Imagawa T, Mori M, et al. Efficacy and safety of tocilizumab in patients with systemic-onset juvenile idiopathic arthritis: a randomised, double-blind, placebo-controlled, withdrawal phase III trial. Lancet. 2008;371(9617):998-1006. [pmid: 18358927].
30 Ilowite N, Porras O, Reiff A, et al. Anakinra in the treatment of polyarticular-course juvenile rheumatoid arthritis: safety and preliminary efficacy results of a randomized multicenter study. Clin Rheumatol. 2009;28(2):129-137. [pmid: 18766426].
31 Lahdenne P, Vahasalo P, Honkanen V. Infliximab or etanercept in the treatment of children with refractory juvenile idiopathic arthritis: an open label study. Ann Rheum Dis. 2003;62(3):245-247. [pmid: 12594111].
32 Hoza J, Kadlecova T, Nemcova D, et al. Sulphasalazine and Delagil—a comparative study in patients with juvenile chronic arthritis. Acta Univ Carol Med (Praha). 1991;37(1-2):80-83. [pmid: 1688268].
33 Silverman E, Mouy R, Spiegel L, et al. Leflunomide or methotrexate for juvenile rheumatoid arthritis. N Engl J Med. 2005;352(16):1655-1666. [pmid: 15843668].
34 Diak P, Siegel J, La Grenade L, et al. Tumor necrosis factor (alpha) blockers and malignancy in children: Forty-eight cases reported to the food and drug administration. Arthritis Rheum. 2010;62(8):2517-2524. [pmid: 20506368].
35 McCroskery P, Wallace CA, Lovell DJ, et al. Summary of worldwide pediatric malignancies reported after exposure to etanercept. Pediatric Rheumatology. 2010:8.
36 Krugmann J, Sailer-Hock M, Muller T, et al. Epstein-Barr virus-associated Hodgkin's lymphoma and legionella pneumophila infection complicating treatment of juvenile rheumatoid arthritis with methotrexate and cyclosporine A. Hum Pathol. 2000;31(2):253-255. [pmid: 10685644].
37 Horneff G, Schmeling H, Biedermann T, et al. The German etanercept registry for treatment of juvenile idiopathic arthritis. Ann Rheum Dis. 2004;63(12):1638-1644. [pmid: 15115709].
38 Horneff G, De Bock F, Foeldvari I, et al. Safety and efficacy of combination of etanercept and methotrexate compared to treatment with etanercept only in patients with juvenile idiopathic arthritis (JIA): preliminary data from the German JIA Registry. Ann Rheum Dis. 2009;68(4):519-525. [pmid: 18413440].
39 Yildirim-Toruner C, Kimura Y, Rabinovich E. Hodgkin's lymphoma and tumor necrosis factor inhibitors in juvenile idiopathic arthritis. J Rheumatol. 2008;35(8):1680-1681. [pmid: 18671328].
40 Cleary AG, McDowell H, Sills JA. Polyarticular juvenile idiopathic arthritis treated with methotrexate complicated by the development of non-Hodgkin's lymphoma. Arch Dis Child. 2002;86(1):47-49. [pmid: 11806884].
41 Takeyama J, Sato A, Nakano K, et al. Epstein-Barr virus associated Hodgkin lymphoma in a 9-year-old girl receiving long-term methotrexate therapy for juvenile idiopathic arthritis. J Pediatr Hematol Oncol. 2006;28(9):622-624. [pmid: 17006270].
42 Padeh S, Sharon N, Schiby G, et al. Hodgkin's lymphoma in systemic onset juvenile rheumatoid arthritis after treatment with low dose methotrexate. J Rheumatol. 1997;24(10):2035-2037. [pmid: 9330950].
43 Wallace CA, Ruperto N, Giannini E, et al. Preliminary criteria for clinical remission for select categories of juvenile idiopathic arthritis. J Rheumatol. 2004;31(11):2290-2294. [pmid: 15517647].
44 Wallace CA, Ravelli A, Huang B, et al. Preliminary validation of clinical remission criteria using the OMERACT filter for select categories of juvenile idiopathic arthritis. J Rheumatol. 2006;33(4):789-795. [pmid: 16482643].
45 Brunner HI, Lovell DJ, Finck BK, et al. Preliminary definition of disease flare in juvenile rheumatoid arthritis. J Rheumatol. 2002;29(5):1058-1064. [pmid: 12022323].
46 Brown GT, Wright FV, Lang BA, et al. Clinical responsiveness of self-report functional assessment measures for children with juvenile idiopathic arthritis undergoing intraarticular corticosteroid injections. Arthritis Rheum. 2005;53(6):897-904. [pmid: 16342103].
47 Bekkering WP, ten Cate R, van Rossum MA, et al. A comparison of the measurement properties of the Juvenile Arthritis Functional Assessment Scale with the childhood health assessment questionnaire in daily practice. Clin Rheumatol. 2007;26(11):1903-1907. [pmid: 17700993].
48 Brunner HI, Johnson AL, Barron AC, et al. Gastrointestinal symptoms and their association with health-related quality of life of children with juvenile rheumatoid arthritis: validation of a gastrointestinal symptom questionnaire. J Clin Rheumatol. 2005;11(4):194-204. [pmid: 16357756].
49 Brunner HI, Klein-Gitelman MS, Miller MJ, et al. Minimal clinically important differences of the childhood health assessment questionnaire. J Rheumatol. 2005;32(1):150-161. [pmid: 15630741].
50 Dempster H, Porepa M, Young N, et al. The clinical meaning of functional outcome scores in children with juvenile arthritis. Arthritis Rheum. 2001;44(8):1768-1774. [pmid: 11508427].
51 Geerdink LM, Prince FH, Looman CW, et al. Development of a digital Childhood Health Assessment Questionnaire for systematic monitoring of disease activity in daily practice. Rheumatology (Oxford). 2009;48(8):958-963. [pmid: 19509189].
52 Len C, Goldenberg J, Ferraz MB, et al. Crosscultural reliability of the Childhood Health Assessment Questionnaire. J Rheumatol. 1994;21(12):2349-2352. [pmid: 7699641].
53 Palmisani E, Solari N, Magni-Manzoni S, et al. Correlation between juvenile idiopathic arthritis activity and damage measures in early, advanced, and longstanding disease. Arthritis Rheum. 2006;55(6):843-849. [pmid: 17139659].
54 Pouchot J, Larbre JP, Lemelle I, et al. Validation of the French version of the Childhood Health Assessment Questionnaire (CHAQ) in juvenile idiopathic arthritis. Joint Bone Spine. 2002;69(5):468-481. [pmid: 12477231].
55 Pouchot J, Ecosse E, Coste J, et al. Validity of the childhood health assessment questionnaire is independent of age in juvenile idiopathic arthritis. Arthritis Rheum. 2004;51(4):519-526. [pmid: 15334422].
56 Saad-Magalhaes C, Pistorio A, Ravelli A, et al. Does removal of aids/devices and help make a difference in the Childhood Health Assessment Questionnaire disability index?. Ann Rheum Dis. 2010;69(1):82-87. [pmid: 19221399].
57 Singh G, Athreya BH, Fries JF, et al. Measurement of health status in children with juvenile rheumatoid arthritis. Arthritis Rheum. 1994;37(12):1761-1769. [pmid: 7986222].
58 Stephens S, Singh-Grewal D, Bar-Or O, et al. Reliability of exercise testing and functional activity questionnaires in children with juvenile arthritis. Arthritis Rheum. 2007;57(8):1446-1452. [pmid: 18050186].
59 Takken T, van den Eijkhof F, Hoijtink H, et al. Examining the psychometric characteristics of the Dutch childhood health assessment questionnaire: room for improvement?. Rheumatol Int. 2006;26(11):979-983. [pmid: 16468046].
60 Tennant A, Kearns S, Turner F, et al. Measuring the function of children with juvenile arthritis. Rheumatology (Oxford). 2001;40(11):1274-1278. [pmid: 11709611].
61 van der Net J, Prakken AB, Helders PJ, et al. Correlates of disablement in polyarticular juvenile chronic arthritis--a cross-sectional study. Br J Rheumatol. 1996;35(1):91-100. [pmid: 8624631].
62 Cespedes-Cruz A, Gutierrez-Suarez R, Pistorio A, et al. Methotrexate improves the health-related quality of life of children with juvenile idiopathic arthritis. Ann Rheum Dis. 2008;67(3):309-314. [pmid: 17875547].
63 Oliveira S, Ravelli A, Pistorio A, et al. Proxy-reported health-related quality of life of patients with juvenile idiopathic arthritis: the Pediatric Rheumatology International Trials Organization multinational quality of life cohort study. Arthritis Rheum. 2007;57(1):35-43. [pmid: 17266064].
64 Selvaag AM, Flato B, Lien G, et al. Measuring health status in early juvenile idiopathic arthritis: determinants and responsiveness of the child health questionnaire. J Rheumatol. 2003;30(7):1602-1610. [pmid: 12858465].
65 Sawyer MG, Carbone JA, Whitham JN, et al. The relationship between health-related quality of life, pain, and coping strategies in juvenile arthritis—a one year prospective study. Qual Life Res. 2005;14(6):1585-1598. [pmid: 16110938].
66 Bazso A, Consolaro A, Ruperto N, et al. Development and testing of reduced joint counts in juvenile idiopathic arthritis. J Rheumatol. 2009;36(1):183-190. [pmid: 19208532].
67 Bekkering WP, ten Cate R, van Suijlekom-Smit LW, et al. The relationship between impairments in joint function and disabilities in independent function in children with systemic juvenile idiopathic arthritis. J Rheumatol. 2001;28(5):1099-1105. [pmid: 11361196].
68 Magni-Manzoni S, Cugno C, Pistorio A, et al. Responsiveness of clinical measures to flare of disease activity in juvenile idiopathic arthritis. Clin Exp Rheumatol. 2005;23(3):421-425. [pmid: 15971436].
69 Ruperto N, Ravelli A, Migliavacca D, et al. Responsiveness of clinical measures in children with oligoarticular juvenile chronic arthritis. J Rheumatol. 1999;26(8):1827-1830. [pmid: 10451084].
70 Moretti C, Viola S, Pistorio A, et al. Relative responsiveness of condition specific and generic health status measures in juvenile idiopathic arthritis. Ann Rheum Dis. 2005;64(2):257-261. [pmid: 15647433].
71 Filocamo G, Sztajnbok F, Cespedes-Cruz A, et al. Development and validation of a new short and simple measure of physical function for juvenile idiopathic arthritis. Arthritis Rheum. 2007;57(6):913-920. [pmid: 17665481].
72 Brunner HI, Klein-Gitelman MS, Miller MJ, et al. Health of children with chronic arthritis: relationship of different measures and the quality of parent proxy reporting. Arthritis Rheum. 2004;51(5):763-773. [pmid: 15478144].
73 Consolaro A, Vitale R, Pistorio A, et al. Physicians' and parents' ratings of inactive disease are frequently discordant in juvenile idiopathic arthritis. J Rheumatol. 2007;34(8):1773-1776. [pmid: 17611978].
74 Filocamo G, Davi S, Pistorio A, et al. Evaluation of 21-numbered circle and 10-centimeter horizontal line visual analog scales for physician and parent subjective ratings in juvenile idiopathic arthritis. J Rheumatol. 2010;37(7):1534-1541. [pmid: 20551105].
75 Sztajnbok F, Coronel-Martinez DL, Diaz-Maldonado A, et al. Discordance between physician's and parent's global assessments in juvenile idiopathic arthritis. Rheumatology (Oxford). 2007;46(1):141-145. [pmid: 16782733].
76 Lurati A, Pontikaki I, Teruzzi B, et al. A comparison of response criteria to evaluate therapeutic response in patients with juvenile idiopathic arthritis treated with methotrexate and/or anti-tumor necrosis factor alpha agents. Arthritis Rheum. 2006;54(5):1602-1607. [pmid: 16646003].
77 Giannini EH, Ruperto N, Ravelli A, et al. Preliminary definition of improvement in juvenile arthritis. Arthritis Rheum. 1997;40(7):1202-1209. [pmid: 9214419].
78 Ruperto N, Ravelli A, Falcini F, et al. Performance of the preliminary definition of improvement in juvenile chronic arthritis patients treated with methotrexate. Italian Pediatric Rheumatology Study Group. Ann Rheum Dis. 1998;57(1):38-41. [pmid: 9536821].
79 Liang MH, Fossel AH, Larson MG. Comparisons of five health status instruments for orthopedic evaluation. Med Care. 1990;28(7):632-642. [pmid: 2366602].
80 Deyo RA, Diehr P, Patrick DL. Reproducibility and responsiveness of health status measures. Statistics and strategies for evaluation. Control Clin Trials. 1991;12(4 Suppl):142S-158S. [pmid: 1663851].
81 Guyatt G, Walter S, Norman G. Measuring change over time: assessing the usefulness of evaluative instruments. J Chronic Dis. 1987;40(2):171-178. [pmid: 3818871].
82 Cohen J. Statistical power for the behavioral sciences. 2. Hillsdale, NJ. Lawrence Erlbaum Associates. 1988.
83 Deyo RA, Centor RM. Assessing the responsiveness of functional scales to clinical change: an analogy to diagnostic test performance. J Chronic Dis. 1986;39(11):897-906. [pmid: 2947907].
84 Consolaro A, Ruperto N, Bazso A, et al. Development and validation of a composite disease activity score for juvenile idiopathic arthritis. Arthritis Rheum. 2009;61(5):658-666. [pmid: 19405003].
85 Magni-Manzoni S, Ruperto N, Pistorio A, et al. Development and validation of a preliminary definition of minimal disease activity in patients with juvenile idiopathic arthritis. Arthritis Rheum. 2008;59(8):1120-1127. [pmid: 18668599].
86 Magni-Manzoni S, Pistorio A, Labo E, et al. A longitudinal analysis of physical functional disability over the course of juvenile idiopathic arthritis. Ann Rheum Dis. 2008;67(8):1159-1164. [pmid: 17965116].
87 Simard JF, Neovius M, Hagelberg S, et al. Juvenile idiopathic arthritis and risk of cancer: A nationwide cohort study. Arthritis Rheum. 2010;62(12):3776-3782. [pmid: 20827782].