# Peer Reviewers

Mara Becker, M.D., M.S.C.E.

University of Missouri/Kansas City

Kansas City, MO

Timothy Beukelman, M.D., M.S.C.E.

University of Alabama at Birmingham

Birmingham, AL

Gerald Gartlehner, M.D., M.P.H.

Danube University Krems;

Krems, Austria

Mark Hoeltzel, M.D.

Children's Mercy Hospital

Kansas City, MO

Norman T Ilowite, M.D.

Children's Hospital at Montefiore and Albert Einstein College of Medicine

Bronx, NY

Yuki Kimura, M.D.

Hackensack University Medical Center

Hackensack, NJ

Carole A Wallace, M.D.

University of Washington and Seattle

Children's Hospital

Seattle, WA