# Excluded Studies

All studies listed below were reviewed in their full-text version and excluded. Following each reference, in italics, is the reason for exclusion. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

Abinun M, Flood TJ, Cant AJ, et al. Autologous T cell depleted haematopoietic stem cell transplantation in children with severe juvenile idiopathic arthritis in the UK (2000-2007). Mol Immunol. 2009;47(1):46-51. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 19203795].
Agarwal V, Aggarwal A, Misra R. Methotrexate induced accelerated nodulosis. J Assoc Physicians India. 2004;52:538-40. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 15645976].
Aggarwal A, Agarwal V, Danda D, et al. Outcome in juvenile rheumatoid arthritis in India. Indian Pediatr. 2004;41(2):180-4. Q1, 2, 4 - Exclude study not prospective. [pmid: 15004305].
Aggarwal R, Manadan AM, Poliyedath A, et al. Safety of etanercept in patients at high risk for mycobacterial tuberculosis infections. J Rheumatol. 2009;36(5):914-7. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 19332623].
Aikawa NE, Carvalho JF, Bonfa E, et al. Macrophage activation syndrome associated with etanercept in a child with systemic onset juvenile idiopathic arthritis. Israel Medical Association Journal. 2009;11(10):635-636. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 20077954].
Alarcon GS, Morgan SL. Folinic acid to prevent side effects of methotrexate in juvenile rheumatoid arthritis. J Rheumatol. 1996;23(12):2184-5. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 8970066].
al-Sewairy W, al-Mazyed A, al D, et al. Methotrexate therapy in systemic-onset juvenile rheumatoid arthritis in Saudi Arabia: a retrospective analysis. Clin Rheumatol. 1998;17(1):52-7. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 9586680].
Andre M, Hagelberg S, Stenstrom CH. The juvenile arthritis foot disability index: development and evaluation of measurement properties. J Rheumatol. 2004;31(12):2488-93. Q5 - Exclude not priority instrument. [pmid: 15570656].
Angeles-Han S, Flynn T, Lehman T. Abatacept for refractory juvenile idiopathic arthritis-associated uveitis- a case report. J Rheumatol. 2008;35(9):1897-8. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 18785302].
Angevaren M, Aufdemkampe G, Verhaar HJ, et al. Physical activity and enhanced fitness to improve cognitive function in older people without known cognitive impairment. Cochrane Database of Systematic Reviews. 2008;(3):CD005381. Exclude - population not JIA/JRA/JCA.
Anonymous. Review Manager (RevMan) [Computer program] Version 5.0. Copenhagen. The Nordic Cochrane Centre, The Cochrane Collaboration. 2008. Exclude - computer program.
Anonymous. Efficacy of etanercept in the treatment of children with polyarticular juvenile rheumatoid arthritis. Eur J Pediatr. 2000;159(10):785. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported.
Ansell BM. Cyclosporin A in paediatric rheumatology. Clin Exp Rheumatol. 1993;11(2):113-5. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 8508552].
Ansell BM, Hall MA. Penicillamine in chronic arthritis of childhood. J Rheumatol Suppl. 1981;7:112-5. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 6939872].
Ansell BM, Hall MA, Loftus JK, et al. A multicentre pilot study of sulphasalazine in juvenile chronic arthritis. Clin Exp Rheumatol. 1991;9(2):201-3. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 1676352].
Ansell BM, Moran H, Arden GP. Penicillamine and wound healing in rheumatoid arthritis. Proc R Soc Med. 3. 1977;70:75-7. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 122679].
Ansell BM, Simpson C. The effect of penicillamine on growth as height in juvenile chronic polyarthritis. Proc R Soc Med. 3. 1977;70:123-5. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 122658].
April KT, Feldman DE, Platt RW, et al. Comparison between children with Juvenile Idiopathic Arthritis (JIA) and their parents concerning perceived quality of life. Research. 2006;15(4):655-661. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude not priority measure.
Arakawa H, Yamasaki M, Kurihara Y, et al. Methotrexate-induced pulmonary injury: serial CT findings. J Thorac Imaging. 2003;18(4):231-6. Q1, 2, 4 - Exclude population > 18. [pmid: 14561908].
Arguedas O, Fasth A, Andersson-Gare B. A prospective population based study on outcome of juvenile chronic arthritis in Costa Rica. J Rheumatol. 2002;29(1):174-83. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no AE data reported. [pmid: 11824957].
Armbrust W, Kamphuis SS, Wolfs TW, et al. Tuberculosis in a nine-year-old girl treated with infliximab for systemic juvenile idiopathic arthritis. Rheumatology (Oxford). 2004;43(4):527-9. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 15024141].
Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. Exclude - methods paper. [pmid: 15205295].
Bacon BR, Treuhaft WH, Goodman AM. Azathioprine-induced pancytopenia. Occurrence in two patients with connective-tissue diseases. Arch Intern Med. 1981;141(2):223-6. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 7458518].
Balci DD, Peker E, Duran N, et al. Sulfasalazine-induced hypersensitivity syndrome in a 15-year-old boy associated with human herpesvirus-6 reactivation. Cutan Ocul Toxicol. 2009;28(1):45-7. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 19514926].
Bandeira M, Falcone A, Pistorio A, et al. Weighting improves the information provided by joint counts on the severity of arthritis and its impact on patients' well-being in juvenile idiopathic arthritis. Rheumatology (Oxford). 2006;45(3):343-347. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude not priority measure. [pmid: 16234273].
Barash J, Cooper M, Tauber Z. Hepatic, cutaneous and hematologic manifestations in juvenile chronic arthritis. Clin Exp Rheumatol. 1991;9(5):541-3. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 1954707].
Barlow JH, Shaw KL, Wright CC. Development and preliminary validation of a self-efficacy measure for use among parents of children with juvenile idiopathic arthritis. Arthritis Care Res. 2000;13(4):227-36. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude not priority instrument. [pmid: 14635277].
Barlow JH, Shaw KL, Wright CC. Development and preliminary validation of a children's arthritis self-efficacy scale. Arthritis Care Res. 2001;45(2):159-166. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention.
Barron KS, Sher MR, Silverman ED. Intravenous immunoglobulin therapy: magic or black magic. J Rheumatol Suppl. 1992;33:94-7. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 1593608].
Bass JC, Giannini EH, Brewer EJ, et al. Pirprofen (Rengasil) in the treatment of juvenile rheumatoid arthritis. A segment I study. J Rheumatol. 1982;9(1):140-3. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 7086772].
Becker M, Rose CD, McIlvain-Simpson G. Niacin-like reaction to infliximab infusion in systemic juvenile rheumatoid arthritis. J Rheumatol. 2004;31(12):2529-30. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 15570667].
Becker ML, Rose CD, Cron RQ, et al. Effectiveness and toxicity of methotrexate in juvenile idiopathic arthritis: Comparison of 2 initial dosing regimens. J Rheumatol. 2010;37(4):870-875. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 20194449].
Benestad B, Vinje O, Veierod MB, et al. Quantitative and qualitative assessments of pain in children with juvenile chronic arthritis based on the Norwegian version of the Pediatric Pain Questionnaire. Scand J Rheumatol. 1996;25(5):293-299. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 8921922].
Bertamino M, Rossi F, Pistorio A, et al. Development and initial validation of a radiographic scoring system for the hip in juvenile idiopathic arthritis. J Rheumatol. 2010;37(2):432-439. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 20032107].
Bertamino M, Rossi F, Pistorio A, et al. Development and initial validation of a radiographic scoring system for the hip in juvenile idiopathic arthritis. J Rheumatol. 2010;37(2):432-9. Exclude - no clinical outcomes measure. [pmid: 20032107].
Berthelot JM, De Bandt M, Goupille P, et al. Exposition to anti-TNF drugs during pregnancy: outcome of 15 cases and review of the literature. Joint Bone Spine. 2009;76(1):28-34. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 19059799].
Bianchi ML, Cimaz R, Galbiati E, et al. Bone mass change during methotrexate treatment in patients with juvenile rheumatoid arthritis. Osteoporos Int. 1999;10(1):20-5. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 10501775].
Biester S, Deuter C, Michels H, et al. Adalimumab in the therapy of uveitis in childhood. Br J Ophthalmol. 2007;91(3):319-24. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 17035274].
Billiau AD, Cornillie F, Wouters C. Infliximab for systemic onset juvenile idiopathic arthritis: experience in 3 children. J Rheumatol. 2002;29(5):1111-4. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 12022340].
Billiau AD, Loop M, Le PQ, et al. Etanercept improves linear growth and bone mass acquisition in MTX-resistant polyarticular-course juvenile idiopathic arthritis. Rheumatology (Oxford). 2010;49(8):1550-1558. Exclude Q1, 2, 4 - no acceptable comparator. [pmid: 20444859].
Bjerkhoel F, Forre O. Cyclosporin treatment of a patient with severe systemic juvenile rheumatoid arthritis. Scand J Rheumatol. 1988;17(6):483-6. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 3242506].
Bloom BJ. Development of diabetes mellitus during etanercept therapy in a child with systemic-onset juvenile rheumatoid arthritis. Arthritis Rheum. 2000;43(11):2606-2608. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 11083287].
Bongartz T. Tocilizumab for rheumatoid and juvenile idiopathic arthritis. Lancet. 2008;371(9617):961-3. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 18358909].
Bout-Tabaku S, Rivas-Chacon R, Restrepo R. Systemic lupus erythematosus in a patient treated with etanercept for polyarticular juvenile rheumatoid arthritis. J Rheumatol. 2007;34(12):2503-4. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 18061971].
Bowyer SL, Roettcher PA, Higgins GC, et al. Health status of patients with juvenile rheumatoid arthritis at 1 and 5 years after diagnosis. J Rheumatol. 2003;30(2):394-400. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 12563701].
Braun-Moscovici Y, Markovits D, Rozin A, et al. Anti-tumor necrosis factor therapy: 6 year experience of a single center in northern Israel and possible impact of health policy on results. Isr Med Assoc J. 2008;10(4):277-81. Q1, 2, 4 - Exclude population >18; Q3 - Exclude population >18 background. [pmid: 18548981].
Bresnihan FP, Ansell BM. Effect of penicillamine treatment on immune complexes in two cases of seropositive juvenile rheumatoid arthritis. Ann Rheum Dis. 1975;35(5):463-5. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 1086656].
Brik R, Berkowitz D, Berant M. Duration of methotrexate treatment until partial and total remission of refractory juvenile rheumatoid arthritis. Ann Rheum Dis. 1998;57(3):174-5. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 9640138].
Brik R, Gepstein V, Berkovitz D. Low-dose methotrexate treatment for oligoarticular juvenile idiopathic arthritis nonresponsive to intra-articular corticosteroids. Clin Rheumatol. 2005;24(6):612-4. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 15877178].
Brunner HI, Silverman ED, To T, et al. Risk factors for damage in childhood-onset systemic lupus erythematosus: cumulative disease activity and medication use predict disease damage. Arthritis Rheum. 2002;46(2):436-44. Q5 - Exclude population not JIA/JRA/JCA. [pmid: 11840446].
Buckley LM, Bullaboy CA, Leichtman L, et al. Multiple congenital anomalies associated with weekly low-dose methotrexate treatment of the mother. Arthritis Rheum. 1997;40(5):971-3. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 9153561].
Burgos-Vargas R, Vazquez-Mellado J, Pacheco-Tena C, et al. A 26 week randomised, double blind, placebo controlled exploratory study of sulfasalazine in juvenile onset spondyloarthropathies. Ann Rheum Dis. 2002;61(10):941-2. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 12228171].
Burmester GR, Mease P, Dijkmans BA, et al. Adalimumab safety and mortality rates from global clinical trials of six immune-mediated inflammatory diseases. Ann Rheum Dis. 2009;68(12):1863-9. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 19147611].
Butbul YA, Tyrrell PN, Schneider R, et al. Comparison of patients with juvenile psoriatic arthritis and nonpsoriatic juvenile idiopathic arthritis: how different are they?. J Rheumatol. 2009;36(9):2033-41. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 19648305].
Camiciottoli G, Trapani S, Castellani W, et al. Effect on lung function of methotrexate and non-steroid anti-inflammatory drugs in children with juvenile rheumatoid arthritis. Rheumatol Int. 1998;18(1):11-6. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 9672993].
Canna S, Frankovich J, Higgins G, et al. Acute hepatitis in three patients with systemic juvenile idiopathic arthritis taking interleukin-1 receptor antagonist. Pediatric Rheumatology. 2009;7. Q1, 2, 4 - Exclude no acceptabl comparator.
Cannioto Z, Taddio A, Lepore L, et al. Atlanto-axial subluxation in a patient with polyarticular juvenile idiopathic arthritis: clinical and radiological response to infliximab. Clin Exp Rheumatol. 2008;26(4):704-5. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 18799110].
Caspi D, Fuchs D, Yaron M. Sulphasalazine induced hepatitis in juvenile rheumatoid arthritis. Ann Rheum Dis. 1992;51(2):275-6. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 1347987].
Cespedes-Cruz A, Gutierrez-Suarez R, Pistorio A, et al. Methotrexate improves the health-related quality of life of children with juvenile idiopathic arthritis. Ann Rheum Dis. 2008;67(3):309-14. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no AE data reported. [pmid: 17875547].
Chan AY, Liu DT. Methotrexate and chronic uveitis associated with juvenile idiopathic arthritis. J Rheumatol. 2006;33(1):198. author reply 198. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 16395772].
Chaplin JE, Koopman HM, Schmidt S, et al. DISABKIDS Smiley questionnaire: The TAKE 6 assisted health-related quality of life measure for 4 to 7-year-olds. Clinical Psychology and Psychotherapy. 2008;15(3):173-180. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 19115438].
Chedeville G, Quartier P, Miranda M, et al. Improvements in growth parameters in children with juvenile idiopathic arthritis associated with the effect of methotrexate on disease activity. Joint Bone Spine. 2005;72(5):392-6. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 16087383].
Chen CC, Lin YT, Yang YH, et al. Sulfasalazine therapy for juvenile rheumatoid arthritis. J Formos Med Assoc. 2002;101(2):110-6. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 12099201].
Chou CT. The clinical application of etanercept in Chinese patients with rheumatic diseases. Mod Rheumatol. 2006;16(4):206-13. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 16906369].
Cimaz R, Corona F, Scarazatti M, et al. Methotrexate treatment every other week in patients with juvenile chronic arthritis. Br J Rheumatol. 1996;35(10):1030-1. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 8883448].
Cimaz R, Gana S, Braccesi G, et al. Sydenham's chorea in a girl with juvenile idiopathic arthritis treated with anti-TNF(alpha) therapy. Mov Disord. 2010;25(4):511-514. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 20014056].
Cleary AG, McDowell H, Sills JA. Polyarticular juvenile idiopathic arthritis treated with methotrexate complicated by the development of non-Hodgkin's lymphoma. Arch Dis Child. 2002;86(1):47-9. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 11806884].
Cohen J. Statistical power for the behavioral sciences. 2. Hillsdale, NJ. Lawrence Erlbaum Associates. 1988. Exclude - methods paper.
Connelly M, Anthony KK, Sarniak R, et al. Parent Pain Responses as Predictors of Daily Activities and Mood in Children with Juvenile Idiopathic Arthritis: The Utility of Electronic Diaries. J Pain Symptom Manage. 2010;39(3):579-590. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 20303032].
Consolaro A, Ruperto N, Bazso A, et al. Development and validation of a composite disease activity score for juvenile idiopathic arthritis. Arthritis Rheum. 2009;61(5):658-66. Q5 - Exclude not priority instrument. [pmid: 19405003].
Consolaro A, Vitale R, Pistorio A, et al. Physicians' and parents' ratings of inactive disease are frequently discordant in juvenile idiopathic arthritis. J Rheumatol. 2007;34(8):1773-6. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no AE data reported. [pmid: 17611978].
Corona F, Bardare M, Cimaz R, et al. Methotrexate in juvenile chronic arthritis. Clin Exp Rheumatol. 1993;11(3):346-7. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 8353993].
Corona F, Scarazatti M, Dell'Era L, et al. Active refractory juvenile idiopathic arthritis: Treatment with infliximab. Efficacy and safety. Italian Journal of Pediatrics. 2004;30(3):165-168. Exclude Q1, Q2, Q4 - no acceptable comparator.
Cortis E, Insalaco A. Macrophage activation syndrome in juvenile idiopathic arthritis. Acta Paediatr Suppl. 2006;95(452):38-41. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 16801165].
Coulton CJ, Zborowsky E, Lipton J, et al. Assessment of the reliability and validity of the arthritis impact measurement scales for children with juvenile arthritis. Arthritis Rheum. 1987;30(7):819-24. Q5 - Exclude does not use TEP-indicated instrument. [pmid: 3619964].
Cron RQ, Beukelman T. Guilt by association - what is the true risk of malignancy in children treated with etanercept for JIA?. Pediatric Rheumatology. 2010;8. Exclude Q1, 2, 4 - publication not peer-reviewed Exclude; Q3 - no AE data reported.
Cron RQ, Sherry DD, Wallace CA. Methotrexate-induced hypersensitivity pneumonitis in a child with juvenile rheumatoid arthritis. J Pediatr. 1998;132(5):901-2. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 9602213].
Dallocchio A, Canioni D, Ruemmele F, et al. Occurrence of inflammatory bowel disease during treatment of juvenile idiopathic arthritis with etanercept: A French retrospective study. Rheumatology (Oxford). 2010;49(9):1694-1698. Exclude Q1, 2, 4 - no acceptable comparator. [pmid: 20472717].
de Castro TC, Terreri MT, Len C, et al. Treatment of refractory juvenile idiopathic arthritis via pulse therapy using methylprednisolone and cyclophosphamide. Sao Paulo Med J. 2003;121(3):117-20. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 12920473].
De Civita M, Dobkin PL, Ehrmann-Feldman D, et al. Development and preliminary reproducibility and validity of the parent adherence report questionnaire: A measure of adherence in juvenile idiopathic arthritis. Journal of Clinical Psychology in Medical Settings. 2005;12(1):1-12. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention.
de Moraes JCB, Aikawa NE, Ribeiro ACM, et al. Immediate complications of 3,555 injections of anti-TNF(alpha). Revista Brasileira de Reumatologia. 2010;50(2):170-175. Exclude Q1, 2, 4 -population not JIA/JRA/JCA Exclude; Q3 - population not JIA/JRA.
Dekker L, Armbrust W, Rademaker CM, et al. Safety of anti-TNFalpha therapy in children with juvenile idiopathic arthritis. Clin Exp Rheumatol. 2004;22(2):252-8. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 15083897].
Del Paine DW, Leek JC, Jakle C, et al. Gynecomastia associated with low dose methotrexate therapy. Arthritis Rheum. 1983;26(5):691-2. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude population > 18. [pmid: 6847735].
Devlin J, Gough A, Huissoon A, et al. The acute phase and function in early rheumatoid arthritis. C-reactive protein levels correlate with functional outcome. J Rheumatol. 1997;24(1):9-13. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 9002004].
Deyo RA, Centor RM. Assessing the responsiveness of functional scales to clinical change: an analogy to diagnostic test performance. J Chronic Dis. 1986;39(11):897-906. Exclude - methods paper. [pmid: 2947907].
Deyo RA, Diehr P, Patrick DL. Reproducibility and responsiveness of health status measures. Statistics and strategies for evaluation. Control Clin Trials. 1991;12(4 Suppl):142S-158S. Exclude - methods paper. [pmid: 1663851].
Dhaille F, Viseux V, Caudron A, et al. Cutaneous sarcoidosis occurring during anti-TNF-Alpha treatment: Report of two cases. Dermatology. 2010;220(3):234-237. Exclude Q1, 2, 4 - population not <18 Exclude; Q3 - population not < 18. [pmid: 20185892].
Diak P, Siegel J, La Grenade L, et al. Tumor necrosis factor (alpha) blockers and malignancy in children: Forty-eight cases reported to the food and drug administration. Arthritis Rheum. 2010;62(8):2517-2524. Exclude Q1, 2, 4 - no acceptable comparator; Q3 Exclude - not JIA/JRA/JCA. [pmid: 20506368].
Ding C, Jones G. Anti-interleukin-6 receptor antibody treatment in inflammatory autoimmune diseases. Rev Recent Clin Trials. 2006;1(3):193-200. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 18473972].
Doggrell SA. Is tocilizumab an option for the treatment of arthritis?. Expert Opin Pharmacother. 2008;9(11):2009-13. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude population not JIA/JRA. [pmid: 18627338].
Doherty E, Yanni G, Conroy RM, et al. A comparison of child and parent ratings of disability and pain in juvenile chronic arthritis. J Rheumatol. 1993;20(9):1563-1566. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 8164216].
Douglas Graham L, Myones BL, Rivas-Chacon RF, et al. Morbidity associated with long-term methotrexate therapy in juvenile rheumatoid arthritis. J Pediatr. 1992;120(3):468-473. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 1538301].
Duffy CM. Measurement of Health Status, Functional Status, and Quality of Life in Children with Juvenile Idiopathic Arthritis: Clinical Science for the Pediatrician. Rheumatic Disease Clinics of North America. 2007;33(3):389-402. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 17936171].
Duffy CM, Arsenault L, Duffy KN, et al. The Juvenile Arthritis Quality of Life Questionnaire--development of a new responsive index for juvenile rheumatoid arthritis and juvenile spondyloarthritides. J Rheumatol. 1997;24(4):738-46. Q5 - Exclude does not use TEP-indicated instrument. [pmid: 9101511].
Duffy CM, Arsenault L, Watanabe Duffy KN. Level of agreement between parents and children in rating dysfunction in juvenile rheumatoid arthritis and juvenile spondyloarthritides. J Rheumatol. 1993;20(12):2134-2139. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 8014944].
Dulgeroglu M. Sulfasalazine in juvenile rheumatoid arthritis. J Rheumatol. 1988;15(5):881. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 2902223].
Dupuis LL, Koren G, Shore A, et al. Methotrexate-nonsteroidal antiinflammatory drug interaction in children with arthritis. J Rheumatol. 1990;17(11):1469-73. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 2273487].
El-Hallak M, Binstadt BA, Leichtner AM, et al. Clinical Effects and Safety of Rituximab for Treatment of Refractory Pediatric Autoimmune Diseases. J Pediatr. 2007;150(4):376-382. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 17382113].
Elliott MJ, Woo P, Charles P, et al. Suppression of fever and the acute-phase response in a patient with juvenile chronic arthritis treated with monoclonal antibody to tumour necrosis factor-alpha (cA2). Br J Rheumatol. 1997;36(5):589-93. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 9189062].
Elwood RL, Pelszynski MM, Corman LI. Multifocal septic arthritis and osteomyelitis caused by group A Streptococcus in a patient receiving immunomodulating therapy with etanercept. Pediatr Infect Dis J. 2003;22(3):286-8. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 12664882].
Epstein WV, Criswell LA, Henke CJ. Methotrexate for juvenile rheumatoid arthritis. N Engl J Med. 1992;327(12):893. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 1508256].
Eraso R, Gedalia A, Espinoza LR. Methotrexate as a possible trigger of macrophage activation syndrome in systemic juvenile idiopathic arthritis. J Rheumatol. 2002;29(5):1104. author reply 1104-5. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 12022333].
Eraso R, Gedalia A, Espinoza LR, et al. Methotrexate as a possible trigger of macrophage activation syndrome in systemic juvenile idiopathic arthritis [1] (multiple letters). J Rheumatol. 2002;29(5):1104-1105. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 12022333].
Erturk E, Casemento JB, Guertin KR, et al. Bilateral acetylsulfapyridine nephrolithiasis associated with chronic sulfasalazine therapy. J Urol. 1994;151(6):1605-6. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 7910643].
Falcini F, Taccetti G, Ermini M, et al. Methotrexate-associated appearance and rapid progression of rheumatoid nodules in systemic-onset juvenile rheumatoid arthritis. Arthritis Rheum. 1997;40(1):175-8. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 9008613].
Falcone A, Cassone R, Rossi F, et al. Inter-observer agreement of the physician's global assessment of disease activity in children with juvenile idiopathic arthritis. Clin Exp Rheumatol. 2005;23(1):113-116. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 15789898].
Farmaki E, Kanakoudi-Tsakalidou F, Spoulou V, et al. The effect of anti-TNF treatment on the immunogenicity and safety of the 7-valent conjugate pneumococcal vaccine in children with juvenile idiopathic arthritis. Vaccine. 2010;28(31):5109-5113. Exclude Q1, 2, 4 - no acceptable comparator Exclude; Q3 - no AE data reported. [pmid: 20470802].
Fathalla BM, Goldsmith DP, Pascasio JM, et al. Development of autoimmune hepatitis in a child with systemic-onset juvenile idiopathic arthritis during therapy with etanercept. J Clin Rheumatol. 2008;14(5):297-8. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 18824922].
Feldman AB, Haley SM, Coryell J. Concurrent and construct validity of the Pediatric Evaluation of Disability Inventory. Phys Ther. 1990;70(10):602-10. Q3 - Exclude population not JIA/JRA/JCA. [pmid: 2217539].
Feldman BM, Grundland B, McCullough L, et al. Distinction of quality of life, health related quality of life, and health status in children referred for rheumatologic care. J Rheumatol. 2000;27(1):226-233. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 10648043].
Feldman BM, Silverman ED. Methotrexate therapy for juvenile rheumatoid arthritis. J Pediatr. 1991;118(6):992-3. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 2040940].
Fitch PG, Cron RQ. Septic abscess in a child with juvenile idiopathic arthritis receiving antitumor necrosis factor-alpha. J Rheumatol. 2006;33(4):825. author reply 826-7. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 16583487].
Flato B, Vinje O, Forre O. Toxicity of antirheumatic and anti-inflammatory drugs in children. Clin Rheumatol. 1998;17(6):505-10. Q1, 2, 4 - Exclude no acceptable DMARD intervention. [pmid: 9890680].
Fleischmann R, Iqbal I, Nandeshwar P, et al. Safety and efficacy of disease-modifying antirheumatic agents: focus on the benefits and risks of etanercept. Drug Saf. 2002;25(3):173-97. Q1, 2, 4 - Exclude study not prospective; Q3 - Exclude no AE data reported. [pmid: 11945114].
Foeldvari I, Burgos-Vargas R, Thon A, et al. High response rate in the phase I/II study of meloxicam in juvenile rheumatoid arthritis. J Rheumatol. 2002;29(5):1079-83. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 12022326].
Foeldvari I, Kruger E, Schneider T. Acute, non-obstructive, sterile cholecystitis associated with etanercept and infliximab for the treatment of juvenile polyarticular rheumatoid arthritis. Ann Rheum Dis. 2003;62(9):908-9. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude population not JIA/JRA. [pmid: 12922972].
Foeldvari I, Nielsen S, Kummerle-Deschner J, et al. Tumor necrosis factor-alpha blocker in treatment of juvenile idiopathic arthritis-associated uveitis refractory to second-line agents: results of a multinational survey. J Rheumatol. 2007;34(5):1146-50. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 17343318].
Foeldvari I, Szer IS, Zemel LS, et al. A prospective study comparing celecoxib with naproxen in children with juvenile rheumatoid arthritis. J Rheumatol. 2009;36(1):174-82. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 19012356].
Foeldvari I, Wierk A. Effectiveness of leflunomide in patients with juvenile idiopathic arthritis in clinical practice. J Rheumatol. 2010;37(8):1763-1767. Exclude Q1, 2, 4 - no acceptable comparator. [pmid: 20472925].
Foell D, Frosch M, Schulze zur Wiesch A, et al. Methotrexate treatment in juvenile idiopathic arthritis: when is the right time to stop?. Ann Rheum Dis. 2004;63(2):206-8. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 14722212].
Fonollosa A, Segura A, Giralt J, et al. Tuberculous uveitis after treatment with etanercept. Graefes Arch Clin Exp Ophthalmol. 2007;245(9):1397-9. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 17364199].
Frenck RW Jr, Seward JF. Varicella vaccine safety and immunogenicity in patients with juvenile rheumatic diseases receiving methotrexate and corticosteroids. Arthritis Care Res (Hoboken). 2010;62(7):903-6. Exclude Q1, 2, 4 - publication not peer-reviewed Exclude; Q3 - no AE data reported. [pmid: 20506363].
Furst DE. Toxicity of antirheumatic medications in children with juvenile arthritis. J Rheumatol Suppl. 1992;33:11-5. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 1593595].
Gallagher KT, Bernstein B. Juvenile rheumatoid arthritis. Curr Opin Rheumatol. 1999;11(5):372-6. Q1, 2, 4 - Exclude study not prospective; Q3 - Exclude no AE data reported. [pmid: 10503657].
Garcia-Carrasco M, Fuentes-Alexandro S, Escarcega RO, et al. Efficacy of thalidomide in systemic onset juvenile rheumatoid arthritis. Joint Bone Spine. 2007;74(5):500-3. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 17706449].
Garcia-Munitis P, Bandeira M, Pistorio A, et al. Level of agreement between children, parents, and physicians in rating pain intensity in juvenile idiopathic arthritis. Arthritis Care Res. 2006;55(2):177-183. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention.
Gattinara M, Lomater C, Gerloni V, et al. Cyclosporin in pediatric rheumatology; a seven years experience. Acta Univ Carol Med (Praha). 1994;40(1-4):105-8. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 9355683].
Gattorno M, Buoncompagni A, Faraci M, et al. Early treatment of systemic onset juvenile chronic arthritis with low-dose cyclosporin A. Clin Exp Rheumatol. 1995;13(3):409-10. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 7554576].
Gedalia A, Barash J, Press J, et al. Sulphasalazine in the treatment of pauciarticular-onset juvenile chronic arthritis. Clin Rheumatol. 1993;12(4):511-4. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 7907286].
Genel F, Arslanoglu S, Hizarcioglu M, et al. Steroid myopathy in a child with juvenile rheumatoid arthritis. Case report. Panminerva Med. 2003;45(1):75-7. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 12682624].
Genovese MC, Kremer JM. Treatment of rheumatoid arthritis with etanercept. Rheum Dis Clin North Am. 2004;30(2):311-28. vi. vii. Q1, 2, 4 - Exclude no outcomes of interest; Q3 - Exclude no AE data reported. [pmid: 15172043].
Gerloni V, Cimaz R, Gattinara M, et al. Efficacy and safety profile of cyclosporin A in the treatment of juvenile chronic (idiopathic) arthritis Results of a 10-year prospective study. Rheumatology (Oxford). 2001;40(8):907-13. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 11511760].
Gerloni V, Pontikaki I, Gattinara M, et al. Efficacy of repeated intravenous infusions of an antitumor necrosis factor alpha monoclonal antibody, infliximab, in persistently active, refractory juvenile idiopathic arthritis: results of an open-label prospective study. Arthritis Rheum. 2005;52(2):548-53. Q1, 2, 4 - Exclude no acceptable comparator Q3 - Exclude no AE data reported. [pmid: 15693004].
Gerloni V, Pontikaki I, Gattinara M, et al. Focus on adverse events of tumour necrosis factor alpha blockade in juvenile idiopathic arthritis in an open monocentric long-term prospective study of 163 patients. Ann Rheum Dis. 2008;67(8):1145-52. Q1, 2, 4 - Exclude population >18; Q3 - Exclude population >18. [pmid: 17981916].
Giannini EH, Cassidy JT, Brewer EJ, et al. Comparative efficacy and safety of advanced drug therapy in children with juvenile rheumatoid arthritis. Semin Arthritis Rheum. 1993;23(1):34-46. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude population no AE data reported. [pmid: 8235664].
Giannini EH, Ilowite NT, Lovell DJ, et al. Effects of long-term etanercept treatment on growth in children with selected categories of juvenile idiopathic arthritis. Arthritis Rheum. 2010;62(11):3259-64. Exclude Q1, 2, 4 - no acceptable comparator; Q3 - no AE data reported. [pmid: 20669280].
Giannini EH, Ilowite NT, Lovell DJ, et al. Long-term safety and effectiveness of etanercept in children with selected categories of juvenile idiopathic arthritis. Arthritis Rheum. 2009;60(9):2794-804. Q1, 2, 4 - Exclude no outcomes of interest. [pmid: 19714630].
Golmia A, Grinblat B, Finger E, et al. The development of erythema elevatum diutinum in a patient with juvenile idiopathic arthritis under treatment with abatacept. Clin Rheumatol. 2008;27(1):105-6. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 17932616].
Gong GWK, Young NL, Dempster H, et al. The quality of my life questionnaire: The minimal clinically important difference for pediatric rheumatology patients. J Rheumatol. 2007;34(3):581-587. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 17183614].
Gottlieb BS, Keenan GF, Lu T, et al. Discontinuation of methotrexate treatment in juvenile rheumatoid arthritis. Pediatrics. 1997;100(6):994-7. Q1, 2, 4 - Exclude study not prospective. [pmid: 9374571].
Graham LD, Myones BL, Rivas-Chacon RF, et al. Morbidity associated with long-term methotrexate therapy in juvenile rheumatoid arthritis. J Pediatr. 1992;120(3):468-73. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 1538301].
Greenberg JD, Kishimoto M, Strand V, et al. Tumor necrosis factor antagonist responsiveness in a United States rheumatoid arthritis cohort. Am J Med. 2008;121(6):532-8. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 18501236].
Guedira N, Hajjaj-Hassouni N, Srairi JE, et al. Third-degree atrioventricular block in a patient under chloroquine therapy. Rev Rhum Engl Ed. 1998;65(1):58-62. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 9523387].
Gunnarsson I, Kanerud L, Pettersson E, et al. Predisposing factors in sulphasalazine-induced systemic lupus erythematosus. Br J Rheumatol. 1997;36(10):1089-94. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 9374926].
Guyatt G, Walter S, Norman G. Measuring change over time: assessing the usefulness of evaluative instruments. J Chronic Dis. 1987;40(2):171-8. Exclude - methods paper. [pmid: 3818871].
Guzman J, Burgos-Vargas R, Duarte-Salazar C, et al. Reliability of the articular examination in children with juvenile rheumatoid arthritis: interobserver agreement and sources of disagreement. J Rheumatol. 1995;22(12):2331-6. Q5 - Exclude no clinical outcome measure. [pmid: 8835571].
Haagsma CJ, van Riel PL. Combination of second-line antirheumatic drugs. Ann Med. 1997;29(2):169-73. Q1, 2, 4 - Exclude no peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 9187235].
Haapasaari J, Kautiainen H, Hakala M. Combining cyclosporine with prevailing antirheumatic drug therapy in the treatment of juvenile idiopathic arthritis. Clin Exp Rheumatol. 2002;20(2):259. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 12051414].
Haapasaari J, Kautiainen H, Hannula S, et al. Good results from combining etanercept to prevailing DMARD therapy in refractory juvenile idiopathic arthritis. Clin Exp Rheumatol. 2002;20(6):867-70. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 12508784].
Halbig M, Horneff G. Improvement of functional ability in children with juvenile idiopathic arthritis by treatment with etanercept. Rheumatol Int. 2009;30(2):229-238. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 19449011].
Halle F, Prieur AM. Evaluation of methotrexate in the treatment of juvenile chronic arthritis according to the subtype. Clin Exp Rheumatol. 1991;9(3):297-302. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 1879091].
Haque MA, Bari MA, Saha GK, et al. Prospective, nonblind trial of methotrexate on seronegative spondyloarthropathy. Journal of Institute of Postgraduate Medicine and Research. 1999;14(2):56-63. Exclude Q1, 2, 4 - population not < 18 Exclude; Q3 - population not < 18.
Haraoui B, Keystone E. Musculoskeletal manifestations and autoimmune diseases related to new biologic agents. Curr Opin Rheumatol. 2006;18(1):96-100. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 16344625].
Hashkes PJ, Balistreri WF, Bove KE, et al. The long-term effect of methotrexate therapy on the liver in patients with juvenile rheumatoid arthritis. Arthritis Rheum. 1997;40(12):2226-34. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude population > 18. [pmid: 9416861].
Hashkes PJ, Balistreri WF, Bove KE, et al. The relationship of hepatotoxic risk factors and liver histology in methotrexate therapy for juvenile rheumatoid arthritis. J Pediatr. 1999;134(1):47-52. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 9880448].
Hashkes PJ, Shajrawi I. Sarcoid-related uveitis occurring during etanercept therapy. Clin Exp Rheumatol. 2003;21(5):645-6. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 14611117].
Hashkes PJ, Uziel Y, Laxer RM. The safety profile of biologic therapies for juvenile idiopathic arthritis. Nature Reviews Rheumatology. 2010;6(10):561-571. Exclude Q1, 2, 4 - publication not peer-reviewed Exclude; Q3 - no AE data reported.
Hendry G, Gardner-Medwin J, Watt GF, et al. A survey of foot problems in juvenile idiopathic arthritis. Musculoskeletal Care. 2008;6(4):221-32. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude not on TEP priority list. [pmid: 18618460].
Henrickson M, Reiff A. Prolonged efficacy of etanercept in refractory enthesitis-related arthritis. J Rheumatol. 2004;31(10):2055-61. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 15468375].
Hertzberger-ten Cate R, Cats A. Toxicity of sulfasalazine in systemic juvenile chronic arthritis. Clin Exp Rheumatol. 1991;9(1):85-8. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 1675939].
Higgins JPT, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. Exclude - methods paper. [pmid: 12111919].
Higgins JPT, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. Exclude - methods paper. [pmid: 12958120].
Hogeweg JA, Kuis W, Huygen AC, et al. The pain threshold in juvenile chronic arthritis. Br J Rheumatol. 1995;34(1):61-7. Q5 - Exclude not on TEP priority list. [pmid: 7881842].
Holl-Wieden A, Beer M, Marx A, et al. Infection of an urachal cyst during etanercept therapy in juvenile idiopathic arthritis. Rheumatol Int. 2008;28(8):819-22. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 18193232].
Hordon LD, Le Gallez P, Isdale AH. Oral methotrexate: hazard of different tablet strengths. Rheumatology (Oxford). 1999;38(12):1304. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 10587572].
Horneff G, De Bock F, Foeldvari I, et al. Safety and efficacy of combination of etanercept and methotrexate compared to treatment with etanercept only in patients with juvenile idiopathic arthritis (JIA): preliminary data from the German JIA Registry. Ann Rheum Dis. 2009;68(4):519-25. Q1, 2, 4 - Exclude study not prospective. [pmid: 18413440].
Horneff G, Ebert A, Fitter S, et al. Safety and efficacy of once weekly etanercept 08 mg/kg in a multicentre 12 week trial in active polyarticular course juvenile idiopathic arthritis. Rheumatology (Oxford). 2009;48(8):916-9. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 19483091].
Horneff G, Schmeling H, Biedermann T, et al. The German etanercept registry for treatment of juvenile idiopathic arthritis. Ann Rheum Dis. 2004;63(12):1638-44. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 15115709].
Howe S, Levinson J, Shear E, et al. Development of a disability measurement tool for juvenile rheumatoid arthritis. The Juvenile Arthritis Functional Assessment Report for Children and their Parents. Arthritis Rheum. 1991;34(7):873-80. Q5 - Exclude does not use TEP-indicated instrument. [pmid: 2059234].
Huang JL. Methotrexate in the treatment of children with chronic arthritis--long-term observations of efficacy and safety. Br J Clin Pract. 1996;50(6):311-4. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 8983319].
Huang JL, Chen LC. Sulphasalazine in the treatment of children with chronic arthritis. Clin Rheumatol. 1998;17(5):359-63. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 9805178].
Huang JL, Hung IJ, Chen LC, et al. Successfully treated sulphasalazine-induced fulminant hepatic failure, thrombocytopenia and erythroid hypoplasia with intravenous immunoglobulin. Clin Rheumatol. 1998;17(4):349-52. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 9776124].
Hung JJ, Huang JL. Etanercept therapy in children with juvenile rheumatoid arthritis. J Microbiol Immunol Infect. 2005;38(6):444-6. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 16341346].
Hunstad DA, French AR. Histoplasmosis in a child with JRA on low-dose methotrexate. Rheumatology (Oxford). 2007;46(1):177-8. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 17114804].
Hunstad DA, French AR. Re: Histoplasmosis in a child with JRA on low-dose methotrexate [11]. Rheumatology (Oxford). 2007;46(7):1216. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported.
Hunt PG, Rose CD, McIlvain-Simpson G, et al. The effects of daily intake of folic acid on the efficacy of methotrexate therapy in children with juvenile rheumatoid arthritis. A controlled study. J Rheumatol. 1997;24(11):2230-2. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 9375889].
Iglesias MJ, Cuttica RJ, Herrera Calvo M, et al. Design and validation of a new scale to assess the functional ability in children with juvenile idiopathic arthritis (JIA). Clin Exp Rheumatol. 2006;24(6):713-8. Q5 - Exclude not TEP priority measure. [pmid: 17207392].
Imundo L. Hodgkin's lymphoma associated with anti-TNF use in juvenile idiopathic arthritis: supplemental case report. J Rheumatol. 2008;35(8):1681. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 18671329].
Imundo LF, Jacobs JC. Sulfasalazine therapy for juvenile rheumatoid arthritis. J Rheumatol. 1996;23(2):360-6. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 8882047].
Ince DO, Ince A, Moore TL. Effect of methotrexate on the temporomandibular joint and facial morphology in juvenile rheumatoid arthritis patients. Am J Orthod Dentofacial Orthop. 2000;118(1):75-83. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 10893476].
Janse AJ, Sinnema G, Uiterwaal CSPM, et al. Quality of life in chronic illness: Children, parents and paediatricians have different, but stable perceptions. Acta Paediatrica, International Journal of Paediatrics. 2008;97(8):1118-1124. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA.
Jones OY, Lovell DJ. Comparison of treatment-response criteria for juvenile idiopathic arthritis: Commentary. Nature Clinical Practice Rheumatology. 2006;2(9):466-467. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported.
Joos R, Veys EM, Mielants H, et al. Sulfasalazine treatment in juvenile chronic arthritis: an open study. J Rheumatol. 1991;18(6):880-4. Q1,2,4 - Exclude no acceptable comparator. [pmid: 1680193].
Kaipiainen-Seppanen O, Leino M. Recurrent uveitis in a patient with juvenile spondyloarthropathy associated with tumour necrosis factor alpha inhibitors. Ann Rheum Dis. 2003;62(1):88-9. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude population > 18. [pmid: 12480683].
Kakati P, Sodhi KS, Sandhu MS, et al. Clinical and ultrasound assessment of the knee in children with juvenile rheumatoid arthritis. Indian J Pediatr. 2007;74(9):831-6. Q5 - Exclude no clinical outcome measure. [pmid: 17901669].
Kakkassery V, Mergler S, Pleyer U. Anti-TNF-alpha treatment: a possible promoter in endogenous uveitis? observational report on six patients: occurrence of uveitis following etanercept treatment. Curr Eye Res. 2010;35(8):751-6. Exclude Q1, 2, 4 - population not < 18 Exclude; Q3 - population not < 18. [pmid: 20673052].
Kasher-Meron M, Uziel Y, Amital H. Successful treatment with B-cell depleting therapy for refractory systemic onset juvenile idiopathic arthritis: a case report. Rheumatology (Oxford). 2009;48(4):445-6. Q1, 2, 4 - not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 19164423].
Katsicas MM, Russo RA. Use of adalimumab in patients with juvenile idiopathic arthritis refractory to etanercept and/or infliximab. Clin Rheumatol. 2009;28(8):985-8. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 19322622].
Kauppi M, Savolainen HA, Anttila VJ, et al. Leukaemia during podophyllotoxin treatment in a patient with juvenile chronic arthritis. Scand J Rheumatol. 1996;25(5):340. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no acceptable DMARD intervention. [pmid: 8921932].
Keim D, Ragsdale C, Heidelberger K, et al. Hepatic fibrosis with the use of methotrexate for juvenile rheumatoid arthritis. J Rheumatol. 1990;17(6):846-8. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 2388211].
Keim DR, Godoshian-Ragsdale C, Sullivan DB. Liver biopsy with the use of methotrexate for juvenile rheumatoid arthritis. J Pediatr. 1991;118(4 (Pt 1)):654. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 2007946].
Kenouch S, Fessi H, Mery JP, et al. Oral low-dose methotrexate (MTX) to be efficient in refractory rheumatoid arthritis and adult-onset Still's disease. Am J Kidney Dis. 1989;14(1):76-7. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude population > 18. [pmid: 2741938].
Khanna D, McMahon M, Furst DE. Anti-tumor necrosis factor alpha therapy and heart failure: what have we learned and where do we go from here?. Arthritis Rheum. 2004;50(4):1040-50. Q1, 3, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 15077286].
Khopkar U, Bhor U. Hodgkin's lymphoma in a patient of psoriasis treated with long-term, low-dose methotrexate therapy. Indian J Dermatol Venereol Leprol. 2008;74(4):379-82. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 18797063].
Kietz DA, Pepmueller PH, Moore TL. Clinical response to etanercept in polyarticular course juvenile rheumatoid arthritis. J Rheumatol. 2001;28(2):360-2. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 11246677].
Kietz DA, Pepmueller PH, Moore TL. Therapeutic use of etanercept in polyarticular course juvenile idiopathic arthritis over a two year period. Ann Rheum Dis. 2002;61(2):171-3. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 11796406].
Kilmartin DJ, Forrester JV, Dick AD. Cyclosporin A therapy in refractory non-infectious childhood uveitis. Br J Ophthalmol. 1998;82(7):737-42. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 9924362].
Kimura E, Oga S, Pereira RM. Comparative study of the pharmacokinetics of MTX in juvenile idiopathic arthritis patients receiving long-term MTX monotherapy or MTX plus chloroquine. J Clin Pharm Ther. 2007;32(6):579-84. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 18021335].
Kimura Y, Pinho P, Walco G, et al. Etanercept treatment in patients with refractory systemic onset juvenile rheumatoid arthritis. J Rheumatol. 2005;32(5):935-42. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 15868633].
Kleiman MB, Wheat LJ, Bowyer S. Histoplasmosis in a child with JRA on low-dose methotrexate. Rheumatology (Oxford). 2007;46(7):1215-6. author reply 1216. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 17545176].
Kocharla L, Taylor J, Weiler T, et al. Monitoring methotrexate toxicity in juvenile idiopathic arthritis. J Rheumatol. 2009;36(12):2813-2818. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 19918032].
Kone-Paut I, Retornaz K, Garnier JM, et al. Visceral leishmaniasis in a patient with systemic juvenile arthritis treated by IL-1RA agonist (Anakinra). Clin Exp Rheumatol. 2007;25(1):119. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 17418007].
Konttinen L, Kankaanpaa E, Luosujarvi R, et al. Effectiveness of anakinra in rheumatic disease in patients naive to biological drugs or previously on TNF blocking drugs: an observational study. Clin Rheumatol. 2006;25(6):882-4. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 16552464].
Kotaniemi K. Late onset uveitis in juvenile-type chronic polyarthritis controlled with prednisolone, cyclosporin A and methotrexate. Clin Exp Rheumatol. 1998;16(4):469-71. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 9706430].
Kristensen K, Nielsen S, Karup Pedersen F, et al. Erythrocyte-methotrexate and disease activity in children treated with oral methotrexate for juvenile chronic arthritis. Scand J Rheumatol. 2000;29(3):187-9. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 10898073].
Krugmann J, Sailer-Hock M, Muller T, et al. Epstein-Barr virus-associated Hodgkin's lymphoma and legionella pneumophila infection complicating treatment of juvenile rheumatoid arthritis with methotrexate and cyclosporine A. Hum Pathol. 2000;31(2):253-5. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 10685644].
Kuek A, Hazleman BL, Gaston JH, et al. Successful treatment of refractory polyarticular juvenile idiopathic arthritis with rituximab. Rheumatology (Oxford). 2006;45(11):1448-9. Q1, 2, 4 - Exclude - not peer-reviewed; Q3 - Exclude population > 18. [pmid: 16920752].
Kuemmerle-Deschner JB, Horneff G. Safety and efficacy of once-weekly application of Etanercept in children with juvenile idiopathic arthritis. Rheumatol Int. 2007;28(2):153-6. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 17641897].
Kummerle-Deschner J, Dannecker G. Sulphasalazine desensitization in a paediatric patient with juvenile chronic arthritis. Acta Paediatr. 1995;84(8):952-4. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 7488828].
Kunzmann S, Warmuth-Metz M, Girschick HJ. Cerebral demyelination in association with TNF-inhibition therapy in a 5-year-old girl with aseptic meningitis as the first symptom of Still's disease. Scand J Rheumatol. 2005;34(1):76-8. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 15903034].
Kvien TK, Heiberg T. Patient perspective in outcome assessments--perceptions or something more?. J Rheumatol. 2003;30(4):873-6. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 12672219].
Kvien TK, Hoyeraal HM, Sandstad B. Gold sodium thiomalate and D-penicillamine. A controlled, comparative study in patients with pauciarticular and polyarticular juvenile rheumatoid arthritis. Scand J Rheumatol. 1985;14(4):346-54. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 3936167].
Kvien TK, Larheim TA, Hoyeraal HM, et al. Radiographic temporomandibular joint abnormalities in patients with juvenile chronic arthritis during a controlled study of sodium aurothiomalate and D-penicillamine. Br J Rheumatol. 1986;25(1):59-66. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 3080044].
Lacki JK, Klama K, Michels H, et al. The effect of methotrexate and azathioprine on the serum levels of IgA-alpha 1-antitrypsin complex in juvenile chronic arthritis. Braz J Med Biol Res. 1997;30(6):763-7. Q1, 2, 4 - Exclude no outcomes of interest; Q3 - Exclude no AE data reported. [pmid: 9292114].
Lahdenne P, Rapola J, Ylijoki H, et al. Hepatotoxicity in patients with juvenile idiopathic arthritis receiving longterm methotrexate therapy. J Rheumatol. 2002;29(11):2442-5. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 12415606].
Lai JH. Taiwan experience with etanercept in juvenile rheumatoid arthritis. J Microbiol Immunol Infect. 2005;38(6):451-4. Q1, 2, 4 - Exclude study not prospective; Q3 - Exclude no AE data reported. [pmid: 16341348].
Lam C, Young N, Marwaha J, et al. Revised versions of the childhood health assessment questionnaire (CHAQ) are more sensitive and suffer less from a ceiling effect. Arthritis Care Res. 2004;51(6):881-889. Q5 Exclude - population not JIA.
Laurent S, Le Parc JM, Clerici T, et al. Onset of psoriasis following treatment with tocilizumab. Br J Dermatol. 2010;163(6):1364-1365. Exclude Q124 - population not < 18; Q3 - population not < 18. [pmid: 20731650].
Lee A, Kasama R, Evangelisto A, et al. Henoch-Schonlein purpura after etanercept therapy for psoriasis. J Clin Rheumatol. 2006;12(5):249-51. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 17023811].
Lee JH, Slifman NR, Gershon SK, et al. Life-threatening histoplasmosis complicating immunotherapy with tumor necrosis factor alpha antagonists infliximab and etanercept. Arthritis Rheum. 2002;46(10):2565-70. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 12384912].
Lee PPW, Lee TL, Wong WHS, et al. The use of methotrexate in juvenile idiopathic arthritis: A single center experience. Hong Kong Journal of Paediatrics. 2006;11(3):191-198+263. Q1, 2, 4 - Exclude no acceptable comparator.
Lehman TJ. Clinical trials for the treatment of systemic onset juvenile rheumatoid arthritis-juvenile idiopathic arthritis. Curr Rheumatol Rep. 2000;2(4):313-5. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 11123076].
Lehman TJ, Schechter SJ, Sundel RP, et al. Thalidomide for severe systemic onset juvenile rheumatoid arthritis: A multicenter study. J Pediatr. 2004;145(6):856-7. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 15580219].
Lehman TJ, Striegel KH, Onel KB. Thalidomide therapy for recalcitrant systemic onset juvenile rheumatoid arthritis. J Pediatr. 2002;140(1):125-7. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 11815776].
Lelieveld OTHM, Takken T, Van Der Net J, et al. Validity of the 6-minute walking test in juvenile idiopathic arthritis. Arthritis Care Res. 2005;53(2):304-307. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention.
Len C, Ferraz MB, Goldenberg J, et al. Pediatric Escola Paulista de Medicina Range of Motion Scale: a reduced joint count scale for general use in juvenile rheumatoid arthritis. J Rheumatol. 1999;26(4):909-13. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude not on TEP priority list. [pmid: 10229415].
Len CA, Ferraz MB, Goldenberg J, et al. Pediatric Escola Paulista de Medicina Range of Motion scale: A reduced joint count scale for general use in juvenile rheumatoid arthritis. J Rheumatol. 1999;26(4):909-913. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no AE data reported. [pmid: 10229415].
Lepore L, Marchetti F, Facchini S, et al. Drug-induced systemic lupus erythematosus associated with etanercept therapy in a child with juvenile idiopathic arthritis. Clin Exp Rheumatol. 2003;21(2):276-7. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 12747299].
Lequerre T, Quartier P, Rosellini D, et al. Interleukin-1 receptor antagonist (anakinra) treatment in patients with systemic-onset juvenile idiopathic arthritis or adult onset Still disease: preliminary experience in France. Ann Rheum Dis. 2008;67(3):302-8. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 17947302].
Levalampi T, Honkanen V, Lahdenne P, et al. Effects of infliximab on cytokines, myeloperoxidase, and soluble adhesion molecules in patients with juvenile idiopathic arthritis. Scand J Rheumatol. 2007;36(3):189-93. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 17657672].
Liang MH, Fossel AH, Larson MG. Comparisons of five health status instruments for orthopedic evaluation. Med Care. 1990;28(7):632-42. Exclude - methods paper. [pmid: 2366602].
Liang TC, Yang YH, Lin YT, et al. Treatment with etanercept for patients with juvenile rheumatoid arthritis in Taiwan--a preliminary report. J Microbiol Immunol Infect. 2005;38(6):447-50. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 16341347].
Lin YT, Tsai MJ, Wang LH, et al. Efficacy and safety of methotrexate therapy for juvenile rheumatoid arthritis. J Formos Med Assoc. 2000;99(8):623-9. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 10969505].
Lin YT, Yang YH, Tsai MJ, et al. Long-term effects of azathioprine therapy for juvenile rheumatoid arthritis. J Formos Med Assoc. 2000;99(4):330-5. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 10870318].
Livermore PA, Murray KJ. Anti-tumour necrosis factor therapy associated with cutaneous vasculitis. Rheumatology (Oxford). 2002;41(12):1450-2. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 12468829].
Lomater G, Gattinara M, Gerloni V, et al. Combination therapy of juvenile rheumatoid arthritis with hydroxychloroquine-gold-methotrexate: a pilot study. Acta Univ Carol Med (Praha). 1994;40(1-4):109-12. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 9355684].
Londino AV Jr, Blatt J, Knisely AS. Hodgkin's disease in a patient with juvenile rheumatoid arthritis taking weekly low dose methotrexate. J Rheumatol. 1998;25(6):1245-6. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 9632099].
Lovell DJ. Newer functional outcome measurements in juvenile rheumatoid arthritis: a progress report. J Rheumatol Suppl. 1992;33:28-31. Q5 - Exclude no test performance data reported. [pmid: 1593598].
Lovell DJ, Howe S, Shear E, et al. Development of a disability measurement tool for juvenile rheumatoid arthritis. The Juvenile Arthritis Functional Assessment Scale. Arthritis Rheum. 1989;32(11):1390-5. Q5 - Exclude not TEP priority measure. [pmid: 2818655].
Lovell DJ, Reiff A, Ilowite NT, et al. Safety and efficacy of up to eight years of continuous etanercept therapy in patients with juvenile rheumatoid arthritis. Arthritis Rheum. 2008;58(5):1496-504. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 18438876].
Lovell DJ, Reiff A, Jones OY, et al. Long-term safety and efficacy of etanercept in children with polyarticular-course juvenile rheumatoid arthritis. Arthritis Rheum. 2006;54(6):1987-94. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 16732547].
Lurati A, Salmaso A, Gerloni V, et al. Accuracy of Wallace criteria for clinical remission in juvenile idiopathic arthritis: A cohort study of 761 consecutive cases. J Rheumatol. 2009;36(7):1532-1535. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 19487265].
Magni-Manzoni S, Epis O, Ravelli A, et al. Comparison of clinical versus ultrasound-determined synovitis in juvenile idiopathic arthritis. Arthritis Rheum. 2009;61(11):1497-504. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 19877100].
Magni-Manzoni S, Ruperto N, Pistorio A, et al. Development and validation of a preliminary definition of minimal disease activity in patients with juvenile idiopathic arthritis. Arthritis Rheum. 2008;59(8):1120-7. Q5 - Exclude not on TEP priority list. [pmid: 18668599].
Manadan AM, Block JA, Sequeira W. Mycobacteria tuberculosis peritonitis associated with etanercept therapy. Clin Exp Rheumatol. 2003;21(4):526. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude population > 18. [pmid: 12942713].
Mangge H, Gindl S, Kenzian H, et al. Atopic dermatitis as a side effect of anti-tumor necrosis factor-alpha therapy. J Rheumatol. 2003;30(11):2506-7. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 14677200].
Mangge H, Heinzl B, Grubbauer HM, et al. Therapeutic experience with infliximab in a patient with polyarticular juvenile idiopathic arthritis and uveitis. Rheumatol Int. 2003;23(5):258-61. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 12687288].
Martini A. Etanercept improves active polyarticular juvenile rheumatoid arthritis. Clin Exp Rheumatol. 2001;19(2):122-4. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 11326472].
Martini A, Ravelli A, Viola S, et al. Methotrexate hepatotoxic effects in children with juvenile rheumatoid arthritis. J Pediatr. 1991;119(2):333-4. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 1861227].
Masi L, Ricci L, Zulian F, et al. Serum osteopontin as a predictive marker of responsiveness to methotrexate in juvenile idiopathic arthritis. J Rheumatol. 2009;36(10):2308-13. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 19684155].
Mateicka F, Lukac J, Rovensky J, et al. Cyclosporin A in treatment of juvenile chronic arthritis: Preliminary results with Consupren(registered trademark). International Journal of Immunotherapy. 1994;10(1):11-14. Exclude Q1, 2, 4 - no acceptable comparator.
McCroskery P, Wallace CA, Lovell DJ, et al. Summary of worldwide pediatric malignancies reported after exposure to etanercept. Pediatric Rheumatology. 2010;8. Exclude Q1, 2, 4 - no acceptable comparator; Q3 - Exclude not JIA/JRA/JCA.
McDermott MF. Rilonacept in the treatment of chronic inflammatory disorders. Drugs Today (Barc). 2009;45(6):423-30. Q1, 2, 4 - Exclude study not prospective; Q3 - Exclude no AE data reported. [pmid: 19649332].
Meiorin S, Filocamo G, Pistorio A, et al. Impact of involvement of individual joint groups on subdimensions of functional ability scales in juvenile idiopathic arthritis. Clin Exp Rheumatol. 2009;27(3):527-33. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude not on TEP priority list. [pmid: 19604450].
Mene P, Franeta AJ, Conti G, et al. Extracapillary glomerulonephritis during etanercept treatment for juvenile psoriatic arthritis. Clin Exp Rheumatol. 2010;28(1):91-93. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 20346246].
Miller E, Uleryk E, Doria AS. Evidence-based outcomes of studies addressing diagnostic accuracy of MRI of juvenile idiopathic arthritis. AJR Am J Roentgenol. 2009;192(5):1209-18. Q5 - Exclude no clinical outcome measure. [pmid: 19380543].
Miller JJ 3rd, Williams GF, Leissring JC. Multiple late complications of therapy with cyclophosphamide, including ovarian destruction. Am J Med. 1971;50(4):530-5. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 5313910].
Miyamae T, Nemoto A, Imagawa T, et al. Cross-cultural adaptation and validation of the Japanese version of the Childhood Health Assessment Questionnaire (CHAQ). Modern Rheumatology. 2008;18(4):336-343. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - does not include all cultural adaptations. [pmid: 18414785].
Mor A, Bingham C 3rd, Barisoni L, et al. Proliferative lupus nephritis and leukocytoclastic vasculitis during treatment with etanercept. J Rheumatol. 2005;32(4):740-3. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 15801034].
Mori M, Takei S, Imagawa T, et al. Pharmacokinetics, efficacy, and safety of short-term (12 weeks) etanercept for methotrexate-refractory polyarticular juvenile idiopathic arthritis in Japan. Modern Rheumatology. 2005;15(6):397-404. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 17029102].
Morishita K, Petty R, Cairns R, et al. Serious musculoskeletal infections in children receiving anti-tumor necrosis factor-alpha therapy: a case series. Clin Rheumatol. 2010;29(6):677-81. Exclude Q1, 2, 4 - no acceptable comparator. [pmid: 20383549].
Moroldo MB, Giannini EH. Estimates of the discriminant ability of definitions of improvement for juvenile rheumatoid arthritis. J Rheumatol. 1998;25(5):986-9. Q5 - Exclude not on TEP priority list. [pmid: 9598903].
Murphy EA, Morris AJ, Walker E, et al. Cyclosporine A induced colitis and acquired selective IgA deficiency in a patient with juvenile chronic arthritis. J Rheumatol. 1993;20(8):1397-8. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 8230025].
Muzaffer MA, Schneider R, Cameron BJ, et al. Accelerated nodulosis during methotrexate therapy for juvenile rheumatoid arthritis. J Pediatr. 1996;128(5 Pt 1):698-700. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 8627446].
Myers A, Clark J, Foster H. Tuberculosis and treatment with infliximab. N Engl J Med. 2002;346(8):623-6. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 11859881].
Narayanan K, Anand KP. Long-term follow up of infliximab therapy in inflammatory arthritis. Indian Journal of Rheumatology. 2007;2(1):8-10. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA.
Narvaez J, Diaz-Torne C, Juanola X, et al. Rituximab therapy for refractory systemic-onset juvenile idiopathic arthritis. Ann Rheum Dis. 2009;68(4):607-8. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude population > 18. [pmid: 19286909].
Nielsen S, Ruperto N, Gerloni V, et al. Preliminary evidence that etanercept may reduce radiographic progression in juvenile idiopathic arthritis. Clin Exp Rheumatol. 2008;26(4):688-92. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 18799107].
Norambuena RX, Mallol J, Rios MG, et al. Therapeutic effects of the anti-tumor necrosis factor monoclonal antibody, infliximab, in four children with refractory juvenile idiopathic arthritis. Allergol Immunopathol (Madr). 2007;35(2):52-6. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 17428400].
Oen K, Duffy CM, Tse SM, et al. Early outcomes and improvement of patients with juvenile idiopathic arthritis enrolled in a Canadian multicenter inception cohort. Arthritis Care Res (Hoboken). 2010;62(4):527-36. Exclude Q1, 2, 4 - no acceptable comparator Exclude; Q3 - no AE data reported. [pmid: 20391508].
Oen K, Reed M, Malleson PN, et al. Radiologic outcome and its relationship to functional disability in juvenile rheumatoid arthritis. J Rheumatol. 2003;30(4):832-40. Q5 - Exclude not on TEP priority list. [pmid: 12672208].
Ohlsson V, Baildam E, Foster H, et al. Anakinra treatment for systemic onset juvenile idiopathic arthritis (SOJIA). Rheumatology (Oxford). 2008;47(4):555-6. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 18321945].
Oppermann J, Mobius D. Therapeutical and immunological effects of methylprednisolone pulse therapy in comparison with intravenous immunoglobulin. Treatment in patients with juvenile chronic arthritis. Acta Univ Carol Med (Praha). 1994;40(1-4):117-21. Q3 - Exclude no AE data reported. [pmid: 9355686].
Ortiz-Alvarez O, Morishita K, Avery G, et al. Guidelines for blood test monitoring of methotrexate toxicity in juvenile idiopathic arthritis. J Rheumatol. 2004;31(12):2501-6. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 15570658].
Ostensen M, Hoyeraal HM, Kass E. Tolerance of cyclosporine A in children with refractory juvenile rheumatoid arthritis. J Rheumatol. 1988;15(10):1536-8. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 3204600].
Ozdogan H, Turunc M, Deringol B, et al. Sulphasalazine in the treatment of juvenile rheumatoid arthritis: a preliminary open trial. J Rheumatol. 1986;13(1):124-5. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 2871188].
Padeh S, Sharon N, Schiby G, et al. Hodgkin's lymphoma in systemic onset juvenile rheumatoid arthritis after treatment with low dose methotrexate. J Rheumatol. 1997;24(10):2035-7. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 9330950].
Palermo TM, Long AC, Lewandowski AS, et al. Evidence-based assessment of health-related quality of life and functional impairment in pediatric psychology. J Pediatr Psychol. 2008;33(9):983-996. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 18430762].
Palermo TM, Witherspoon D, Valenzuela D, et al. Development and validation of the Child Activity Limitations Interview: a measure of pain-related functional impairment in school-age children and adolescents. Pain. 2004;109(3):461-70. Q5 - Exclude population not JIA/JRA/JCA. [pmid: 15157707].
Palermo TM, Zebracki K, Cox S, et al. Juvenile idiopathic arthritis: Parent-child discrepancy on reports of pain and disability. J Rheumatol. 2004;31(9):1840-1846. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude no measure of interest. [pmid: 15338510].
Palmisani E, Solari N, Pistorio A, et al. Agreement between physicians and parents in rating functional ability of children with juvenile idiopathic arthritis. Pediatr Rheumatol Online J. 2007;5:23. Q5 - Exclude instrument not on priority list. [pmid: 18072960].
Pay S, Dinc A, Simsek I, et al. Sulfasalazine-induced angioimmunoblastic lymphadenopathy developing in a patient with juvenile chronic arthritis. Rheumatol Int. 2000;20(1):25-7. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 11149657].
Peek R, Scott-Jupp R, Strike H, et al. Psoriasis after treatment of juvenile idiopathic arthritis with etanercept. Ann Rheum Dis. 2006;65(9):1259. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 16905590].
Pendleton TB, Coleman MR, Grossman BJ. Numerical scale for evaluation of the patient with inflammatory joint disease. Phys Ther. 1973;53(4):373-80. Q5 - Exclude no test performance data reported. [pmid: 4693289].
Phillips K, Husni ME, Karlson EW, et al. Experience with etanercept in an academic medical center: Are infection rates increased?. Arthritis Care Res. 2002;47(1):17-21. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude > 18.
Pileggi GS, de Souza CB, Ferriani VP. Safety and immunogenicity of varicella vaccine in patients with juvenile rheumatic diseases receiving methotrexate and corticosteroids. Arthritis Care Res (Hoboken). 2010;62(7):1034-9. Exclude Q1, 2, 4 - no acceptable comparator Exclude; Q3 - no AE data reported. [pmid: 20235203].
Pinana E, Lei SH, Merino R, et al. DRESS-syndrome on sulfasalazine and naproxen treatment for juvenile idiopathic arthritis and reactivation of human herpevirus 6 in an 11-year-old caucasian boy. J Clin Pharm Ther. 2010;35(3):365-370. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 20831538].
Pipitone MA, Adams B, Sheth A, et al. Crusted scabies in a patient being treated with infliximab for juvenile rheumatoid arthritis. J Am Acad Dermatol. 2005;52(4):719-20. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 15793541].
Pistoia V, Buoncompagni A, Scribanis R, et al. Cyclosporin A in the treatment of juvenile chronic arthritis and childhood polymyositis-dermatomyositis. Results of a preliminary study. Clin Exp Rheumatol. 1993;11(2):203-8. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 8508564].
Pohjankoski H, Kautiainen H, Kotaniemi K, et al. Autoimmune diseases in children with juvenile idiopathic arthritis. Scand J Rheumatol. 2010;39(5):435-436. Exclude Q124 - no acceptable comaprator; Q3 - no AE data reported. [pmid: 20476854].
Press J, Neumann L, Uziel Y, et al. Assessment of quality of life of parents of children with juvenile chronic arthritis. Clin Rheumatol. 2002;21(4):280-283. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 12189453].
Prieur AM, Adleff A, Debre M, et al. High dose immunoglobulin therapy in severe juvenile chronic arthritis: Long-term follow-up in 16 patients. Clin Exp Rheumatol. 1990;8(6):603-609. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 2289332].
Prince FH, Twilt M, Jansen-Wijngaarden NC, et al. Effectiveness of a once weekly double dose of etanercept in patients with juvenile idiopathic arthritis: a clinical study. Ann Rheum Dis. 2007;66(5):704-5. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 17324973].
Prince FH, Twilt M, ten Cate R, et al. Long-term follow-up on effectiveness and safety of etanercept in juvenile idiopathic arthritis: the Dutch national register. Ann Rheum Dis. 2009;68(5):635-41. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 18413443].
Prince FH, van Suijlekom-Smit LW. Initiating etanercept in a once weekly dose in children with juvenile idiopathic arthritis. Rheumatol Int. 2008;28(4):397-8. author reply 399. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 17940772].
Prince FHM, Geerdink LM, Borsboom GJJM, et al. Major improvements in health-related quality of life during the use of etanercept in patients with previously refractory juvenile idiopathic arthritis. Ann Rheum Dis. 2010;69(1):138-42. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported Q5 - Exclude not on TEP priority list. [pmid: 19581280].
Quartier P, Taupin P, Bourdeaut F, et al. Efficacy of etanercept for the treatment of juvenile idiopathic arthritis according to the onset type. Arthritis Rheum. 2003;48(4):1093-101. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 12687553].
Quinn MA, Green MJ, Gaugh AKS, et al. Low dose methotrexate osteopathy in a patient with polyarticular juvenile idiopathic arthritis [3] (multiple letters). Ann Rheum Dis. 2003;62(11):1123-1124. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude population < 18 years old. [pmid: 14583584].
Quinn MA, Green MJ, Gough AK. Low dose methotrexate osteopathy in a patient with polyarticular juvenile idiopathic arthritis. Ann Rheum Dis. 2003;62(11):1123-4. author reply 1124. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude population > 18. [pmid: 14583584].
Ramanan AV, Schneider R. Macrophage activation syndrome following initiation of etanercept in a child with systemic onset juvenile rheumatoid arthritis. J Rheumatol. 2003;30(2):401-3. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 12563702].
Ramos-Casals M, Brito-Zeron P, Munoz S, et al. Autoimmune diseases induced by TNF-targeted therapies: analysis of 233 cases. Medicine (Baltimore). 2007;86(4):242-51. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 Exclude no AE data reported. [pmid: 17632266].
Rapoff MA, Lindsley CB, Purviance MR. The validity and reliability of parental ratings of disease activity in juvenile rheumatoid arthritis. Arthritis Care Res. 1991;4(3):136-9. Q5 - Exclude does not use TEP-indicated instrument. [pmid: 11188599].
Ravelli A. The time has come to include assessment of radiographic progression in juvenile idiopathic arthritis clinical trials. J Rheumatol. 2008;35(4):553-7. Q5 - Exclude not peer-reviewed. [pmid: 18398949].
Ravelli A, Caria MC, Buratti S, et al. Methotrexate as a possible trigger of macrophage activation syndrome in systemic juvenile idiopathic arthritis. J Rheumatol. 2001;28(4):865-7. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 11327264].
Ravelli A, De Benedetti F, Viola S, et al. Macrophage activation syndrome in systemic juvenile rheumatoid arthritis successfully treated with cyclosporine. J Pediatr. 1996;128(2):275-8. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 8636829].
Ravelli A, Gerloni V, Corona F, et al. Oral versus intramuscular methotrexate in juvenile chronic arthritis. Italian Pediatric Rheumatology Study Group. Clin Exp Rheumatol. 1998;16(2):181-3. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 9536397].
Ravelli A, Ioseliani M, Norambuena X, et al. Adapted versions of the Sharp/van der Heijde score are reliable and valid for assessment of radiographic progression in juvenile idiopathic arthritis. Arthritis Rheum. 2007;56(9):3087-95. Q5 - Exclude not TEP priority measure. [pmid: 17763418].
Ravelli A, Migliavacca D, Viola S, et al. Efficacy of folinic acid in reducing methotrexate toxicity in juvenile idiopathic arthritis. Clin Exp Rheumatol. 1999;17(5):625-7. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 10544851].
Ravelli A, Moretti C, Temporini F, et al. Combination therapy with methotrexate and cyclosporine A in juvenile idiopathic arthritis. Clin Exp Rheumatol. 2002;20(4):569-72. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 12175118].
Ravelli A, Viola S, Migliavacca D, et al. Discordance between proxy-reported and observed assessment of functional ability of children with juvenile idiopathic arthritis. Rheumatology (Oxford). 2001;40(8):914-919. Q1, 2, 4 - Exclude noa cceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude unclear if differences in CHAQ are related to true perceived differences in function or different definitions of “some” and “much” difficulty. [pmid: 11511761].
Ravelli A, Viola S, Migliavacca D, et al. The extended oligoarticular subtype is the best predictor of methotrexate efficacy in juvenile idiopathic arthritis. J Pediatr. 1999;135(3):316-20. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 10484796].
Ravelli A, Viola S, Ramenghi B, et al. Frequency of relapse after discontinuation of methotrexate therapy for clinical remission in juvenile rheumatoid arthritis. J Rheumatol. 1995;22(8):1574-6. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 7473486].
Reiff A. The use of anakinra in juvenile arthritis. Curr Rheumatol Rep. 2005;7(6):434-40. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no original AE data reported. [pmid: 16303102].
Reiff A, Lovell DJ, Adelsberg JV, et al. Evaluation of the comparative efficacy and tolerability of rofecoxib and naproxen in children and adolescents with juvenile rheumatoid arthritis: a 12-week randomized controlled clinical trial with a 52-week open-label extension. J Rheumatol. 2006;33(5):985-95. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no AE data reported. [pmid: 16583464].
Reiff A, Rawlings DJ, Shaham B, et al. Preliminary evidence for cyclosporin A as an alternative in the treatment of recalcitrant juvenile rheumatoid arthritis and juvenile dermatomyositis. J Rheumatol. 1997;24(12):2436-43. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 9415655].
Reiff A, Shaham B, Wood BP, et al. High dose methotrexate in the treatment of refractory juvenile rheumatoid arthritis. Clin Exp Rheumatol. 1995;13(1):113-8. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 7774090].
Reiff A, Takei S, Sadeghi S, et al. Etanercept therapy in children with treatment-resistant uveitis. Arthritis Rheum. 2001;44(6):1411-5. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 11407702].
Remesal A, De Inocencio J, Merino R, et al. Discontinuation of etanercept after successful treatment in patients with juvenile idiopathic arthritis. J Rheumatol. 2010;37(9):1970-1971. Exclude Q1, 2, 4 - publication not peer-reviewed Exclude; Q3 - no AE data reported. [pmid: 20810527].
Ringold S, Bittner R, Neogi T, et al. Performance of rheumatoid arthritis disease activity measures and juvenile arthritis disease activity scores in polyarticular-course juvenile idiopathic arthritis: Analysis of their ability to classify the american college of rheumatology pediatric measures of response and the preliminary criteria for flare and inactive disease. Arthritis Care Res. 2010;62(8):1095-1102. Exclude - no clinical outcomes measure.
Ringold S, Chon Y, Singer NG. Associations between the American College of Rheumatology pediatric response measures and the continuous measures of disease activity used in adult rheumatoid arthritis: a secondary analysis of clinical trial data from children with polyarticular-course juvenile idiopathic arthritis. Arthritis Rheum. 2009;60(12):3776-83. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude not on TEP priority list. [pmid: 19950286].
Ringold S, Wallace CA. Measuring clinical response and remission in juvenile idiopathic arthritis. Curr Opin Rheumatol. 2007;19(5):471-6. Exclude - methods paper. [pmid: 17762613].
Ringold S, Wallace CA, Rivara FP. Health-related quality of life, physical function, fatigue, and disease activity in children with established polyarticular juvenile idiopathic arthritis. J Rheumatol. 2009;36(6):1330-6. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude not on TEP priority list. [pmid: 19411394].
Robinson RF, Nahata MC, Hayes JR, et al. Quality-of-life measurements in juvenile rheumatoid arthritis patients treated with etanercept. Clinical Drug Investigation. 2003;23(8):511-518. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 17535063].
Rose CD, Singsen BH, Eichenfield AH, et al. Safety and efficacy of methotrexate therapy for juvenile rheumatoid arthritis. J Pediatr. 1990;117(4):653-9. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 2213397].
Ross CK, Lavigne JV, Hayford JR, et al. Validity of reported pain as a measure of clinical state in juvenile rheumatoid arthritis. Ann Rheum Dis. 1989;48(10):817-819. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention. [pmid: 2818018].
Rossi F, Di Dia F, Galipo O, et al. Use of the Sharp and Larsen scoring methods in the assessment of radiographic progression in juvenile idiopathic arthritis. Arthritis Rheum. 2006;55(5):717-23. Q5 - Exclude instrument not on TEP priority list. [pmid: 17013855].
Roux CH, Brocq O, Breuil V, et al. Pregnancy in rheumatology patients exposed to anti-tumour necrosis factor (TNF)-alpha therapy. Rheumatology (Oxford). 2007;46(4):695-8. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population > 18. [pmid: 17158212].
Rudler M, Pouchot J, Paycha F, et al. Low dose methotrexate osteopathy in a patient with polyarticular juvenile idiopathic arthritis. Ann Rheum Dis. 2003;62(6):588-9. Q1, 2, 4 - Exclude population notJIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 12759303].
Ruemmele FM, Prieur AM, Talbotec C, et al. Development of Crohn disease during anti-TNF-alpha therapy in a child with juvenile idiopathic arthritis. J Pediatr Gastroenterol Nutr. 2004;39(2):203-6. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 15269630].
Ruperto N, Giannini EH. Redundancy of conventional articular response variables used in juvenile chronic arthritis clinical trials. Ann Rheum Dis. 1996;55(1):73-5. Q5 - Exclude no test performance data reported. [pmid: 8572741].
Ruperto N, Lovell DJ, Cuttica R, et al. Long-term efficacy and safety of infliximab plus methotrexate for the treatment of polyarticular-course juvenile rheumatoid arthritis: Findings from an open-label treatment extension. Ann Rheum Dis. 2010;69(4):718-722. Q1, 2, 4 - Exclude (open label extension of Ruperto 2007). [pmid: 20237125].
Ruperto N, Murray KJ, Gerloni V, et al. A randomized trial of parenteral methotrexate comparing an intermediate dose with a higher dose in children with juvenile idiopathic arthritis who failed to respond to standard doses of methotrexate. Arthritis Rheum. 2004;50(7):2191-201. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 15248217].
Ruperto N, Ravelli A, Castell E, et al. Cyclosporine A in juvenile idiopathic arthritis. Results of the PRCSG/PRINTO phase IV post marketing surveillance study. Clin Exp Rheumatol. 2006;24(5):599-605. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 17181934].
Ruperto N, Ravelli A, Falcini F, et al. Responsiveness of outcome measures in juvenile chronic arthritis. Italian Pediatric Rheumatology Study Group. Rheumatology (Oxford). 1999;38(2):176-80. Q5 - Exclude no test performance data reported. [pmid: 10342633].
Ruperto N, Ravelli A, Pistorio A, et al. The provisional Paediatric Rheumatology International Trials Organisation/American College of Rheumatology/European League Against Rheumatism Disease activity core set for the evaluation of response to therapy in juvenile dermatomyositis: a prospective validation study. Arthritis Rheum. 2008;59(1):4-13. Q5 - Exclude population not JIA/JRA/JCA. [pmid: 18163404].
Russo RA, Katsicas MM. Tolerance of parenteral, higher dose methotrexate in children with juvenile chronic arthritis. Clin Exp Rheumatol. 2000;18(3):425. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 10895392].
Russo RA, Katsicas MM. Clinical remission in patients with systemic juvenile idiopathic arthritis treated with anti-tumor necrosis factor agents. J Rheumatol. 2009;36(5):1078-82. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 19435972].
Russo RA, Katsicas MM, Zelazko M. Etanercept in systemic juvenile idiopathic arthritis. Clin Exp Rheumatol. 2002;20(5):723-6. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 12412209].
Rybar I, Rozborilova E, Zanova E, et al. The effectiveness for prevention of tuberculosis in patients with inflammatory rheumatic diseases treated with TNF inhibitors. Bratisl Lek Listy. 2008;109(4):164-7. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 18814432].
Saba NS, Kosseifi SG, Charaf EA, et al. Adalimumab-induced acute myelogenic leukemia. South Med J. 2008;101(12):1261-2. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 19005432].
Sahn EE, Maize JC, Garen PD, et al. D-penicillamine-induced elastosis perforans serpiginosa in a child with juvenile rheumatoid arthritis. Report of a case and review of the literature. J Am Acad Dermatol. 1989;20(5 Pt 2):979-88. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 2523911].
Saint Marcoux B, De Bandt M. Vasculitides induced by TNFalpha antagonists: a study in 39 patients in France. Joint Bone Spine. 2006;73(6):710-3. Q1, 2 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 17127088].
Saougou I, Papagoras C, Markatseli TE, et al. A case report of a psoriatic arthritis patient on hemodialysis treated with tumor necrosis factor blocking agent and a literature review. Clin Rheumatol. 2010;29(12):1455-1459. Exclude Q124 - population not < 18; Q3 - population not < 18. [pmid: 20490588].
Sari I, Binicier O, Birlik M, et al. Thymic enlargement in a patient with juvenile idiopathic arthritis during etanercept therapy. Rheumatol Int. 2009;29(5):591-3. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 18810448].
Saurenmann RK, Levin AV, Feldman BM, et al. Risk of new-onset uveitis in patients with juvenile idiopathic arthritis treated with anti-TNFalpha agents. J Pediatr. 2006;149(6):833-6. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 17137902].
Savolainen HA, Kautiainen H, Isomaki H, et al. Azathioprine in patients with juvenile chronic arthritis: a longterm followup study. J Rheumatol. 1997;24(12):2444-50. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 9415656].
Savolainen HA, Leirisalo-Repo M. Eosinophilia as a side-effect of methotrexate in patients with chronic arthritis. Clin Rheumatol. 2001;20(6):432-4. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 11771529].
Sawar H, Espinoza LR, Gedalia A. Macrophage activation syndrome and etanercept in children with systemic juvenile rheumatoid arthritis. J Rheumatol. 2004;31(3):623. author reply 623-4. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 14994420].
Schmeling H, Biber D, Heins S, et al. Influence of methylenetetrahydrofolate reductase polymorphisms on efficacy and toxicity of methotrexate in patients with juvenile idiopathic arthritis. J Rheumatol. 2005;32(9):1832-6. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 16142884].
Schmeling H, Mathony K, John V, et al. A combination of etanercept and methotrexate for the treatment of refractory juvenile idiopathic arthritis: a pilot study. Ann Rheum Dis. 2001;60(4):410-2. Q1, 2, 4 - Exclude no acceptable no comparator; Q3 - Exclude no AE data reported. [pmid: 11247875].
Schmeling H, Stephan V, Burdach S, et al. Pulmonary function in children with juvenile idiopathic arthritis and effects of methotrexate therapy. Z Rheumatol. 2002;61(2):168-72. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 12056294].
Seid M, Opipari L, Huang B, et al. Disease control and health-related quality of life in juvenile idiopathic arthritis. Arthritis Rheum. 2009;61(3):393-9. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude not on TEP priority list. [pmid: 19248113].
Settas L, Alexiou P, Dimitriadis G, et al. Effect of sulphasalazine in patients with juvenile chronic arthritis (JCA). Acta Univ Carol Med (Praha). 1991;37(1-2):76-9. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 1688267].
Shaikov AV, Maximov AA, Speransky AI, et al. Repetitive use of pulse therapy with methylprednisolone and cyclophosphamide in addition to oral methotrexate in children with systemic juvenile rheumatoid arthritis--preliminary results of a longterm study. J Rheumatol. 1992;19(4):612-6. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 1593584].
Shanmugavel C, Sodhi KS, Sandhu MS, et al. Role of power Doppler sonography in evaluation of therapeutic response of the knee in juvenile rheumatoid arthritis. Rheumatol Int. 2008;28(6):573-8. Q5 - Exclude no test performance data reported. [pmid: 17987293].
Sharma SM, Ramanan AV, Riley P, et al. Use of infliximab in juvenile onset rheumatological disease-associated refractory uveitis: efficacy in joint and ocular disease. Ann Rheum Dis. 2007;66(6):840-1. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude population not JIA/JRA. [pmid: 17170050].
Shaw KL, Southwood TR, Duffy CM, et al. Health-related quality of life in adolescents with juvenile idiopathic arthritis. Arthritis Rheum. 2006;55(2):199-207. Q5 - Exclude not TEP priority measure. [pmid: 16583399].
Shetty AK, Zganjar BE, Ellis GS Jr, et al. Low-dose methotrexate in the treatment of severe juvenile rheumatoid arthritis and sarcoid iritis. J Pediatr Ophthalmol Strabismus. 1999;36(3):125-8. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 10358815].
Sicotte NL, Voskuhl RR. Onset of multiple sclerosis associated with anti-TNF therapy. Neurology. 2001;57(10):1885-8. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 11723281].
Sijssens KM, Rothova A, Van De Vijver DA, et al. Risk factors for the development of cataract requiring surgery in uveitis associated with juvenile idiopathic arthritis. Am J Ophthalmol. 2007;144(4):574-9. Q1, 2, 4 - Exclude study not prospective; Q3 - Exclude no AE data reported. [pmid: 17706583].
Silverman E, Spiegel L, Hawkins D, et al. Long-term open-label preliminary study of the safety and efficacy of leflunomide in patients with polyarticular-course juvenile rheumatoid arthritis. Arthritis Rheum. 2005;52(2):554-62. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 15693001].
Silverman ED, Laxer RM, Greenwald M, et al. Intravenous gamma globulin therapy in systemic juvenile rheumatoid arthritis. Arthritis Rheum. 1990;33(7):1015-22. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 1695098].
Simard JF, Neovius M, Hagelberg S, et al. Juvenile idiopathic arthritis and risk of cancer: A nationwide cohort study. Arthritis Rheum. 2010;62(12):3776-3782. Exclude Q124 - no acceptable comparator. [pmid: 20827782].
Simon D, Prieur AM, Quartier P, et al. Early recombinant human growth hormone treatment in glucocorticoid-treated children with juvenile idiopathic arthritis: a 3-year randomized study. J Clin Endocrinol Metab. 2007;92(7):2567-73. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARDintervention. [pmid: 17488793].
Simonini G, Zannin ME, Caputo R, et al. Loss of efficacy during long-term infliximab therapy for sight-threatening childhood uveitis. Rheumatology (Oxford). 2008;47(10):1510-1514. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 18676502].
Skoglund RR, Schanberger JE, Kaplan JM. Cyclophosphamide therapy for severe juvenile rheumatoid arthritis. Am J Dis Child. 1971;121(6):531-3. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 5581027].
Skytta E, Pohjankoski H, Savolainen A. Etanercept and urticaria in patients with juvenile idiopathic arthritis. Clin Exp Rheumatol. 2000;18(4):533-4. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 10949736].
Slifman NR, Gershon SK, Lee JH, et al. Listeria monocytogenes infection as a complication of treatment with tumor necrosis factor alpha-neutralizing agents. Arthritis Rheum. 2003;48(2):319-24. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 12571839].
Smith JR, Levinson RD, Holland GN, et al. Differential efficacy of tumor necrosis factor inhibition in the management of inflammatory eye disease and associated rheumatic disease. Arthritis Rheum. 2001;45(3):252-7. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population >18. [pmid: 11409666].
Sobrin L, Christen W, Foster CS. Mycophenolate mofetil after methotrexate failure or intolerance in the treatment of scleritis and uveitis. Ophthalmology. 2008;115(8):1416-21. 1421 e1. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 18221998].
Somerville MF, Scott DG. Neoral--new cyclosporin for old?. Br J Rheumatol. 1997;36(10):1113-5. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 9374930].
Speckmaier M, Findeisen J, Woo P, et al. Low-dose methotrexate in systemic onset juvenile chronic arthritis. Clin Exp Rheumatol. 1989;7(6):647-50. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 2612084].
Stinson JN, Petroz GC, Stevens BJ, et al. Working out the kinks: Testing the feasibility of an electronic pain diary for adolescents with arthritis. Pain Research and Management. 2008;13(5):375-382. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude not relevant measure. [pmid: 18958308].
Stinson JN, Stevens BJ, Feldman BM, et al. Construct validity of a multidimensional electronic pain diary for adolescents with arthritis. Pain. 2008;136(3):281-92. Q5 - Exclude not priority instrument. [pmid: 17723279].
Sukal SA, Nadiminti L, Granstein RD. Etanercept and demyelinating disease in a patient with psoriasis. J Am Acad Dermatol. 2006;54(1):160-4. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 16384777].
Sulpice M, Deslandre CJ, Quartier P. Efficacy and safety of TNFalpha antagonist therapy in patients with juvenile spondyloarthropathies. Joint, Bone, Spine: Revue du Rhumatisme. 2009;76(1):24-7. Q1, 2, 4 - Exclude no acceptabl comparator; Q3 - Exclude no AE data reported.
Swale VJ, Perrett CM, Denton CP, et al. Etanercept-induced systemic lupus erythematosus. Clin Exp Dermatol. 2003;28(6):604-7. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 14616825].
Swartz MO, Silver RM. D-penicillamine induced polymyositis in juvenile chronic arthritis: report of a case. J Rheumatol. 1984;11(2):251-2. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 6726729].
Takei S, Groh D, Bernstein B, et al. Safety and efficacy of high dose etanercept in treatment of juvenile rheumatoid arthritis. J Rheumatol. 2001;28(7):1677-80. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 11469478].
Takeyama J, Sato A, Nakano K, et al. Epstein-Barr virus associated Hodgkin lymphoma in a 9-year-old girl receiving long-term methotrexate therapy for juvenile idiopathic arthritis. J Pediatr Hematol Oncol. 2006;28(9):622-4. Q11, 2, 4 - Exclude no acceptable comparator. [pmid: 17006270].
Tanaka H, Tsugawa K, Suzuki K, et al. Treatment of difficult cases of systemic-onset juvenile idiopathic arthritis with tacrolimus. Eur J Pediatr. 2007;166(10):1053-5. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 17187256].
Tauber T, Daniel D, Barash J, et al. Optic neuritis associated with etanercept therapy in two patients with extended oligoarticular juvenile idiopathic arthritis. Rheumatology (Oxford). 2005;44(3):405. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 15637094].
Tauber T, Turetz J, Barash J, et al. Optic neuritis associated with etanercept therapy for juvenile arthritis. J AAPOS. 2006;10(1):26-9. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 16527676].
ten Cate R, van Suijlekom-Smit LW, Brinkman DM, et al. Etanercept in four children with therapy-resistant systemic juvenile idiopathic arthritis. Rheumatology (Oxford). 2002;41(2):228-9. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 11886975].
Ting TV, Hashkes PJ. Methotrexate/naproxen-associated severe hepatitis in a child with juvenile idiopathic arthritis. Clin Exp Rheumatol. 2007;25(6):928-9. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 18173932].
Toussirot E, Streit G, Wendling D. Infectious complications with anti-TNFalpha therapy in rheumatic diseases: a review. Recent Pat Inflamm Allergy Drug Discov. 2007;1(1):39-47. Q1, 2, 4 - Exclude study not prospective; Q3 - Exclude no AE data reported. [pmid: 19075965].
Trapanotto M, Giorgino D, Zulian F, et al. The italian version of the pedsqltm in children with rheumatic diseases. Clin Exp Rheumatol. 2009;27(2):373-380. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude only 74% JIA. [pmid: 19473585].
Tristano AG. Neurological adverse events associated with anti-tumor necrosis factor alpha treatment. J Neurol. 2010;257(9):1421-1431. Exclude Q1, 2, 4 - publication not peer-reviewed Exclude; Q3 - population not JIA/JRA. [pmid: 20495815].
Truckenbrodt H, Hafner R. Methotrexate therapy in juvenile rheumatoid arthritis: a retrospective study. Arthritis Rheum. 1986;29(6):801-7. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 3718568].
Tse SM, Laxer RM, Babyn PS, et al. Radiologic Improvement of juvenile idiopathic arthritis-enthesitis-related arthritis following anti-tumor necrosis factor-alpha blockade with etanercept. J Rheumatol. 2006;33(6):1186-8. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 16755667].
Tukova J, Chladek J, Nemcova D, et al. Methotrexate bioavailability after oral and subcutaneous dministration in children with juvenile idiopathic arthritis. Clin Exp Rheumatol. 2009;27(6):1047-53. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 20149329].
Tutar E, Ekici F, Nacar N, et al. Delayed maculopapular, urticarial rash due to infliximab in two children with systemic onset juvenile idiopathic arthritis. Rheumatology (Oxford). 2004;43(5):674-5. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 15103034].
Tyler LN, Harville TO, Blackall DP. Multiple alloantibodies after transfusion in an infant treated with infliximab. N Engl J Med. 2007;357(20):2092-3. discussion 2093. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 18003972].
Tynjala P, Lindahl P, Honkanen V, et al. Infliximab and etanercept in the treatment of chronic uveitis associated with refractory juvenile idiopathic arthritis. Ann Rheum Dis. 2007;66(4):548-50. Q1, 2, 4 - Exclude study not prospective. [pmid: 17068061].
Tynjala P, Vahasalo P, Honkanen V, et al. Drug survival of the first and second course of anti-tumour necrosis factor agents in juvenile idiopathic arthritis. Ann Rheum Dis. 2009;68(4):552-7. Q1, 2, 4 - Exclude not prospective; Q3 - Exclude no AE data reported. [pmid: 18467515].
Tzaribachev N, Kuemmerle-Deschner J, Eichner M, et al. Safety and efficacy of etanercept in children with juvenile idiopathic arthritis below the age of 4 years. Rheumatol Int. 2008;28(10):1031-4. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 18369626].
Uziel Y, Laxer RM, Schneider R, et al. Intravenous immunoglobulin therapy in systemic onset juvenile rheumatoid arthritis: a followup study. J Rheumatol. 1996;23(5):910-8. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 8724308].
van der Meer A, Wulffraat NM, Prakken BJ, et al. Psychological side effects of MTX treatment in juvenile idiopathic arthritis: a pilot study. Clin Exp Rheumatol. 2007;25(3):480-5. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 17631750].
Van Hecke E, Kint A, Temmerman L. A lichenoid eruption induced by penicillamine. Arch Dermatol. 1981;117(10):676-7. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 7283463].
van Kerckhove C, Giannini EH, Lovell DJ. Temporal patterns of response to D-penicillamine, hydroxychloroquine, and placebo in juvenile rheumatoid arthritis patients. Arthritis Rheum. 1988;31(10):1252-8. Q3 - Exclude no AE data reported. [pmid: 3178907].
van Pelt PA, Kruize AA, Goren SS, et al. Transition of rheumatologic care, from teenager to adult: which health assessment questionnaire can be best used?. Clin Exp Rheumatol. 2010;28(2):281-6. Exclude - no clinical outcomes measure. [pmid: 20483054].
van Rossum MA, Boers M, Zwinderman AH, et al. Development of a standardized method of assessment of radiographs and radiographic change in juvenile idiopathic arthritis: introduction of the Dijkstra composite score. Arthritis Rheum. 2005;52(9):2865-72. Q5 - Exclude does not use TEP-indicated instrument. [pmid: 16142707].
van Rossum MA, van Soesbergen RM, Boers M, et al. Long-term outcome of juvenile idiopathic arthritis following a placebo-controlled trial: sustained benefits of early sulfasalazine treatment. Ann Rheum Dis. 2007;66(11):1518-24. Q1, 2, 4 - Exclude study not prospective. [pmid: 17491099].
Vandvik IH, Hoyeraal HM, Larsen S. Agreement between parents and physicians regarding clinical evaluation of patients with juvenile rheumatoid arthritis. Scand J Rheumatol. 1988;17(6):459-463. Q1, 2, 4 - Exclude no acceptable DMARD intervention; Q3 - Exclude no acceptable DMARD intervention Q5 - Exclude no measure of interest. [pmid: 3232036].
Varbanova BB, Dyankov ED. Sulphasalazine. An alternative drug for second-line treatment of juvenile chronic arthritis. Adv Exp Med Biol. 1999;455:331-6. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 10599365].
Varma S. Juvenile rheumatoid arthritis with focal segmental glomerulosclerosis: A rare association. Pediatr Nephrol. 2010;25(10):2189-2190. Exclude Q1, 2, 4 - publication not peer-reviewed Exclude; Q3 - no acceptable DMARD intervention. [pmid: 20306089].
Varni JW, Seid M, Knight TS, et al. The PedsQL 4.0 Generic Core Scales: sensitivity, responsiveness, and impact on clinical decision-making. J Behav Med. 2002;25(2):175-93. Exclude - no responsiveness or construct validity data reported. [pmid: 11977437].
Varni JW, Seid M, Kurtin PS. PedsQL 4.0: reliability and validity of the Pediatric Quality of Life Inventory version 4.0 generic core scales in healthy and patient populations. Med Care. 2001;39(8):800-12. Exclude - population not JIA. [pmid: 11468499].
Varni JW, Seid M, Rode CA. The PedsQL: measurement model for the pediatric quality of life inventory. Med Care. 1999;37(2):126-39. Exclude - population not JIA. [pmid: 10024117].
Varni JW, Seid M, Smith Knight T, et al. The PedsQL in pediatric rheumatology: reliability, validity, and responsiveness of the Pediatric Quality of Life Inventory Generic Core Scales and Rheumatology Module. Arthritis Rheum. 2002;46(3):714-25. Exclude - not JIA population. [pmid: 11920407].
Verbsky JW, White AJ. Effective use of the recombinant interleukin 1 receptor antagonist anakinra in therapy resistant systemic onset juvenile rheumatoid arthritis. J Rheumatol. 2004;31(10):2071-5. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 15468378].
Vilca I, Munitis PG, Pistorio A, et al. Predictors of poor response to methotrexate in polyarticular-course juvenile idiopathic arthritis: Analysis of the PRINTO methotrexate trial. Ann Rheum Dis. 2010;69(8):1479-1483. Exclude Q1, 2, 4 - no acceptable comparator Exclude; Q3 - no AE data reported. [pmid: 20525842].
Viola S, Felici E, Magni-Manzoni S, et al. Development and validation of a clinical index for assessment of long-term damage in juvenile idiopathic arthritis. Arthritis Rheum. 2005;52(7):2092-102. Q5 - Exclude not priority instrument. [pmid: 15986372].
Visvanathan S, Wagner C, Marini JC, et al. The effect of infliximab plus methotrexate on the modulation of inflammatory disease markers in juvenile idiopathic arthritis: Analyses from a randomized, placebo-controlled trial. Pediatric Rheumatology. 2010;8. Exclude Q1, 2, 4 - no outcomes of interest Exclude; Q3 - no AE data reported.
Vuorimaa H, Honkanen V, Konttinen YT, et al. Improved factor structure for self-efficacy scales for children with JIA (CASE) and their parents (PASE). Clin Exp Rheumatol. 2007;25(3):494-501. Q5 - Exclude no clinical outcome measure. [pmid: 17631752].
Wallace CA, Bleyer WA, Sherry DD, et al. Toxicity and serum levels of methotrexate in children with juvenile rheumatoid arthritis. Arthritis Rheum. 1989;32(6):677-81. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 2735961].
Wallace CA, Ravelli A, Huang B, et al. Preliminary validation of clinical remission criteria using the OMERACT filter for select categories of juvenile idiopathic arthritis. J Rheumatol. 2006;33(4):789-95. Exclude - methods paper. [pmid: 16482643].
Wallace CA, Ruperto N, Giannini E, et al. Preliminary criteria for clinical remission for select categories of juvenile idiopathic arthritis. J Rheumatol. 2004;31(11):2290-4. Q5 - Exclude no test performance data reported. [pmid: 15517647].
Wallace CA, Sherry DD. Preliminary report of higher dose methotrexate treatment in juvenile rheumatoid arthritis. J Rheumatol. 1992;19(10):1604-7. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 1464876].
Wallace CA, Sherry DD. Trial of intravenous pulse cyclophosphamide and methylprednisolone in the treatment of severe systemic-onset juvenile rheumatoid arthritis. Arthritis Rheum. 1997;40(10):1852-5. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 9336421].
Wallace CA, Smith AL, Sherry DD. Pilot investigation of naproxen/methotrexate interaction in patients with juvenile rheumatoid arthritis. J Rheumatol. 1993;20(10):1764-8. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 8295192].
Weinblatt M, Schiff M, Goldman A, et al. Selective costimulation modulation using abatacept in patients with active rheumatoid arthritis while receiving etanercept: a randomised clinical trial. Ann Rheum Dis. 2007;66(2):228-34. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 16935912].
Weiss AH, Wallace CA, Sherry DD. Methorexate for resistant chronic uveitis in children with juvenile rheumatoid arthritis. J Pediatr. 1998;133(2):266-268. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 9709718].
White PH, Ansell BM. Methotrexate for juvenile rheumatoid arthritis. N Engl J Med. 1992;326(16):1077-8. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 1549155].
Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Medical Research Methodology. 2006;6:9. Exclude - methods paper. [pmid: 16519814].
Wiegering V, Morbach H, Dick A, et al. Crohn's disease during etanercept therapy in juvenile idiopathic arthritis: A case report and review of the literature. Rheumatol Int. 2010;30(6):801-804. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 19506877].
Winterhalter S, Niehues T. TNFalpha-blocking agents or conventional immunosuppressive drugs in the therapy of children with uveitis? - an evidence based approach. Klin Padiatr. 2008;220(6):342-7. Q1, 2, 4 - Exclude population not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA. [pmid: 18949668].
Woo P. Anakinra treatment for systemic juvenile idiopathic arthritis and adult onset Still disease. Ann Rheum Dis. 2008;67(3):281-2. Q1, 2, 4 - Exclude not peer-reviewed; Q3 - Exclude no AE data reported. [pmid: 18292104].
Woo P, Wilkinson N, Prieur AM, et al. Open label phase II trial of single, ascending doses of MRA in Caucasian children with severe systemic juvenile idiopathic arthritis: proof of principle of the efficacy of IL-6 receptor blockade in this type of arthritis and demonstration of prolonged clinical improvement. Arthritis Res Ther. 2005;7(6):R1281-8. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 16277681].
Workie DW, Graham TB, Laor T, et al. Quantitative MR characterization of disease activity in the knee in children with juvenile idiopathic arthritis: a longitudinal pilot study. Pediatr Radiol. 2007;37(6):535-43. Q5 - Exclude not priority instrument. [pmid: 17401557].
Wright FV, Kimber JL, Law M, et al. The Juvenile Arthritis Functional Status Index (JASI): a validation study. J Rheumatol. 1996;23(6):1066-79. Q5 - Exclude does not use TEP-indicated instrument. [pmid: 8782142].
Wright FV, Law M, Crombie V, et al. Development of a self-report functional status index for juvenile rheumatoid arthritis. J Rheumatol. 1994;21(3):536-44. Q5 - Exclude does not use TEP-indicated instrument. [pmid: 8006899].
Yildirim Y. Primary ovarian large B-cell lymphoma in patient with juvenile rheumatoid arthritis treated with low dose Methotrexate. Gynecol Oncol. 2005;97(1):249-52. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 15790469].
Yildirim-Toruner C, Kimura Y, Rabinovich E. Hodgkin's lymphoma and tumor necrosis factor inhibitors in juvenile idiopathic arthritis. J Rheumatol. 2008;35(8):1680-1. Q1, 2, 4 - Exclude not peer-reviewed. [pmid: 18671328].
Yokota S, Kishimoto T. Tocilizumab: Molecular intervention therapy in children with systemic juvenile idiopathic arthritis. Expert Review of Clinical Immunology. 2010;6(5):735-743. Exclude Q1, 2, 4 - publication not peer-reviewed Exclude; Q3 - population not JIA/JRA. [pmid: 20828281].
Yokota S, Miyamae T, Imagawa T, et al. Therapeutic efficacy of humanized recombinant anti-interleukin-6 receptor antibody in children with systemic-onset juvenile idiopathic arthritis. Arthritis Rheum. 2005;52(3):818-25. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 15751095].
Zangi HA, Garratt A, Hagen KB, et al. Emotion regulation in patients with rheumatic diseases: Validity and responsiveness of the emotional approach coping scale (EAC). BMC Musculoskeletal Disorders. 2009;10(1). Q1, 2, 4 - Exclude population Not JIA/JRA/JCA; Q3 - Exclude population not JIA/JRA.
Zeft A, Hollister R, LaFleur B, et al. Anakinra for systemic juvenile arthritis: the Rocky Mountain experience. J Clin Rheumatol. 2009;15(4):161-4. Q1, 2, 4 - Exclude no acceptable comparator. [pmid: 19363453].
Zeltser R, Valle L, Tanck C, et al. Clinical, histological, and immunophenotypic characteristics of injection site reactions associated with etanercept: a recombinant tumor necrosis factor alpha receptor: Fc fusion protein. Arch Dermatol. 2001;137(7):893-9. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - Exclude no AE data reported. [pmid: 11453808].
Zimmer-Galler I, Lie JT. Choroidal infiltrates as the initial manifestation of lymphoma in rheumatoid arthritis after treatment with low-dose methotrexate. Mayo Clin Proc. 1994;69(3):258-61. Q1, 2, 4 - Exclude population > 18; Q3 - Exclude population > 18. [pmid: 7510810].
Zulian F, Balzarin M, Falcini F, et al. Abatacept for severe anti-tumor necrosis factor (alpha) refractory juvenile idiopathic arthritis-related uveitis. Arthritis Care Res. 2010;62(6):821-825. Q1, 2, 4 - Exclude no acceptable comparator; Q3 - no AE data reported.