# Data Abstraction Forms

KQ 1–4—Blank ET/Data Abstraction Form

Study | Interventions and study design | Patient characteristics | Results | Comments/quality/applicability
StudyID | Geographical location: Study dates: Funding source: Setting: Study design: RCT Nonrandomized comparative study Other Intervention(s):; - DMARD name:; - Dose:; - Titration:; - N:; Comparator(s): Were additional arthritis medications allowed?: If Yes to above, was this done: Per protocol At discretion of clinician/investigator NR Study duration: Primary outcome(s): Secondary outcome(s): | Number of patients:; - Screened for inclusion:; - Eligible for inclusion:; - Randomized:; - Began treatment:; - Completed treatment:; - Withdrawals/losses to followup:; Age:; - Mean (SD):; - Median:; - Range:; Sex:; - Female:; - Male:; Race/ethnicity: JIA diagnosis: JRA JCA JIA Spondyloarthropathy Psoriatic arthritis Other (describe) Baseline severity: Active joint count: Duration of disease: Other (specify): NR Percentage with uveitis: Inclusion criteria: Exclusion criteria: | 1. Active joint count:; 2. Quality of life/functional status:; 3. Number of joints with limited range of motion:; 4. Global assessment of current status:; - Physician:; - Patient/Parent:; 5. Laboratory measures of inflammation:; - ESR:; - Other:; 6. Radiographic evidence of progression of disease:; 7. Pain control:; 8. Clinical remission:; 9. Flare of disease:; 10. Discontinuation of DMARD due to:; - Remission of disease:; - Inefficacy:; - Intolerance/AEs:; 11. Mortality:; 12. Adverse events reported?:; - Yes; - No; 13. Other: | Exclusion reasons (if appropriate): General comments: Quality assessment: Primary outcome:; - Overall rating:; - Comments:; Adverse events:; - Overall rating:; - Comments:; Applicability: This article is relevant to: Question #_____

KQ 5—Blank ET/Data Abstraction Form

Study | Study design | Patient characteristics | Instrument(s) | Results | Comments/quality/applicability
StudyID | Geographical location: Setting: Specialty clinic Other [specify] Study design: RCT Longitudinal non-RCT Cross-sectional Other [specify] Study objective(s): Duration of followup: | Number of patients: Age:; - Mean (SD):; - Median:; - Range:; Sex:; - Female:; - Male:; Race/ethnicity: JIA diagnosis: JRA JCA JIA Spondyloarthropathy Psoriatic arthritis Other (describe) Percentage with systemic JIA: Baseline severity: Time since diagnosis: Active joint count: Other [specify]: NR Inclusion criteria: Exclusion criteria: | Instrument(s) evaluated: Mode of administration: Self-administered Interviewer-administered Other [specify] | 1) Reliability:; - Test-retest:; - Kappa statistics:; - Inter-rater:; - Intra-rater:; - Intra-class correlation:; 2) Validity:; - Versus clinical outcomes:; - Versus lab results:; - Versus radiological results:; - New instrument versus established instrument:; 3) Other:; - Feasibility: NR [or report results]; - Responsiveness: NR [or report results]; - ROC curves: NR [or report results] | Exclusion reasons (if appropriate): General comments: Quality assessment: