# Exact Search Strings

## Search Strategies Used to Search MEDLINE^®^ via PubMed^®^— Last Search Date December 23, 2010

### Key Questions 1, 2, 3, and 4

((“arthritis, juvenile rheumatoid”[MeSH Terms] OR (“arthritis”[All Fields] AND “juvenile”[All Fields] AND “rheumatoid”[All Fields]) OR “juvenile rheumatoid arthritis”[All Fields] OR (“juvenile”[All Fields] AND “idiopathic”[All Fields] AND “arthritis”[All Fields]) OR “juvenile idiopathic arthritis”[All Fields]) AND (((“abatacept”[Substance Name] OR “abatacept”[All Fields]) OR (“abatacept”[Substance Name] OR “abatacept”[All Fields] OR “orencia”[All Fields]) OR (“adalimumab”[Substance Name] OR “adalimumab”[All Fields]) OR (“interleukin 1 receptor antagonist protein”[MeSH Terms] OR “interleukin 1 receptor antagonist protein”[All Fields] OR “anakinra”[All Fields]) OR (“interleukin 1 receptor antagonist protein”[MeSH Terms] OR “interleukin 1 receptor antagonist protein”[All Fields] OR “kineret”[All Fields]) OR (“azathioprine”[MeSH Terms] OR “azathioprine”[All Fields]) OR (“azathioprine”[MeSH Terms] OR “azathioprine”[All Fields] OR “imuran”[All Fields]) OR (“canakinumab”[Substance Name] OR “canakinumab”[All Fields]) OR ilaris[All Fields] OR (“cyclosporine”[MeSH Terms] OR “cyclosporine”[All Fields] OR “cyclosporine a”[All Fields]) OR (“cyclosporine”[MeSH Terms] OR “cyclosporine”[All Fields] OR “neoral”[All Fields]) OR gengraf[All Fields] OR (“penicillamine”[MeSH Terms] OR “penicillamine”[All Fields] OR “d penicillamine”[All Fields]) OR Depen[All Fields] OR (“penicillamine”[MeSH Terms] OR “penicillamine”[All Fields] OR “cuprimine”[All Fields]) OR (“TNFR-Fc fusion protein”[Substance Name] OR “TNFR-Fc fusion protein”[All Fields] OR “etanercept”[All Fields]) OR (“TNFR-Fc fusion protein”[Substance Name] OR “TNFR-Fc fusion protein”[All Fields] OR “enbrel”[All Fields]) OR (“hydroxychloroquine”[MeSH Terms] OR “hydroxychloroquine”[All Fields]) OR (“hydroxychloroquine”[MeSH Terms] OR “hydroxychloroquine”[All Fields] OR “plaquenil”[All Fields]) OR (“infliximab”[Substance Name] OR “infliximab”[All Fields]) OR (“infliximab”[Substance Name] OR “infliximab”[All Fields] OR “remicade”[All Fields]) OR (“leflunomide”[Substance Name] OR “leflunomide”[All Fields]) OR (“immunoglobulins, intravenous”[MeSH Terms] OR (“immunoglobulins”[All Fields] AND “intravenous”[All Fields]) OR “intravenous immunoglobulins”[All Fields] OR “ivig”[All Fields]) OR carimune[All Fields] OR flebogamma[All Fields] OR (“Gamunex”[Substance Name] OR “Gamunex”[All Fields] OR “gamunex”[All Fields]) OR (“immunoglobulins, intravenous”[MeSH Terms] OR (“immunoglobulins”[All Fields] AND “intravenous”[All Fields]) OR “intravenous immunoglobulins”[All Fields] OR “gammagard”[All Fields]) OR (“immunoglobulins, intravenous”[MeSH Terms] OR (“immunoglobulins”[All Fields] AND “intravenous”[All Fields]) OR “intravenous immunoglobulins”[All Fields] OR “iveegam”[All Fields]) OR (“Octagam”[Substance Name] OR “Octagam”[All Fields] OR “octagam”[All Fields]) OR panglobulin[All Fields] OR polygam[All Fields] OR (“Privigen”[Substance Name] OR “Privigen”[All Fields] OR “privigen”[All Fields]) OR (“leflunomide”[Substance Name] OR “leflunomide”[All Fields] OR “arava”[All Fields]) OR (“methotrexate”[MeSH Terms] OR “methotrexate”[All Fields]) OR (“mycophenolate mofetil”[Substance Name] OR “mycophenolate mofetil”[All Fields]) OR (“mycophenolate mofetil”[Substance Name] OR “mycophenolate mofetil”[All Fields] OR “cellcept”[All Fields]) OR (“rilonacept”[Substance Name] OR “rilonacept”[All Fields]) OR arcalyst[All Fields] OR (“rituximab”[Substance Name] OR “rituximab”[All Fields]) OR (“rituximab”[Substance Name] OR “rituximab”[All Fields] OR “rituxan”[All Fields]) OR (“sulphasalazine”[All Fields] OR “sulfasalazine”[MeSH Terms] OR “sulfasalazine”[All Fields]) OR (“sulfasalazine”[MeSH Terms] OR “sulfasalazine”[All Fields] OR “azulfidine”[All Fields]) OR (“tacrolimus”[MeSH Terms] OR “tacrolimus”[All Fields]) OR (“tacrolimus”[MeSH Terms] OR “tacrolimus”[All Fields] OR “fk506”[All Fields]) OR (“tacrolimus”[MeSH Terms] OR “tacrolimus”[All Fields] OR “prograf”[All Fields]) OR (“thalidomide”[MeSH Terms] OR “thalidomide”[All Fields]) OR (“thalidomide”[MeSH Terms] OR “thalidomide”[All Fields] OR “thalomid”[All Fields]) OR (“sulfadiazine”[MeSH Terms] OR “sulfadiazine”[All Fields] OR “sulfazine”[All Fields]) OR (“tocilizumab”[Substance Name] OR “tocilizumab”[All Fields]) OR (“tocilizumab”[Substance Name] OR “tocilizumab”[All Fields] OR “actemra”[All Fields]) OR (disease-modifying[All Fields] AND (“antirheumatic agents”[MeSH Terms] OR (“antirheumatic”[All Fields] AND “agents”[All Fields]) OR “antirheumatic agents”[All Fields] OR (“anti”[All Fields] AND “rheumatic”[All Fields] AND “drugs”[All Fields]) OR “anti rheumatic drugs”[All Fields] OR “antirheumatic agents”[Pharmacological Action])) OR dmards[All Fields]) OR ((“betamethasone”[MeSH Terms] OR “betamethasone”[All Fields]) OR (“betamethasone”[MeSH Terms] OR “betamethasone”[All Fields] OR “celestone”[All Fields]) OR (“celecoxib”[Substance Name] OR “celecoxib”[All Fields]) OR (“celecoxib”[Substance Name] OR “celecoxib”[All Fields] OR “celebrex”[All Fields]) OR (“etodolac”[MeSH Terms] OR “etodolac”[All Fields]) OR (“etodolac”[MeSH Terms] OR “etodolac”[All Fields] OR “lodine”[All Fields]) OR (“triamcinolone”[MeSH Terms] OR “triamcinolone”[All Fields]) OR (“triamcinolone acetonide”[MeSH Terms] OR (“triamcinolone”[All Fields] AND “acetonide”[All Fields]) OR “triamcinolone acetonide”[All Fields] OR “kenalog”[All Fields]) OR (“triamcinolone hexacetonide”[Substance Name] OR “triamcinolone hexacetonide”[All Fields] OR “aristospan”[All Fields]) OR (“ibuprofen”[MeSH Terms] OR “ibuprofen”[All Fields]) OR advil[All Fields] OR (“ibuprofen”[MeSH Terms] OR “ibuprofen”[All Fields] OR “motrin”[All Fields]) OR (“indomethacin”[MeSH Terms] OR “indomethacin”[All Fields]) OR (“indomethacin”[MeSH Terms] OR “indomethacin”[All Fields] OR “indocin”[All Fields]) OR (“meloxicam”[Substance Name] OR “meloxicam”[All Fields]) OR (“meloxicam”[Substance Name] OR “meloxicam”[All Fields] OR “mobic”[All Fields]) OR (“naproxen”[MeSH Terms] OR “naproxen”[All Fields]) OR (“naproxen”[MeSH Terms] OR “naproxen”[All Fields] OR “naprosyn”[All Fields]) OR (“naproxen”[MeSH Terms] OR “naproxen”[All Fields] OR “aleve”[All Fields]) OR (“oxaprozin”[Substance Name] OR “oxaprozin”[All Fields]) OR (“oxaprozin”[Substance Name] OR “oxaprozin”[All Fields] OR “daypro”[All Fields]) OR (“tolmetin”[MeSH Terms] OR “tolmetin”[All Fields]) OR (“tolmetin”[MeSH Terms] OR “tolmetin”[All Fields] OR “tolectin”[All Fields]) OR (“anti-inflammatory agents, non-steroidal”[MeSH Terms] OR (“anti-inflammatory”[All Fields] AND “agents”[All Fields] AND “non-steroidal”[All Fields]) OR “non-steroidal anti-inflammatory agents”[All Fields] OR “nsaids”[All Fields] OR “anti-inflammatory agents, non-steroidal”[Pharmacological Action]) OR (“adrenal cortex hormones”[MeSH Terms] OR (“adrenal”[All Fields] AND “cortex”[All Fields] AND “hormones”[All Fields]) OR “adrenal cortex hormones”[All Fields] OR “corticosteroids”[All Fields] OR “adrenal cortex hormones”[Pharmacological Action])))) AND (“humans”[MeSH Terms] AND English[lang])

### Key Question 5

((“ACR30”[All Fields] OR (American[All Fields] AND College[All Fields] AND (“rheumatology”[MeSH Terms] OR “rheumatology”[All Fields]) AND 30[All Fields]) OR (American[All Fields] AND College[All Fields] AND (“rheumatology”[MeSH Terms] OR “rheumatology”[All Fields]) AND Pediatric[All Fields]) OR (ACR[All Fields] AND Pediatric[All Fields])) OR (((“arthritis, juvenile rheumatoid”[MeSH Terms] OR (“arthritis”[All Fields] AND “juvenile”[All Fields] AND “rheumatoid”[All Fields]) OR “juvenile rheumatoid arthritis”[All Fields] OR (“juvenile”[All Fields] AND “idiopathic”[All Fields] AND “arthritis”[All Fields]) OR “juvenile idiopathic arthritis”[All Fields]) AND (“humans”[MeSH Terms] AND English[lang])) AND ((“quality of life”[MeSH Terms] OR (“quality”[All Fields] AND “life”[All Fields]) OR “quality of life”[All Fields]) OR (“health status”[MeSH Terms] OR (“health”[All Fields] AND “status”[All Fields]) OR “health status”[All Fields]) OR (“outcome assessment (health care)”[MeSH Terms] OR (“outcome”[All Fields] AND “assessment”[All Fields] AND “(health”[All Fields] AND “care)”[All Fields]) OR “outcome assessment (health care)”[All Fields] OR (“outcome”[All Fields] AND “assessment”[All Fields]) OR “outcome assessment”[All Fields]) OR “disability evaluation”[MeSH Terms] OR “severity of illness index”[MeSH Terms] OR “endpoint determination/methods”[Mesh Terms]))) AND (reliability[All Fields] OR (“reproducibility of results”[MeSH Terms] OR (“reproducibility”[All Fields] AND “results”[All Fields]) OR “reproducibility of results”[All Fields]) OR concordance[All Fields] OR (“sensitivity and specificity”[MeSH Terms] OR (“sensitivity”[All Fields] AND “specificity”[All Fields]) OR “sensitivity and specificity”[All Fields] OR “sensitivity”[All Fields]) OR (“sensitivity and specificity”[MeSH Terms] OR (“sensitivity”[All Fields] AND “specificity”[All Fields]) OR “sensitivity and specificity”[All Fields] OR “specificity”[All Fields]) OR (“roc curve”[MeSH Terms] OR (“roc”[All Fields] AND “curve”[All Fields]) OR “roc curve”[All Fields] OR (“receiver”[All Fields] AND “operating”[All Fields] AND “characteristic”[All Fields]) OR “receiver operating characteristic”[All Fields]) OR (response[All Fields] AND (“Change”[Journal] OR “change”[All Fields])) OR (sensitive[All Fields] AND (“Change”[Journal] OR “change”[All Fields])) OR ((“sensitivity and specificity”[MeSH Terms] OR (“sensitivity”[All Fields] AND “specificity”[All Fields]) OR “sensitivity and specificity”[All Fields] OR “sensitivity”[All Fields]) AND (“Change”[Journal] OR “change”[All Fields])) OR responsiveness[All Fields] OR (“psychometrics”[MeSH Terms] OR “psychometrics”[All Fields]) OR validity[All Fields] OR “Validation Studies as Topic”[Mesh] AND (“humans”[MeSH Terms] AND English[lang])) AND (“humans”[MeSH Terms] AND English[lang])

## Search Strategies Used to Search EMBASE^®^—Last Search Date December 23, 2010

### Key Questions 1, 2, 3, and 4

‘mycophenolate mofetil’/exp OR ‘mycophenolate mofetil’ OR ‘abatacept’/exp OR ‘abatacept’/de OR ‘orencia’/exp OR ‘orencia’/de OR ‘adalimumab’/exp OR ‘adalimumab’/de OR ‘anakinra’/exp OR ‘anakinra’/de OR ‘kineret’/exp OR ‘kineret’/de OR ‘azathioprine’/exp OR ‘azathioprine’/de OR azasan OR ‘imuran’/exp OR ‘imuran’/de OR ‘canakinumab’/exp OR ‘canakinumab’/de OR ‘ilaris’/exp OR ‘ilaris’/de OR ‘cyclosporine’/exp OR ‘cyclosporine’/de OR ‘neoral’/exp OR ‘neoral’/de OR ‘gengraf’/exp OR ‘gengraf’/de OR ‘d penicillamine’/exp OR ‘d penicillamine’/de OR ‘depen’/exp OR ‘depen’/de OR ‘cuprimine’/exp OR ‘cuprimine’/de OR ‘etanercept’/exp OR ‘etanercept’/de OR ‘enbrel’/exp OR ‘enbrel’/de OR ‘hydroxychloroquine’/exp OR ‘hydroxychloroquine’/de OR ‘plaquenil’/exp OR ‘plaquenil’/de OR ‘infliximab’/exp OR ‘infliximab’/de OR ‘remicade’/exp OR ‘remicade’/de OR ‘leflunomide’/exp OR ‘leflunomide’/de OR ivig OR carimune OR ‘flebogamma’/exp OR ‘flebogamma’/de OR ‘gamunex’/exp OR ‘gamunex’/de OR ‘gammagard’/exp OR ‘gammagard’/de OR ‘iveegam’/exp OR ‘iveegam’/de OR ‘octagam’/exp OR ‘octagam’/de OR ‘panglobulin’/exp OR ‘panglobulin’/de OR ‘polygam’/exp OR ‘polygam’/de OR ‘privigen’/exp OR ‘privigen’/de OR ‘arava’/exp OR ‘arava’/de OR ‘methotrexate’/exp OR ‘methotrexate’/de OR ‘mycophenolate’/exp OR ‘cellcept’/exp OR ‘cellcept’/de OR ‘rilonacept’/exp OR ‘rilonacept’/de OR ‘arcalyst’/exp OR ‘arcalyst’/de OR ‘rituximab’/exp OR ‘rituximab’/de OR ‘rituxan’/exp OR ‘rituxan’/de OR ‘sulfasalazine’/exp OR ‘sulfasalazine’/de OR ‘azulfidine’/exp OR ‘azulfidine’/de OR ‘tacrolimus’/exp OR ‘tacrolimus’/de OR ‘fk506’/exp OR ‘fk506’/de OR ‘prograf’/exp OR ‘prograf’/de OR ‘thalidomide’/exp OR ‘thalidomide’/de OR ‘thalomid’/exp OR ‘thalomid’/de OR ‘sulfazine’/exp OR ‘sulfazine’/de OR ‘tocilizumab’/exp OR ‘tocilizumab’/de OR ‘actemra’/exp OR ‘actemra’/de OR dmards OR ‘disease modifying antirheumatic drug’/exp AND (‘juvenile rheumatoid arthritis’/exp OR ‘juvenile rheumatoid arthritis’) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim)

### Key Question 5

‘juvenile rheumatoid arthritis’/exp OR ‘juvenile rheumatoid arthritis’ AND (‘reliability’/exp OR reliability OR ‘reproducibility’/exp OR reproducibility OR ‘sensitivity and specificity’/exp OR ‘sensitivity and specificity’ OR ‘psychometry’/exp OR psychometry OR ‘health status’/exp OR ‘health status’ OR ‘quality of life’/exp OR ‘quality of life’ OR ‘outcome assessment’/exp OR ‘outcome assessment’ OR ‘validity’/exp OR validity OR ‘validation study’/exp OR ‘validation study’ OR ‘bioassay’/exp OR bioassay OR ‘disability’/exp OR disability OR ‘disease severity’/exp OR ‘disease severity’ OR ‘receiver operating characteristic’/exp OR ‘receiver operating characteristic’ OR ‘psychometrics’/exp OR psychometrics OR response OR responsiveness OR acr30 OR (american AND (‘college’/exp OR college) AND (‘rheumatology’/exp OR rheumatology) AND 30) OR ‘endpoint determination’/exp OR ‘endpoint determination’ OR concordance OR sensitivity OR specificity OR (acr AND (‘pediatrics’/exp OR pediatrics))) AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim)