# Appendixes

Appendix A Exact Search Strings

Appendix B Screening Criteria

Appendix C Data Abstraction Forms

Appendix D Evidence Tables—Main Literature Search

Appendix E Adverse Events—Wider Literature Search

Appendix F Excluded Studies