# Abbreviations

ACR: American College of Rheumatology
ACR Pediatric: American College of Rheumatology Pediatric Response Criteria
AHRQ: Agency for Healthcare Research and Quality
AJC: Active joint count
CD: Cluster of differentiation
CHAQ: Childhood Health Assessment Questionnaire
CHAQ-DI: Childhood Health Assessment Questionnaire Disability Index
CHQ: Child Health Questionnaire
CHQ PhS: Child Health Questionnaire physical score
CHQ PsS: Child Health Questionnaire psychosocial score
CI: Confidence interval
DMARD(s): Disease-modifying antirheumatic drug(s)
EPC: Evidence-based Practice Center
ESR: Erythrocyte sedimentation rate
EULAR: European League Against Rheumatism
Fc: Fragment crystallizable
FDA: U.S. Food and Drug Administration
GRADE: Grading of Recommendations Assessment, Development and Evaluation
HAQ: Stanford Health Assessment Questionnaire
IgM: Immunoglobulin M
IL: Interleukin
ILAR: International League of Associations for Rheumatology
IVIG: Intravenous immunoglobulin
JCA: Juvenile chronic arthritis
JADAS: Juvenile Arthritis Disease Activity Score (JADAS)
JIA: Juvenile idiopathic arthritis
JRA: Juvenile rheumatoid arthritis
LROM: Limited range of motion
MDA: Minimal disease activity
MeSH: Medical Subject Headings
NSAID(s): Non-steroidal anti-inflammatory drug(s)
PedsQL: Pediatric Quality of Life Inventory
PedsQL-RM: Pediatric Quality of Life Inventory Rheumatology Module
PGA: Physician global assessment of disease activity
PGW: Parent/patient global assessment of well-being
PICOTS: Population, interventions, comparators of interest, outcomes, timing, settings
RCT: Randomized controlled trial
ROC: Receiver operating characteristic
RR: Risk ratio
SAARD(s): Slow-acting antirheumatic drug(s)
SRC: Scientific Resource Center
T-cell/-lymphocyte: Thymus cell/lymphocyte
TEP: Technical expert panel
TNF: Tumor necrosis factor