# Technical Expert Panel

Linda Humphrey, M.D., M.P.H.

American College of Physicians

Portland, OR

Silvio Inzucchi, M.D.

Yale School of Medicine

New Haven, CT

Sue Kirkman, M.D.

American Diabetes Association

Alexandria, VA

Leonard Pogach, M.D.

Veterans Administration Health Care System

East Orange, NJ

Helena W. Rodbard, M.D., F.A.C.P., M.A.C.E.

Endocrine and Metabolic Consultants

Rockville, MD

Chris Saudek, M.D.

Johns Hopkins University

Baltimore, MD

Christopher H. Schmid, Ph.D.

Tufts Medical Center

Boston, MA

Donna Sweet, M.D.

American College of Physicians

Wichita, KS

Susan Tan-Torres, M.D., M.P.H.

Blue Cross and Blue Shield

Audubon, PA