# Results

## Search Results

A summary of the search results is presented in Figure 2. From the search, we retrieved 20,748 unique citations. After a review of the titles and abstracts, 1,027 were deemed eligible for further review, and the full articles were retrieved. A total of 166 articles were included in this review.

Figure 2 Summary of the literature search (number of articles)

*Total may exceed number in corresponding box, as articles could be excluded for more than one reason at this level.

†71 studies were included in the 2007 review

CENTRAL = Central Register of Controlled Trials

Figure 2 depicts the flow diagram for our literature search. We searched three electronic databases. We obtained 7927 citations from Medline, 6507 citations from Cochrane Central Registrar of Controlled Trials (CENTRAL), and 16093 citations from EMBASE. Hand searching retrieved an additional 203 citations. In total, 30,730 citations were retrieved. After removing 9982 duplicates, 20,748 titles were reviewed. We excluded 14,882 at the title review level. We reviewed 5,866 abstracts. We excluded 4,839 abstracts. Reasons for exclusion are did not apply to a key question (273 abstracts), no original data (2,188 abstracts), no comparison group (120 abstracts), does not have a drug comparison of interest (575 abstracts), no subjects with type 2 diabetes (43 abstracts), less than 40 subjects in the study (486 abstracts), study participants on drugs for less than 30 days (18 abstracts), no human data reported (42 abstracts), not written in English (6 abstracts), no subjects over the age of 18 years (3 abstracts) and some other reason for exclusion (37 abstracts). Since articles could be excluded for more than one reason, the total number of reasons for exclusion may exceed the number excluded. We reviewed the full text of 1027 articles and excluded 861. Reasons for exclusion are did not apply to a key question (65 articles), did not meet the study design criteria (44 articles), study duration less than 3 months (13 articles), no original data (139 articles), no comparison group (33 articles), does not have a drug comparison of interest (226 articles), no subjects with type 2 diabetes (1 article), less than 40 subjects in the study (32 articles), not written in English (14 articles), no subjects over the age of 18 years (1 article), and some other reason for exclusion (86 articles). For this review, we included 166 studies, 71 of which were included in the 2007 report.

## Key Question 1 In adults age 18 or older with type 2 diabetes mellitus, what is the comparative effectiveness of the treatment options (see list of comparisons) for the intermediate outcomes of glycemic control (in terms of HbA1c), weight, or lipids?

### Key Points and Evidence Grades

#### HbA1c

##### Monotherapy Versus Monotherapy

- Most oral diabetes medications had similar efficacy in achieving reductions in HbA1c, with absolute reduction by around 1 percent compared with baseline values. The strength of evidence was graded high for metformin versus sulfonylurea with a pooled between-group difference of 0.1 percent (95 percent confidence interval [CI] −0.1 percent to 0.3 percent). The strength of evidence was graded as moderate for the following comparisons: metformin versus thiazolidinediones, thiazolidinediones versus sulfonylureas, sulfonylureas versus repaglinide, and pioglitazone versus rosiglitazone.
- Metformin had a greater reduction in hemoglobin A1c (HbA1c) compared with dipeptidyl peptidase-4 (DPP-4) inhibitors, with a pooled between-group difference of −0.4 percent (95 percent CI −0.5 percent to −0.2 percent), with moderate strength of evidence.

##### Combination Therapy Versus Monotherapy

- All combination therapies were better at reducing HbA1c than monotherapy regimens, with between-group differences of about 1 percent. The strength of evidence was graded high for metformin versus metformin plus thiazolidinediones, and metformin versus metformin plus sulfonylureas, and graded moderate for metformin versus metformin plus DPP-4 inhibitors.

##### Combination Therapy Versus Combination Therapy

- The combination of metformin plus thiazolidinedione had similar efficacy in reducing HbA1c compared to the combination of metformin plus sulfonylurea, with moderate strength of evidence.
- Nine other combination therapy comparisons had low strength of evidence, making it difficult to draw firm conclusions. However, the majority showed similar efficacy in reducing HbA1c.
  ○ Five combinations showed similar efficacy in reducing HbA1c: metformin plus repaglinide versus metformin plus thiazolidinedione, metformin plus sitagliptin versus metformin plus thiazolidinedione, metformin plus sulfonylurea versus metformin plus DPP-4 inhibitor, metformin plus thiazolidinedione versus metformin plus glucagon-like peptide-1 (GLP-1) agonist, and metformin plus GLP-1 agonist versus metformin plus basal insulin.
  ○ The combination of metformin plus GLP-1 agonist reduced HbA1c more than metformin plus DPP-4 inhibitors, with a pooled between-group difference of −0.6 percent (95 percent CI −0.8 percent to −0.4 percent). Two other comparisons only minimally favored one combination over another with differences in HbA1c ranging from 0.03 percent to 0.09 percent: metformin plus sulfonylurea favored versus thiazolidinediones plus sulfonylurea, and thiazolidinediones plus sulfonylureas favored versus metformin plus thiazolidinediones.

#### Weight

##### Monotherapy Versus Monotherapy

- When compared with thiazolidinediones, metformin maintained or decreased weight with a pooled between-group difference of −2.6 kg (95 percent CI −4.1 kg to −1.2 kg). The strength of evidence was graded as high, favoring metformin.
- When compared with sulfonylureas, metformin maintained or decreased weight with a pooled between-group difference of −2.7 kg (95 percent CI −3.5 kg to −1.9 kg). The strength of evidence was graded as high, favoring metformin.
- Sulfonylureas had similar effects on body weight as the meglitinides when used as monotherapy, with a high evidence grade.
- When compared with sulfonylureas, GLP-1 agonists decreased weight (pooled between-group difference of −2.5 kg, 95 percent CI −3.8 kg to −1.1 kg). The strength of evidence was graded moderate favoring GLP-1 agonists.
- When compared with DPP-4 inhibitors, metformin had greater weight reduction (pooled between-group difference of −1.4 kg (95 percent CI −1.8 kg to −1.0 kg). The strength of evidence was graded as moderate, favoring metformin.
- Sulfonylureas caused slightly less weight gain when compared with thiazolidinediones (between-group difference of −1.2 kg, 95 percent CI −1.9 kg to −0.6 kg). While this was graded as low evidence for the monotherapy comparisons, it was strengthened by the combination comparisons (described below) which favor metformin plus sulfonylurea over metformin plus a thiazolidinedione (pooled between-group difference of −0.9 kg, 95 percent CI −1.3 kg to −0.4 kg) with a moderate grade of evidence.

##### Combination Therapy Versus Monotherapy

- Metformin monotherapy had a more favorable effect on weight compared with the combination of metformin plus a thiazolidinedione (between-group difference of −2.2 kg, 95 percent CI −2.6 kg to −1.9 kg) or metformin plus a sulfonylurea (pooled between-group difference of −2.3 kg, 95 percent CI −3.3 kg to −1.2 kg). The strength of evidence was graded high for these comparisons.
- Metformin monotherapy had no significant differences in weight when compared with the combination of metformin plus DPP-4 inhibitors (pooled between-group difference of −0.2 kg, 95 percent CI −0.7 kg to 0.2 kg). The strength of evidence was graded moderate for this comparison.

##### Combination Therapy Versus Combination Therapy

- Metformin plus sulfonylurea had a more favorable effect on weight compared with both the combinations of a thiazolidinedione plus sulfonylurea (between-group difference of −3.2 kg, 95 percent CI −5.2 kg to −1.1 kg) and metformin plus a thiazolidinedione (between-group difference of −0.9 kg, 95 percent CI −1.3 kg to −0.4 kg). Both comparisons had moderate strength of evidence.
- Several combination therapies, metformin plus sulfonylurea, metformin plus thiazolidinedione, metformin plus basal insulin, and metformin plus DPP-4 inhibitor, were compared with metformin plus GLP-1 agonists, all favoring the combination of metformin plus GLP-1 agonists which decreased weight.
  ○ While all the individual comparisons were graded as low evidence, the data as a whole suggested a beneficial effect on weight for the combination of metformin plus GLP-1 agonists compared with several other standard combination therapies. The range in between group differences was 1.9 kg to 12.3 kg, and all but one study had less than a 5 kg between-group difference.
- The combination of metformin plus DPP-4 inhibitors decreased weight when compared with the combinations of metformin plus thiazolidinedione or metformin plus sulfonylurea. While these individual comparisons are graded as low strength of evidence due to few studies with the same comparators, the data suggest that metformin plus DPP-4 inhibitors may have a more favorable effect on weight than the other two standard combinations. The range of between-group differences was small (1.5 kg to 2.5 kg).

#### Low-Density Lipoproteins

##### Monotherapy Versus Monotherapy

- Metformin decreased low-density lipoproteins (LDL) while sulfonylureas generally had little effect on LDL (pooled between-group difference favoring metformin of −10.1 mg/dL, 95 percent CI −13.3 mg/dL to −7.0 mg/dL), with high strength of evidence.
- Rosiglitazone and pioglitazone increased LDL while metformin decreased LDL with moderate strength of evidence. The pooled between-group differences comparing metformin to rosiglitazone and pioglitazone were −12.8 mg/dL (95 percent CI −24.0 mg/dL to −1.6 mg/dL) and −14.2 mg/dL (95 percent CI −15.3 mg/dL to −13.1 mg/dL), respectively.
- Metformin decreased LDL compared to DPP-4 inhibitors, with a pooled between-group difference of −5.9 mg/dL (95 percent CI −9.8 mg/dL to −2.0 mg/dL), with moderate strength of evidence.

##### Combination Therapy Versus Monotherapy

- The combination of metformin and rosiglitazone increased LDL compared to metformin monotherapy (pooled between-group difference of 14.5 mg/dL, 95 percent CI 13.3 mg/dL to 15.7 mg/dL), with high strength of evidence.

##### Combination Therapy Versus Combination Therapy

- The combination of metformin and a sulfonylurea decreased LDL more than the combination of metformin and rosiglitazone (pooled between-group difference −13.5 mg/dL, 95 percent CI −17.9 mg/dL to −9.1 mg/dL), with moderate strength of evidence.

#### High-Density Lipoproteins

##### Monotherapy Versus Monotherapy

- Pioglitazone increased high-density lipoproteins (HDL) compared to metformin (pooled between-group difference of 3.2 mg/dL, 95 percent CI 2.1 mg/dL to 5.7 mg/dL) with high strength of evidence.
- Neither rosiglitazone nor sulfonylureas had an effect on HDL relative to metformin, with high strength of evidence for sulfonylureas and moderate for rosiglitazone
- Rosiglitazone increased HDL less than pioglitazone (pooled between-group difference of −2.3 mg/dL, 95 percent CI −3.5 mg/dL to −1.2 mg/dL), with moderate strength of evidence. Pioglitazone increased HDL when compared with sulfonylureas (pooled between-group difference of 4.3 mg/dL, 95 percent CI 1.9 mg/dL to 6.6 mg/dL), with moderate strength of evidence.

##### Combination Therapy Versus Monotherapy

- The combination of rosiglitazone and metformin increased HDL relative to metformin monotherapy (pooled between-group difference of 2.8 mg/dL, 95 percent CI 2.2 mg/dL to 3.5 mg/dL), with high strength of evidence.
- The combination of metformin and DPP-4 inhibitors did not affect HDL relative to metformin monotherapy. The pooled between-group difference in HDL for metformin compared to the combination of metformin and saxagliptin was 0.5 mg/dL (95 percent CI −1.5 mg/dL to 2.5 mg/dL) with moderate strength of evidence

##### Combination Therapy Versus Combination Therapy

- The combination of rosiglitazone or pioglitazone with metformin increased HDL compared to the combination of metformin and a sulfonylurea. The strength of evidence was graded as moderate for these comparisons:
  ○ The pooled between-group difference for the combination of metformin and rosiglitazone compared to the combination of metformin and a sulfonylurea was 2.7 mg/dL (95 percent CI 1.4 mg/dL to 4.1 mg/dL).
  ○ The combination of metformin and pioglitazone increased HDL by about 5 mg/dL compared to the combination of metformin and a sulfonylurea.
- The combination comparisons with pioglitazone favored the pioglitazone containing arm (range of between-group differences were 3.1 mg/dL to 10.5 mg/dL) for the following comparisons:
  ○ The combination of pioglitazone plus metformin versus metformin monotherapy, the combination of metformin plus pioglitazone versus the combination of metformin plus sulfonylurea, and the combination of sulfonylurea plus pioglitazone versus the combination of metformin plus sulfonylurea. The strength of evidence was graded as low for each individual comparison.

#### Triglycerides

##### Monotherapy Versus Monotherapy

- Pioglitazone decreased triglycerides (TG) more than metformin (pooled between-group difference −27.2 mg/dL, 95 percent CI −30.0 mg/dL to −24.4 mg/dL), with high strength of evidence.
- Metformin decreased TG relative to rosiglitazone which increased TG (pooled between-group difference −26.9 mg/dL, 95 percent CI −49.3 mg/dL to −4.5 mg/dL), with moderate strength of evidence.
- Metformin decreased TG compared to sulfonylureas (pooled between-group difference −8.6 mg/dL, 95 percent CI −15.6 mg/dL to −1.6 mg/dL) with moderate strength of evidence.
- Sulfonylureas and meglitinides had similar effects on TG (pooled between-group difference 0.2 mg/dL, 95 percent CI −3.8 mg/dL to 4.2 mg/dL), with moderate strength of evidence.

##### Combination Therapy Versus Monotherapy

- Metformin monotherapy decreased TG compared to the combination of metformin and rosiglitazone (pooled between-group difference −14.5 mg/dL, 95 percent CI −15.7 mg/dL to −13.3 mg/dL), with high strength of evidence.

##### Combination Therapy Versus Combination Therapy

- The combination of metformin and rosiglitazone had similar effects on TG compared to a combination of metformin and a sulfonylurea, with moderate strength of evidence.
- The combination of metformin and pioglitazone decreased TG compared to the combination of metformin and a sulfonylurea by about 15 mg/dL, with moderate strength of evidence.

See Table 4 for the evidence grades and specific conclusions for each comparison. Details of the evidence grades are in Appendix G, Table 1.

Table 4 Key findings and strength of the evidence comparing diabetes medications as monotherapy or combination therapy for intermediate outcomes

Comparison | HbA1c | Weight/BMI | LDL | HDL | TG
MONOTHERAPY COMPARISONS
Metformin versus
TZD | Neither Favored; Mod | Favors Met; High | Favors Met; Mod^‡^ Favors Met; High^§^ | Neither Favored; Mod^‡^ Favors Pio; High^§^ | Favors Met; Mod^‡^ Favors Pio; High^§^
SU | Neither Favored; High | Favors Met; High | Favors Met; High | Neither Favored; High | Favors Met; Mod
DPP-4 inhibitor | Favors Met; Mod | Favors Met; Mod | Favors Met; Mod | Neither Favored; Low | Neither Favored; Low
Meglitinides | Neither Favored; Low^*^ Favors Met; Low^†^ | Unclear; Low | Unclear; Low | Unclear; Low | Unclear; Low
GLP-1 agonist | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + TZD | Favors Met+TZD; High | Favors Met; High | Favors Met; High^‡^ Unclear; Low^§^ | Favors Met+Rosi; High^‡^ Favors Met+Pio; Low^§^ | Favors Met; High^‡^ Unclear; Low^§^
Metformin + SU | Favors Met+SU; High | Favors Met; High | Neither Favored; Low | Neither Favored; Low | Neither Favored; Low
Metformin + DPP-4 inhibitor | Favors Met+DPP-4; Mod | Neither Favored; Mod | Neither Favored; Low | Neither Favored; Mod | Favors Met+DPP-4; Low
Metformin + meglitinides | Favors Met+Meg; Low | Favors Met; Low | Unclear; Low | Neither Favored; Low | Favors Met+Meg; Low
TZD versus
TZD | Neither Favored; Mod | Neither Favored; Low | Favors Pio; Low | Favors Pio; Mod | Neither Favored; Low
SU | Neither Favored; Mod | Favors SU; Low | Favors SU; Low^‡,§^ | Favors Rosi; Low^‡^ Favors Pio; Mod^§^ | Unclear; Low^‡^ Favors Pio; Low^§^
DPP-4 inhibitor | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Meglitinides | Unclear; Low^*^ Neither Favored; Low^†^ | Unclear; Low | Unclear; Low^‡,§^ | Unclear; Low^‡^ Favors Pio; Low^§^ | Unclear; Low^‡^ Favors Pio; Low^§^
GLP-1 agonist | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
SU versus
DPP-4 inhibitor | Neither Favored; Low | Unclear; Low | Neither Favored; Low | Neither Favored; Low | Neither Favored; Low
Meglitinides | Neither Favored; High^*^ Neither Favored; Low^†^ | Neither Favored; High | Neither Favored; Low | Neither Favored; High | Neither Favored; Mod
GLP-1 agonist | Unclear; Low | Favors GLP-1; Mod | Unclear; Low | Insufficient | Unclear; Low
DPP-4 inhibitor versus
Meglitinides | Insufficient | Insufficient | Insufficient | Unclear; Low | Insufficient
GLP-1 agonist | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
COMBINATION COMPARISONS
Metformin + TZD versus
Metformin + SU | Neither favored; Mod | Favors Met+SU; Mod | Favors Met+SU; Mod^‡^ Favors Met+SU; Low^§^ | Favors Met+Rosi; Mod^‡^ Favors Met+Pio; Low^§^ | Neither favored; Mod^‡^ Favors Met+Pio; Mod^§^
Metformin + meglitinides | Neither favored; Low^*^ Insufficient^†^ | Unclear; Low | Favors Met+Meg; Low^‡^ Insufficient^§^ | Favors Met+Rosi; Low^‡^ Insufficient^§^ | Neither favored; Low^‡^ Insufficient^§^
Metformin + DPP-4 inhibitor | Neither favored; Low | Favors Met+DPP4; Low | Insufficient^‡,§^ | Low; Unclear^‡^ Insufficient^§^ | Low; Favors Met+Sita^‡^ Insufficient^§^
Metformin + GLP-1 agonist | Neither favored; Low | Favors Met+GLP1; Low | Unclear; Low^‡,§^ | Favors Met+Rosi; Low^‡^ Insufficient^§^ | Favors Met+GLP1; Low^‡^ Insufficient^§^
TZD + SU | Favors TZD+SU; Low | Insufficient | Insufficient^‡^ Neither favored; Low^§^ | Insufficient^‡^ Favors Met+Pio; Low^§^ | Insufficient^‡^ Favors Met+Pio; Low^§^
Met + SU versus
Metformin + meglitinides | Insufficient^*^ Unclear; Low^†^ | Unclear; Low | Unclear; Low | Neither favored; Low | Unclear; Low
Metformin + DPP-4 inhibitor | Neither favored; Low | Favors Met+DPP4; Low | Insufficient | Insufficient | Insufficient
Metformin + GLP-1 agonist | Unclear; Low | Favors Met+GLP1; Low | Insufficient | Insufficient | Insufficient
TZD + SU | Favors Met+SU; Low | Favors Met+SU; Mod | Unclear; Low^‡^ Favors Met+SU; Low^§^ | Unclear; Low^‡^ Favors Pio+SU; Low § | Unclear; Low^‡^ Favors Pio+SU; Low^§^
Metformin + premixed insulin | Unclear; Low | Favors Met+Basal; Low | Insufficient | Insufficient | Insufficient
Met + Basal Insulin versus
Metformin + premixed insulin | Neither favored; Low | Neither favored; Low | Insufficient | Insufficient | Insufficient
Metformin + GLP-1 agonist | Neither favored; Low | Favors Met+GLP1; Low | Insufficient | Insufficient | Insufficient
Met + DPP-4 inhibitor versus
Met + GLP-1 agonist | Favors Met+GLP1; Low | Favors Met+GLP1; Low | Unclear; Low | Neither favored; Low | Unclear; Low

BMI = body mass index; HDL = high density lipoprotein; HbA1c = hemoglobin A1c; Meg = meglitinides; Met = metformin; LDL = low density lipoprotein; Pio = pioglitazone; Rosi = rosiglitazone; Sita = sitagliptin; SU = sulfonylurea; TG = triglycerides; TZD = thiazolidinedione

* For comparisons with repaglinide

† For comparisons with nateglinide

‡ For comparisons with rosiglitazone

§ For comparisons with pioglitazone

The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Mod = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable.

All other comparisons and intermediate outcomes were graded as insufficient since there were no studies.

### Study Design and Population Characteristics

One hundred nineteen randomized controlled trials (RCTs) (reported in 122 articles) evaluated intermediate clinical outcomes for adults with type 2 diabetes, and met our inclusion criteria (Appendix G, Tables 2 and 3). One hundred four, 79, and 74 of these RCTs reported HbA1c, weight, and lipid outcomes, respectively. All trials were parallel-arm RCTs except one, which used a crossover design.36 About half the trials answering Key Question 1 occurred partly or exclusively in the United States (n = 32), Italy (n = 13), and/or were multinational (n = 28); the rest of the trials occurred in developed or newly industrialized countries. These RCTs lasted from 12 weeks to 9 years; however, most studies lasted less than a year and only three studies lasted more than 2 years (United Kingdom Prospective Diabetes Study [UKPDS], Rosiglitazone Evaluated for Cardiac Outcomes and Regulation of Glycemia in Diabetes [RECORD], and A Diabetes Outcome Progression Trial [ADOPT]).16,37,38 Only seven studies reported receiving no pharmaceutical support,39–45 while about one-quarter of RCTs (n = 33) did not describe whether or not they received pharmaceutical support.

Study participants were mainly middle-aged, overweight or obese adults who had diabetes between 3 to 6 years duration. The exclusion criteria were generally similar for most trials: significant renal, cardiovascular, and hepatic disease. About half the trials (58 percent) excluded older subjects (generally older than 75 to 80 years old). Almost all the studies reported a diverse gender mix among the participants. About 20 percent of the RCTs did not report race. When race was reported, most subjects were Caucasian. The mean baseline HbA1c among study subjects varied from 6 to 12 absolute percentage points, with most subjects having a mean baseline HbA1c between 7 and 9 absolute percentage points.

### The Evidence About Hemoglobin A1c (Appendix G, Table 4)

Metformin versus thiazolidinediones. Fourteen RCTs lasting around a year or less directly compared metformin versus thiazolidinedione, showing no between-group differences in HbA1c, with a pooled between-group difference of −0.1 percent (95 percent CI −0.2 percent to 0.04 percent) (Figure 3).39,45–57 We conducted a standard sensitivity analysis testing the relative effect of each individual study to the combined point estimate. Only removing the study by Lawrence et al. affected the combined point estimate resulting in a pooled mean difference of −0.1 percent (95 percent CI −0.2 percent to −0.003 percent) which minimally favored metformin. However, we have no reason to exclude this small comparably dosed RCT, especially given the unlikely clinical relevance of such a minimal difference. No substantial heterogeneity was noted.

Figure 3 Mean difference in HbA1c comparing metformin with thiazolidinediones

CI = confidence interval; diff = difference; HbA1c = hemoglobin A1c

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 14.47 with 13 degrees of freedom (p = 0.34)

I-squared statistic = 10%

The range in change scores for HbA1c for the comparison group, thiazolidinediones, was −2.6% to −0.3%. The median change was −1.0%.

Figure 3 is a forest plot for the meta-analysis of the mean difference in hemoglobin A1c comparing metformin with thiazolidinediones. There are 14 studies included in this meta-analysis: Hallsten 2002 with a mean difference of -.4 (95 percent CI -.88 to .08), Pavo 2003 with a mean difference of -.2 (95 percent CI -.48 to .08), Schernthaner 2004 with a mean difference of -.09 (95 percent CI -.2 to .02), Lawrence 2004 with a mean difference of .31 (95 percent CI -.15 to .77), Ramachandran 2004 with a mean difference of 1.2 (95 percent CI -.04 to 2.44), Yamanouchi 2005 with a mean difference of .2 (95 percent CI -.2 to .6), Rosenstock 2006 with a mean difference of -.2 (95 percent CI -.59 to .19), Iliadis 2007 with a mean difference of -.7 (95 percent CI -1.83 to .43), Erdem 2008 with a mean difference of .15 (95 percent CI -.83 to 1.13), Derosa 2009 with a mean difference of -.1 (95 percent CI -.75 to .55), Gupta 2009 with a mean difference of -.15 (95 percent CI -.59 to .29), Kiyici 2009 with a mean difference of .4 (95 percent CI -.47 to 1.27), Perez 2009 with a mean difference of -.03 (95 percent CI -.37 to .31), Kato 2009 with a mean difference of .22 (95 percent CI -1.07 to 1.51). Numbers greater than 0 favor thiazolidinediones, and numbers less than 0 favor metformin. The pooled mean difference was -0.07 percent (95 percent confidence interval -0.18 percent to 0.04 percent). There was no statistically significant heterogeneity across the studies.

We excluded two studies from the meta-analysis, one with a median study duration of 4 years38 and one which reported median HbA1c instead of means.58 The 4-year double-blind RCT (known as the ADOPT study) was designed to compare long-term glycemic control between metformin, rosiglitazone, and glyburide monotherapy as initial treatment for type 2 diabetic adults.38 While they found a statistically significant difference between groups favoring rosiglitazone (mean difference between groups 0.1 percent, 95 percent CI 0.05 percent to 0.2 percent), the clinical relevance of this difference is less clear. Of note, the HbA1c decreased in all groups for the first 6 months, and then increased in all groups over the rest of the study. The other short-duration RCT excluded from the meta-analysis was consistent with the pooled results, reporting no between-group differences in median HbA1c.58

Metformin versus sulfonylureas. We combined 17 studies comparing metformin with a second-generation sulfonylurea and showed similar changes in HbA1c in both groups, with a pooled between-group difference of 0.1 percent (95 percent CI −0.1 percent to 0.3 percent) (Figure 4).36,50,51,53,59–71 Removing the 1-year study by DeFronzo et al. changed the results of the meta-analysis, favoring second-generation sulfonylureas slightly with a pooled between-group difference of 0.2 percent (95 percent CI 0.02 percent to 0.3 percent);70 which may reflect the slightly longer study duration.

Figure 4 Mean difference in HbA1c comparing metformin with sulfonylureas

CI = confidence interval; diff = difference; HbA1c = hemoglobin A1c

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 43.22 with 16 degrees of freedom (p = 0.003)

I-squared statistic = 63%

The range in change scores for HbA1c for the comparison group, sulfonylureas, was −2.5% to 0.5%. The median change was −1.2%.

Figure 4 is a forest plot for the meta-analysis of the mean difference in hemoglobin A1c comparing metformin with sulfonylureas. There are 17 studies included in this meta-analysis: Hermann 1991 with a mean difference of .4 (95 percent CI -.37 to 1.17), Campbell 1994 with a mean difference of -.64 (95 percent CI -1.69 to .41), Hermann 1994 with a mean difference of .4 (95 percent CI -.15 to .95), DeFronzo 1995 with a mean difference of -.6 (95 percent CI -.88 to -.32), Amador-Licona 2000 with a mean difference of -.1 (95 percent CI -.79 to .59), Charpentier 2001 with a mean difference of -.12 (95 percent CI -.4 to .16), Blonde 2002 with a mean difference of .5 (95 percent CI .14 to .86), Marre 2002 with a mean difference of .1 (95 percent CI -.38 to .58), Garber 2002 with a mean difference of .21 (95 percent CI -.03 to .45), Tosi 2003 with a mean difference of .05 (95 percent CI -.83 to .93), Goldstein 2003 with a mean difference of .2 (95 percent CI -.13 to .53), Garber 2003 with a mean difference of .37 (95 percent CI .06 to .68), Derosa 2004 with a mean difference of .2 (95 percent CI -3.74 to 4.14), Lawrence 2004 with a mean difference of -.09 (95 percent CI -.6 to .42), Ramachandran 2004 with a mean difference of 1.1 (95 percent CI -.3 to 2.5), Yamanouchi 2005 with a mean difference of . (95 percent CI -.38 to .38), Chien 2007 with a mean difference of -.43 (95 percent CI -1.29 to .43). Numbers greater than 0 favor sulfonylureas and numbers less than 0 favor metformin. The pooled mean difference was 0.07 percent (95 percent confidence interval -0.12 percent to 0.26 percent). There was statistically significant heterogeneity across the studies.

While most of the point estimates were close to zero, substantial heterogeneity was found. Metaregression suggested that study duration may explain some of the heterogeneity (p = 0.09). Studies lasting less than 6 months seemed to favor sulfonylureas slightly (pooled between-group difference of 0.2 percent, 95 percent CI 0.01 percent to 0.3 percent), while those lasting 6 months to a year showed no between-group differences in medications (pooled between-group difference of −0.1 percent, 95 percent CI −0.5 percent to 0.3 percent). The small possible difference of 0.18 percent seen with studies lasting less than 6 months has questionable clinical relevance. Baseline HbA1c and dosing ratio did not explain the heterogeneity.

The two long-term studies excluded from the meta-analysis (ADOPT and UKPDS) lasting longer than 4 years have conflicting results related to glycemic control. ADOPT favored metformin over sulfonylurea after a median followup of 4 years.38 UKPDS appeared to favor sulfonylurea over metformin in overweight individuals on monotherapy after 9 years of followup, while showing no between-group differences in mean HbA1c after 10 years of followup for those subjects where other diabetes medications were added to their monotherapy regimen.8 These differences could be due to different types of sulfonylureas between studies, study duration, or study design components such as double-blind versus open label.

The ADOPT study was excluded from the meta-analysis since the median followup was 4 years compared with the other shorter duration studies lasting less than 1 year.38 As mentioned previously, this double-blind RCT evaluated the long-term glycemic control between metformin, rosiglitazone, and glyburide monotherapy as initial treatment for type 2 diabetic adults. The between-group difference between metformin and glyburide favored metformin after 4 years (mean difference between-groups of −0.3 percent, 95 percent CI −0.2 percent to −0.4 percent). Of note, the glyburide group reduced HbA1c more than metformin initially, but then the HbA1c started to rise after about 6 months in all groups. The HbA1c rose more in the glyburide arm compared with the metformin arm by 1.5 years after treatment was started.

One of the UKPDS studies was included in this report since the article evaluated only those overweight individuals assigned metformin or sulfonylurea who did not have a second medication added over time.37 They compared the proportion of subjects who achieved a target HbA1c less than 7 percent after 9 years of followup between metformin and sulfonylurea, and appeared to favor sulfonylurea slightly (13 percent versus 21 percent respectively with nonoverlapping confidence intervals). However, only 25 percent of subjects were able to achieve a target HbA1c after 9 years on monotherapy alone.

The rest of the UKPDS72–74 studies were excluded from this section of the report since they were allowed to add other diabetes medications to their initial monotherapy groups, making it impossible to discern comparative drug effects. We describe it here briefly since it is a well known study with the longest followup (up to 10 years). The UKPDS was a multicenter trial conducted in the United Kingdom comparing different types of treatment for type 2 diabetes. Patients were recruited starting in 1977, and initially put on a diet with 50 percent carbohydrates, high fiber, reduced calories if obese, and low saturated fat. After 3 months, subjects were randomized to treatment arms or diet based on the fasting plasma glucose. If subjects had very high serum glucose values and symptoms of hyperglycemia prior to the 3-month main randomization, they were randomized to treatment early without a diet arm (the primary diet failure group). Both groups (the main randomization and the primary diet failure groups) were randomized to medications stratified by weight. If subjects were overweight based on ideal body weight, they could be randomized to insulin, chlorpropamide, glibenclamide, metformin, or diet. If they were not overweight, they could be randomized to insulin, diet, chlorpropamide, or glibenclamide. No metformin arm was available if the patient was not overweight. Metformin, glibenclamide, and insulin could be added to any of the groups if a participant was still hyperglycemic based on study protocols. Losses to followup were less than or equal to 5 percent in both the primary diet failure and main randomization groups.

The 1-year, 3-year, 6-year, and 10-year data all showed similar changes in HbA1c between groups.8,72–74 After 10 years, the change in median HbA1c from baseline was similar in both the metformin and glibenclamide arms for the main randomization group as reported in a figure (+1.3 percent versus +1.0 percent).8 The median HbA1c results were not broken down by medication type in the primary diet failure group at 10 years. After 6 years, the reported 95 percent CI for the mean final HbA1c was 7.1 percent to 9.4 percent for metformin and 6.8 percent to 9.7 percent for glibenclamide/chlorpropamide in overweight patients in the primary diet failure group.72 Of note, the main randomization group of UKPDS demonstrated that HbA1c was reduced within the first few years of the study for patients on either glibenclamide or metformin then began to rise again for all medications.8

Metformin versus DPP-4 inhibitors. Three short-duration RCTs (reported in four articles) compared metformin with DPP-4 inhibitors, reporting greater reductions in HbA1c by metformin, with a pooled between-group difference of −0.4 percent (95 percent CI −0.5 percent to −0.2 percent) (Figure 5).75–78 Two studies used metformin compared with sitagliptin,76,77 and one study compared metformin with saxagliptin.78 One RCT was reported in two articles.75,76 The first article was a 24-week RCT,75 while the second article was the 30-week continuation study with a higher loss to followup.76 The between-group difference in HbA1c of −0.5 percent favored metformin over sitagliptin at both 24 and 54 weeks of followup. We included the 24-week study in the meta-analysis since the other two studies in the meta-analysis were both 24 weeks long. No substantial heterogeneity was found in the meta-analysis. A standard sensitivity analysis was conducted to determine if any one study strongly influenced the results. The removal of the study by Goldstein et al.75 changed the pooled between-group difference to −0.2 percent (95 percent CI −0.5 percent to 0.008 percent), showing no significant differences between-groups. There would be no reason to exclude this trial compared to the other trials, however. In fact, one study used an underdosed metformin arm compared to the maximum dose DPP-4 inhibitor, thereby strengthening the result that favors metformin.78

Figure 5 Mean difference in HbA1c comparing metformin with DPP-4 inhibitors

CI = confidence interval; diff = difference; DPP-4 inhibitors = dipeptidyl peptidase-4 inhibitors; HbA1c = hemoglobin A1c

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 1.87 with 2 degrees of freedom (p = 0.39)

I-squared statistic = 0%

The range in change scores for HbA1c for the comparison group, DPP-4 inhibitors, was −1.7% to −0.4%. The median change was −0.7%.

Figure 5 is a forest plot for the meta-analysis of the mean difference in hemoglobin A1c comparing metformin with DPP-4 inhibitors. There are 3 studies included in this meta-analysis: Goldstein 2007 with a mean difference of -.47 (95 percent CI -.7 to -.24), Jadzinsky 2009 with a mean difference of -.3 (95 percent CI -.64 to .04), Aschner 2010 with a mean difference of -.18 (95 percent CI -.55 to .19). Numbers greater than 0 favor DPP-4 inhibitors and numbers less than 0 favor metformin. The pooled mean difference was -0.37 percent (95 percent confidence interval -0.54 percent to -0.20 percent). There was no statistically significant heterogeneity across the studies.

Metformin versus meglitinides. Three RCTs (reported in four articles) lasting 3 months to 1 year compared metformin with meglitinides, showing similar effects on HbA1c.79–82 One study favored the slightly underdosed metformin arm compared with the nateglinide arm (−0.3 percent between-group difference).79 This same study reported in a second article showed no between-group differences in HbA1c; however, they evaluated only the subset of patients who were treatment naïve.80 The other two studies evaluated metformin and repaglinide at comparable doses showing non-meaningful between-group differences of 0.1 percent and 0.05 percent.81,82

Metformin versus a combination of metformin and thiazolidinediones. Eleven studies compared metformin with the combination of metformin plus a thiazolidinedione (most rosiglitazone except for four studies with pioglitazone),46,49,56,83–90 showing a greater improvement in HbA1c with the combination in all the studies. The pooled between-group difference was 0.7 percent (95 percent CI 0.5 percent to 0.9 percent) (Figure 6). No single study markedly affected the results. Despite the substantial heterogeneity reported, all studies favored the combination arm. Metaregression showed that baseline HbA1c was a significant source of heterogeneity (p = 0.01) while study duration and dosing ratio were not. Studies with higher baseline HbA1c (HbA1c > 8 percent) had greater between-group differences (pooled between-group difference of 0.9 percent (95 percent CI 0.7 percent to 1.1 percent) than studies with lower baseline HbA1c (HbA1c < 8 percent; pooled between-group difference of 0.4 percent, 95 percent CI 0.2 percent to 0.7 percent).

Figure 6 Mean difference in HbA1c comparing metformin with combination of metformin and thiazolidinediones

CI = confidence interval; diff = difference; HbA1c = hemoglobin A1c

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 63.83 with 10 degrees of freedom (p = 0.0000)

I-squared statistic = 84%

The range in change scores for HbA1c for the comparison group, a combination of metformin and thiazolidinediones, was −2.3% to −0.33%. The median change was −0.83%.

Figure 6 is a forest plot for the meta-analysis of the mean difference in hemoglobin A1c comparing metformin with a combination of metformin and thiazolidinediones. There are 11 studies included in this meta-analysis: Fonseca 2000 with a mean difference of 1.01 (95 percent CI .67 to 1.35), Einhorn 2000 with a mean difference of .83 (95 percent CI .41 to 1.25), Gomez-Perez 2002 with a mean difference of 1.5 (95 percent CI .79 to 2.21), Bailey 2005 with a mean difference of .22 (95 percent CI .09 to .35), Leiter 2005 with a mean difference of .36 (95 percent CI .16 to .56), Weissman 2005 with a mean difference of .22 (95 percent CI .05 to .39), Rosenstock 2006 with a mean difference of .5 (95 percent CI .1 to .9), Scott 2008 with a mean difference of .57 (95 percent CI .37 to .77), Kaku 2009 with a mean difference of .92 (95 percent CI .66 to 1.18), Derosa 2009 with a mean difference of 1. (95 percent CI .47 to 1.53), Perez 2009 with a mean difference of .84 (95 percent CI .5 to 1.18). Numbers greater than 0 favor the combination of metformin and thiazolidinediones, and numbers less than 0 favor metformin. The pooled mean difference was 0.66 percent (95 percent confidence interval 0.45 percent to 0.86 percent). There was statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and sulfonylureas. Fourteen RCTs compared metformin with the combination of metformin plus a second-generation sulfonylurea with all of the studies favoring the combination arm over monotherapy (pooled between-group difference of 1.0 percent, 95 percent CI 0.8 percent to 1.3 percent) (Figure 7).36,46,59,61–65,68–71,91,92

Figure 7 Mean difference in HbA1c comparing metformin with combination of metformin and sulfonylureas

CI = confidence interval; diff = difference; HbA1c = hemoglobin A1c

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 81.30 with 13 degrees of freedom (p = 0.0000)

I-squared statistic = 84%

The range in change scores for HbA1c for the comparison group, a combination metformin and sulfonylurea, was −2.3% to −0.7%. The median change was −1.6%.

Figure 7 is a forest plot for the meta-analysis of the mean difference in hemoglobin A1c comparing metformin with a combination of metformin and sulfonylureas. There are 14 studies included in this meta-analysis: Hermann 1991 with a mean difference of 1.2 (95 percent CI .29 to 2.11), Hermann 1994 with a mean difference of 1.3 (95 percent CI .59 to 2.01), DeFronzo 1995 with a mean difference of 1.3 (95 percent CI 1.02 to 1.58), Charpentier 2001 with a mean difference of .92 (95 percent CI .63 to 1.21), Blonde 2002 with a mean difference of 2.03 (95 percent CI 1.67 to 2.39), Marre 2002 with a mean difference of 1. (95 percent CI .53 to 1.47), Garber 2002 with a mean difference of .5 (95 percent CI .26 to .74), Garber 2003 with a mean difference of .74 (95 percent CI .43 to 1.05), Tosi 2003 with a mean difference of 1.4 (95 percent CI .7 to 2.1), Goldstein 2003 with a mean difference of .98 (95 percent CI .69 to 1.27), Feinglos 2005 with a mean difference of .47 (95 percent CI .19 to .75), Chien 2007 with a mean difference of 1.3 (95 percent CI .45 to 2.15), Derosa 2009 with a mean difference of .1 (95 percent CI -.46 to .66), Nauck 2009 with a mean difference of 1.1 (95 percent CI .82 to 1.38). Numbers greater than 0 favor the combination of metformin and sulfonylureas and numbers less than 0 favor metformin. The pooled mean difference was 1.0 percent (95 percent confidence interval 0.75 percent to 1.25 percent). There was statistically significant heterogeneity across the studies.

No single study markedly influenced the results. Metaregression was conducted due to substantial heterogeneity, showing that higher dose combinations had greater between-group effects and lower dose combinations had smaller between-group effects (p = 0.002). The study by Blonde et al. showed the greatest between-group differences since this study used a high-dose combination and started with the highest baseline HbA1c compared with other studies.63 Three of the six dose-response studies showed a dose-response gradient favoring greater reductions in HbA1c with a higher dose combination than with a lower dose combination.63,64,68 One crossover study initially showed a difference between groups at the first crossover and then a negative rebound effect when changing the combination to monotherapy.36

Metformin versus a combination of metformin and DPP-4 inhibitors. Six RCTs directly compared metformin with the combination of metformin plus a DPP-4 inhibitor—all favoring the combination arm, with a pooled between-group difference of 0.7 percent (95 percent CI 0.6 percent to 0.8 percent) (Figure 8).75,78,85,93–95 No single study markedly influenced the results, and no substantial heterogeneity was found. One RCT was published twice, first with the 24-week RCT results75 and second as a 30-week continuation76 to that same study. We included the shorter duration results in the meta-analysis since the study duration was more homogenous with the rest of the studies, plus had less loss to followup.75 The 54-week results also favored the combination arm over the monotherapy arm, with a between-group difference of 0.8 percent.76 They also showed a small dose-response effect in the combination arms, with the 2,000 mg metformin and 100 mg sitagliptin arm reducing HbA1c more than the 1,000 mg metformin plus 100 mg sitagliptin arm (mean change from baseline −1.8 percent versus −1.4 percent respectively).

Figure 8 Mean difference in HbA1c comparing metformin with combination of metformin and DPP-4 inhibitors

CI = confidence interval; diff = difference; DPP-4 inhibitors = dipeptidyl peptidase-4 inhibitors; HbA1c = hemoglobin A1c Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 179.59 with 5 degrees of freedom (p = 0.00)

I-squared statistic = 97%

The range in change scores for HbA1c for the comparison group, a combination of metformin and DPP-4 inhibitor, was −2.5% to −0.7%. The median change was −0.9%.

Figure 8 is a forest plot for the meta-analysis of the mean difference in hemoglobin A1c comparing metformin with a combination of metformin and DPP-4 inhibitors. There are 6 studies included in this meta-analysis: Charbonnel 2006 with a mean difference of .65 (95 percent CI .49 to .81), Goldstein 2007 with a mean difference of .77 (95 percent CI .54 to 1.), Scott 2008 with a mean difference of .51 (95 percent CI .32 to .7), Raz 2008 with a mean difference of 1. (95 percent CI .6 to 1.4), Jadzinsky 2009 with a mean difference of .5 (95 percent CI .17 to .83), DeFronzo 2009 with a mean difference of .83 (95 percent CI .63 to 1.03). Numbers greater than 0 favor the combination of metformin and DPP-4 inhibitors and numbers less than 0 favor metformin. The pooled mean difference was 0.69 percent (95 percent confidence interval 0.56 percent to 0.82 percent). There was statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and meglitinides. Three RCTs compared metformin with combination of metformin plus meglitinides, all favoring the combination arm (range in between-group differences of −0.5 percent to −1.08 percent). We separated out nateglinide from repaglinide combinations since indirect monotherapy comparisons suggest nateglinide has less effect on HbA1c than repaglinide.21

Two similarly dosed 24-week studies reported in three articles compared metformin versus metformin plus nateglinide, showing greater reductions in HbA1c in the combination arms compared with the monotherapy arms (range in between-group differences of −0.5 percent to −0.8 percent).79,80,96 Only one of these RCTs reported that this between-group difference was also statistically significant,96 while the other study did not report on the between-group statistical significance in either article.79,80

One additional short duration study compared metformin versus metformin plus repaglinide, which also favored the combination therapy over monotherapy (between-group difference of −1.1 percent, 95 percent CI −1.8 percent to −0.3 percent).82

Rosiglitazone versus pioglitazone. Three RCTs with similar dosing of the medications compared rosiglitazone with pioglitazone, and showed no significant between-group differences in HbA1c, with a pooled between-group difference of 0.1 percent (95 percent CI −0.2 percent to 0.3 percent) (Figure 9).97–99 No one study significantly influenced the results, and no substantial heterogeneity was found.

Figure 9 Mean difference in HbA1c comparing rosiglitazone with pioglitazone

CI = confidence interval; diff = difference; HbA1c = hemoglobin A1c

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.16 with 2 degrees of freedom (p = 0.92)

I-squared statistic = 0%

The range in change scores for HbA1c for the comparison group, pioglitazone, was −1.3% to −0.2%. The median change was −0.7%.

Figure 9 is a forest plot for the meta-analysis of the mean difference in hemoglobin A1c comparing rosiglitazone with pioglitazone. There are 3 studies included in this meta-analysis: Khan 2002 with a mean difference of -.1 (95 percent CI -1.19 to .99), Goldberg 2005 with a mean difference of .1 (95 percent CI -.18 to .38), Vijay 2009 with a mean difference of .01 (95 percent CI -.73 to .75). Numbers greater than 0 favor the pioglitazone and numbers less than 0 favor rosiglitazone. The pooled mean difference was 0.08 percent (95 percent confidence interval -0.17 percent to 0.33 percent). There was no statistically significant heterogeneity across the studies.

Thiazolidinediones versus sulfonylureas. Both thiazolidinediones (TZDs) (pioglitazone and rosiglitazone) and second-generation sulfonylureas (glibenclamide, glimepiride, and glyburide) had similar effects on HbA1c, with a pooled mean difference between-groups of −0.1 percent (95 percent CI −0.2 percent to 0.01 percent) (Figure 10).41,50,51,53,100–108 When we combined the 3 out of 13 studies with comparable dosing,53,100,107 the results were similar with a weighted mean difference of −0.1 percent (95 percent CI −0.4 percent to 0.2 percent). In a standard sensitivity analysis which tests the relative influence of each individual study on the combined point estimate, we found that removal of one study influenced the pooled results. When the study by Hanefeld et al.100 was removed from the main meta-analysis, the pooled mean difference favored TZDs slightly, with a pooled mean difference between-groups of −0.1 percent (95 percent CI −0.2 percent to −0.004 percent). However, the study by Hanefeld et al100 is similar to the other studies, and should not be removed from the overall meta-analysis. No other single study influenced the results, and no substantial heterogeneity was found. Glipizide was the only second-generation sulfonylurea that was not evaluated in head-to-head trials with the thiazolidinediones.

Figure 10 Mean difference in HbA1c comparing thiazolidinediones with sulfonylureas

CI = confidence interval; diff = difference; HbA1c = hemoglobin A1c

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 7.07 with 12 degrees of freedom (p = 0.85)

I-squared statistic = 0%

The range in change scores for HbA1c for the comparison group, sulfonylureas, was −2.5% to 1.5%. The median change was −0.9%.

Figure 10 is a forest plot for the meta-analysis of the mean difference in hemoglobin A1c comparing thiazolidinediones with sulfonylureas. There are 13 studies included in this meta-analysis: Nakamura 2000 with a mean difference of 0.0 (95 percent CI -.81 to .81), Bakris 2003 with a mean difference of 0.0 (95 percent CI -.49 to .49), Lawrence 2004 with a mean difference of -.4 (95 percent CI -.85 to .05), Ramachandran 2004 with a mean difference of -.1 (95 percent CI -1.23 to 1.03), Tan 2004a with a mean difference of -.1 (95 percent CI -.56 to .36), Tan 2004b with a mean difference of -.1 (95 percent CI -.31 to .11), Nakamura 2004 with a mean difference of .2 (95 percent CI -1.01 to 1.41), Yamanouchi 2005 with a mean difference of -.2 (95 percent CI -.59 to .19), Pfuztner 2005 with a mean difference of -.2 (95 percent CI -.46 to .06), Jain 2006 with a mean difference of -.05 (95 percent CI -.42 to .32), Nakamura 2006 with a mean difference of -.8 (95 percent CI -4.18 to 2.58), Teramoto 2007 with a mean difference of .63 (95 percent CI -.32 to 1.58), Hanefeld 2007 with a mean difference of .2 (95 percent CI -.26 to .66). Numbers greater than 0 favor the sulfonylureas and numbers less than 0 favor thiazolidinediones. The pooled mean difference was -0.10 percent (95 percent confidence interval -0.22 percent to 0.01 percent). There was no statistically significant heterogeneity across the studies.

We excluded the ADOPT study from the meta-analysis due to the longer study duration (median followup of 4 years).38 As mentioned previously, this double-blind RCT evaluated the long-term glycemic control between metformin, rosiglitazone, and glyburide monotherapy as initial treatment for type 2 diabetic adults. The between-group difference between rosiglitazone and glyburide favored rosiglitazone after 4 years (mean difference between-groups of −0.4, 95 percent CI −0.5 percent to −0.3 percent). Of note, glyburide reduced HbA1c more than rosiglitazone initially. The HbA1c then rose higher in the glyburide arm compared with the rosiglitazone arm after 1.5 years.

Thiazolidinediones versus meglitinides. Two 24-week similar quality head-to-head trials compared thiazolidinediones with repaglinide specifically, and showed no consistent effects favoring one of the medications.109,110 These inconsistent results may be due to different thiazolidinediones, or different dosing. One study with slightly lower doses of pioglitazone (30 mg fixed dose) versus upward titration of repaglinide to a maximum of 12 mg per day favored repaglinide monotherapy (between-group difference of 0.5 percent).110 The other study with more comparable dosing between rosiglitazone and repaglinide favored rosiglitazone with a between-group difference of 0.39 percent.109

A one-year RCT compared pioglitazone with nateglinide at comparable doses, and reported similar reductions in HbA1c in each arm (−1.6 percent and −1.4 percent respectively).108

Sulfonylureas versus DPP-4 inhibitors. One double-blind moderately sized RCT directly compared four doses of sitagliptin to glipizide upward titrated to 20 mg daily.111 After 12 weeks, both high dose sitagliptin (100 mg per day) and glipizide (maximum dose of 20 mg per day) similarly reduced HbA1c (−0.77 percent versus −1.00 percent respectively), with overlapping confidence intervals for the placebo-subtracted change from baseline in each group. A small absolute dose-response relationship was reported but it was not statistically significant.

Sulfonylureas versus meglitinides. Seven RCTs compared a second-generation sulfonylurea with repaglinide, showing a pooled between-group difference of 0.1 percent (95 percent CI −0.2 percent to 0.3 percent) (Figure 11).112–118 No single study markedly influenced these results nor was there substantial heterogeneity among the studies. There were no differences in results when only evaluating the studies using comparable doses.113,117,118

Figure 11 Mean difference in HbA1c comparing sulfonylureas with meglitinides

CI = confidence interval; diff = difference; HbA1c = hemoglobin A1c

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 10.548 with 6 degrees of freedom (p = 0.10)

I-squared statistic = 43%

The range in change scores for HbA1c for the comparison group, meglitinides, was −1.2% to 0.58%. The median change was −0.2%.

Figure 11 is a forest plot for the meta-analysis of the mean difference in hemoglobin A1c comparing sulfonylureas with meglitinides. There are 7 studies included in this meta-analysis: Wolffenbuttel 1993 with a mean difference of 0.0 (95 percent CI -1.21 to 1.21), Marbury 1999 with a mean difference of .02 (95 percent CI -.23 to .27), Landgraf 1999 with a mean difference of -.1 (95 percent CI -.38 to .18), Wolffenbuttel 1999 with a mean difference of -.13 (95 percent CI -.42 to .16), Madsbad 2001 with a mean difference of .59 (95 percent CI .21 to .97), Derosa 2003 with a mean difference of .1 (95 percent CI -3.72 to 3.92), Jibran 2006 with a mean difference of .3 (95 percent CI -.84 to 1.44). Numbers greater than 0 favor the meglitinides and numbers less than 0 favor sulfonylureas. The pooled mean difference was 0.07 percent (95 percent confidence interval -0.15 percent to 0.29 percent). There was no statistically significant heterogeneity across the studies.

Two short-duration RCTs compared a slightly under-dosed glibenclamide arm with nateglinide at somewhat higher doses, showing no significant differences between groups (range in non-significant between-group differences of −0.5 percent to −0.2 percent).108,119 We did not include these studies in a meta-analysis due to potential differences in glycemic control between nateglinide and repaglinide.

Sulfonylurea versus GLP-1 agonists. Three RCTs compared sulfonylureas directly with liraglutide with conflicting results. We did not combine these trials in a meta-analysis due to dosing differences within and between studies. One comparably dosed small RCT reported no statistically significant differences between the two arms.120 The two other larger RCTs favored the liraglutide arm,121,122 yet one of these studies underdosed the sulfonylurea arm compared with the liraglutide arm making it difficult to discern true drug differences versus dosing differences.121

Combination of metformin and thiazolidinediones versus combination of metformin and sulfonylureas. Six comparably dosed shorter duration RCTs directly compared the combination of metformin plus a thiazolidinedione with metformin plus a sulfonylurea, showing a pooled mean difference in HbA1c between groups of −0.1 percent (95 percent CI −0.2 percent to 0.1 percent) (Figure 12).123–128 No single study markedly influenced the results, and no substantial heterogeneity was found. We excluded two studies due to inconsistent dosing within arms of the study and therefore between them and the rest of the studies.46,129 Both studies underdosed the metformin in the metformin plus sulfonylurea arms, and found between-group differences in HbA1c favoring the metformin plus thiazolidinedione arms (−0.3 percent in both studies). A sensitivity analysis including both these studies in the meta-analysis showed no differences between-groups but increases the heterogeneity between studies markedly.

Figure 12 Mean difference in HbA1c comparing combination of metformin and thiazolidinediones with combination of metformin and sulfonylureas

CI = confidence interval; diff = difference; HbA1c = hemoglobin A1c; Met = metformin; SU = sulfonylurea; TZD = thiazolidinedione

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 7.45 with 5 degrees of freedom (p = 0.19)

I-squared statistic = 33%

The range in change scores for HbA1c for the comparison group, a combination of metformin and sulfonylurea, was −1.5% to 0.9%. The median change was −0.9%.

Figure 12 is a forest plot for the meta-analysis of the mean difference in hemoglobin A1c comparing a combination of metformin and thiazolidinediones with a combination of metformin and sulfonylureas. There are 6 studies included in this meta-analysis: Derosa 2005 with a mean difference of -.3 (95 percent CI -.75 to .15), Bakris 2006 with a mean difference of -.2 (95 percent CI -.45 to .05), Umpierrez 2006 with a mean difference of .07 (95 percent CI -.14 to .28), Garber 2006 with a mean difference of .4 (95 percent CI -.08 to .88), Home 2007 with a mean difference of -.07 (95 percent CI -.23 to .09), Hamann 2008 with a mean difference of -.09 (95 percent CI -.26 to .08). Numbers greater than 0 favor the combination of metformin and sulfonylurea and numbers less than 0 favor the combination of metformin and thiazolidinediones. The pooled mean difference was -0.06 percent (95 percent confidence interval -0.17 percent to 0.06 percent). There was no statistically significant heterogeneity across the studies.

In the meta-analysis, we included the shorter duration RECORD study since the study duration was more comparable to the other included studies.124 The RECORD study was a multicenter open label RCT evaluating 4447 patients with type 2 diabetes and uncontrolled glycemia already on metformin or sulfonylurea monotherapy.16,124 They randomly assigned subjects to addition of rosiglitazone or to a combination of metformin and sulfonylurea, and the primary endpoint was cardiovascular hospitalization or cardiovascular death. They reported glycemic control at a mean of 18 months and 5.5 years after study start.16,124 The between-group difference in HbA1c of −0.07 percent was small and not significant in the 516 subjects with 18-month followup.124 In the article reporting on the mean followup of 5.5 years in 2,222 subjects, the between-group difference in HbA1c of −0.29 percent significantly favored metformin plus rosiglitazone over metformin plus sulfonylurea.16 However, it is unclear whether these mild differences in glycemic control affect cardiovascular outcomes. While the RECORD study reported cardiovascular outcomes in the rosiglitazone arm versus active control showing no statistically significant differences between groups, they did not break it out further into specific drug combination comparisons.16

Combination of metformin and thiazolidinediones versus combination of metformin and DPP-4 inhibitors. Two short-duration RCTs compared metformin plus rosiglitazone with the combination of metformin plus sitagliptin, showing similar reductions in HbA1c in each arm. One double-blind study with comparable dosing of the medications showed no between-group differences in HbA1c (mean difference of −0.1 percent, 95 percent CI −0.3 percent to 0.1 percent).85 The other RCT compared a submaximally dosed metformin plus rosiglitazone arm to a maximally dosed metformin plus sitagliptin arm, and showed similar reductions in HbA1c after 16 weeks (−0.6 percent in rosiglitazone combination arm versus −0.4 percent in sitagliptin combination arm).130

Combination of metformin and thiazolidinediones versus combination of metformin and meglitinides. One RCT lasting 26 weeks compared metformin plus rosiglitazone twice daily with the combination of metformin plus repaglinide twice daily and three times daily, showing no significant between-group differences.131

Combination of metformin and thiazolidinediones versus combination of metformin and GLP-1 agonists. One 20-week RCT with comparable dosing of medications compared the combination of metformin and rosiglitazone with the combination of metformin and exenatide, showing no significant between-group differences in HbA1c (between-group difference of −0.1 percent, p = 0.7).132

Combination of metformin and thiazolidinediones versus combination of thiazolidinediones and sulfonylureas. One small RCT conducted a post hoc analysis comparing the combination of pioglitazone added to either existing metformin or existing sulfonylurea, favoring the pioglitazone plus sulfonylurea combination arm by 0.03 percent (p = 0.04).129

Combination of metformin and sulfonylureas versus combination of metformin and DPP-4 inhibitors. One double-blinded moderately sized RCT compared fixed dose metformin plus sulfonylurea (mean dose of sulfonylurea was 10 mg) with the combination of fixed dose metformin plus fixed dose sitagliptin (100 mg), showing no between group-differences in HbA1c after 1 year (mean between-group difference of −0.01 percent, 95 percent CI −0.1 percent to 0.1 percent).133 This RCT was extended a second year and continued to show no statistically significant between-group differences in HbA1c.134

Combination of metformin and sulfonylureas versus combination of metformin and meglitinides. Two moderately sized double-blinded RCTs lasting 1 to 2 years directly compared the combination of metformin plus sulfonylurea with metformin plus nateglinide showing conflicting results.135,136 These differences may reflect differences in dosing. The first RCT compared the combination of metformin (mean dose 2,500 mg) plus glibenclamide (mean dose 12.5 mg) with metformin (mean dose 2,500 mg) plus nateglinide (mean dose 300 mg), and significantly favored the slightly higher dosed metformin plus nateglinide combination arm, with a between-group difference of 0.8 percent.135 The second RCT showed no significant difference between groups (between-group difference of −0.3 percent) despite the higher dosed metformin plus nateglinide arm.136

Combination of metformin and sulfonylureas versus combination of metformin and GLP-1 agonists. Two RCTs compared metformin plus sulfonylurea with metformin plus a GLP-1 agonist with conflicting results. One small comparably dosed RCT lasting a year compared the combination of metformin and glibenclamide with the combination of metformin and exenatide, reporting no significant between-group differences in HbA1c (between-group difference of −0.3 percent, p > 0.05).44 A second comparably dosed medium-sized RCT directly compared the combination of metformin and glimepiride with two different dosing arms of the combination of metformin and liraglutide (titrated to a maximum dose of 1.2 mg of liraglutide in one combination arm and 1.8 mg in a second liraglutide combination arm).92 Both dosing comparisons showed greater reductions in HbA1c in the metformin plus liraglutide arms (between-group differences of −1.1 percent, 95 percent CI −1.3 percent to −0.9 percent for both arms). No dose-response gradient was reported. It is unclear whether the differences were due to differences in study medications, study duration, or other study characteristics.

Combination of metformin and sulfonylureas versus combination of metformin and premixed insulin. Two 16-week RCTs compared metformin plus glibenclamide with the combination of metformin plus a premixed insulin analogue-insulin aspart 70/30 in one study and insulin lispro 75/25 in the other study, showing different results.137,138 These differences may have been due to differences in dosing of the medications. The RCT137 that showed no significant between-group differences in HbA1c (−0.11 percent, p = 0.238) reported their mean total dose for each combination arm, while the other RCT which significantly favored the metformin plus premixed insulin analogue (insulin aspart 70/30) arm over the metformin plus sulfonylurea arm (between-group difference of 0.46 percent, p = 0.027) did not clearly report mean total or maximum doses.138 Another possible difference may have been the type of premixed insulin analogue.

Combination of metformin and sulfonylureas versus combination of thiazolidinediones and sulfonylureas. Six similar RCTs directly compared the combination of metformin and sulfonylurea with the combination of thiazolidinediones and sulfonylurea, showing no between-group differences in HbA1c (pooled between-group difference of −0.1 percent, 95 percent CI −0.2 percent to 0.01 percent) (Figure 13).42,124,129,139–141 No one study markedly influenced the results, and these studies showed no significant heterogeneity.

Figure 13 Mean difference in HbA1c comparing combination of metformin and sulfonylureas with combination of thiazolidinediones and sulfonylureas

CI = confidence interval; diff = difference; HbA1c = hemoglobin A1c; Met = metformin; SU = sulfonylurea; TZD = thiazolidinedione

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 1.37 with 5 degrees of freedom (p = 0.93)

I-squared statistic = 0%

The range in change scores for HbA1c for the comparison group, a combination of thiazolidinediones and sulfonylureas, was −1.3% to 0.6%. The median change was −1.1%.

Figure 13 is a forest plot for the meta-analysis of the mean difference in hemoglobin A1c comparing a combination of metformin and sulfonylureas with a combination of thiazolidinediones and sulfonylureas. There are 6 studies included in this meta-analysis: Yang 2003 with a mean difference of .14 (95 percent CI -.8 to 1.08), Hanefeld 2004 with a mean difference of -.16 (95 percent CI -.33 to .01), Comaschi 2007 with a mean difference of .01 (95 percent CI -.52 to .54), Home 2007 with a mean difference of -.06 (95 percent CI -.21 to .09), Kim 2007 with a mean difference of 0.0 (95 percent CI -.46 to .46), van der Meer 2009 with a mean difference of -.1 (95 percent CI -.72 to .52). Numbers greater than 0 favor the combination of thiazolidinedione and sulfonylurea and numbers less than 0 favor the combination of metformin and thiazolidinedione. The pooled mean difference was -0.09 percent (95 percent confidence interval -0.19 percent to 0.01 percent). There was no statistically significant heterogeneity across the studies.

We excluded two articles from the meta-analysis with longer study durations16,142 since both studies had other articles in the meta-analysis that presented the shorter term glycemic results124,140 which were more comparable to the other RCTs. The RECORD study was a multicenter open label RCT evaluating 4,447 patients with type 2 diabetes and uncontrolled glycemia already on metformin or sulfonylurea monotherapy.16,124 They randomly assigned subjects to addition of rosiglitazone or to a combination of metformin and sulfonylurea, with a primary endpoint of cardiovascular hospitalization or cardiovascular death. They reported glycemic control at a mean of 18 months and 5.5 years after study start.16,124 The between-group difference in HbA1c of −0.06 percent was small and not significant in the 573 subjects with 18-month followup.124 In the article reporting on the mean followup of 5.5 years in 2,225 subjects, the between-group difference in HbA1c of 0.26 percent significantly favored rosiglitazone plus sulfonylurea over metformin plus sulfonylurea.16 However, it is unclear whether these mild differences in glycemic control affect cardiovascular outcomes. While the RECORD study reported cardiovascular outcomes in the rosiglitazone arm versus active control showing no statistically significant differences between-groups, they did not break it out further into specific drug-drug combination comparisons.16

The second RCT excluded was a 2-year followup142 of the 1-year study140 presented in the meta-analysis. Both articles presented similar between-group differences in HbA1c between the combination of thiazolidinedione plus sulfonylurea and metformin plus sulfonylurea (nonsignificant between-group differences of −0.16 percent and −0.13 percent).

Combination of metformin and DPP-4 inhibitors versus combination of metformin and GLP-1 agonists. One 26-week RCT with comparable dosing of medications directly compared the combination of metformin and sitagliptin with the combination of metformin and liraglutide in 2 dosing arms (maximum dose liraglutide 1.2 mg in one arm and 1.8 mg in the second combination arm), showing statistically significant greater reductions in HbA1c in the metformin and liraglutide combination arms.143 The between-group differences in HbA1c ranged from −0.34 percent when compared with the lower dosed liraglutide combination arm to −0.60 percent when compared with the higher dosed liraglutide combination arm.143

Combination of metformin and GLP-1 agonists versus combination of metformin and basal insulin. One small 56-week RCT compared the combination of metformin and exenatide with the combination of metformin and glargine insulin, showing similar reductions in HbA1c (between-group difference of −0.1 percent).144 The exenatide combination arm had about 25 percent of their subjects on higher than the maximum recommended dose of exenatide.

Combination of metformin and basal insulin versus combination of metformin and premixed insulin. Three RCTs directly compared the combination of metformin plus basal insulin with the combination of metformin plus premixed insulin, showing no between-group differences in HbA1c (pooled between-group difference of 0.3 percent, 95 percent CI −0.3 percent to 0.9 percent) (Figure 14).145–147 No single study strongly influenced the results, and no substantial heterogeneity was found.

Figure 14 Mean difference in HbA1c comparing combination of metformin and basal insulin with combination of metformin and premixed insulin

CI = confidence interval; diff = difference; HbA1c = hemoglobin A1c; Met = metformin

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.003 with 2 degrees of freedom (p = 0.99)

I-squared statistic = 0%

The range in change scores for HbA1c for the comparison group, combination metformin and premixed insulin, was −2.9% to 0.7%. The median change was −1.1%.

Figure 14 is a forest plot for the meta-analysis of the mean difference in hemoglobin A1c comparing a combination of metformin and basal insulin with a combination of metformin and premixed insulin. There are 3 studies included in this meta-analysis: Robbins 2007 with a mean difference of .3 (95 percent CI -.32 to .92), Raskin 2007 with a mean difference of .43 (95 percent CI -4. to 4.86), Davies 2007 with a mean difference of .3 (95 percent CI -1.05 to 1.65). Numbers greater than 0 favor the combination of metformin and premixed insulin and numbers less than 0 favor the combination of metformin and basal insulin. The pooled mean difference was 0.30 percent (95 percent confidence interval -0.26 percent to 0.86 percent). There was no statistically significant heterogeneity across the studies.

### The Evidence About Weight (Appendix G, Table 4)

Metformin versus thiazolidinediones. Eight RCTs lasting around a year or less directly compared metformin versus thiazolidinedione favoring metformin, with a pooled mean between group difference of −2.6 kg (95 percent CI −4.1 kg to −1.2 kg) (see Figure 15).47–49,51,52,54,55,148 All the metformin arms had small decreases in weight while the thiazolidinedione arms had mild increases in weight except for two studies.48,51 No single study markedly influenced the results. There was significant heterogeneity, yet we felt comfortable combining these studies since almost all the point estimates favored metformin. Meta-regression suggested that differences in baseline weight between studies (p = 0.07) may have contributed to the heterogeneity. We excluded two studies from the meta-analysis that had consistent results favoring metformin, since the median study duration was 4 years for one study38 and no measure of variability was reported for the second study.56 The 4-year double-blind RCT (known as the ADOPT study) was designed to compare long-term glycemic control between metformin, rosiglitazone, and glyburide monotherapy as initial treatment for diabetic adults, where weight was evaluated as a secondary outcome. The between-group difference in weight was −6.9 kg (95 percent CI −6.3 kg to −7.4 kg) favoring metformin. The second shorter duration RCT reported weight gain (1.6 kg) with pioglitazone and weight loss (−1.3 kg) with metformin, but no measures of variability.56

Figure 15 Mean difference in weight comparing metformin with thiazolidinediones

CI = confidence interval; diff = difference; kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 46.51 with 7 degrees of freedom (p = 0.0000)

I-squared statistic = 85%

The range in change scores for weight for the comparison group, thiazolidinediones, was −2 kg to 2.4 kg. The median change was −0.3 kg.

Figure 15 is a forest plot for the meta-analysis of the mean difference in weight comparing a metformin with thiazolidinediones. There are 8 studies included in this meta-analysis: Hallsten 2002 with a mean difference of -2.6 (95 percent CI -9.5 to 4.3), Pavo 2003 with a mean difference of -3.1 (95 percent CI -3.9 to -2.3), Schernthaner 2004 with a mean difference of 0.0 (95 percent CI -1.8 to 1.8), Ramachandran 2004 with a mean difference of .4 (95 percent CI -5.6 to 6.4), Natali 2004 with a mean difference of -1.1 (95 percent CI -2.1 to -.1), Rosenstock 2006 with a mean difference of -4.4 (95 percent CI -5.9 to -2.9), Iliadis 2007 with a mean difference of -2.2 (95 percent CI -4.4 to 0.0), Gupta 2009 with a mean difference of -5.4 (95 percent CI -6.5 to -4.2). Numbers greater than 0 favor thiazolidinediones and numbers less than 0 favor the metformin. The pooled mean difference was -2.61 kg (95 percent confidence interval -4.06 kg to -1.16 kg). There was statistically significant heterogeneity across the studies.

Metformin versus sulfonylureas. We combined 12 studies comparing metformin with a second-generation sulfonylurea, with a pooled mean difference of −2.7 kg (95 percent CI −3.5 kg to −1.9 kg) favoring metformin (Figure 16).51,61–71 We stratified the meta-analyses based on study duration (less than 24 weeks and more than 24 weeks) since this may have been a source of the heterogeneity between studies. The longer studies had slightly larger between-group differences in weight. In eight studies with less than 24 weeks duration, studies favored metformin with a pooled between-group difference of −1.9 kg (95 percent CI −2.5 kg to −1.4 kg) (Figure 17).51,61–66,71 Four studies lasting 24 weeks or longer were combined and favored metformin, with a pooled between-group difference of −3.6 kg (95 percent CI −4.1 kg to −3.1 kg) (Figure 18).67–70 Heterogeneity tests were not significant once we stratified the meta-analyses by study duration.

Figure 16 Mean difference in weight comparing metformin with sulfonylureas

CI = confidence interval; diff = difference; kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 22.64 with 11 degrees of freedom (p = 0.02)

I-squared statistic = 51%

The range in change scores for weight for the comparison group, sulfonylureas, was −0.3 kg to 2.67 kg. The median change was 1.6 kg.

Figure 16 is a forest plot for the meta-analysis of the mean difference in weight comparing metformin with sulfonylureas. There are 12 studies included in this meta-analysis: Hermann 1991 with a mean difference of -3.7 (95 percent CI -12.4 to 5.), Hermann 1994 with a mean difference of -4.4 (95 percent CI -6.1 to -2.7), Campbell 1994 with a mean difference of -4.6 (95 percent CI -13.8 to 4.6), DeFronzo 1995 with a mean difference of -3.5 (95 percent CI -4.1 to -2.9), Amador-Licona 2000 with a mean difference of -2.0 (95 percent CI -9.3 to 5.3), Charpentier 2001 with a mean difference of -1.5 (95 percent CI -2.3 to -.8), Blonde 2002 with a mean difference of -2.5 (95 percent CI -6.1 to 1.1), Marre 2002 with a mean difference of -1.7 (95 percent CI -6.2 to 2.8), Garber 2002 with a mean difference of -2.3 (95 percent CI -5.6 to 1.), Garber 2003 with a mean difference of -3.1 (95 percent CI -6.6 to .4), Goldstein 2003 with a mean difference of -2.3 (95 percent CI -3.1 to -1.5), Ramachandran 2004 with a mean difference of -2.5 (95 percent CI -9. to 4.). Numbers greater than 0 favor sulfonylureas and numbers less than 0 favor the metformin. The pooled mean difference was -2.73 kg (95 percent confidence interval -3.53 kg to -1.93 kg). There was statistically significant heterogeneity across the studies.

Figure 17 Mean difference in weight comparing metformin with sulfonylureas among studies less than 24 weeks in duration

CI = confidence interval; diff = difference; kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 2.51 with 7 degrees of freedom (p = 0.93)

I-squared statistic = 0%

The range in change scores for weight for the comparison group, sulfonylureas, was −0.3 kg to 1.7 kg. The median change was 0.9 kg.

Figure 17 is a forest plot for the meta-analysis of the mean difference in weight comparing metformin with sulfonylureas among studies less than 24 weeks in duration. There are 8 studies included in this meta-analysis: Amador-Licona 2000 with a mean difference of -2.0 (95 percent CI -9.3 to 5.3), Charpentier 2001 with a mean difference of -1.5 (95 percent CI -2.3 to -.8), Blonde 2002 with a mean difference of -2.5 (95 percent CI -6.1 to 1.1), Marre 2002 with a mean difference of -1.7 (95 percent CI -6.2 to 2.8), Garber 2002 with a mean difference of -2.3 (95 percent CI -5.6 to 1.), Garber 2003 with a mean difference of -3.1 (95 percent CI -6.6 to .4), Goldstein 2003 with a mean difference of -2.3 (95 percent CI -3.1 to -1.5), Ramachandran 2004 with a mean difference of -2.5 (95 percent CI -9. to 4.). Numbers greater than 0 favor sulfonylureas and numbers less than 0 favor the metformin. The pooled mean difference was -1.93 kg (95 percent confidence interval -2.46 kg to -1.40 kg). There was no statistically significant heterogeneity across the studies.

Figure 18 Mean difference in weight comparing metformin with sulfonylureas among studies 24 weeks or longer in duration

CI = confidence interval; diff = difference; kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 1.04 with 3 degrees of freedom (p = 0.79)

I-squared statistic = 0%

The range in change scores for weight for the comparison group, sulfonylureas, was −0.3 kg to 3.3 kg. The median change was 2.7 kg.

Figure 18 is a forest plot for the meta-analysis of the mean difference in weight comparing metformin with sulfonylureas among studies 24 weeks or longer in duration. There are 4 studies included in this meta-analysis: Hermann 1991 with a mean difference of -3.7 (95 percent CI -12.4 to 5.), Hermann 1994 with a mean difference of -4.4 (95 percent CI -6.1 to -2.7), Campbell 1994 with a mean difference of -4.6 (95 percent CI -13.8 to 4.6), DeFronzo 1995 with a mean difference of -3.5 (95 percent CI -4.1 to -2.9). Numbers greater than 0 favor sulfonylureas and numbers less than 0 favor the metformin. The pooled mean difference was -3.59 kg (95 percent confidence interval -4.12 kg to -3.07 kg). There was no statistically significant heterogeneity across the studies.

The ADOPT study was excluded from the meta-analysis since the median followup was 4 years compared with the other shorter duration studies lasting less than a year, yet showed consistent results favoring metformin over glyburide (mean between-group difference in weight of −2.5 kg; 95 percent CI −2.0 kg to −3.1 kg).38 This double-blind RCT evaluated long-term glycemic control between metformin, rosiglitazone, and glyburide monotherapy as initial treatment for type 2 diabetic adults, where weight was a secondary end point. Metformin decreased weight over the study duration while glyburide increased weight in the first year followed by weight maintenance for the rest of the study.

The UKPDS,8,72,74 while consistent with the above meta-analysis, was excluded from this section of the report since they were allowed to add other diabetes medications to their initial monotherapy groups. We describe it here briefly since it is a well known study with the longest followup (up to 10 years). In the 3-year followup of UKPDS in the obese subjects from the primary diet failure and main randomization groups combined, the between-group difference was −2 kg, favoring metformin.74 In the 6-year followup in the primary diet failure group only, the between-group difference was −5 kg comparing obese subjects taking metformin with obese and nonobese subjects taking glibenclamide.72 In the 10-year followup comparing obese subjects on metformin with obese and nonobese subjects on glibenclamide, the between-group difference still favored metformin at −2 kg.8 None of these papers reported the statistical significance of these differences except as it relates to diet or insulin. Of note, most of the weight gain in the glibenclamide group occurred in the first 2 years, while metformin maintained weight in the first 2 years and then had some weight gain after that.8

Metformin versus DPP-4 inhibitors. Three short duration RCTs (reported in four articles) compared metformin with DPP-4 inhibitors, reporting greater reductions in weight with metformin (pooled between-group difference of −1.4 kg, 95 percent CI −1.8 kg to −1.0 kg) (Figure 19).75–78 No substantial heterogeneity was found in the meta-analysis, and no single study markedly influenced the results. Two studies used metformin compared with sitagliptin,76,77 and one study compared metformin with saxagliptin.78 One RCT was reported in two articles.75,76 The first article was a 24-week RCT,75 while the second article was the 30-week continuation study with a higher loss to followup.76 The higher dosed metformin arm had greater weight loss from baseline compared with the lower dose metformin arm. We included the 24-week study in the meta-analysis since the other two studies in the meta-analysis were both 24 weeks long.

Figure 19 Mean difference in weight comparing metformin with DPP-4 inhibitors

CI = confidence interval; diff = difference; DPP-4 inhibitor = dipeptidyl peptidase-4 inhibitor; kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 2.10 with 2 degrees of freedom (p = 0.35)

I-squared statistic = 5%

The range in change scores for weight for the comparison group, DPP-4 inhibitors, was −1.1 kg to 0.6 kg. The median change was −0.6 kg.

Figure 19 is a forest plot for the meta-analysis of the mean difference in weight comparing metformin with DPP-4 inhibitors. There are 3 studies included in this meta-analysis: Williams-Herman 2009 with a mean difference of -2.1 (95 percent CI -3.2 to -1.), Jadzinsky 2009 with a mean difference of -.5 (95 percent CI -5. to 4.), Aschner 2010 with a mean difference of -1.3 (95 percent CI -1.7 to -.9). Numbers greater than 0 favor DPP-4 inhibitors and numbers less than 0 favor the metformin. The pooled mean difference was -1.40 kg (95 percent confidence interval -1.80 kg to -1.00 kg). There was no statistically significant heterogeneity across the studies.

Metformin versus meglitinides. Two small comparably-dosed RCTs lasting about a year compared metformin with repaglinide, suggesting metformin may reduce weight compared with repaglinide (range in between-group differences from −2.0 kg to −3.4 kg).81,82 One study reported this difference as nonsignificant,81 and one reported only that there were significant differences from baseline in both arms.82 The small number of subjects may have precluded the ability to detect significant differences between groups.

Metformin versus a combination of metformin and thiazolidinediones. We combined five studies that directly compared metformin monotherapy with the combination of metformin plus a thiazolidinedione (mostly rosiglitazone), showing a pooled between-group difference in weight of −2.2 kg (95 percent CI −2.6 kg to −1.9 kg) favoring metformin (Figure 20).49,84,85,87,90 There was no significant heterogeneity between studies, and no single study markedly affected the results. All five studies showed that the metformin arms had weight loss while the combination arms had weight gain. One study reported only qualitatively that the metformin arm had relatively no weight change while the combination therapy arm had a significant increase in weight of 1.6 kg reported quantitatively.83 While consistent with the meta-analysis results, we did not have sufficient quantitative data to include it with the other studies. Another study was excluded from the meta-analysis since no measures of variability were reported; however, this study was consistent with the meta-analysis findings.56 The 24-week RCT reported weight gain (0.7 kg) with combination metformin and pioglitazone and weight loss (−1.3 kg) with metformin monotherapy.56

Figure 20 Mean difference in weight comparing metformin with combination metformin and thiazolidinediones

CI = confidence interval; diff = difference; kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 1.35 with 4 degrees of freedom (p = 0.85)

I-squared statistic = 0%

The range in change scores for weight for the comparison group, a combination of metformin and thiazolidinedione, was 0.7 kg to 1.7 kg. The median change was 1.5 kg.

Figure 20 is a forest plot for the meta-analysis of the mean difference in weight comparing metformin with a combination of metformin and thiazolidinediones. There are 5 studies included in this meta-analysis: Fonseca 2000 with a mean difference of -1.9 (95 percent CI -2.8 to -1.0), Bailey 2005 with a mean difference of -2.2 (95 percent CI -2.9 to -1.5), Rosenstock 2006 with a mean difference of -2.9 (95 percent CI -4.4 to -1.4), Scott 2008 with a mean difference of -2.3 (95 percent CI -2.9 to -1.7), Kaku 2009 with a mean difference of -2.2 (95 percent CI -4.3 to 0.0). Numbers greater than 0 favor the combination of metformin and thiazolidinediones and numbers less than 0 favor the metformin. The pooled mean difference was -2.24 kg (95 percent confidence interval -2.62 kg to -1.86 kg). There was no statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and sulfonylureas. Ten RCTs compared metformin with the combination of metformin plus a second-generation sulfonylurea favoring metformin monotherapy, with a pooled between-group difference of −2.3 kg (95 percent CI −3.3 kg to −1.2 kg) (Figure 21).61,62,64,65,68–71,91,92 No single study markedly influenced the results. While heterogeneity existed, all studies favored the metformin arm over the combination arm with minimal between-group differences among the studies. Studies with lower baseline weight appeared to have somewhat smaller between-group differences than studies with higher baseline weight.

Figure 21 Mean difference in weight comparing metformin with combination metformin and sulfonylureas

CI = confidence interval; diff = difference; kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 52.88 with 9 degrees of freedom (p = 0.0000)

I-squared statistic = 83%

The range in change scores for weight for the comparison group, a combination of metformin and sulfonylureas, was −0.3 kg to 1.9 kg. The median change was 0.7 kg.

Figure 21 is a forest plot for the meta-analysis of the mean difference in weight comparing metformin with a combination of metformin and sulfonylureas. There are 10 studies included in this meta-analysis: Hermann 1991 with a mean difference of -2.0 (95 percent CI -10.8 to 6.8), Hermann 1994 with a mean difference of -.6 (95 percent CI -1.9 to .7), DeFronzo 1995 with a mean difference of -4.2 (95 percent CI -4.8 to -3.6), Charpentier 2001 with a mean difference of -1.3 (95 percent CI -2.1 to -.6), Marre 2002 with a mean difference of -1.4 (95 percent CI -5.9 to 3.1), Garber 2002 with a mean difference of -2.5 (95 percent CI -6. to 1.), Garber 2003 with a mean difference of -2.7 (95 percent CI -6.2 to .8), Goldstein 2003 with a mean difference of -2.4 (95 percent CI -3.2 to -1.6), Feinglos 2005 with a mean difference of -2.1 (95 percent CI -9. to 4.8), Nauck 2009 with a mean difference of -2.5 (95 percent CI -3.2 to -1.8). Numbers greater than 0 favor the combination of metformin and sulfonylureas and numbers less than 0 favor metformin. The pooled mean difference was -2.26 kg (95 percent confidence interval -3.31 kg to -1.22 kg). There was statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and DPP-4 inhibitors. Three RCTs directly compared metformin with the combination of metformin plus a DPP-4 inhibitor, with a pooled between-group difference of −0.2 kg (95 percent CI −0.7 kg to 0.2 kg) (Figure 22).75,78,^8^5 No single study markedly influenced the results, and no substantial heterogeneity was found. Only three out of six studies had sufficient quantitative data to combine in a meta-analysis. The other three studies reported results that were consistent with the meta-analysis.85,94,95 One RCT was published twice, first with the 24-week RCT results75 and second as a 30-week continuation study.76 The 24-week study was included in the meta-analysis since the study duration was more similar to the other included studies. The 54-week results were consistent with the 24-week results, reporting a significant weight loss from baseline in both groups with overlapping confidence intervals or a non-significant between-group difference of 0.2 kg.76 They also showed a small dose-response effect in the combination arms, with the 2000 mg metformin and 100 mg sitagliptin arm reducing weight more than the 1000 mg metformin plus 100 mg sitagliptin arm (mean change from baseline −1.7 kg versus −0.7 kg respectively).

Figure 22 Mean difference in weight comparing metformin with combination metformin and DPP-4 inhibitors

CI = confidence interval; diff = difference; DPP-4 inhibitor = dipeptidyl peptidase-4 inhibitor; kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 1.16 with 2 degrees of freedom (p = 0.56)

I-squared statistic = 0%

The range in change scores for weight for the comparison group, a combination of metformin and DPP-4 inhibitors, was −1.1 kg to 0.6 kg. The median change was −0.4 kg.

Figure 22 is a forest plot for the meta-analysis of the mean difference in weight comparing metformin with a combination of metformin and DPP-4 inhibitors. There are 3 studies included in this meta-analysis: Scott with a mean difference of -.4 (95 percent CI -1. to .2), Williams-Herman 2009 with a mean difference of .2 (95 percent CI -.8 to 1.2), Jadzinsky 2009 with a mean difference of .2 (95 percent CI -4.3 to 4.7). Numbers greater than 0 favor the combination of metformin and DPP-4 inhibitors and numbers less than 0 favor metformin. The pooled mean difference was -0.24 kg (95 percent confidence interval -0.72 kg to 0.24 kg). There was no statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and meglitinides. Two RCTs compared metformin with combination of metformin plus meglitinides; both slightly favoring the monotherapy metformin arms.82–96 One small 3-month RCT compared metformin (mean dose 1800 mg) versus metformin (mean dose 1,800 mg) plus repaglinide (maximum titrated dose of 4 mg before meals), and reported qualitatively that weight remained stable in the metformin arm while increasing from baseline in the metformin plus repaglinide arm (3.0 kg ± 0.5 kg, p < 0.05).82 The second 24-week moderately sized study compared metformin with metformin plus nateglinide at two different doses, showing a statistically significant between-group difference in weight of 0.9 kg favoring metformin monotherapy when compared with the higher dosed metformin plus nateglinide arm (120 mg three times daily). No significant difference was reported when metformin was compared with the metformin plus lower dose nateglinide (60 mg three times daily).96

Rosiglitazone versus pioglitazone. Three RCTS with similar dosing of medications compared rosiglitazone with pioglitazone, and showed no significant between-group differences in weight, with a pooled between-group difference of −0.4 kg (95 percent CI −0.8 kg to 0.0 kg) (Figure 23).97–99 No one study significantly influenced the results, and no substantial heterogeneity was found. All three short-duration studies showed an increase in weight from baseline, ranging from 0.7 kg to 2 kg for both thiazolidinediones.

Figure 23 Mean difference in weight comparing rosiglitazone with pioglitazone

CI = confidence interval; diff = difference; kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.02 with 2 degrees of freedom (p = 0.99)

I-squared statistic = 0%

The range in change scores for weight for the comparison group, pioglitazone, was 1.2 kg to 2.0 kg. The median change was 2.0 kg.

Figure 23 is a forest plot for the meta-analysis of the mean difference in weight comparing rosiglitazone with pioglitazone. There are 3 studies included in this meta-analysis: Khan 2002 with a mean difference of 0.0 (95 percent CI -14.8 to 14.8), Goldberg 2005 with a mean difference of -.4 (95 percent CI -1. to .2), Vijay 2009 with a mean difference of -.5 (95 percent CI -1.1 to .2). Numbers greater than 0 favor pioglitazone and numbers less than 0 favor rosiglitazone. The pooled mean difference was -0.42 kg (95 percent confidence interval -0.84 kg to 0.0 kg). There was no statistically significant heterogeneity across the studies.

Thiazolidinediones versus sulfonylureas. Five studies lasting a year or less compared a thiazolidinedione to a second-generation sulfonylurea, showing higher weight gain in the thiazolidinedione arms, with a pooled between-group difference of 1.2 kg (95 percent CI 0.6 kg to 1.9 kg) (Figure 24).51,100,101,106,149 One study showed a dose response relationship between rosiglitazone and weight; patients treated with rosiglitazone (4 mg per day) gained 1.8 kg and those treated with 8 mg per day gained 3.0 kg over 52 weeks compared with the glibenclamide arm which gained 1.9 kg.100 No single study markedly influenced the results, and no substantial heterogeneity was found.

Figure 24 Mean difference in weight comparing thiazolidinediones with sulfonylureas

CI = confidence interval; diff = difference; kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 3.16 with 4 degrees of freedom (p = 0.53)

I-squared statistic = 0%

The range in change scores for weight for the comparison group, sulfonylureas, was 1.1 kg to 3.4 kg. The median change was 1.9 kg.

Figure 24 is a forest plot for the meta-analysis of the mean difference in weight comparing thiazolidinediones with sulfonylureas. There are 5 studies included in this meta-analysis: StJohnSutto 2002 with a mean difference of 1.6 (95 percent CI .2 to 3.), Ramachandran 2004 with a mean difference of -2.9 (95 percent CI -8.4 to 2.6), Tan 2004 with a mean difference of 1.9 (95 percent CI -2.8 to 6.6), Jain 2006 with a mean difference of 1.7 (95 percent CI .3 to 3.1), Hanefeld 2007 with a mean difference of 1.1 (95 percent CI .3 to 1.8). Numbers greater than 0 favor sulfonylureas and numbers less than 0 favor thiazolidinediones. The pooled mean difference was 1.24 kg (95 percent confidence interval 0.63 kg to 1.85 kg). There was no statistically significant heterogeneity across the studies.

We excluded two RCTs from the meta-analysis due to the longer study duration of 3 to 4 years.38,150 Both RCTs had results that were consistent with the meta-analysis. As mentioned previously, the ADOPT study was a double-blind RCT evaluating the long-term glycemic control between metformin, rosiglitazone, and glyburide monotherapy as initial treatment for type 2 diabetic adults, with weight as a secondary outcome.38 The between-group difference between rosiglitazone and glyburide was consistent with the results of the meta-analysis of the shorter duration studies favoring sulfonylureas after an estimated 5 years of followup (mean difference between-groups of 2.5 kg, 95 percent CI 2.0 kg to 3.1 kg). Of note, the glyburide arm showed increased weight over the first year when weight began to stabilize, while the rosiglitazone arm had continued weight gain over the course of the study. The second large 3-year multicenter study comparing pioglitazone and glibenclamide showed a 5.2 kg weight gain in the pioglitazone-treated group and a 0.9 kg weight gain in the glibenclamide-treated group.150

Thiazolidinediones versus meglitinides. Two 24-week non-blinded RCTs compared thiazolidinediones with repaglinide specifically, and both reported slightly greater weight gain in the thiazolidinedione groups (range in between-group differences of 0.7 to 1.7 kg, no measures of variability reported).109,110

Sulfonylureas versus DPP-4 inhibitors. One double-blind moderately sized RCT directly compared four doses of sitagliptin to glipizide, showing a potential benefit in weight of sitagliptin over glipizide.111 After 12 weeks, the high dose sitagliptin arm (100 mg a day) showed a nonsignificant between-group difference comparing sitagliptin with placebo of 0.4 kg (95 percent CI −0.2 kg to 0.9 kg) while the glipizide (maximum dose: 20 mg a day) arm showed a significant between-group difference compared with placebo of 1.3 kg (95 percent CI 0.8 kg to 1.8 kg). The study did not report the direct between-group differences in weight.

Sulfonylureas versus meglitinides. Six RCTs compared weight between a second-generation sulfonylurea and repaglinide showing no differences between groups, with a pooled between-group difference of 0.01 kg (95 percent CI −1.0 kg to 1.0 kg) (Figure 25).112,113,115–118 Heterogeneity tests were not significant, and no single study markedly influenced this result. Most studies showed no change in weight in both treatment arms.

Figure 25 Mean difference in weight comparing sulfonylureas with meglitinides

CI = confidence interval; diff = difference; kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 1.15 with 5 degrees of freedom (p = 0.95)

I-squared statistic = 0%

The range in change scores for weight for the comparison group, meglitinides, was −1.7 kg to 0.2 kg. The median change was −0.1 kg.

Figure 25 is a forest plot for the meta-analysis of the mean difference in weight comparing sulfonylureas with meglitinides. There are 6 studies included in this meta-analysis: Wolffenbuttel 1993 with a mean difference of 1.3 (95 percent CI -5.1 to 7.7), Wolffenbuttel 1999 with a mean difference of .7 (95 percent CI -2.2 to 3.6), Marbury 1999 with a mean difference of .3 (95 percent CI -1.1 to 1.7), Landgraf 1999 with a mean difference of -.7 (95 percent CI -4. to 2.6), Derosa 2003 with a mean difference of -.6 (95 percent CI -2.5 to 1.3), Jibran 2006 with a mean difference of -1.2 (95 percent CI -10.1 to 7.7). Numbers greater than 0 favor meglitinides and numbers less than 0 favor sulfonylureas. The pooled mean difference was 0.01 kg (95 percent confidence interval -0.97 kg to 0.99 kg). There was no statistically significant heterogeneity across the studies.

Sulfonylureas versus GLP-1 agonists. Three RCTs comparing sulfonylureas directly with liraglutide showed greater weight gain with sulfonylurea (pooled between-group difference of 2.5 kg, 95 percent CI 1.2 kg to 3.8 kg) (Figure 26).120–122 No single study strongly influenced the results. Substantial heterogeneity was found. Metaregression found statistically significant differences due to drug dosing (p = 0.017). Given the low power of metaregression when only 3 studies are evaluated, other characteristics such as study duration may have partly explained the heterogeneity (p = 0.15). The one study with the largest between-group difference in weight122 lasted at least 24 weeks longer than the other two studies. Additionally, one of the two studies with a lower between-group difference under-dosed the sulfonylurea arm121 while the study with more comparable and higher drug doses had a larger between-group difference. All three studies however showed weight gain with sulfonylureas and weight loss with liraglutide when compared with baseline weight.

Figure 26 Mean difference in weight comparing sulfonylureas with GLP-1 agonists

CI = confidence interval; diff = difference; GLP-1 agonists = glucagon-like peptide-1 agonists; kg = kilogram

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 28.23 with 2 degrees of freedom (p = 0.00)

I-squared statistic = 93%

The range in change scores for weight for the comparison group, GLP-1 agonist, was −2.5 kg to 1.0 kg. The median change was −0.7 kg.

Figure 26 is a forest plot for the meta-analysis of the mean difference in weight comparing sulfonylureas with GLP-1 agonists. There are 3 studies included in this meta-analysis: Madsbad 2004 with a mean difference of 1.7 (95 percent CI -.3 to 3.6), Garber 2009 with a mean difference of 3.5 (95 percent CI 3.1 to 3.9), Seino 2010 with a mean difference of 1.9 (95 percent CI 1.5 to 2.3). Numbers greater than 0 favor GLP-1 agonists and numbers less than 0 favor sulfonylureas. The pooled mean difference was 2.48 kg (95 percent confidence interval 1.15 kg to 3.82 kg). There was statistically significant heterogeneity across the studies.

Combination of metformin and thiazolidinediones versus combination of metformin and sulfonylureas. We combined five studies that directly compared metformin plus a thiazolidinedione to metformin plus a sulfonylurea favoring the combination of metformin plus sulfonylurea, with a pooled between-group difference of 0.9 kg (95 percent CI 0.4 kg to 1.3 kg) (Figure 27).123–126,151 No one study markedly influenced the results, and no substantial heterogeneity was found.

Figure 27 Mean difference in weight comparing combination metformin and thiazolidinediones with combination metformin and sulfonylureas

CI = confidence interval; diff = difference; kg = kilogram; Met = metformin; SU = sulfonylureas; TZD = thiazolidinediones

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 3.41 with 4 degrees of freedom (p = 0.49)

I-squared statistic = 0%

The range in change scores for weight for the comparison group, a combination of metformin and sulfonylureas, was −4.5 kg to 1.7 kg. The median change was 1.5 kg.

Figure 27 is a forest plot for the meta-analysis of the mean difference in weight comparing the combination of metformin and thiazolidinediones with the combination of metformin and sulfonylureas. There are 5 studies included in this meta-analysis: Derosa 2005 with a mean difference of 1.4 (95 percent CI -1. to 3.8), Bakris 2006 with a mean difference of .4 (95 percent CI -.8 to 1.7), Umpierrez 2006 with a mean difference of .1 (95 percent CI -1. to 1.2), Home 2007 with a mean difference of 1.2 (95 percent CI .4 to 2.), Hamann 2008 with a mean difference of 1.1 (95 percent CI .3 to 1.9). Numbers greater than 0 favor the combination of metformin and sulfonylureas and numbers less than 0 favor the combination of metformin and thiazolidinediones. The pooled mean difference was 0.88 kg (95 percent confidence interval 0.41 kg to 1.34 kg). There was no statistically significant heterogeneity across the studies.

In the meta-analysis, we included the shorter duration RECORD study since the study duration was more comparable to the other included studies.124 The RECORD study was a multicenter open label RCT evaluating 4447 patients with type 2 diabetes and uncontrolled glycemia already on metformin or sulfonylurea monotherapy.16,124 Body weight was increased significantly with rosiglitazone plus metformin compared to sulfonylurea plus metformin, with a mean difference between-groups of 1.2 kg (95 percent CI 0.4 kg to 2.0 kg) after 18 months124 which increased to 3.8 kg after 5 years of followup.16

We excluded one short duration RCT from the meta-analysis since the dosing was not comparable to the other studies, which likely explains its conflicting results.128 This RCT used a lower dose of metformin in the metformin plus sulfonylurea arm compared with a higher dose of metformin in the metformin plus thiazolidinedione arm. Since metformin has been shown to reduce or maintain weight compared with most other monotherapy diabetes medications, a higher dose of metformin in the thiazolidinedione combination arm would bias the results in favor of that combination.

Combination of metformin and thiazolidinediones versus combination of metformin and DPP-4 inhibitors. Two short duration RCTs compared metformin plus rosiglitazone with the combination of metformin plus sitagliptin, showing weight loss in the metformin plus sitagliptin arms and weight gain in the metformin plus thiazolidinedione arms. Neither study reported on the between-group difference in weight, only on the difference from baseline for each arm. In one study, the metformin plus rosiglitazone arm had an increase in weight from baseline of 1.5 kg (95 percent CI 1.0 kg to 1.9 kg) while the metformin plus sitagliptin arm had a decrease in weight from baseline of −0.4 kg (95 percent CI −0.8 kg to 0.0 kg).85 The nonoverlapping confidence intervals suggest that this difference between groups is statistically significant. The other open label 16-week RCT showed a statistically significant weight loss from baseline with the metformin plus sitagliptin arm (−1.2 kg, p = 0.0008) and a nonsignificant small weight gain with the metformin plus rosiglitazone arm (0.3 kg, p = 0.59).130

Combination of metformin and thiazolidinediones versus combination of metformin and meglitinides. One RCT with 568 patients lasting 26 weeks compared metformin plus rosiglitazone twice daily with the combination of metformin plus repaglinide twice daily and three times daily; they reported qualitatively no significant between-group differences in weight but did not report any quantitative numbers.131

Combination of metformin and thiazolidinediones versus combination of metformin and GLP-1 agonists. One 20-week RCT with comparable dosing of medications compared the combination of metformin and rosiglitazone with the combination of metformin and exenatide, favoring the combination of metformin and exenatide with a between-group difference of 2.7 kg (p < 0.001).132 The metformin and rosiglitazone arm showed weight gain from baseline (+1.5 kg) while the metformin and exenatide arm showed weight loss from baseline (−1.2 kg).132

Combination of metformin and sulfonylureas versus combination of metformin and DPP-4 inhibitors. One double-blinded moderately sized RCT compared fixed-dose metformin plus sulfonylurea (mean dose of sulfonylurea was 10 mg) with the combination of fixed dose metformin plus fixed dose sitagliptin (100 mg), showing body weight was significantly reduced in the metformin plus sitagliptin arm compared with an increase in body weight from baseline in the metformin plus sulfonylurea arm (mean difference between-groups of −2.5 kg, 95 percent CI −3.1 kg to −2.0 kg).133 This RCT was extended a second year and continued to show weight loss in the metformin plus sitagliptin arm (−1.6 kg) and weight gain in the metformin plus glipizide arm (+0.7 kg) with a between-group mean difference of −2.3 kg (95 percent CI −3.0 kg to −1.6 kg).134

Combination of metformin and sulfonylureas versus combination of metformin and meglitinides. Two moderately sized double-blinded RCTs lasting 2 years directly compared the combination of metformin plus sulfonylurea with metformin plus nateglinide showing slightly different results.136,152 One study showed a small but significant between-group difference of −1.2 kg favoring the metformin plus nateglinide arm (p = 0.01).136 The other comparable study did not report quantitative data, only stating no clinically relevant changes in weight were found in either group.152

Combination of metformin and sulfonylurea versus combination of metformin and GLP-1 agonists. Two RCTs compared metformin plus sulfonylurea with metformin plus a GLP-1 agonist, favoring the combination of metformin and GLP-1 agonist (between-group differences of 3.8 kg and 12.3 kg).44,92 Both RCTs showed weight loss with the combination of metformin and GLP-1 agonists and weight gain with the combination of metformin and sulfonylurea. One RCT with comparable dosing of medications lasting a year compared the combination of metformin and glibenclamide with the combination of metformin and exenatide, reporting weight loss with metformin and exenatide (−8 kg, p < 0.001) and weight gain with metformin and glibenclamide (4.3 kg, p < 0.05).44 This article did not report on the between-group difference in weight.44 Another short-duration RCT with comparable dosing of medications directly compared the combination of metformin and glimepiride with three different dosing arms of the combination of metformin and liraglutide (0.6 mg, 1.2 mg and 1.8 mg).92 All three dosing comparisons showed a dose response effect on weight in the metformin plus liraglutide arms (range in weight loss of −1.8 kg to −2.8 kg with greater weight loss using higher doses) and a weight gain in metformin and glimepiride arm (1 kg). The between-group differences in weight were statistically significant for this study.92

Combination of metformin and sulfonylureas versus combination of metformin and premixed insulin. Two short-duration RCTS compared metformin plus glibenclamide with the combination of metformin plus a premixed insulin analogue-insulin aspart 70/30 in one study and insulin lispro 75/25 in the other study; both studies nonsignificantly favored the metformin plus sulfonylurea arms (range in between-group differences of −0.7 kg to −0.5 kg).137,138 None of the study arms decreased weight from baseline.

Combination of metformin and sulfonylureas versus combination of thiazolidinediones and sulfonylureas. Four RCTs compared the combination of metformin plus a sulfonylurea with a combination of a thiazolidinedione plus a sulfonylurea, favoring the metformin plus sulfonylurea arms with a pooled between-group difference of −3.2 kg (95 percent CI −5.2 kg to −1.1 kg) (Figure 28).124,126,140,142 Heterogeneity was significant but all between-group point estimates are in the same direction with minimal differences between studies. No single study markedly influenced these results.

Figure 28 Mean difference in weight comparing combination metformin and sulfonylureas with combination thiazolidinediones with sulfonylureas

CI = confidence interval; diff = difference; kg = kilogram; Met = metformin; SU = sulfonylureas; TZD = thiazolidinediones

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 21.67 with 3 degrees of freedom (p = 0.0001)

I-squared statistic = 86%

The range in change scores for weight for the comparison group, a combination of thiazolidinedione and sulfonylureas, was −1 kg to 3 kg. The median change was 2.2 kg.

Figure 28 is a forest plot for the meta-analysis of the mean difference in weight comparing the combination of metformin and sulfonylureas with the combination of thiazolidinediones and sulfonylureas. There are 4 studies included in this meta-analysis: Hanefeld 2004 with a mean difference of -3.8 (95 percent CI -7.8 to .2), Home 2007 with a mean difference of -4.3 (95 percent CI -5.1 to -3.5), Kim 2007 with a mean difference of -1.8 (95 percent CI -2.5 to -1.1), van de Meer 2009 with a mean difference of -3.0 (95 percent CI -13.9 to 7.9). Numbers greater than 0 favor the combination of thiazolidinediones and sulfonylureas and numbers less than 0 favor the combination of metformin and sulfonylureas. The pooled mean difference was -3.17 kg (95 percent confidence interval -5.21 kg to -1.13 kg). There was statistically significant heterogeneity across the studies.

We included only the shorter duration results for the RECORD study124 in the meta-analysis since all other studies were shorter duration. However, the longer duration results were consistent with the shorter duration studies favoring the metformin plus sulfonylurea arm.16 The RECORD study was a multicenter open label RCT evaluating 4,447 patients with type 2 diabetes and uncontrolled glycemia already on metformin or sulfonylurea monotherapy.16,124 They randomly assigned subjects to addition of rosiglitazone or metformin to existing sulfonylurea, with a primary endpoint of cardiovascular hospitalization or cardiovascular death. These two studies showed a significant increase in weight for the thiazolidinedione plus sulfonylurea arm compared with a slight decrease in weight from baseline in the metformin plus sulfonylurea arm (significant between-group differences of 4.3 kg in the 18-month followup and 5.9 kg in the estimated 5-year followup).

Combination of metformin and DPP-4 inhibitors versus combination of metformin and GLP-1 agonists. One 26-week RCT with comparable dosing of medications directly compared the combination of metformin and sitagliptin with the combination of metformin and liraglutide in 2 dosing arms (maximum dose liraglutide 1.2 mg in one arm and 1.8 mg in the second combination arm), showing a significantly greater weight loss in the metformin and liraglutide arms compared to the metformin and sitagliptin arm. The mean difference between groups in weight was −2.4 kg (95 percent CI −3.1 kg to −1.7 kg) for the liraglutide (1.8 mg) plus metformin arm versus the combination of metformin plus sitagliptin and −1.9 kg (95 percent CI −2.6 kg to −1.2 kg) for the liraglutide (1.2 mg) plus metformin arm versus the combination of metformin plus sitagliptin.143

Combination of metformin and GLP-1 agonists versus combination of metformin and basal insulin. One small 56-week RCT compared the combination of metformin and exenatide with the combination of metformin and glargine insulin, showing statistically significant weight loss with the metformin plus exenatide treated group compared to the metformin plus glargine insulin treated group (between group difference of −4.6 kg, p < 0.0001).144 Of note, the exenatide combination arm had about 25 percent of their subjects on higher than the maximum recommended dose of exenatide. Weight returned to baseline 12 weeks after discontinuation of treatment in both arms.

Combination of metformin and basal insulin versus combination of metformin and premixed insulin. Three RCTs directly compared the combination of metformin plus basal insulin with the combination of metformin plus premixed insulin, showing no between-group differences in weight (pooled mean difference of −1.8 kg, 95 percent CI −7.8 kg to 4.2 kg) (Figure 29).145–147 No single study strongly influenced the results, and no substantial heterogeneity was found.

Figure 29 Mean difference in weight comparing combination metformin and basal insulin with combination metformin and premixed insulin

CI = confidence interval; diff = difference; kg = kilogram; Met = metformin

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 21.67 with 3 degrees of freedom (p = 0.0001)

I-squared statistic = 86%

The range in change scores for weight for the comparison group, combination metformin and premixed insulin, was 0.9 kg to 5.6 kg. The median change was 2.2 kg.

Figure 29 is a forest plot for the meta-analysis of the mean difference in weight comparing the combination of metformin and basal insulin with the combination of metformin and premixed insulin. There are 3 studies included in this meta-analysis: Robbins 2007 with a mean difference of -1.4 (95 percent CI -9. to 6.2), Raskin 2007 with a mean difference of -2.6 (95 percent CI -14.9 to 9.7), Davies 2007 with a mean difference of -2.2 (95 percent CI -17.6 to 13.2). Numbers greater than 0 favor the combination of metformin and premixed insulin and numbers less than 0 favor the combination of metformin and basal insulin. The pooled mean difference was -1.80 kg (95 percent confidence interval -7.76 kg to 4.16 kg). There was statistically significant heterogeneity across the studies.

### The Evidence About Low-Density Lipoproteins (Appendix G, Table 4)

Metformin versus rosiglitazone. Six RCTs compared metformin to rosiglitazone and favored metformin (pooled between-group difference −12.8 mg/dL, 95 percent CI −24.0 mg/dL to −1.6 mg/dL) (Figure 30).45,48,49,148,153,154 Removal of any of three studies resulted in point estimates which still favored metformin but loss of the statistical significance of those pooled between-group differences in LDL.49,148,153 While there was statistical evidence of heterogeneity, all studies reported between-group differences consistent with the pooled estimate. Another study reported that median LDL decreased by 31.2 mg/dL in the metformin arm and by 15.6 mg/dL in the rosiglitazone arm but was not included the meta-analysis because it reported medians and not means.58

Figure 30 Mean difference in LDL comparing metformin with rosiglitazone

CI = confidence interval; diff = difference; LDL = low density lipoprotein; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 11.38 with 5 degrees of freedom (p = 0.04)

I-squared statistic = 56%

The range in change scores for LDL for the comparison group, rosiglitazone, was −3.9 mg/dL to 23.4 mg/dL. The median change was 5.1 mg/dL.

Figure 30 is a forest plot for the meta-analysis of the mean difference in LDL comparing metformin with rosiglitazone. There are 6 studies included in this meta-analysis: Virtanen 2003 with a mean difference of -31.2 (95 percent CI -84.2 to 21.8), Natali 2004 with a mean difference of -10. (95 percent CI -23.5 to 3.5), Hallsten 2004 with a mean difference of -35.1 (95 percent CI -56.7 to -13.5), Rosenstock 2006 with a mean difference of -17.5 (95 percent CI -38.7 to 3.7), Iliadis 2007 with a mean difference of -2. (95 percent CI -7.4 to 3.4), Kiyici 2009 with a mean difference of -3.9 (95 percent CI -39.8 to 32.). Numbers greater than 0 favor rosiglitazone and numbers less than 0 favor metformin. The pooled mean difference was -12.76 mg/dL (95 percent confidence interval -23.96 mg/dL to -1.56 mg/dL). There was statistically significant heterogeneity across the studies.

Metformin versus pioglitazone. Six studies compared metformin to pioglitazone favoring metformin (pooled between-group difference in LDL −14.2 mg/dL, 95 percent CI −15.3 mg/dL to −13.1 mg/dL) (Figure 31).39,47,52–54,57 No one study significantly influenced results, and there was no evidence of heterogeneity.

Figure 31 Mean difference in LDL comparing metformin with pioglitazone

CI = confidence interval; diff = difference; LDL = low density lipoprotein; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 4.13 with 5 degrees of freedom (p = 0.53)

I-squared statistic = 0%

The range in change scores for LDL for the comparison group, pioglitazone, was −4.0 mg/dL to 10.5 mg/dL. The median change was 7.2 mg/dL.

Figure 31 is a forest plot for the meta-analysis of the mean difference in LDL comparing metformin with pioglitazone. There are 6 studies included in this meta-analysis: Pavo 2003 with a mean difference of -13.3 (95 percent CI -14.8 to -11.7), Schernthaner 2004 with a mean difference of -15.2 (95 percent CI -16.8 to -13.7), Lawrence 2004 with a mean difference of -7.8 (95 percent CI -36.4 to 20.8), Erdem 2008 with a mean difference of -15.8 (95 percent CI -47.9 to 16.3), Gupta 2009 with a mean difference of -16.8 (95 percent CI -30.5 to -3.2), Kato 2009 with a mean difference of -2.0 (95 percent CI -31.3 to 27.4). Numbers greater than 0 favor pioglitazone and numbers less than 0 favor metformin. The pooled mean difference was -14.21 mg/dL (95 percent confidence interval -15.29 mg/dL to -13.13 mg/dL). There was no statistically significant heterogeneity across the studies.

Metformin versus sulfonylureas. Eight RCTs compared metformin with sulfonylureas with a pooled between-group difference in LDL of −10.1 mg/dL (95 percent CI −13.3 mg/dL to −7.0 mg/dL) which favored metformin (Figure 32).60–62,64,67,68,70,155 No one study significantly influenced results. While there was statistical evidence of heterogeneity, point estimates from all studies favored metformin. Another study reported no difference in overall lipid levels between groups but did not provide quantitative results.63

Figure 32 Mean difference in LDL comparing metformin with sulfonylureas

CI = confidence interval; diff = difference; LDL = low density lipoprotein; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 46.42 with 7 degrees of freedom (p = 0.0000)

I-squared statistic = 85%

The range in change scores for LDL for the comparison group, sulfonylurea, was −3.9 mg/dL to 5.1 mg/dL. The median change was 1.4 mg/dL.

Figure 32 is a forest plot for the meta-analysis of the mean difference in LDL comparing metformin with sulfonylureas. There are 8 studies included in this meta-analysis: Hermann 1991 with a mean difference of -5.9 (95 percent CI -8.5 to -3.2), Campbell 1994 with a mean difference of -21.5 (95 percent CI -25.6 to -17.3), Hermann 1994 with a mean difference of -10.5 (95 percent CI -11.9 to -9.1), DeFronzo 1995 with a mean difference of -9.0 (95 percent CI -14.5 to -3.5), Marre 2002 with a mean difference of -7.8 (95 percent CI -9.3 to -6.3), Goldstein 2003 with a mean difference of -6.8 (95 percent CI -16.8 to 3.2), Garber 2003 with a mean difference of -8. (95 percent CI -16.9 to .9), Derosa 2004 with a mean difference of -9.0 (95 percent CI -27.1 to 9.1). Numbers greater than 0 favor sulfonylureas and numbers less than 0 favor metformin. The pooled mean difference was -10.14 mg/dL (95 percent confidence interval -13.27 mg/dL to -7.00 mg/dL). There was statistically significant heterogeneity across the studies.

Metformin versus DPP-4 inhibitors. Three RCTs compared metformin with DPP-4 inhibitors with a pooled between-group difference in LDL of −5.9 mg/dL (95 percent CI −9.7 mg/dL to −2.0 mg/dL) favoring metformin (Figure 33).76–78 No one study significantly influenced results, and there was no evidence of heterogeneity.

Figure 33 Mean difference in LDL comparing metformin with DPP-4 inhibitors

CI = confidence interval; diff = difference; DPP-4 inhibitors = dipeptidyl peptidase-4 inhibitors; LDL = low density lipoprotein; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 2.77 with 2 degrees of freedom (p = 0.25)

I-squared statistic = 28%

The range in change scores for LDL for the comparison group, DPP-4 inhibitors, was −1.6 mg/dL to 11.2 mg/dL. The median change was −0.5 mg/dL.

Figure 33 is a forest plot for the meta-analysis of the mean difference in LDL comparing metformin with DPP-4 inhibitors. There are 3 studies included in this meta-analysis: Jadzinsky 2009 with a mean difference of -3.5 (95 percent CI -7.5 to .5), Williams-Herman 2009 with a mean difference of -5.2 (95 percent CI -18.7 to 8.3), Ashner 2010 with a mean difference of -8.7 (95 percent CI -13.3 to -4.1). Numbers greater than 0 favor DPP-4 inhibitors and numbers less than 0 favor metformin. The pooled mean difference was -5.85 mg/dL (95 percent confidence interval -9.65 mg/dL to -2.05 mg/dL). There was no statistically significant heterogeneity across the studies.

Metformin versus meglitinides. As seen in the previous report,21 in a single RCT, the between-group difference in LDL (−3.12 mg/dL) favored metformin over repaglinide, but this difference was not statistically significant (p > 0.05).81

Metformin versus a combination of metformin and rosiglitazone. Seven RCTs favored metformin over the combination of metformin and rosiglitazone (pooled between-group difference in LDL −14.5 mg/dL, 95 percent CI −15.7 mg/dL to −13.3 mg/dL) (Figure 34).49,85–88,90,156 No one study significantly affected results, and there was no evidence of statistical heterogeneity.

Figure 34 Mean difference in LDL comparing metformin with combination metformin and rosiglitazone

CI = confidence interval; diff = difference; LDL = low density lipoprotein; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 1.83 with 6 degrees of freedom (p = 0.93)

I-squared statistic = 0%

The range in change scores for LDL for the comparison group, a combination of metformin and rosiglitazone, was −0.3 mg/dL to 20.4 mg/dL. The median change was 16.4 mg/dL.

Figure 34 is a forest plot for the meta-analysis of the mean difference in LDL comparing metformin with a combination of metformin and rosiglitazone. There are 7 studies included in this meta-analysis: Fonseca 2000 with a mean difference of -14.4 (95 percent CI -15.9 to -13.), Gomez-Perez 2002 with a mean difference of -15.9 (95 percent CI -27. to -4.8), Weissman 2005 with a mean difference of -15.7 (95 percent CI -18.5 to -12.9), Bailey 2005 with a mean difference of -13.4 (95 percent CI -16.9 to -9.9), Stewart 2006 with a mean difference of -14. (95 percent CI -30. to 1.9), Rosenstock 2006 with a mean difference of -12.1 (95 percent CI -28. to 3.8), Scott 2008 with a mean difference of -7.6 (95 percent CI -24.8 to 9.6). Numbers greater than 0 favor the combination of metformin and rosiglitazone and numbers less than 0 favor metformin. The pooled mean difference was -14.51 mg/dL (95 percent confidence interval -15.72 mg/dL to -13.30 mg/dL). There was no statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and pioglitazone. Two RCTs compared the effect of metformin to the combination of metformin and pioglitazone on LDL. One RCT found a between-group difference of −2.6 mg/dL,84 and the other reported a between-group difference in percentage change from baseline of 4.2 percentage points.89 Statistical significance was not reported.

Metformin versus a combination of metformin and sulfonylureas. Six RCTs found no between-group difference in LDL (pooled between-group difference −0.2 mg/dL, 95 percent CI −5.6 mg/dL to 5.2 mg/dL) for metformin compared to the combination of metformin and a sulfonylurea (Figure 35).61 62 64 68 70 155 No one study significantly affected results. Meta-regression revealed study duration as a potential source of heterogeneity. Shorter duration studies (16 to 18 weeks) tended to favor the combination of metformin and a sulfonylurea,68 70 155 and longer duration studies (24 to 26 weeks) tended to favor metformin.61 62 64 Another study reported no changes in lipid values between groups but did not provide quantitative results.63

Figure 35 Mean difference in LDL comparing metformin with combination metformin and sulfonylureas

CI = confidence interval; diff = difference; LDL = low density lipoprotein; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 112.04 with 5 degrees of freedom (p = 0.0000)

I-squared statistic = 96%

The range in change scores for LDL for the comparison group, a combination of metformin and sulfonylureas, was −7.8 mg/dL to 4.5 mg/dL. The median change was −4.5 mg/dL.

Figure 35 is a forest plot for the meta-analysis of the mean difference in LDL comparing metformin with a combination of metformin and sulfonylureas. There are 6 studies included in this meta-analysis: Hermann 1991 with a mean difference of 5.5 (95 percent CI 4. to 6.9), Hermann 1994 with a mean difference of 6.6 (95 percent CI 3.3 to 9.9), DeFronzo 1995 with a mean difference of 2. (95 percent CI -3.5 to 7.5), Marre 2002 with a mean difference of -3.9 (95 percent CI -5.2 to -2.6), Goldstein 2003 with a mean difference of -7. (95 percent CI -17.6 to 3.6), Garber 2003 with a mean difference of -10.2 (95 percent CI -19.5 to -.9). Numbers greater than 0 favor the combination of metformin and sulfonylureas and numbers less than 0 favor metformin. The pooled mean difference was -0.19 mg/dL (95 percent confidence interval -5.60 mg/dL to 5.22 mg/dL). There was statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and DPP-4 inhibitors. Four RCTs found no between-group difference in LDL for metformin compared to the combination of metformin and a DPP-4 inhibitor (pooled between-group difference −0.4 mg/dL, 95 percent CI −5.4 mg/dL to 6.2 mg/dL) (Figure 36).76,78,85,94 There was no statistical evidence of heterogeneity, and no one study significantly influenced results. One study evaluated LDL at 24 weeks and after a continuation (at 54 weeks).76 We included the shorter duration results in the meta-analysis since the study duration was more homogenous with the rest of the studies and had less loss to followup.76 The 54-week results were similar to those at 24-weeks; significance of the between-group difference was not reported, but the 95 percent CIs for percentage change in LDL from baseline were overlapping.76 There was a possible dose-response relationship with the 2000 mg metformin and 100 mg sitagliptin arm reducing LDL (mean change from baseline −1.1 percent at 24 weeks and −4.1 percent at 54 weeks) compared to the 1000 mg metformin plus 100 mg sitagliptin arm (mean change in LDL from baseline 1.4 percent at 24 weeks and −0.3 percent at 54 weeks). Another study studied two combination arms: metformin plus saxagliptin 5 mg once daily and metformin plus saxagliptin 10 mg once daily.78 We included the arm with saxagliptin dosing of 5 mg per day in the meta-analysis since this is the FDA-approved dose.78 However, percent changes in LDL were similar in both arms, −4.6 mg/dL and −3.8 mg/dL for the 5- and 10-mg saxagliptin arms, respectively.78

Figure 36 Mean difference in LDL comparing metformin with combination metformin and DPP-4 inhibitors

CI = confidence interval; diff = difference; DPP-4 inhibitors = dipeptidyl peptidase-4 inhibitors; LDL = low density lipoprotein; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.61 with 3 degrees of freedom (p = 0.90)

I-squared statistic = 0%

The range in change scores for LDL for the comparison group, a combination of metformin and DPP-4 inhibitors, was −4.6 mg/dL to 9.2 mg/dL. The median change was −0.9 mg/dL.

Figure 36 is a forest plot for the meta-analysis of the mean difference in LDL comparing metformin with a combination of metformin and DPP-4 inhibitors. There are 4 studies included in this meta-analysis: Charbonnel 2006 with a mean difference of 0.0 (95 percent CI -9.2 to 9.2), Scott 2008 with a mean difference of 3.6 (95 percent CI -13.4 to 20.6), Williams-Herman 2009 with a mean difference of -3.6 (95 percent CI -16.8 to 9.6), Jadzinsky 2009 with a mean difference of 2.2 (95 percent CI -8.5 to 12.9). Numbers greater than 0 favor the combination of metformin and DPP-4 inhibitors and numbers less than 0 favor metformin. The pooled mean difference was 0.36 mg/dL (95 percent confidence interval -5.43 mg/dL to 6.16 mg/dL). There was no statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and meglitinides. A single 24-week RCT directly compared the combination of metformin and nateglinide at two different doses (60 mg and 120 mg) to the combination of metformin and placebo and showed no between-group difference in LDL (0 mg/dL) over the course of the study.96

Rosiglitazone versus pioglitazone. Three RCTs comparing rosiglitazone directly with pioglitazone showed a greater increase in LDL with rosiglitazone, (pooled between-group difference of 14.3 mg/dL, 95 percent CI 5.8 mg/dL to 22.7 mg/dL) (Figure 37).97–99 No one study significantly influenced results. While there was statistical evidence of heterogeneity, point estimates from all studies favored pioglitazone. Due to these differences, pioglitazone and rosiglitazone were not combined for comparisons including these thiazolidinediones for the LDL section.

Figure 37 Mean difference in LDL comparing rosiglitazone with pioglitazone

CI = confidence interval; diff = difference; LDL = low density lipoprotein; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 9.65 with 2 degrees of freedom (p = 0.008)

I-squared statistic = 79%

The range in change scores for LDL for the comparison group, pioglitazone, was −18 to 12.3 mg/dL. The median change was −13.7 mg/dL.

Figure 37 is a forest plot for the meta-analysis of the mean difference in LDL comparing rosiglitazone with pioglitazone. There are 3 studies included in this meta-analysis: Khan 2002 with a mean difference of 16. (95 percent CI -4.4 to 36.4), Goldberg 2005 with a mean difference of 9. (95 percent CI 4.6 to 13.4), Vijay 2009 with a mean difference of 19.1 (95 percent CI 14.5 to 23.6). Numbers greater than 0 favor pioglitazone and numbers less than 0 favor rosiglitazone. The pooled mean difference was 14.26 mg/dL (95 percent confidence interval 5.79 mg/dL to 22.73 mg/dL). There was statistically significant heterogeneity across the studies.

Rosiglitazone versus sulfonylureas. Two RCTs compared rosiglitazone to a sulfonylurea, and in both studies, rosiglitazone (8 mg daily) increased median LDL relative to a sulfonylurea (range in median between-group difference 15.2 mg/dL to 19.5 mg/dL).100,149 Statistical significance of between-group differences were not reported. There was suggestion of a dose-response given that a lower dose rosiglitazone (4 mg daily) was associated with a smaller median between-group difference (11.7 mg/dL) in one study.100

Pioglitazone versus sulfonylureas. Three RCTs compared pioglitazone to a sulfonylurea (pooled between-group difference in LDL 7.1 mg/dL, 95 percent CI 5.3 mg/dL to 9.0 mg/dL) (Figure 38).41,105,106 No one study affected results, and there was no significant heterogeneity. Rosiglitazone versus meglitinides. As seen in the previous evidence report,21 a single RCT compared rosiglitazone to repaglinide and found a between-group difference in LDL of 15 mg/dL.109

Figure 38 Mean difference in LDL comparing pioglitazone with sulfonylureas

CI = confidence interval; diff = difference; LDL = low density lipoprotein; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 2.08 with 2 degrees of freedom (p = 0.35)

I-squared statistic = 4%

The range in change scores for LDL for the comparison group, sulfonylureas, was −8 mg/dL to −1.2 mg/dL. The median change was −1.4 mg/dL.

Figure 38 is a forest plot for the meta-analysis of the mean difference in LDL comparing pioglitazone with sulfonylureas. There are 3 studies included in this meta-analysis: Tan 2004 with a mean difference of 6.6 (95 percent CI 4.7 to 8.5), Pfutzner 2005 with a mean difference of 5.0 (95 percent CI -3.4 to 13.4), Teramoto 2007 with a mean difference of 10.0 (95 percent CI 5.5 to 14.4). Numbers greater than 0 favor sulfonylureas and numbers less than 0 favor pioglitazone. The pooled mean difference was 7.12 mg/dL (95 percent confidence interval 5.26 mg/dL to 8.98 mg/dL). There was no statistically significant heterogeneity across the studies.

Pioglitazone versus meglitinides. As seen in the previous report,21 a single RCT compared pioglitazone to repaglinide and found a between-group difference in LDL of −16 mg/dL.110

Sulfonylureas versus DPP-4 inhibitors. One double-blind moderately sized RCT directly compared four doses of sitagliptin to glipizide upward titrated to 20 mg daily.111 After 12 weeks, both high dose sitagliptin (100 mg a day) and glipizide (maximum dose 20 mg a day) increased LDL (5.5 percent versus 2.2 percent respectively) with overlapping confidence intervals for the placebo-subtracted change from baseline in each group.111

Sulfonylureas versus meglitinides. As seen in the previous evidence report,21 two RCTs compared a sulfonylurea with repaglinide and showed no significant between-group differences in LDL (range in between-group differences of −1.5 mg/dL to 1 mg/dL).113,117 An additional RCT reported no difference between nateglinide and glibenclamide in LDL, but no quantitative results were provided.119

Sulfonylurea versus GLP-1 agonists. A single RCT compared a sulfonylurea to liraglutide and found a non-significant between-group difference in LDL: 2.7 mg/dL (95 percent CI −1.5 mg/dL to 6.6 mg/dL).121 Of note, the dose used in the sulfonylurea arm was low relative to that used in the liraglutide arm.121

Combination of metformin and rosiglitazone versus combination of metformin and sulfonylureas. Four RCTs compared the combination of metformin and rosiglitazone to metformin and a sulfonylurea. The pooled between-group difference in LDL was 13.5 mg/dL (95 percent CI 9.1 mg/dL to 17.9 mg/dL) comparing metformin and rosiglitazone with metformin and a sulfonylurea (Figure 39).123,124,128,157 There was no statistical evidence of heterogeneity, and no single study significantly influenced results. We included results from the 18-month analysis of RECORD in the meta-analysis since this duration was more comparable to the other studies included in the meta-analysis.124 At 5.5 years, the combination of metformin and rosiglitazone decreased LDL less than the combination of metformin and a sulfonylurea (between-group difference 6.6 mg/dL (p = 0.0001).16

Figure 39 Mean difference in LDL comparing combination of metformin and rosiglitazone with combination of metformin and sulfonylureas

CI = confidence interval; diff = difference; LDL = low density lipoprotein; Met = metformin; mg/dL = milligrams per deciliter; Rosi = rosiglitazone; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 2.16 with 3 degrees of freedom (p = 0.54)

I-squared statistic = 0%

The range in change scores for LDL for the comparison group, a combination of metformin and sulfonylureas, was −16 mg/dL to −4 mg/dL. The median change was −8.2 mg/dL.

Figure 39 is a forest plot for the meta-analysis of the mean difference in LDL comparing a combination of metformin and rosiglitazone with a combination of metformin and sulfonylureas. There are 4 studies included in this meta-analysis: Garber 2006 with a mean difference of 14.0 (95 percent CI 0.0 to 28.), Derosa 2006 with a mean difference of 20. (95 percent CI 10.2 to 29.8), Home 2007 with a mean difference of 11.7 (95 percent CI 6. to 17.4), Hamann 2008 with a mean difference of 11.3 (95 percent CI -2.8 to 25.5). Numbers greater than 0 favor the combination of metformin and sulfonylureas and numbers less than 0 favor the combination of metformin and rosiglitazone. The pooled mean difference was 13.55 mg/dL (95 percent confidence interval 9.15 mg/dL to 17.95 mg/dL). There was no statistically significant heterogeneity across the studies.

Combination of metformin and pioglitazone versus combination of metformin and sulfonylureas. A single RCT compared the combination of metformin and pioglitazone to the combination of metformin and glimepiride at 26 weeks and reported a between-group difference of 8.5 mg/dL (p = 0.03) favoring the combination of metformin and glimepiride.126

Combination of metformin and rosiglitazone versus combination of metformin and DPP-4 inhibitors. Two RCTs compared metformin plus rosiglitazone with the combination of metformin plus sitagliptin showing between-group differences in percentage change in LDL from baseline of 14.8 percentage points (95 percent CI 5.7 percent to 23.9 percent)85 and 0.1 percent.130

Combination of metformin and rosiglitazone versus combination of metformin and meglitinides. One RCT lasting 26 weeks compared metformin plus rosiglitazone twice daily with the combination of metformin plus repaglinide twice daily and three times daily, showing a significant between-group difference in LDL of 12.2 mg/dL (p = 0.0002).131

Combination of metformin and rosiglitazone versus combination of metformin andGLP-1 agonists. A single RCT 20 weeks in duration compared the combination of metformin and rosiglitazone to the combination of metformin and exenatide yielding a between-group difference in LDL of 14.7 mg/dL.132 Significance was not reported.132

Combination of metformin and pioglitazone versus combination of pioglitazone and sulfonylureas. A single RCT found no difference in LDL for pioglitazone added to either metformin or a sulfonylurea (p = 0.28) in a post-hoc analysis at 6 months.158

Combination of metformin and sulfonylureas versus combination of metformin and meglitinides. Two moderately sized double-blinded RCTs lasting 1 to 2 years directly compared the combination of metformin plus sulfonylurea with metformin plus nateglinide.135–136 One study reported that LDL decreased by less than 5 percent in both groups.136 The other study reported a decrease in LDL which was greater in the metformin plus sulfonylurea arm compared with the metformin plus nateglinide arm (between group difference −7 mg/dL).135

Combination of metformin and sulfonylureas versus combination of rosiglitazone and sulfonylureas. One RCT lasting only 12 weeks reported less of a decrease in LDL in the metformin plus sulfonylurea arm compared to the rosiglitazone plus sulfonylurea arm (between-group difference 2.7 mg/dL, p = 0.005).42 At 18 months, the RECORD trial reported a between-group difference in LDL of −18.7 mg/dL (p < 0.001)124 and −12.1 mg/dL (p < 0.0001) at 5.5 years124 comparing metformin plus sulfonylurea to rosiglitazone plus sulfonylurea.

Combination of metformin and sulfonylureas versus combination of pioglitazone and sulfonylureas. Two RCTs found that the combination of metformin and sulfonylurea decreased LDL relative to the combination of pioglitazone and sulfonylurea. One study reported a median between-group difference of −11.7 mg/dL (p = 0.11), and the other a mean between-group difference of −9.4 mg/dL (p = 0.0002).140,141

Combination of metformin and DPP-4 inhibitors versus combination of metformin and GLP-1 agonists. A single RCT lasting 26 weeks compared the combination of metformin and sitagliptin with the combination of metformin and one of 2 doses of liraglutide.143 LDL increased in all arms, and the dose of liraglutide did not affect this change: mean between-group difference in LDL 1.9 mg/dL (95 percent CI −6.6 mg/dL to 2.7 mg/dL, daily dose of liraglutide 1.2 mg) and 3.1 mg/dL (95 percent CI −7.7 mg/dL to 1.5 mg/dL, daily dose of liraglutide 1.8 mg) for the metformin plus sitagliptin arm compared with the metformin plus liraglutide arms.143

### The Evidence About High-Density Lipoproteins (Appendix G, Table 4)

Metformin versus rosiglitazone. Six RCTs reported no between-group difference in HDL for metformin compared to rosiglitazone (pooled between-group difference −0.5 mg/dL, 95 percent CI −2.3 mg/dL to 1.4 mg/dL) (Figure 40).45,48,49,148,153,154 No one study significantly affected results, and there was no statistical evidence of heterogeneity.

Figure 40 Mean difference in HDL comparing metformin with rosiglitazone

CI = confidence interval; diff = difference; HDL = high density lipoproteins; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 3.65 with 5 degrees of freedom (p = 0.60)

I-squared statistic = 0%

The range in change scores for HDL for the comparison group, rosiglitazone, was 0.8 mg/dL to 7.8 mg/dL. The median change was 3.5 mg/dL.

Figure 40 is a forest plot for the meta-analysis of the mean difference in HDL comparing metformin with rosiglitazone. There are 6 studies included in this meta-analysis: Virtanen 2003 with a mean difference of 0.0 (95 percent CI -26.5 to 26.5), Natali 2004 with a mean difference of .4 (95 percent CI -5.1 to 5.9), Hallsten 2004 with a mean difference of 0.0 (95 percent CI -10.8 to 10.8), Rosenstock 2006 with a mean difference of -1.2 (95 percent CI -5.8 to 3.4), Iliadis 2007 with a mean difference of .2 (95 percent CI -2.2 to 2.6), Kiyici 2009 with a mean difference of -7.8 (95 percent CI -15.9 to .3). Numbers greater than 0 favor metformin and numbers less than 0 favor rosiglitazone. The pooled mean difference was -0.45 mg/dL (95 percent confidence interval -2.34 mg/dL to 1.43 mg/dL). There was no statistically significant heterogeneity across the studies.

Metformin versus pioglitazone. Eight RCTs favored pioglitazone over metformin with a pooled between-group difference in HDL of −3.2 mg/dL (95 percent CI −4.3 mg/dL to −2.1 mg/dL) (Figure 41).39,47,50–54,57 No one study significantly affected results. While there was statistical evidence of heterogeneity, point estimates from all studies favored pioglitazone.

Figure 41 Mean difference in HDL comparing metformin with pioglitazone

CI = confidence interval; diff = difference; HDL = high density lipoproteins; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 100.55 with 7 degrees of freedom (p = 0.0000)

I-squared statistic = 93%

The range in change scores for HDL for the comparison group, pioglitazone, was −1.9 mg/dL to 9.4 mg/dL. The median change was 4.5 mg/dL.

Figure 41 is a forest plot for the meta-analysis of the mean difference in HDL comparing metformin with pioglitazone. There are 8 studies included in this meta-analysis: Pavo 2003 with a mean difference of -3.5 (95 percent CI -4. to -3.1), Schernthaner 2004 with a mean difference of -3.1 (95 percent CI -3.4 to -2.8), Ramachandran 2004 with a mean difference of -.8 (95 percent CI -1.6 to .1), Lawrence 2004 with a mean difference of -5. (95 percent CI -11.4 to 1.4), Yamanouchi 2005 with a mean difference of -4.7 (95 percent CI -5. to -4.4), Erdem 2008 with a mean difference of -4.2 (95 percent CI -15.7 to 7.4), Gupta 2009 with a mean difference of -4.5 (95 percent CI -8.7 to -.3), Kato 2009 with a mean difference of -3.5 (95 percent CI -20. to 13.). Numbers greater than 0 favor metformin and numbers less than 0 favor pioglitazone. The pooled mean difference was -3.22 mg/dL (95 percent confidence interval -4.32 mg/dL to -2.13 mg/dL). There was statistically significant heterogeneity across the studies.

Metformin versus sulfonylureas. Eleven studies found no significant change in HDL for metformin compared to a sulfonylurea (pooled between-group difference 0.2 mg/dL, 95 percent CI −0.4 mg/dL to 0.8 mg/dL) (Figure 42).50,51,60–52,64,66–68,70,71 No one study significantly affected results. There was no obvious source of the observed heterogeneity on metaregression. Another study reported no changes in lipid values between groups but did not provide quantitative results.63

Figure 42 Mean difference in HDL comparing metformin with sulfonylureas

CI = confidence interval; diff = difference; HDL = high density lipoproteins; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 175.80 with 10 degrees of freedom (p = 0.0000)

I-squared statistic = 94%

The range in change scores for HDL for the comparison group, sulfonylureas, was −0.4 mg/dL to 5.9 mg/dL. The median change was 0.5 mg/dL.

Figure 42 is a forest plot for the meta-analysis of the mean difference in HDL comparing metformin with sulfonylureas. There are 11 studies included in this meta-analysis: Campbell 1994 with a mean difference of 1.2 (95 percent CI .3 to 2.1), Hermann 1994 with a mean difference of -.4 (95 percent CI -.7 to 0.0), DeFronzo 1995 with a mean difference of 1.0 (95 percent CI -1.8 to 3.8), Amador-Licona 2000 with a mean difference of 1.2 (95 percent CI .3 to 2.0), Charpentier 2001 with a mean difference of 1.6 (95 percent CI 1.1 to 2.0), Marre 2002 with a mean difference of .8 (95 percent CI .5 to 1.1), Garber 2003 with a mean difference of -.9 (95 percent CI -1.1 to -.7), Goldstein 2003 with a mean difference of 0.0 (95 percent CI -1.2 to 1.2), Derosa 2004 with a mean difference of 0.0 (95 percent CI -5.2 to 5.2), Ramachandran 2004 with a mean difference of -2. (95 percent CI -3. to -.9), Yamanouchi 2005 with a mean difference of 0.0 (95 percent CI -.3 to .3). Numbers greater than 0 favor metformin and numbers less than 0 favor sulfonylureas. The pooled mean difference was 0.21 mg/dL (95 percent confidence interval -0.43 mg/dL to 0.85 mg/dL). There was statistically significant heterogeneity across the studies.

Metformin versus DPP-4 inhibitors. Three RCTs compared metformin with DPP-4 inhibitors on HDL with a pooled between-group difference of 2.3 mg/dL (95 percent CI −0.28 mg/dL to 4.9 mg/dL) (Figure 43).76–78 Removal of the largest study77 led to a statistically significant pooled between-group difference in HDL favoring metformin. Only 3 studies were included in this meta-analysis making it difficult to understand the significance of this. There was no statistical evidence of heterogeneity.

Figure 43 Mean difference in HDL comparing metformin with DPP-4 inhibitors

CI = confidence interval; diff = difference; DPP-4 inhibitors = dipeptidyl peptidase-4 inhibitors; HDL = high density lipoproteins; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 3.90 with 2 degrees of freedom (p = 0.14)

I-squared statistic = 49%

The range in change scores for HDL for the comparison group, DPP-4 inhibitors, was 0.5 mg/dL to 6.2 mg/dL. The median change was 3.9 mg/dL.

Figure 43 is a forest plot for the meta-analysis of the mean difference in HDL comparing metformin with DPP-4 inhibitors. There are 3 studies included in this meta-analysis: Williams-Herman 2009 with a mean difference of 1.8 (95 percent CI -2.3 to 5.9), Jadzinsky 2009 with a mean difference of 5. (95 percent CI 1.5 to 8.5), Aschner 2010 with a mean difference of .8 (95 percent CI -1.4 to 3.). Numbers greater than 0 favor metformin and numbers less than 0 favor DPP-4 inhibitors. The pooled mean difference was 2.30 mg/dL (95 percent confidence interval -0.28 mg/dL to 4.88 mg/dL). There was no statistically significant heterogeneity across the studies.

Metformin versus meglitinides. As seen in the previous evidence report,21 in a single RCT, the between-group difference in HDL (−4.3 mg/dL) favored repaglinide over metformin, but this difference was not statistically significant.81

Metformin versus a combination of metformin and rosiglitazone. Seven RCTs compared metformin to the combination of metformin and rosiglitazone (pooled between-group difference in HDL −2.8 mg/dL, 95 percent CI −3.5 mg/dL to −2.2 mg/dL) (Figure 44).49,85–88,90,156 No one study significantly affected results. While there was evidence of substantial heterogeneity, point estimates from each study were consistent with the pooled results.

Figure 44 Mean difference in HDL comparing metformin with combination metformin and rosiglitazone

CI = confidence interval; diff = difference; HDL = high density lipoproteins; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 34.57 with 6 degrees of freedom (p = 0.0000)

I-squared statistic = 83%

The range in change scores for HDL for the comparison group, a combination of metformin and rosiglitazone, was 1.8 mg/dL to 6.4 mg/dL. The median change was 3.5 mg/dL.

Figure 44 is a forest plot for the meta-analysis of the mean difference in HDL comparing metformin with a combination of metformin and rosiglitazone. There are 7 studies included in this meta-analysis: Fonseca 2000 with a mean difference of -3.1 (95 percent CI -3.4 to -2.9), Gomez-Perez 2002 with a mean difference of -7.1 (95 percent CI -10.6 to -3.6), Weissman 2005 with a mean difference of -2.5 (95 percent CI -4.3 to -.7), Bailey 2005 with a mean difference of -2.6 (95 percent CI -4.6 to -.6), Rosenstock 2006 with a mean difference of -2.3 (95 percent CI -6.7 to 2.1), Stewart 2006 with a mean difference of -2.3 (95 percent CI -2.4 to -2.2), Scott 2008 with a mean difference of -2.9 (95 percent CI -8.6 to 2.8). Numbers greater than 0 favor metformin and numbers less than 0 favor the combination of metformin and rosiglitazone. The pooled mean difference was -2.82 mg/dL (95 percent confidence interval -3.49 mg/dL to -2.16 mg/dL). There was statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and pioglitazone. Two RCTs favored the combination of metformin and pioglitazone over metformin on the change in HDL.84,89 One reported a between-group difference of 6.4 mg/dL (significance not reported),84 and the other found a statistically significant percentage difference in percentage change from baseline (8.7 percent).89

Metformin versus a combination of metformin and sulfonylureas. Five RCTs found no between-group difference in HDL (pooled between-group difference 0.3 mg/dL, 95 percent CI −1.6 mg/dL to 2.1 mg/dL) for metformin compared to the combination of metformin and a sulfonylurea (Figure 45).61,62,64,68,71,91 There was substantial evidence of heterogeneity, and meta-regression suggested medication dose as a potential source of heterogeneity (p = 0.072). In particular, the study with the lowest relative dose of metformin monotherapy compared to the combination of metformin and sulfonylurea reported the largest point estimate (between-group difference 3.1 mg/dL).71 Removal of this study from the meta-analysis led to a significant pooled between-group difference of −0.75 mg/dL (95 percent CI −1.3 mg/dL to −0.2 mg/dL).71 Another study reported no changes in lipid values between groups but did not provide quantitative results.63

Figure 45 Mean difference in HDL comparing metformin with combination metformin and sulfonylureas

CI = confidence interval; diff = difference; HDL = high density lipoproteins; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 282.15 with 4 degrees of freedom (p = 0.0000)

I-squared statistic = 99%

The range in change scores for HDL for the comparison group, a combination of metformin and sulfonylurea, was −1.2 mg/dL to 1.6 mg/dL. The median change was 0.8 mg/dL.

Figure 45 is a forest plot for the meta-analysis of the mean difference in HDL comparing metformin with a combination of metformin and sulfonylureas. There are 5 studies included in this meta-analysis: Hermann 1994 with a mean difference of -.8 (95 percent CI -1.2 to -.3), Charpentier 2001 with a mean difference of 3.1 (95 percent CI 2.7 to 3.6), Marre 2002 with a mean difference of .8 (95 percent CI -.7 to 2.2), Goldstein 2003 with a mean difference of -.5 (95 percent CI -1.9 to .9), Garber 2003 with a mean difference of -1.2 (95 percent CI -1.4 to -1.). Numbers greater than 0 favor metformin and numbers less than 0 favor the combination of metformin and sulfonylurea. The pooled mean difference was 0.29 mg/dL (95 percent confidence interval -1.57 mg/dL to 2.14 mg/dL). There was statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and DPP-4 inhibitors. Four RCTs found no between-group difference in HDL for metformin compared to the combination of metformin and sitagliptin (pooled between-group difference 0.5 mg/dL, 95 percent CI −1.5 mg/dL to 2.5 mg/dL) (Figure 46).76,78,85,94 There was no statistical evidence of heterogeneity, and no one study significantly influenced results. One study evaluated HDL at 24 weeks and after a continuation (at 54 weeks).76 We included the shorter duration results in the meta-analysis since the study duration was more homogenous with the rest of the studies and had less loss to followup.76 The 54-week results were similar to those at 24 weeks; significance of the between-group difference was not reported, but the 95 percent CIs for percentage change in HDL from baseline were overlapping.76 There was a possible dose-response relationship with the 2000 mg metformin and 100 mg sitagliptin arm increasing HDL (mean change from baseline 5.8 percent at 24 weeks and 7.2 percent at 54 weeks) compared to the 1,000 mg metformin plus 100 mg sitagliptin arm (mean change in HDL from baseline 3.6 percent at 24 weeks and 5.1 percent at 54 weeks). Another study varied the dose of saxagliptin (5 mg and 10 mg daily) in two separate combination arms.78 We included the lower-dose arm in the meta-analysis since this is the FDA-approved dose. HDL increased similarly in the lower and higher dose combination arms.78

Figure 46 Mean difference in HDL comparing metformin with combination metformin and DPP-4 inhibitors

CI = confidence interval; diff = difference; DPP-4 inhibitors = dipeptidyl peptidase-4 inhibitors; HDL = high density lipoproteins; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 1.42 with 3 degrees of freedom (p = 0.70)

I-squared statistic = 0%

The range in change scores for HDL for the comparison group, a combination of metformin and DPP-4 inhibitors, was -4.8 mg/dL to 6.7 mg/dL. The median change was 1.2 mg/dL.

Figure 46 is a forest plot for the meta-analysis of the mean difference in HDL comparing metformin with a combination of metformin and DPP-4 inhibitors. There are 4 studies included in this meta-analysis: Charbonnel 2006 with a mean difference of -.4 (95 percent CI -3.6 to 2.8), Scott 2008 with a mean difference of -1.2 (95 percent CI -7.4 to 5.), Williams-Herman 2009 with a mean difference of .5 (95 percent CI -3.8 to 4.8), Jadzinsky 2009 with a mean difference of 2.2 (95 percent CI -1.4 to 5.8). Numbers greater than 0 favor metformin and numbers less than 0 favor the combination of metformin and DPP-4 inhibitors. The pooled mean difference was 0.50 mg/dL (95 percent confidence interval -1.50 mg/dL to 2.50 mg/dL). There was no statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and meglitinides. A single 24-week RCT directly compared the combination of metformin and nateglinide at two different doses (60 mg and 120 mg) to the combination of metformin and placebo and showed no between-group difference in HDL (0 mg/dL) over the course of the study.96

Rosiglitazone versus pioglitazone. Three RCTs directly comparing rosiglitazone with pioglitazone showed that pioglitazone increased HDL more than rosiglitazone (pooled between-group difference of −2.3 mg/dL, 95 percent CI −3.5 mg/dL to −1.2 mg/dL) (Figure 47).97–99 No one study significantly influenced results. While there was statistical evidence of heterogeneity, point estimates from all studies favored pioglitazone. Due to these differences, pioglitazone and rosiglitazone were not combined for comparisons including these thiazolidinediones for the HDL section. Removal of the largest study led to loss of significance of the pooled estimate, but the pooled estimate still favored pioglitazone.

Figure 47 Mean difference in HDL comparing rosiglitazone with pioglitazone

CI = confidence interval; diff = difference; HDL = high density lipoproteins; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 1.35 with 2 degrees of freedom (p = 0.51)

I-squared statistic = 0%

The range in change scores for HDL for the comparison group, pioglitazone, was 2 mg/dL to 5.2 mg/dL. The median change was 4.7 mg/dL.

Figure 47 is a forest plot for the meta-analysis of the mean difference in HDL comparing rosiglitazone with pioglitazone. There are 3 studies included in this meta-analysis: Khan 2002 with a mean difference of -.5 (95 percent CI -9.8 to 8.8), Goldberg 2005 with a mean difference of -2.8 (95 percent CI -4.2 to -1.4), Vijay 2009 with a mean difference of -1.5 (95 percent CI -3.4 to .5). Numbers greater than 0 favor rosiglitazone and numbers less than 0 favor pioglitazone. The pooled mean difference was -2.33 mg/dL (95 percent confidence interval -3.46 mg/dL to -1.20 mg/dL). There was no statistically significant heterogeneity across the studies.

Rosiglitazone versus sulfonylureas. Two RCTs compared rosiglitazone to a sulfonylurea, and in both studies, rosiglitazone (8 mg daily) increased median HDL relative to a sulfonylurea (range in median between-group difference 3.5 mg/dL to 7.7 mg/dL).100,149 The statistical significance of between-group differences was not reported. There was suggestion of a dose-response relationship given that a lower dose rosiglitazone (4 mg daily) was associated with a smaller median between-group difference (1.6 mg/dL) in one study.100

Pioglitazone versus sulfonylureas. Six RCTs favored pioglitazone over a sulfonylurea (pooled between-group difference in HDL 4.3 mg/dL, 95 percent CI 1.9 mg/dL to 6.6 mg/dL) (Figure 48).41,50,51,105,106,108 Removal of either of the 2 largest studies50,106 resulted in pooled between-group differences (3.8 mg/dL and 4.7 mg/dL) that were nonsignificant. Meta-regression suggested that study duration was a potential source of heterogeneity (p = 0.04). Increased study duration was associated with an increase in between-group differences in HDL.

Figure 48 Mean difference in HDL comparing pioglitazone with sulfonylureas

CI = confidence interval; diff = difference; HDL = high density lipoproteins; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 485.49 with 5 degrees of freedom (p = 0.0000)

I-squared statistic = 99%

The range in change scores for HDL for the comparison group, sulfonylureas was −4.5 mg/dL to 5.9 mg/dL. The median change was 0.5 mg/dL.

Figure 48 is a forest plot for the meta-analysis of the mean difference in HDL comparing pioglitazone with sulfonylureas. There are 6 studies included in this meta-analysis: Ramachandran 2004 with a mean difference of -1.2 (95 percent CI -2.1 to -.3), Tan 2004 with a mean difference of 7. (95 percent CI 6.9 to 7.1), Pfutzner 2005 with a mean difference of 7. (95 percent CI .5 to 13.5), Yamanouchi 2005 with a mean difference of 4.7 (95 percent CI 4.4 to 5.), Nakamura 2006 with a mean difference of 8. (95 percent CI -3.6 to 19.6), Teramoto 2007 with a mean difference of 5. (95 percent CI 2.6 to 7.4). Numbers greater than 0 favor pioglitazone and numbers less than 0 favor sulfonylureas. The pooled mean difference was 4.27 mg/dL (95 percent confidence interval 1.93 mg/dL to .61 mg/dL). There was statistically significant heterogeneity across the studies.

Rosiglitazone versus meglitinides. As seen in the previous evidence report,21 a single RCT compared rosiglitazone to repaglinide and found a between-group difference in HDL of 1.3 mg/dL.109

Pioglitazone versus meglitinides. Two RCTs compared pioglitazone with a meglitinide and found a between-group difference in HDL of 7 mg/dL in both studies.108,110 Neither study commented on the statistical significance of this difference.

Sulfonylureas versus DPP-4 inhibitors. One double-blind moderately sized RCT directly compared four doses of sitagliptin to glipizide upward titrated to 20 mg daily.111 After 12 weeks, both high dose sitagliptin (100 mg per day) and glipizide (maximum dose of 20 mg per day) increased HDL (4.6 percent versus 2.8 percent respectively) with overlapping confidence intervals for the placebo-subtracted change from baseline in each group.111

Sulfonylureas versus meglitinides. Six RCTs compared a sulfonylurea to a meglitinide and found no significant difference in HDL (pooled between-group difference −0.7 mg/dL, 95 percent CI −2.1 mg/dL to 0.7 mg/dL) (Figure 49).108,113–117 Removal of one of the larger studies resulted in a statistically significant pooled between-group difference (−1.2 mg/dL, 95 percent CI −1.9 mg/dL to −0.4 mg/dL).114 This study did not appear to be different from the other studies and was therefore kept in the meta-analysis. No source of heterogeneity was found on meta-regression. One additional RCT reported no difference between nateglinide and glibenclamide in HDL consistent with the results of the meta-analysis, but no quantitative results were provided.119

Figure 49 Mean difference in HDL comparing sulfonylureas with meglitinides

CI = confidence interval; diff = difference; HDL = high density lipoproteins; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 92.38 with 5 degrees of freedom (p = 0.0000)

I-squared statistic = 95%

The range in change scores for HDL for the comparison group, meglitinides was −0.8 mg/dL to 1.2 mg/dL. The median change was 1.1 mg/dL.

Figure 49 is a forest plot for the meta-analysis of the mean difference in HDL comparing sulfonylureas with meglitinides. There are 6 studies included in this meta-analysis: Marbury 1999 with a mean difference of .7 (95 percent CI -.8 to 2.2), Landgraf 1999 with a mean difference of -1.6 (95 percent CI -2.1 to -1.), Wolffenbuttel 1999 with a mean difference of -1.2 (95 percent CI -1.7 to -.7), Madsbad 2001 with a mean difference of 1.2 (95 percent CI .8 to 1.6), Derosa 2003 with a mean difference of -3. (95 percent CI -5.2 to -.8), Nakamura 2006 with a mean difference of -1. (95 percent CI -9.8 to 7.8). Numbers greater than 0 favor sulfonylureas and numbers less than 0 favor meglitinides. The pooled mean difference was -0.67 mg/dL (95 percent confidence interval -2.07 mg/dL to 0.74 mg/dL). There was statistically significant heterogeneity across the studies.

Sulfonylureas versus GLP-1 agonists. A single RCT compared a sulfonylurea with liraglutide and found a non-significant between-group difference in HDL: −0.4 mg/dL (95 percent CI −1.2 mg/dL to 1.9 mg/dL).121 Of note, the dose used in the sulfonylurea arm was low relative to that used in the liraglutide arm.121

Combination of metformin and rosiglitazone versus combination of metformin and sulfonylureas. Four RCTs compared the combination of metformin and rosiglitazone with the combination of metformin and a sulfonylurea. The pooled between-group difference in HDL was 2.7 mg/dL (95 percent CI 1.4 mg/dL to 4.1 mg/dL) comparing combination metformin and rosiglitazone with combination metformin and a sulfonylurea (Figure 50).123,124,128,157 There was no statistical evidence of heterogeneity, and no one study significantly influenced results. We included results from the 18-month analysis of RECORD in the meta-analysis since this duration was more comparable to the other included studies.124 At 5.5 years, the combination of metformin and rosiglitazone increased HDL more than the combination of metformin and a sulfonylurea (between-group difference 3.1 mg/dL, p < 0.0001).16

Figure 50 Mean difference in HDL comparing combination metformin and rosiglitazone with combination metformin and sulfonylureas

CI = confidence interval; diff = difference; HDL = high density lipoproteins; Met = metformin; mg/dL = milligrams per deciliter; Rosi = rosiglitazone; SU = sulfonylureas

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 1.25 with 3 degrees of freedom (p = 0.74)

I-squared statistic = 0%

The range in change scores for HDL for the comparison group, a combination of metformin and sulfonylureas, was −2 mg/dL to 1.2 mg/dL. The median change was 0.4 mg/dL.

Figure 50 is a forest plot for the meta-analysis of the mean difference in HDL comparing a combination of metformin and rosiglitazone with a combination of metformin and sulfonylureas. There are 4 studies included in this meta-analysis: Derosa 2006 with a mean difference of 2. (95 percent CI -.8 to 4.8), Garber 2006 with a mean difference of 4. (95 percent CI 1. to 7.), Home 2007 with a mean difference of 2.3 (95 percent CI .4 to 4.3), Hamann 2008 with a mean difference of 3.5 (95 percent CI -.5 to 7.5). Numbers greater than 0 favor the combination of metformin and rosiglitazone and numbers less than 0 favor the combination of metformin and sulfonylureas. The pooled mean difference was 2.72 mg/dL (95 percent confidence interval 1.39 mg/dL to 4.06 mg/dL). There was no statistically significant heterogeneity across the studies.

Combination of metformin and pioglitazone versus combination of metformin and sulfonylureas. Two RCTs compared the combination of metformin and pioglitazone to metformin and a sulfonylurea.126,158 In both studies, HDL increased in the metformin and pioglitazone arm and decreased in the metformin and sulfonylurea arm; between-group differences ranged from 5.1 mg/dL (p < 0.001) to 5.8 mg/dL (p = 0.0001).126,158

Combination of metformin and rosiglitazone versus combination of metformin and DPP-4 inhibitors. One double-blind small RCT lasting 18 weeks compared maximum dose metformin plus rosiglitazone to the combination of maximum dose metformin plus sitagliptin showing a significant between-group difference in HDL (mean difference in percentage change from baseline of 4.9 percent, 95 percent CI 0.6 percent to 9.2 percent).85 Another small RCT 16 weeks in duration found that the mean percent decrease in HDL from baseline was slightly greater in the metformin plus rosiglitazone arm compared with the metformin plus sitagliptin arm (mean difference in percentage change from baseline of −1 percent, significance not reported).130

Combination of metformin and rosiglitazone versus combination of metformin and meglitinides. One RCT lasting 26 weeks compared metformin plus rosiglitazone twice daily with the combination of metformin plus repaglinide twice daily and three times daily, showing a significant between-group difference in HDL of 4.6 mg/dL (p < 0.0001).131

Combination of metformin and rosiglitazone versus combination of metformin and GLP-1 agonists. A single small RCT 20 weeks in duration compared metformin plus rosiglitazone with metformin plus exenatide and found a between-group mean difference in HDL of 0.8 mg/dL (significance not reported).132

Combination of metformin and pioglitazone versus combination of pioglitazone and sulfonylureas. In a post hoc analysis in a single RCT, metformin plus pioglitazone increased HDL (2.3 mg/dL, p = 0.009) over pioglitazone plus sulfonylurea (0.4 mg/dL, p = 0.62) at 6 months.158

Combination of metformin and sulfonylureas versus combination of metformin and meglitinides. Two moderately sized double-blinded RCTs lasting 1 to 2 years directly compared the combination of metformin plus sulfonylurea with metformin plus nateglinide.135,136 One study reported that HDL increased by approximately 5 percent in both groups.136 The other study showed no between-group difference (0 mg/dL) in HDL as well.135

Combination of metformin and sulfonylureas versus combination of metformin and premixed insulin. A single RCT lasting 4 months compared the combination of metformin and premixed insulin with the combination of metformin and a sulfonylurea, and HDL increased more in the metformin and premixed insulin group relative to the metformin plus sulfonylurea group (between-group difference 2.0 mg/dL), but this difference was not statistically significant.138

Combination of metformin and sulfonylureas versus combination of rosiglitazone and sulfonylureas. One RCT lasting only 12 weeks reported less of a decrease in HDL in the metformin plus sulfonylurea arm compared to the rosiglitazone plus sulfonylurea arm (between-group difference 2.7 mg/dL, p = 0.87).42 At 18 months, the RECORD trial reported a between-group difference in HDL of −0.4 mg/dL (p > 0.05)124 and −1.6 mg/dL (p < 0.0001) at 5.5 years124 comparing metformin plus sulfonylurea to rosiglitazone plus sulfonylurea.

Combination of metformin and sulfonylureas versus combination of pioglitazone and sulfonylureas. Three RCTs found that the combination of pioglitazone and sulfonylurea increased HDL relative to the combination of metformin and sulfonylurea.140,141,158 In one study, the between-group difference in median HDL was 3.1 mg/dL (p = 0.009),141 and two other RCTs found a range of between-group differences of 5.5 mg/dL (p = 0.20) to 10.5 mg/dL (p < 0.0001).140,158

Combination of metformin and DPP-4 inhibitors versus combination of metformin and GLP-1 agonists. A single RCT lasting 26 weeks compared the combination of metformin and sitagliptin with the combination of metformin and one of 2 doses of liraglutide.143 HDL did not change in any arm, and thus there was no between-group difference in HDL change regardless of liraglutide dose.143

### The Evidence About Triglycerides (Appendix G, Table 4)

Metformin versus rosiglitazone. Six RCTs favored metformin over rosiglitazone in terms of lowering TG levels (pooled between-group difference −26.9 mg/dL, 95 percent CI −49.3 mg/dL to −4.5 mg/dL) (Figure 51).45,48,49,148,153,154 When either of the largest studies was excluded from the meta-analysis, the point estimate still favored metformin but the confidence interval included 0.^48,148^ We performed meta-regression because of substantial heterogeneity. Study duration and dose were possible sources of heterogeneity with longer study duration and higher relative dose of metformin associated with a greater pooled between-group difference in TG. Another study reported that median TG decreased by 81 mg/dL in the metformin arm and increased by 9.8 mg/dL in the rosiglitazone arm. This study was not included in the meta-analysis because it only provided medians for point estimates, but the results were consistent with the meta-analysis.58

Figure 51 Mean difference in triglycerides comparing metformin with rosiglitazone

CI = confidence interval; diff = difference; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 16.38 with 5 degrees of freedom (p = 0.006)

I-squared statistic = 70%

The range in change scores for triglycerides for the comparison group, rosiglitazone, was −44 mg/dL to 22 mg/dL. The median change was −4.2 mg/dL.

Figure 51 is a forest plot for the meta-analysis of the mean difference in triglycerides comparing metformin with rosiglitazone. There are 6 studies included in this meta-analysis: Virtanen 2003 with a mean difference of 26.7 (95 percent CI -80.4 to 133.8), Natali 2004 with a mean difference of -47.0 (95 percent CI -61.1 to -32.9), Hallsten 2004 with a mean difference of 35.6 (95 percent CI -13.7 to 84.9), Rosenstock 2006 with a mean difference of -18.9 (95 percent CI -65.3 to 27.5), Iliadis 2007 with a mean difference of -51.0 (95 percent CI -62.1 to -39.9), Kiyici 2009 with a mean difference of 8.9 (95 percent CI -65.8 to 83.6). Numbers greater than 0 favor rosiglitazone and numbers less than 0 favor metformin. The pooled mean difference was -26.86 mg/dL (95 percent confidence interval -49.26 mg/dL to -4.47 mg/dL). There was statistically significant heterogeneity across the studies.

Metformin versus pioglitazone. Eight RCTs compared metformin to pioglitazone and found a pooled between-group difference in TG of 27.2 mg/dL (95 percent CI 24.4 mg/dL to 30.0 mg/dL) (Figure 52).39,47,50–54,57 No one study significantly affected results, and there was no statistical evidence of heterogeneity.

Figure 52 Mean difference in triglycerides comparing metformin with pioglitazone

CI = confidence interval; diff = difference; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 4.34 with 7 degrees of freedom (p = 0.74)

I-squared statistic = 0%

The range in change scores for triglycerides for the comparison group, pioglitazone, was −155.6 mg/dL to −8.0 mg/dL. The median change was −26.6 mg/dL.

Figure 52 is a forest plot for the meta-analysis of the mean difference in triglycerides comparing metformin with pioglitazone. There are 8 studies included in this meta-analysis: Pavo 2003 with a mean difference of 24.8 (95 percent CI 16.6 to 33.), Schernthaner 2004 with a mean difference of 27.5 (95 percent CI 23.4 to 31.5), Lawrence 2004 with a mean difference of .6 (95 percent CI -76.4 to 77.6), Ramachandran 2004 with a mean difference of 35.4 (95 percent CI 23.3 to 47.5), Yamanouchi 2005 with a mean difference of 26.6 (95 percent CI 21.8 to 31.4), Erdem 2008 with a mean difference of 5.7 (95 percent CI -82.3 to 93.7), Gupta 2009 with a mean difference of 131.9 (95 percent CI -57.7 to 321.5), Kato 2009 with a mean difference of 7.1 (95 percent CI -65.2 to 79.5). Numbers greater than 0 favor pioglitazone and numbers less than 0 favor metformin. The pooled mean difference was 27.21 mg/dL (95 percent confidence interval 24.40 mg/dL to 30.02 mg/dL). There was no statistically significant heterogeneity across the studies.

Metformin versus sulfonylureas. Eleven RCTs favored metformin over sulfonylurea (pooled between-group difference in TG −8.6 mg/dL, 95 percent CI −15.6 mg/dL to −1.6 mg/dL) (Figure 53).50,51,60–62,64,66–68,70,71 Removal of one study resulted in loss of statistical significance (pooled between-group difference −6.9 mg/dL (95 percent CI −13.9 mg/dL to 0.1 mg/dL).64 There was no obvious source of the observed heterogeneity on meta-regression. Another study reported no changes in lipid values between groups but did not provide quantitative results.63

Figure 53 Mean difference in triglycerides comparing metformin with sulfonylureas

CI = confidence interval; diff = difference; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 122.78 with 10 degrees of freedom (p = 0.0000)

I-squared statistic = 92%

The range in change scores for triglycerides for the comparison group, sulfonylureas, was −44.5 mg/dL to 59.8 mg/dL. The median change was 0 mg/dL.

Figure 53 is a forest plot for the meta-analysis of the mean difference in triglycerides comparing metformin with sulfonylureas. There are 11 studies included in this meta-analysis: Hermann 1994 with a mean difference of -13.3 (95 percent CI -17.5 to -9.), Campbell 1994 with a mean difference of -10.6 (95 percent CI -18.1 to -3.1), DeFronzo 1995 with a mean difference of -27. (95 percent CI -46.4 to -7.6), Amador-Licona 2000 with a mean difference of -9.7 (95 percent CI -13.8 to -5.7), Charpentier 2001 with a mean difference of 2.7 (95 percent CI -.4 to 5.8), Marre 2002 with a mean difference of -17.7 (95 percent CI -21. to -14.4), Garber 2003 with a mean difference of -24.5 (95 percent CI -62.2 to 13.2), Goldstein 2003 with a mean difference of -61.4 (95 percent CI -105.6 to -17.2), Ramachandran 2004 with a mean difference of 17.7 (95 percent CI 7.3 to 28.2), Derosa 2004 with a mean difference of 0.0 (95 percent CI -49.6 to 49.6), Yamanouchi 2005 with a mean difference of -3.5 (95 percent CI -8.7 to 1.6). Numbers greater than 0 favor sulfonylureas and numbers less than 0 favor metformin. The pooled mean difference was -8.56 mg/dL (95 percent confidence interval -15.57 mg/dL to -1.56 mg/dL). There was statistically significant heterogeneity across the studies.

Metformin versus DPP-4 inhibitors. Three RCTs found that sitagliptin decreased TG more than metformin, but the pooled between-group difference was not significant (3.4 mg/dL, 95 percent CI −0.4 mg/dL to 7.2 mg/dL) (Figure 54).76–78 No one study significantly influenced results, and there was no evidence of heterogeneity.

Figure 54 Mean difference in triglycerides comparing metformin with DPP-4 inhibitors

CI = confidence interval; diff = difference; DPP-4 inhibitors = dipeptidyl peptidase-4 inhibitors; mg/dL = milligrams per deciliter Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.97 with 2 degrees of freedom (p = 0.62)

I-squared statistic = 0%

The range in change scores for triglycerides for the comparison group, DPP-4 inhibitors, was −3.7 mg/dL to 6 mg/dL. The median change was −3 mg/dL.

Figure 54 is a forest plot for the meta-analysis of the mean difference in triglycerides comparing metformin with DPP-4 inhibitors. There are 3 studies included in this meta-analysis: Williams-Herman 2009 with a mean difference of 22. (95 percent CI -21.3 to 65.3), Jadzinsky 2009 with a mean difference of 1.5 (95 percent CI -6.3 to 9.3), Aschner 2010 with a mean difference of 3.8 (95 percent CI -.6 to 8.2). Numbers greater than 0 favor DPP-4 inhibitors and numbers less than 0 favor metformin. The pooled mean difference was 3.40 mg/dL (95 percent confidence interval -0.39 mg/dL to 7.19 mg/dL). There was no statistically significant heterogeneity across the studies.

Metformin versus meglitinides. As seen in the previous evidence report,21 in a single RCT, the between-group difference in triglycerides (−8.01 mg/dL) favored metformin over repaglinide, but this difference was not statistically significant.81

Metformin versus a combination of metformin and rosiglitazone. Seven RCTs compared metformin to the combination of metformin and rosiglitazone (pooled between-group difference in TG −14.5 mg/dL, 95 percent CI −15.7 mg/dL to −13.3 mg/dL) (Figure 55).49,85–88,90,156 No one study significantly affected results, and there was no statistical evidence of heterogeneity.

Figure 55 Mean difference in triglycerides comparing metformin with combination metformin and rosiglitazone

CI = confidence interval; diff = difference; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 3.66 with 6 degrees of freedom (p = 0.72)

I-squared statistic = 0%

The range in change scores for triglycerides for the comparison group, a combination of metformin and rosiglitazone, was −33.7 mg/dL to 11.8 mg/dL. The median change was 0 mg/dL.

Figure 55 is a forest plot for the meta-analysis of the mean difference in triglycerides comparing metformin with a combination of metformin and rosiglitazone. There are 7 studies included in this meta-analysis: Fonseca 2000 with a mean difference of -14.4 (95 percent CI -15.9 to -13.), Gomez-Perez 2002 with a mean difference of -15.9 (95 percent CI -27. to -4.8), Bailey 2005 with a mean difference of -13.4 (95 percent CI -16.9 to -9.9), Weissman 2005 with a mean difference of -15.7 (95 percent CI -18.5 to -12.9), Rosenstock 2006 with a mean difference of 6.7 (95 percent CI -38.4 to 51.8), Stewart 2006 with a mean difference of -15.1 (95 percent CI -48.3 to 18.1), Scott 2008 with a mean difference of 22.2 (95 percent CI -33.2 to 77.6). Numbers greater than 0 favor a combination of metformin and rosiglitazone and numbers less than 0 favor metformin. The pooled mean difference was -14.53 mg/dL (95 percent confidence interval -15.75 mg/dL to -13.31 mg/dL). There was no statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and pioglitazone. Two RCTs compared metformin to the combination of metformin and pioglitazone.84,89 One RCT found a between-group difference of −6.1 mg/dL (significance not reported),84 and the other reported statistically significant between-group percentage change in percentage change from baseline of 18.2 percent.89

Metformin versus a combination of metformin and sulfonylureas. As seen in the previous evidence report,21 six RCTs found no between-group difference in TG (pooled between-group difference 6.9 mg/dL, 95 percent CI −1.1 mg/dL to 14.9 mg/dL) for metformin compared to the combination of metformin and a sulfonylurea (Figure 56).61,62,64,68,70,71 Meta-regression did not reveal a source of the observed statistical heterogeneity. Removal of one study from the meta-analysis resulted in a significant pooled between-group difference of 8.9 mg/dL (95 percent CI 0.2 mg/dL to 17.7 mg/dL).64 Two studies reported no changes in lipid values between groups but did not provide quantitative results.63,91

Figure 56 Mean difference in triglycerides comparing metformin with combination metformin and sulfonylureas

CI = confidence interval; diff = difference; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 57.40 with 5 degrees of freedom (p = 0.0000)

I-squared statistic = 91%

The range in change scores for triglycerides for the comparison group, a combination of metformin and sulfonylureas, was −17.8 mg/dL to 18.5 mg/dL. The median change was −10.2 mg/dL.

Figure 56 is a forest plot for the meta-analysis of the mean difference in triglycerides comparing metformin with a combination of metformin and sulfonylureas. There are 6 studies included in this meta-analysis: Hermann 1994 with a mean difference of .9 (95 percent CI -3.4 to 5.1), DeFronzo 1995 with a mean difference of 12.0 (95 percent CI -6.8 to 30.8), Charpentier 2001 with a mean difference of 15.9 (95 percent CI 12.8 to 19.1), Marre 2002 with a mean difference of 0.0 (95 percent CI -3.7 to 3.7), Goldstein 2003 with a mean difference of -20.1 (95 percent CI -62.5 to 22.3), Garber 2003 with a mean difference of 12.4 (95 percent CI 6.7 to 18.1). Numbers greater than 0 favor a combination of metformin and sulfonylureas and numbers less than 0 favor metformin. The pooled mean difference was 6.92 mg/dL (95 percent confidence interval -1.07 mg/dL to 14.91 mg/dL). There was statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and DPP-4 inhibitors. Four RCTs compared metformin to the combination of metformin and sitagliptin and found that metformin decreased TG less than the combination with a pooled between-group difference of 20.7 mg/dL (95 percent CI −0.8 mg/dL to 42.1 mg/dL) (Figure 57).76,78,85,94 Removal of the largest study led to a significant pooled between-group difference (34.8 mg/dL, 95 percent CI 11.3 mg/dL to 58.3 mg/dL). There was no statistical evidence of heterogeneity. One study evaluated TG at 24 weeks and after a continuation (at 54 weeks).76 We included the shorter duration results in the meta-analysis since the study duration was more homogenous with the rest of the studies and had less loss to followup.76 The 54-week results were similar to those at 24 weeks.76 Results suggested a dose-response relationship with the 2000 mg metformin and 100 mg sitagliptin arm decreasing TG (mean change from baseline −10.1 percent at 24 weeks (p < 0.05) and −7.1 percent at 54 weeks (p < 0.05)) compared to the 1000 mg metformin plus 100 mg sitagliptin arm (mean change in TG from baseline −3.7 percent at 24 weeks (p > 0.05) and −4.6 percent at 54 weeks (p > 0.05)).76 Another study evaluated two combination arms: metformin plus saxagliptin 5 mg once daily and metformin plus saxagliptin 10 mg once daily.78 We included the arm with saxagliptin at 5 mg per day in the meta-analysis since this is the FDA-approved dose.78 However, percent changes in TG were similar in both arms, −5.8 percent and −4.5 percent for the 5 and 10 mg saxagliptin arms, respectively.78

Figure 57 Mean difference in triglycerides comparing metformin with combination metformin and DPP-4 inhibitors

CI = confidence interval; diff = difference; DPP-4 inhibitors = dipeptidyl peptidase-4 inhibitors; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 6.03 with 3 degrees of freedom (p = 0.11)

I-squared statistic = 50%

The range in change scores for triglycerides for the comparison group, a combination of metformin and DPP-4 inhibitors, was −16 mg/dL to 7.7 mg/dL. The median change was −10.2 mg/dL.

Figure 57 is a forest plot for the meta-analysis of the mean difference in triglycerides comparing metformin with a combination of metformin and DPP-4 inhibitors. There are 4 studies included in this meta-analysis: Charbonnel 2006 with a mean difference of 26.7 (95 percent CI -11.7 to 65.1), Scott 2008 with a mean difference of 34.9 (95 percent CI -9.8 to 79.6), Williams-Herman 2009 with a mean difference of 43.5 (95 percent CI 3.7 to 83.3), Jadzinsky 2009 with a mean difference of 4.3 (95 percent CI -4.5 to 13.1). Numbers greater than 0 favor a combination of metformin and DPP-4 inhibitors and numbers less than 0 favor metformin. The pooled mean difference was 20.68 mg/dL (95 percent confidence interval -0.79 mg/dL to 42.14 mg/dL). There was no statistically significant heterogeneity across the studies.

Metformin versus a combination of metformin and meglitinides. A single 24-week RCT directly compared the combination of metformin and nateglinide at two different doses (60 mg and 120 mg) to the combination of metformin and placebo and showed a small reduction in triglycerides in the combination arms compared to the monotherapy arm (range in between-group differences in triglycerides −17.8 mg/dL to 8.9 mg/dL). This difference was statistically significant (p < 0.05) for the higher-dose nateglinide (120 mg) arm.96

Rosiglitazone versus pioglitazone. Three RCTs compared rosiglitazone with pioglitazone and demonstrated a favorable effect of pioglitazone on TG relative to rosiglitazone (pooled between-group difference 33.2 mg/dL, 95 percent CI −16.7 mg/dL to 83.1 mg/dL comparing rosiglitazone to pioglitazone) (Figure 58).97–99 Removal of either of the largest studies led to a statistically significant difference which still favored pioglitazone (pooled between-group difference 63.3 mg/dL, 95 percent CI 42.1 mg/dL to 84.5 mg/dL and pooled between-group difference 7.7 mg/dL, 95 percent CI 2.2 mg/dL to 13.2 mg/dL).98,99 While there was statistical evidence of heterogeneity, point estimates from all studies favored pioglitazone. Due to these differences, pioglitazone and rosiglitazone were not combined for comparisons including these thiazolidinediones for the TG section.

Figure 58 Mean difference in triglycerides comparing rosiglitazone with pioglitazone

CI = confidence interval; diff = difference; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 25.37 with 2 degrees of freedom (p = 0.0000)

I-squared statistic = 92%

The range in change scores for triglycerides for the comparison group, pioglitazone, was −51 mg/dL to −15 mg/dL. The median change was −33.0 mg/dL.

Figure 58 is a forest plot for the meta-analysis of the mean difference in triglycerides comparing rosiglitazone with pioglitazone. There are 3 studies included in this meta-analysis: Khan with a mean difference of 21. (95 percent CI -86.5 to 128.5), Goldberg 2005 with a mean difference of 65. (95 percent CI 43.4 to 86.6), Vijay 2009 with a mean difference of 7.7 (95 percent CI 2.2 to 13.2). Numbers greater than 0 favor pioglitazone and numbers less than 0 favor rosiglitazone. The pooled mean difference was 33.20 mg/dL (95 percent confidence interval -16.71 mg/dL to 83.12 mg/dL). There was statistically significant heterogeneity across the studies.

Rosiglitazone versus sulfonylureas. In one RCT, rosiglitazone (8 mg/day) and a sulfonylurea both decreased TG at 52 weeks (mean between-group difference 11 mg/dL for rosiglitazone relative to sulfonylurea) which was reported to be nonsignificant.149 Another RCT found that at 4 mg/day, rosiglitazone decreased TG relative to a sulfonylurea (mean between-group difference −7 mg/dL), but at 8 mg/day rosiglitazone increased TG relative to a sulfonylurea (mean between-group difference 15 mg/dL) at 52 weeks; statistical significance was not reported.100

Pioglitazone versus sulfonylureas. Six RCTs favored pioglitazone over a sulfonylurea (pooled between-group difference −31.6 mg/dL, 95 percent CI −49.1 mg/dL to −14.1 mg/dL) (Figure 59).41,50,51,105,106,108 While there was statistical evidence of heterogeneity, point estimates from all studies favored pioglitazone. No one study significantly influenced results.

Figure 59 Mean difference in triglycerides comparing pioglitazone with sulfonylureas

CI = confidence interval; diff = difference; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 57.26 with 5 degrees of freedom (p = 0.0000)

I-squared statistic = 91%

The range in change scores for triglycerides for the comparison group, sulfonylrueas, was −44 mg/dL to 7.3 mg/dL. The median change was −3.6 mg/dL.

Figure 59 is a forest plot for the meta-analysis of the mean difference in triglycerides comparing pioglitazone with sulfonylureas. There are 6 studies included in this meta-analysis: Ramachandran 2004 with a mean difference of -17.7 (95 percent CI -27.3 to -8.1), Tan 2004 with a mean difference of -29.4 (95 percent CI -57.2 to -1.6), Pfutzner 2005 with a mean difference of -5. (95 percent CI -37. to 27.), Yamanouchi 2005 with a mean difference of -30.1 (95 percent CI -35.4 to -24.8), Nakamura 2006 with a mean difference of -32. (95 percent CI -61.6 to -2.4), Teramoto 2007 with a mean difference of -65. (95 percent CI -74.5 to -55.5). Numbers greater than 0 favor sulfonylureas and numbers less than 0 favor pioglitazone. The pooled mean difference was -31.62 mg/dL (95 percent confidence interval -49.15 mg/dL to -14.10 mg/dL). There was statistically significant heterogeneity across the studies.

Rosiglitazone versus meglitinides. As seen in the previous evidence report,21 one RCT found that compared to repaglinide, rosiglitazone caused a greater absolute increase in TG (between-group difference 23 mg/dL), but statistical significance was not reported.109

Pioglitazone versus meglitinides. As seen in the previous evidence report,21 one RCT found that compared with repaglinide, pioglitazone caused a greater absolute reduction in TG (between-group difference −96 mg/dL), but statistical significance was not reported.110 A small RCT comparing pioglitazone to nateglinide found a between-group difference in TG of −32 mg/dL favoring pioglitazone, but statistical significance was not reported.108

Sulfonylureas versus DPP-4 inhibitors. One double-blind moderately sized RCT directly compared four doses of sitagliptin to glipizide upward titrated to 20 mg daily.111 After 12 weeks, both high dose sitagliptin (100 mg per day) and glipizide (maximum dose of 20 mg a day) increased TG (3.6 percent versus 7.0 percent respectively) with overlapping confidence intervals for the placebo-subtracted change from baseline in each group.111

Sulfonylureas versus meglitinides. Four RCTs compared sulfonylureas with a meglitinide and found no difference in TG (pooled between-group difference of 0.2 mg/dL, 95 percent CI −3.8 mg/dL to 4.2 mg/dL) (Figure 60).108,113,114,117 There was no statistical evidence of heterogeneity, and no one study markedly influenced the results. Two additional RCTs also reported no significant differences in TG between sulfonylureas and meglitinides; one study did not report a measure of variance (e.g., standard error), and the other study did not provide quantitative results.116,119

Figure 60 Mean difference in triglycerides comparing sulfonylureas with meglitinides

CI = confidence interval; diff = difference; mg/dL = milligrams per deciliter

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.54 with 3 degrees of freedom (p = 0.91)

I-squared statistic = 0%

The range in change scores for triglycerides for the comparison group, meglitinides, was −18 mg/dL to 6.57 mg/dL. The median change was 1.0 mg/dL.

Figure 60 is a forest plot for the meta-analysis of the mean difference in triglycerides comparing sulfonylureas with meglitinides. There are 4 studies included in this meta-analysis: Marbury 1999 with a mean difference of -13. (95 percent CI -57.3 to 31.3), Madsbad 2001 with a mean difference of 0.0 (95 percent CI -4.3 to 4.3), Derosa 2003 with a mean difference of 3. (95 percent CI -9.6 to 15.6), Nakamura 2006 with a mean difference of 0.0 (95 percent CI -28.9 to 28.9). Numbers greater than 0 favor meglitinides and numbers less than 0 favor sulfonylureas. The pooled mean difference was 0.20 mg/dL (95 percent confidence interval -3.83 mg/dL to 4.22 mg/dL). There was no statistically significant heterogeneity across the studies.

Sulfonylureas versus GLP-1 agonists. A single RCT compared a sulfonylurea with liraglutide and found a nonsignificant between-group difference in TG: 4.4 mg/dL (95 percent CI −9.7 mg/dL to 8.0 mg/dL).121 Of note, the dose used in the sulfonylurea arm was low relative to that used in the liraglutide arm.121

Combination of metformin and rosiglitazone versus combination of metformin and sulfonylureas. Four RCTs compared the combination of metformin and rosiglitazone with the combination of metformin and a sulfonylurea and found a pooled between-group difference in TG of 4.6 mg/dL (95 percent CI −16.5 mg/dL to 25.8 mg/dL) (Figure 61).123,124,128,159 Removal of one study159 from the meta-analysis led to statistical significance of the between-group difference (16.5 mg/dL, 95 percent CI 2.2 mg/dL to 30.8 mg/dL); this study did not seem different from the other studies in terms of dosing, duration, or baseline TG and was left in the meta-analysis. No source of heterogeneity was found on metaregression. We included results from the 18-month analysis of RECORD in the meta-analysis since this duration was more comparable to the other included studies.124 At 5.5 years, the combination of metformin and rosiglitazone decreased TG more than the combination of metformin and a sulfonylurea (between-group difference −10.7 mg/dL, p = 0.046).16

Figure 61 Mean difference in triglycerides comparing combination metformin and rosiglitazone with combination metformin and sulfonylureas

CI = confidence interval; diff = difference; Met = metformin; mg/dL = milligrams per deciliter; Rosi = rosiglitazone; SU = sulonylureas

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 10.28 with 3 degrees of freedom (p = 0.02)

I-squared statistic = 71%

The range in change scores for triglycerides for the comparison group, combination metformin and sulfonylureas, was −41 mg/dL to 13.4 mg/dL. The median change was −5.6 mg/dL.

Figure 61 is a forest plot for the meta-analysis of the mean difference in triglycerides comparing a combination of metformin and rosiglitazone with a combination of metformin and sulfonylureas. There are 4 studies included in this meta-analysis: Derosa 2005 with a mean difference of -16. (95 percent CI -31.6 to -.4), Garber 2006 with a mean difference of 9. (95 percent CI -22. to 40.), Home 2007 with a mean difference of 23.1 (95 percent CI 4.5 to 41.8), Hamann 2008 with a mean difference of 5.3 (95 percent CI -26.3 to 37.0). Numbers greater than 0 favor the combination of metformin and sulfonylureas and numbers less than 0 favor the combination of metformin and rosiglitazone. The pooled mean difference was 4.63 mg/dL (95 percent confidence interval -16.50 mg/dL to 25.77 mg/dL). There was statistically significant heterogeneity across the studies.

Combination of metformin and pioglitazone versus combination of metformin and sulfonylureas. Two RCTs compared the combination of metformin and pioglitazone to metformin and a sulfonylurea.126,158 In both studies, TG decreased in the metformin and pioglitazone arm. TG decreased in the metformin and sulfonylurea arm in one study126 and increased slightly in another.158 Between-group differences ranged from −10 mg/dL (p = 0.30) to −24.9 mg/dL (p = 0.045) for the combination of metformin and pioglitazone relative to the combination of metformin and a sulfonylurea.126,158

Combination of metformin and rosiglitazone versus combination of metformin and DPP-4 inhibitors. One double-blind small RCT lasting 18 weeks compared maximum dose metformin plus rosiglitazone to the combination of maximum dose metformin plus sitagliptin showing a significant between-group difference in TG (mean difference in percentage change from baseline of 17.9 percent, 95 percent CI 6.7 percent to 29.2 percent).85 Another small RCT 16 weeks in duration found that the mean percent decrease in TG from baseline was greater in the metformin plus rosiglitazone arm compared with the metformin plus sitagliptin arm (mean difference in percentage change from baseline of 25.4 percent, significance not reported).130

Combination of metformin and rosiglitazone versus combination of metformin and repaglinide. One RCT lasting 26 weeks compared metformin plus rosiglitazone twice daily with the combination of metformin plus repaglinide twice daily and three times daily, showing no significant between-group difference in TG (7.4 mg/dL, p = 0.60).131

Combination of metformin and rosiglitazone versus combination of metformin and GLP-1 agonists. A single small RCT 20 weeks in duration compared metformin plus rosiglitazone with metformin plus exenatide and found a between-group mean difference in TG of 36.3 mg/dL (significance not reported).132

Combination of metformin and pioglitazone versus combination of pioglitazone and sulfonylureas. On a post hoc analysis in a single RCT, addition of pioglitazone to a sulfonylurea decreased TG (−28.5 mg/dL, p = 0.017) relative to the addition of pioglitazone to metformin (−17.8 mg/dL, p = 0.07) at 6 months.158

Combination of metformin and sulfonylureas versus combination of metformin and meglitinides. Two moderately sized double-blinded RCTs lasting 1 to 2 years directly compared the combination of metformin plus sulfonylurea with metformin plus nateglinide.135,136 One study reported that TG decreased by approximately 10 percent in both groups.136 The other study reported a decrease in TG in each arm which was greater in the metformin plus sulfonylurea arm compared to the metformin plus nateglinide arm (between group difference −6 mg/dL).

Combination of metformin and sulfonylureas versus combination of metformin and premixed insulin. A single RCT lasting 4 months compared the combination of metformin and 70/30 insulin aspart with the combination of metformin and a sulfonylurea, and TG decreased less in the metformin and premixed insulin group relative to the metformin plus sulfonylurea group (between-group difference 13.3 mg/dL), but this difference was not statistically significant.138

Combination of metformin and sulfonylurea versus combination of rosiglitazone and sulfonylureas. One RCT lasting only 12 weeks reported less of a decrease in TG in the metformin plus sulfonylurea compared with the rosiglitazone plus sulfonylurea arm (between-group difference 20.5 mg/dL, p = 0.63).42 The RECORD trial reported a between-group difference in HDL of −0.4 mg/dL (p > 0.05) at 18 months124 and −1.6 mg/dL (p < 0.0001) at 5.5 years16 comparing metformin plus sulfonylurea to rosiglitazone plus sulfonylurea.

Combination of metformin and sulfonylurea versus combination of pioglitazone and sulfonylureas. One RCT reported that median TG increased by 17.8 mg/dL (p = 0.60) in the metformin plus sulfonylurea group relative to the pioglitazone plus sulfonylurea group at 24 weeks.141 Another 24-week study reported that mean TG increased by 31.1 mg/dL (p < 0.05) in the metformin plus sulfonylurea group relative to the pioglitazone plus sulfonylurea group.158 A longer RCT (52 weeks) reported that TG decreased in both arms but less so in the metformin plus sulfonylurea arm (between-group difference −12.5 mg/dL, p = 0.008).140 Another small RCT reported median TG at baseline and 24 weeks and found that median TG increased by 17.7 mg/dL in the metformin plus sulfonylurea arm compared with the pioglitazone and sulfonylurea arm (significance not reported).160

Combination of metformin and DPP-4 inhibitors versus combination of metformin and GLP-1 agonists. A single RCT lasting 26 weeks compared the combination of metformin and sitagliptin with the combination of metformin and one of 2 doses of liraglutide.143 TG decreased in all arms. Compared with metformin plus sitagliptin, TG decreased less in the metformin plus 1.2 mg liraglutide arm (between group difference −18.6 mg/dL, 95 percent CI −40.7 mg/dL to 3.5 mg/dL) but decreased more in the metformin plus 1.8 mg liraglutide arm (between-group difference 2.7 mg/dL, 95 percent CI −18.6 mg/dL to 24.8 mg/dL).143

### Publication Bias

Overall, we did not find strong evidence for publication bias in this literature. Across all analyses of intermediate outcomes, there were only two statistically significant comparisons (p < 0.05) by the less conservative Egger’s test. Metformin versus rosiglitazone for the TG outcome was one of the comparisons (p = 0.02, number of studies (N) = 6). Based on the funnel plot, this comparison was missing one or two large studies with smaller between-group differences and missing a few smaller studies with larger between-group differences. Including a few larger studies with smaller between-group differences and smaller studies with larger between-group differences may have slightly changed the effect size, but would have been unlikely to change the overall conclusions showing that metformin reduces triglycerides compared with rosiglitazone. The second comparison with significant publication bias was metformin versus metformin plus thiazolidinedione for HbA1c outcome (p = 0.002, number of studies (N) = 11). Few to no small studies with smaller between-group differences were included based on the funnel plot. This may have led to a slight overestimation of effect; however, including these types of studies would likely not have changed the overall conclusion. For all other comparisons, the funnel plots appeared roughly symmetrical and the Begg’s and Egger’s tests were not significant. In most cases, the number of studies in each comparison was small and was unlikely to have had high power to detect moderate publication bias.

### Gray Literature

After reviewing the data from the FDA and clinical trials registry, we found this data to be consistent with the published peer-reviewed literature included in this report on the intermediate outcomes.

### Applicability

The applicability of these studies to the question of comparable efficacy and effectiveness of the drugs will depend largely on the comparability of the drug interventions, duration of exposure to the drug, and how similar the trial populations are to the U.S. population with type 2 diabetes. The studies had generally applicable populations, interventions, outcomes, and settings to adults with type 2 diabetes in the United States with a few exceptions: less comorbidity, less older populations, less racial diversity, and shorter duration of drug exposure.

Study population differences are the most pronounced threat to applicability for this section. As mentioned under study population characteristics, study participants were mainly middle-aged, overweight or obese adults who had diabetes between 3 to 6 years duration. This is similar to the general U.S. population of type 2 diabetes.161 However, most of the studies excluded older people over the age of 75 or 80 years and excluded people with significant renal, hepatic, cardiovascular disease, and other significant comorbidity, making these studies less applicable to type 2 diabetic adults with comorbidity and older adults with diabetes. When race was reported, most subjects were Caucasian. These studies are therefore less applicable to people of different races, some of whom have greater diabetes disease burden than Caucasians (i.e., African Americans, Hispanics, and Pima Indians).2,162,163

While comparability of interventions could impact applicability, most studies used comparable dosing, frequency, and monitoring to usual care. One possible threat to applicability relates to the duration of drug exposure, especially for glycemic control. All but four studies lasted 2 years or less. Longer exposure to certain diabetes medications may begin to show differences in glycemic control later than most of these trials, especially since insulin sensitivity may allow insulin sensitizers to work longer as monotherapy than non-insulin sensitizers. In usual care, diabetes subjects are kept on medications for over 10 years and are on multiple medications which impacts adherence and side effects. If we were able to determine comparable effectiveness in glycemic control over a longer time frame, we might be able to reduce the number of medications a person takes for a longer period of time after diagnosis (assuming there were differences in glycemic control over longer time frames, and that these differences impacted longer term clinical outcomes).

We had few concerns regarding applicability of the trial settings to usual care. While many trials did not take place exclusively in the United States, they did occur in similar settings. About half the trials occurred partly or exclusively in the United States (n = 32), Italy (n = 13), and/or were multinational (n = 28); the rest of the trials occurred in developed or newly industrialized countries. However, few of the trials (about 10 percent) reported on the setting for recruitment such as outpatient versus inpatient or primary care versus specialty care.

## Key Question 2 In adults age 18 or older with type 2 diabetes mellitus, what is the comparative effectiveness of the treatment options (see list of comparisons) in terms of the following long-term clinical outcomes?

- All-cause mortality
- Cardiovascular mortality
- Cardiovascular and cerebrovascular disease morbidity (e.g., myocardial infarction and stroke)
- Retinopathy
- Nephropathy
- Neuropathy

### Key Points and Evidence Grades

#### All-Cause Mortality

- The majority of comparisons were graded with low strength of evidence because many RCTs had short duration (less than 1 year) and had few deaths, limiting the precision of results.
- Metformin was associated with lower risk of all-cause mortality compared with a sulfonylurea, with low strength of evidence because of moderate risk of bias from primarily observational studies, and inconsistent results when compared to a 4-year RCT.
- We found insufficient evidence for several comparisons, including: most DPP-4 inhibitor and GLP-1 agonist comparisons; rosiglitazone versus pioglitazone; comparisons involving insulin in combination with an oral agent; and the majority of other combination therapy comparisons, including those using insulin.

#### Cardiovascular Mortality

- Only one RCT, the RECORD trial, had cardiovascular disease mortality as its primary outcome, and the completeness of its outcome ascertainment has been a source of concern.
- The majority of studied comparisons were graded with low strength of evidence because many RCTs had short duration (less than 1 year) and had few deaths, limiting the precision of results.
- Metformin was associated with slightly lower risk of cardiovascular mortality compared with a sulfonylurea, with low strength of evidence because of high imprecision and moderate risk of bias, with the majority of studies being observational.
- Risk of cardiovascular mortality was similar between metformin and thiazolidinediones as monotherapy, with low strength of evidence because of high imprecision and moderate risk of bias.
- Metformin alone was slightly favored over a combination of metformin and rosiglitazone for lower risk of fatal myocardial infarction, with consistent direction of results, but high imprecision.
- We found insufficient evidence for several comparisons, including: most DPP-4 inhibitor and GLP-1 agonist comparisons; rosiglitazone versus pioglitazone; and the majority of combination therapy comparisons, including those using insulin.

#### Cardiovascular and Cerebrovascular Morbidity

- Only six studies reported any cerebrovascular morbidity outcomes (stroke, transient ischemic attack).
- The majority of these comparisons were graded with low strength of evidence because many RCTs had short duration (less than 1 year) and had few cardiovascular or cerebrovascular events, limiting the precision of results.
- Risk of cardiovascular and cerebrovascular morbidity between metformin and thiazolidinedione as monotherapy was inconclusive, with low strength of evidence because of high imprecision and inconsistency in direction of findings.
- Metformin alone was slightly favored over a combination of metformin and rosiglitazone for lower risk of combined fatal and non-fatal ischemic heart disease, with consistent direction of results but high imprecision, which did not reach the level of statistical significance. The pooled odds ratio (OR) for combined fatal and nonfatal ischemic heart disease events was 0.463, 95 percent CI 0.17 to 1.10.
- We found insufficient evidence for several comparisons, including: most DPP-4 inhibitor and GLP-1 agonist comparisons; rosiglitazone versus pioglitazone; and the majority of combination therapy comparisons, including those using insulin.

#### Retinopathy

- We found insufficient evidence for the outcome of retinopathy.

#### Nephropathy

- For most comparisons addressed in this review, there was insufficient evidence about nephropathy. Where evidence was available, it was mostly of low strength because the studies were at moderate to high risk for bias, provided imprecise results, or used surrogate outcomes that provided indirect evidence only.
- The only comparison with moderately strong evidence showed that pioglitazone has favorable effects on renal function compared to metformin over a treatment period of 1 year. It is unclear whether the statistically significant reductions in urinary albumin-to-creatinine ratio translate into lower rates of nephropathy.

#### Neuropathy

- For most comparisons addressed in this review, there was insufficient evidence about neuropathy.
- We found low strength of evidence for three comparisons for the outcome of neuropathy: metformin versus metformin plus a thiazolidinedione; metformin versus metformin plus DPP-4 inhibitors; and metformin plus a thiazolidinedione versus metformin plus a sulfonylurea. Where evidence was available, it was graded as low strength because studies were at high risk for bias, had low sample sizes, and had poorly defined outcomes. As a consequence, we could not draw any conclusions regarding the comparative effects of oral diabetes drugs on neuropathy.

See Table 5 for the evidence grades and specific conclusions for each comparison. Details of the evidence grades are in Appendix G, Table 5.

Table 5 Strength of evidence and key findings comparing diabetes medications as monotherapy or combination therapy for long-term clinical outcomes

Comparison | All-cause mortality | CVD mortality | CVD and cerebrovascular morbidity | Nephropathy, neuropathy
MONOTHERAPY COMPARISONS
Metformin versus
TZD | Neither favored; Low | Neither favored; Low | Unclear; Low | Favors Pio^*^; Mod
SU | Favors Met; Low | Favors Met; Low | Unclear; Low | Unclear^*^; Low Insufficient^†^
DPP-4 inhibitor | Unclear; Low | Insufficient | Insufficient | Insufficient
Meglitinide | Unclear; Low | Unclear; Low | Unclear; Low | Insufficient
GLP-1 agonist | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + TZD | Unclear; Low | Unclear; Low | Unclear; Low | Insufficient^*^ Unclear^†^; Low
Metformin + SU | Neither favored; Low | Unclear; Low | Favors Met; Low | Insufficient
Metformin + DPP-4 inhibitor | Unclear; Low | Unclear; Low | Unclear; Low | Insufficient^*^ Unclear^†^; Low
Metformin + meglitinide | Unclear; Low | Unclear; Low | Unclear; Low | Insufficient
TZD versus
TZD | Insufficient | Insufficient | Unclear; Low | Insufficient
SU | Neither favored; Low | Unclear; Low | Unclear; Low | Unclear^*^; Low
DPP-4 inhibitor | Insufficient | Insufficient | Insufficient | Insufficient
Meglitinide | Insufficient | Insufficient | Insufficient | Unclear^*^; Low
GLP-1 agonist | Unclear; Low | Insufficient | Unclear; Low | Insufficient
SU versus
DPP-4 inhibitor | Insufficient | Insufficient | Insufficient | Insufficient
Meglitinide | Unclear; Low | Unclear; Low | Unclear; Low | Insufficient
GLP-1 agonist | Insufficient | Insufficient | Insufficient | Insufficient
DPP-4 inhibitor versus
Meglitinide | Insufficient | Insufficient | Insufficient | Insufficient
GLP-1 agonist | Insufficient | Insufficient | Insufficient | Insufficient
COMBINATION COMPARISONS
Metformin + another agent versus
Metformin + TZD | Unclear; Low | Unclear; Low | Unclear; Low | Low. Conclusion unclear for nephropathy and neuropathy.
Metformin + SU | Unclear; Low | Unclear; Low | Unclear; Low | Insufficient
Metformin + meglitinide | Unclear; Low | Insufficient | Insufficient | Insufficient
Metformin + DPP-4 inhibitor | Unclear; Low | Unclear; Low | Unclear; Low | Insufficient
Metformin + GLP-1 agonist | Insufficient | Unclear; Low | Insufficient | Insufficient
Metformin + basal insulin | Insufficient | Unclear; Low | Unclear; Low | Insufficient
Metformin + premixed insulin | Unclear; Low | Unclear; Low | Insufficient | Insufficient
TZD + another agent versus
Metformin + TZD | Insufficient | Insufficient | Unclear; Low | Insufficient
Metformin + SU | Unclear; Low | Insufficient | Unclear; Low | Insufficient
Metformin + meglitinide | Unclear; Low | Insufficient | Insufficient | Insufficient
Metformin + DPP-4 inhibitor | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + GLP-1 agonist | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + basal insulin | Unclear; Low | Insufficient | Insufficient | Insufficient
Metformin + premixed insulin | Unclear; Low | Insufficient | Unclear; Low | Insufficient

CVD = cardiovascular disease; DPP-4 inhibitor = dipeptidyl peptidase-4 inhibitor; GLP-1 agonist = glucagon-like peptide 1 agonist; Met = metformin; Pio = pioglitazone; SU = sulfonylurea; TZD = thiazolidinedione

Data presented here are strength of the evidence and main conclusion. The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable.

* Key finding for nephropathy.

† Key finding for neuropathy.

### Study Design and Population Characteristics

Sixty-six studies (totaling 67 publications) reported on the comparative effectiveness of oral diabetes medications on long-term outcomes (Appendix G, Tables 6 and 7). Twenty-three studies occurred in North America, approximately 16 in Europe, and several were multicontinent studies.

Forty-eight studies were RCTs, with the study duration ranging from 12 weeks to 6 years. Fifteen of the RCTs lasted 1 year or more in duration. Only one RCT had a long-term outcome as the primary outcome;16 the others had intermediate outcomes (see Key Question 1), but then also reported the incidence of one or more long-term outcomes (e.g., mortality), usually as an adverse event. Two studies used a crossover design.164,165 Thirty-seven RCTs reported support from a pharmaceutical company.

There were 16 cohort studies and 1 case-control cohort study with duration of followup ranging from 6 months to 8 years, which analyzed data from twelve unique cohorts, with four studies coming from the Saskatchewan Health databases166–169 and three studies coming from the U.K. General Practice Research Database (GPRD).170–172 Two observational studies reported support from a pharmaceutical company.

The mean age of participants ranged from approximately 48 years to 75 years, with the majority of studies reporting a mean age in the mid-50s. Participants were about 50 percent female and the majority Caucasian. Two RCTs reported greater than 25 percent African American participants;85,131 two studies reported 70 percent to 80 percent Hispanic participants;88,130 and four studies were based in Asia.59,108,121,173 Most trials excluded people with coexisting illness, such as renal, cardiovascular, or liver disease.

### The Evidence About All-Cause Mortality (Appendix G, Table 8)

Forty four studies reported the number of deaths by treatment group. Thirty-one studies were RCTs, and 13 studies were observational studies based on data from 7 unique cohorts. Most of the RCTs were of short duration and had no deaths in at least one of the treatment arms. Twenty-nine of the 31 RCTs had support from a pharmaceutical company.

#### Metformin Versus Thiazolidinediones

Randomized controlled trials. Four RCTs compared the effects of metformin versus a thiazolidinedione. A Diabetes Outcome Progression Trial (ADOPT) trial was the largest of these trials and had the longest duration. This study, which recruited participants from 488 different centers in the United States, Canada, and Europe, randomized participants to treatments with rosiglitazone, metformin, or glyburide for a median duration of 4 years.38 There were 1,454 participants in the metformin arm and 1,456 in the rosiglitazone arm, and there was a similar number of deaths in each of these two arms with 31 (2.1 percent) and 34 (2.3 percent) deaths during followup respectively. Another trial comparing metformin and rosiglitazone of 32 weeks duration reported no deaths in either arm.49 The other two trials compared metformin and pioglitazone.52,53 The larger of these trials, which lasted 52 weeks, also had a similar number of deaths in each arm: two in the metformin arm and three in the pioglitazone arm.52

Observational studies. Two cohort studies compared the effects of thiazolidinediones and metformin. One cohort study using data from the U.K. GPRD found no significant difference in all-cause mortality between users of rosiglitazone as monotherapy (n = 8,442) and users of metformin as monotherapy (n = 68,181) with users of rosiglitazone having an adjusted hazard ratio (HR) of 1.07 (95 percent CI 0.77 to 1.49) compared to metformin users over a mean followup period of 7.1 years.171 Another cohort study used data from the Cleveland Clinic electronic health record system (EHR) on people with newly and previously diagnosed diabetes from 1998 to 2006.^174^ It also found no significant difference in all-cause mortality between users of rosiglitazone as monotherapy for their initial treatment of diabetes compared with users of metformin as initial monotherapy (adjusted HR 1.33, 95 percent CI 0.93 to 1.91) or between users of pioglitazone as monotherapy for their initial treatment of diabetes compared to users of metformin as initial monotherapy (adjusted HR 1.08, 95 percent CI 0.78 to 1.51). This study, however, did not describe the followup time of participants, nor did it describe what, how many, or when other medications might have been added on to these initial regimens during the study period.

Metformin versus sulfonylureas. Five RCTs and 11 observational studies, reporting findings from 5 unique cohorts, evaluated the effect of metformin versus a sulfonylurea (Table 6).

Table 6 Studies comparing metformin versus sulfonylurea for all-cause mortality

Author, year | Number of deaths: metformin versus sulfonylurea | Measure of association | Estimate of the measure of association (95% CI) (sulfonylurea as reference group)
Randomized controlled trials
Chien, 2007^59^ | 0/17 versus 0/17 | NR | NR
Kahn, 2006^38^ | 31/1454 versus 31/1441 | NR | NR
Garber, 2003^61^ | 0/164 versus 0/151 | NR | NR
Goldstein, 2003^62^ | 0/76 versus 0/84 | NR | NR
DeFronzo, 1995^70^ | 1/210 versus 0/209 | NR | NR
Cohort studies
Kahler, 2007^175^ | 82/2988 versus 1005/19053 | Adjusted OR | 0.87 (0.68 to 1.10)
Simpson, 2006^166^ | 39.6/1000 person-years versus 61.4/1000 person-years | Unadjusted OR^*^ | 0.55 (0.47 to 0.63)
Johnson, 2002^168^ | 159/1150 versus 750/3033 | Adjusted OR | 0.60 (0.49 to 0.74)
Eurich, 2005^169^ | 69/208 versus 404/773 | Adjusted HR | 0.70 (0.54 to 0.91)
Evans, 2006^176^ | 4.7% versus 17.9% | NR | NR
Gulliford, 2004^170^ | 144/2232 versus 1030/6620 | Unadjusted OR^*^ | 0.35 (0.29 to 0.42)
Fisman, 2001^177^ | 25/79 versus 324/953 | Unadjusted OR^*^ | 0.90 (0.56 to 1.47)
Fisman, 1999^178^ | 20/78 versus 234/1041 | NR | NR
Tzoulaki, 2009^171^ | NR | Adjusted HR^*^ | 0.81 (0.74 to 0.88)
Pantalone, 2008^174^ | NR | Adjusted HR | 0.54 (0.46 to 0.64)

* Calculated for this report from values published in study

CI = confidence interval; HR = hazard ratio; NR= not reported; OR = odds ratio

Randomized controlled trials. Of the RCTs, four trials lasted less than 30 weeks. Described above, the ADOPT trial was the largest and with the longest duration; 1,454 participants were randomized to metformin and 1,441 to glyburide. There were equal number of deaths from any cause, with 31 deaths in each arm.38 Three smaller trials were of short duration (16 to 18 weeks) and reported no deaths in either treatment arm.59,61,62 One 29-week study had a single death in the metformin arm and no deaths in the sulfonylurea arm.70

Observational studies. Three observational studies166,168,169 reported all-cause mortality from the cohort based on the Saskatchewan Health registry, which maintains health records for people in the province with prescription drug benefits, and compared metformin versus a sulfonylurea as monotherapy. One study reported an adjusted OR of all-cause mortality of 0.60 (95 percent CI 0.49 to 0.74) for those on metformin compared with sulfonylurea monotherapy, adjusted for age, sex, chronic disease score, and nitrate use.168 Similar results were found in another study which found that higher doses of sulfonylurea were associated with even higher risk of death.166

Another study from this cohort examined people with incident heart failure who were then initiated on either sulfonylurea or metformin monotherapy with a mean followup time of 2.5 years.169 This study reported a higher number of deaths among those on a sulfonylurea alone. The sulfonylurea group had 404 deaths out of 773 people (52 percent) compared with 69 deaths out of 208 people in the metformin group (33 percent). Adjusted multivariate analyses confirmed these findings, with a lower HR of death among those on metformin of 0.70 (95 percent CI 0.54 to 0.91) compared with those on sulfonylurea monotherapy, after adjusting for age, sex, chronic disease score, medications, and number of physician visits before diagnosis of heart failure.

A cohort study that followed people receiving care through the U.K. National Health Service in Tayside, Scotland for about 8 years also reported a higher risk of overall mortality among those on sulfonylurea compared with metformin monotherapy, with an adjusted risk ratio of mortality of 1.43 (95 percent CI 1.15 to 1.77).176

Three observational studies170–172 reported all-cause mortality from the cohort based on the UK GPRD, which maintains de-identified health records of about 5 million people, and compared metformin versus a sulfonylurea as monotherapy. One of these studies, with patient data from 1992 to 1998 and with a mean duration of followup of 1.7 to 3.5 years, described a higher rate of death among users of sulfonylurea alone compared with metformin. The crude mortality rate was 58.6 per 1000 person-years in the sulfonylurea group compared with a crude mortality rate of 25.5 per 1000 person-years in the metformin group, with an unadjusted OR of 0.35 (95 percent CI 0.29 to 0.42) among those on metformin compared to sulfonylurea.170 A study using the same database but extending the “enrollment period” from 1990 to 2005 with a longer mean followup period of 7.1 years per person also found a significantly lower risk of mortality in those using metformin as monotherapy compared to sulfonylureas with an adjusted HR of 0.81 (95 percent CI 0.74 to 0.88).171 A nested case-control study using this data drew the same conclusions and found that, over a median followup period of 3.5 years, those on metformin monotherapy had an adjusted relative risk (RR) of death from any cause of 0.70 (95 percent CI 0.64 to 0.75) compared with users of sulfonylurea monotherapy. This lower risk of death persisted among metformin users regardless of the duration of metformin use, which was categorized as less than 4 months, 4 to 8 months, or at least 8 months.172

In a smaller Israeli cohort of people with known coronary artery disease, mortality was similar but slightly higher among those on glyburide compared with metformin.177

A large cohort, the Veterans’ Health Administrations’ Diabetes Epidemiology Cohort, includes all veterans with diabetes who have received care at the Department of Veterans Affairs (VA) centers since October 1996. In that cohort, analysis showed a higher number of deaths among subjects taking sulfonylureas (1,005 deaths of 19,053 people [5.3 percent]) compared with subjects taking metformin only (82 deaths out of 2,988 people (2.7 percent)).175 The adjusted OR for death for metformin versus sulfonylurea was 0.87 (95 percent CI 0.68 to 1.10), after adjusting for propensity score plus age, diabetes duration, HbA1c, serum creatinine, number of physician visits related to diabetes, and use of medications for dyslipidemia and hypertension.175

Finally, the cohort study based on data from the Cleveland Clinic EHR found a lower risk of all-cause mortality among users of metformin as initial monotherapy compared with users of sulfonylureas, with an adjusted HR of 0.54 (95 percent CI 0.46 to 0.64); however, limitations of this study include its lack of description of followup time and lack of description or adjustment for addition of other diabetes medications during the study period.174

Metformin versus meglitinides. Only one 24-week trial assessed the mortality of participants on metformin compared to a meglitinide and reported one death in the metformin arm and no deaths in the nateglinide arm.79

Metformin versus DPP-4 inhibitors. Two short-term RCTs compared the effects of metformin as monotherapy compared to sitagliptin as monotherapy and reported deaths during the study period. One multinational trial over 24 weeks, with 328 participants on metformin monotherapy and 335 participants on sitagliptin monotherapy, reported 3 deaths in the metformin arm and no deaths in the sitagliptin arm.78 The second trial, also multinational and lasting 24 weeks, with 439 participants on metformin monotherapy and 455 participants on sitagliptin monotherapy, reported 1 death in the sitagliptin arm due to metastatic lung cancer, thought not to be related to the study medication.77

Metformin versus a combination of metformin and thiazolidinediones. Four RCTs of relatively short duration, ranging from 24 to 32 weeks, and one article describing post hoc pooled data from two different RCTs lasting 6 months each, compared the effects of metformin as monotherapy versus a combination of metformin plus rosiglitazone. Overall, there were very few deaths in these studies. In one RCT, there were no deaths in either arm.49 For three other RCTs, each reported one death in the combination therapy arm and no deaths in the metformin monotherapy arm.86,87,90 One death was due to sudden death, one was due to an acute myocardial infarction, and one death was due to unknown causes. In the article that describes data from two RCTs in a post hoc fashion, there was one death in the combination therapy arm due to fatal myocardial infarction and no deaths in the metformin monotherapy arm.179

Metformin versus a combination of metformin and sulfonylureas. Four RCTs and four unique cohort studies (published in five articles) assessed the effect of metformin monotherapy versus a combination of metformin plus a sulfonylurea (Table 7). All of these studies had also examined the effect of metformin versus a sulfonylurea, each as monotherapy, and are referred to above.

Table 7 Studies comparing metformin with combination of metformin and sulfonylurea for all-cause mortality

Author, year | Number of deaths: metformin versus combination of metformin and sulfonylurea | Measure of association | Measurement of association (95% CI) (combination therapy as reference group)
Randomized controlled trials
Chien, 2007^59^ | 0/14 versus 0/42 | NR | NR
Garber, 2003^61^ | 0/164 versus 2/171 | NR | NR
Goldstein, 2003^62^ | 0/76 versus 0/87 | NR | NR
DeFronzo, 1995^70^ | 1/210 versus 0/213 | NR | NR
Cohort studies
Kahler, 2007^175^ | 82/2988 versus 468/13820 | Unadjusted OR^*^ | 0.81 (0.63 to 1.02)
Gulliford, 2004^170^ | 144/3099 versus 159/2735 | Unadjusted OR^*^ | 0.79 (0.63 to 1.00)
Johnson, 2002^168^ | 159/1150 versus 635/4683 | NR | NR
Eurich, 2005^169^ | 69/208 versus 263/852 | NR | NR
Fisman, 2001^177^ | 25/79 versus 111/253 | Unadjusted OR^*^ | 0.59 (0.35 to 1.01)
Fisman, 1999^178^ | 20/78 versus 84/266 | NR | NR

* Calculated for this report from values published in study

CI = confidence interval; NR= not reported; OR = odds ratio

Randomized controlled trials. All four RCTs were of short duration, ranging from 16 to 29 weeks. Again, there were few deaths in any of these trials. Two trials reported no deaths59,62 and one study reported two deaths in the combination arm and no deaths in the metformin monotherapy arm.61 Another study reported one death in the metformin as monotherapy arm and no deaths in the combination therapy arm.70

Observational studies. The Veterans’ Health Administrations’ Diabetes Epidemiology Cohort and the UK’s GPRD cohorts found similar numbers of deaths between the metformin monotherapy group and the combination treatment groups, with only slightly higher rates of death among the combination therapy group. In the VA cohort, which followed people for about 2 years, 3.4 percent of those in the combination treatment arm died compared to 2.7 percent in the metformin treatment arm, with an unadjusted OR of death of metformin compared to combination therapy of 0.81 (95 percent CI 0.63 to 1.02).175 In the U.K. GPRD cohort, which followed people for about 6 years, 5.8 percent of people in the combination treatment groups (reported as those who were treated with metformin first then sulfonylurea combined with those treated with sulfonylurea first then metformin) died compared to 4.6 percent in the metformin monotherapy group, with an unadjusted OR of mortality of 0.79 (95 percent CI 0.63 to 1.00) for those on metformin alone compared to those on combination therapy.170

Data from the Saskatchewan Health database also showed similar results with no clear difference in mortality rates for metformin as monotherapy compared with metformin plus a sulfonylurea (13.8 percent versus 13.6 percent, respectively).168 Even among the subgroup of people with heart failure, there was a similar rate of death between these two treatment groups, 33 percent for those on metformin alone and 31 percent for those on the metformin plus sulfonylurea combination therapy.169

Unlike the cohorts described above, the Israeli cohort included only people with known heart disease. There was a higher rate of death among those people who were on metformin plus sulfonylurea combination therapy compared with metformin alone, with a mortality rate of 43.9 percent for those on combination therapy compared to a mortality rate of 31.6 percent for those on metformin alone, with an unadjusted OR of 0.59 (95 percent CI 0.35 to 1.01) of mortality for those in metformin compared to combination therapy, over a mean period of 7.7 years.177

Metformin versus a combination of metformin and DPP-4 inhibitors. Three RCTs looked at the effect of metformin as monotherapy versus metformin combined with sitagliptin. One was a multinational study of 190 participants over approximately 30 weeks. In this study, there was one death due to a myocardial infarction in the metformin group and no deaths in the combination treatment group.93 The second was a 24-week multinational RCT which reported three deaths in the metformin monotherapy arm (n = 328) and no deaths in the combination treatment groups (n = 643).78 The third was a 54-week multinational trial of 1,091 patients, which reported one death in each arm.76

Metformin versus a combination of metformin and meglitinides. Only one RCT looked at the comparison of effects between metformin as monotherapy and metformin combined with a meglitinide agent. This study had one death due to heart disease in the metformin arm and no deaths in the combination arm over a 24-week period.79

Rosiglitazone versus pioglitazone. One cohort study used the Cleveland Clinic EHR to compare the effects of rosiglitazone and pioglitazone on all-cause mortality. This cohort of people with newly and previously diagnosed diabetes from 1998 to 2006 found that those on initial pioglitazone monotherapy had no significant difference in risk of death compared with those on initial rosiglitazone monotherapy, with an adjusted HR of 0.81 (95 percent CI 0.52 to 1.27). This study, however, did not describe the followup time of participants, nor did it describe what, how many, or when other medications might have been added on to these initial regimens.174

Thiazolidinediones versus sulfonylureas. Three RCTs and one cohort study compared the effect of a thiazolidinedione and a sulfonylurea.

Randomized clinical trials. The largest and longest duration of these trials was the ADOPT trial, which reported a similar number of deaths in the rosiglitazone arm compared with the glyburide arm (2.3 percent versus 2.2 percent, respectively).38 A smaller trial lasting 56 weeks reported two deaths in the glyburide arm and no deaths in the pioglitazone arm.101 Another trial reported no deaths in either the thiazolidinedione or sulfonylurea arms.100

Observational study. The cohort from the Cleveland Clinic EHR compared risk of all-cause mortality between initial users of pioglitazone monotherapy versus initial users of sulfonylurea monotherapy as well as between users of rosiglitazone monotherapy versus initial users of sulfonylurea monotherapy. This study found that those in the pioglitazone group had a significantly lower risk of death compared with the sulfonylurea group, with an adjusted HR of 0.59 (95 percent CI 0.43 to 0.81). Those in the rosiglitazone did not have a statistically significant difference in risk of death compared with those in the sulfonylurea group, with an adjusted HR of 0.73 (95 percent CI 0.51 to 1.02). Again, followup time was not specified, and participants could have changed medication regimens during the study period.174

Sulfonylureas versus meglitinides. One RCT compared the effects of a sulfonylurea with a meglitinide. This 1-year U.S. study reported three deaths among the 362 participants randomized to the repaglinide group and one death among the 182 randomized to glyburide.117

Sulfonylureas versus GLP-1 agonists. One 24-week RCT from Japan compared the effects of use of glibenclamide and liraglutide as monotherapy and reported on deaths. This short-term study reported one death in the liraglutide arm due to gastroenteritis, which required hospitalization and subsequent cardio-respiratory arrest, and no deaths in the sulfonylurea arm.121

Combination of metformin and thiazolidinediones versus combination of metformin and sulfonylureas. Two RCTs123,125 directly compared the effect of the combination of metformin plus a thiazolidinedione with the combination of metformin plus a sulfonylurea. One multinational study recruited about 600 participants and randomized them to treatment with metformin plus a sulfonylurea (either glibenclamide or gliclazide) or metformin plus rosiglitazone. This study reported two deaths in each arm over the 52-week treatment period.123 The second trial was also multinational and randomized participants to treatment with metformin combined with glyburide or metformin with rosiglitazone. This trial had one death due to a fatal myocardial infarction in the metformin plus rosiglitazone combination arm and no deaths in the metformin plus sulfonylurea combination arm.125

Combination of metformin and thiazolidinediones versus combination of metformin and meglitinides. One U.S. RCT compared the effect of the combination of metformin with a thiazolidinedione (rosiglitazone) versus the combination of metformin with a meglitinide (repaglinide). This study of 26 weeks reported one death in the metformin plus meglitinide combination arm and no deaths in the metformin plus thiazolidinedione combination arm.131

Combination of metformin and sulfonylureas versus combination of metformin and DPP-4 inhibitors. One multinational RCT compared the effect of the combination of metformin plus a sulfonylurea (glipizide) with the combination of metformin plus sitagliptin. This study randomized 1,172 participants to the 2 treatment arms. At 52 weeks, they reported two deaths in the metformin plus sulfonylurea combination arm and one death in the metformin plus sitagliptin combination arm.133 At 2 years of followup, they had 519 participants and reported 8 deaths in the metformin plus sulfonylurea arm due to various causes including sudden cardiac death, myocardial infarction, cancer, sepsis, and suicide, and still only one death in the metformin plus sitagliptin arm, which was due to trauma.134

Combination of metformin and sulfonylureas versus combination of metformin and meglitinides. Two U.S. RCTs136,152 and one Italian cohort study180 compared the effect of the combination of metformin with a sulfonylurea with the combination of metformin with a meglitinide (nateglinide).

The larger of the RCTs compared metformin plus glyburide versus metformin plus nateglinide over 2 years and reported one death in each arm.136 Another study of similar duration looked at the effect of the same combinations of medications among a subpopulation of its RCT study population (66 participants that were 65 years of age or older) and reported a single death in the metformin plus sulfonylurea combination arm and no deaths in the metformin plus nateglinide combination arm.152

The main purpose of the cohort study that looked at the effect of these combinations of medications was to assess the mortality of people on combinations of secretagogues and biguanides among people with and without ischemic heart disease. Among those with and without ischemic heart disease on a combination of metformin and any sulfonylurea, there were 35 deaths over 6,344 person-months. Among those with and without heart disease who were on metformin and repaglinide, there was a slightly lower mortality rate: 5 deaths over 2,013 person-months.180

Combination of metformin and sulfonylureas versus combination of metformin or sulfonylureas and thiazolidinediones. One large multinational RCT, the RECORD trial, randomized about 4,450 participants to the following four treatments: combination of metformin plus rosiglitazone, combination of metformin plus sulfonylurea, combination of rosiglitazone plus sulfonylurea, and combination of metformin plus sulfonylurea. For analyses for the outcome of all-cause mortality, the two groups assigned to rosiglitazone were combined and compared to the combination of metformin and sulfonylurea. Over a mean of 5.5 years of treatment and followup, there were a similar number of deaths in the two groups with 136 deaths out of 2,220 in the rosiglitazone group and 157 deaths out of 2,227 in the metformin plus sulfonylurea combination group with an HR of mortality of 0.86 (95 percent CI 0.68 to 1.08) for those on rosiglitazone compared to those not on rosiglitazone.16

Combination of metformin and sulfonylureas versus combination of metformin and biphasic insulin. Two multinational RCTs compared the effect of the combination of metformin plus a sulfonylurea with the combination of metformin plus a form of biphasic insulin (insulin aspart 70/30 in one study and insulin lispro 75/25 in the other). Both studies reported one death each in the metformin combined with biphasic insulin arms and no deaths in the metformin combined with sulfonylurea arms during the trial period.137,138

Combination of metformin and sulfonylureas versus combination of thiazolidinediones and sulfonylureas. One RCT directly compared the effect of the combination of metformin plus a sulfonylurea with the combination of a thiazolidinedione plus a sulfonylurea. This study recruited 639 participants from European countries and Canada, who were already on a sulfonylurea, and randomized them to the addition of either metformin or pioglitazone with a mean treatment duration of 11 months. This study reported that there were two deaths in the metformin plus sulfonylurea combination arm and one death in the pioglitazone plus sulfonylurea combination arm.140

### The Evidence About Cardiovascular Mortality (Appendix G, Table 8)

Twelve trials and 4 cohort studies contained 14 head-to-head comparisons of interest for the outcome of cardiovascular mortality.

Metformin versus thiazolidinediones. The ADOPT trial was a large double-blind RCT involving 4,360 patients followed for a median of 4 years, with patients randomly assigned to metformin, rosiglitazone, or glyburide. There were equal rates of cardiovascular mortality in the metformin and rosiglitazone arms, each with two fatal myocardial infarctions (0.1 percent).38 A smaller 24-week RCT of metformin versus pioglitazone did not report any cardiovascular deaths in either arm.53

Metformin versus sulfonylureas. The ADOPT trial also compared metformin with glyburide, and reported slightly higher incidence of cardiovascular mortality in the glyburide arm versus the metformin arm, with two fatal myocardial infarctions in the metformin arm and three in the sulfonylurea arm (0.2 percent versus 0.1 percent), without report of a statistical test.38

In addition, four cohort studies compared metformin with a second-generation sulfonylurea.167,168,176,177 Two of these studies were from the Saskatchewan Health databases, a longitudinal cohort of the residents of this Canadian province. They identified more than 4,000 residents with type 2 diabetes between 1991 and 1999 and grouped them by their first dispensation of an oral diabetes medication. Metformin was associated with lower risk for cardiovascular mortality than any sulfonylurea (HR 0.64, 95 percent CI 0.49 to 0.84), after adjusting for age, sex, chronic disease score, and nitrate use.168 This result was confirmed in another analysis in this same cohort after additional adjustment for a calculated propensity score to adjust for between-group differences (HR 0.76, 95 percent CI 0.58 to 1.00).167 A different 5-year retrospective cohort study of 5,730 Scottish subjects also reported higher mortality from cardiovascular disease in the second-generation sulfonylurea group versus metformin group, after adjustment for potential confounders, including prior cardiovascular disease-related hospital admission (RR 1.70, 95 percent CI 1.18 to 2.45).176

In contrast, a prospective cohort study of 2,275 Israeli patients with type 2 diabetes and prior coronary artery disease showed slightly higher age-adjusted mortality from coronary artery disease in the metformin versus the glyburide groups (30 per 1,000 person-years versus 24.5 per 1,000 person-years, respectively).177

Metformin versus meglitinides. One 24-week RCT with 701 participants reported no cardiovascular deaths in the nateglinide arm and one death in the metformin arm.79

Metformin versus a combination of metformin and thiazolidinediones. Two large RCTs87,90 and one study that reported the combined results of two smaller RCTs179 compared metformin versus metformin with the addition of rosiglitazone. Bailey et al. reported no deaths from cardiovascular disease in the metformin arm. In the metformin plus rosiglitazone arm there was one sudden death in sleep, which may have been sudden cardiac death, and one death related to a myocardial infarction.87 Fonseca et al. was a trial of 348 participants, with 119 randomized to metformin plus 4 mg per day of rosiglitazone, 113 to metformin plus 8 mg per day of rosiglitazone, and 116 to metformin alone. In this study there was one death due to myocardial infarction in the metformin plus 4 mg per day of rosiglitazone arm and none in the other arms.90 The study that pooled the results of two RCTs reported one fatal myocardial infarction out of 126 participants in the metformin plus rosiglitazone arms and no events in the 121 participants in the metformin arms.179 We pooled these three RCTs with four RCTs reporting nonfatal ischemic heart disease events (Figure 62).

Figure 62 Pooled odds ratio of fatal and nonfatal ischemic heart disease comparing metformin with combination of metformin and rosiglitazone

CI = confidence interval; Met = metformin; Rosi = rosiglitazone

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 2.80 with 6 degrees of freedom (p = 0.83)

I-squared statistic = 0%

Figure 62 is a forest plot of the odds ratio of fatal and non-fatal ischemic heart disease comparing metformin with a combination of metformin and rosiglitazone. There are 7 studies included in this meta-analysis. The number of events in the metformin group and the metformin plus rosiglitazone groups in each study are: Stewart, 2006, less than 1 event among 272 patients and 4 events among 254 patients (odds ratio = 0.0); Bailey, 2005, less than 1 event among 280 patients and 2 events among 288 patients (odds ratio =0.0); Jones, 2003, less than 1 event among 121 patients and 1 event among 162 patients (odds ratio = 0.01); Fonseca, 2000, less than 1 event among 116 patients and 1 event among 232 patients (odds ratio = 0.01); Weissman, 2005, 3 events among 384 patients and 5 events among 382 patients (odds ratio = 0.60, 95 percent confidence interval 0.14 to 2.52); Gomez-Perez, 2002, 1 event among 34 patients and 2 events among 76 patients (odds ratio = 1.12, 95 percent confidence interval 0.10 to 12.75); and Rosenstock, 2006, 2 events among 154 patients and 1 event among 155 patients (odds ratio = 2.01, 95 percent confidence interval 0.18 to 22.43). Numbers greater than 1 favor metformin plus rosiglitazone and numbers less than 1 favor metformin. The pooled odds ratio was 0.43 (95 percent confidence interval 0.17 to 1.10). There was no statistical heterogeneity.

Metformin versus a combination of metformin and sulfonylureas. Two of the cohort studies described above (under comparison of metformin versus sulfonylurea) showed decreased cardiovascular mortality in the group taking metformin alone as compared to subjects taking the combination of metformin and sulfonylurea.176,177

Compared with those on metformin monotherapy, one cohort study reported a risk ratio of 1.94 (95 percent CI 1.25 to 3.01) in subjects who were started on metformin, with sulfonylurea subsequently added-on and 2.50 (95 percent CI 1.69 to 3.71) in those started on sulfonylurea with metformin subsequently added-on, but the numbers in these groups were small.176 Risk ratios were adjusted multiple confounding variables, including sociodemographics, cardiovascular risk factors, prior cardiovascular disease admission and use of cardiovascular medications, making confounding by indication less likely.

A second cohort study examined 2,275 Israeli patients with type 2 diabetes and known prior coronary artery disease. Among subjects on metformin alone, the age-adjusted mortality rate for ischemic heart disease per 1,000 person-years was slightly lower compared to the combination of metformin plus sulfonylurea group (30.0 versus 31.2), but these estimates were not adjusted for cardiovascular disease severity.177

Metformin versus a combination of metformin and DPP-4 inhibitors. We identified two RCTs. One was a 30-week RCT in 190 participants on metformin randomized to the addition of sitagliptin or placebo, which reported one fatal myocardial infarction in the metformin plus placebo arm and no cardiovascular deaths in the metformin plus sitagliptin arm.93 The second RCT was a multinational trial with 1,091 participants, and reported one sudden cardiovascular death in the metformin arm in the first 24-weeks of the trial, which was prior to starting metformin treatment, and no cardiovascular deaths in the combination arm.76

Metformin versus a combination of metformin and meglitinides. Horton et al. (described above under metformin versus meglitinides) also contained a metformin plus nateglinide arm, enabling an additional comparison with metformin alone.79 In all arms, there was a single death attributed to cardiovascular disease and it occurred in the metformin alone arm.

Thiazolidinediones versus sulfonylureas. The ADOPT trial also contained a comparison of rosiglitazone with glyburide. As described above, there were two myocardial infarctions in the rosiglitazone arm and three myocardial infarctions in the glyburide arm, but no statistical test of this difference.38

Sulfonylureas versus meglitinides. A 1-year RCT with 576 participants reported one cardiovascular death in the glyburide arm and one in the repaglinide arm.117

Combination of metformin and thiazolidinediones versus combination of metformin and meglitinides. One 26-week RCT comparing metformin plus rosiglitazone versus metformin plus repaglinide reported one death likely attributable to sudden cardiac death in the metformin plus repaglinide arm.131

Combination of metformin and sulfonylureas versus combination of metformin or sulfonylureas and thiazolidinediones. The RECORD study was an open-label noninferiority multicenter RCT with 4,447 participants with type 2 diabetes taking either metformin or a sulfonylurea randomly assigned to one of three arms, metformin plus rosiglitazone, sulfonylurea plus rosiglitazone, or metformin plus sulfonylurea, with time to first cardiovascular hospitalization or death as its primary outcome.16 For analyses of the primary endpoint at a mean of 5.5 years, they combined the two rosiglitazone arms (metformin or sulfonylurea plus rosiglitazone) and compared rosiglitazone with the active control of metformin plus sulfonylurea and showed non-inferiority for cardiovascular mortality (HR 0.84, 95 percent CI 0.59 to 1.18).

Combination of metformin and sulfonylureas versus combination of metformin and DPP-4 inhibitors. One RCT reported in two articles, providing 52-week133 and 2-year data,134 compared metformin plus the sulfonylurea, glipizide, versus metformin plus sitagliptin. After 52 weeks, there were two deaths from cardiovascular disease (one from sudden cardiac death and one from myocardial infarction) in the metformin plus glipizide arm and none in the metformin plus sitagliptin arm.133 No additional cardiovascular mortality was reported during the second year of the trial.134

Combination of metformin and DPP-4 inhibitors versus combination of metformin plus GLP-1 agonists. One 26-week open-label RCT randomized 665 patients with poorly controlled diabetes on metformin alone to the addition of oral sitagliptin (100 mg), or one of two doses of daily subcutaneous injections of liraglutide (1.2 mg or 1.8 mg). It reported one fatal cardiac arrest in the metformin plus sitagliptin arm and none in the metformin plus liraglutide arms.143

Combination of metformin and sulfonylureas versus combination of metformin and premixed insulin. In a 16-week open-label RCT, 341 participants with poorly controlled type 2 diabetes on metformin alone were randomly assigned to metformin plus glibenclamide or metformin plus twice daily insulin aspart 70/30, a premixed insulin analog containing 30 percent soluble, rapid-acting insulin aspart and 70 percent intermediate-acting protamine-bound aspart in each injection.138 There was one death from myocardial infarction in the metformin plus premixed insulin arm and none in the metformin plus glibenclamide arm.

Combination of metformin and basal insulin versus combination of metformin and premixed insulin. A 32-week open-label crossover study randomized 97 patients to metformin plus insulin glargine versus metformin plus insulin lispro 75/25 twice daily. It reported one fatal myocardial infarction in the metformin plus insulin lispro arm and no such events in the metformin plus glargine arm.165

### The Evidence About Cardiovascular and Cerebrovascular Disease Morbidity (Appendix G, Table 8)

Seventeen trials and seven cohort studies contained eighteen head-to-head comparisons of interest for the outcome of cardiovascular disease morbidity. We identified six studies that reported one of the cerebrovascular disease morbidity outcomes.

Metformin versus thiazolidinediones. Three RCTs38,49,55 and five retrospective cohort studies171,173,174,181,182 compared metformin versus rosiglitazone. One small 24-week RCT53 and four cohort studies171,173,174,182 compared metformin versus pioglitazone.

Among the RCTs, the ADOPT trial was the largest (total N = 4360 for three study arms) and had the longest duration of treatment (median 4 years). The study reported minimal differences between the metformin and rosiglitazone arms for nonfatal myocardial infarction and stroke (1.4 percent versus 1.7 percent for nonfatal myocardial infarction, 1.3 percent versus 1.1 percent for stroke, respectively), without a statistical test.38 The other smaller RCTs did not show any difference in event rates.49,55 Among the cohort studies, three reported no increased risk of ischemic heart disease for rosiglitazone compared with metformin.171,174,181

Two cohort studies comparing metformin with rosiglitazone showed increased risk of cardiovascular disease associated with rosiglitazone.173,182 A 6-year retrospective cohort study of newly diagnosed patients with diabetes used Taiwan’s National Health Insurance, and reported higher risk for myocardial infarction (HR 2.09, 95 percent CI 1.36 to 3.24), angina pectoris (adjusted HR 1.79, 95 percent CI 1.39 to 2.30), and transient ischemic attack (adjusted HR 2.57, 95 percent CI 1.33 to 4.96), but not stroke (adjusted HR 1.61, 95 percent CI 0.72 to 3.62) for rosiglitazone compared with metformin. A higher proportion of patients prescribed thiazolidinediones as monotherapy had previous cardiovascular disease compared with the metformin group.173

One 24-week RCT of 60 patients compared metformin with pioglitazone in two of three of its arms and reported no cardiovascular events in either group.53 Four cohort studies comparing metformin and pioglitazone171,173,174,182 showed no significant difference in cardiovascular disease risk between groups.

Metformin versus sulfonylureas. Two RCTs38,68 and five cohort studies167,171,173,174,181 reported outcomes for metformin versus a second-generation sulfonylurea

The ADOPT trial, described above, also contained a glyburide arm. Incidences of nonfatal myocardial infarction and stroke in the glyburide arm were 1.0 percent and 1.2 percent, respectively, showing minimal difference compared with the metformin arm (1.4 percent and 1.3 percent, respectively), without a statistical test.38 Two large cohort studies did not show significant differences in cardiovascular events.171,174 Tzoulaki et al. reported the results of a large cohort study of 91,521 people with diabetes in the United Kingdom general practice research database and described no increase in the risk of incident myocardial infarction in its fully adjusted model for users of second-generation sulfonylureas compared with metformin users (adjusted HR 1.09, 95 percent CI 0.94 to 1.27).171

Conversely, two cohort studies described higher risk of cardiovascular disease morbidity for a sulfonylurea versus metformin.167,181 In the retrospective cohort study from Saskatchewan health databases, metformin was associated with a decreased risk of nonfatal cardiovascular hospitalization as compared with unspecified sulfonylurea (HR 0.78, 95 percent CI 0.63 to 0.97) in the fully adjusted model.167 McAfee et al. reported a 23 percent risk reduction of the composite outcome of acute myocardial infarction or coronary revascularization for metformin as compared with sulfonylurea monotherapy (HR 0.77, 95 percent CI 0.62 to 0.96), in a propensity score matched cohort study.181 Hsaio et al. only reported crude cardiovascular event rates for this comparison.173

Metformin versus meglitinides. Only one 24-week RCT with 701 participants compared metformin with nateglinide and reported low rates of study-related electrocardiogram abnormalities in both arms.79

Metformin versus a combination of metformin and thiazolidinediones. Six RCTs49 85–88 156 and two cohort studies173,181 compared metformin with a combination of metformin plus rosiglitazone and reported the incidence of ischemic cardiac events. One of the cohorts also reported metformin versus metformin plus pioglitazone.173 The six RCTs were similar in study duration (range 18 to 32 weeks) and used doses of rosiglitazone ranging from 2 mg to 8 mg. Scott et al. reported no cardiovascular events in either the metformin or metformin plus rosiglitazone arms.85 The five RCTs that had at least one event in were pooled with the three RCTs reporting nonfatal ischemic heart disease events (totaling seven studies because one study contributed one fatal and one nonfatal event) in a meta-analysis.49,86–88,90,156,179 In a fixed effects model using treatment arm continuity correction for arms with zero events, the pooled odds ratio of ischemic heart disease events was 0.43 (95 percent CI 0.17 to 1.10) for metformin compared with metformin plus thiazolidinedione, which was not statistically significant (Figure 62). Neither Begg’s nor Egger’s tests for publication bias were statistically significant, and the funnel plot for these seven studies was fairly symmetrical, indicating a low likelihood of publication bias.

McAfee et al., a large retrospective cohort study, showed minimal difference in incidence rate ratios (IRR) for the composite outcome of hospitalization for myocardial infarction or coronary revascularization between subjects treated with metformin (IRR 13.90, 95 percent CI 11.80 to 16.27) compared with metformin plus rosiglitazone (IRR 14.26, 95 percent CI 9.37 to 20.86).181 Hsaio et al. only reported crude cardiovascular event rates for this comparison.173

Metformin versus a combination of metformin and sulfonylureas. One RCT68 and one cohort study181 assessed this comparison for cardiovascular morbidity. In a 6-month RCT, Hermann et al. reported a 5 percent versus 14 percent rate of unspecified cardiovascular adverse events in the metformin versus combination metformin plus sulfonylurea arms, respectively.68 In a 36-month retrospective cohort study using claims data, the adjusted incidence rates for the composite outcome of hospitalization for myocardial infarction or coronary revascularization between subjects was lower in subjects started on metformin compared with metformin plus sulfonylurea (adjusted incidence rate of 13.90 versus 19.44, respectively per 1,000 person-years).181 Hsaio et al. did not report adjusted analyses for this comparison.173

Metformin versus a combination of metformin and DPP-4 inhibitors. One 30-week RCT in 190 participants reported three cases (3.1 percent) of angina pectoris in the metformin plus sitagliptin arm and none in the metformin alone arm.93 A shorter 18-week study also reported two coronary artery disease events in the metformin plus sitagliptin arm and none in the metformin alone arm.85

Metformin versus a combination of metformin and meglitinides. Horton et al. (described above under metformin versus meglitinides) also contained an arm of the combination of metformin plus nateglinide arm and reported two study-related electrocardiogram abnormalities in the combination arm and one in the metformin arm.79

Rosiglitazone versus pioglitazone. No RCTs directly compared rosiglitazone with pioglitazone for cardiovascular outcomes, but we identified three cohort studies that included this comparison.171,173,174 Tzoulaki et al. (described under the rosiglitazone versus sulfonylurea comparison) and Pantalone et al. did not show any significant risk difference for ischemic heart disease in rosiglitazone versus pioglitazone users.171,174 Hsaio et al. reported a higher incidence of composite cardiovascular events (which included angina pectoris and myocardial infarction) in rosiglitazone versus pioglitazone users, but no adjusted statistical analyses was presented and there was evidence of differences in previous cardiovascular disease rates between the two groups.173

Thiazolidinediones versus sulfonylureas. Two RCTs38,149 and three retrospective cohort studies173,181,182 compared rosiglitazone with a sulfonylurea. One RCT101 and two cohort studies173,174 compared pioglitazone with a sulfonylurea. The ADOPT trial (described in detail under metformin versus thiazolidinedione) reported minimal differences between the rosiglitazone arms and sulfonylurea arms for non-fatal myocardial infarction and stroke (1.7 percent versus 1.0 percent for non-fatal myocardial infarction, 1.3 percent versus 1.2 percent for stroke, respectively).38 A 52-week RCT with 351 participants reported a higher incidence of “cardiac-related” adverse events in the rosiglitazone versus glyburide groups (15.4 percent versus 12.1 percent, respectively). These events included mitral insufficiency, tachycardia, myocardial infarction, and palpitations.149

Results from the three cohort studies comparing rosiglitazone with second-generation sulfonylureas were not consistent. One 36-month retrospective cohort study reported a lower adjusted incidence rate for the composite outcome of hospitalization for myocardial infarction or coronary revascularization for rosiglitazone compared with sulfonylureas (adjusted incidence rate of 15.71 versus 19.55 per 1,000 person-years).181 Another cohort study showed no significant differences in risk for myocardial infarction or stroke, but elevated risk for transient ischemic attack (adjusted HR 1.90, 95 percent CI 1.02 to 3.57) and angina pectoris (adjusted HR 1.45, 95 percent CI 1.15 to 1.85) for rosiglitazone versus sulfonylurea.173 Brownstein et al. reported an elevated adjusted risk for myocardial infarction for rosiglitazone compared with a sulfonylurea (RR 1.4, 95 percent CI 1.0 to 2.0).

A 56-week RCT with 502 participants randomly assigned participants to glyburide or pioglitazone. It reported fewer cardiovascular adverse events, defined as coronary artery disease, myocardial infarction, and chest pain, in the pioglitazone arm compared with the glyburide arm (1 percent versus 3 percent).101 One cohort study reported no significant difference in coronary artery disease between pioglitazone and sulfonylurea users.174

Sulfonylureas versus meglitinides. Two 1-year RCTs compared glyburide with repaglinide.116,117 One RCT with over 500 participants reported 5 percent cardiovascular adverse events in the repaglinide arm and 2 percent in the glyburide arm without a statistical test.117 The other RCT had 242 participants and stated that cardiac events occurred with similar frequencies between treatment arms.116

Sulfonylureas versus GLP-1 agonists. One 24-week double-blind RCT of 411 patients randomized to oral glibenclamide versus once-daily subcutaneous liraglutide reported one acute myocardial infarction in the liraglutide arm and none in the glibenclamide arm.121

Combination of metformin and rosiglitazone versus combination of metformin and pioglitazone. One cohort study reported a higher risk of myocardial infarction for metformin plus pioglitazone compared with metformin plus rosiglitazone (HR 6.34, 95 percent CI 1.80 to 22.31), although the estimated precision was very low, with a wide confidence interval. There was no difference in risk of stroke, angina pectoris, and transient ischemic attack for this same comparison.173

Combination of metformin and thiazolidinediones versus combination of metformin and sulfonylureas. One open-label RCT of 250 participants reported one acute myocardial infarction in the metformin plus pioglitazone arm versus no events on the metformin plus sulfonylurea arm.129

Combination of metformin and thiazolidinediones versus combination of metformin and meglitinides. One 26-week RCT comparing metformin plus rosiglitazone versus metformin plus repaglinide reported one subject with ventricular fibrillation and one with non-cardiac chest pain in the metformin plus rosiglitazone arm, and one transient ischemic attack in the metformin plus repaglinide arm.131

Combination of metformin and thiazolidinediones versus combination of metformin and DPP-4 inhibitors. Another 18-week trial reported no cardiovascular events in the 87 participants in the metformin plus rosiglitazone arm, and two coronary artery disease events in the 94 participants in the metformin plus sitagliptin arm.85

Combination of metformin and sulfonylureas versus combination of metformin or sulfonylureas and thiazolidinediones. The RECORD study, a 5.5-year RCT of 4,447 subjects, combined the two rosiglitazone arms (metformin or sulfonylurea plus rosiglitazone) and compared results with the active control of metformin plus sulfonylurea to assess cardiovascular outcomes. Fatal and nonfatal myocardial infarctions were combined and showed no difference between the two combined rosiglitazone arms and metformin plus sulfonylurea arm (HR 1.14, 95 percent CI 0.80 to 1.63). Fatal and nonfatal stroke were also combined and showed no difference between the two combined rosiglitazone arms and metformin plus sulfonylurea (HR 0.72, 95 percent CI 0.49 to 1.06).16

Combination of metformin and thiazolidinediones versus combination of metformin and DPP-4 inhibitors. One 16-week open-label trial randomized 169 patients with inadequate glycemic control on metformin alone to rosiglitazone versus sitagliptin and reported one transient ischemic attack each in the rosiglitazone and sitagliptin arms.130

Combination of metformin and sulfonylureas versus combination of metformin and DPP-4 inhibitors. In a 52-week trial with 1,172 participants, there was one myocardial infarction in the metformin plus glipizide arm compared with none in the metformin plus sitagliptin arm.133 There were no additional events reported at 2 years of followup.134

Combination of metformin and DPP-4 inhibitors versus combination of metformin plus GLP-1 agonists. One 26-week open-label RCT randomized 665 patients on metformin alone to the addition of oral sitagliptin (100 mg), or one of two doses of daily subcutaneous injections of liraglutide (1.2 mg or 1.8 mg). It reported the occurrence of “cardiac disorders” in one patient on metformin plus 1.8 mg liraglutide and in one patient on metformin plus sitagliptin.143

Combination of metformin and basal insulin versus combination of metformin and premixed insulin. In a 16-week cross-over study, 105 patients with newly diagnosed type 2 diabetes were randomly assigned to metformin plus insulin glargine versus metformin plus insulin lispro 75/25 twice daily.164 In addition, there was an 8-week lead-in period when patients received neutral protamine Hagedorn at night and the metformin dose was titrated. During the lead-in period, one patient experienced a myocardial infarction, and during treatment with the premixed insulin there was one case of chest pain, but it was not reported whether these events occurred before or after the crossover.164

Combination of metformin and thiazolidinediones versus combination of thiazolidinediones and sulfonylureas. Rosak et al. was a 6-month observational study of over 22,000 patients in Germany. Fewer myocardial infarctions and strokes occurred in the group with rosiglitazone added onto metformin therapy compared with the rosiglitazone plus sulfonylurea combination (incidence of 0.04 percent versus 0.11 percent for myocardial infarction and 0.01 percent versus 0.18 percent for stroke, respectively).183

A limitation of the RECORD study was that it contained separate metformin plus thiazolidinedione and sulfonylurea plus thiazolidinedione arms to make this comparison, but did not report these analyses for cardiovascular disease morbidity.16

Combination of metformin and sulfonylureas versus combination of thiazolidinediones and sulfonylureas. One 52-week trial with 639 participants compared metformin plus a sulfonylurea versus pioglitazone plus a sulfonylurea and reported no difference in the incidence of “cardiac disorders” between the two groups (4.1 percent versus 3.1 percent respectively) but no statistical test results were provided.140

### The Evidence About Retinopathy

There were no studies included in the report that evaluated the outcome of diabetic retinopathy.

### The Evidence About Nephropathy (Appendix G, Table 8)

For the nephropathy analyses, we included studies where changes in renal function was described for each treatment group, which could have included the number of patients developing nephropathy or changes in urinary albumin-to-creatinine ratio or glomerular filtration rate. There were nine trials reporting on nephropathy as an outcome.52,66,102-104,108,125,140,184 In none of the studies was nephropathy a primary outcome. It was either a secondary outcome or reported under adverse effects.

Metformin versus thiazolidinediones. Two larger trials (total n = 1,176^52^ and n = 639^140^) compared the effects of metformin and pioglitazone on renal function. In both trials, the urinary albumin-to-creatinine ratio declined in patients receiving pioglitazone by 15 percent140 and 19 percent,52 respectively but remained unchanged in patients with metformin with statistically significant differences between groups in both trials.

Metformin versus sulfonylureas. One small trial of 3 months duration compared metformin with sulfonylurea (glibenclamide).66 Microalbuminuria decreased significantly in patients with metformin while it increased with glibenclamide. Also, glomerular filtration rate remained stable in patients receiving metformin while it increased significantly in patients with glibenclamide. However, no formal between-group comparisons were reported.

Thiazolidinediones versus sulfonylureas. Five small trials compared a thiazolidinedione (pioglitazone or rosiglitazone) with a sulfonylurea.102-104,108,184 One trial found significantly less albuminuria in patients receiving pioglitazone compared with glibenclamide.102 Two other trials also reported reductions in albuminuria with pioglitazone but the differences compared with patients receiving a sulfonylurea were either not significant184 or not reported.103 Another small trial included patients with longstanding diabetes and microalbuminuria and reported reduced urinary albumin excretion with pioglitazone compared to glibenclamide, but no formal statistical comparisons between groups were shown.108

One trial compared 12-month treatment with rosiglitazone and glyburide104 and found no statistically significant difference in the urinary albumin-to-creatinine ratio. Similarly, there was no difference in the proportion of patients with progression to microalbuminuria.

Thiazolidinediones versus meglitinides. One small trial of patients with longstanding diabetes and microalbuminuria compared pioglitazone and nateglinide and reported reduced urinary albumin excretion with pioglitazone as compared with nateglinide. No formal statistical comparisons between groups were shown.108

Combination of metformin and thiazolidinediones versus combination of metformin and sulfonylureas. One trial125 compared metformin plus a thiazolidinedione (rosiglitazone) and metformin plus a sulfonylurea (glyburide) and found a greater reduction of the urinary albumin:creatinine ratio with the combination of metformin plus a thiazolidinedione but the difference to the group with metformin plus a sulfonylurea was not statistically significantly different.

### The Evidence About Neuropathy (Appendix G, Table 8)

For the neuropathy analyses, we included studies where newly developed neuropathy was reported for each treatment group. Three small short-term trials reported on neuropathy as an adverse outcome.88,93,129 In all three studies, neuropathy was reported under adverse effects.

Metformin versus a combination of metformin and thiazolidinediones. One trial88 comparing metformin (n = 34) and metformin plus a thiazolidinedione (rosiglitazone) at 2 different dosages (n = 35 and n = 36, respectively) reported on one withdrawal due to undefined neuropathy in the metformin alone group but did not provide any formal between-group comparison.

Metformin versus a combination of metformin and DPP-4 inhibitors. The other trial93 reported on the incidence of (undefined) diabetic neuropathy with metformin alone (n = 2, 2.1 percent) and metformin plus sitagliptin (n = 4, 4.2 percent) but did not provide a statistical comparison.

Combination of metformin and thiazolidinediones versus combination of metformin and sulfonylureas. In a 6-month trial129 neuropathy was not a prespecified primary or secondary outcome but there was one patient (n = 103) who developed neuropathy in the group with combination metformin plus thiazolidinedione whereas none of the patients with combination metformin plus sulfonylurea (n = 80) developed neuropathy.

### Summary of Results of Updated Search Through December 2010 for Long-Term Clinical Outcomes

We screened 805 records and identified 4 articles that addressed Key Question 2’s long term clinical outcomes (Appendix H). Two were RCT’s;185,186 one185 trial was a 50-week extension of a previously included 54-week study.76 The other two articles were observational studies.187,188 Results of these four studies were consistent with our review’s findings and did not change the conclusions or strength of evidence grades.

### Gray Literature

We found eight unpublished reports from clinicaltrials.gov and the Food and Drug Administration (FDA) Web site that reported on long-term clinical outcomes for our comparisons of interest. These results were generally consistent with the results from the published studies included in the review.

Metformin versus thiazolidinediones. One unpublished study had 2,902 subjects in the rosiglitazone group and 225 subjects in the metformin group, and reported myocardial infarction in nine subjects in the rosiglitazone group and one subject in the metformin group.189 This study also reported the occurrence of a cerebrovascular disorder in four subjects in the rosiglitazone group and one in the metformin group.

Metformin versus sulfonylureas. One unpublished study had 160 subjects in the metformin group and 157 in the sulfonylurea group and reported one death due to myocardial infarction in each arm.190 Another unpublished study had 225 subjects in the metformin group and 626 subjects in the sulfonylurea group, and reported myocardial infarction in two subjects in the sulfonylurea group and one in the metformin group.189 An unpublished study had 225 subjects in the metformin group and 626 subjects in the sulfonylurea group, and reported a cerebrovascular disorder in one subject in the metformin group and none in the sulfonylurea group.189

Metformin versus DPP-4 inhibitors. One unpublished 54-week RCT, with 364 subjects in the metformin group and 179 subjects in the sitagliptin group, reported myocardial infarction in one subject in the sitagliptin group and none in the metformin group.191

Metformin versus a combination of metformin and sulfonylureas. One unpublished study had 160 subjects in the metformin arm and 315 subjects on the combination of metformin plus sulfonylurea, and reported one death from myocardial infarction in the metformin group and two deaths in the combination therapy group.192

A 24-week double-blind active-controlled trial, with 521 subjects on metformin plus sulfonylurea and 177 subjects on metformin alone, reported one death in the combination therapy group and none in the metformin group.193

Combination of metformin and sulfonylureas versus combination of metformin and DPP-4 inhibitors. An unpublished 52-week RCT had 559 subjects in the metformin plus glipizide group and 576 subjects in the metformin plus sitagliptin group, and reported one death in the metformin plus sitagliptin combination group and three in the metformin plus glipizide combination group. There were two myocardial infarctions in the metformin plus glipizide combination group, and none in the metformin plus sitagliptin combination group.191

### Applicability

The majority of studies included for Key Question 2 had a short duration limiting their applicability to the assessment of long-term outcomes and complications of diabetes in patients with type 2 diabetes in the U.S. Among the RCTs, the two with the longest study duration were 6 years38 and 7.5 years,16 but the majority were less than 6 months long.

Most trials did not report the source for participant recruitment, such as an outpatient clinical or subspecialty clinical setting, which is relevant because most patients with diabetes are cared for by primary care physicians. In the 29 trials identified since the 2007 report, four reported recruitment from outpatient primary care settings.16,78,131,184 Six studies reported excluding greater than 10 percent of participants following a run-in period, which may limit their generalizability to outpatient settings with varying degrees of medication adherence.49,123,125,133,156,164

Overall, participants were middle-aged, which is fairly representative of the U.S. population with type 2 diabetes, but most studies excluded people greater than age 74. Participants were about 50 percent female and the majority was identified as Caucasian. Notably, two RCTs reported greater than 25 percent African American participants,85,131 although many studies did not report any racial-ethnic breakdown of the participants. Two RCTs took place in Mexico,66,88 and one in both Mexico and Colombia,130 with 70 percent to 80 percent Hispanic participants.88 Most trials had similar exclusion criteria for coexisting illnesses, such as renal, cardiovascular, and hepatic disease, with the implication that participants were overall less complicated, and thus at lower risk for long-term complications of diabetes.

A majority of studies were conducted in the United States or multinational Europe, where the practice of medicine related to the treatment of diabetes is fairly similar. Most studies received pharmaceutical company support.

## Key Question 3 In adults age 18 or older with type 2 diabetes mellitus, what is the comparative safety of the treatment options (see list of comparisons) in terms of the following adverse events and side effects?

- Hypoglycemia
- Liver injury
- Congestive heart failure
- Severe lactic acidosis
- Cancer
- Severe allergic reactions
- Hip and non-hip fractures
- Pancreatitis
- Cholecystitis
- Macular edema or decreased vision
- Gastrointestinal side effects

### Key Points and Evidence Grades

#### Hypoglycemia

- There was high strength of evidence to conclude that the risk of hypoglycemia with sulfonylureas exceeds the risk with metformin with a pooled OR for mild to moderate hypoglycemic events of 4.6 (95 percent CI 3.2 to 6.5) for sulfonylurea versus metformin.
- There was high strength of evidence to conclude that the risk of hypoglycemia with sulfonylureas exceeds the risk with thiazolidinediones with a pooled OR of 3.9, 95 percent CI 3.0 to 4.9 for mild to moderate hypoglycemia for sulfonylurea versus thiazolidinediones.
- There was high strength of evidence to conclude that the risk of hypoglycemia with metformin plus sulfonylurea is about six times as high as the risk of metformin plus thiazolidinediones.
- Moderate grade evidence showed that the risk of hypoglycemia with metformin is comparable to the risk with thiazolidinediones.
- Moderate grade evidence showed that the risk of hypoglycemia with metformin plus sulfonylurea is higher than the risk with metformin alone.
- Moderate grade evidence showed that the risk of hypoglycemia with sulfonylurea exceeds the risk with DPP-4 inhibitors.
- Moderate grade evidence showed a modest increase (OR 3.0, 95 percent CI 1.8 to 5.2) in risk of hypoglycemia with meglitinides over metformin.
- Moderate grade evidence showed a modest increase in risk of hypoglycemia with metformin plus a thiazolidinedione over metformin alone (OR 1.6, 95 percent CI 1.0 to 2.4).
- Moderate grade evidence showed that metformin with aDPP-4 inhibitor has similar risk of hypoglycemia as metformin alone.
- Moderate grade evidence showed that metformin with a sulfonylurea has a higher risk of hypoglycemia than metformin with liraglutide.
- Moderate grade evidence showed a modestly lower risk of hypoglycemia when metformin is combined with a basal insulin rather than a premixed insulin.
- The evidence about hypoglycemia for the other comparisons had low strength or was insufficient.
- No monotherapy or combination therapy convincingly demonstrated more occurrences of severe hypoglycemia than another.

#### Liver Injury

- High grade evidence showed that rates of liver injury are similar between thiazolidinediones and sulfonylureas.
- Moderate grade evidence showed that the rates of liver injury are similar between thiazolidinediones and metformin.

#### Congestive Heart Failure

- Moderate evidence showed that thiazolidinediones increase the risk of heart failure when compared to sulfonylureas.
- There were no long-term trials that provide a robust assessment of the comparative safety of the DPP-4 inhibitors and GLP-1 agonists on the risk of heart failure.

#### Severe Lactic Acidosis

- Moderate strength of evidence indicated that there is no increased risk of lactic acidosis in metformin users compared to those using a sulfonylurea or a combination of metformin and a sulfonylurea.

#### Cancer

- The evidence had low strength and did not allow definitive conclusions about the risk of cancer with any of the antidiabetic medication comparisons.

#### Severe Allergic Reactions

- No studies addressed the outcome of severe allergic reactions, and therefore insufficient evidence.

#### Hip and Non-Hip Fractures

- High grade evidence showed that thiazolidinediones, either in combination with another medication or as monotherapy, are associated with a higher risk of bone fractures compared with metformin alone or in combination with sulfonylurea.

#### Pancreatitis

- The evidence had low strength and did not allow definitive conclusions about the comparative safety of oral antidiabetic agents on the outcome of acute pancreatitis.

#### Cholecystitis

- The evidence had low strength and did not allow definitive conclusions about the comparative safety of diabetes medications regarding the outcome of cholecystitis.

#### Macular Edema or Decreased Vision

- The evidence had low strength and did not allow definitive conclusions about the comparative safety of oral antidiabetic agents on the outcome of macular edema.

#### Gastrointestinal (GI) Side Effects

- High grade evidence showed that metformin was associated with more frequent GI adverse events compared with thiazolidinediones.
- High strength of evidence demonstrated that the rates of GI adverse effects were similar between thiazolidinediones and sulfonylureas.
- Moderate strength of evidence showed that metformin was associated with more frequent GI adverse events compared with second-generation sulfonylureas.
- Moderate strength of evidence showed that metformin monotherapy was associated with more frequent GI adverse events than the combination of metformin plus a second-generation sulfonylurea or metformin plus thiazolidinediones if the metformin component was a lower dose than the metformin monotherapy arm.
- Moderate strength of evidence suggested that a combination of metformin and sulfonylurea is associated with more frequent GI adverse events compared with a combination of a thiazolidinedione and a sulfonylurea.
- Moderate strength of evidence showed that metformin was associated with more frequent GI adverse events compared with DPP-4 inhibitors.

See Table 8 for the evidence grades and specific conclusions for each comparison. Details of the evidence grades are in Appendix G, Table 9.

Table 8 Key findings and strength of the evidence comparing diabetes medications as monotherapy or combination therapy for adverse events

Comparison | Hypoglycemia | Liver Injury | GI adverse events | CHF | Macular edema | Pancreatitis and cholecystitis | Fractures
MONOTHERAPY COMPARISONS
Metformin versus
TZD | Neither favored; Mod | Neither favored; Mod | Favors TZD; High | Neither favored; Mod | Insufficient | Favors Met^*^; Low Insufficient^†^ | Favors Met; High
SU | Favored Met; High | Unclear; Low | Favors SU; Mod | Favors Met; Mod | Insufficient | Insufficient | Unclear; Low
DPP-4 inhibitor | Neither favored; High | Insufficient | Favors DPP-4; Mod | Insufficient | Insufficient | Insufficient | Insufficient
Meglitinides | Favors Met; Mod | Insufficient | Favors Meg^‡^; Low | Insufficient | Insufficient | Insufficient | Insufficient
GLP-1 agonists | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + TZD | Favors Met; Mod | Insufficient | Favors Met+TZD^‡^; Mod | Insufficient | Insufficient | Favors Met+TZD^*^; Low Insufficient^†^ | Favors Met; Low
Metformin + SU | Favors Met; Mod | Insufficient | Favors Met+SU^§^; Mod | Insufficient | Insufficient | Insufficient^*^ Favors Met^†^; Low | Unclear; Low
Metformin + DPP-4 inhibitor | Neither favored; Mod | Insufficient | Unclear; Low | Insufficient | Insufficient | Insufficient | Unclear; Low
Metformin + meglitinides | Favors Met; Low | Insufficient | Unclear; Low | Insufficient | Insufficient | Insufficient | Insufficient
TZD versus
TZD | Favors Rosi; Low | Unclear; Low | Insufficient | Unclear; Low | Insufficient | Insufficient | Insufficient
SU | Favors TZD; High | Neither favored; High | Neither favored; High | Favors SU; Mod | Insufficient | Neither favored^*^; Low Insufficient^†^ | Favors SU; High
DPP-4 inhibitors | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Meglitinides | Favors TZD; Low | Insufficient | Unclear; Low | Insufficient | Insufficient | Insufficient | Insufficient
GLP-1 agonists | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
SU versus
DPP-4 inhibitors | Favors DPP4; Mod | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Meglitinides | Favors Meg; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
GLP-1 agonist | Favors GLP1; High | Insufficient | Favors SU; Low | Insufficient | Insufficient | Insufficient | Insufficient
DPP-4 inhibitor versus
Meglitinides | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
GLP-1 agonists | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient^*^ Neither favored^†^; Low | Insufficient
COMBINATION COMPARISONS
Metformin + another agent versus
Metformin + TZD | Favors Met+TZD; High | Neither favored; Low | Neither favored; Low | Insufficient | Favors Met+ other; Low | Insufficient | Favors Met+ other; High
Metformin + SU | Unclear; Low | Insufficient | Unclear; Low | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + meglitinides | Insufficient | Insufficient | Favors Met+SU^¶^; Low | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + DPP-4 | Insufficient | Insufficient | Neither favored; Low | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + GLP-1 | Insufficient | Insufficient | Unclear; Low | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + basal insulin | Favors Met+Basal Insulin; Mod | Insufficient | Unclear; Low | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + premixed insulin | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
TZD + another agent versus
Metformin + TZD | Favors Met+TZD; Low | Insufficient | Insufficient | Favors Met+ TZD; Low | Insufficient | Insufficient | Insufficient
Metformin + SU | Favors TZD+SU; Low | Neither favored; Low | Favors TZD combination; Mod | Favors Met+SU; Low | Insufficient | Insufficient | Favors Met+SU; High
Metformin + meglitinides | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + DPP-4 | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + GLP-1 | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + basal insulin | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Metformin + premixed insulin | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient

CHF = congestive heart failure; GI = gastrointestinal; Met = metformin; Rosi = rosiglitazone; SU = sulfonylurea; TZD = thiazolidinedione

* Key finding and evidence grade for cholecystitis.

† Key finding and evidence grade for pancreatitis.

‡ For diarrhea only.

§ When lower dose of metformin.

¶ For dyspepsia.

The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Mod = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable.

All other comparisons and intermediate outcomes were graded as insufficient since there were no studies.

### Study Design and Population Characteristics

One hundred thirteen studies are included for Key Question 3 describing adverse effects during treatment (Appendix G, Tables 10 and 11). We included 38 articles from the Comparative Effectiveness Review (CER) published in 2007 that described adverse events for our comparisons of interest and identified an additional 74 studies describing adverse events since completion of that review for this update. The majority of the studies were RCTs. None of the studies was designed explicitly to evaluate adverse events from these medications and medication combinations.

### The Evidence About Hypoglycemia (Appendix G, Table 12)

From the 2007 CER21 we included 29 RCTs,36,50,60,61,63–65,68,70,71,79,81,86,87,89–91,106,109,110,114–119,128,140,149 and 3 cohort studies that reported hypoglycemia.194–196 Of the newly identified studies, 51 wereRCTs,38,44,49,59,75–78,80,82,84,85,92–96,100,101,111,112,120–123,125,126,129–134,136–138,142,144–147,150,152,156,164,165,179,184,197,198 one was a nonrandomized trial199 and four were cohort studies.183,200–202 The high-quality study from by Home, et al. (RECORD), was not used to look at hypoglycemic events because the authors did not report the number of affected people stratified by the therapy accompanying the thiazolidinedione (e.g., rosiglitazone plus sulfonylurea or rosiglitazone plus metformin).16

Metformin versus thiazolidinediones. This comparison was addressed by a single, large trial.38 The trial was the ADOPT study, a high-quality trial comparing metformin, rosiglitazone, and glyburide. There was no significant difference in the number of self-reported hypoglycemic events among individuals receiving rosiglitazone and those receiving metformin (141/1456 versus 167/1454, RR 0.90, 95 percent CI 0.80 to 1.0) with just a single serious event in each group.38

Metformin versus sulfonylureas. Nine RCTs were eligible for pooling,50,59–61,63–65,70,71 although two studies had no events in either arm.59 There was moderate statistical heterogeneity between these studies with an I-squared of 68 percent. The pooled odds ratio having at least one mild or moderate hypoglycemic event was 4.6 (95 percent CI 3.2 to 6.5) with use of sulfonylurea relative to metformin (Figure 63). Only one study reported on severe hypoglycemia and found no significant difference between arms (p = 0.18).68

Figure 63 Pooled odds ratio of having at least one mild or moderate hypoglycemic event comparing metformin with sulfonylureas

CI = confidence interval; Met = metformin; SU = sulfonylurea

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 18.68 with 6 degrees of freedom (p = 0.005)

I-squared statistic = 67.9%

The range of rates for mild to moderate hypoglycemia for the comparison group, sulfonylureas, was 0% to 64.9%. The median rate was 2.8%.

Figure 63 is a forest plot of the odds ratio of having at least one mild or moderate hypoglycemic event comparing metformin with sulfonylureas. There are 7 studies included in this meta-analysis. The number of events in the metformin group and the sulfonylurea groups in each study are: DeFronzo, 1995, 4 events among 210 patients and 6 events among 209 patients (odds ratio = 1.51, 95 percent confidence interval 0.43 to 5.30); Charpentier, 2001, 8 events among 75 patients and 17 events among 150 patients (odds ratio = 1.07, 95 percent confidence interval 0.44 to 2.58); Marre, 2002, 0 events among 104 patients and 7 events among 103 patients (odds ratio = 7.92, 95 percent confidence interval 1.76 to 35.65); Blonde, 2002, 1 event among 153 patients and 3 events among 164 patients (odds ratio = 2.56, 95 percent confidence interval 0.36 to 18.38); Garber, 2002, 0 events among 159 patients and 10 events among 160 patients (odds ratio = 7.78, 95 percent confidence interval 2.21 to 27.37); Garber, 2003, 29 events among 164 patients and 98 events among 151 patients (odds ratio = 7.07, 95 percent confidence interval 4.51 to 11.09); and Yamanouchi, 2005, 0 events among 39 patients and 1 events among 37 patients (odds ratio = 7.80, 95 percent confidence interval 0.15 to 393.60). Derosa 2004 and Chien 2007 were excluded from the analysis. Numbers greater than 1 favor metformin and numbers less than 1 favor sulfonylureas. The pooled odds ratio was 4.59 (95 percent confidence interval 3.24 to 6.50). There was statistically significant heterogeneity across studies.

Two additional RCTs could not be pooled and had results in the same direction as those in the pooled analysis (Table 9).38,198

Table 9 Additional randomized controlled trials comparing metformin with sulfonylurea for hypoglycemia

Author, year | Outcome | Results | Comments
Kahn, 2006^38^ | Self-report hypoglycemia, severity unspecified | 168/1451 in metformin arm versus 557/1441 events in sulfonylurea arm | High quality trial, Individuals with short duration of disease, HbA1c = 7.3% at baseline
Wright, 2006^198^ | Mild to severe (not just transient symptoms) | Mean annual percentage 0.30% in 290 patients in metformin arm versus 1.20% in 1418 patients in sulfonylurea arm | Part of UKPDS study, open-label, HbA1c 6.9% at baseline, mostly non-obese participants

HbA1c = hemoglobin A1c; UKPDS = United Kingdom Prospective Diabetes Study

Metformin versus DPP-4 inhibitors. Three studies looked at this comparison for hypoglycemic outcomes.76–78 The first study of sitagliptin was a continuation of that by Goldstein et al.75 Two of 182 patients randomized to metformin and two of 179 randomized to sitagliptin had mild or moderate hypoglycemic symptoms.76 A more recent study reported that 3.3 percent of the 522 patients treated with metformin had mild or moderate hypoglycemic symptoms while 1.7 percent of the 528 treated with 100 mg daily of sitagliptin did (p = 0.12). There were no patients with severe hypoglycemia in the metformin group and two patients in the sitagliptin group.77 The other study reported 13 patients of 328 treated with metformin and five patients of 335 treated with 10 mg of saxagliptin with mild hypoglycemia and no patient in either group with severe symptoms.78

Metformin versus meglitinides. Five RCTs reported mild or moderate hypoglycemia for this comparison.79–82,197 One had no events in either arm.81 There was minimal statistical heterogeneity between these studies (I-squared = 0.0 percent). The odds ratio for hypoglycemia was 3.0 (95 percent CI 1.8 to 5.2) for meglitinides compared to metformin (Figure 64). No additional trials or observational studies reported this outcome.

Figure 64 Pooled odds ratio of having at least one mild or moderate hypoglycemic event comparing metformin with meglitinides

CI = confidence interval; Meg = meglitinides; Met = metformin

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.18 with 3 degrees of freedom (p = 0.98)

I-squared statistic = 0%

The range of rates for mild to moderate hypoglycemia for comparison group, meglinitides, was 0 to 50%. The median rate was 1.9%.

Figure 64 is a forest plot of the odds ratio of having at least one mild or moderate hypoglycemic event comparing metformin with meglitinides. There are 4 studies included in this meta-analysis. The number of events in the metformin group and the meglitinides groups in each study are: Moses, 1999, 1 event among 27 patients and 3 events among 28 patients (odds ratio = 2.78, 95 percent confidence interval 0.37 to 20.86); Horton, 2000, 1 event among 178 patients and 3 events among 179 patients (odds ratio = 2.70, 95 percent confidence interval 0.38 to 19.30); Horton, 2004, 1 events among 104 patients and 2 events among 104 patients (odds ratio = 1.96, 95 percent confidence interval 0.20 to 19.06); and Lund, 2007, 22 events among 93 patients and 45 events among 89 patients (odds ratio = 3.16, 95 percent confidence interval 1.73 to 5.76). Derosa 2003 was excluded from the analysis. Numbers greater than 1 favor metformin and numbers less than 1 favor meglitinides. The pooled odds ratio was 3.01 (95 percent confidence interval 1.76 to 5.15). There was no statistically significant heterogeneity across studies.

Metformin versus a combination of metformin and thiazolidinediones. Eight RCTs were acceptable for pooling for the outcome of mild or moderate hypoglycemia (Figure 65).49,84–87,89,90,156 There was minimal statistical heterogeneity. The odds ratio from the fixed effects model was 1.6 (95 percent CI 1.0 to 2.4) favoring metformin alone for the outcome of hypoglycemia. No additional trials or observational studies reported this outcome.

Figure 65 Pooled odds ratio of having at least one mild or moderate hypoglycemic event comparing metformin with metformin plus thiazolidinedione

CI = confidence interval; Met = metformin; TZD = thiazolidinediones

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate. Test for heterogeneity: Q = 2.93 with 7 degrees of freedom (p = 0.89)

I-squared statistic = 0% The range of rates for mild to moderate hypoglycemia for comparison group, a combination of metformin and thiazolidinedione, was 0.6% to 12.2%. The median rate was 1.1%.

Figure 65 is a forest plot of the odds ratio of having at least one mild or moderate hypoglycemic event comparing metformin with a combination of metformin and thiazolidinediones. There are 8 studies included in this meta-analysis. The number of events in the metformin group and the combination metformin and thiazolidinedione groups are: Fonseca, 2000, 2 events among 116 patients and 5 events among 113 patients (odds ratio = 2.48, 95 percent confidence interval 0.55 to 11.12); Einhorn, 2000, 1 event among 160 patients and 1 event among 168 patients (odds ratio = 0.95, 95 percent confidence interval 0.06 to 15.30); Weissman, 2005, 4 events among 384 patients and 4 events among 382 patients (odds ratio = 1.01, 95 percent confidence interval 0.25 to 4.05); Bailey, 2005, 1 event among 280 patients and 3 events among 288 patients (odds ratio = 2.66, 95 percent confidence interval 0.37 to 18.96); Rosenstock, 2006, 14 events among 154 patients and 19 events among 155 patients (odds ratio = 1.39, 95 percent confidence interval 0.68 to 2.86); Stewart, 2006, 10 events among 272 patients and 17 events among 254 patients (odds ratio = 1.86, 95 percent confidence interval 0.86 to 4.02); Scott, 2008, 2 events among 91 patients and 1 events among 87 patients (odds ratio = 0.53, 95 percent confidence interval 0.05 to 5.19); and Kaku, 2009, 0 events among 86 patients and 1 event among 83 patients (odds ratio = 7.66, 95 percent confidence interval 0.15 to 386.33). Numbers greater than 1 favor metformin and numbers less than 1 favor combination therapy. The pooled odds ratio was 1.57 (95 percent confidence interval 1.01 to 2.43). There was no statistically significant heterogeneity across studies.

Metformin versus a combination of metformin and sulfonylureas. There were nine RCTs of this comparison (Table 10).59,61,63,64,68,70,71,91,92 Seven reported mild or moderate hypoglycemia and were pooled, but there was substantial statistical heterogeneity (I-squared of 73 percent) so this pooled outcome is not reported.

Table 10 Randomized controlled trials comparing metformin with a combination of metformin and sulfonylurea for hypoglycemia

Author, year | Outcome | Results (metformin versus metformin + sulfonylurea) | Comments (metformin as the reference group)
Defronzo, 1995^70^ | Individuals with mild or moderate hypoglycemia | 4/210 versus 38/213 | RR = 9.3 (95% CI 3.4 to 26)
Charpentier, 2001^71^ | Individuals with mild or moderate hypoglycemia | 8/75 versus 30/147 | RR = 2 (95% CI 0.9 to 4)
Blonde, 2002^63^ | Individuals with mild or moderate hypoglycemia | 1/153 versus 22/162 | RR = 20.8 (95% CI 3 to 152) Definition of hypoglycemia required symptoms with a measured glucose < 60 mg/dl
Marre, 2002^64^ | Individuals with mild or moderate hypoglycemia | 0/104 versus 12/103 | RR = 25 (95% CI 1.5 to 421)
Garber, 2003^61^ | Individuals with mild or moderate hypoglycemia | 29/164 versus 59/171 | RR = 2 (95% CI 1.3 to 2.9)
Feinglos, 2005^91^ | Individuals with mild or moderate hypoglycemia | 2/56 versus 9/56 | RR = 4.5 (95% CI 1.0 to 20)
Chien, 2007^59^ | Individuals with mild or moderate hypoglycemia | 0/25 versus 0/26 | Most subjects had been on both medications before the trial began.
Hermann, 1994^68^ | Individuals with severe hypoglycemia | 8/38 versus 24/72 | RR = 1.6 (95% CI 0.8 to 3.2)
Nauk, 2009^92^ | Individuals with severe hypoglycemia | 0/122 versus 0/244 | Not a significant difference

CI = confidence interval; mg/dL = milligrams per deciliter; RR = relative risk

Metformin versus a combination of metformin and DPP-4 inhibitors. Five articles, describing four trials, examined hypoglycemia with metformin compared to metformin with sitagliptin.75,76,85,93,94 Williams-Herman et al,76 is an extension of the Goldstein et al. trial.75 There was minimal heterogeneity between these studies. The addition of sitagliptin to metformin does not raise the risk of mild or moderate hypoglycemia (odds ratio [OR] = 0.9, 95 percent CI 0.4 to 2.3) (Figure 66). No additional trials or observational studies reported this outcome.

Figure 66 Pooled odds ratio of having at least one mild or moderate hypoglycemic event comparing metformin with metformin plus DPP-4 inhibitors

CI = confidence interval; DPP4 inhibitors = dipeptidyl peptidase-4 inhibitors; Met = metformin

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 2.59 with 3 degrees of freedom (p = 0.46)

I-squared statistic = 0%

The range of rates for mild to moderate hypoglycemia for comparison group, a combination of metformin and DPP-4 inhibitors, was 0 to 2.1%. The median rate was 1.5%.

Figure 66 is a forest plot of the odds ratio of having at least one mild or moderate hypoglycemic event comparing metformin with a combination of metformin and DPP-4 inhibitors. The number of events in the metformin groups and the combination metformin and DPP-4 inhibitor groups are: Charbonnel, 2006, 5 events among 237 patients and 6 events among 464 patients (odds ratio = 0.59, 95 percent confidence interval 0.17 to 2.08); Scott, 2007, 2 events among 91 patients and 1 event among 94 patients (odds ratio = 0.49, 95 percent confidence interval 0.05 to 4.80); Raz, 2008, 0 events among 94 patients and 1 event among 96 patients (odds ratio = 7.24, 95 percent confidence interval 0.14 to 364.79); and Williams-Herman, 2009, 2 events among 182 patients and 4 events among 190 patients (odds ratio = 1.88, 95 percent confidence interval 0.38 to 9.43). Numbers greater than 1 favor metformin monotherapy, and numbers less than 1 favor combination therapy. The pooled odds ratio was 0.93 (95 percent confidence interval 0.38 to 2.25). There was no statistically significant heterogeneity across studies.

Two trials examined metformin compared to metformin plus saxagliptin at doses ranging from 2.5 mg to 10 mg.78,95 In one, 13 of 328 patients treated with metformin had mild hypoglycemia while 11 of 320 patients in the 5 mg saxagliptin plus metformin group had hypoglycemia and 16 of 323 in the 10 mg saxagliptin plus metformin group did. Two patients in the higher dose arm had severe hypoglycemia defined as serum glucose < 50 mg/dl with symptoms.78 In the other trial, 9 of 170 metformin-treated patients had mild hypoglycemia; when saxagliptin was added the counts were 15 of 192, 10 of 191, and 7 of 181 in the groups receiving 2.5 mg, 5 mg, and 10 mg, respectively. One patient in each arm had severe symptoms, including the metformin only arm.95

Metformin versus a combination of metformin and meglitinides. Three studies reported mild or moderate hypoglycemia for this comparison.80,92,96 There was minimal statistical heterogeneity between the studies. One high-quality study had very few affected individuals and used a low dose of nateglinide.96 Results are unclear but suggest possibly an increased risk of hypoglycemia with the combination (Figure 67). No additional trials or observational studies reported this outcome.

Figure 67 Pooled odds ratio of having at least one mild or moderate hypoglycemic event comparing metformin with metformin plus meglitinides

CI = confidence interval; Meg = meglitinides; Met = metformin

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 2.52 with 2 degrees of freedom (p = 0.28)

I-squared statistic = 20.7%

The range of rates for mild to moderate hypoglycemia for comparison group, a combination of metformin and meglitinides, was 0 to 33%. The median rate was 3.4%.

Figure 67 is a forest plot of the odds ratio of having at least one mild or moderate hypoglycemic event comparing metformin with a combination of metformin and meglitinides. There are 3 studies included in this meta-analysis. The number of events in the metformin groups and the combination metformin and meglitinides groups in each study are: Moses, 1999, 3 events among 27 patients and 9 events among 27 patients (odds ratio = 3.53, 95 percent confidence interval 0.99 to 12.59); Marre, 2002, 1 event among 152 patients and 0 events among 160 patients (odds ratio = 0.13, 95 percent confidence interval 0 to 6.48); and Horton, 2004, 1 event among 104 patients and 3 events among 89 patients (odds ratio = 3.26, 95 percent confidence interval 0.45 to 23.63). Numbers greater than 1 favor metformin monotherapy and numbers less than 1 favor combination therapy. The pooled odds ratio was 2.75 (95 percent confidence interval 0.98 to 7.71). There was no statistically significant heterogeneity across studies.

Rosiglitazone versus pioglitazone. This was addressed by a single, retrospective cohort study.202 The subjects had poor glycemic control at cohort entry with a mean HbA1c of 9.5 percent in the rosiglitazone group and 9.6 percent in the pioglitazone group. The prevalence of hypoglycemia did not differ significantly between groups (11 out of 96 in the rosiglitazone-treated group and 18 out of 106 in the pioglitazone group).

Thiazolidinediones versus sulfonylureas. Nine studies examined hypoglycemic outcomes for this comparison.38,50,100,101,106,149,150,184,200 Two looked at counts of events rather than individuals,38,184 and one described only the severe events in both arms.149 The pooled results for mild or moderate hypoglycemia for the five studies reporting affected individuals showed a higher risk of hypoglycemia among those on a sulfonylurea than on any thiazolidinedione (OR = 3.9, 95 percent CI 3.1 to 4.9) (Figure 68).

Figure 68 Pooled odds ratio of having at least one mild or moderate hypoglycemic event comparing thiazolidinediones with sulfonylureas

CI = confidence interval; SU = sulfonylureas; TZD = thiazolidinediones

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 6.78 with 4 degrees of freedom (p = 0.15)

I-squared statistic = 41%

The range of rates for mild to moderate hypoglycemia for comparison group, sulfonylureas, was 2.7% to 29.4%. The median rate was 12.1%.

Figure 68 is a forest plot of the odds ratio of having at least one mild or moderate hypoglycemic event comparing thiazolidinediones with sulfonylureas. There are 5 studies included in this meta-analysis. The number of events in the thiazolidinedione groups and the sulfonylurea groups in each study are: Tan, 4 events among 91 patients and 32 events among 109 patients (odds ratio = 5.38, 95 percent confidence interval 2.61 to 11.08); Yamanouchi, 0 events among 38 patients and 1 event among 37 patients (odds ratio = 7.59, 95 percent confidence interval 0.15 to 382.72); Jain, 11 events among 251 patients and 61 events among 251 patients (odds ratio = 5.04, 95 percent confidence interval 3.06 to 8.31); Hanefeld, 1 event among 200 patients and 25 events among 07 patients (odds ratio = 6.90, 95 percent confidence interval 3.12 to 15.26); and Tolman, 40 events among 1051 patients and 119 events among 1046 patients (odds ratio = 2.94, 95 percent confidence interval 2.13 to 4.07). Numbers greater than 1 favor thiazolidinediones and numbers less than 1 favor sulfonylureas. The pooled odds ratio was 3.88 (95 percent confidence interval 3.05 to 4.94). There was no statistically significant heterogeneity across studies.

However, the large multicontinent RCT (ADOPT) reported no significant difference in the number of events in each group (1,341 out of 1,456 in the group on rosiglitazone and 1338 out of 1,441 in the sulfonylurea group, p = 0.44).38 This high number of events suggests that even very minor events were included in this count. One additional trial reported two events of hypoglycemia in the pioglitazone arm among 22 randomized participants and one event among 22 randomized participants receiving sulfonylurea (glipizide).184 A cohort study evaluating a population over age 65 years reported that 2.6 percent of recipients of sulfonylurea reported hypoglycemia and 2.2 percent of thiazolidinedione recipients, which are not significantly different percentages.200

There were very few patients affected by severe hypoglycemia. Only a single individual treated with a thiazolidinedione in the four studies reporting this outcome had an event (this was in the ADOPT trial38); 0 to 3 percent of the sulfonylurea-treated patients had severe events.38,50,100,149

Thiazolidinediones versus meglitinides. Two RCTs reported hypoglycemic outcomes for this comparison (Table 11).109,110

Table 11 Randomized controlled trials comparing thiazolidinediones with meglitinides for hypoglycemia

Author, year | Outcome | Results (thiazolidinediones versus meglitinides) | RR and comments (thiazolidinediones as reference group)
Jovanovic, 2004^110^ | Individuals with mild or moderate hypoglycemia | 4/62 versus 8/61 | RR = 1.2 (95% CI 0.8 to 1.8)
Raskin, 2004^109^ | Individuals with mild or moderate hypoglycemia | 1/62 versus 4/63 | RR = 1.6 (95% CI 1.0 to 2.6)
Raskin, 2004^109^ | Severe hypoglycemia | None | NA

CI = confidence interval; NA = not applicable; RR = relative risk

Sulfonylureas versus DPP-4 inhibitors. A single high-quality RCT examined hypoglycemia with this comparison.111 Subjects had a mean HbA1c of 7.9 percent upon enrollment. Twenty-one of 123 patients treated with a sulfonylurea had mild or moderate hypoglycemia while none did among the 122 patients treated with sitagliptin.

Sulfonylureas versus meglitinides. Eight studies reported hypoglycemia with this comparison.112,114–119,203 One looked only at severe events,114 and one trial focused on the comparison while patients were fasting in observance of Ramadan.203 The other six had similar outcomes and were amenable to pooling. Fewer patients receiving meglitinides had hypoglycemia than those receiving sulfonylurea although the pooled risk ratio was not statistically significant (OR = 0.8, 95 percent CI 0.6 to 1.1) (Figure 69).

Figure 69 Pooled odds ratio of having at least one mild or moderate hypoglycemic event comparing sulfonylureas with meglitinides

CI = confidence interval; Meg = meglitinides; SU = sulfonylureas

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 4.89 with 4 degrees of freedom (p = 0.30)

I-squared statistic = 18.2%

The range of rates for mild to moderate hypoglycemia for comparison group, meglitinides was 0% to 14.1%. The median rate was 4.6%.

Figure 69 is a forest plot of the odds ratio of having at least one mild or moderate hypoglycemic event comparing sulfonylureas with meglitinides. There are 5 studies included in this meta-analysis. The number of events in the sulfonylurea groups and the meglitinides groups in each study are: Wolffenbuttel, 1993, 1 event among 15 patients and 0 events among 29 patients (odds ratio = 0.05, 95 percent confidence interval 0 to 3.33); Landgraf, 1999, 9 events among 100 patients and 9 events among 94 patients (odds ratio = 1.07, 95 percent confidence interval 0.41 to 2.82); Wolfenbuttel, 1999, 13 events among 139 patients and 26 events among 286 patients (odds ratio = 0.97, 95 percent confidence interval 0.48 to 1.95); Marbury, 1999, 35 events among 193 patients and 54 events among 383 patients (odds ratio = 0.73, 95 percent confidence interval 0.46 to 1.19); and Vakkilainen, 2002, 3 events among 24 patients and 0 events among 24 patients (odds ratio = 0.12, 95 percent confidence interval 0.01 to 1.25). Jibran 2006 was excluded from the analysis. Numbers greater than 1 favor sulfonylureas and numbers less than 1 favor meglitinides. The pooled odds ratio was 0.78 (95 percent confidence interval 0.55 to 1.12). There was no statistically significant heterogeneity across studies.

In the trial by Madsbad et al., there were no severe hypoglycemic events in either treatment group.114 The high quality trial by Mafauzy et al. randomized patients to repaglinide or glibenclamide during the period of Ramadan.203 The number of hypoglycemic events with midday blood glucose less than 81 mg/dL was significantly lower in the meglitinide group (2.8 percent) than in the sulfonylurea group (7.9 percent) (p < 0.001).

Sulfonylureas versus GLP-1 agonists. Three trials compared a sulfonylurea (glibenclamide or glimepiride) to liraglutide.120–122 One was a small 12-week dose-finding study that reported a single episode of mild hypoglycemia among the 30 individuals receiving 0.6 mg of liraglutide daily and no episodes in the higher dose group (0.75 mg). Four of 26 patients in the glimepiride group had mild hypoglycemic episodes.120 The larger trial which also used glimepiride found 12 of 251 (1.2 mg of liraglutide) and 8 of 247 (1.8 mg of liraglutide) episodes of mild hypoglycemia, compared to 26 of 248 in the sulfonylurea group, which is significantly higher in the sulfonylurea group. The number of episodes was comparable in the 1.2 mg of liraglutide group and the 1.8 mg of liraglutide group.204 The other trial used glibenclamide and compared it to 0.9 mg of liraglutide.121 There were 45 of 132 individuals with symptomatic hyperglycemia in the glibenclamide group (and 228 events) compared to 36 individuals of 268 in the liraglutide group (and 61 events), significantly favoring the liraglutide arm. There were also more episodes of measured low blood sugar among the glibenclamide treated individuals (p < 0.0001). There was no severe hypoglycemia in this trial.

Combination of metformin and thiazolidinediones versus combination of metformin and sulfonylureas. Five trials examined hypoglycemic outcomes,123,125,126,128,129 as did one nonrandomized interventional study.201 Among those reporting mild or moderate hypoglycemia, there was minimal heterogeneity between studies (Figure 70). The trial by Hamann et al. was designed so that patients were withdrawn from the study if they did not reach an efficacy target after 8 weeks of treatment.123 The rates of hypoglycemia were high as medications were titrated up to efficacy, although the relative risk of hypoglycemia in the two arms was comparable to the other studies.

Figure 70 Pooled odds ratio of having at least one mild or moderate hypoglycemic event comparing combination metformin and thiazolidinediones with combination metformin and sulfonylureas

CI = confidence interval; Met = metformin; SU = sulfonylureas; TZD = thiazolidinediones

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 3.79 with 4 degrees of freedom (p = 0.44)

I-squared statistic = 0%

The range of rates for the comparison group, a combination of metformin and sulfonylureas, was 1.3% to 33.3%. The median rate was 29.9%.

Figure 70 is a forest plot of the relative risk of having at least one mild or moderate hypoglycemic event comparing a combination of metformin and thiazolidinediones with a combination of metformin and sulfonylureas. There are 5 studies included in this meta-analysis. The number of events in the combination metformin and thiazolidinedione groups and the combination metformin and sulfonylurea groups in each study are: Bakris, 2006, 2 events among 194 patients and 22 events among 180 patients (odds ratio = 6.41, 95 percent confidence interval 2.81 to 14.66); Garber, 2006, 2 events among 155 patients and 53 events among 159 patients (odds ratio = 9.12, 95 percent confidence interval 5.10 to 16.31); Umpierrez, 2006, 10 events among 107 patients and 32 events among 96 patients (odds ratio = 4.28, 95 percent confidence interval 2.17 to 8.44); Comaschi, 2007, 0 events among 103 patients and 1 event among 80 patients (odds ratio = 9.85, 95 percent confidence interval 0.19 to 512.22); and Hamann, 2008, 18 events among 294 patients and 90 events among 301 patients (odds ratio = 4.94, 95 percent confidence interval 3.26 to 7.50). Numbers greater than 1 favor a combination of metformin and thiazolidinediones and numbers less than 1 favor a combination of metformin and sulfonylureas. The pooled odds ratio was 5.77 (95 percent confidence interval of 4.35 to 7.67). There was no statistically significant heterogeneity across studies.

In the studies that reported severe hypoglycemia, the rates were higher in the combination of metformin and sulfonylurea arms than the combination of metformin and thiazolidinedione arms. In Garber et al., 7 of 159 patients had severe hypoglycemic events in the metformin with sulfonylurea arm and none in the metformin with thiazolidinedione group.128 This study included patients with high HbA1c upon enrollment and had a higher proportion of Asian patients than most studies (12 percent Asian).

One nonrandomized trial compared addition of pioglitazone with addition of glibenclamide in patients taking metformin, with a mean followup of 42 months.201 More patients receiving glibenclamide had hypoglycemic events than those who received pioglitazone (34 out of 250 compared to five out of 250, respectively).

Combination of metformin and thiazolidinediones versus combination of metformin and meglitinides. A single RCT reported hypoglycemia for this comparison.131 This study compared meglitinide plus metformin to two different intensities of metformin plus thiazolidinedione (twice-daily or three-times daily dosing). The combination of metformin plus meglitinide was associated with more hypoglycemia than the combination of metformin plus thiazolidinedione. In the repaglinide plus metformin twice-daily group, 8 of 187 randomized participants had 162 events and in the rosiglitazone plus metformin twice-daily group, one of the 187 randomized participants had 11 events (RR = 1.8, 95 percent CI 1.4 to 2.3 comparing the number of affected participants). There were no episodes of severe hypoglycemia in either group.

Combination of metformin and thiazolidinediones versus combination of metformin and another agent. One study randomized 56 patients to metformin and rosiglitazone and 56 to metformin and sitagliptin. One patient in the rosiglitazone group withdrew for hypoglycemia but it is not clearly reported how many in each group experienced hypoglycemia.205 The other study randomized 45 patients to metformin and rosiglitazone and 45 to metformin and exenatide. No patients receiving rosiglitazone described hypoglycemia while two receiving exenatide did, although this difference was not statistically significant.132 There were no severe hypoglycemic events in the latter study.

Combination of metformin and sulfonylureas versus combination of metformin and another agent. Nine trials examined hypoglycemia for metformin plus sulfonylurea compared to metformin plus another drug (Table 12).44,92,133,134,136–138,152,199

Table 12 Randomized controlled trials comparing combination of metformin and sulfonylurea with combination metformin and another agent for hypoglycemia

Author, year | Comparison | Outcome | Results | RR and comments (combination metformin and another agent as reference)
Gerich, 2005^136^ | Metformin + sulfonylurea versus metformin + meglitinides | Mild or moderate | 38/209 versus 18/219 | RR = 2.2 (95% CI 1.3 to 3.8)
Gerich, 2005^136^ | Metformin + sulfonylurea versus metformin + meglitinides | Severe | 2/209 versus 0/219 | No significant difference
Schwarz, 2008^152^ | Metformin + sulfonylurea versus metformin + meglitinides | Severe | 1/40 versus 0/35 | No significant difference
Nauck, 2007^133^ | Metformin + sulfonylurea versus metformin + sitagliptin | Severe | 7/584 versus 1/588 | RR = 7.0 (95% CI 0.9 to 57)
Malone, 2003^137^ | Metformin + sulfonylurea versus metformin + insulin | Nocturnal | (N = 597 in trial) Greater number of participants with nocturnal hypoglycemia (p < 0.01) with metformin plus sulfonylurea than metformin plus insulin. | NA
| | Severe | Comparable number with severe hypoglycemia | p = 1.0
Kvapil, 2006^138^ | Metformin + sulfonylurea versus metformin + insulin | Mild or moderate | 9/114 versus 13/108 | RR = 1.5 (95% CI 0.7 to 3.4)
Nauck, 2009^92^ | Metformin + sulfonylurea versus metformin + liraglutide | Mild and separately reports severe | 17% versus 3% of patients | Same in low dose and high dose groups receiving liraglutide; no severe episodes in any arm
Seck, 2010^134,†^ | Metformin + sulfonylurea versus metformin + sitagliptin | Severe | 18/584 versus 2/588 | RR = 9.1 (95% CI 2.1 to 39)
Derosa, 2010^44^ | Metformin + sulfonylurea versus metformin + exenatide | Withdrawal from study for hypoglycemia | 3/65 versus 0/63 | Not calculable
Dimic, 2009^199,*^ | Metformin + sulfonylurea versus metformin + repaglinide | Moderate | 7/30 versus 5/30, patients each with one episode | RR = 1.4 (95% CI 0.5 to 3.9)

CI = confidence interval; NA = not available; RR = relative risk

* patients assigned a treatment, not clearly randomized

† Continuation of Nauck, 2007^133^

Combination of metformin and exenatide versus metformin and a basal insulin. A single small study evaluated this comparison.144 More patients receiving insulin had hypoglycemic events than patients receiving exenatide. Of the 33 patients receiving insulin, 24 percent had hypoglycemia while 8 percent of the 36 receiving exenatide with their metformin had hypoglycemia. There was no severe hypoglycemia in either arm.

Combination of metformin and a basal insulin versus combination of metformin and another insulin. Five trials examined the comparison of metformin plus insulin glargine to metformin plus another insulin preparation (Table 13).145–147,164,165

Table 13 Randomized controlled trials comparing combination of metformin and a basal insulin with combination of metformin and another insulin for hypoglycemia

Author, year | Comparison | Outcome | Results | RR and comments (combination metformin and another insulin as reference group)
Malone, 2004^164^ | Metformin + glargine versus metformin + lispro 75/25 | Mild or moderate | 40/101 versus 57/100 (87 versus 181 events) | RR = 0.69 (95% CI 0.5 to 0.9), both arms of cross-over pooled
Malone, 2004^164^ | Metformin + glargine versus metformin + lispro 75/25 | Severe | None | NA
Malone, 2005^165^ | Metformin + glargine versus metformin + lispro 75/25 | Mild or moderate | 0.44 versus 0.61 events/patient/30 days | P = 0.47; more daytime hypoglycemia with lispro 75/25 but less nocturnal hypoglycemia
Malone, 2005^165^ | Metformin + glargine versus metformin + lispro 75/25 | Severe | None | NA
Raskin, 2007^146^ | Metformin + glargine versus metformin + aspart 70/30 | Mild or moderate | 11/78 versus 33/79 (23 versus 121 events) | RR = 0.34 (95% CI 0.2 to 0.6)
Robbins, 2007^145^ | Metformin + glargine versus metformin + lispro 50/50 | Mild or moderate | 75/158 versus 79/157 | RR = 0.94 (95% CI 0.8 to 1)
Robbins, 2007^145^ | Metformin + glargine versus metformin + lispro 50/50 | Severe | 2/158 versus 3/157 | RR = 0.66 (95% CI 0.1 to 4)
Davies, 2007^147^ | Metformin + NPH versus metformin + NPH/regular 70/30 | Mild or moderate | 7/29 versus 8/27 | RR = 0.81 (95% CI 0.34 to 1.9); a poorly conducted trial

CI = confidence interval; NA = not available; NPH = neutral protamine Hagedorn; RR = relative risk

Combination of metformin and thiazolidinediones versus combination of thiazolidinediones and sulfonylureas. A single large cohort study examined this comparison.183 This prospective cohort study enrolled 22,808 patients in Germany who were treated with rosiglitazone and observed their outcomes as their own clinicians prescribed additional medications. Hypoglycemic events occurred at a rate of 0.05 per 100 person-years of followup in the metformin plus thiazolidinedione group and 0.47 per 100 person-years of followup in the thiazolidinedione plus sulfonylurea group.

Combination of metformin and sulfonylureas versus combination of thiazolidinediones and sulfonylureas. A single study compared metformin plus sulfonylurea to a thiazolidinedione plus sulfonylurea.142 This was the longer term followup on the patients enrolled in the study first reported by Hanefeld et al.140 There was a 10 percent withdrawal rate from adverse events and an 8 percent withdrawal rate for lack of efficacy. Fifty of 224 subjects receiving metformin plus sulfonylurea had mild or moderate hypoglycemic symptoms while 36 of 217 receiving thiazolidinedione plus sulfonylurea had symptoms (RR 1.3, 95 percent CI 0.9 to 2).

Severe hypoglycemia. As noted above, relatively few studies separately described severe hypoglycemia.38,44,68,78,92,95,114,133,134,136,137,145,152,164,165 The definitions differed across studies, but it was most commonly defined as hypoglycemia requiring assistance for resolution. The studies that compared metformin with a sulfonylurea to metformin with another agent were the studies that most commonly reported this outcome. In the seven studies reporting, only one found a higher rate of severe hypoglycemia in the arm with a sulfonylurea than in the arm with sitagliptin. Otherwise, none of the comparisons reporting this outcome found more severe hypoglycemia in one arm relative to the other. Many of the studies were underpowered to demonstrate differences for this infrequent outcome.

### The Evidence About Liver Injury (Appendix G, Table 12)

Metformin versus thiazolidinediones. One 52-week trial compared metformin and pioglitazone and reported on changes in liver enzymes.52 There were 3 instances of hepatotoxicity leading to drug discontinuation—1 patient of 597 treated with metformin and 2 of 597 treated with pioglitazone. Liver enzyme abnormalities were more frequent. In the metformin group, 2.2 percent of participants had an increase in alanine transaminase to 3 times the upper limit of normal as did 0.9 percent of pioglitazone-treated patients (p = 0.06). In both groups, the mean alanine transaminase, gamma-glutamyltransferase concentrations, and alkaline phosphatase concentrations decreased during the trial. Additionally, a single cohort study assessed liver injury with metformin as compared with pioglitazone, using propensity scores to match subjects based on disease severity.206 The incidence of liver failure or hepatitis was defined using claims data. For the 1,847 subjects in each group for the metformin versus pioglitazone comparison, the rate of liver failure or hepatitis was 0.8 percent and 0.4 percent, respectively, which was not statistically different in Cox proportional hazard models.

Metformin versus sulfonylureas. The ADOPT study, a large 6-year parallel-arm RCT, compared metformin with glyburide, with over 1,400 subjects in each arm.38 The average age in the metformin group was 57.9 (standard deviation [SD] 9.9). Average age in the glyburide group was 56.4 (SD 10.4). The percentage of individuals with liver injury was 1.1 percent among the 1,341 individuals in the metformin group and 0.8 percent among the individuals in the glyburide group. Mean alanine aminotransferase (ALT) levels were slightly higher in the glyburide group (27.2 international units [IU]/liter; 95 percent CI 26.3 IU/liter to 28.1 IU/liter) compared to the metformin group (24.9 IU/liter; 95 percent CI 24.1 IU/liter to 25.8 IU/liter), but the clinical significance of this slight difference is not clear and there was no statistical test performed.

Rosiglitazone versus pioglitazone. This comparison was addressed by a single, cohort study conducted in the US using a pharmacy database.206 As mentioned above, the diagnosis of liver failure or hepatitis was based on claims data. There was no difference in the incidence of liver injury between the two treatment groups. The incidence of hepatitis was 0.4 percent among the 1,847 people treated with rosiglitazone and 0.5 percent among the 1,847 treated with pioglitazone.

Thiazolidinediones versus sulfonylureas. This comparison was addressed with the ADOPT study, described above, which compared rosiglitazone with glyburide.38 The average age of participants in the rosiglitazone and glyburide groups was 57.9 (SD 9.9) and 56.4 (SD 10.4), respectively. The outcome of liver injury was based on elevated liver enzymes. There were no cases of liver injury among the 1,456 people randomized to rosiglitazone or the 1,441 people randomized to glyburide. The cohort study discussed above also compared pioglitazone versus any sulfonylurea and assessed rates of liver failure and hepatitis.206 The incidence of hepatitis, defined with claims data, was 0.6 percent among the 1,474 individuals treated with pioglitazone and 1 percent in the 1,474 individuals treated with any sulfonylurea, which was not significant. One additional large trial reported this outcome.150 None of the 1,051 patients receiving pioglitazone had liver enzyme abnormalities while four of the 1,046 individuals receiving glyburide did (p = 0.06).

Combination of metformin and thiazolidinediones versus combination of metformin and sulfonylureas. One RCT examined liver injury as an adverse event for this comparison.127 Liver injury was defined as an ALT or aspartate aminotransferase value more than 3 times the upper limit of normal. There were no cases of liver injury reported in the 48 patients in the combination metformin plus rosiglitazone arm and none in the 47 patients in the combination metformin plus glimepiride arm.

Combination of metformin and sulfonylureas versus combination of thiazolidinediones and sulfonylureas. A single parallel arm 12-week RCT in 198 participants, conducted in China, examined this comparison.139 Individuals with poor glucose control were randomized to receive metformin plus an sulfonylurea or rosiglitazone plus a sulfonylurea. There were no cases of liver injury reported in either group in this short trial. One additional trial describing liver enzyme changes reported this as an outcome (rather than as an adverse event) and saw improvement in gamma-glutamyl transpeptidase, alanine aminotransferase, and alkaline phosphatase in both groups over the 52-week trial.140

### The Evidence About Congestive Heart Failure (Appendix G, Table 12)

Seven trials38,83,141,149,150,164,184 and 11 observational studies171,173,174,183,195,200,202,207–210 reported on the outcome of heart failure for our comparisons of interest.

Metformin versus thiazolidinediones. Three trials38,83,141 and four observational studies171,173,174,200 examined heart failure for this comparison (Table 14). Low grade evidence showed that thiazolidinediones increase the risk of heart failure when compared to metformin. The ADOPT study, a large long-term RCT of median duration of treatment of 4 years, which compared metformin with rosiglitazone, with over 1,400 subjects in each arm. There was no difference between the incidences of investigator reported heart failure in these two arms.38

Table 14 Studies comparing metformin with thiazolidinediones for heart failure events

Author, year | Study design | Comparison | Heart failure incidence (metformin as reference group)
Kahn, 2006^38^ | RCT | Rosiglitazone versus metformin | 22/1456 versus 19/1454 versus
Leiter, 2005^83^ | RCT | Rosiglitazone versus metformin | 3/405 versus 0/78
Van der Meer, 2009^141^ | RCT | Pioglitazone versus metformin | No events reported in either arm
Asche, 2008^200^ | Observational study | Thiazolidinedione versus metformin | 19/889 versus 0/2326
Pantalone, 2009^174^ | Observational study | Rosiglitazone versus metformin | HR 1.16 (95% CI 0.78 to 1.73)
Pantalone, 2009^174^ | Observational study | Pioglitazone versus metformin | HR 1.38 (95% CI 1.00 to 1.90)
Hsiao, 2009^173^ | Observational study | Rosiglitazone versus metformin | HR 1.30 (95% CI 0.89 to 1.89)
| | Pioglitazone versus metformin | HR 1.54 (95% CI 0.65 to 3.64)
Tzoulaki, 2009^171^ | Observational study | Rosiglitazone versus metformin | HR 0.61 (95% CI 0.33 to 1.15)
| | Pioglitazone versus metformin | HR 1.17 (95% CI 0.77 to 1.77)

CI = confidence interval; HR = hazard ratio for TZDs with metformin as references group; RCT = randomized controlled trial

Metformin versus sulfonylureas. Five observational studies reported on the risk of heart failure events with the sulfonylureas compared to metformin.174,195,207,208,211

A retrospective cohort study from Canada reported a higher rate of heart failure with a sulfonylurea (96 percent of SU users used glyburide) compared to metformin (adjusted HR 1.2, 95 percent CI 1.0 to 1.5). The risk of heart failure associated with sulfonylureas was dose-responsive with increasing risk with higher doses.208 Another retrospective cohort study of nearly 30,000 patients using the General Practitioner Research Database in the U.K. reported a higher incidence of heart failure with sulfonylurea monotherapy (27/1000 person-years) compared to metformin monotherapy (19/1000 person-years).195 A short observational study of around 10 months reported a lower risk of incident heart failure hospitalization among metformin users (HR 0.7, 95 percent CI 0.5 to 1.0, p = 0.05) compared to sulfonylurea users.207 Another observational study reported a lower risk of congestive heart failure with metformin compared with sulfonylureas (HR 0.76, 95 percent CI 0.64 to 0.91, p = 0.003).174 Yet another observational study reported a higher risk of congestive heart failure with second-generation sulfonylureas compared with metformin (HR 1.18, 95 percent CI 1.04 to 1.34, p = 0.011).171

Rosiglitazone versus pioglitazone. Four observational studies reported on this comparison.173,174,202,210 A prospective observational study from Ontario reported a statistically significant lower risk of congestive heart failure among patients on pioglitazone compared to rosiglitazone (HR 0.77, 95 percent CI 0.69 to 0.87).210 Another observational study reported 66 cases of congestive heart failure among 2,093 participants exposed to rosiglitazone monotherapy compared with 13 cases of heart failure among 495 participants exposed to pioglitazone monotherapy (3.33 percent versus 2.66 percent).173 Another observational study reported no difference in the risk of congestive heart failure with pioglitazone compared with rosiglitazone (HR 1.19, 95 percent CI 0.74 to 1.91, p = 0.48).174 One prospective observational study in Australia reported nearly similar rates of pulmonary edema when pioglitazone (2/107) was compared to rosiglitazone (3/96).202

Thiazolidinediones versus sulfonylureas. Four trials38,149,150,184 and four observational studies173,174,200,207,208 examined outcomes for this comparison (Table 15). A meta-analysis of the 4 RCTs38,149,150,184 showed an increased risk of congestive heart failure with thiazolidinediones compared with second-generation sulfonylureas which did not reach statistical significance but could not rule out a clinically significant excess associated with the thiazolidinediones (RR 1.68, 95 percent CI 0.99 to 2.85) (Figure 71). There was no evidence of statistical heterogeneity among the included studies (I^2^ = 0 percent). Moderate grade evidence showed that thiazolidinediones increase the risk of heart failure when compared with sulfonylureas.

Table 15 Studies comparing thiazolidinediones with sulfonylureas for heart failure events

Author, year | Study design | Comparison | Heart failure incidence (sulfonylurea as reference)
Asche, 2008^200^ | Observational study | Thiazolidinedione versus sulfonylurea | 19/889 and 0/2223
Karter, 2005^207^ | Observational study | Pioglitazone versus sulfonylurea | HR = 1.3 (95% CI 0.85 to 1.92) for incident hospitalization for heart failure
Pantalone, 2009^174^ | Observational study | Rosiglitazone versus sulfonylurea | HR = 0.88 (95% CI 0.60 to 1.31), p = 0.55
| | Pioglitazone versus sulfonylurea | HR = 1.05 (95% CI 0.77 to 1.43), p = 0.76
Hsiao, 2009^173^ | Observational study | Rosiglitazone versus sulfonylurea | HR = 1.22 (95% CI 0.86 to 1.74), p = 0.26
| | Pioglitazone versus sulfonylurea | HR = 1.37 (95% CI 0.58 to 3.20), p = 0.46

CI = confidence interval; HR = hazard ratio

Figure 71 Pooled odds ratio of congestive heart failure comparing thiazolidinediones with second-generation sulfonylureas

CI = confidence interval; RR = relative risk

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study. The diamond at the bottom of the graph indicates the 95 percent confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 2.37 with 3 degrees of freedom (p = 0.50)

I-squared statistic = 0%

Figure 71 is a forest plot of the odds ratio of congestive heart failure comparing thiazolidinediones with second-generation sulfonylureas. There are 4 studies included in this meta-analysis. The number of events in the thiazolidinedione groups and sulfonylurea groups in each study are: Agarwal, 2005, 2 events among 100 patients and 2 events among 100 patients (odds ratio = 1.00, 95 percent confidence interval 0.14 to 7.24); Tolman, 2009, 12 events among 1051 patients and 11 events among 1046 patients (odds ratio = 1.09, 95 percent confidence interval 0.48 to 2.47); Kahn, 2006, 22 events among 1456 patients and 9 events among 1441 patients (odds ratio = 2.44, 95 percent confidence interval 1.12 to 5.32); and St. John Sutton, 2002, 1 event among 63 patients and 0 events among 66 patients (odds ratio = 67.06). Numbers greater than 1 favor sulfonylureas and numbers less than 1 favor thiazolidinediones. The pooled odds ratio is 1.68 (95 percent confidence interval 0.99 to 2.85). There was no statistically significant heterogeneity across studies.

Combination of metformin and sulfonylureas versus combination of metformin or sulfonylureas and thiazolidinediones. The RECORD trial was a long-term open-label noninferiority trial designed to assess cardiovascular outcomes with rosiglitazone. Low grade evidence from the RECORD showed that the combination of thiazolidinediones and another agent (second or third generation sulfonylurea or metformin) was associated with a significant doubling in the risk of heart failure in comparison to combination of sulfonylurea and metformin (61/2220 versus 29/2227, RR 2.1, 95 percent CI 1.35 to 3.27).16

Combination of metformin and a basal insulin versus combination of metformin and another insulin. In an RCT that compared a combination of insulin glargine daily plus metformin with combination of insulin lispro 75/25 plus metformin, hospitalization due to heart failure was reported in a single patient on the insulin lispro 75/25 and metformin combination.164

Combination of metformin and thiazolidinediones versus combination of thiazolidinediones and sulfonylureas. A 6-month observational study from Germany reported rates of heart failure that were higher with a thiazolidinedione and sulfonylurea (0.47/100 person-years) relative to a thiazolidinedione and metformin combination (0.13/100 person-years).183

### The Evidence for Lactic Acidosis (Appendix G, Table 12)

We identified two double-blind RCTs comparing the rates of lactic acidosis between metformin, second-generation sulfonylurea, and metformin in combination with a second-generation sulfonylurea.62,63 Both the trials were conducted in the United States and lasted only 16 to 18 weeks. The average age of individuals participating in both these trials was greater than 50 years and individuals with significant renal or liver diseases were excluded. There were no cases of lactic acidosis reported in any of the treatment arms in either of the two trials.

### The Evidence About Cancer (Appendix G, Table 12)

We found four RCTs93,101,143,197 and one observational study212 which reported on cancer outcomes.

Metformin versus sulfonylureas. A retrospective cohort study of 62,089 patients reported on cancer outcomes in the U.K. in The Health Information Network in U.K. General Practices.212 Compared with those using metformin alone, users of sulfonylureas reported a higher risk of cancer (HR 1.36, 95 percent CI 1.19 to 1.54, p < 0.001).

Metformin versus meglitinides. Additionally, we identified a single crossover RCT reporting cancer outcomes that compared metformin to meglitinides.197 The study was conducted in 96 individuals with two 4-month treatment periods with a 1-month washout period in between. Two cancers (one cancer of the vocal plicae and one lung cancer) were reported in patients on metformin, while none were reported among patients on meglitinides.

Metformin versus a combination of metformin and sulfonylureas. In the same study, compared with metformin alone, users of both metformin and sulfonylureas reported no difference in the risk of cancer (HR 1.08, 95 percent CI 0.96 to 1.21, p = 0.21).212

Metformin versus a combination of metformin and DPP-4 inhibitors. The second trial was a 30-week trial conducted among 190 individuals randomly assigned to sitagliptin or placebo as an add-on to ongoing metformin therapy.93 Three cases of cancer were reported in the metformin only group while none were reported in the combination metformin and sitagliptin group.

Thiazolidinediones versus sulfonylureas. In a 56-week, multicenter trial in the United States and Puerto Rico conducted among 502 individuals randomly assigned to pioglitazone (n = 251) or second-generation sulfonylurea, glyburide (n = 251),101 two events of stage 4 colon cancer (0.8 percent) were reported in the sulfonylurea group while none were reported in the thiazolidinedione group.

Combination of metformin and DPP-4 inhibitors versus combination of metformin and GLP-1 agonists. One case of cancer was reported in each group in another 26-week open label RCT that compared 221 participants randomized to the liraglutide and metformin group, compared with 219 participants in the sitagliptin and metformin combination group.143

### The Evidence About Severe Allergic Reactions

None of the studies included in the report evaluated the outcome of severe allergic reactions.

### The Evidence About Hip and Non-Hip Fractures (Appendix G, Table 12)

Metformin versus thiazolidinediones. The ADOPT study was a large RCT comparing rosiglitazone, metformin, and glyburide for a median of 4 years duration. They reported a separate analysis examining time to first fracture, rates of occurrence, and fracture site. The estimated hazard ratio for risk of fracture with rosiglitazone versus metformin was 1.57 (95 percent CI 1.13 to 2.17). They also included a subgroup analysis to examine fracture risk by sex (see Key Question 4). Among the 1,840 women, there were 111 fractures, 60 (9.3 percent) in the rosiglitazone arm, 30 (5.1 percent) in the metformin arm, and 21 (3.5 percent) in the glyburide arm. This represented an increased HR for risk of fracture for rosiglitazone versus metformin (HR 1.81, 95 percent CI 1.17 to 2.80, p = 0.008) among women. There was no excess risk among men.213 A 24-week RCT reported on one wrist fracture in the metformin monotherapy group (wrist fracture in males (n = 210) without any fractures reported in the pioglitazone group (n = 189).56 A retrospective study in the U.K. GPRD reported no statistically significant difference in the risk of fractures when rosiglitazone was compared with metformin (HR 1.09, 95 percent CI 0.72 to 1.68, p = 0.69) or when pioglitazone was compared with metformin (HR 1.28, 95 percent CI 0.93 to 1.77, p = 0.127).171

Metformin versus sulfonylureas. Two RCTs reported on fractures for the comparison of metformin and second-generation sulfonylureas.59,213 In the ADOPT subanalysis described above,213 there were slightly more fractures in the metformin arm (59 out of 1,454, 4.1 percent) compared with the glyburide arm (49 out of 1441, 3.4 percent) but no statistical test was performed. A small 16-week trial, conducted in Taiwan, compared glyburide (n = 17) and metformin (n = 17) as monotherapy and in combination. This study reported one fracture of the right metacarpal bone of the hand in a single subject in the glyburide arm.59

The risk of fractures associated with second-generation sulfonylureas was not statistically different when compared with metformin alone (HR 1.09, 95 percent CI 0.97 to 1.23, p = 0.129) in a retrospective study in the U.K. general practice research database.171

Metformin versus a combination of metformin and thiazolidinediones. A 24-week RCT reported one wrist fracture in a male patient in the metformin monotherapy group (n = 210) compared with one wrist fracture in a female in the combination of metformin and pioglitazone group (n = 201).56 A retrospective study in the U.K. GPRD reported a higher risk of non-hip fractures with rosiglitazone combination therapy compared with metformin alone after adjusting for potential confounders (HR 1.53, 95 percent CI 1.25 to 1.88, p < 0.01).171 A cross-sectional study of males having diabetes reported a higher risk of fractures among those treated with rosiglitazone plus metformin compared with metformin alone (66.7 percent versus 27.3 percent, p = 0.01), with a significantly higher odds of fractures in the combination arm (OR 6.5, 95 percent CI 1.3 to 38.1, p = 0.03) after adjusting for age and body mass index.214

Metformin versus a combination of metformin and sulfonylureas. The above 16-week trial only reported a single fracture in the glyburide monotherapy group as compared with no fractures in the two combination metformin plus glyburide groups (n = 42).59

Metformin versus a combination of metformin and DPP-4 inhibitors. One 30-week multicontinent, parallel-arm RCT randomized 190 subjects to metformin or metformin plus sitagliptin.93 They reported one case of osteoporotic limb fracture among the 94 individuals in the metformin group and no fractures in the metformin plus sitagliptin group.

Thiazolidinediones versus sulfonylureas. This comparison was assessed by two RCTs101,213 and one observational study.215 In the ADOPT subanalysis on fracture risk, there was an increased HR (2.13, 95 percent CI 1.30 to 3.51) for rosiglitazone as compared with glyburide.213 A second trial randomized subjects to pioglitazone or glyburide.101 There were no reported cases of ankle fracture among the 251 individuals in the pioglitazone arm. Two ankle fractures (incidence of 0.2 percent) were reported among the 251 participants in the glyburide group, without a statistical test.

Another prospective study reported on the comparison between thiazolidinediones and first- and second-generation sulfonylureas acetohexamide, chlorpropamide, gliclazide, glimepiride, glyburide, and tolbutamide for fractures among men and women.215 Thiazolidinediones were associated with an increased risk of all fractures compared with sulfonylureas (HR 1.28, 95 percent CI 1.12 to 1.45, p < 0.001) after adjusting for various confounders. Compared with the sulfonylureas, the hazard ratios for any fractures with the thiazolidinediones did not reach statistical significance for men (HR 1.15, 95 percent CI 0.95 to 1.40, p = 0.14) but was statistically significantly higher for women (HR 1.40, 95 percent CI 1.18 to 1.67, p < 0.001). Among women, both pioglitazone (HR 1.70, 95 percent CI 1.30 to 2.23, p < 0.001) and rosiglitazone (HR 1.29, 95 percent CI 1.04 to 1.59, p = 0.02) were significantly associated with an increased risk of fractures compared with the sulfonylureas.

Combination of metformin and sulfonylureas versus combination of metformin or sulfonylureas and thiazolidinediones. The RECORD study was an open-label noninferiority multicenter RCT with 4,447 participants with type 2 diabetes taking either metformin or a second- or third-generation sulfonylurea, glyburide/glibenclamide (normal or micronized), gliclazide or glimepiride randomly assigned to one of three arms, metformin plus rosiglitazone, sulfonylurea plus rosiglitazone, or metformin plus sulfonylurea.16 The incidence of participant-reported bone fractures was higher in the combined metformin plus rosiglitazone and sulfonylurea plus rosiglitazone arms, with 49 events out of 2,220 participants (2.3 percent) versus 36 out of 2227 participants (1.6 percent) in the metformin plus sulfonylurea arms. The risk ratio was 1.57 (95 percent CI 1.26 to 1.97, p < 0.0001) for the rosiglitazone combination therapy arms compared with the combination metformin plus sulfonylurea arms. Consistent with the ADOPT trial reporting metformin versus rosiglitazone monotherapy, the RR was higher for women compared with men (RR 1.82, 95 percent CI 1.37 to 2.41 versus 1.23, 95 percent CI 0.85 to 1.77). The fractures occurred predominantly in the upper limb, distal lower limb, and not hip or femur fractures.16

### The Evidence About Acute Pancreatitis (Appendix G, Table 12)

We identified five trials that reported on the rates of acute pancreatitis with the specific drug comparisons.92,121,122,143,144

Metformin versus a combination of metformin and sulfonylureas. The Liraglutide Effect and Action in Diabetes (LEAD) 2 trial reported one patient with acute pancreatitis in the metformin plus glimepiride arm among 242 exposed patients compared with none in the metformin arm among 121 exposed patients.92

Sulfonylureas versus GLP-1 agonists. The Liraglutide Versus Glimepiride monotherapy for type 2 diabetes (LEAD-3 Mono) trial also reported two participants with pancreatitis in the liraglutide arm (n = 498) compared with none having pancreatitis in the glimepiride arm, (n = 248)122 for 52 weeks. Another 24-week trial that compared liraglutide (n = 272) to glibenclamide (n = 139) also reported no episodes of pancreatitis.216

DPP-4 inhibitors versus GLP-1 agonists. Another 26-week trial that compared liraglutide (n = 446) with sitagliptin (n = 219) reported no episodes of pancreatitis.143

Combination of metformin and GLP-1 agonist versus combination of metformin and basal insulin. One patient on metformin plus exenatide developed pancreatitis (n = 36) compared with none in the metformin plus insulin glargine arm (n = 33) in another RCT.144

### The Evidence About Cholecystitis (Appendix G, Table 12)

Three RCTs reported on the outcome of cholecystitis.54,87,150

Metformin versus thiazolidinediones. One trial identified a single participant with cholecystitis among 105 treated with a thiazolidinedione; none of the 100 patients treated with metformin suffered from cholecystitis.54

Metformin versus combination of metformin and thiazolidinediones. In an RCT, one patient had cholecystitis (n = 280) in the metformin arm compared with none (n = 288) in the metformin plus rosiglitazone arm.87

Thiazolidinediones versus sulfonylureas. A 3-year RCT reported that four participants developed cholecystitis NOS (not otherwise specified) and zero participants developed acute cholecystitis NOS among 1,051 patients randomized to pioglitazone, compared with 3 patients developing cholecystitis NOS and 1 participant developing acute cholecystitis NOS among 1,046 patients randomized to glyburide.150

### The Evidence About Macular Edema (Appendix G, Table 12)

In one trial, macular edema was reported in two subjects with metformin plus thiazolidinedione compared to none in the metformin plus meglitinide arm.131

### The Evidence About Gastrointestinal Effects (Appendix G, Table 12)

Fifty-one studies examined GI adverse events, which included nausea, abdominal pain, diarrhea, or a composite outcome. We included 21 studies36,52,54,60–63,65,66,68,70,71,79,81,86–88,110,128,140,159 from the 2007 CER21 and identified 30 additional studies38,44,49,56,59,76–78,80,84,85,92–95,100,101,121–123,126,132,133,142,145,150,152,156,197,200 for the update that reported GI adverse events for comparisons of interest.

Metformin versus thiazolidinediones. Five RCTs compared GI adverse events between metformin and either rosiglitazone or pioglitazone (Table 16).38,49,52,54,56 GI adverse event rates were consistently higher in the metformin arm compared with a thiazolidinedione.

Table 16 Randomized controlled trials comparing metformin with thiazolidinediones for gastrointestinal effects

Author, year | Outcome | Event rates (metformin versus thiazolidinediones)
Kahn, 2006^38^ | Combined GI events | 38% (557/1454) versus 23% (335/1456)
Kahn, 2006^38^ | Nausea | 11.7% (170/1454) versus 7.7% (112/1456)
Kahn, 2006^38^ | Vomiting | 5.8%(84/1454) versus 4% (58/1456)
Kahn, 2006^38^ | Diarrhea | 23.7%(345/1454) versus 8.9% (129/1456)
Kahn, 2006^38^ | Abdominal discomfort | 15.4%(224/1454) versus 11.1% (161/1456)
Rosenstock, 2006^49^ | Nausea/vomiting | 13% (20/154) versus 8% (13/159)
Rosenstock, 2006^49^ | Diarrhea | 21% (32/154) versus 7% (11/159)
Rosenstock, 2006^49^ | Dyspepsia | 8% (12/154) versus 9% (14/159)
Schernthaner, 2004^52^ | Diarrhea | 11.1% (66/597) versus 3.2% (19/597)
Schernthaner, 2004^52^ | Nausea | 4.2% (25/597) versus 2.3% (14/597)
Pavo, 2003^54^ | Diarrhea | 16% (16/100) versus 3% (4/105)
Perez, 2009^56^ | Diarrhea | 15.3% (32/210) versus 2.6% (5/189)

GI = gastrointestinal

Metformin versus sulfonylureas. Eleven RCTs examined GI adverse events between metformin and a second-generation sulfonylurea.38,59–53,65,66,68,70,71 GI adverse events rates were consistently higher in the metformin arm compared with a sulfonylurea (Table 17).

Table 17 Randomized controlled trials comparing metformin with sulfonylureas for gastrointestinal effects

Author, year | Outcome | Event rates (metformin versus sulfonylureas)
Chien, 2007^59^ | Combined GI events | 32% (8/25) versus 13% (3/23)
Kahn, 2006^38^ | Combined GI events | 38% (557/1454) versus 22% (316/1441)
Kahn, 2006^38^ | Nausea | 11.7% (170/1454) versus 6.9% (99/1441)
Kahn, 2006^38^ | Vomiting | 5.8% (84/1454) versus 3.1% (45/1441)
Kahn, 2006^38^ | Diarrhea | 23.7% (345/1454) versus 9.9% (142/1441)
Kahn, 2006^38^ | Abdominal discomfort | 15.4% (224/1454) versus 11.3% (163/1441)
Garber, 2003^61^ | Nausea/vomiting | 10.4% (17/164) versus 6.6% (10/151)
Garber, 2003^61^ | Abdominal pain | 6.1% (10/164) versus 4% (6/151)
Garber, 2003^61^ | Diarrhea | 18% (30/164) versus 5.3% (18/151)
Blonde, 2002^63^ | Nausea and vomiting | 12.4% (19/153) versus 5.5% (9/164)
Blonde, 2002^63^ | Dyspepsia/heartburn | 4.6% (7/153) versus 3% (5/164)
Blonde, 2002^63^ | Flatulence | 2% (3/153) versus 0% (0/164)
Hermann, 1994^68^ | Any GI outcome | 63% (24/38) versus 32% (11/34)
Hermann, 1994^68^ | Abdominal pain | 18% (7/38) versus 6% (2/34)
Hermann, 1994^68^ | Diarrhea | 50% (19/38) versus 0 (0/34)
Hermann, 1994^68^ | Nausea | 24% (9/38) versus 9% (3/34)
Hermann, 1994^68^ | Withdrawal for GI symptoms | 14% versus 0%
Goldstein, 200362 | Diarrhea | 17.3% (13/75) versus 13.1% (11/84)
Derosa, 2004^60^ | Nausea and diarrhea | 2.4% (2/75) versus 0% (0/73)
Charpentier, 2001^71^ | Diarrhea | 7% (5/75) versus 1% (1/150)
DeFronzo, 1995^70^ | Nausea and diarrhea | 1.4% (3/210) versus 1.0% (2/209)
Amador-Licona, 2000^66^ | Diarrhea and abdominal pain | 14.3% (4/28) for metformin; event rates are not reported for sulfonylurea
Garber, 2002^65^ | | metformin (n = 159); glyburide (n = 160)
Garber, 2002^65^ | Any GI outcome | 43% versus 24%
Garber, 2002^65^ | Diarrhea | 15.1% versus 4.4%
Garber, 2002^65^ | Nausea/Vomiting | 6.3% versus 0.6%
Garber, 2002^65^ | Abdominal pain | 5% versus 3.1%
Garber, 2002^65^ | Dyspepsia | 5% versus 2.5%

GI = gastrointestinal

One retrospective cohort study compared the risk of adverse events associated with the use of metformin, sulfonylureas, and thiazolidinediones among geriatric patients in an outpatient settings.200 Consistent with the results from the trials, this cohort reported higher GI adverse events with the use of metformin. However, the incidence of metformin-associated diarrhea in this study was much lower than in the clinical trials and the authors suggested that it may be a result of pre-therapy screening or effective patient self-management.

Metformin versus DDP-4 inhibitors. Two RCTs compared metformin and sitagliptin. The first assessed the incidence of total GI adverse events, including abdominal pain, diarrhea, nausea, and vomiting.76 Compared with the arm with highest dose of metformin, the sitagliptin arm had fewer GI adverse events overall (31 percent versus 20 percent), and less diarrhea (12 percent versus 4 percent), nausea (10 percent versus 1 percent), and vomiting (3 percent versus 1 percent). There was no reported difference between groups for abdominal pain. The second RCT also compared metformin with sitagliptin for the combined outcomes of diarrhea, nausea, abdominal pain, and vomiting and found a higher incidence in the metformin group (20.7 percent versus 11.6 percent). When each outcome was looked at individually, it became evident that diarrhea accounted for most of this difference (incidence 10.9 percent versus 3.6 percent) followed by nausea (3.1 percent versus 1.1 percent) and vomiting (1.3 percent versus 0.4 percent).77

One RCT compared metformin with saxagliptin and found a higher incidence of diarrhea in the metformin arm (24 percent versus 10 percent).78

Metformin versus meglitinides. Four RCTs compared GI adverse events between metformin and a meglitinide (Table 18).79–81,197 Composite GI adverse events rates were generally higher in the metformin arm compared with a meglitinide, but one trial80 reported higher diarrhea rates, but similar rates for abdominal pain and dyspepsia.

Table 18 Randomized controlled trials comparing metformin with meglitinides for gastrointestinal effects

Author, year | Outcome | Event rates (metformin versus meglitinides)
Lund, 2007^197^ | Combined GI events | 70% (65/83) versus 47% (47/82)
Horton, 2004^80^ | Diarrhea | 20.2% (21/104) versus 3.8% (4/104)
Horton, 2004^80^ | Abdominal pain | 6.7% (7/104) versus 6.7% (7/104)
Horton, 2004^80^ | Dyspepsia | 7.7% (8/104) versus 9.6% (10/104)
Derosa, 2003^81^ | Withdrawal for GI symptoms | 3.6% (2/56) versus 0% (0/56)
Horton, 2000^79^ | Withdrawal for GI symptoms | 3.4% (6/178) versus 0.6% (1/179)

GI = gastrointestinal

Metformin versus a combination of metformin and thiazolidinediones. Eight RCTs compared the rates of GI adverse events between metformin and a combination of metformin and a thiazolidinedione, generally showing similar rates between the two groups (Table 19).49,56,84–88,156

Table 19 Randomized controlled trials comparing metformin with a combination of metformin and thiazolidinediones for gastrointestinal effects

Author, year | Outcome | Event rates (metformin versus metformin plus thiazolidinediones)
Kaku, 2009^84^ | Constipation & Abdominal Pain | 2.3% (2/86) versus 2.4% (2/83)
Scott, 2008^85^ | Combined GI events | 9% (8/91) versus 7% (6/87)
Rosenstock, 2006^49^ | Diarrhea | 51% (79/154) versus 47% (73/155) (Minimal difference in rates of nausea, vomiting and dyspepsia)
Stewart, 2006^156^ | Diarrhea | 18% (49/272) versus 8% (20/254)
Bailey, 2005^87^ | Withdrawal due to GI events | 5.4% (15/280) versus 3% (9/288)
Weissman, 2005^86^ | Withdrawal due to GI events | 6.8% (26/384) versus 3.1% (12/382)
Weissman, 2005^86^ | Combined GI events | OR 1.6 (95% CI 1.2 to 2.2)
Gomez-Perez, 2002^88^ | Combined GI events | 15.4% (5/35) versus 16.8% (6/35) for low dose combination and 16.8% (6/36) for high dose combination
Perez, 2009^56^ | Diarrhea | 15.3% (32/210) versus 9% (18/201)

CI = confidence interval; GI = gastrointestinal; OR = odds ratio

In studies that showed lower rates of diarrhea in the combination arm, the dose of metformin was lower when used in combination than when used as monotherapy.

Metformin versus a combination of metformin and sulfonylureas. Ten RCTs examined GI adverse events comparing metformin and metformin plus a second-generation sulfonylurea.36,59,61–63,65,68,70,71,92 One RCT compared subjects with GI adverse events between metformin and a combination of metformin plus glyburide and favored the combination arm.59 It reported an incidence of 32 percent for metformin alone versus 7.69 percent in the metformin/lowest dose glyburide combination (p = 0.021).59 The combination arm had a lower dose of metformin than the metformin monotherapy arm, which may account for this difference.

Six studies that were included from the 2007 CER21 compared GI events between metformin versus metformin plus glyburide or glibenclamide.36,61,63,65,68,70 Three studies did not significantly favor either arm;62,70,92 the others found fewer events in the combination arm for at least one GI adverse event, most commonly diarrhea.36,61,63,65,68,71 In general, the combination arm was favored if the doses of metformin in the combination was lower than in the monotherapy arm.

Metformin versus a combination of metformin and DPP-4 inhibitors. Four RCTs compared the incidence of GI adverse events between metformin and metformin plus sitagliptin and there was no clear difference between the two groups (Table 20).76,85,93,94 Two RCTs compared the incidence of diarrhea between metformin and metformin plus saxagliptin (Table 20).78,95 One RCT reported a higher incidence of diarrhea in the group receiving metformin and high dose saxagliptin than in the group receiving metformin alone or the group receiving metformin and low dose saxagliptin.78 A second RCT found a higher incidence of diarrhea in the metformin only group than in the two groups receiving saxagliptin and metformin.95

Table 20 Randomized controlled trials comparing metformin with a combination of metformin and DPP-4 inhibitors for gastrointestinal effects

Author, year | Outcome | Event rates (metformin versus combination of metformin and DPP-4 inhibitor)
Williams-Herman, 2009^76^ | Combined GI events | 31% (57/182) versus 29% (53/182) (no difference)
Williams-Herman, 2009^76^ | Diarrhea | 7% versus 13% (high dose combination) and 9% (low dose combination)
Williams-Herman, 2009^76^ | Abdominal Pain | 4% versus 3% (high dose combination) and 4% (low dose combination)
Williams-Herman, 2009^76^ | Vomiting | 0% versus 2% (high dose combination) and 4% (low dose combination)
Scott, 2008^85^ | Combined GI events | 9% (8/91) versus 1% (1/94)
Raz, 2008^93^ | Abdominal Pain | 7.4% (7/94) versus 10.4% (10/96)
Raz, 2008^93^ | Gastritis | 3.2% (3/94) versus 2.1% (2/96)
Raz, 2008^93^ | Upper GI Hemorrhage | 1 case in metformin versus 0 in combination group
Charbonnel, 2006^94^ | Combined GI events | 10.5% (25/237) versus 11.9% (55/464) (no difference)
Jadzinsky, 2009^78^ | Diarrhea | 7.3% (24/328) versus 9.6% (31/323) versus 6.9% (22/320); metformin versus higher dose saxagliptin combination versus lower dose saxagliptin combination
DeFronzo, 2009^95^ | Diarrhea | 11.2% (20/179) versus 5.5% (10/181) versus 5.8% (11/191) versus 9.9% (19/192); metformin versus higher dose versus intermediate dose versus lower dose saxagliptin combination

GI = gastrointestinal

Metformin versus a combination of metformin and meglitinides. One RCT compared diarrhea, abdominal pain, dyspepsia, and nausea between metformin and metformin plus nateglinide.80 The incidence of diarrhea and dyspepsia were similar between the treatment groups, but the incidence of abdominal pain was 6.7 percent in the metformin arm compared with 12.4 percent in the combination arm.

Thiazolidinediones versus sulfonylureas. Three RCTs compared diarrhea between pioglitazone or rosiglitazone and either glyburide or its chemical equivalent, glibenclamide, and showed no consistent difference between the groups (Table 21).38,100,101,150

Table 21 Randomized controlled trials comparing thiazolidinediones with sulfonylureas for gastrointestinal effects

Author, year | Outcome | Event rates (thiazolidinediones versus sulfonylureas)
Jain, 2006^101^ | Diarrhea | 6.0% (15/251) versus 6.4% (16/251) (no difference)
Hanefeld, 2007^100^ | Combined GI events | 5.5% versus 3.4% (no difference) (4mg dose of rosiglitazone)
Kahn, 2006^38^ | Any GI outcome | 23% (335/1456) versus 21.9% (316/1441)
Kahn, 2006^38^ | Nausea | 8% (112/1456) versus 7% (99/1441)
Kahn, 2006^38^ | Vomiting | 4% (58/1456) versus 3% (45/1441)
Kahn, 2006^38^ | Diarrhea | 9% (129/1456) versus 10% (142/1441)
Kahn, 2006^38^ | Abdominal discomfort | 11% (161/1456) versus 11% (163/1441)
Tolman, 2009^150^ | Diarrhea | 8.8% (93/1051) versus 7.6% (80/1046)

GI = gastrointestinal; mg = milligram

Thiazolidinediones versus meglitinides. A single RCT compared diarrhea incidence between pioglitazone and repaglinide and reported slightly fewer events in the pioglitazone arm (3 percent versus 5 percent).110

Sulfonylureas versus GLP-1 agonists. One RCT compared constipation between glibenclamide and liraglutide and found a similar incidence: 5/132 versus 15/268 (3.8 percent versus 5.6 percent). The same study also compared diarrhea and found an incidence of 5/132 versus 17/268 (3.8 percent versus 6.3 percent).121

One RCT compared GI adverse events between glimepiride and liraglutide and found significantly more events in the liraglutide group.122 Overall, the incidence of participants with GI adverse events was 49 percent and 51 percent in the liraglutide groups (at 1.2 mg and 1.8 mg respectively) and 26 percent in the glimepiride arm. Nausea was reported by 27.5 percent and 29.3 percent of participants in the liraglutide groups (at 1.2 mg and 1.8 mg respectively) compared with 8.5 percent in the glimepiride group (p < 0.0001 for both comparisons). Vomiting was seen in 9.3 percent and 12.4 percent of patients in the liraglutide groups versus 3.6 percent of patients on glimepiride. Diarrhea was seen in 15.5 percent (liraglutide 1.2 mg, p = 0.0283), 18.7 percent (liraglutide 1.8 mg, p = 0.0017) and 8.9 percent (glimepiride group).

Combination of metformin and thiazolidinediones versus combination of metformin and sulfonylureas. Four RCTs examined GI adverse events between metformin plus a thiazolidinedione and metformin plus a sulfonylurea with inconsistent results (Table 22).123,126,128,159

Table 22 Randomized controlled trials comparing a combination of metformin and thiazolidinediones with a combination of metformin and sulfonylureas for gastrointestinal effects

Author, year | Outcome | Event rates (metformin plus thiazolidinedione versus metformin plus sulfonylurea)
Umpierrez, 2006^126^ | Diarrhea | 4.7% (5/104) versus 6% (6/96) (no difference)
Hamann, 2008^123^ | Combined GI events | 13% (38/294) versus 18% (54/301)
Derosa, 2005^159^ | Flatulence | 4.2% (2/48) versus 2.1% (1/47)
Garber, 2006^128^ | Combined GI events | 10% (16/155) versus 11% (18/159) (no difference)
| Diarrhea | 3% (5/155) versus 6% (10/159)
| Abdominal pain | 4% (6/155) versus 6% (10/159)

GI = gastrointestinal

Combination of metformin and thiazolidinediones versus combination of metformin and GLP-1 agonists. One RCT compared metformin and rosiglitazone to metformin and exenatide for the individual outcomes of diarrhea and vomiting and found a higher incidence for both outcomes in the exenatide group (diarrhea: 4 percent versus 7 percent; vomiting: 0 percent versus 22 percent, respectively).132

Combination of metformin and thiazolidinediones versus combination of metformin and DPP-4 inhibitors. One RCT compared GI adverse events in the combination of metformin plus rosiglitazone versus the combination metformin plus sitagliptin and did not favor either arm for total GI events or for the specific events of diarrhea, nausea, abdominal pain, and vomiting.85

Combination of metformin and sulfonylureas versus combination of metformin and DPP-4 inhibitors. One RCT compared diarrhea, abdominal pain, nausea, and vomiting between metformin with glipizide and metformin with sitagliptin and did not favor either arm.133

Combination of metformin and sulfonylureas versus combination of metformin and meglitinides. One RCT compared diarrhea and constipation between metformin with glyburide and metformin with nateglinide and did not show an overall difference between arms, but did report more dyspepsia in the metformin with glyburide arm (13 percent versus 3 percent).152

Combination of metformin and sulfonylureas versus combination of metformin and GLP-1 agonists. One RCT compared metformin and glibenclamide versus metformin and exenatide for vomiting and diarrhea with a similar incidence of adverse events in both groups (vomiting: 1/65 versus 1/63; diarrhea: 1/65 versus 2/63).44

Another RCT compared metformin and glimepiride versus metformin and liraglutide for the combined outcomes of nausea, vomiting, and diarrhea and found a higher incidence in the liraglutide group (17 percent versus 40 percent and 44 percent respectively as the total dose of liraglutide increased from 1.2 mg to 1.8 mg.92

Combination of metformin and a basal insulin versus combination of metformin and another insulin. One RCT compared diarrhea incidence between metformin in a combination regimen with either insulin glargine or lispro and neither arm was favored.145

Combination of metformin and sulfonylureas versus combination of thiazolidinediones and sulfonylureas. Two RCTs compared GI adverse events between a combination of metformin and a sulfonylurea versus a combination of a thiazolidinedione and a sulfonylurea.140,142 One RCT compared diarrhea incidence and reported a higher incidence of diarrhea in the metformin combination arm (14.4 percent versus 3.4 percent). A second RCT had consistent results, favoring the thiazolidinedione combination arm compared with the metformin combination arm. It reported higher rates of diarrhea and withdrawals due to diarrhea in the metformin combination arm (diarrhea: 12 percent in the metformin combination arm versus 3 percent in the thiazolidinedione combination arm; withdrawals: 23 percent in the metformin combination arm versus 12 percent in the thiazolidinedione combination arm, respectively).140

### Publication Bias

For each meta-analysis, we examined graphical displays of publication bias and found little. We appreciate the insensitivity of these methods when the number of studies is low. We think it is more relevant to KQ3 to recognize the selective reporting of outcomes. The body of literature about adverse events is smaller than that for efficacy outcomes suggesting selective reporting of adverse event outcomes. Additionally, it is hard to know in the literature where the absence of a statement about an adverse event is evidence that it did not occur, or that it just was not reported in the publication. We conservatively opted to assume that it was just not reported and drew no conclusions from the absence of statements about adverse events.

### Gray Literature

Metformin versus sulfonylureas. One study evaluated the safety profile of metformin versus sulfonylurea.193 The study reported a higher incidence of GI adverse drug effects in the metformin group (20.3 percent) compared to the sulfonylurea groups (12.9 percent). Hypoglycemia (defined as finger stick glucose < 50 mg/dl) was reported in 3 percent of those treated with sulfonylurea but none in those treated with metformin.

Metformin versus DPP-4 inhibitors. In a pre-approval trial, sitagliptin was tested against metformin in a 24-week trial. Adverse events were very similar except for gastrointestinal side effects which were much higher with metformin (54/364 versus 11/179). The rates of hypoglycemia, cancer, fractures, and cholecystitis were very low in both groups.191 This is likely to be the same data as was published by Williams-Herman.76

Metformin versus a combination of metformin and thiazolidinediones. In a pre-approval trial, the addition of a thiazolidinedione to metformin resulted in no increased rate of hypoglycemia when compared to rates with metformin alone.217 This differs from the published data which suggests that patients treated with the combination have slightly more hypoglycemia.

In another study, metformin was compared to metformin with rosiglitazone (4 mg and 8 mg) in a 26-week trial in the United States. Hypoglycemia requiring assistance was reported in one patient on 4 mg rosiglitazone, one patient on 8 mg rosiglitazone and no patients in the metformin arm.189

Metformin versus a combination of metformin and sulfonylureas. The combination of metformin and sulfonylurea was evaluated against metformin in a 28-week trial. Hypoglycemia was reported in 3 percent of patients on metformin, 11 percent of patients on a fixed combination of 250 mg/1.25 mg and 38 percent of patients on 500 mg/2.5 mg. While no patient on metformin had hypoglycemia below 50 mg/dL, 8 of 158 patients in the low-dose combination group and 26 of 168 in the high-dose combination group reported hypoglycemia less than 50 mg/dL. In the same study the frequency of GI adverse events was 43.4 percent with metformin monotherapy, 31.6 percent with the low dose combination (p = 0.037) and 38.3 percent with the higher dose combination (difference with metformin not significant).190 One study evaluated metformin 500 mg and a low-dose combination and a high-dose combination with approximately 160 participants in each group. One patient on metformin reported symptoms of hypoglycemia compared to 22 patients on combination therapy. There were no reports of serious hypoglycemia. GI adverse events occurred in 39 percent of metformin recipients versus 35 percent of metformin with sulfonylurea recipients.192

One study evaluated the safety profile of combination of metformin plus sulfonylurea versus metformin (500 mg).193 The study reported a higher incidence of GI adverse effects in metformin group (20.3 percent) compared to in any of the three combination groups (15.9 percent, 12.2 percent and 11.6 percent respectively). Hypoglycemia (defined as finger stick glucose less than 50 mg/dL) was reported in 5 percent, 8 percent and 9 percent of those treated with the combination but none in those treated with metformin.

Metformin versus a combination of metformin and DPP-4 inhibitors. One trial for FDA approval of the combination of metformin and sitagliptin reported on the adverse outcomes of this combination (two dose levels) compared to metformin alone (two dose levels). The rates of hypoglycemia were low in the subjects treated in the combination group (6/372) and similar to that in the metformin groups (3/364). There was a single report of congestive heart failure in the combination group. Cancers were rare and equivalent in the groups as were fractures. Similarly, GI adverse events were reported in 49 participants in the combination groups and 54 in the metformin groups.191 This is probably the same data as was published by Williams-Herman.76

Thiazolidinediones versus sulfonylureas. This was a 52-week active-controlled study at different centers in Europe which compared two dosing levels of rosiglitazone to glyburide. Hypoglycemia was reported in 25/207 patients on glyburide compared to 1/200 patients on 2 mg rosiglitazone and 3/191 on 4 mg rosiglitazone. Nearly half of the events in the glyburide arm occurred in the first 14 days of treatment.189

Another trial evaluated rosiglitazone 2mg twice daily versus glyburide 10 mg twice daily for 26 weeks. No hypoglycemia was reported in the thiazolidinedione group versus 6 of 106 patients in sulfonylurea group. Hypoglycemia requiring assistance was reported by one patient in the sulfonylurea group.218 One additional study was double-blind placebo-controlled in which patients were randomized to rosiglitazone 1 mg or rosiglitazone 2mg or placebo and continued concurrent sulfonylurea therapy for 60 weeks in Europe. Hypoglycemia was reported in 2 percent of patients on sulfonylurea alone compared to 3.4 percent and 5.3 percent on low dose thiazolidinedione with sulfonylurea and high-dose thiazolidinedione with sulfonylurea, respectively.218

A 52-week, double-blind RCT assessed the risk of hypoglycemia in those treated with a thiazolidinedione and those treated with a sulfonylurea.219 A higher incidence of hypoglycemia was reported in patients treated with glyburide (12.1 percent) compared to those treated with rosiglitazone, 2 mg twice daily (0.5 percent) or rosiglitazone 4 mg twice daily (1.6 percent).

Sulfonylureas versus DPP-4 inhibitors. One preapproval trial of sitagliptin compared to glipizide showed markedly higher rates of hypoglycemia with glipizide when compared to sitagliptin (187/584 versus 29/588). The rates of congestive heart failure were low and similar (1 versus 1), as were GI sides effects (69 versus 74), cancer (7 versus 5) and cholecystitis (2 versus 0).191 This is consistent with the published literature.

### Applicability

The applicability of this body of studies to the question of harm depends largely on the characteristics of the participants enrolled in the trials and how different the enrolled subjects are from the population of patients with diabetes who may experience harms when treated with these drugs. Additionally, the evidence can only be considered highly applicable if the doses of the drugs administered are comparable to that which is used in practice and the treated patients are monitored at a frequency comparable to that used in practice. We have no concerns about the applicability of these studies regarding the latter two criteria—the tested drug regimens are quite comparable by dose, frequency and monitoring to those used in a usual care setting.

The majority of the evidence about harms of these drugs comes from trials lasting 2 years or less. This duration of exposure of the subjects to the drug is shorter than would typically be seen in practice where these drugs may be prescribed for decades. Nonetheless, for the majority of the harms from the drugs, such as hypoglycemia or lactic acidosis, the incidence rate per year is not expected to increase with the duration of exposure to the drug. It is less clear with other harms like congestive heart failure whether this may be dependent on the duration of exposure. If the harms do increase with exposure time, these relatively short trials are not entirely applicable to addressing this question.

The most pronounced threat to the applicability of these studies to addressing the question about harm is the enrolled population. The vast majority of studies had a mean age of participants in their 50s. Fewer than 10 studies enrolled older participants and these had a mean age in the low 60s. The prevalence of diabetes increases with age and these trials of harms from hypoglycemic agents are not necessarily applicable to older adults in their 70s and 80s or older. Further, the trials were very restrictive in their inclusion criteria, as is necessary for the safety of the participants. Thus, these studies are not necessarily applicable to the broader patient population with diabetes, many of whom have some renal insufficiency and coronary artery disease. The studies’ populations were primarily Caucasian, although some of the trials in Asia enrolled only Asian patients. The proportion of participants of African descent was uniformly low (nearly always less than 10 percent), so the applicability of these results to that large patient population cannot be assured.

## Key Question 4 Do safety and effectiveness of these treatment options (see list of comparisons) differ across subgroups of adults with type 2 diabetes, in particular for adults age 65 or older, in terms of mortality, hypoglycemia, cardiovascular and cerebrovascular outcomes?

### Key Points

- Few studies had sufficient power to assess comparative effectiveness or safety by subgroup. The evidence favoring one medication over another across subgroups is unclear.

Twenty-eight studies reported comparative effectiveness and safety for subpopulations relevant to Key Question 4. Three studies179,180,213 focused on a specific population for the study and the others conducted subgroup analyses of larger clinical trials or cohorts.

We included 21 RCTs and 7 cohort studies that addressed this key question. The majority of trials evaluated differences in the outcome of glycemic control by baseline HbA1c.75,78,85,93,96,133,136,138,220 Other trial outcomes included weight gain,179,221,222 nephropathy,184 fractures,213 and congestive heart failure.223 The cohort study outcomes focused on mortality166,169,180,224 and congestive heart failure.195,207 None of the studies conducted subgroup analyses on adverse events or mortality by age. We were unable to draw conclusions based on subgroup analyses and studies conducted in population subgroups because of the small number of studies available for each comparison of interest for each subgroup.

### The Evidence for Comparative Effectiveness and Safety in Subpopulations

Subpopulations by baseline glycemic control. The majority of studies with subgroup analyses examined differences by baseline HbA1c.75–78,85,93,96,133,136,138,220 One RCT of metformin plus nateglinide versus metformin plus glyburide found that in both treatment arms, patients with higher baseline HbA1c had a greater mean decrease in HbA1c than patients with lower baseline HbA1c.136 Ten other trials similarly found that among all treatment arms, patients with higher HbA1c had greater HbA1c reduction (see Table 23). One study of metformin versus glibenclamide found that the percent of patients achieving target glucose control did not vary by baseline HbA1c.225 A study of patients treated with nateglinide plus metformin versus metformin alone found that the subgroup of patients with lower baseline HbA1c treated with high-dose nateglinide plus metformin had increased rates of hypoglycemic symptoms compared with patients with higher baseline HbA1c.96 One study investigated the efficacy of sitagliptin versus metformin in terms of HbA1c lowering by baseline HbA1c.77

Table 23 Results from randomized controlled trials reporting outcomes in a subpopulation

Subgroup | Outcome
| HbA1c | Weight | CHF | Fractures | Nephropathy
Elevated baseline HbA1c | Met vs. met + sita:75,93 Favors met + sita Met vs. sita:77 Conclusion unclear Met vs. met + saxa:78 Favors met + saxa Met vs. met + meg:96 Favors met + meg Met + rosi vs. met + sita:85 Favors met + rosi Met + SU vs. met + meg:136 Conclusion unclear Met + glipizide vs. met + sita:133 Favors met + glipizide Met + SU vs. met + premixed:138 Favors met + premixed | No evidence | No evidence | No evidence | No evidence
Age | Met vs. sita:77 Conclusion unclear Met vs. met + sita:75,93 Favors met + sita across age groups Met + rosi vs. met + sita:85 Conclusion unclear Met + SU vs. met + meg:136 Conclusion unclear | No evidence | TZD vs. SU:223 Favors SU over pio in patients over age 64 with baseline CHF | No evidence | No evidence
Sex | Met vs. met + sita:75,93 Favors met + sita regardless of sex Met + TZD vs. met + sita:85 Conclusion unclear Met + SU vs. met + meg:136 Conclusion unclear Met vs. sita:77 Conclusion unclear | Met vs. met + pio:221 Favors met + pio for weight control regardless of gender | TZD vs. SU:223 Favors SU over pio in men with baseline CHF; Women less likely to develop heart failure than men across all treatment modalities | Met vs. TZD vs. SU:213,215 Glyburide and met favored over rosi in pre- and post- menopausal women; difference in men unclear | No evidence
Duration of diabetes | Met vs. met + sita:75,93 Favors met + sita regardless of duration Met + TZD vs. met + sita:85 Conclusion unclear Met vs. sita:77 Conclusion unclear | No evidence | No evidence | No evidence | No evidence
Prior treatment | Met vs. met + SU:92 Favors met + SU regardless of prior treatment. Met + insulin glargine vs. met + premixed:145 Favors met + premixed regardless of prior number of injections Met + TZD vs. met + meg:131 Conclusion unclear Met vs. sita:77 Conclusion unclear | No evidence | TZD vs. SU:223 Favors SU over pio in patients with baseline CHF and insulin use. | No evidence | No evidence
Obesity | Met vs. SU:37 Favors SU among obese patients in long-term treatment (over 9 years) Met vs. met + rosi:179 Favors met + rosi among overweight and obese patients Met vs. met + sita:75,93 Favors met + sita across BMI groups Met + rosi vs. met + sita:85 Conclusion unclear Met + SU vs. met + nateglinide:136 Conclusion unclear Met vs. sita:77 Conclusion unclear | Met vs. SU:222 Obese patients lost more weight with met Met vs. met + rosi:179 Favors met for weight loss among obese patients | No evidence | No evidence | No evidence
Geo-graphic region | Met vs. sita:77 Conclusion unclear
Elevated DBP | No evidence | No evidence | No evidence | No evidence | Pio vs. SU:184 Conclusion unclear
Race | Met + SU vs. met + nateglinide:136 Conclusion unclear | No evidence | No evidence | No evidence
Baseline proteinuria | No evidence | No evidence | No evidence | No evidence | Pio vs. SU:184 Conclusion unclear Rosi vs. SU:104 Conclusion unclear

BMI = body mass index; CHF = congestive heart failure; DBP=diastolic blood pressure; HbA1c = hemoglobin A1c; Meg = meglitinides; Met = metformin; Pio = pioglitazone; Premixed = premixed insulin; Rosi = rosiglitazone; Saxa = saxagliptin; Sita = sitagliptin; SU = sulfonylurea; TZD = thiazolidinedione

Subpopulations by age, sex or race. Five studies examined the impact of age on glycemic control, but we were unable to draw conclusions regarding comparative medication effectiveness in older adults with diabetes. Five found no difference in the effect on HbA1c,75,77,85,93,136 one found that patients over age 46 were more likely to require combination therapy to reach target glucose control than younger patients.222 One study of the impact of diabetes treatment on congestive heart failure hospitalizations and cardiovascular mortality in patients with baseline New York class II or III heart failure found that among patients over age 64 years, higher rates of heart failure progression were noted in the pioglitazone users compared with glyburide users whereas no significant difference was seen in younger patients.223

Six studies examined the impact of sex on glycemic control, and found no differences in the effect on HbA1c.75,77,85,93,136,222 However, a retrospective analysis of the ADOPT trial by sex found that women treated with rosiglitazone were at increased risk of fracture relative to those treated with metformin or glyburide (HR 1.57 and 1.61, respectively)213 over a median followup of 4 years. Consistent with the ADOPT trial, the RECORD study reported higher fracture risk in women compared with men (RR 1.82, 95 percent CI 1.37 to 2.41 versus 1.23, 95 percent CI 0.85 to 1.77) in the rosiglitazone plus metformin or sulfonylurea arm, as compared to the metformin plus sulfonylurea active control arm. The fractures occurred predominantly in the upper limb, distal lower limb, and were not hip fractures.16

Two studies examined the impact of race on HbA1c reduction, and found no impact on glycemic control.77,136 A retrospective study of all-cause mortality among patients treated with hypoglycemic agents found that in women, metformin use was associated with lower mortality rate at 1 year than use of sulfonylureas, whereas in men mortality was increased in metformin users compared to sulfonylurea users.224 Higher rates of heart failure progression in patients with baseline congestive heart failure were found among men treated with pioglitazone compared with glyburide, but rates were similar among women.223 A retrospective study of heart failure development among patients with diabetes treated with metformin, insulin, or sulfonylurea found that women were less likely to develop heart failure than men across all treatment modalities.195

None of the studies we included assessed the impact of socioeconomic status or education level on glycemic control or outcomes.

Subpopulations by obesity, duration of diabetes, or geographical region. Five studies found no effect of body mass index on HbA1c reduction or glycemic control.75,77,85,136,222 A study evaluating rosiglitazone plus metformin combination therapy versus metformin monotherapy found that among patients treated with metformin monotherapy fewer obese patients had at least one adverse event than non-obese patients, most commonly diarrhea and headache.179 Another study of efficacy at achieving an HbA1c less than 7 percent found that obese patients treated with metformin had greater chance of achieving the targeted HbA1c level without additional agents than patients treated with sulfonylurea or insulin.37 An important consideration in obese patients is medication impact on weight control, and a prospective study found that obese patients allocated to insulin had a greater mean increase in body weight than those allocated to sulfonylurea, and those allocated to metformin, on average, lost weight.222

Four studies found no impact of the duration of diabetes on glycemic control.75,77,85,93 One study found that among patients treated with glibenclamide, the percent of patients achieving targeted glycemic control varied inversely with duration of diabetes.225

One RCT compared sitagliptin and metformin and found that glycemic control did not differ by “geographical region” (regions not specified).77

Subpopulations by required medication dosage. Two retrospective studies examined outcomes among patients who required higher than median doses of sulfonylurea and metformin and found that high-dose sulfonylurea users (chlorpropamide, tolbutamide, glipizide, and glyburide) had higher risk of heart failure208 and increased mortality166 than those treated with lower doses of these medications. Notably, high-dose users of metformin were not at elevated risk of heart failure or increased mortality.166,208 These findings were from observational studies so there was likely to be residual confounding, related to the patients’ need for higher doses.

Subpopulations by prior comorbid conditions. A retrospective cohort study concluded that patients with a prior diagnosis of ischemic heart disease treated with either sulfonylurea or repaglinide had higher all-cause mortality than those treated with metformin alone after adjusting for age, sex, and comorbidity.180 A retrospective cohort study of patients with heart failure treated with metformin monotherapy, sulfonylurea monotherapy, or combination therapy found that use of metformin, alone or in combination, was associated with reduced all-cause 1-year mortality compared with sulfonylurea monotherapy (adjusted HR 0.66, 95 percent CI 0.44 to 0.97 and 0.54, 95 percent CI 0.42 to 0.70, respectively). This mortality benefit persisted after mean followup of 2.5 years.169 No studies in our review specifically reported the comparative effectiveness of medications in patients with other underlying cardiovascular disease risk factors, such as hypertension.

A trial of rosiglitazone versus glyburide for reduction of urinary albumin excretion found that among patients with baseline microalbuminuria (baseline urine albumin to creatinine ratio ≥ 30 ug/mg) there was a correlation between reduction in mean blood pressure and reduction in albumin excretion (r = 0.875) for patients treated with rosiglitazone but not glyburide. There was no significant difference in reduction of baseline microalbuminuria between the two groups. 104 No studies included in our review compared the safety and efficacy of diabetes medications by patients’ renal function.

Observational studies. Seven cohort studies reported on subpopulations.166,169,180,195,207,215,224 Three studies only reported analyses adjusted for several key patient characteristics but did not specifically report differences by group.166,169,207

Two observational studies reported on mortality in subpopulations. One retrospective cohort study included 8,494 participants in a nationwide population-based followup study of Danish patients with a myocardial infarction. Among women, the use of metformin was associated with a lower mortality rate than the use of sulfonylureas (adjusted 1-year HR 0.49, 95 percent CI 0.30 to 0.79), whereas among men the risk appeared to be increased (adjusted 1-year HR 1.82, 95 percent CI 1.25 to 2.64).224 Another study favored metformin over sulfonylurea or repaglinide for all-cause age-adjusted mortality in people with prior ischemic heart disease.180

One study supported the finding from a RCT223 that men were more likely to develop congestive heart failure than women regardless of pharmacologic treatments, which included various monotherapy and combination therapies for the cohort study.195

One cohort study of 84,339 patients from British Columbia, Canada, compared fracture rates in users of pioglitazone, rosiglitazone and sulfonylureas in men and women. In women, the overall fracture rate among users of any thiazolidinedione was greater than sulfonylureas (adjusted HR 1.34, 95 percent CI 1.10 to 1.64), but this was not the case for men. For both women and men, pioglitazone use was associated with higher risk of peripheral fracture (defined by the International Classification of Diseases, 9th Edition [ICD-9] codes) compared with sulfonylurea (adjusted HR for women 1.77, 95 percent CI 1.32 to 2.38 and adjusted HR for men 1.61; 95 percent CI 1.18 to 2.20). Rosiglitazone use was not associated with increased fracture risk in men or women.215

## Quality Assessment

Quality assessment of trials. Out of the 143 trials included in this report, only six were described as non-randomized trials and two were a crossover study (Appendix G, Table 13). Among the 136 RCTs, 35 percent described their randomization scheme and another 58 percent were described as being double-blinded. About one-third of all double-blinded RCTs also described the steps taken to ensure blinding. The majority of trials (74 percent) described the withdrawals and dropouts. Although we evaluated the quality of the studies included in our 2007 CER, we used a different approach for the additional articles identified for this update. Among the 55 trials included from the 2007 review, only about one third of them received the highest two quality scores (4 or 5) on the five-point scale used in our update. Among the 88 trials identified for the update, 37 percent were rated as “good” quality, 46 percent as “fair” quality and 17 percent as “poor” quality.

Quality assessment of observational studies. We assessed the quality of the 26 observational studies newly identified for the update (Appendix G, Table 14). In the 2007 review, we did not assess the quality of observational studies. Of the newly identified studies, 42 percent reported the study setting or study population from which the study sample was drawn, 88 percent described inclusion/exclusion criteria, and 73 percent provided at least some description of key characteristics of the study population. Thirty-one percent of the studies provided details about treatment, which included treatment type, dose, timing and duration of medication. Seventy-seven percent of studies described and objectively measured the outcomes of interest. The majority of studies conducted appropriate statistical analyses and presented results adjusted or stratified for differences in groups or stated that the groups were comparable at baseline. Only five of the prospective cohort studies described the number of participants who were lost to followup after the start of the period of observation. Twenty-five of 26 observational studies were rated as having fair or good overall quality.

## Articles Reporting More Than One Study

Nine studies reported on more than one study (see Table 24).226–234 Since many of these studies pooled data from studies already included in our review, we did not abstract that data. For articles that pooled data from studies not included in our review, we abstracted and reported the results. The results from these studies are consistent with the findings from our review.

Table 24 Summary of studies reporting on more than one study

Author, year | Results of pooled studies if not duplicated or already in our report
Belcher, 2004^226^ | Mean blood pressure was slightly reduced by all treatments, with pioglitazone treatment resulting in the largest falls (approximately 1.5 mmHg). Hospitalizations for cardiac or cerebrovascular events were similar with the different treatments. Overall mortality was 7 of 1857 for pioglitazone and 10 of 1856 for non-pioglitazone treatments, of which 3 and 6 were cardiac deaths, respectively. The incidence of congestive cardiac failure was similar with pioglitazone (12/1857) and non- pioglitazone (10/1856) treatments.
Khan, 2004^227^ | Pioglitazone, alone or combined with metformin or sulfonylurea, resulted in mean decreases in triglycerides (9 to 11%), and mean increases in HDL cholesterol (17 to 20%).
Davidson, 2004^228^ | Individual studies were included in the report
Perez, 2004^229^ | This study mostly discusses subfractionations of lipids. They do state that pioglitazone in combination with metformin or sulfonylurea was significantly associated with an increase in HDL after 24 weeks. For pioglitazone plus metformin only, LDL increased from baseline significantly.
Belcher, 2005^230^ | Individual studies were included in the report
Belcher, 2005^231^ | Individual studies were included in the report
Charbonnel, 2005^232^ | Individual studies were included in the report
Ceriello, 2005^233^ | Individual studies were included in the report
Rendell, 2003^234^ | Individual studies were included in the report

HDL = high density lipoprotein; LDL = low density lipoprotein; mmHg = millimeters of mercury