# Peer Reviewers

Lloyd Axelrod, M.D.

Massachusetts General Hospital

Boston, MA

Gilad Gordon, M.D., M.B.A.

ORRA Group

Boulder, CO

Tarek Hammad, M.D.

Food and Drug Administration

Silver Spring, MD

Steven Mitchell

Consumer Union

Leonard Pogach, M.D.

Veterans Administration Health Care System

East Orange, NJ

Helena W. Rodbard, M.D., F.A.C.P., M.A.C.E.

Endocrine and Metabolic Consultants

Rockville, MD

Donna Sweet, M.D.

American College of Physicians

Wichita, KS