# Introduction

## Background

Type 2 diabetes is a common chronic illness, with an increasing prevalence that parallels the rise in obesity rates. Type 2 diabetes is characterized by insulin resistance, which is worsened by obesity and physical inactivity. Over time, the pancreatic beta cells lose their ability to maintain the high insulin levels needed to counter liver and muscle insulin resistance and beta cell failure occurs.1 The natural history of type 2 diabetes has been described in several populations.1

In the United States, the prevalence of diabetes has increased from 5.1 percent during 1988–1994 to 6.5 percent during 1999–2002.^2^ Like many chronic illnesses, diabetes disproportionately affects older people, and its prevalence is higher among racial and ethnic minority populations.3 The annual economic burden of diabetes is estimated to be $132 billion4 and is increasing, mostly attributable to costly complications of the disease.5

Complications of longstanding diabetes include the microvascular complications of retinopathy and blindness, neuropathy, nephropathy, and end-stage kidney disease. In addition, there is a twofold to fourfold increased death rate from cardiovascular disease in adults with type 2 diabetes compared to adults without diabetes.6 Management of hyperglycemia using diet and pharmacologic therapy is the cornerstone of treatment for type 2 diabetes, along with management of coexisting lipid abnormalities and hypertension. Results from randomized controlled trials have demonstrated that the risk of microvascular complications, particularly retinopathy, can be reduced with good glycemic control in patients with type 2 diabetes.7–9 However, studies have had mixed results regarding the impact of intensive glycemic control (hemoglobin A1c [HbA1c] < 7 percent) on cardiovascular events and mortality. While older studies indicated that intensive glycemic control may reduce cardiovascular morbidity and mortality,10,11 recent studies have raised the possibility that intensive glycemic control has either no effect or a negative effect on cardiovascular morbidity and mortality.12,13 These mixed results suggest the need for further research, including investigation of the long-term safety of glucose-lowering therapies.8,11,14

Early data from the United Kingdom Prospective Diabetes Study suggested a protective effect of improved glucose control on cardiovascular disease morbidity and mortality. In particular, treatment with metformin compared with sulfonylureas and insulin resulted in greater cardiovascular benefit.8 However, in the last two years, several major trials have found no benefit from intensive glycemic control.12–13 In fact, the Action to Control Cardiovascular Disease in Diabetes study identified an increased risk for death from cardiovascular causes and higher total mortality among those participants treated with an intensive glucose control strategy.13 There have been concerns, too, about an increased risk of ischemic heart disease and congestive heart failure associated with specific oral hypoglycemic agents, specifically rosiglitazone, from the thiazolidinedione class.15,16 National trends in the treatment of diabetes have reflected the public’s concern about this drug, with a 63 percent decrease in rosiglitazone use between 2004 and 2007.^17–19^

In 1995, the only drugs for treating diabetes were sulfonylureas and insulin. Since 1995 many new pharmacotherapy options have become available. Currently there are 11 classes of diabetes medications, including sulfonylureas, meglitinides, glucagon-like peptide-1 (GLP-1) receptor agonists, biguanides, an amylin analogue, thiazolidinediones, bromocriptine, alpha-glucosidase inhibitors, dipeptidyl peptidase-4 (DPP-4) inhibitors, colesevalam (a bile-acid sequestrant), and insulins (Table 1).17 The newer agents are more costly than the older medications, and some are only approved as adjunctive therapies.

Table 1 Characteristics of medications included in this report

Drug | Trade name | Dosing | Cost in U.S. dollars^*^
ORAL AGENTS
Biguanides
Metformin | Glucophage, Glucophage XR | Oral: 500 to 2550 mg divided doses (qd to tid) Max dose: 2550 mg; 2000 mg for XR | Tablets 500 mg (100): $35.57 850 mg (100): $38.63 1000 mg (100): $45.97 Tablet, 24-hour 750 mg (100): $114.98
Thiazolidinediones
Pioglitazone | Actos | Oral: 15 to 30 mg qd max dose: 45 mg qd | 15 mg (30): $144.36 30 mg (30): $220.61 45 mg (30): $239.29
Rosiglitazone | Avandia | Oral: 4 to 8 mg qd or 2 to 4 mg bid max dose: 8 mg qd or 4 mg qd with insulin or sulfonylurea | 2 mg (60): $158.94 4 mg (30): $117.95 8 mg (30): $214.31
Sulfonylureas
Glimepiride | Amaryl | Oral:1 to 8 mg qd max dose: 8 mg qd | 1 mg (100): $13.41 2 mg (100): $21.74 4 mg (100): $41.00
Glipizide | Glucotrol, Glucotrol XL or GITS | Oral: 5 to 15 mg qd or 5 to 20 mg bid max dose: 20 mg bid, 20 mg qd for XL | Tablets 5 mg (100): $64.07 10 mg (100): $117.58 Tablet, 24-hour 2.5 mg (30): $19.00 5 mg (100): $63.34 10 mg (100): $125.52
Glyburide | Micronase, Diabeta, Glynase Prestab | Oral: 2.5–20 mg qd or bid max dose: 20 mg qd | Tablets 1.25 mg (100): $12.44 2.5 mg (100): $18.93 5 mg (30): $28.31
Dipeptidyl peptidase-4 inhibitors
Sitagliptin | Januvia | Oral: 25 to 100 mg qd recommended dose is 100 mg qd | 100 mg (30): $192.52
Saxagliptin | Onglyza | Oral: 2.5–5 mg qd | Not listed
Meglitinides
Repaglinide | Prandin | Oral: 0.5 to 4 mg before meals max dose:16 mg | 0.5 mg (100): $194.14 1 mg (100): $194.14 2 mg (90): $194.14
Nateglinide | Starlix | Oral: 60 to 120 mg before meals | 60 mg (100): $177.31 120 mg (100): $184.22
NON-INSULIN SUBCUTANEOUS AGENTS
GLP-1 agonists
Exenatide injection | Byetta | SC injection: 5–10 mcg SC bid | 5 mcg/0.02 mL solution 1.2 mL: $231.20 10 mcg/0.04 mL solution 2.4 mL: $271.32
Liraglutide injection | Victoza | SC injection: 1.6–1.8 mg SC qd | Not listed
INSULIN
Long-or intermediate-acting insulin
NPH insulin | Humulin N Novolin N | NA | Humulin N: 100 unit/mL suspension 10 mL vial: $33.20 Novolin N: not listed
Insulin detemir | Levemir | NA | 100 unit/mL solution 10 mL vial: $103.18
Insulin glargine | Lantus | 1–80 units daily | 100 unit/mL solution 10 mL vial: $103.16
Premixed insulin
50% NPH: 50% Regular | Humulin 50/50 | NA | Not listed
70% NPH: 30% Regular | Humulin 70/30 Novolin 70/30 | NA | Humulin: 10 mL vial: $143.34
50% lispro protamine suspension: 50% lispro | Humalog Mix 50/50 | NA | 10 mL vial: $111.24
75% lispro protamine suspension: 25% lispro | Humalog Mix 75/25 | NA | 10 mL vial: $111.24
70% aspart protamine suspension: 30% aspart | NovoLog Mix 70/30 | NA | 10 mL vial: $111.20

bid = twice daily; GITS = gastrointestinal therapeutic system; HCl = hydrogen chloride; max = maximum; mcg = micrograms; mg = milligram; mL = milliliter; NA = not applicable; NPH = neutral protamine Hagedorn; qd = once daily; SC = subcutaneous; tid = three-times daily; U.S. = United States; XL = extended release; XR = extended release

Used Micromedix: http://www.thomsonhc.com/hcs/librarian for pharmaceutical information.

* Information provided includes dose, pill count, and cost in U.S. dollars (Red Book Pharmacy’s Fundamental Reference, 2009 Edition); Prices for branded medications are italicized.

With the increasing number of available medication choices for diabetes, patients are being managed with a greater number of classes of medications in combination. During 2005–2006, 35.3 percent of all patients with diabetes were taking two classes of antidiabetes medications and 14.2 percent were taking three or more classes, compared to only 5.6 percent percent taking three or more classes during 1999–2000.^20^ Some experts advocate earlier use of combination therapies to prevent the progressive beta cell failure associated with diabetes, but the evidence for this protection is still not clear.1 With newer insulin products on the market since 2001, use of insulin has started to increase. Long-acting insulin glargine and the ultra-short-acting insulin lispro are the most commonly used individual insulin therapies in 2007.^17^

## Rationale for Update of Review on Comparative Effectiveness of Diabetes Medications

In 2007, the Agency for Healthcare Research and Quality (AHRQ) published its first systematic review on the comparative effectiveness of oral hypoglycemic medications for type 2 diabetes.21 This comprehensive review was unique because it included comparisons of all oral diabetes medications. It also had a broad scope, including both intermediate outcomes like glycemic control and clinical outcomes like cardiovascular disease and nephropathy, as well as adverse events. This review of 216 studies concluded that most oral diabetes medications had a similar effect on reducing HbA1c, most drugs except for metformin and acarbose caused increases in body weight, and only metformin decreased low-density lipoprotein cholesterol. There were too few studies to support any conclusions about differential effects of the oral diabetes medications on all-cause mortality, cardiovascular mortality and morbidity, and microvascular complications. The sulfonylurea class was shown to be associated with an increased risk of hypoglycemia, metformin with gastrointestinal problems, and the thiazolidinediones with heart failure.

In the years following publication of that review, enough studies were published to merit an update to address research gaps and integrate newer evidence. Since the first review, the Food and Drug Administration (FDA) approved two new medication classes. The noninsulin injectable GLP-1 agonists, exenatide and liraglutide, were FDA-approved in 2005 and 2010, respectively. The DPP-4 inhibitors, sitagliptin and saxagliptin, were FDA-approved in 2006 and 2009. Additionally, an update of the review was needed to include evidence about combinations of medications, including combinations of an oral medication with insulin therapy. Accordingly, AHRQ requested this update to the previously published work to amalgamate and update the previously published work.

## Conceptual Model

Our conceptual model describes the decisions that patients and their providers face when managing type 2 diabetes pharmacologically (Figure 1). It highlights the comparisons and outcomes of interest that correspond to each of the key questions in our review.

Figure 1 Conceptual model

HbA1c = hemoglobin A1c; KQ=key question; NPH = neutral protamine Hagedorn

Figure 1 describes our analytic framework. It starts with the diagnosis of type 2 diabetes. The diagnosis of type 2 diabetes leads to initial medical treatment. There are several options for initial medical treatment, including: biguanides (e.g., metformin); thiazolidinediones (TZD) (e.g., rosiglitazone and pioglitazone); second generation sulfonylureas (e.g., glyburide and glipizide); meglitinides (e.g., repaglinide and nateglinide); dipeptidyl peptidase-4 (DPP-4) inhibitors (e.g., sitagliptin and saxagliptin); and glucagon-like peptide receptor agonist (GLP-1; e.g., exenatide and liraglutide). After initial medical treatment has begun, hemoglobin A1c is tested. If there is inadequate control, then a second line agent is added. Second line agents include: the addition of a second oral medication; the addition of insulin (such as a basal insulin or a premixed insulin), or the addition of an injectable GLP-1 agonist. For both initial medical treatment and the addition of a second line agent, outcomes will be measured. Outcomes include short-term outcomes (KQ1; glycemic control, lipids, and weight), long-term outcomes (KQ2; macrovascular complications and microvascular complications), mortality (KQ2), and safety and adverse events (KQ3; e.g., congestive heart failure, hypoglycemia, pancreatitis, fractures, and cancer). The effect of initial and second-line medical treatment on outcomes can be modified by age, race, sex, medical comorbidity, and medication adherence (KQ4).

When beginning medical treatment, patients usually begin with one of five drug classes, (Table 1) which have all been FDA-approved for monotherapy. These include biguanides, sulfonylureas, thiazolidinediones, DPP-4 inhibitors, meglitinides, and the GLP-1 agonists. Clinical guidelines of the American Diabetes Association recommend monitoring the HbA1c to determine the need for changing the medication dose or adding another agent to improve glycemic control.22,23 If the HbA1c is not adequately controlled, clinicians typically add an additional oral hypoglycemic medication, or may add insulin or a noninsulin injectable medication like a GLP-1 agonist. Both intermediate- and long-term outcomes are monitored as indicators of effectiveness. Intermediate outcomes include HbA1c, weight, and lipids. In addition, clinicians monitor short-term and long-term safety and adverse effects of the drug.

## Scope and Key Questions

AHRQ commissioned this Comparative Effectiveness Review to update Comparative Effectiveness Review No. 8, The Comparative Effectiveness and Safety of Oral Diabetes Medications for Adults with Type 2 Diabetes.21 Because of the rapid advances in the field of diabetes, with new medications on the market and the increasing use of medications in combination, AHRQ recognized the need to conduct an updated review and synthesis. We conducted a topic refinement process to identify the evidence gaps specified in the prior review, to assess the utility and impact of the review in subsequent guideline development, and to refine the key questions for this update. Based on this process, there are several notable distinctions from the 2007 Review, which include:

1. A focus on priority head-to-head drug comparisons, identified a priori as clinically relevant comparisons for which there were evidence gaps;
2. The inclusion of two newly FDA-approved medication classes: GLP-1 agonists (exenatide, liraglutide) and DPP-4 inhibitors (sitagliptin, and saxagliptin);
3. The inclusion of comparisons of two-drug combinations with a focus on:
  a. Metformin and thiazolidinediones in combination with another medication;
  b. Basal and premixed insulin therapy in combination with an oral medication;
4. The addition of safety outcomes, including fractures and macular edema; and
5. The exclusion of the alpha-glucosidase inhibitors (e.g., acarbose) because they are less frequently prescribed in the United States, have lower efficacy for glycemic control, and have high rates of gastrointestinal side effects limiting tolerability.21

### Key Questions

We addressed the following key questions:

Key Question 1. In adults age 18 or older with type 2 diabetes mellitus, what is the comparative effectiveness of these treatment options (Table 2 and Appendix A) for the intermediate outcomes of glycemic control (in terms of HbA1c), weight, or lipids?

Table 2 Priority medication comparisons included for each of the key questions

| Main intervention | Comparisons
Monotherapy as main intervention | Metformin | - Thiazolidinedione; - Sulfonylurea; - DPP-4 inhibitor; - Meglitinides; - GLP-1 agonist; - Combination of metformin plus thiazolidinedione; - Combination of metformin plus sulfonylurea; - Combination of metformin plus DPP-4 inhibitor; - Combination of metformin plus meglitinides
Monotherapy as main intervention | Thiazolidinedione | - Different thiazolidinedione; - Sulfonylurea; - DPP-4 inhibitor; - Meglitinides; - GLP-1 agonist
Monotherapy as main intervention | Sulfonylurea | - DPP-4 inhibitor; - Meglitinides; - GLP-1 agonist
Monotherapy as main intervention | DPP-4 inhibitors | - DPP-4 inhibitor; - Meglitinides; - GLP-1 agonist
Monotherapy as main intervention | Meglitinides | - GLP-1 agonist
Combination therapy as main intervention | Combination of metformin plus (a thiazolidinedione or a sulfonylurea or a meglitinide or DPP-4 inhibitor or GLP-1 agonist or a basal insulin or a premixed insulin) | - Combination of metformin plus (a thiazolidinedione or a sulfonylurea or a meglitinides or DPP-4 inhibitor or GLP-1 agonist or a basal insulin or a premixed insulin)
Combination therapy as main intervention | Combination of metformin plus (a thiazolidinedione or a sulfonylurea or a meglitinides or DPP-4 inhibitor or GLP-1 agonist or a basal insulin or a premixed insulin) | - Combination of a thiazolidinedione plus (a sulfonylurea or a meglitinides or DPP-4 inhibitor or GLP-1 agonist)

DPP-4 inhibitor = dipeptidyl peptidase-4 inhibitor; GLP-1 agonist = glucagon-like peptide-1 receptor agonist

Key Question 2. In adults age 18 or older with type 2 diabetes mellitus, what is the comparative effectiveness of these treatment options (Table 2) in terms of the following long-term clinical outcomes?

- All-cause mortality
- Cardiovascular mortality
- Cardiovascular and cerebrovascular morbidity (e.g., myocardial infarction and stroke)
- Retinopathy
- Nephropathy
- Neuropathy

Key Question 3. In adults age 18 or older with type 2 diabetes mellitus, what is the comparative safety of the following treatment options (Table 2) in terms of the following adverse events and side effects?

- Hypoglycemia
- Liver injury
- Congestive heart failure
- Severe lactic acidosis
- Cancer
- Severe allergic reactions
- Hip and non-hip fractures
- Pancreatitis
- Cholecystitis
- Macular edema or decreased vision
- Gastrointestinal side effects

Key Question 4. Do safety and effectiveness of these treatment options (Table 2) differ across subgroups of adults with type 2 diabetes, in particular for adults age 65 or older, in terms of mortality, hypoglycemia, and cardiovascular and cerebrovascular outcomes?