# Acknowledgments

The Evidence-based Practice Center thanks Erica Shelton, M.D. for her management of the guideline analysis and Sachin Srinivasan, Ugonna Nwosu, and Rukeme Ake for their assistance with reviewing articles.