# Abbreviations

ACCORD: Action to Control Cardiovascular Disease in Diabetes
ADOPT: A Diabetes Outcome Progression Trial
AHRQ: Agency for Healthcare Research and Quality
ALT: Alanine aminotransferase
AST: Aspartate aminotransferase
CI: Confidence interval
DPP-4: Dipeptidyl peptidase-4
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
GI: Gastrointestinal
GLP-1: Glucagon-like peptide-1
GPRD: General Practice Research Database
HDL: High density lipoproteins
HbA1c: Hemoglobin A1c
HR: Hazard ratio
HR: Hazard ratio
IRR: Incidence rate ratios
IU: International units
kg: Kilograms
LDL: Low density lipoproteins
mg/dL: Milligrams per deciliter
MI: Myocardial infarction
NPH: Neutral protamine Hagedorn
OR: Odds ratio
PROactive: PROspective pioglitAzone Clinical Trial in macroVascular Events
RCT: Randomized controlled trial
RECORD: Rosiglitazone Evaluated for Cardiac Outcomes and Regulation of Glycemia in Diabetes
RR: Relative risk
TG: Triglycerides
U.K.: United Kingdom
UKPDS: United Kingdom Prospective Diabetes Study
U.S.: United States
VA: Department of Veterans Affairs