# Appendixes

Appendix A Medication Comparisons

Appendix B Detailed Electronic Database Search Strategies

Appendix C Hand-Searched Journals

Appendix D Forms

Appendix E Tallies for Comparisons Not Included in Review

Appendix F Excluded Articles

Appendix G Evidence Tables

Appendix H Summary of Updated Literature Search for Long-Term Clinical Trials (Number of Articles)