# Summary of Updated Literature Search for Long-Term Clinical Trials (Number of Articles)

Total may exceed number in corresponding box, as articles could be excluded for more than one reason at this level.

CENTRAL = Central Register of Controlled Trials; CINAHL = Cumulative Index to Allied Health and Nursing Literature; FDA = U.S. Food and Drug Administration