# Evidence Tables

Table 1 Number of studies, strength of evidence domains, magnitude of effect, and strength of evidence (KQ1)

Outcome: Hemoglobin A1c
# of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^*^ | Precision | Magnitude and direction of effect
Met vs. TZD
16 | 5592 | Medium | Consistent for short-duration studies. One long-term study Inconsistent. | Direct | Precise | No effect; Neither drug favored | Moderate
Met vs. SU
19 | 6936 | Low | Consistent | Direct | Precise | No effect; Neither drug favored | High
Met vs. DPP-4 Inhibitors
3 | 1908 | Medium | Consistent | Direct | Precise | Small; Favored Met | Moderate
Met vs. Nateg
1 | 267 | Medium | NA | Direct | Imprecise | Small; Favored Met | Low
Met vs. Repag
2 | 167 | Medium | Consistent | Direct | Imprecise | No effect; Neither drug favored | Low
Met vs. Met + TZD
11 | 3495 | Low | Consistent | Direct | Precise | Small; Favored Met + TZD | High
Met vs. Met + SU
14 | 3619 | Low | Consistent | Direct | Precise | Small; Favored Met + SU | High
Met vs. Met + DPP-4 Inhibitors
6 | 4263 | Medium | Consistent | Direct | Precise | Small; Favored Met + DPP-4 Inhibitor | Moderate
Met vs. Met + Nateg
2 | 969 | Low | Consistent | Direct | Imprecise | Small; Favored Met + Nateg | Low
Met vs. Met + Repag
1 | 54 | Low | NA | Direct | Precise | Small; Favored Met + Repag | Low
Rosi vs. Pio
3 | 886 | Medium | Consistent | Direct | Precise | No effect; Neither drug favored | Moderate
TZD vs. SU
14 | 5578 | Medium | Consistent | Direct | Precise | No effect; Neither drug favored | Moderate
TZD vs. Repag
2 | 225 | High | Inconsistent | Direct | Precise | Small; Unable to determine which drug favored | Low
TZD vs. Nateg
1 | 34 | Medium | NA | Direct | Imprecise | No effect; Neither drug favored | Low
SU vs. DPP-4 Inhibitors
1 | 618 | Low | NA | Direct | Imprecise | No effect; Neither drug favored | Low
SU vs. Repag
7 | 1543 | Low | Consistent | Direct | Precise | No effect; Neither drug favored | High
SU vs. Nateg
2 | 82 | Medium | Consistent | Direct | Imprecise | No effect; Neither drug favored | Low
SU vs. GLP-1 Agonists
3 | 1310 | Medium | Inconsistent | Direct | Precise | Unable to determine | Low
Met + TZD vs. Met + SU
8 | 2729 | Low | Consistent for short-term trials. One long-term study Inconsistent. | Direct | Precise | No effect; Neither drug combination favored in the short term | Moderate
Met + TZD vs. Met + DPP-4 Inhibitors
2 | 293 | Medium | Consistent | Direct | Precise | No effect; Neither drug combination favored | Low
Met + TZD vs. Met + Repag
1 | 561 | Medium | NA | Direct | Precise | No effect; Neither drug combination favored | Low
Met + TZD vs. Met + GLP-1 Agonists
1 | 90 | Medium | NA | Direct | Imprecise | No effect; Neither drug combination favored | Low
Met + TZD vs. TZD + SU
1 | 170 | Medium | NA | Direct | Imprecise | Small; Favored combination of TZD + SU | Low
Met + SU vs. Met + DPP-4 Inhibitors
1 | 1172 | Low | NA | Direct | Precise | No effect; Neither drug combination favored | Low
Met + SU vs. Met + Nateg
2 | 661 | Low | Inconsistent | Direct | Imprecise | Unable to determine | Low
Met + SU vs. Met + GLP-1 Agonists
2 | 1215 | Medium | Inconsistent | Direct | Imprecise | Unable to determine | Low
Met + SU vs. Met + Premixed Insulin
2 | 827 | Medium | Inconsistent | Direct | Imprecise | Unable to determine | Low
Met + SU vs. TZD + SU
6 | 1844 | Medium | Consistent for short term trials. One longer study Inconsistent. | Direct | Precise | No effect; Neither drug combination favored | Moderate
Met + DPP-4 Inhibitors vs. Met + GLP-1 Agonists
1 | 661 | Medium | NA | Direct | Precise | Small; Favored combination of Met + GLP-1 Agonist | Low
Met + GLP-1 Agonists vs. Met + Basal Insulin
1 | 69 | High | NA | Direct | Imprecise | No effect; Neither drug favored | Low
Met + Basal Insulin vs. Met + Premixed Insulin
3 | 530 | Medium | Consistent | Direct | Precise | No effect; Neither drug combination favored | Low

Outcome: Weight
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^**^ | Precision | Magnitude and direction of effect
Met vs. TZD
10 | 5239 | Low | Consistent | Direct | Precise | Small; Favored Met | High
Met vs. SU
13 | 5067 | Medium | Consistent | Direct | Precise | Small; Favored Met | High
Met vs. DPP-4 Inhibitors
3 | 1908 | Medium | Consistent | Direct | Precise | Small; Favored Met | Moderate
Met vs. Meg (both Repag)
2 | 166 | High | Possibly Inconsistent | Direct | Imprecise | Unable to determine | Low
Met vs. Met + TZD
7 | 2647 | Low | Consistent | Direct | Precise | Small; Favored Met monotherapy | High
Met vs. Met + SU
10 | 2510 | Low | Consistent | Direct | Precise | Small; Favored Met monotherapy | High
Met vs. Met + DPP-4 Inhibitors
6 | 4263 | Medium | Consistent | Direct | Precise | No effect; Neither drug favored | Moderate
Met vs. Met + Meg
2 | 521 | Low | Consistent | Direct | Imprecise | Small; Favored Met monotherapy | Low
TZD vs. TZD
3 | 886 | Medium | Consistent | Direct | Precise | No effect; Neither drug favored | Low
TZD vs. SU
7 | 6226 | High | Consistent | Direct | Precise | Small; Favored SU | Low
TZD vs. Meg
2 | 198 | High | Consistent | Direct | Imprecise | Unable to determine | Low
SU vs. DPP-4 Inhibitors
1 | 618 | Low | NA | Direct | Imprecise | Unable to determine | Low
SU vs. Meg (all Repag)
6 | 1326 | Low | Consistent | Direct | Precise | No effect; Neither drug favored | High
SU vs. GLP-1 Agonists
3 | 1310 | Medium | Consistent | Direct | Imprecise | Small; Favored GLP-1 Agonist | Moderate
Met + TZD vs. Met + SU
6 | 2407 | Low | Consistent | Direct | Precise | Small; Favored Met + SU | Moderate
Met + TZD vs. Met + DPP-4 Inhibitors
2 | 293 | Medium | Consistent | Direct | Imprecise | Small; Favored Met + DPP-4 Inhibitor | Low
Met + TZD vs. Met + Meg
1 | 561 | Medium | NA | Direct | Imprecise | Unable to determine | Low
Met + TZD vs. Met + GLP-1 Agonists
1 | 90 | Low | NA | Direct | Precise | Small; Favored Met + GLP-I Agonist | Low
Met + SU vs. Met + DPP-4 Inhibitors
1 | 1172 | Low | NA | Direct | Precise | Small; Favored Met + DPP-4 Inhibitor | Low
Met + SU vs. Met + Meg
2 | 494 | Low | Inconsistent | Direct | Imprecise | Unable to determine | Low
Met + SU vs. Met + GLP-1 Agonists
2 | 1215 | Medium | Consistent | Direct | Imprecise | Small; Favored Met + GLP-I Agonist | Low
Met + SU vs. Met + Premixed Insulin
2 | 819 | Low | Consistent | Direct | Precise | No effect; Neither drug combination favored | Low
Met + SU vs. TZD + SU
4 | 2341 | Low | Consistent | Direct | Imprecise | Small; Favored Met + SU | Moderate
Met + DPP-4 Inhibitors vs. Met + GLP-1 Agonists
1 | 661 | Medium | NA | Direct | Precise | Small; Favored Met + GLP-1 Agonist | Low
Met + GLP-1 Agonists vs. Met + Basal Insulin
1 | 69 | High | NA | Direct | Imprecise | Small; Favored Met + GLP-1 Agonist | Low
Met + Basal Insulin vs. Met + Premixed Insulin
3 | 530 | Medium | Consistent | Direct | Imprecise | No effect; Neither drug combination favored | Low

Outcome: Low density lipoprotein
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^***^ | Precision | Magnitude and direction of effect
Met vs. Rosi
7 | 511 | Low | Consistent | Direct | Imprecise | Large; Favored Met | Moderate
Met vs. Pio
6 | 1526 | Low | Consistent | Direct | Precise | Large; Favored Met | High
Met vs. SU
9 | 1774 | Medium | Consistent | Direct | Precise | Large; Favored Met | High
Met vs. DPP-4 Inhibitors
3 | 663 | Medium | Consistent | Direct | Imprecise | Small; Favored Met | Moderate
Met vs. Meg
1 | 112 | High | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
Met vs. Met + Rosi
7 | 2445 | Low | Consistent | Direct | Precise | Large; Favored Met | High
Met vs. Met + Pio
2 | 423 | Medium | Inconsistent | Direct | Imprecise | Unable to determine, unable to determine | Low
Met vs. Met + SU
7 | 1845 | Medium | Inconsistent | Direct | Imprecise | No effect; Neither favored | Low
Met vs. Met + DPP-4 Inhibitors
4 | 1943 | Medium | Inconsistent | Direct | Imprecise | No effect; Neither favored | Low
Met vs. Met + Meg
1 | 467 | High | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
TZD vs. TZD
2 | 846 | High | Consistent | Direct | Imprecise | Small; Favored Pio | Low
Rosi vs. SU
2 | 716 | Medium | Consistent | Direct | Imprecise | Large; Favored SU | Low
Pio vs. SU
3 | 465 | High | Consistent | Direct | Precise | Small; Favored SU | Low
TZD vs. DPP-4 Inhibitors
0 | | NA | NA | NA | NA | NA | Insufficient
Rosi vs. Meg
1 | 54 | High | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
Pio vs. Meg
1 | 56 | High | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
SU vs. DPP-4 Inhibitors
1 | 618 | Low | NA | Direct | Imprecise | No effect; Neither favored | Low
SU vs. Meg
2 | 668 | Medium | Consistent | Direct | Imprecise | No effect; Neither favored | Low
SU vs. GLP-1 Agonists
1 | 400 | High | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
DPP-4 Inhibitors vs. Meg
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Rosi vs. Met + SU
4 | 1708 | Low | Consistent | Direct | Imprecise | Large; Favored Met + SU | Moderate
Met + Pio vs. Met + SU
1 | 205 | Low | NA | Direct | Imprecise | Small; Favored Met + SU | Low
Met + Rosi vs. Met + DPP-4 Inhibitors
2 | 293 | Medium | Consistent | Direct | Imprecise | Unable to determine, Favored Met + DPP-4 Inhibitor | Low
Met + Rosi vs. Met + Meg
1 | 561 | | NA | Direct | Precise | Large; Favored Met + Meg | Low
Met + Rosi vs. Met + GLP-1 Agonists
1 | 90 | Medium | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
Met + Pio vs. Pio + SU
1 | 170 | Medium | NA | Direct | Imprecise | No effect; Neither favored | Low
Met + SU vs. Met + Meg
3 | 661 | Low | Inconsistent | Direct | Imprecise | Unable to determine, unable to determine | Low
Met + SU vs. Rosi + SU
2 | 696 | Medium | Inconsistent | Direct | Imprecise | Unable to determine, unable to determine | Low
Met + SU vs. Pio + SU
2 | 717 | Medium | Consistent | Direct | Imprecise | Small; Favored Met + SU | Low
Met + DPP-4 Inhibitors vs. Met + GLP-1 Agonists
1 | 661 | Low | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
Met + DPP-4 Inhibitors vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Meg vs. Met + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Meg vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + GLP-1 Agonists vs. Met + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + GLP-1 Agonists vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Basal Insulin vs. Met + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Basal Insulin vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Premixed Insulin vs. Met + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Premixed Insulin vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient

Outcome: High density lipoprotein
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^****^ | Precision | Magnitude and direction of effect
Met vs. Rosi
6 | 393 | Medium | Consistent | Direct | Precise | No effect; Neither favored | Moderate
Met vs. Pio
8 | 506 | Medium | Consistent | Direct | Precise | Small; Favored Pio | High
Met vs. SU
12 | 1953 | Medium | Consistent | Direct | Precise | No effect; Neither favored | High
Met vs. DPP-4 Inhibitors
3 | 2100 | Medium | Inconsistent | Direct | Imprecise | No effect; Neither favored | Low
Met vs. Meg
1 | 112 | High | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
Met vs. Met + Rosi
7 | 2689 | Low | Consistent | Direct | Precise | Small; Favored Rosi | High
Met vs. Met + Pio
2 | 470 | Medium | Consistent | Direct | Imprecise | Large; Favored Met + Pio | Low
Met vs. Met + SU
7 | 1841 | Medium | Inconsistent | Direct | Imprecise | No effect; Neither favored | Low
Met vs. Met + DPP-4 Inhibitors
4 | 2271 | Medium | Inconsistent | Direct | Precise | No effect; Neither favored | Moderate
Met vs. Met + Meg
1 | 467 | Low | NA | Direct | Imprecise | No effect; Neither favored | Low
TZD vs. TZD
3 | 886 | High | Consistent | Direct | Precise | Small; Favored Pio | Moderate
Rosi vs. SU
2 | 790 | Medium | Consistent | Direct | Imprecise | Large; Favored Rosi | Low
Pio vs. SU
5 | 616 | Medium | Consistent | Direct | Imprecise | Small; Favored Pio | Moderate
TZD vs. DPP-4 Inhibitors
0 | | NA | NA | NA | NA | NA | Insufficient
Rosi vs. Meg
1 | 74 | High | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
Pio vs. Meg
2 | 94 | High | Consistent | Direct | Imprecise | Small; Favored Pio | Low
SU vs. DPP-4 Inhibitors
1 | 618 | Low | NA | Direct | Imprecise | No effect; Neither favored | Low
SU vs. Meg
6 | 1108 | Low | Consistent | Direct | Precise | No effect; Neither favored | High
DPP-4 Inhibitors vs. Meg
0 | | NA | NA | NA | NA | NA | Insufficient
DPP-4 Inhibitors vs. GLP-1 Agonists
1 | 400 | High | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
Met + Rosi vs. Met + SU
4 | 1738 | Low | Consistent | Direct | Imprecise | Small; Favored Met + Rosi | Moderate
Met + Pio vs. Met + SU
2 | 388 | Medium | Consistent | Direct | Precise | Large; Favored Met + Pio | Low
Met + Rosi vs. Met + DPP-4 Inhibitors
2 | 181 | Medium | Inconsistent | Direct | Imprecise | Unable to determine, unable to determine | Low
Met + Rosi vs. Met + Meg
1 | 561 | ? | NA | Direct | Precise | Small; Favored Met + Rosi | Low
Met + Rosi vs. Met + GLP-1 Agonists
1 | 90 | Medium | NA | Direct | Imprecise | Small; Favored Met + Rosi | Low
Met + Pio vs. Pio + SU
1 | 170 | Medium | NA | Direct | Imprecise | Small; Favored Met + Pio | Low
Met + TZD vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + SU vs. Met + Meg
2 | 661 | Low | Consistent | Direct | imprecise | No effect; Neither favored | Low
Met + SU vs. Met + Premixed Insulin
1 | 230 | Low | NA | Direct | imprecise | No effect; Neither favored | Low
Met + SU vs. Rosi + SU
2 | 980 | Medium | Inconsistent | Direct | imprecise | Unable to determine, unable to determine | Low
Met + SU vs. Pio + SU
3 | 864 | Medium | Consistent | Direct | imprecise | Small; Favored Pio + SU | Low
Met + SU vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + DPP-4 Inhibitors vs. Met + liraglutide
1 | 661 | Medium | NA | Direct | Precise | No effect; Neither favored | Low
Met + DPP-4 Inhibitors vs. Met + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + DPP-4 Inhibitors vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Meg vs. Met + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Meg vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + GLP-1 Agonists vs. Met + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + GLP-1 Agonists vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Basal Insulin vs. Met + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Basal Insulin vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Premixed Insulin vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient

Outcome: Triglycerides
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness***** | Precision | Magnitude and direction of effect
Met vs. Rosi
7 | 459 | Medium | Inconsistent | Direct | imprecise | Large; Favored Met | Moderate
Met vs. Pio
8 | 506 | Medium | Consistent | Direct | Precise | Large; Favored Pio | High
Met vs. SU
12 | 1531 | Medium | Consistent | Direct | Imprecise | Small; Favored Met | Moderate
Met vs. DPP-4 Inhibitors
3 | 2100 | Medium | Consistent | Direct | Imprecise | No effect; Neither favored | Low
Met vs. Meg
1 | 112 | High | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
Met vs. Met + Rosi
7 | 2470 | Low | Consistent | Direct | Precise | Large; Favored Met | High
Met vs. Met + Pio
2 | 479 | Medium | Inconsistent | Direct | Imprecise | Unable to determine, unable to determine | Low
Met vs. Met + SU
8 | 1584 | Medium | Inconsistent | Direct | Imprecise | No effect; Neither favored | Low
Met vs. Met + DPP-4 Inhibitors
4 | 2594 | Medium | Consistent | Direct | Imprecise | Large; Favored Met + DPP-4 Inhibitor | Low
Met vs. Met + Meg
1 | 467 | Low | NA | Direct | Imprecise | Small; Favored Met + Meg | Low
TZD vs. TZD
3 | 886 | High | Consistent | Direct | Imprecise | No effect; Neither favored | Low
Rosi vs. SU
2 | 716 | Medium | Inconsistent | Direct | Imprecise | Unable to determine, unable to determine | Low
Pio vs. SU
6 | 616 | High | Consistent | Direct | Imprecise | Large; Favored Pio | Low
TZD vs. DPP-4 Inhibitors
0 | | NA | NA | NA | NA | NA | Insufficient
Rosi vs. Meg
1 | 74 | High | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
Pio vs. Meg
2 | 94 | High | Consistent | Direct | Imprecise | Large; Favored Pio | Low
SU vs. DPP-4 Inhibitors
1 | 618 | Low | NA | Direct | Imprecise | No effect; Neither favored | Low
SU vs. Meg
6 | 1113 | Medium | Consistent | Direct | Precise | No effect; Neither favored | Moderate
SU vs. GLP-1 Agonists
1 | 400 | High | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
DPP-4 Inhibitors vs. Meg
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Rosi vs. Met + SU
4 | 1735 | Low | Consistent | Direct | Imprecise | No effect; Neither favored | Moderate
Met + Pio vs. Met + SU
2 | 388 | Medium | Consistent | Direct | Precise | Large; Favored Met + Pio | Moderate
Met + Rosi vs. Met + DPP-4 Inhibitors
2 | 673 | Medium | Consistent | Direct | Imprecise | Unable to determine, Favored Met + DPP-4 Inhibitor | Low
Met + Rosi vs. Met + Meg
1 | 181 | | NA | Direct | Imprecise | No effect; Neither favored | Low
Met + Rosi vs. Met + GLP-1 Agonists
1 | 90 | Medium | NA | Direct | Imprecise | Large; Favored Met + GLP-1 Agonist | Low
Met + Pio vs. Pio + SU
1 | 170 | Medium | NA | Direct | Imprecise | Small; Favored Pio + SU | Low
Met + TZD vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + SU vs. Met + Meg
2 | 661 | Low | Inconsistent | Direct | Imprecise | Unable to determine, unable to determine | Insufficient
Met + SU vs. Met + Premixed Insulin
1 | 230 | Low | NA | Direct | Unable to determine | No effect; Neither favored | Low
Met + SU vs. Rosi + SU
2 | 3390 | Medium | Inconsistent | Direct | Imprecise | Unable to determine, unable to determine | Insufficient
Met + SU vs. Pio + SU
4 | 942 | Medium | Inconsistent | Direct | Imprecise | Unable to determine, Favored Pio + SU | Low
Met + SU vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + DPP-4 Inhibitors vs. Met + GLP-1 Agonists
1 | 661 | Low | NA | Direct | Imprecise | Unable to determine, unable to determine | Low
Met + DPP-4 Inhibitors vs. Met + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + DPP-4 Inhibitors vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Meg vs. Met + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Meg vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + GLP-1 Agonists vs. Met + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + GLP-1 Agonists vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Basal Insulin vs. Met + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Basal Insulin vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient
Met + Premixed Insulin vs. TZD + Another agent
0 | | NA | NA | NA | NA | NA | Insufficient

DPP-4 = dipeptidyl peptidase-4; GLP-1 = glucagon-like peptide-1; Meg = meglitinides; Met = metformin; NA = not applicable; Nateg = nateglinide; Pio = pioglitazone; RCT = randomized controlled trial; Repag = repaglinide; Rosi = rosiglitazone; Sita = sitagliptin; SU = sulfonylurea; TZD = thiazolidinedione.

All other comparisons were graded as insufficient since there were no studies of those comparisons. The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable. N=total N for all studies in each comparison. This is not necessarily the N for analysis because the N for analysis often was not stated for each outcome.

* Directness was graded based on how well the evidence for a particular comparison related to the outcome of hemoglobin A1c.

** Directness was graded based on how well the evidence for a particular comparison related to the outcome of weight.

*** Directness was graded based on how well the evidence for a particular comparison related to the outcome of low density lipoprotein

**** Directness was graded based on how well the evidence for a particular comparison related to the outcome of high density lipoprotein.

***** Directness was graded based on how well the evidence for a particular comparison related to the outcome of triglycerides.

Table 2 Study design characteristics of studies reporting on the comparative effectiveness of diabetes medications on intermediate outcomes (KQ1)

Author, year Country | Enrollment period Followup duration | Run-in period | Planned interval of followup | Pharmaceutical support | Number screened/enrolled Source population | Exclusion criteria
Seino, 2010^121^ Japan | Neither year reported 24 weeks | Yes | < 6 months | Yes | NR/464 NR | Age <20 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), retinopathy, HbA1c <7% or >10%, BMI >35 kg/m^2^, treated with insulin within 12 weeks of the start of the study, receiving or expecting to receive systemic corticosteroids, known hypoglycemia unawareness or recurrent major hypoglycemia unawareness or recurrent major hypoglycemia, no Type 2 DM, treated with diet therapy for less than 8 weeks, on more than 1/2 of the recommended maximum dose of an SU (e.g., on more than 2.5 mg of glibenclamide)
Derosa, 2010^44^ Italy | Neither year reported 12 months | No run-in period | < 6 months | No | 128/128 patients identified from case notes and clinical registers | Age <18 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), neuropathy, retinopathy, HbA1c < 8%, BMI <25 kg/m^2^ or ≥30 kg/m^2^, pregnant, nursing, not using adequate contraception, history of ketoacidosis, severe anemia, not intolerant to metformin at maximum dosage (3,000 mg/day), not on metformin, diabetic neuropathy
DeFronzo, 2010^287^ U.S. | Start Year 2006 End Year 2008 20 weeks | No run-in period | < 6 months | Yes | NR/137 NR | Age <18 or >75 years, HbA1c <6.8% or >10%, BMI <25 kg/m^2^ or >40 kg/m^2^, not on stable dose of metformin for at least 6 weeks, body weight stable for past 6 months, islet cell auto-antibodies, treatment with any other ODM (other than metformin)
Aschner, 2010^77^ Multicontinent | Neither year reported 24 weeks | Run-in period but number of participants excluded was NR | NR | Yes | 2068/1050 NR | Age <18 or >78 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <6.5% or >9%, treatment naive, no Type 2 DM, FPG <120 or >250 mg/dL, triglycerides >600 mg/dL, CK > 2x upper limit normal
Seck, 2010^134^ NR | Neither year reported 2 years | Run-in period but number of participants excluded was NR | < 6 months | Yes | 2141/1172 NR | Age <17 or >78 years
Pratley, 2010^143^ Multicontinent Europe, U.S., and Canada | Start year 2008 End year 2009 26 months | No run-in period | >= 6months | Yes | 1302/665 “Office-based”-possibly out patient | Age <18 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c >7.5% or <10%, BMI >45 kg/m^2^, no Type 2 DM, cancer, contraindication to trial drugs, recurrent hypoglycemic or hypoglycemia unawareness, not on metformin for at least 3 months, on any non-metformin anti-hypoglycemic in past 3 months
Home, 2009^16^ Multinational Europe | Start year 2001 End year 2003 7.5 Years | Run-in period but number of participants excluded was NR | >= 6 months | Yes | 7428/4458 Outpatient primary care | Age <40 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), contraindication or history of intolerance to metformin, history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c < 7% or >9%, BMI <25 kg/m^2^, pregnant, nursing, not using adequate contraception
Raskin, 2009^131^ NR | Neither year reported 26 Weeks | No run-in period | < 6 months | Yes | 1093/383 Outpatient primary care | Age <18 years, pregnant, nursing, currently not under monotherapy at least 2 months or dual therapy, FBG >260 mg/dL, any disease or abnormality as judged by the investigator, treatment with the investigational drug for 4 weeks, allergy to study drugs or related compounds, history of hypoglycemia unawareness or recurrent severe hyperglycemia
Derosa, 2009^46^ Italy | Neither year reported 15 Months | Fewer than 10% of participants were excluded during run-in | < 6 months | NR | 271/252 Outpatient primary care, computerized clinic registry | Age <18 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), neuropathy, retinopathy, HbA1c <6.5%, BMI <25 kg/m^2^ or >30 kg/m^2^, pregnant, nursing, not using adequate contraception, no Type 2 DM, history of ketoacidosis, severe anemia
Van der Meer, 2009^141^ Netherlands | Neither year reported 24 Weeks | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | 173/80 NR | Age <45 or >65 years, female, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <6.5% or >8.5%, BMI <25 kg/m^2^ or >32 kg/m^2^, SBP <150 mmHg, DBP <85 mmHg, prior TZD or insulin use
Kaku, 2009^84^ Japan | Start year 2005 40 Weeks | Yes | < 6 months | Yes | NR/236 NR | Age ≤ 20 and ≥65 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g., failed initial treatment), HbA1c <6.5% or >10%, other pre-existing conditions that potentially require hospitalization such as cancer, severe lung, gastrointestinal, pancreatic and hematological disorders, history of lactic acidosis, ketoacidosis, diabetic coma, or pre-coma within the preceding 26 weeks, if on any medications that might affect glycemic control, drug or alcohol dependency
Gupta, 2009^47^ NR | Neither year reported 16 Weeks | No run-in period | < 6 months | Yes | 247/51 NR | Age <35 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), pregnant, not using adequate contraception, FPG >200 mg/dL, individuals using orlistat, sibutramine, ephedrine, steroids, significant lung diseases, significant neurologic diseases, baseline BP>140/90 mmHg, prior use of TZD, beta blockers, smokers, alcohol abuse and using drugs, patients using metal objects precluding required scans
Williams-Herman, 2009^76^ NR | Neither year reported 54 Weeks | Run-in period but number of participants excluded was NR | NR | Yes | 3544/1091 NR | Age <18 or >78 years, HbA1c <7.5% or >11% after screening diet/exercise run-in (which included a wash-out period), lack of adequate compliance (>=75% by tablet count) during 2-week single-blind placebo run-in period, no Type 2 DM
Derosa, 2009^135^ Italy | Neither year reported 12 Months | Fewer than 10% of participants were excluded during run-in | >= 6 months | NR | NR/248 Inpatient/hospital | Age >18 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), neuropathy, retinopathy, HbA1c < 7%, BMI <25 kg/m^2^ OR >28 kg/m^2^, pregnant, nursing, not using adequate contraception, no Type 2 DM, history of ketoacidosis, severe anemia, no hypertension
Nauck, 2009^92^ Multicontinent | Neither year reported 26 Weeks | Run-in period but number of participants excluded was NR | >= 6 months | Yes | 1662/1087 NR | Age <18 or >80 years, HbA1c <7% or >11% if on monotherapy; 10% if on combination therapy (both greater than 3 months), BMI >40 kg/m^2^, used insulin in last 3 months
Vijay, 2009^99^ India | Neither year reported 4 months | No run-in period | < 6 months | NR | NR/40 Outpatient subspecialty care setting | Age <30 or >70 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <8%, BMI >36 kg/m^2^, unstable weight for at least 3 months before study, pre-existing chronic diseases, any amount of smoking during previous 6 months, previous use of insulin or any TZDs, on medications such as glucocorticoids or other drugs that affect glucose metabolism, lipid lowering drugs or psychoactive substances and alcohol
Kiyici, 2009^45^ Turkey | Neither year reported 52 weeks | No run-in period | < 6 months | No | NR/50 Outpatient subspecialty care setting | Age <30 or >65 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c >8%, BMI >40 kg/m^2^, gastrointestinal disease, rheumatological, or neoplastic, infectious diseases, history of using anti-diabetic medications, any endocrine disease except diabetes or hyperlipidemia, smoking, microvascular complications of diabetes, history of substance abuse
Jonker, 2009^160^ Netherlands | Neither year reported 24 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | 173/78 Outpatient Primary care setting | Age <45 or >65 years, female, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), neuropathy, retinopathy, HbA1c <6.5% or >8.5%, BMI <25 kg/m^2^ or >32 kg/m^2^, no Type 2 DM, prior use of TZD/insulin, BP >150/85 mm Hg
Perez, 2009^56^ U.S., multinational Europe | Neither year reported 24 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | 1436/600 NR | Age <18 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g., “failed initial treatment”), contraindication or history of intolerance to metformin, HbA1c <7.5% or >10%, BMI >45 kg/m^2^, pregnant, nursing, triglycerides >500 mg/dL, discontinued metformin and TZD therapy due to lack of efficacy
Rigby, 2009^130^ U.S., multicontinent | Start year 2007 End year 2008 16 months | No run-in period | < 6 months | Yes | 356/169 NR | Age <18 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <7% (6.5% if on metformin combination therapy) or >10% (9.5% if on metformin combination therapy), BMI > 40 kg/m^2^, LDL <50 mg/dL or triglycerides ≥500 mg/dL, weight loss program with ongoing weight loss or starting an intensive exercise program within 4 weeks of screening, need for oral corticosteroids, bile acid sequestrants, or any antidiabetes medications other than metformin, >2months insulin, not on metformin for ≥3 months (1500–2550 mg/day), Type 1 DM and/or ketoacidosis, dysphagia/swallowing disorders, intestinal motility disorders, pancreatitis, HIV/AIDS, drug/alcohol abuse within 2 years, any serious disorder including pulmonary, hepatic, gastrointestinal, uncontrolled endocrine/metabolic, hematologic/oncologic (within 5 years), neurologic, or psychiatric diseases, current treatment with TZD/combo with metformin/colesevelam/fixed-dose combination product including metformin, hospitalization within 14 days of screening
Tolman, 2009^150^ U.S. | Start year 2000 End Year 2005 3 years | No run-in period | < 6 months | Yes | NR/2120 NR | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <7%, BMI <20kg/m^2^ or >48 kg/m^2^, not taking metformin and/or SU, history of ketoacidosis, history of TZD use other than troglitazone before 4/00
Jadzinsky, 2009^78^ Multicontinent | Start year 2006 End year 2008 24 weeks | Fewer than 10% participants excluded during run-in period | < 6 months | Yes | 2936/1394 Outpatient Primary care setting | Age <18 or >77 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g., “failed initial treatment”), HbA1c <8% or >12%, BMI >40 kg/m^2^, prior treatment, diabetic ketoacidosis or nonketotic hyperosmolar coma, CV events 6 months prior, LVEF <40%, psychiatric history, alcohol or drug abuse, abnormal metabolic or hematologic test
DeFronzo, 2009^95^ NR | Neither year reported 24 weeks | Yes | < 6 months | Yes | 1462/743 NR | Age <18 or >77 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g., “failed initial treatment”), contraindication or history of intolerance to metformin, neuropathy, retinopathy, HbA1c < 7% or >10%, BMI >40 kg/m^2^, pregnant, nursing, alcohol or drug abuse, NYHA III and IV, LVEF <40%
Bunck, 2009^144^ Sweden, Finland, and Netherlands | Start year 2004 End year 2007 56 weeks | No run-in period | < 6 months | Yes | 150/69 NR | Age <30 or >75 years, HbA1c <6.5% or >9.5%, BMI <25 kg/m^2^ or >40 kg/m^2^, metformin treatment not at a stable dose for at least 2 months, no other blood glucose lowering medications allowed in 3 months prior to study, no changes in other medications known to affect beta cell function (ACEI, beta blockers)
Garber, 2009^122^ U.S., Mexico | Start year 2006 End year 2007 52 weeks | Fewer than 10 % participants excluded during run-in period | < 6 months | Yes | NR/746 NR | Age <18 or >80 years, HbA1c <7% or >11% if prior treatment was diet; >10% if prior treatment was drug, BMI >45 kg/m^2^, either not treated with diet and exercise or up to half the highest dose of oral antidiabetic drug monotherapy for at least 2 months prior to trial, insulin treatment during the previous 3 months (except short-term treatment for intercurrent illness), treatment with systemic corticosteroids, hypoglycemia unawareness or recurrent severe hypoglycemia, impaired liver function (aspartate aminotransferase or alanine aminotransferase concentrations 5 times upper normal range)
Kato, 2009^57^ Multinational Europe | Neither year reported 12 weeks | No run-in period | NR | NR | NR/50 NR | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), neuropathy, retinopathy, no Type 2 DM, no metabolic syndrome, not on continuous diet/exercise therapy, no anemia, no history of heart failure
Erdem, 2008^39^ Turkey | Neither year reported 12 weeks | No run-in period | < 6 months | No | 53/44 outpatient department of internal medicine clinic | Age <30 or >70 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), BMI >35 kg/m^2^, other chronic disease as detected by history and physical
Scott, 2008^85^ Multi-continent | Neither year reported 18 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | 486/273 NR | Age <18 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), HbA1c <7% or >11%, not on 10 weeks on stable dose of metformin, insulin use, Type 1 DM, glucose >270 mg/dL
Seufert, 2008^142^ Multicontinent | Neither year reported 104 weeks | No run-in period | NR | Yes | NR/1269 NR | Age <35 or >75 years, history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g., failed initial treatment), HbA1c <7.5% or >11%, pregnant, nursing, fasting C-peptide >1.5 ng/mL, ketoacidosis, symptomatic heart failure, acute malabsorption, chronic pancreatitis, familial polyposis coli, malignant disease in the previous 10 years
Hamann, 2008^123^ Multinational Europe, Mexico | Neither year reported 52 weeks | Yes | < 6 months | NR | 818/596 NR | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <7% or >10%, BMI <25 kg/m^2^, used any oral antidiabetic drug other than metformin in the prior 12 weeks, or insulin at any time other than during pregnancy or for emergency treatment, history of metabolic acidosis, edema requiring pharmacological treatment (either ongoing or within the prior 12 months), anemia (hemoglobin <11.0 g/dl for men and <10.0 g/dl for women), C-peptide <0.5nmol/L, SBP >170mmHg, DBP >100mmHg
Schwarz, 2008^152^ U.S. | Neither year reported 104 weeks | Run-in period but number of participants excluded was NR | < 6 months | NR | 75/69 NR | Age <18 or >77 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), contraindication or history of intolerance to metformin, HbA1c <7.0% or >11.0%, BMI <22 kg/m^2^ or >45 kg/m^2^, FBG >270 mg/dL, history of lactic acidosis, congestive cardiac failure requiring pharmacologic treatment, Type 1 DM or secondary forms of DM
Comaschi, 2008^158^ Italy | Neither year reported 6 Months | Run-in period but number of participants excluded was NR | < 6 months | Yes | 398/250 NR | Age <35 years, HbA1c <7.5% or >11%, fasting C- peptide <0.33 nmol/L, had not received treatment with a stable dose of either metformin or an SU as a monotherapy for at least 3 months before study entry, on other oral hypoglycemic agents, insulin, benzoic acid, long treatments with beta-blockers, or corticosteroids
Iliadis, 2007^48^ Greece | Neither year reported 18 weeks | Run-in period but number of participants excluded was NR | NR | NR | NR/48 Outpatient subspecialty care setting | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), diagnosis of Type 2 DM >3 years, use of any diabetes medication, no Type 2 DM, any heart failure
Robbins, 2007^145^ U.S., Multinational Europe, multi-continent, India, Australia | Neither year reported 24 weeks | Run-in period but number of participants excluded was NR | < 6 months | NR | 433/317 NR | Age <35 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), HbA1c <6.5% or >11%, pregnant, nursing, not using adequate contraception, patients who were receiving continuous SC insulin injections or a total daily insulin of >2.0 U/kg or who had a change in type or dose of lipid-altering medications or TZD use up to 3 months before the study, fasting triglyceride level >4.5 mmol/L, serum creatinine >134 micromol/L (men) or >109 micromol/L (women)
Chien, 2007^59^ Taiwan | Neither year reported 16 weeks | No run-in period | < 6 months | Yes | 166/100 5 medical centers. Does not specify inpatient or outpatient | Age <30 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), contraindication or history of intolerance to metformin, retinopathy, HbA1c > 12% and FPG>250 mg/dL at screening visit, HbA1c < 7% and FPG<140 mg/dL at screening visit, BMI <18.5 kg/m^2^ or >35 kg/m2, current significant GI disorder, hyperglycemic hyperosmolar non-ketotic coma, hypersensitivity to glyburide or metformin, current infection, treatment with insulin in last 6 months, surgery in past 4 weeks, history of cancer in 5 yr, on concurrent drugs affect sugar metabolism, FPG < 140 mg/dl at second visit, not on a stable dose of SU at baseline or dose of metformin>1000mg/day or SU dose too low (glyburide or gliclazide<10 mg/day, glimepiride<4mg/d, gliclazide<160mg/d)
Derosa, 2007^288^ Italy | Neither year reported 12 months | Fewer than 10% of participants were excluded during run-in | < 6 months | No | NR/248 NR | Age <18 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), neuropathy, retinopathy, HbA1c <7.0%, BMI <25 kg/m^2^ or >28 kg/m^2^, pregnant, nursing, not using adequate contraception, history of ketoacidosis, severe anemia, non-Caucasians, SBP <130 mm Hg, DBP <85 mm Hg
Turkmen Kemal, 2007^58^ Turkey | Start year 2005 6 months | No run-in period | < 6 months | NR | 46/46 Outpatient subspecialty care setting | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), patient on diuretics, uncontrolled hypertension
Comaschi, 2007^129^ Italy | Neither year reported 6 months | Run-in period but number of participants excluded was NR | < 6 months | Yes | 398/250 NR | Age <35 years, HbA1c < 7.5% or >11%, had not received SU or metformin as a monotherapy at a stable dose for at least 3 months, fasting C-peptide <0.33 nmol/L
Home, 2007^124^ Multinational Europe, Australia and New Zealand | Start year 2000 End year 2002 18 months | Run-in period but number of participants excluded was NR | >= 6 months | NR | 7428/4458 NR | Age <40 or >75 years, HbA1c <7% or >9%, BMI <25 kg/m^2^
Teramoto, 2007^41^ Japan | Neither year reported 24 weeks | Yes | NR | No | 126/92 NR | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), any medication affecting glucose metabolism, history of diabetic ketoacidosis, history of diabetic coma or pre-coma, Cushing s syndrome, history of allergy to thiazolizinediones, tumor therapy, receiving insulin for severe infection
Goldstein, 2007^75^ Multicontinent | Neither year reported 24 weeks | Run-in period but number of participants excluded was NR | NR | Yes | 3544/1091 NR | Age <18 or >78 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), patient with less than 75% compliance during placebo run in period, patient with HbA1c <7.5% or >11 % after diet/exercise run in/wash-out period, patients with fasting glucose >280 mg/dl after run-in period, no Type 2 DM, Type 1 DM
Davies, 2007^147^ United Kingdom | Neither year reported 4 months | Run-in period but number of participants excluded was NR | < 6 months | NR | NR/82 NR | Age <30 or >80 years, history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), contraindication or history of intolerance to metformin, HbA1c >7.0%, BMI >43 kg/m^2^, not using adequate contraception, history of previous insulin use for >2 weeks, duration of Type 2 DM <12 months, c-peptide levels <0.33, severe concurrent disease, serum Cr >150umol/l
Lund, 2007^197^ Denmark | Start year 2001 End year 2002 8 months | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | 127/96 Outpatient subspecialty care setting | Age <40 years for onset of diabetes diagnosis, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c >9.5% with ongoing ODMs prior to study start; 10.5 on 2 visits with >1m interval, HbA1c <6.5% after run- in period, BMI >27 kg/m^2^, pregnant, insulin treated Type 2 DM, secondary DM, Factor II, VII, X <0.7, ongoing co-existing illness with life shortening prognosis, mental retardation or reduced intellectual behavior, history of drug abuse, weight loss of >5kg in past 6 months prior to study start, fasting C-peptide <300 of non fasting glucagon stimulated C-peptide <600, ketonuria, ketoacidosis
Nauck, 2007^133^ U.S., multinational Europe, multi-continent | Neither year reported 52 weeks | Yes | < 6 months | Yes | 2141/1172 NR | Age <18 or >78 years, any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), FPG >15 mmol/L, insulin use within 8 weeks of screening, history of Type 1 DM, other treatments for hypoglycemia
Kim, 2007^42^ South Korea | Neither year reported 12 weeks | Fewer than 10% of participants were excluded during run-in | < 6 months | No | NR/120 Outpatient primary care, Outpatient subspecialty care setting | Age <30 or >70 years, any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), duration of diabetes >5 years, not on a stable medication with a SU and/or alpha glucosidase inhibitor for at least 3 months, episodes of ketonuria or ketoacidosis, current malignancy, tuberculosis, rheumatic disease, thyroid disease, corticosteroid treatment, previous TZD or metformin treatment
Raskin, 2007^146^ US | Neither year reported 28 weeks | Run-in period but number of participants excluded was NR | < 6 months | NR | N/NR NR | Age <18 or >75 years, HbA1c ≤8.0%, BMI >40 kg/m^2^ or weight >125 kg (275lbs), pregnant, nursing, not using adequate contraception, if not on metformin ≥1,000mg/day as a single agent or in ODM combination therapy for at least 3 months before the trial, history of insulin use
Hanefeld, 2007^100^ Multinational Europe | Neither year reported 52 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | NR/598 NR | Age <40 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), BMI <22 kg/m^2^ or >38 kg/m^2^, pregnant, patient on insulin therapy, patient with diabetic complications requiring treatment, hematologic impairment, FPG < 7mmol/l or >15 mmol/l, C peptide <0.27 nmol/l
Scott, 2007^111^ U.S. | Neither year reported 12 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | 2186/743 NR | Age <21 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), Type 1 DM, gall bladder disease, elevated CK
Kahn, 2006^38^ Multicontinent | Start year 2000 End year 2006 6 years | No run-in period | NR | Yes | 6676/4360 NR | Age <30 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), uncontrolled hypertension, FPG <126 or >180 mg/dL, history of lactic acidosis
Charbonnel, 2006^94^ Multicontinent | Neither year reported 24 weeks | Run-in period but number of participants excluded was NR | NR | Yes | 1464/701 NR | Age <18 or >78 years, any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), HbA1c <7% or >10%, Type 1 DM, insulin use within 8 weeks of screening, FPG >14.4mmol/l
Rosenstock, 2006^49^ Multicontinent | Start year 2003 to 2004 32 weeks | Yes | < 6 months | Yes | 1252/468 multicenter | Age <18 or >70 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <7% or >11%, FPG >15 mmol/l, hematological disease, uncontrolled hypertension while on antihypertensive treatment, intermittent or chronic use of oral or intravenous corticosteroids, investigators discretion, use of investigational agent within 30 days of the study (or five half lives of the investigational drug if longer than 30 days), previous history of severe edema or medically serious fluid related event associated with TZD, acute or chronic metabolic acidosis, history of diabetic ketoacidosis
Jain, 2006^101^ U.S., Puerto Rico | Neither year reported 56 weeks | Run-in period but number of participants excluded was NR | < 6 months | NR | NR/502 NR | Age <18 or >80 years, any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g., failed initial treatment), HbA1c <7.5% or >11.5%, pregnant, nursing, duration of diabetes > than 2 years, intolerance to rosiglitazone, pioglitazone, or troglitazone, drug or alcohol abuse, previous treatment with meglitinide analog, alpha glucosidase inhibitor, metformin, insulin, SU for 3 months or more, use of hydrochlorothiazide, joint injections, niacin greater than 250 mg/day, oral anti-diabetic drugs, concurrent participation in another investigational study, serum creatinine level >1.5 mg/dl for men, 1.4 mg/dl for women, 1+ proteinuria, anemia (<10 g/dl women, <12 g/dl men), BMI ≤20 kg/m^2^ or >45 kg/m^2^; hypertension, chronic pulmonary disease, history of cancer not in remission for at least 5 years
Stewart, 2006^156^ Multinational Europe | Start year 2003 to 2004 32 weeks | Yes | < 6 months | Yes | 1397/526 NR | Age < 18 or > 70 years, history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c < 7% or >9%, drug naive patients with FPG <7 mmol/l or >9 mmol/l, patient on monotherapy with FPG <6.0 mmol/l or >8 mmol/l, prior history of exposure to TZDs within previous 6 months, use of insulin anytime in the past, uncontrolled hypertension
Bakris, 2006^125^ U.S., multi-continent, South America, Europe | Neither year reported 32 weeks | Yes | < 6 months | Yes | 560/514 NR | Age <40 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), BMI <22 kg/m^2^, use of any TZD in the 3 months prior to screening, use of insulin for ≥ 6 months at any time prior to screening, anemia, severe angina, SBP >159 mm Hg (can’t adjust the BP meds during the trial), DBP >99 mm Hg
Umpierrez, 2006^126^ U.S. | Neither year reported 28 Weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | 538/210 Outpatient primary care, Outpatient subspecialty care setting | Age <18 or >79 years, HbA1c <7.5% and >10%, BMI <24 kg/m^2^, diagnosis of Type 2 DM <6 months, no taking stable doses of metformin (1–2.5g/day) or extended-release metformin (0.5 –2.0g/day) as their only ODM for at least 2months prior to the study, C-peptide <0.27nmol/L, subjects treated with insulin, TZDs or SU within 3months prior to study enrollment, history of substance abuse, severe hypoglycemia, acute metabolic complications, clinically significant abnormal baseline laboratory values including hematology, blood chemistry or urinalysis
Nakamura, 2006^108^ Japan | Neither year reported 12 weeks | No run-in period | < 6 months | NR | NR/68 NR | HbA1c >6.5%, history of ketoacidosis, treatment other than by diet alone, fasting C-peptide level of less than 0.33 mmol/l, hematuria, non-diabetic renal disease, microalbuminura defined as a median urinary albumin excretion of 20 to 200 ug/min
Kvapil, 2006^138^ Multinational Europe | Neither year reported 16 weeks | No run-in period | < 6 months | NR | NR/341 NR | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), retinopathy, recurrent severe hypoglycemia, anemia, change in dose of meds known to interfere with glucose metabolism, inclusion criteria is not adequately controlled on metformin
Jibran, 2006^112^ Pakistan | Start year 2000 End year 2001 12 months | NA | < 6 months | NR | NR/100 Outpatient subspecialty care setting | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), poorly controlled on prior treatments (e.g., failed initial treatment), no Type 2 DM, on insulin
Derosa, 2006^157^ Italy | Neither year reported 12 months | No run-in period | < 6 months | NR | NR/99 Outpatient primary care, Outpatient subspecialty care setting | History of ketoacidosis, background retinopathy, nephropathy, neuropathy, impaired liver or kidney function, anemia, CVD or cerebrovascular conditions, pregnant, lactating, of child bearing potential while not taking adequate contraceptive
Garber, 2006^128^ U.S. | Not extracted 24 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <20 or >78 years, any liver disease, any kidney disease, history of CVD, HbA1c ≤7% or ≥12% no Type 2 DM, other
Derosa, 2005^151^ Italy | Neither year reported 12 months | No run-in period | < 6 months | NR | NR/99 case-report forms or computerized clinic registers | Age ≤18 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), poorly controlled on prior treatments (e.g., failed initial treatment), neuropathy, retinopathy, HbA1c <7.5%, BMI ≤25.3 kg/m^2^, pregnant, nursing, not using adequate contraception, if no Type 2 DM for minimum 6 months based on ADA criteria, if no metabolic syndrome based on NCEP ATP III, if no hypertension, triglycerides ≤150mg/dl, C-peptide ≤1.0ng/ml, history of ketoacidosis, anemia, receiving lipid-lowering meds, anticoagulation, glimepiride, or a TZD
Gerich, 2005^136^ U.S. | Neither year reported 2 Years | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | 908/428 NR | Age <18 or >77 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), neuropathy, retinopathy, HbA1c <7% or >11%, BMI < 22 kg/m^2^ and >45 kg/m^2^, not using adequate contraception, FPG ≥15 mmol/l, if Type 1 DM, symptomatic hypoglycemia with >10% weight loss in previous 8 weeks, history of lactic acidosis or CHF requiring meds, other medical conditions that could interfere with interpretation of results or pose sig risk to the subject, had to be drug naive
Derosa, 2005^127^ Italy | Neither year reported 12 months | No run-in period | < 6 months | NR | NR/99 case notes and/or clinic registers | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g., failed initial treatment), neuropathy, retinopathy, HbA1c < 7%, pregnant, nursing, not using adequate contraception, no type 2 DM by ADA criteria for at least 6 mo, fasting c-peptide <1.0ng/ml, no metabolic syndrome with at least 3 components (based on NCEP ATP III), ketoacidosis, anemia, cerebrovascular conditions within 6 months, consumption of glimepiride or TZDs or prior intolerance to these medications
Leiter, 2005^83^ Canada | Neither year reported 32 weeks | No run-in period | < 6 months | Yes | 720/613 Outpatient primary care | Age <20 or >80 years, HbA1c <9.5%, no Type 2 DM, FBG <7 and >14 mmol/l
Weissman, 2005^86^ U.S. | Not extracted 24 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <18 or >75 years, any liver disease, any kidney disease, history of CVD, HbA1c <6.5% or >8.5% for patients having received prior combination treatment, HbA1c <7% or >10% prior monotherapy or drug naive patients, no Type 2 DM, other
Bailey, 2005^87^ U.K., 14 European countries | Not extracted 24 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <18 or >70 years, history of CVD, no Type 2 DM, other
Betteridge, 2005^289^ U.K. | Not extracted 104 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <35 or >75 years, HbA1c <7.5% or >11%, no Type 2 DM
Yamanouchi, 2005^50^ Japan | Not extracted 12 months (planned duration) | Not extracted | Not extracted | NR | Not extracted | Any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, retinopathy, HbA1c <7.0%, no Type 2 DM, other
Goldberg, 2005^98^ U.S., Puerto Rico, Mexico, and Columbia | Not extracted 24 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <35 years, any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <7% or >11.5%, if naive to ODM therapy, HbA1c <7% or >9.5% if previously treated with ODM, no Type 2 DM, other
Pfutzner, 2005^105^ Germany | Not extracted 26 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <40 or >75 years, any liver disease, any kidney disease, history of CVD, HbA1c <6.6% or >9.9%, other
Derosa, 2005^159^ Italy | Not extracted 12 months (planned duration) | Not extracted | Not extracted | NR | Not extracted | Age <18 years, any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c <7.5%, no Type 2 DM, other
Langenfeld, 2005^290^ Germany | Not extracted 24 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <40 or >75 years, any liver disease, any kidney disease, history of CVD, HbA1c <6.6% or >9.9%, no Type 2 DM, other
Feinglos, 2005^91^ U.S. | Not extracted 16 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <30 or >81 years, any liver disease, any kidney disease, history of CVD, HbA1c <7.0% or >8.5%, no Type 2 DM, other
Smith, 2004^291^ U.S., Multinational Europe | Neither year reported 52 weeks | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | NR/598 NR | Age <36 or >81 years, BMI <22 or >38 kg/m^2^, FPG <126 or >270 mg/dL, fasting C-peptide >0.79 ng/ml
Hallsten, 2004^153^ Finland | Neither year reported 26 weeks | Run-in period but number of participants excluded was NR | >= 6 months | Yes | NR/44 NR | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), neuropathy, retinopathy, diabetes meds, oral corticosteroid treatment, BP >160/100 mm Hg
Nakamura, 2004^102^ Japan | Neither year reported 12 months | No run-in period | >= 6 months | NR | NR/45 Inpatient/hospital | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c >6.5%, BP <140/90 mm Hg, controlled on diet alone, C-peptide <0.33 mmol/l, creatinine <1.5 mg/dL, no antihypertensive medications, malignancy, no microalbuminuria, collagen vascular disease, non-diabetic renal disease
Horton, 2004^80^ NR | Neither year reported 24 Weeks | Yes | < 6 months | Yes | 701/401 NR | Age <30 years, any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), neuropathy, retinopathy, HbA1c <6.8% or >11%, Type 1 or secondary DM, diabetes >3 month duration, FPG <15 mmol/l, diabetic complication, on corticosteroids, non treatment naive
Ramachandran, 2004^51^ India | Not extracted 14 weeks (planned duration) | Not extracted | Not extracted | NR | Not extracted | Age <30 or >60 years, treatment experienced, HbA1c >11%, no Type 2 DM, other
Schernthaner, 2004^52^ Europe | Not extracted 12 months (planned duration) | Not extracted | Not extracted | NR | Not extracted | Age <35 or >75 years, treatment experienced, HbA1c <7.5% or >11%, no Type 2 DM
Derosa, 2004^60^ Italy | Not extracted 12 months (planned duration) | Not extracted | Not extracted | NR | Not extracted | Age <46 or >67 years, any liver disease, any kidney disease, history of CVD, treatment experienced, no Type 2 DM, other
Tan, 2004^106^ Denmark, Finland, Norway, and Sweden | Not extracted 52 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Treatment experienced, HbA1c <7.5% or >11% for patients not receiving ODM, <7.5 or >9.5 for patients receiving ODM, no Type 2 DM, other
Tan, 2004^107^ Mexico | Not extracted NR | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, history of CVD, HbA1c <7.5% or >11% in patients who were not receiving ODMs, and <7.5 or >9.5 in patients who were receiving ODM monotherapy, no Type 2 DM, other
Natali, 2004^148^ London and Italy | Not extracted 16 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <40 or >80 years, any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c >10% after washout, other
Raskin, 2004^109^ U.S. | Not extracted 12 titration and 12 maintenance weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <18 years, HbA1c <7% or >12% during previous monotherapy with SU or metformin at 50% or more of maximal recommended dose for at least 3 months, no Type 2 DM, other
Jovanovic, 2004^110^ U.S. | Not extracted 12 titration and 12 maintenance weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <18 years, HbA1c <7% or >12%, no Type 2 DM, other
Hanefeld, 2004^140^ Canada, U.K., Hungary, Finland, Slovak Republic, Belgium, Estonia, Lithuania, Denmark, Italy, Greece, Sweden, and the Netherlands | Not extracted NR | Not extracted | Not extracted | Yes | Not extracted | Age <35 or >75 years, history of CVD, HbA1c <7.5% or >11%, no Type 2 DM, other
Lawrence, 2004^53^ U.K. | Not extracted 12 titration and 12 maintenance weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <45 or >80 years, any liver disease, any kidney disease, history of CVD, HbA1c for diet treated diabetes <7% or >10% and for low-dose ODM >7.5%, no Type 2 DM, other
Madsbad, 2004^120^ Multinational Europe | Start year 2000 End year 2001 12 weeks | No run-in period | < 6 months | Yes | 311/193 Outpatient Primary Care setting | Age <30 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g., “failed initial treatment”), HbA1c < 7.5% or >10% on diet treatment, BMI >40 kg/m^2^, pregnant, nursing, not using adequate contraception, no Type 2 DM, no treatment for DM with ODM or diet, HbA1c >9.5% on ODM, history of CHF, NYHA class III, IV, use of TZDs or other investigational drugs
Malone, 2003^137^ 14 countries not specified | Neither year reported 16 Weeks | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | NR/597 subgroup completing test | Age <30 or >75 years, HbA1c <125% of upper limit of normal by local lab within 4 weeks prior to entry, BMI >40 kg/m^2^, not Type 2 DM, not use of single oral agent (metformin or SU) for 3 months prior to study at maximum clinically effective dose for previous 30 days
Yang, 2003^139^ China | Neither year reported 12 Weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | NR/211 NR | Age <35 or >70 years, poorly controlled on prior treatments (e.g., failed initial treatment), no Type 2 DM as defined by WHO, not treated with diet and SU for 6-months
Garber, 2003^61^ U.S. | Not extracted 16 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <20 or >79 years, any liver disease, any kidney disease, treatment experienced, HbA1c >7% or <12%, no Type 2 DM, other
Tosi, 2003^36,*^ Italy | Not extracted 6 months (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <6.3%, no Type 2 DM, other
Goldstein, 2003^62^ U.S. | Not extracted 18 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, history of CVD, HbA1c <7.5% and >12.0%, other
Derosa, 2003^81^ Italy | Not extracted 12 months (planned duration) | Not extracted | Not extracted | NR | Not extracted | Any kidney disease, history of CVD, treatment experienced, HbA1c <7%, no Type 2 DM, other
Derosa, 2003^113^ Italy | Not extracted 12 months (planned duration) | Not extracted | Not extracted | NR | Not extracted | Any kidney disease, history of CVD, HbA1c <7.0%, no Type 2 DM, other
Pavo, 2003^54^ Russia and Hungary | Not extracted 32 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <40 years, any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <7.5% or >11.0%, no Type 2 DM, other
Bakris, 2003^104^ U.S. and U.K. | Not extracted 52 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | NR
Virtanen, 2003^154^ Finland | Not extracted 26 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <45 or >75 years, any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, retinopathy, no Type 2 DM, other
Marre, 2002^96^ Multicontinent | Neither year reported 24 weeks | Yes | < 6 months | Yes | 680/467 NR | Age <30 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <6.8% or >11%, BMI <20 or >35 kg/m^2^, DM at least 6 months, FPG >15 mmol/l, gastroparesis, change in body weight during run-in, treated with diabetes meds other than metformin 3 months before study
Vakkilainen, 2002^119^ Finland | Neither year reported 12 weeks (planned duration) | Run-in period but number of participants excluded was NR | < 6 months | Yes | NR/48 NR | Age <18 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), HbA1c <6.5% or >10%, BMI >33 kg/m^2^, FPG >15 mmol/l, total cholesterol >6.5 mmol/l, triglycerides >4.5 mmol/l, thyroid disease, smoking, nicotine therapy, use of lipid lowering agents, insulin, hormone replacement therapy
Hallsten, 2002^55^ Finland | Not extracted 26 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, history of CVD, no Type 2 DM, other
Blonde, 2002^63^ U.S. | Not extracted 16 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <30 or >75 years, any liver disease, any kidney disease, history of CVD, HbA1c <7.4%, no Type 2 DM, other
St John Sutton, 2002^149^ U.S | Not extracted 52 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <40 or >80 years, any liver disease, any kidney disease, history of CVD, no Type 2 DM, other
Marre, 2002^64^ Netherlands, Denmark, Portugal, France, Belgium | Not extracted 4 months (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <18 years, any liver disease, any kidney disease, history of CVD, other
Garber, 2002^65^ U.S. | Not extracted 20 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, treatment experienced, HbA1c <7% or >11%, no Type 2 DM, other
Gomez-Perez, 2002^88^ Mexico | Not extracted 26 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <40 or >80 years, any liver disease, any kidney disease, history of CVD, treatment experienced, no Type 2 DM, other
Khan, 2002^97^ U.S. | Not extracted 16 weeks (planned duration) | Not extracted | Not extracted | NR | Not extracted | Any liver disease, other
Charpentier, 2001^71^ France | Not extracted 20 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age ≤34 or ≥71 years, any kidney disease, history of CVD, no Type 2 DM, other
Madsbad, 2001^114^ Denmark and Scandinavia | Not extracted 12 months (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age ≤39 or ≥76 years, any liver disease, any kidney disease, HbA1c <6.5% or >10%, no Type 2 DM, other
Amador-Licona, 2000^66^ Mexico | Not extracted 12 weeks (planned duration) | Not extracted | Not extracted | NR | Not extracted | Age >65 years, any liver disease, history of CVD, other
Einhorn, 2000^89^ U.S. | Not extracted 16 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c <8.0%, no Type 2 DM, other
Fonseca, 2000^90^ U.S. | Not extracted 26 weeks (planned duration) | Not extracted | Not extracted | NR | Not extracted | Age <40 or >80 years, any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, no Type 2 DM, other
Nakamura, 2000^103^ Japan | Not extracted 3 months (planned duration) | Not extracted | Not extracted | NR | Not extracted | Any liver disease, history of CVD, treatment experienced, HbA1c <6.5%, no Type 2 DM, other
Horton, 2000^79^ U.S. | Not extracted 24 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <30 years, any kidney disease, HbA1c <6.8% or >11%, no Type 2 DM, other
Turner, 1999^37^ U.K. | Start year 1977 End year 1991 9 Years | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | NR/4075 23 UKPDS centers | Age <25 or >65 years, FPG<6 mmol/l x 2, individuals on diet only therapy who maintained their blood sugars <6 mmol/l on followup visits
Moses, 1999^82^ Australia | Neither year reported 4 to 5 months | No run-in period | NR | NR | 108/83 NR | Age <40 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), contraindication or history of intolerance to metformin, HbA1c < 7.1%, BMI <21 kg/m^2^, no Type 2 DM, not on metformin for more than 6 months, alcohol abuse, drug use, intention to become pregnant, history of lactic acidosis, vitamin B12 <150 pmol/l with anemia
Landgraf, 1999^115^ Germany, Austria, and Netherlands | Not extracted 14 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, history of CVD, treatment experienced, no Type 2 DM, other
Marbury, 1999^117^ US and Canada | Not extracted 12 months (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <37 or >75 years, any liver disease, any kidney disease, history of CVD, treatment experienced, retinopathy, HbA1c <6.5% or >14.6%, no Type 2 DM, other
Wolffenbuttel, 1999^116^ Germany, Austria, and Netherlands | Not extracted 12 months (planned duration) | Not extracted | Not extracted | NR | Not extracted | Age <40 or >75 years, any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <6.5% if treated with diet only, >12% if treated with diet plus ODM, other
DeFronzo, 1995^70^ U.S. | Not extracted 29 weeks (planned duration) | Not extracted | Not extracted | NR | Not extracted | Age <40 or >70 years, any liver disease, any kidney disease, history of CVD, treatment experienced, no Type 2 DM, other
Hermann, 1994^68^ Sweden | Not extracted 6 months (planned duration) | Not extracted | Not extracted | Yes | Not extracted | No Type 2 DM, other
Campbell, 1994^67^ U.K. | Not extracted 52 weeks (planned duration) | Not extracted | Not extracted | NR | Not extracted | Age <40 or >69 years, any liver disease, any kidney disease, history of CVD, no Type 2 DM, other
Wolffenbuttel, 1993^118^ Netherlands | Not extracted 12 (4 week titration, 8 week treatment) (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, HbA1c <7.0% or >12.0%, no Type 2 DM, other
Hermann, 1991^69^ Sweden | Not extracted 6 months (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, history of CVD, no Type 2 DM, other
Hermann, 1991^155^ Sweden | Not extracted 6 months (planned duration) | Not extracted | Not extracted | NR | Not extracted | No Type 2 DM, other

* Crossover study, no washout period

ACEI = angiotensin-converting enzyme inhibitors; ADA = American Diabetes Association; ALT = alanine aminotransferase; AST = asparate aminotransferase; BMI = body mass index; BP = blood pressure; CAD = coronary artery disease; CHF = congestive heart failure; CK = creatine phosphokinase; CVD = cardiovascular diseases; DBP = diastolic blood pressure; DM = diabetes mellitus; FBG = fasting blood glucose; FPG = fasting plasma glucose; g/day = grams per day; g/dl = grams per deciliter; GFR = glomerular filtration rate; GI disorder = gastrointestinal disorders; HbA1c = hemoglobin A1c; kg = kilogram; kg/m^2^ = kilograms per meter squaredlbs = pounds; LDL = low density lipoprotein; LVEF = left ventricular ejection fraction; met = metformin; mg = milligram; mg/d = milligrams per day; mg/dL = milligrams per deciliter; mm Hg = millimeters of mercury; mmol/l = millimoles per liter; NCEP ATP III = National Cholesterol Education Program Adult Treatment Panel IIIng/ml = nanograms per milliliter; nmol/l = nanomoles per liter; NR = not reported; NYHA = New York Heart Association; ODM = oral diabetes medications; pmol/l = picomoles per liter; SBP = systolic blood pressure; SGOT = serum glutamyl oxaloacetic transaminase; SGPT = serum glutamyl pyruvic transaminase; SU = sulfonylurea; TZD = thiazolidinedione; U/kg = units per kilogram; UKPDS = The UK Prospective Diabetes Study; US = United States; WHO = World Health Organization; yrs = years

Table 3 Population characteristics of the studies reporting on the comparative effectiveness of diabetes medications on intermediate outcomes (KQ1)

Author, year | Group, N | Mean age (age range) | Male, % | Race, % | Mean BMI in kg/m2 Mean weight in kg | Mean HbA1c in % | Mean duration of diabetes in years | N of withdrawals
Seino, 2010^121^ | Glibenclamide, 132 | 58.5 | 65 | Asian: 100 | 24.4 NR | 8.978 | 8.5 | 12
Seino, 2010^121^ | Liraglutide, 268 | 58.2 | 68 | NR | 24.5 NR | 8.92 | 8.1 | 22
Derosa, 2010^44^ | Metformin + glibenclamide, 65 | NR | 51 | NR | 28.5 NR | 8.9 | NR | 8
Derosa, 2010^44^ | Metformin + exenatide, 45 | NR | 67 | NR | 28.7 NR | 8.8 | NR | 4
DeFronzo, 2010^132^ | Metformin + rosiglitazone, 45 | NR | NR | NR | NR NR | 7.9 | NR | 11
DeFronzo, 2010^132^ | Metformin + exenatide, 45 | NR | NR | NR | NR NR | 7.8 | NR | 12
Aschner, 2010^77^ | Metformin, 439 | 55.7 | 44 | NR | 30.9 NR | 7.2 | 2.1 | 75
Aschner, 2010^77^ | Sitagliptin, 455 | 56.3 | 48 | NR | 30.7 NR | 7.2 | 2.6 | 61
Seck, 2010^134^ | Metformin + sitagliptin, 248 | 57.6 | 57.3 | AA: 3.6, Asian: 9.3, C: 77.4, H: 5.6, Other: 4 | 30.9 NR | 7.3 | 5.8 | 231
Seck, 2010^134^ | Metformin + glipizide, 584 | 57 | 62.9 | AA: 5.1, Asian: 8.2, C: 78.5, H: 5.1, Other: 3.1 | 31.3 NR | 7.3 | 5.7 | 328
Pratley, 2010^143^ | Metformin + sitagliptin, 219 | 55 | 55 | AA: 5, Asian: 1, C: 91, H: 16, Other: 4 | 32.6 93.1 kg | 8.5 | 6.3 | 25
Pratley, 2010^143^ | Metformin + liraglutide, 221 | 55.9 | 52 | AA: 10, Asian: 3, C: 82, H: 17, Other: 5 | 32.6 93.7 kg | 8.4 | 6 | 27
Pratley, 2010^143^ | Metformin + liraglutide, 221 | 55 | 52 | AA: 7, Asian: 2, C: 87, H: 15, Other: 4 | 33.1 94.6 kg | 8.4 | 6.4 | 52
Home, 2009^16^ | Metformin + rosiglitazone, 1117 | 57 | 53.8 | C: 98.9 | NR 93.5kg | 7.8 | 6.1 | NR
Home, 2009^16^ | Metformin + sulfonylurea, 1105 | 57.2 | 52.9 | C: 98.4 | NR 93.3 kg | 7.8 | 6.3 | NR
Home, 2009^16^ | Metformin + sulfonylurea, 1122 | 59.7 | 50.6 | C: 99.1 | NR 84.3kg | 8 | 7.9 | NR
Home, 2009^16^ | Metformin + sulfonylurea, 2227 | 58.5 | 51.7 | C: 98.7 | 31.5 NR | 7.9 | 7.1 | 233
Home, 2009^16^ | Rosiglitazone, 2220 | 58.4 | 51.4 | C: 99.1 | 31.6 NR | 7.9 | 7 | 218
Home, 2009^16^ | Rosiglitazone + sulfonylurea, 1103 | 59.8 | 49 | NR | 30.3 85.0kg | 8 | 7.9 | NR
Raskin, 2009^131^ | Metformin + repaglinide, 187 | 54.8 (20 to 87) | 58 | AA: 16, Asian: 4, C: 75, American Indian: 1, Other: 4 | 32.9 NR | 8.45 | 7.4 | 62
Raskin, 2009^131^ | Metformin + repaglinide, 187 | 54.5 | 59 | AA: 13, Asian: 5, C: 80, American Indian: 1, Other: 2 | 32.5 NR | 8.29 | 7.3 | 58
Raskin, 2009^131^ | Metformin + rosiglitazone, 187 | 55.5 (28 to 83) | 51 | AA: 13, Asian: 2, C: 79, American Indians: 1, Others: 4 | 32.2 NR | 8.46 | 7.1 | 58
Derosa, 2009^46^ | Metformin, 67 | 55 (50 to 60) | 51 | C: 100 | 27.2 77.7 kg | 9.1 | NR | 7
Derosa, 2009^46^ | Metformin + glimepiride, 66 | 57.7 (51.7–64.7) | 48 | C: 100 | 27.1 77.4 kg | 9 | NR | 6
Derosa, 2009^46^ | Metformin + pioglitazone, 69 | 57 (50 to 64) | 49 | C: 100 | 27.4 76.4 kg | 9.3 | NR | 9
Derosa, 2009^46^ | Pioglitazone, 69 | 54 (48 to 60) | 46 | C: 100 | 27.5 76.7 kg | 9.2 | NR | 9
van der Meer, 2009^141^ | Metformin + glimepiride, 39 | 56.4 | 100 | NR | 29.3 NR | 7 | 3 | 2
van der Meer, 2009^141^ | Pioglitazone + glimepiride, 39 | 56.8 | 100 | NR | 28.2 NR | 7.1 | 4 | 5
Kaku, 2009^84^ | Metformin, 86 | 53 | 57 | NR | 25.4 NR | 7.55 | 5.6 | 7
Kaku, 2009^84^ | Metformin + pioglitazone, 83 | 52 | 66 | NR | 25.6 NR | 7.58 | 4.5 | 9
Gupta, 2009^47^ | Metformin, 17 | 56.9 | 37.5 | C: 62.5 | 36.4 97.8 kg | 6.0 | NR | 1
Gupta, 2009^47^ | Pioglitazone, 16 | 59.2 | 25 | C: 78.5 | 35.7 98.5 kg | 6.2 | NR | 2
Gupta, 2009^47^ | Pioglitazone, 18 | 55.7 | 33 | C: 50 | 34.3 95.3 kg | 6.4 | NR | 0
Williams-Herman, 2009^76^ | Metformin, 182 | 54.2 | 45 | NR | 32 NR | 8.5 | 4.1 | 46
Williams-Herman, 2009^76^ | Metformin, 182 | 53.7 | 48 | NR | 32 NR | 8.7 | 4.1 | 56
Williams-Herman, 2009^76^ | Metformin + sitagliptin, 182 | 53.6 | 41 | NR | 32 NR | 8.7 | 4.6 | 41
Williams-Herman, 2009^76^ | Metformin + sitagliptin, 190 | 53.7 | 53 | NR | 32 NR | 8.8 | 4.1 | 42
Williams-Herman, 2009^76^ | Sitagliptin, 179 | 53.5 | 52 | NR | 31 NR | 8.7 | 3.9 | 57
Derosa, 2009^135^ | Metformin + glibenclamide, 114 | 56 (52 to 60) | 51 | NR | 26.5 NR | 8.2 | 4 | 5
Derosa, 2009^135^ | Metformin + nateglinide, 119 | 55 (50 to 60) | 49 | NR | 26.4 NR | 8.1 | 4 | 5
Nauck, 2009^92^ | Metformin, 122 | 56 | 60 | AA: 3, Asian: 7, C: 88, Other: 3 | 31.6 NR | 8.4 | 8 | 48
Nauck, 2009^92^ | Metformin + glimepiride, 244 | 57 | 57 | AA: 2, Asian: 9, C: 89, Other: 1 | 31.2 NR | 8.4 | 8 | 34
Nauck, 2009^92^ | Metformin + liraglutide, 242 | 57 | 59 | AA: 2, Asian: 7, C: 88, Other: 2 | 30.9 NR | 8.4 | 8 | 51
Nauck, 2009^92^ | Metformin + liraglutide, 241 | 57 | 54 | AA: 4, Asian: 8, C: 88, Other:1 | 31.1 NR | 8.3 | 7 | 44
Vijay, 2009^99^ | Rosiglitazone, 20 | 47.75 | NR | NR | 32.01 82.46 kg | 9.10 | 15.40 | NR
Vijay, 2009^99^ | Pioglitazone, 20 | 48.1 | NR | NR | 32.26 81.90 kg | 9.27 | 16.55 | NR
Kiyici, 2009^45^ | Metformin, 16 | 52.4 | NR | NR | 31.6 NR | 6.7 | NR | NR
Kiyici, 2009^45^ | Rosiglitazone, 19 | 50.7 | NR | NR | 31.2 NR | 7.1 | NR | NR
Jonker, 2009^160^ | Metformin + glimepiride, 39 | 56.4 | 100 | NR | 29.1 NR | 7 | NR | NR
Jonker, 2009^160^ | Pioglitazone + glimepiride, 39 | 56.8 | 100 | NR | 28 NR | 7.1 | NR | NR
Perez, 2009^56^ | Metformin, 210 | 53.7 | 46.7 | AA: 6.7, Asian: 2.4, C: 88.1, H: 26.2 | 30.8 NR | 8.65 | NR | 68
Perez, 2009^56^ | Metformin + pioglitazone, 201 | 54.7 | 44.8 | AA: 6, Asian: 1.5, C: 91.5, H: 24.4 | 30.8 NR | 8.89 | NR | 44
Perez, 2009^56^ | Pioglitazone, 189 | 54 | 34.9 | AA: 6.9, Asian: 2.6, C: 87.3, H: 25.9 | 31.2 NR | 8.69 | NR | 64
Rigby, 2009^130^ | Metformin + rosiglitazone, 56 | 54.7 | 41 | AA: 3.6, Asian: 0, C: 28.6, H: 67.9 | NR 81.1 kg | 8.06 | 7.57 | 5
Rigby, 2009^130^ | Metformin + sitagliptin, 56 | 54.8 | 35.7 | AA: 1.8, Asian: 0, C: 23.2, H: 73.2 | NR 79.6 kg | 8.17 | 8.35 | 11
Tolman, 2009^150^ | Pioglitazone, 1063 | 54 (20–82) | 57.2 | AA: 14.5, Asian: 3.4, C: 59.8, H: 19.1 | 32.5 NR | 9.5 | 5.86 | 649
Tolman, 2009^150^ | Glibenclamide, 1057 | 55 (19–81) | 55.5 | AA: 13.2, Asian: 2.5, C: 62.1, H: 18.7 | 32.5 NR | 9.5 | 5.61 | 641
Jadzinsky, 2009^78^ | Metformin + saxagliptin, 320 | 52.4 | 51.6 | AA: 2.2, Asian: 15.9, C: 76.9, Other: 5 | 29.9 NR | 9.4 | 2 | 58
Jadzinsky, 2009^78^ | Metformin + saxagliptin, 323 | 52.1 | 45.2 | AA: 2.2, Asian: 16.7, C: 75.2, Other: 5.9 | 30.3 NR | 9.5 | 1.4 | 62
Jadzinsky, 2009^78^ | Metformin, 328 | 51.8 | 49.7 | AA: 1.2, Asian: 15.9, C: 76.5, Other: 6.4 | 30.2 NR | 9.4 | 1.7 | 85
Jadzinsky, 2009^78^ | Saxagliptin, 335 | 52 | 50.4 | AA: 1.8, Asian: 16.7, C: 76.1, Other: 5.4 | 30.2 NR | 9.6 | 1.7 | 110
DeFronzo, 2009^95^ | Metformin + saxagliptin, 192 | 54.7 | 43.2 | AA: 3.9, Asian: 4.2, C: 79.7, Other: 12 | 31.7 NR | 8.1 | 6.7 | 44
DeFronzo, 2009^95^ | Metformin + saxagliptin, 191 | 54.7 | 53.9 | AA: 5.8, Asian: 1.6, C: 83.2, Other: 9.4 | 31.2 NR | 8.1 | 6.4 | 48
DeFronzo, 2009^95^ | Metformin + saxagliptin, 181 | 54.2 | 52.5 | AA: 7.7, Asian: 2.8, C: 79.6, Other: 9.9 | 31.1 NR | 8.0 | 6.3 | 41
DeFronzo, 2009^95^ | Metformin, 179 | 54.8 | 53.6 | AA: 3.9, Asian: 2.2, C: 83.8, Other: 10.1 | 31.6 NR | 8.1 | 6.7 | 40
Bunck, 2009^144^ | Metformin + exenatide, 36 | 58.4 | 63.9 | NR | 30.9 90.6 kg | 7.6 | 5.7 | 6
Bunck, 2009^144^ | Metformin + glargine, 33 | 58.3 | 66.7 | NR | 30.1 92.4 kg | 7.4 | 4 | 3
Garber, 2009^122^ | Glimepiride, 248 | 53.4 | 54 | AA: 12, Asian: 4, C: 77, H: 38, Other: 7 | 33.2 93.4 kg | 8.4 | 5.6 | 96
Garber, 2009^122^ | Liraglutide, 247 | 52 | 49 | AA: 12, Asian: 6, C: 75, H: 35, Other: 7 | 32.8 92.8 kg | 8.3 | 5.3 | 74
Garber, 2009^122^ | Liraglutide, 251 | 53.7 | 47 | AA: 14, Asian: 2, C: 80, H: 32, Other: 5 | 32.3 92.5 kg | 8.3 | 5.2 | 89
Kato, 2009^57^ | Metformin, 25 | 58.6 | 56 | NR | 27.5 NR | 7.1 | NR | NR
Kato, 2009^57^ | Pioglitazone, 25 | 51.4 | 48 | NR | 28.4 NR | 7.4 | NR | NR
Erdem, 2008^39^ | Metformin, 27 | 55.09 | 33 | NR | 31.41 NR | 6.74 | NR | 4
Erdem, 2008^39^ | Pioglitazone, 26 | 54.9 | 31 | NR | 30.41 NR | 6.34 | NR | 5
Iliadis, 2007^48^ | Metformin, 16 | 57.8 | NR | NR | 30.8 80.8 kg | 7.8 | 20.9 months | 1
Iliadis, 2007^48^ | Rosiglitazone, 16 | 56.3 | NR | NR | 31 83.2 kg | 7.2 | 30.7 months | 2
Scott, 2008^85^ | Metformin, 92 | 55.3 | 59 | Asian: 39, C: 61 | 30 84.6 kg | 7.7 | 5.4 | 9
Scott, 2008^85^ | Metformin + rosiglitazone, 87 | 54.8 | 63 | Asian: 38, C: 59, Others: 3 | 30.4 84.9 kg | 7.7 | 4.6 | 2
Scott, 2008^85^ | Metformin + sitagliptin, 94 | 55.2 | 55 | Asian: 38, C: 61, Others: 1 | 30.3 83.1 kg | 7.8 | 4.9 | 9
Seufert, 2008^142^ | Metformin + sulfonylurea, 320 | 60 | 54.7 | NR | 30 NR | 8.8 | 7.1 | 58
Seufert, 2008^142^ | Pioglitazone + sulfonylurea, 319 | 60 | 53.6 | NR | 30.2 NR | 8.81 | 7 | 38
Robbins, 2007^145^ | Metformin + glargine, 159 | 58.1 | 49.4 | AA: 5.7, Asian: 14.6, C: 63.3, H: 16.4 | 32 88.1kg | 7.8 | 12.5 | 22
Robbins, 2007^145^ | Metformin + insulin lispro 50/50, 158 | 57.4 | 50.3 | AA: 5.7, Asian: 14, C: 65, H: 15.3 | 32.1 89.1kg | 7.8 | 11.3 | 15
Hamann, 2008^123^ | Metformin + rosiglitazone, 294 | 58.5 | 53 | C: 94 | 33 91.4kg | 8 | 6.3 | 61
Hamann, 2008^123^ | Metformin + sulfonylurea, 302 | 59.3 | 52 | C: 95 | 32.2 88.9kg | 8 | 6.4 | 71
Chien, 2007^59^ | Glyburide, 25 | 63 | 53 | NR | 25.3 63.7 kg | 8.69 | 8.6 | 6
Chien, 2007^59^ | Metformin, 25 | 59 | 41 | NR | 25.7 65.6 kg | 8.88 | 6.4 | 8
Chien, 2007^59^ | Metformin + glyburide, 26 | 60 | 71 | NR | 24.2 63.8 kg | 8.71 | 9 | 5
Chien, 2007^59^ | Metformin + glyburide, 26 | 57 | 62 | NR | 24.2 61.3 kg | 8.85 | 6.6 | 5
Derosa, 2007^288^ | Metformin + glibenclamide, 114 | 56 | 51 | NR | 26.5 NR | 8.2 | 4 | 10
Derosa, 2007^288^ | Metformin + nateglinide, 119 | 55 | 49 | NR | 26.4 NR | 8.1 | 5 | 5
Schwarz, 2008^152^ | Metformin + glyburide, 40 | 70.4 | 50 | AA: 11.1, C: 77.8, Other: 11 | 33.5 NR | 7.7 | 2.5 | 18
Schwarz, 2008^152^ | Metformin + nateglinide, 35 | 70.1 | 51.5 | AA: 9.1, C: 78.8, Other: 12.1 | 30.4 NR | 7.8 | 1.7 | 14
Comaschi, 2008^158^ | Metformin + glibenclamide, 80 | 59.9 | 55 | NR | 29.85 81.9 kg | 8.57 | NR | 13
Comaschi, 2008^158^ | Metformin + pioglitazone, 103 | 57 | 45.63 | NR | 32.2 85.8 kg | 8.4 | NR | 27
Comaschi, 2008^158^ | Pioglitazone + sulfonylurea, 67 | 62.2 | 56.72 | NR | 28.9 78.8kg | 8.7 | NR | 15
Turkmen Kemal, 2007^58^ | Metformin, 16 | 56.8 (40 to 70) | 25 | NR | 34.5 NR | 6.3 | 1.5 | 0
Turkmen Kemal, 2007^58^ | Rosiglitazone, 13 | 55.92 (42 to 68) | 30 | NR | 30.8 75 kg | 6.2 | 2.75 | 1
Comaschi, 2007^129^ | Metformin + pioglitazone, 103 | 57 | 45.63 | NR | 32.2 85.8 kg | 8.4 | NR | 27
Comaschi, 2007^129^ | Metformin + sulfonylurea, 80 | 59.9 | 55 | NR | 29.9 81.9 kg | 8.6 | NR | 13
Comaschi, 2007^129^ | Pioglitazone + sulfonylurea, 67 | 62.2 | 56.72 | NR | 28.9 78.8 kg | 8.7 | NR | 14
Home, 2007^124^ | Metformin + rosiglitazone, 259 | 57 | 54 | NR | 32.7 93kg | 7.9 | 6.1 | 52
Home, 2007^124^ | Metformin + sulfonylurea, 265 | 57 | 52 | NR | NR 91kg | 7.8 | 7 | 22
Home, 2007^124^ | Metformin + sulfonylurea, 284 | 60 | 52 | NR | NR 83kg | 8 | 8.1 | 54
Home, 2007^124^ | Rosiglitazone + sulfonylurea, 311 | 61 | 49 | NR | NR 84kg | 8 | 7.9 | 74
Teramoto, 2007^41^ | Glibenclamide, 46 | 56.4 | 76 | NR | 25.2 NR | 8.36 | NR | 5
Teramoto, 2007^41^ | Pioglitazone, 46 | 57 | 72 | NR | 24.7 NR | 8.01 | NR | 7
Goldstein, 2007^75^ | Metformin, 182 | 53.4 | 48.9 | AA: 6.6, Asian: 7.7, C: 47.8, H: 30.2, not specified: 7.7 | 32.1 NR | 8.9 | 4.5 | 29
Goldstein, 2007^75^ | Metformin, 182 | 53.2 | 45.1 | AA: 4.9, Asian: 5.5, C: 58.2, H: 21.4, not specified: 9.9 | 32.2 NR | 8.7 | 4.4 | 182
Goldstein, 2007^75^ | Metformin + sitagliptin, 182 | 53.3 | 42.3 | AA: 7.7, Asian: 6, C: 52.2, H: 26.9, not specified: 7.1 | 32.4 NR | 8.7 | 4.4 | 18
Goldstein, 2007^75^ | Metformin + sitagliptin, 190 | 54.1 | 55.3 | AA: 6.8, Asian: 4.7, C: 53.7, H: 28.9, not specified: 5.8 | 32.1 NR | 8.8 | 4.5 | 26
Goldstein, 2007^75^ | Sitagliptin, 179 | 53.3 | 52 | AA: 6.1, Asian: 3.4, C: 52, H: 29.1, not specified: 9.5 | 31.2 NR | 8.9 | 4.4 | 37
Lund, 2007^197^ | Metformin, 48 | 59.45 | 77 | C: 100 | 24.71 74.81 kg | 7.34 | (Median: 3 years) | 12^*^
Lund, 2007^197^ | Repaglinide, 48 | 63.31 | 75 | C: 100 | 24.82 75.57 kg | 7.57 | (Median: 5 years) | 8^†^
Nauck, 2007^133^ | Metformin + glipizide, 584 | 56.6 | 61.3 | AA: 6, Asian: 8.4, C: 74.3, H: 7.9, Other: 3.4 | 31.3 89.7 kg | 7.6 | 6.2 | 172
Nauck, 2007^133^ | Metformin + sitagliptin, 588 | 56.8 | 57.1 | AA: 7, Asian: 8.5, C: 73.5, H: 7.3, Other: 3.7 | 31.2 89.5 kg | 7.7 | 6.5 | 202
Kim, 2007^42^ | Metformin + glimepiride, 60 | 57.6 | 50 | NR | 25.8 66.7 kg | 7.7 | 3.4 | 4
Kim, 2007^42^ | Rosiglitazone + glimepiride, 60 | 56.5 | 52.63 | NR | 25.7 68.1 kg | 8.1 | 3.5 | 3
Raskin, 2007^146^ | Metformin + aspart 70/30, 79 | 52 | 52 | AA: 13, Asian: 3, C: 52, H: 32, Other: 1 | 31.2 88.7kg | 9.9 | NR | 12
Raskin, 2007^146^ | Metformin + glargine, 78 | 51.7 | 54 | AA: 15, Asian: 4, C: 47, H: 32, Other: 1 | 30.8 86.2kg | 9.9 | NR | 6
Hanefeld, 2007^100^ | Glibenclamide, 203 | 60.1 | 70 | AA: 0, C: 99, Other: 1 | 28.7 NR | 8.2 | 6.4 | 13
Hanefeld, 2007^100^ | Rosiglitazone, 189 | 60.6 | 58 | AA: 0, C: 97, Other: 3 | 28.8 NR | 8.2 | 6 | 9
Hanefeld, 2007^100^ | Rosiglitazone, 195 | 60.4 | 68 | AA: 0, C: 8, Other: 2 | 28.7 NR | 8.1 | 5.9 | 12
Scott, 2007^111^ | Glipizide, 123 | 54.7 (21 to 76) | 56.9 | AA: 3.3, Asian: 4.9, C: 61, Other: 24.4, Multiracial: 6.5 | 30.6 NR | 7.9 | 4.7 | 23
Scott, 2007^111^ | Sitagliptin, 123 | 56.2 (34 to 75) | 48 | AA: 4.9, Asian: 4.9, C: 63.4, multiracial: 5.7, Other: 21.1 | 30.5 NR | 7.9 | 4.9 | 7
Scott, 2007^111^ | Sitagliptin, 123 | 55.6 (34 to 76) | 57.7 | AA: 8.9, Asian: 4.9, C: 61, Multiracial: 6.5, Other: 18.7 | 31.4 NR | 7.9 | 5 | 15
Scott, 2007^111^ | Sitagliptin, 124 | 55.1 (28 to 75) | 52.4 | AA: 4.8, Asian: 2.4, C: 69.4, Multiracial: 7.3, Other: 16.1 | 30.4 NR | 7.8 | 4.2 | 12
Scott, 2007^111^ | Sitagliptin, 125 | 55.1 (30 to 76) | 49.6 | AA: 6.4, Asian: 7 5.6, C: 68.8, multiracial: 6.4, Other: 12.8 | 30.8 NR | 7.9 | 4.3 | 18
Davies, 2007^147^ | Metformin + NPH, 29 | 57.9 | 48.28 | AA: 0, Asian: 21, C: 66 | 32.6 90.4 kg | 10 | 7.3 | 5
Davies, 2007^147^ | Metformin + BHI 70/30, 27 | 57.4 | 80 | AA: 4, Asian: 22, C: 70 | 30.2 82.2 kg | 9 | 9.1 | 0
Kahn, 2006^38^ | Glyburide, 1441 | 56.4 | 58 | AA: 4.2, Asian: 2.2, C: 89, H: 4.2, Other: 0.3 | 32.2 92 kg | 7.35 | (<1: 44, 1–2: 52, >2: 4) | 634
Kahn, 2006^38^ | Metformin, 1454 | 57.9 | 59.4 | AA: 3.7, Asian: 2.4, C: 89.1, H: 3.8, Other: 1 | 32.1 91.6 kg | 7.36 | (<1: 46, 1–2: 50, >2: 4) | 551
Kahn, 2006^38^ | Rosiglitazone, 1456 | 56.3 | 55.7 | AA: 4.2, Asian: 2.7, C: 87.2, H: 76 5.2, Other: 0.7 | 32.2 91.5 kg | 7.36 | (<1: 45, 1–2: 52, >2: 3) | 539
Charbonnel, 2006^94^ | Metformin, 237 | 54.7 | 59.5 | AA: 5.9, Asian: 11, C: 67.1, H: 11.8, Other: 4.2 | 31.5 NR | (<8: 54, 8 –8.9: 30, ≥9: 15) | 6.6 | 45
Charbonnel, 2006^94^ | Metformin + sitagliptin, 464 | 54.4 | 55.8 | AA: 6.7, Asian: 10.6, C: 63.1, H: 15.5 | 30.9 NR | (<8: 55, 8 –8.9: 31, ≥9: 14) | 6 | 48
Rosenstock, 2006^49^ | Metformin, 154 | 51.5 | 56 | AA: 5, Asian: 14, C: 58, H: 21, Other: <1 | 32.5 NR | 8.8 | 2.9 | 31
Rosenstock, 2006^49^ | Metformin + rosiglitazone, 155 | 50.1 | 57 | AA: 6, Asian: 12, C: 54, H: 26 | 33.2 NR | 8.9 | 2.3 | 19
Rosenstock, 2006^49^ | Rosiglitazone, 159 | 50.6 | 58 | AA: 5, Asian: 14, C: 59, H: 19, Other: 3 | 32.8 NR | 8.8 | 2.7 | 22
Jain, 2006^101^ | Glyburide, 251 | 52.1 | 56.2 | AA: 13.5, Asian: 0, C: 65.7, H: 19.9, Native American: 0.4, Other: 0.4 | 32.8 94.3 kg | 9.2 | 0.78 | 123
Jain, 2006^101^ | Pioglitazone, 251 | 52.1 | 53 | AA: 15.9, Asian: 1.6, C: 61, H: 20.7, 0ther: 0.4, Native American: 1 0.4 | 32.5 93.9 kg | 9.2 | 0.8 | 117
Stewart, 2006^156^ | Metformin, 272 | 59 | 56 | AA: <1, Asian: <1, C: 99, H: <1, Native Hawaiian/Other Pacific Islander: <1 | 30.6 87.2 kg | 7.2 | 3.7 | 54
Stewart, 2006^156^ | Metformin + rosiglitazone, 254 | 58.8 | 55 | AA: 0, Asian: 1, C: 98, H: <1, Native Hawaiian/Other pacific islander: 0 | 30.9 88.1 kg | 7.2 | 3.7 | 50
Bakris, 2006^125^ | Metformin + glyburide, 185 | 58.8 | 69 | C: 76 | 31.8 90.3 kg | 8.3 | 7.6 | 5
Bakris, 2006^125^ | Metformin + rosiglitazone, 204 | 60 | 63 | C: 78 | 31.6 89.2 kg | 8.5 | 8 | 10
Umpierrez, 2006^126^ | Metformin + glimepiride, 96 | 51.6 | 55.2 | AA: 13.5, Asian: 1.0, C: 79.2, H: 5.2, Other: 1.0 | 34.54 NR | 8.4 | 4.9 | 11
Umpierrez, 2006^126^ | Metformin + pioglitazone, 109 | 55.7 | 52.3 | AA: 15.9, Asian: 3.7, C: 78.5, H: 1.9, Other: 0 | 33.81 NR | 8.31 | 5.9 | 17
Kvapil, 2006^138^ | Metformin + aspart 70/30, 116 | 56.4 | 46 | NR | 30.4 85.1 kg | 9. | 6.7 | 11
Kvapil, 2006^138^ | Metformin + glibenclamide, 114 | 58.1 | 46 | NR | 30.5 84.0 kg | 9.4 | 8.1 | 5
Derosa, 2005^151^ | Metformin + glimepiride, 49 | 52 | 47 | NR | 26.8 75.6 kg | 7.9 | 4 | 2
Derosa, 2005^151^ | Metformin + rosiglitazone, 50 | 54 | 50 | NR | 26.6 74.2 kg | 8.0 | 5 | 2
Gerich, 2005^136^ | Metformin + glyburide, 209 | 53.5 | 48 | AA: 16.7, Asian: 0.5, C: 65.2, Other: 17.7 | 33.5 NR | 8.3 | 2.0 | 87
Gerich, 2005^136^ | Metformin + nateglinide, 219 | 52.6 | 51 | AA: 13, Asian: 2.4, C: 64.4, Other: 20.2 | 33.3 NR | 8.4 | 1.5 | 78
Derosa, 2005^127^ | Metformin + glimepiride, 49 | 52 | 47 | NR | 26.8 NR | 7.9 | 4 | 2
Derosa, 2005^127^ | Metformin + rosiglitazone, 50 | 54 | 50 | NR | 26.6 NR | 8.0 | 5 | 2
Smith, 2004^291^ | Glyburide, 203 | 60 | 70 | NR | 28.7 NR | 8.2 | 6.4 | 0
Smith, 2004^291^ | Rosiglitazone, 384 | 61 | 33 | NR | 28.7 NR | 8.1 | 6 | NR
Hallsten, 2004^153^ | Metformin, 9 | 54 | 56 | NR | 29.9 NR | 6.8 | NR | 2
Hallsten, 2004^153^ | Rosiglitazone, 14 | 59.4 | 79 | | 29 NR | 6.6 | NR | NR
Nakamura, 2004^102^ | Glibenclamide, 15 | 55 | 53 | NR | NR NR | 7.8 | 19.2 | 0
Nakamura, 2004^102^ | Pioglitazone, 15 | 57 | 60 | NR | NR NR | 7.9 | 17.5 | NR
Horton, 2004^80^ | Metformin, 104 | 55.4 | 67.3 | NR | 29.9 NR | 8.3 | 3.7 | NR
Horton, 2004^80^ | Metformin + nateglinide, 89 | 57.7 | 65.2 | NR | 30.6 NR | 8.2 | 3.4 | NR
Horton, 2004^80^ | Nateglinide, 104 | 57.9 | 56.7 | NR | 29.9 NR | 8.1 | 4.7 | NR
Malone, 2003^137^ | Metformin + glibenclamide, 301 | 59 | 49 | AA: 1, C: 89, H: 6, Other: 4 | 29.6 81.7 kg | 9.27 | 7.4 | 29
Malone, 2003^137^ | Metformin + lispro 75/25, 296 | 58 | 57 | AA: 0.7, C: 88.9, H: 7.4, Other: 3 | 29.8 83.0 kg | 9.17 | 8.0 | 25
Yang, 2003^139^ | Metformin + sulfonylurea | NR | NR | NR | NR NR | 8.59 | NR | NR
Yang, 2003^139^ | Rosiglitazone + sulfonylurea | NR | NR | NR | NR NR | 8.61 | NR | NR
Marre, 2002^96^ | Metformin, 152 | 56.4 | 55.3 | AA: 3.3, Asian: 2.6, C: 90.8 | 29.6 NR | 8.25 | 6.5 | 16
Marre, 2002^96^ | Metformin + nateglinide, 155 | 57.9 | 61.3 | AA: 4.5, Asian: 3.2, C: 90.3 | 29.4 NR | 7.99 | 7.2 | 18
Marre, 2002^96^ | Metformin + nateglinide, 160 | 57.3 | 61.3 | AA: 3.8, Asian: 3.1, C: 91.3 | 29.3 NR | 8.18 | 6.8 | 15
Turner, 1999^37^ | Any in the Sulfonylurea class, 1305 | NR | NR | NR | NR NR | NR | NR | NR
Turner, 1999^37^ | Metformin, 340 | NR | NR | NR | NR NR | NR | NR | NR
Turner, 1999^37^ | Total, 4075 | 53 | NR | AA: 9, Asian: 10, C: 81 | 29 NR | (median: 9.1) | NR | 4 loss to followup
Moses, 1999^82^ | Metformin, 27 | 57.8 | 63 | Asian: 7, C: 85, Not specified: 7 | 31.8 NR | 8.6 | 8 | 0
Moses, 1999^82^ | Metformin + repaglinide, 27 | 57.2 | 67 | C: 96, Not specified: 4 | 33.2 NR | 8.3 | 5.9 | 0
Moses, 1999^82^ | Repaglinide, 28 | 60.3 | 54 | Asian: 7, C: 93 | 31.3 NR | 8.6 | 7 | 0
Jibran, 2006^112^ | Glibenclamide, 50 | 45.8 | 20 | NR | 30.4 72.7 kg | 10.2 | 0 | 0
Jibran, 2006^112^ | Repaglinide, 50 | 46.6 | 32 | NR | 27.1 65.8 kg | 9.9 | 0 | 0
Leiter, 2005^83^ | Metformin, 78 | 60 | 56 | C: 78, Other: 22 | 32.2 NR | 7.5 | 5.7 | 13
Leiter, 2005^83^ | Metformin + rosiglitazone, 158 | 58 | 65 | C: 76, Other: 24 | 33 NR | 7.5 | 5.3 | 18
Derosa, 2006^157^ | Metformin + rosiglitazone, 48 | 54 | 52 | NR | 26.6 NR | 8 | 5 | 4 from both groups
Derosa, 2006^157^ | Metformin + glimepiride, 47 | 52 | 49 | NR | 26.8 NR | 7.9 | 4 | 4 from both groups
Garber, 2006^128^ | Metformin + rosiglitazone, 158 | 56 (24 – 78) | 65 | AA: 6, C: 79, Asian: 3, H: 10, O: 3 | 32 94 kg | 8.4 | 6 | Not extracted
Garber, 2006^128^ | Metformin + glibenclamide, 160 | 56 (31 – 78) | 56 | AA: 5, C: 80, Asian: 3, H: 11, O: 2 | 32 93 kg | 8.5 | 5 | Not extracted
Nakamura, 2006^108^ | Pioglitazone, 17 | 56 | 53 | NR | NR NR | 8 | 16 | NR
Nakamura, 2006^108^ | Glibenclamide, 18 | 53.5 | 56 | NR | NR NR | 7.8 | 16.5 | NR
Nakamura, 2006^108^ | Nateglinide, 16 | 53.5 | 56 | NR | NR NR | 7.7 | 16.6 | NR
Weissman, 2005^86^ | Metformin + rosiglitazone, 358 | 55.5 | NR | NR | 34.4 98.2 kg | 8.05 | NR | Not extracted
Weissman, 2005^86^ | Metformin, 351 | 55.7 | NR | NR | 33.8 96.7 kg | 7.97 | NR | Not extracted
Bailey, 2005^87^ | Metformin + rosiglitazone, 288 | 58.1 | 58 | AA: 1, C: 97, Asian: 1, H: 0, O: 1 | 32.2 90.9 kg | 7.4 | 6 | Not extracted
Bailey, 2005^87^ | Metformin, 280 | 57.6 | 57 | AA: <1, C: 98, Asian: 1, H: 0, O: 1 | 32.1 89.5 kg | 7.5 | 6.1 | Not extracted
Betteridge, 2005^289^ | Metformin + pioglitazone, 317 | NR | NR | NR | NR NR | NR | NR | Not extracted
Betteridge, 2005^289^ | Metformin + unspecified sulfonylurea, 320 | NR | NR | NR | NR NR | NR | NR | Not extracted
Betteridge, 2005^289^ | Pioglitazone + unspecified sulfonylurea, 319 | NR | NR | NR | NR NR | NR | NR | Not extracted
Yamanouchi, 2005^50^ | Pioglitazone, 38 | 55.2 | 47 | AA: 0, C: 0, Asian: 0, H: 0, O: 100 | 25.8 NR | 10.2 | 3.2 months | Not extracted
Yamanouchi, 2005^50^ | Glimepiride, 37 | 55.6 | 51 | AA: 0, C: 0, Asian: 0, H: 0, O: 100 | 25.6 NR | 9.8 | 3.3 months | Not extracted
Yamanouchi, 2005^50^ | Metformin, 39 | 54.7 | 20 | AA: 0, C: 0, Asian: 0, H: 0, O: 100 | 26.2 NR | 9.9 | 3 months | Not extracted
Goldberg, 2005^98^ | Pioglitazone, 369 | 55.9 | 53.9 | AA: 2.4, C: 64.8, Asian: 2.7, H: 28.5, O: 1.6 | 33.7 93.7 kg | 7.6 | 3.9 | Not extracted
Goldberg, 2005^98^ | Rosiglitazone, 366 | 56.3 | 54.9 | AA: 2.7, C: 59.8, Asian: 3.3, H: 32.2, O: 1.9 | 32.6 92.5 kg | 7.5 | 4 | Not extracted
Pfutzner, 2005^105^ | Glimepiride, 84 | 63 | 61.9 | AA: 0, C: 96.4, Asian: 0, H: 0, O: 3.7 | 31.8 NR | 7.44 | 6.9 | Not extracted
Pfutzner, 2005^105^ | Pioglitazone, 89 | 62.2 | 61.8 | AA: 0, C: 98.8, Asian: 0, H: 0, O: 1.1 | 31.7 NR | 7.52 | 7.4 | Not extracted
Langenfeld, 2005^290^ | Pioglitazone, 89 | 62 | 61.8 | AA: 0; C: 98.9; Asian: 0; H: 0; O: 1.1 | 31.7 NR | 7.52 | 7.4 | Not extracted
Langenfeld, 2005^290^ | Glimepiride, 84 | 63 | 61.9 | AA: 0; C: 96.4; Asian: 0; H: 0; O: 3.6 | 31.8 NR | 7.44 | 6.9 | Not extracted
Derosa, 2005^159^ | Metformin + glimepiride, 47 | 52 | 49 | NR | 26.8 NR | 7.9 | 4 | Not extracted
Derosa, 2005^159^ | Metformin + rosiglitazone, 48 | 54 | 52 | NR | 26.6 NR | 8 | 5 | Not extracted
Feinglos, 2005^91^ | Metformin + glipizide, 61 | 57.7 (30–80) | 46 | AA: 8.2, C: 78.7, Asian: 3.3, H: 8.2, O: 1.6 | 31.7 90 kg | 7.45 | 6.5 | Not extracted
Feinglos, 2005^91^ | Metformin, 61 | 58.8 (40–81) | 41 | AA: 16.4, C: 68.9, Asian: 3.3, H: 8.2, O: 3.3 | 32.1 90.8 kg | 7.64 | 4.6 | Not extracted
Ramachandran, 2004^51^ | Glimepiride, 18 | 45.3 | 50 | AA: 0, C: 0, Asian: 0, H: 0, O: 100 | 24.6 65.7 kg | 10.2 | 0 | Not extracted
Ramachandran, 2004^51^ | Metformin, 21 | 44.4 | 71 | AA: 0, C: 0, Asian: 0, H: 0, O: 100 | 25.7 67.7 kg | 9.6 | 0 | Not extracted
Ramachandran, 2004^51^ | Pioglitazone, 23 | 45.1 | 74 | AA: 0, C: 0, Asian: 0, H: 0, O: 100 | 25.5 68.9 kg | 9.3 | 0 | Not extracted
Schernthaner, 2004^52^ | Metformin, 597 | 56 | 57.8 | NR | 31.4 89.7 kg | 8.7 | 3.1 | Not extracted
Schernthaner, 2004^52^ | Pioglitazone, 597 | 57 | 52.6 | NR | 31.2 88.2 kg | 8.7 | 3.4 | Not extracted
Derosa, 2004^60^ | Glimepiride, 81 | 56 | 47 | NR | 27.6 NR | 8.5 | NR | Not extracted
Derosa, 2004^60^ | Metformin, 83 | 58 | 51 | NR | 28.1 NR | 8.4 | NR | Not extracted
Tan, 2004^106^ | Glibenclamide, 109 | 57.9 | 73 | AA: 0, C: 100, Asian: 0, H: 0, O: 0 | 29.6 89 kg | 8.5 | 62.6 months | Not extracted
Tan, 2004^106^ | Pioglitazone, 91 | 60 | 62 | AA: 0, C: 99, Asian: 0, H: 0, O: 1 | 30.2 88.4 kg | 8.4 | 57.1 months | Not extracted
Tan, 2004^107^ | Glimepiride, 123 | 55.7 | 53 | AA: 0, C: 1, Asian: 0, H: 99, O: 0 | 28.8 74.5 kg | 8.45 | 81.2 months | Not extracted
Tan, 2004^107^ | Pioglitazone, 121 | 55.1 | 45 | AA: 0, C: 0, Asian: 0, H: 100, O: 0 | 29.3 74.2 kg | 8.54 | 77.8 months | Not extracted
Natali, 2004^148^ | Metformin, 28 | 58 | 79 | NR | 28 NR | 7.8 | 6.3 | Not extracted
Natali, 2004^148^ | Rosiglitazone, 24 | 59 | 92 | NR | 27.6 NR | 7.7 | 6.5 | Not extracted
Raskin, 2004^109^ | Repaglinide + rosiglitazone, 127 | 57.5 | 51 | AA: 17, C: 65, Asian: 0, H: 3, O: 15 | NR NR | NR | 7.3 | Not extracted
Raskin, 2004^109^ | Repaglinide, 63 | 58.5 | 62 | AA: 16, C: 63, Asian: 0, H: 2, O: 19 | NR NR | NR | 7.2 | Not extracted
Raskin, 2004^109^ | Rosiglitazone, 62 | 56.6 | 53 | AA: 13, C: 68, Asian: 0, H: 0, O: 19 | NR NR | NR | 7.4 | Not extracted
Jovanovic, 2004^110^ | Pioglitazone, 62 | 56.2 | 50 | AA: 11, C: 82, Asian: 0, H: 3, O: 3 | 32.1 NR | 9.1 | 6.1 | Not extracted
Jovanovic, 2004^110^ | Repaglinide, 61 | 57.8 | 59 | AA: 11, C: 75, Asian: 0, H: 5, O: 8 | 31.2 NR | 9 | 6.9 | Not extracted
Hanefeld, 2004^140^ | Metformin + unspecified Sulfonylurea, 320 | 60 | 54.7 | AA: 0.9, C: 98.4, Asian: 0, H: 0, O: 0.6 | 30 84.9 kg | 8.8 | 7.1 | Not extracted
Hanefeld, 2004^140^ | Unspecified sulfonylurea + pioglitazone, 31 | 60 | 53.6 | AA: 0.6, C: 99.4, Asian: 0, H: 0, O: 0 | 30.2 85.3 kg | 8.82 | 7 | Not extracted
Lawrence, 2004^53^ | Metformin, 20 | 59.5 | 60 | NR | (Median 29.2) NR | 8.04 | NR | Not extracted
Lawrence, 2004^53^ | Pioglitazone, 20 | 60.4 | 70 | NR | (Median 30.6) NR | 7.43 | NR | Not extracted
Madsbad, 2004^120^ | Glimepiride, 27 | 57 | 59 | NR | 30.2 NR | 7.8 | 3.8 | 0
Madsbad, 2004^120^ | Liraglutide, 26 | 53 | 85 | NR | 30.2 NR | 7.4 | 4.1 | 3
Madsbad, 2004^120^ | Liraglutide, 25 | 58 | 60 | NR | 32 NR | 7.9 | 4.4 | 3
Madsbad, 2004^120^ | Liraglutide, 27 | 57 | 67 | NR | 30.1 NR | 7.7 | 4.5 | 7
Madsbad, 2004^120^ | Liraglutide, 30 | 57 | 67 | NR | 30.4 NR | 7.4 | 4.6 | 2
Madsbad, 2004^120^ | Liraglutide, 29 | 58 | 55 | NR | 31.9 NR | 7.4 | 6.1 | 2
Garber, 2003^61^ | Glyburide, 151 | 55.3 | 43.7 | AA: 7.3, C: 81.5, Asian: 0, H: 7.9, O: 3.3 | 31.1 91 kg | 8.7 | 3 | Not extracted
Garber, 2003^61^ | Metformin + glyburide, 171 | 55.6 | 44 | AA: 10.5, C: 77.2, Asian: 0, H: 8.8, O: 3.5 | 31.4 91.9 kg | 8.8 | 3 | Not extracted
Garber, 2003^61^ | Metformin, 164 | 54.7 | 43.3 | AA: 6.7, C: 80.5, Asian: 0, H: 9.1, O: 3.7 | 31.4 92.8 kg | 8.5 | 2.6 | Not extracted
Tosi, 2003^36^ | Glibenclamide, 20 | NR | NR | NR | NR NR | NR | NR | Not extracted
Tosi, 2003^36^ | Glibenclamide, 21 | NR | NR | NR | NR NR | NR | NR | Not extracted
Tosi, 2003^36^ | Metformin + glibenclamide, 39 | NR | NR | NR | NR NR | NR | NR | Not extracted
Tosi, 2003^36^ | Metformin + glibenclamide, 41 | NR | NR | NR | NR NR | NR | NR | Not extracted
Tosi, 2003^36^ | Metformin, 19 | NR | NR | NR | NR NR | NR | NR | Not extracted
Tosi, 2003^36^ | Metformin, 20 | NR | NR | NR | NR NR | NR | NR | Not extracted
Goldstein, 2003^62^ | Glipizide, 84 | 57.4 | 64.3 | AA: 11.9, C: 71.4, Asian: 2.4, H: 14.3, O: 0 | 30.6 89.9 kg | 8.9 | 6.5 | Not extracted
Goldstein, 2003^62^ | Metformin + glipizide, 87 | 54.6 | 58.6 | AA: 11.5, C: 72.4, Asian: 0, H: 16.1, O: 0 | 31.7 94 kg | 8.7 | 5.9 | Not extracted
Goldstein, 2003^62^ | Metformin, 76 | 56.6 | 61.8 | AA: 15.8, C: 65.8, Asian: 1.3, H: 17.1, O: 0 | 31.6 93.8 kg | 8.7 | 7.3 | Not extracted
Derosa, 2003^81^ | Metformin, 56 | 52 | 58 | NR | 24.7 72.3 kg | 7.4 | 5 | Not extracted
Derosa, 2003^81^ | Repaglinide, 56 | 55 | 52 | NR | 25.2 70.2 kg | 7.6 | 4 | Not extracted
Derosa, 2003^113^ | Glimepiride, 62 | 54 | 48 | NR | 26.4 77.1 kg | 7.8 | NR | Not extracted
Derosa, 2003^113^ | Repaglinide, 62 | 56 | 50 | NR | 26.1 76.4 kg | 8 | NR | Not extracted
Pavo, 2003^54^ | Metformin, 100 | 55.8 | 56 | NR | 31.1 88.9 kg | 8.6 | 0.53 | Not extracted
Pavo, 2003^54^ | Pioglitazone, 105 | 54.2 | 43.8 | NR | 31.3 86.6 kg | 8.6 | 0.47 | Not extracted
Bakris, 2003^104^ | Rosiglitazone, 57 | 5.1 | 75 | NR | NR NR | 9.1 | NR | Not extracted
Bakris, 2003^104^ | Glyburide, 64 | 56.1 | 71 | NR | NR NR | 9.5 | NR | Not extracted
Virtanen, 2003^154^ | Metformin, 13 | 58 | 62 | NR | 29.9 88.8 kg | 6.9 | NR | Not extracted
Virtanen, 2003^154^ | Rosiglitazone, 14 | 58 | 71 | NR | 29.1 83.7 kg | 6.8 | NR | Not extracted
Vakkilainen, 2002^119^ | Glibenclamide, 20 | 63 | NR | NR | 28.8 NR | 7.6 | NR | Not extracted
Vakkilainen, 2002^119^ | Nateglinide, 23 | 63 | NR | NR | 27.8 NR | 7.6 | NR | Not extracted
Hallsten, 2002^55^ | Metformin, 13 | 57.8 | 62 | NR | 29.9 NR | 6.9 | NR | Not extracted
Hallsten, 2002^55^ | Rosiglitazone, 14 | 58.6 | 71 | NR | 29.3 NR | 6.8 | NR | Not extracted
Blonde, 2002^63^ | Glyburide, 164 | 55.8 | 57.3 | AA: 12.2, C: 66.5, Asian: 0, H: 17.1, O: 4.3 | 30.3 88 kg | 9.64 | 7.01 | Not extracted
Blonde, 2002^63^ | Metformin + glyburide, 160 | 55.4 | 55.6 | AA: 12.5, C: 70, Asian: 0, H: 15.6, O: 1.9 | 30.7 89.4 kg | 9.41 | 7.36 | Not extracted
Blonde, 2002^63^ | Metformin + glyburide, 162 | 55.6 | 63.6 | AA: 9.3, C: 67.9, Asian: 0, H: 19.1, O: 3.7 | 30.6 89.6 kg | 9.42 | 6.97 | Not extracted
Blonde, 2002^63^ | Metformin, 153 | 57.6 | 62.1 | AA: 10.5, C: 69.3, Asian: 0, H: 17, O: 3.3 | 30.6 89.5 kg | 9.51 | 8.18 | Not extracted
St John Sutton, 2002^149^ | Glyburide, 99 | 56.1 (40 – 76) | 71 | AA: 3, C: 76, Asian: 0, H: 0, O: 21 | (BMI ≥27: 65.7) NR | 9.5 | 6.2 | Not extracted
St John Sutton, 2002^149^ | Rosiglitazone, 104 | 55.1 (40 – 77) | 75 | AA: 5, C: 73, Asian: 0, H: 0, O: 22 | (BMI ≥27: 67.3) NR | 9.1 | 5.3 | Not extracted
Marre, 2002^64^ | Glibenclamide, 103 | 58.7 | 55 | NR | 29.3 82.5 kg | 7.88 | 6.6 | Not extracted
Marre, 2002^64^ | Metformin + glibenclamide, 101 | 58 | 50 | NR | 30.1 84.7 kg | 7.89 | 5.9 | Not extracted
Marre, 2002^64^ | Metformin + glibenclamide, 103 | 60.7 | 54 | NR | 29.7 83.1 kg | 7.62 | 6.7 | Not extracted
Marre, 2002^64^ | Metformin, 104 | 57.5 | 60 | NR | 29.9 84.9 kg | 8.09 | 5.4 | Not extracted
Garber, 2002^65^ | Glyburide, 161 | 56.5 | 50.9 | AA: 9.3, C: 78.3, Asian: 0, H: 8.7, O: 3.7 | 30.3 87.2 kg | 8.21 | 2.81 | Not extracted
Garber, 2002^65^ | Metformin + glyburide, 158 | 56.9 | 57.6 | AA: 12.7, C: 74.1, Asian: 0, H: 11.4, O: 1.9 | 30.1 88.8 kg | 8.25 | 3.52 | Not extracted
Garber, 2002^65^ | Metformin + glyburide, 165 | 58.1 | 58.2 | AA: 6.1, C: 79.4, Asian: 0, H: 9.7, O: 4.9 | 29.6 86.7 kg | 8.18 | 3.3 | Not extracted
Garber, 2002^65^ | Metformin, 161 | 56 | 57.8 | AA: 4.3, C: 80.7, Asian: 0, H: 12.4, O: 2.5 | 30.4 88.6 kg | 8.26 | 2.98 | Not extracted
Gomez-Perez, 2002^88^ | Metformin + rosiglitazone, 35 | 51.7 (40 – 73) | 29 | AA: 0, C: 0, Asian: 0, H: 80, O: 20 | 28 NR | NR | 11.1 | Not extracted
Gomez-Perez, 2002^88^ | Metformin + rosiglitazone, 36 | 54.2 (42 – 76) | 19 | AA: 0, C: 11, Asian: 0, H: 72, O: 17 | 27.6 NR | NR | 10.7 | Not extracted
Gomez-Perez, 2002^88^ | Metformin, 34 | 53.4 (40 – 68) | 29 | AA: 0, C: 3, Asian: 0, H: 76, O: 21 | 28.5 NR | NR | 9.1 | Not extracted
Khan, 2002^97^ | Pioglitazone, 67 | 57.8 | 52 | NR | 35.2 NR | 8 | NR | Not extracted
Khan, 2002^97^ | Rosiglitazone, 60 | 57.1 | 45 | NR | 35.6 NR | 7.9 | NR | Not extracted
Charpentier, 2001^71^ | Metformin + glimepiride, 147 | 56.8 (36 – 70) | 59 | NR | 29.5 81.2 kg | 6.4 | 5.6 | Not extracted
Charpentier, 2001^71^ | Glimepiride, 150 | 55.4 (35 – 70) | 58 | NR | 29.3 81 kg | 6.5 | 5.3 | Not extracted
Charpentier, 2001^71^ | Metformin, 75 | 56.7 (36 – 69) | 60 | NR | 29.2 82.2 kg | 6.8 | 7 | Not extracted
Madsbad, 2001^114^ | Glipizide, 81 | 62 | 64 | NR | 28 83.6 kg | 7.2 | 7 | Not extracted
Madsbad, 2001^114^ | Repaglinide, 175 | 60.2 | 61 | NR | 28 82.9 kg | 7.3 | 8.1 | Not extracted
Amador-Licona, 2000^66^ | Glibenclamide, 23 | 48.2 | 30 | NR | 30.4 73.2 kg | 8.4 | 4 | Not extracted
Amador-Licona, 2000^66^ | Metformin, 28 | 49.3 | 39 | NR | 26.8 70.7 kg | 8.5 | 4.5 | Not extracted
Einhorn, 2000^89^ | Metformin + pioglitazone, 168 | 55.5 | 54.8 | AA: 8.3, C: 81, Asian: 0, H: 10.1, O: 0.6 | 32.11 NR | 9.86 | NR | Not extracted
Einhorn, 2000^89^ | Metformin, 160 | 55.7 | 60 | AA: 6.3, C: 86.9, Asian: 0, H: 3.8, O: 3.1 | 32.12 NR | 9.75 | NR | Not extracted
Fonseca, 2000^90^ | Metformin + rosiglitazone, 113 | 58.3 | 68.2 | AA: 10, C: 77.3, Asian: 0, H: 0, O: 12.7 | 29.8 NR | 8.9 | 8.3 | Not extracted
Fonseca, 2000^90^ | Metformin + rosiglitazone, 119 | 57.5 | 62.1 | AA: 6.9, C: 80.2, Asian: 0, H: 0, O: 12.9 | 30.2 NR | 8.9 | 7.5 | Not extracted
Fonseca, 2000^90^ | Metformin, 116 | 58.8 | 74.3 | AA: 3.5, C: 81.4, Asian: 0, H: 0, O: 15 | 30.3 NR | 8.6 | 7.3 | Not extracted
Nakamura, 2000^103^ | Glibenclamide, 15 | 61 | 53 | NR | NR NR | 7.8 | 14 | Not extracted
Nakamura, 2000^103^ | Pioglitazone, 15 | 60 | 47 | NR | NR NR | 7.7 | 16 | Not extracted
Horton, 2000^79^ | Metformin + nateglinide, 172 | 58.4 | 59 | AA: 11.6, C: 82.6, Asian: 0.6, H: 0, O: 5.2 | 30 NR | 8.4 | 4.5 | Not extracted
Horton, 2000^79^ | Metformin, 178 | 56.8 | 68 | AA: 9.6, C: 79.2, Asian: 2.2, H: 0, O: 9 | 29.6 NR | 8.4 | 7.5 | Not extracted
Horton, 2000^79^ | Nateglinide, 179 | 58.6 | 61 | AA: 9.5, C: 82.1, Asian: 2.8, H: 0, O: 5.6 | 29.6 NR | 8.3 | 4.7 | Not extracted
Landgraf, 1999^115^ | Glibenclamide, 100 | 63 | 57 | AA: 6, C: 93, Asian: 0, H: 0, O: 1 | 27.5 79 kg | 8 | 10 | Not extracted
Landgraf, 1999^115^ | Repaglinide, 94 | 61 | 60 | AA: 0, C: 96, Asian: 0, H: 0, O: 4 | 27.6 80 kg | 7.8 | 10 | Not extracted
Marbury, 1999^117^ | Glyburide, 182 | 58.7 | 66 | AA: 9, C: 79, Asian: 0, H: 0, O: 12 | 29.1 NR | 8.9 | 8.3 | Not extracted
Marbury, 1999^117^ | Repaglinide, 362 | 58.3 | 67 | AA: 9, C: 77, Asian: 0, H: 0, O: 14 | 29.4 NR | 8.7 | 7.2 | Not extracted
Wolffenbuttel, 1999^116^ | Placebo + glyburide, 139 | 61 | 68 | NR | 28 81.3 kg | 7 | (Median 6) | Not extracted
Wolffenbuttel, 1999^116^ | Repaglinide, 286 | 61 | 62 | NR | 28.4 81.5 kg | 7.1 | (Median 6) | Not extracted
DeFronzo, 1995^70^ | Metformin + glyburide, 213 | 55 | 46 | NR | 29 92.1 kg | 8.8 | 7.8 | Not extracted
DeFronzo, 1995^70^ | Metformin, 143 | 53 | 43 | NR | 29.9 94.4 kg | 8.4 | 6 | Not extracted
DeFronzo, 1995^70^ | Glyburide, 209 | 56 | 49 | NR | 29.1 92.6 kg | 8.5 | 8.7 | Not extracted
DeFronzo, 1995^70^ | Metformin, 210 | 55 | 46 | NR | 29.4 92.6 kg | 8.9 | 8.4 | Not extracted
Hermann, 1994^68^ | Glibenclamide, 21 | NR | NR | NR | NR 82.6 kg | 6.7 | NR | Not extracted
Hermann, 1994^68^ | Metformin + glibenclamide, 13 | NR | NR | NR | NR 84.6 kg | 7.8 | NR | Not extracted
Hermann, 1994^68^ | Metformin + glibenclamide, 13 | NR | NR | NR | NR 76 kg | 7.8 | NR | Not extracted
Hermann, 1994^68^ | Metformin + glibenclamide, 18 | NR | NR | NR | NR 83.2 kg | 8.4 | NR | Not extracted
Hermann, 1994^68^ | Metformin + glibenclamide, 54 | NR | NR | NR | NR 80.2 kg | 6.8 | NR | Not extracted
Hermann, 1994^68^ | Metformin, 25 | 60 (34 – 74) | NR | NR | NR 78.6 kg | 6.9 | 4 | Not extracted
Campbell, 1994^67^ | Glipizide, 24 | 57 | 33 | NR | 31.2 82.2 kg | 11.8 | 2.8 | Not extracted
Campbell, 1994^67^ | Metformin, 24 | 57 | 33 | NR | 29.6 78.2 kg | 11.5 | 2.3 | Not extracted
Wolffenbuttel, 1993^118^ | Glibenclamide, 15 | 62 (45 – 75) | 25 | NR | 26.1 70.9 kg | (Range 7.0 – 12.0) | 9 | Not extracted
Wolffenbuttel, 1993^118^ | Repaglinide, 29 | 62 (45 – 75) | 25 | NR | 26.1 74 kg | (Range 7.0 – 12.0) | 9 | Not extracted
Hermann, 1991^69^ | Metformin, 16 | 60 overall (38 – 73 overall) | 64 overall | NR | 27 76.5 kg | 6.7 | NR | Not extracted
Hermann, 1991^69^ | Glibenclamide, 17 | 60 overall (38 – 73 overall) | 64 overall | NR | 29.2 84.1 kg | 6.6 | NR | Not extracted
Hermann, 1991^69^ | Metformin + glibenclamide, 11 | 60 overall (38 – 73 overall) | 64 overall | NR | 26.1 74.4 kg | 7.8 | NR | Not extracted
Hermann, 1991^69^ | Metformin + glibenclamide, 12 | 60 overall (38 – 73 overall) | 64 overall | NR | 30 87.3 kg | 7.7 | NR | Not extracted
Hermann, 1991^155^ | Glibenclamide, 34 | NR | NR | NR | NR NR | NR | NR | Not extracted
Hermann, 1991^155^ | Metformin + glibenclamide, 72 | 60 (34 – 74) | 79 | NR | 28.4 82.3 kg | NR | NR | Not extracted
Hermann, 1991^155^ | Metformin, 38 | NR | NR | NR | NR NR | NR | NR | Not extracted

AA = African American; BHI = biphasic human insulin; C = Caucasian; H = Hispanic; kg = kilogram; NPH = neutral protamine Hagedorn; NR = not reported; sd = standard deviation

* 5 while on metformin prior to second crossover; 2 during washout period; and 5 while on repaglinide after crossover

† 2 excluded on repaglinide prior to first crossover; 1 during washout, and 5 after first crossover while on metformin

Table 4 Comparative effectiveness of diabetes medications on intermediate outcomes (KQ1): baseline, final, and mean difference from baseline values for hemoglobin A1c, weight and lipids

Author, year | Intervention | Hemoglobin A1c, mean (SD) | LDL, mean (SD) | HDL, mean (SD) | Triglycerides, mean (SD) | Weight, mean (SD)
Metformin versus thiazolidinedione
Kiyici, 2009^45^ | Grp1: Metformin Fixed Mean: 850 mg Grp2: Rosiglitazone Fixed Mean: 4 mg | Grp1 B: 6.7 (0.9) F: 6.4 (0.6) p:> 0.05 F-B: −0.3 Grp2 B: 7.1 (0.9) F: 6.4 (0.6) p:0.008 F-B: −0.7 Grp1-Grp2: 0.4 | Grp1 B: 136.5 (27.3) F: 128.7 (31.2) p:> 0.05 F-B: −7.8 Grp2 B: 120.9 (27.3) F: 117 (39) p:> 0.05 F-B: −3.9 Grp1-Grp2: −3.9 | Grp1 B: 46.8 (3.9) F: 46.8 (7.8) p:> 0.05 F-B: 0 Grp2 B: 42.9 (3.9) F: 50.7 (11.7) p:0.018 F-B: 7.8 Grp1-Grp2: −7.8 p: 0.015 | Grp1 B: 124.6 (71.2) F: 115.7 (62.3) p: > 0.05 F-B: −8.9 Grp2 B: 142.4 (53.4) F: 124.6 (71.2) p: > 0.05 F-B: −17.8 Grp1-Grp2: 8.9
Perez, 2009^56^ | Grp1: Metformin Fixed Start: 850 mg Grp2: Pioglitazone Fixed | Grp1 F-B: −0.99 Grp2 F-B: −0.96 Grp1-Grp2: −0.03 (0.17) | | | | Grp1 F-B: −1.28 Grp2 F-B: 1.64 Grp1-Grp2: −2.92
Kato, 2009^57^ | Grp1: Metformin Fixed Max: 500 mg Grp2: Pioglitazone Fixed Max: 15 mg | Grp1 B: 7.14 (1.4) F: 6.31 (0.9) p:<0.01 F-B: −0.83 Grp2 B: 7.37 (1.8) F: 6.32 (1.2) p:<0.01 F-B: −1.05 Grp1-Grp2: 0.22 | Grp1 B: 134.94 (32.37) F: 133.38 (33.93) F-B: −1.56 Grp2 B: 127.14 (28.6) F: 127.53 (26.52) F-B: 0.39 Grp1-Grp2: −1.95 | Grp1 B: 54.6 (12.09) F: 60.45 (14.43) F-B: 5.85 Grp2 B: 57.72 (19.5) F: 67.08 (21.06) F-B: 9.36 Grp1-Grp2: −3.51 | Grp1 B: 145.07 (61.41) F: 134.39 (74.76) F-B: −10.68 Grp2 B: 143.29 (96.12) F: 125.49 (66.75) p: <0.05 F-B: −17.8 Grp1-Grp2: 7.12
Derosa, 2009^46^ | Grp1: Metformin Varied, prespecified target dose Start: 1000 mg, Max: 3000 mg D: 3 mos Grp2: Pioglitazone Varied Start: 15 mg, Max: 45 mg D: 3 mos | Grp1 B: 9.1 (1.2) F: 7.9 (0.5) p: <0.01 F-B: −1.1 (0.5) p: <0.01 Grp2 B: 9.2 (1.3) F: 8.2 (0.7) p: <0.01 F-B: −1 (0.7) p: <0.01 Grp1-Grp2: −0.1 (SE: 0.33)
Gupta, 2009^47^ | Grp1: Metformin + ADA diet Varied, prespecified target dose Start: 500 mg, Max: 2000 mg D: every 1 wk increment by 500 mg Grp2: Pioglitazone + ADA diet Varied, glucose: FPG > 100 mg, HbA1c: 7.0% Start: 30 mg, Max: 45 mg D: 8 wks | Grp1 F-B: −0.24 (0.14) Grp2 F-B: −0.09 (0.13) Grp1-Grp2: −0.15 (SE: 0.22) | Grp1 F-B: −2.54 (5.36) Grp2 F-B: 14.3 (4.43) Grp1-Grp2: −16.84 (SE: 6.95) | Grp1 F-B: 1.67 (0.91) Grp2 F-B: 6.2 (1.94) Grp1-Grp2: −4.53 (SE: 2.14) | Grp1 F-B: −23.7 (14.7) Grp2 F-B: −72.8 (38.8) Grp1-Grp2: 49.1 | Grp1 F-B: −3.21 (0.7) Grp2 F-B: 2.15 (1.09) Grp1-Grp2: −5.36
Gupta, 2009^47^ | Grp1: Metformin + ADA diet Varied, prespecified target dose Start: 500 mg/day, Max: 2000 mg/day D: every 1 wk increment by 500 mg Grp2: Pioglitazone + PC diet Varied, glucose: FPG > 100 mg, HbA1c: 7% Start: 30 mg, Max: 45 mg D: 8 wks | Grp1 F-B: −0.24 (0.14) Grp2 F-B: −0.42 (0.17) Grp1-Grp2: 0.18 (SE: 0.23) | Grp1 F-B: −2.54 (5.36) Grp2 F-B: 8.85 (6.45) Grp1-Grp2: −11.39 (SE: 1.42) | Grp1 F-B: 1.67 (0.91) Grp2 F-B: 8.11 (1.7) Grp1-Grp2: −6.44 (SE: 0.67) | Grp1 F-B: −23.7 (14.7) Grp2 F-B: −155.6 (95.6) Grp1-Grp2: 131.9 | Grp1 F-B: −3.21 (0.7) Grp2 F-B: −2.59 (1.25) Grp1-Grp2: −0.62
Erdem, 2008^39^ | Grp1: Metformin Varied, glucose: 110 mg/dL Start: 1000 mg, Max: 2000 mg D: every 2 wks until goal Grp2: Pioglitazone Varied, glucose: 110 mg/dL Start: 15 mg, Max: 45 mg D: every 2 wks until goal | Grp1 B: 6.74 (1.3) F: 6.15 (0.53) p: 0.02 F-B: −0.59 Grp2 B: 6.34 (1.2) p: 0.31 F: 5.6 (0.7) p: 0.01 F-B: −0.74 Grp1-Grp2: 0.15 (SE: 0.50) | Grp1 B: 132.42 (30.9) F: 112.57 (27.8) F-B: −19.85 p: <0.001 Grp2 B: 132.66 (35.6) p: 0.98 F: 128.62 (30.51) F-B: −4.04 p: 0.76 Grp1-Grp2: −15.81 (SE: 16.4) | Grp1 B: 48.31 (13.1) F: 49.37 (11.8) F-B: 1.06 p: 0.39 Grp2 B: 48.04 (9.4) p: 0.94 F: 53.25 (10.7) F-B: 5.21 p: 0.01 Grp1-Grp2: −4.15 (SE: 5.89) | Grp1 B: 166.05 (81.8) F: 150.05 (67.3) p:0.32 Grp2 B: 183.95 (105.04) p: 0.54 F: 162.23 (84.6) p: 0.29 Grp1-Grp2: 5.72 (SE: 44.9)
Iliadis, 2007^48^ | Grp1: Metformin Varied, glucose: euglycemia Max: 1700 mg Grp2: Rosiglitazone Varied, glucose: euglycemia Max: 8 mg | Grp1 F-B: −1.7 (1.1) p: <0.001 Grp2 F-B: −1 (0.7) p: <0.01 Grp1-Grp2: −0.7 (SE: 0.59) | Grp1 F-B: 1 (17) p: NSG Grp2 F-B: 3 (24) p: NSG Grp1-Grp2: −2 (SE: 2.76) | Grp1 F-B: 1 (3) p: NSG Grp2 F-B: 0.8 (5) p: NSG Grp1-Grp2: 0.2 (SE: 1.22) | Grp1 F-B: −29 (101) p: NSG Grp2 F-B: 22 (73) p: NSG Grp1-Grp2: −51 (SE: 5.7) | Grp1 F-B: −2.5 (3.5) p: <0.05 Grp2 F-B: −0.3 (3.3) p: NSG Grp1-Grp2: −2.2
Turkmen Kemal, 2007^58^ | Grp1: Metformin Fixed Start: 1700 mg D: 6 mos Grp2: Rosiglitazone Fixed Start: 8 mg | Grp1 B: 5.95 Range: 5.6 F: 5.85 Range: 1.9 Grp2 B: 6 Range: 2.4 F: 5.95 Range: 1.9 | Grp1 B: Median: 3.4 range: 2.69 mmol/l F: Median: 2.62 range: 1.78 mmol/l Grp2 B: Median: 2.88 range: 2.48 mmol/l F: Median: 2.48 range: 1.81 mmol/l | | Grp1 B: Median: 4.27 range: 5.93 F: Median: 3.36 range: 5.36 Grp2 B: Median: 3.17 range: 3.96 F: Median: 3.28 range: 3.31
Kahn, 2006^38^ | Grp1: Metformin Varied, glucose: <140 mg Start: 500 mg, Max: 2000 mg Grp2: Rosiglitazone Varied, glucose: <140 mg Start: 4 mg, Max: 8 mg | Grp1: Annualized slope: 0.14 (CI: 0.13, 0.16) Grp2: Annualized slope: 0.07 (CI: 0.06, 0.09) Grp2-Grp1: −0.13 (CI: −0.22, −0.05) p: 0.002 | | | | Grp1: Annualized slope: −0.3 (CI: −0.4, −0.2) Grp2: Annualized slope: 0.7 (CI: 0.6, 0.8) Grp1-Grp2: 6.9 (CI: 6.3, 7.4) p: <0.001
Rosenstock, 2006^49^ | Grp1: Metformin Varied, glucose: Mean daily glucose <= 6.1 mmol/l Start: 500 mg, Max: 2000 mg, Mean: 1847 mg D: 32 wks Grp2: Rosiglitazone Varied, glucose: Mean daily glucose <= 6.1 mmol/l Start: 4 mg, Max: 8 mg, Mean: 7.7 mg D: 32 wks | Grp1 B: 8.8 (1.0) F: 7.0 (1.0) F-B: −1.8 Grp2 B: 8.8 (1.0) F: 7.2 (1.0) F-B: −1.6 Grp1-Grp2: −0.2 (SE 0.20) | Grp1 B: 116 (CV: 33.9) F: 103.6 (CV: 35.5) F-B: −12.4 Grp2 B: 114.6 (CV: 40.5) F: 119.7 (CV: 58) F-B: 5.1 Grp1-Grp2: −17.5 (SE: 10.79) | Grp1 B: 42.9 (CV: 23.8) F: 43 (CV: 23) F-B: 0.1 Grp2 B: 42.8 (CV: 24.5) F: 44.1 (CV: 27) F-B: 1.3 Grp1-Grp2: −1.2 (SE: 2.35) | Grp1 B: 175.7 (CV: 62.3) F: 148.7 (CV: 58.3) Grp2 B: 166.6 (CV: 67.6) F: 158.5 (CV: 74.8) Grp1-Grp2: −18.9 (SE: 23.7) | Grp1 F-B: Median: −2.2 (IQR: −5.5, −0.5) Grp2 F-B: Median: 1.7 (IQR: −1.2, −4.5)
Hallsten, 2004^153^ | Grp1: Metformin Varied Start: 500 mg bid, Max: 1 g bid D: 2 wks Grp2: Rosiglitazone Varied Start: 2 mg bid, Max: 4 mg bid D: 2 wks | | | Grp1 F-B: 3.9 (SE: 3.9) p: >0.05 Grp2 F-B: 3.9 (SE: 3.9) p: >0.05 Grp1-Grp2: 0 (SE: 5.52) | Grp1 F-B: 0.2 (0.2) p: >0.05 Grp2 F-B: −0.2 (0.2) p: >0.05 Grp1-Grp2: 35.6 (SE: 25.1)
Yamanouchi, 2005^50^ | Grp1: Metformin Fixed Start: 750 mg Grp2: Pioglitazone Fixed Start: 30 mg for women and 45 mg for men | Grp1 B: 9.9 (0.7) F: 7.8 (1.0) F-B: −2.1 p: <0.005 Grp2 B: 10.2 (0.8) F: 7.9 (1.0) F-B: −2.3 p: <0.005 Grp1-Grp2: 0.2 | | Grp1 B: 53.82 (4.68) F: 58.11 (3.51) F-B: 4.29 p: NSG Grp2 B: 51.87 (3.51) F: 51.48 (4.68) F-B: −0.39 p: NSG Grp1-Grp2: 4.68 | Grp1 B: 219.83 (112.14) F: 185.12 (96.12) F-B: −39.16 p: NSG Grp2 B: 205.59 (101.46) F: 197.58 (94.34) F-B: −8.01 p: NSG Grp1-Grp2: −31.15
Ramachandran, 2004^51^ | Grp1: Metformin Varied Start: 250 mg, Max: 850 mg Grp2: Pioglitazone Varied Start: 15 mg, Max: 30 mg | Grp1 B: 9.6 (2.4) F: 8.2 (2.5) F-B: −1.4 p: 0.05 Grp2 B: 9.3 (1.8) F: 6.7 (1.3) F-B: −2.6 p: 0.01 Grp1-Grp2: 1.2 | | Grp1 B: 38.22 (5.85) F: 42.9 (7.8) F-B: 4.68 p: <0.01 Grp2 B: 39 (7.8) F: 42.9 (11.7) F-B: 3.9 Grp1-Grp2: 0.78 | Grp1 B: 258.1 (213.6) F: 195.8 (124.6) F-B: −62.3 p: <0.05 Grp2 B: 249.2 (222.5) F: 222.5 (160.2) F-B: −26.7 Grp1-Grp2: −35.6 | Grp1 B: 68.9 (9.1) F: 67.8 (7.9) F-B: −1.1 Grp2 B: 67.7 (11.5) F: 67 (11.4) F-B: −0.7 Grp1-Grp2: −0.4
Schernthaner, 2004^52^ | Grp1: Metformin Varied Start: 850 mg up to 3 times/day, Max: 2550 mg Grp2: Pioglitazone Varied Start: 30 mg, Max: 45 mg | Grp1 B: 8.68 (0.98) F: 7.18 F-B: −1.5 Grp2 B: 8.69 (1.02) F: 7.28 F-B: −1.41 Grp1-Grp2: −0.09 | Grp1 B: 138.84 F: 134.16 F-B: −4.68 Grp2 B: 138.84 F: 149.37 F-B: 10.53 Grp1-Grp2: −15.21 | Grp1 B: 44.07 F: 50.31 F-B: 6.24 Grp2 B: 44.07 F: 47.19 F-B: 3.12 Grp1-Grp2: 3.12 p: 0.001 | Grp1 B: 234.96 F: 180.67 F-B: −54.29 Grp2 B: 232.29 F: 205.59 F-B: −26.7 Grp1-Grp2: −27.59 p: 0.001 | Grp1 F-B: 1.9 Grp2 F-B: −2.5 Grp1-Grp2: 4.4
Lawrence, 2004^53^ | Grp1: Metformin Varied Start: 500 mg bid, Max: 1000 mg tid Grp2: Pioglitazone Varied Start: 30 mg, Max: 45 mg | Grp1 B: 8.04 (0.9) F: 6.9 (0.5) F-B: −1.12 (0.84) p: <0.01 Grp2 B: 7.43 (0.9) F: 6.62 (0.5) F-B: −0.81 (0.63) p: <0.01 Grp1-Grp2: −0.31 p: NSG | Grp1 B: 200.5 (42.6) F: 200.9 (50.5) F-B: 0.4 Grp2 B: 194.2 (43.2) F: 202.4 (46.9) F-B: 8.2 Grp1-Grp2: −7.8 | Grp1 B: 49.6 (11.8) F: 52.7 (11.1) F-B: 3.1 p: <0.05 Grp2 B: 48.7 (9.4) F: 46.8 (8.5) F-B: −1.9 p: NSG Grp1-Grp2: 5 | Grp1 B: 203 (149) F: 176 (115) F-B: −27 p: NSG Grp2 B: 202 (110) F: 175.6 (114.4) F-B: −26.4 Grp1-Grp2: −0.6
Pavo, 2003^54^ | Grp1: Metformin Varied Start: 850 mg, Max: 2550 mg Grp2: Pioglitazone Varied Start: 30 mg, Max: 45 mg | Grp1 B: 8.6 F: 7.1 F-B: −1.5 p: <0.0001 Grp2 B: 8.6 F: 7.3 F-B: −1.3 p: <0.0001 Grp1-Grp2: −0.2 p: 0.28 | Grp1 F-B: −7.02 p: 0.04 Grp2 F-B: 6.24 p: 0.055 Grp1-Grp2: −13.26 p: 0.003 | Grp1 F-B: 8.58 Grp2 F-B: 5.07 Grp1-Grp2: 3.51 p: 0.02 | Grp1 F-B: −80.99 p: 0.001 Grp2 F-B: -56.07 p: 0.03 Grp1-Grp2: −24.92 | Grp1 B: 86.1 (15.6) F: 86.8 F-B: −0.7 (0.4) Grp2 B: 88.9 (15.9) F: 90.2 F-B: 2.4 Grp1-Grp2: −3.1 p: <0.0001
Hallsten, 2002^55^ | Grp1: Metformin Varied Start: 500 mg bid, Max: 1000 mg bid Grp2: Rosiglitazone Varied Start: 2 mg bid, Max: 4 mg bid | Grp1 B: 6.9 (0.2) F: 6.2 (0.2) F-B: −0.7 p: <0.0001 Grp2 B: 6.8 (0.2) F: 6.5 (0.2) F-B: −0.3 p: <0.05 Grp1-Grp2: −0.4 p: NSG | | | | Grp1 B: 83.7 (7.9) F: 84.3 (3.5) F-B: 0.6 p: NSG Grp2 B: 88.8 (10.8) F: 86.8 F-B: −2 p: <0.05 Grp1-Grp2: −2.6
Natali, 2004^148^ | Grp1: Metformin Fixed Start: 500 mg tid Grp2: Rosiglitazone Fixed Start: 4 mg bid | | Grp1 B: 118 (SE: 25) F: 120 F-B: 2 Grp2 B: 120 (SE: 29) F: 131 F-B: 11 Grp1-Grp2: −10 (CI: −23, 4) | Grp1 B: 46 (SEM: 9) F: 50 F-B: 4 Grp2 B: 46 (SEM: 15) F: 49 F-B: 3 Grp1-Grp2: 0.4 (CI: −5, 6) p: NSG | Grp1 B: 142 (SEM 7.3) F: 178 F-B: 36 (32) Grp2 B: 196 (SEM 251) F: 152 F-B: −44 (41) Grp1-Grp2: 47 p: NSG | Grp1 B: 80.4 (SEM 10.1) F: 80.9 F-B: 0.5 (0.5) p: NSG Grp2 B: 77.3 (SEM 12.5) F: 76.7 F-B: −0.6 (0.4) p: NSG Grp1-Grp2: 1.1 p: NSG
Virtanen, 2003^154^ | Grp1: Metformin Varied Start: 500 mg bid, Max: 1000 mg bid Grp2: Rosiglitazone Varied Start: 2 mg bid, Max: 4 mg bid | | Grp1 B: 109.2 (SE: 7.8) F: 101.4 (SE: 7.8) F-B: −7.8 Grp2 B: 113.1 (SE: 7.8) F: 136.5 (SE: 7.8) F-B: 23.4 Grp1-Grp2: −31.2 | Grp1 B: 42.9 (SE: 3.9) F: 46.8 (SE: 3.9) F-B: 3.9 p: NSG Grp2 B: 42.9 (SE: 3.9) F: 46.8 (SE: 3.9) F-B: 3.9 p: NSG Grp1-Grp2: 0 | Grp1 B: 151.3 (SE: 17.8) F: 133.5 (SE: 17.8) F-B: −17.8 Grp2 B: 106.8 (SE: 8.9) F: 115.7 (SE: 17.8) F-B: 8.9 Grp1-Grp2: −26.7 p: NSG
Metformin versus sulfonylurea
Chien, 2007^59^ | Grp1: Metformin Varied, glucose: <140 mg/dL Start: 1000 mg, Max: 2000 mg, Final mean dose: 1910 mg D: 4 wks Grp2: Glyburide Varied, glucose: <140 mg/dL Start: 10 mg, Max: 20 mg, Final mean dose: 19 mg D: 4 wks | Grp1 B: 8.88 (1.08) F: 8.98 F-B: 0.09 (SE: 0.37) p: NS Grp2 B: 8.69 (0.94) F: 9.21 F-B: 0.52 (SE: 0.24) p: 0.018 Grp1-Grp2: −0.43 (SE: 0.44)
Kahn, 2006^38^ | Grp1: Metformin Varied, glucose: <140 mg/dL Start: 500 mg, Max: 2000 mg Grp2: Glyburide Varied, glucose: <140 mg/dL Start: 2.5 mg, Max: 15 mg | Grp1: Annualized slope: 0.14 (CI: 0.13, 0.16) Grp2: Annualized slope: 0.24 (CI: 0.23, 0.26) | | | | Grp1: Annualized slope: −0.3 (CI: −0.4, − 0.2) Grp2: Annualized slope: −0.2 (CI: −0.3, 0.0)
Turner, 1999^37^ | Grp1: Metformin Varied, glucose: FPG <6 mmol/L Max: 2550 mg/day D: 9 yrs Grp2: Any in the Sulfonylurea class Varied, glucose: 6 mmol/L Max: Chlorpropramide-500 mg; Glyburide 20 mg D: 9 yrs | Grp1 Proportion achieving HbA1c<7% at 3 yrs: 44 (CI: 42, 46) 6 yrs: 34 (CI: 32, 37) 9 yrs: (CI: 11, 15) Grp2 Proportion achieving HbA1c<7% at 3 yrs: 45 (CI: 43, 48) 6 yrs: 28 (CI: 26, 30) 9 yrs: (CI: 19, 23)
Yamanouchi, 2005^50^ | Grp1: Metformin Fixed Start: 750 mg Grp2: Glimepiride Varied Start: 1 mg, Max: 2 mg | Grp1 B: 9.9 (0.7) F: 7.8 (1.0) F-B: −2.1 p: <0.005 Grp2 B: 9.8 (0.7) F: 7.7 (0.9) F-B: −2.1 p: <0.005 Grp1-Grp2: 0 | | Grp1 B: 51.87 (3.51) F: 51.48 (4.68) F-B: −0.39 p: NSG Grp2 B: 52.65 (4.29) F: 52.26 (4.29) F-B: −0.39 p: NSG Grp1-Grp2: 0 | Grp1 B: 205.59 (101.46) F: 197.58 (94.34) F-B: −8.01 p: NSG Grp2 B: 234.07 (121.93) F: 229.62 (112.14) F-B: −4.45 p: NSG Grp1-Grp2: −3.56
Ramachandran, 2004^51^ | Grp1: Metformin Varied Start: 250 mg, Max: 850 mg Grp2: Glimepiride Varied Start: 1 mg, Max: 2 mg | Grp1 B: 9.6 (2.4) F: 8.2 (2.5) F-B: −1.4 p: <0.05 Grp2 B: 10.2 (2.2) F: 7.7 (1.7) F-B: −2.5 p: <0.01 Grp1-Grp2: 1.1 | | Grp1 B: 39 (7.8) F: 42.9 (11.7) F-B: 3.9 p: NSG Grp2 B: 37.05 (11.7) F: 42.9 (7.8) F-B: 5.85 p: NSG Grp1-Grp2: −1.95 | Grp1 B: 249.2 (222.5) F: 222.5 (160.2) F-B: −26.7 Grp2 B: 195.8 (124.6) F: 151.3 (80.1) F-B: −44.5 p: <0.05 Grp1-Grp2: 17.8 | Grp1 B: 67.7 (11.5) F: 67 (11.4) F-B: −0.7 Grp2 B: 65.7 (9.1) F: 67.5 (9.2) F-B: 1.8 p: <0.05 Grp1-Grp2: −2.5
Derosa, 2004^60^ | Grp1: Metformin Varied Start: 1000 mg, Max: 1000 mg tid Grp2: Glimepiride Varied Start: 1 mg, Max: 2 mg bid | Grp1 B: 8.4 (1.0) F: 7 (0.9) F-B: −1.4 (CI: −5.7, −0.51) p: 0.01 Grp2 B: 8.5 (1.2) F: 6.9 (0.7) F-B: −1.6 (CI: −6.4, −0.47) p: 0.01 Grp1-Grp2: 0.2 | Grp1 B: 144 (20) F: 130 (25) F-B: −14 (CI: −42, −8) Grp2 B: 135 (20) F: 130 (15) F-B: −5 (CI: 2.8, 9.6) Grp1-Grp2: −9 p: <0.05 | Grp1 B: 43 (5) F: 45 (4) F-B: 2 p: NSG Grp2 B: 42 (4) F: 44 (6) F-B: 2 p: NSG Grp1-Grp2: 0 | Grp1 B: 180 (25) F: 165 (25) F-B: −15 p: NSG Grp2 B: 160 (20) F: 145 (25) F-B: −15 p: NSG Grp1-Grp2: 0
Garber, 2003^61^ | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glyburide Varied Start: 2.5 mg, Max: 10 mg | Grp1 B: 8.42 (1.4) F: 7.01 F-B: −1.53 Grp2 B: 8.67 (1.4) F: 6.75 F-B: −1.9 Grp1-Grp2: 0.37 | Grp1 B: 122.7 (3.2) F: 117 F-B: −5.7 p:<0.05 Grp2 B: 122.2 (3.2) F: 124.5 F-B: 2.3 p: NSG Grp1-Grp2: −8 | Grp1 B: 42.3 (0.9) F: 41.9 F-B: −0.4 p: NSG Grp2 B: 41.6 (1) F: 42.1 F-B: 0.5 p: NSG Grp1-Grp2: −0.9 | Grp1 B: 256.8 (26.7) F: 217.2 F-B: −39.6 p: NSG Grp2 B: 236.3 (19.1) F: 221.2 F-B: −15.1 p: NSG Grp1-Grp2: −24.5 | Grp1 B: 92.8 (15.6) F: 91.7 F-B: −1.1 p: <0.001 Grp2 B: 91 (16.0) F: 93 F-B: 2 p: NSG Grp1-Grp2: −3.1
Tosi, 2003^36^ | Grp1: Metformin Varied Start: 500 mg, Max: 3000 mg Grp2: Glibenclamide Varied Start: 5 mg, Max: 15 mg | Grp1 B: 7.7 (1.4) F: 7.3 F-B: −0.4 Grp2 B: 7.85 (1.4) F: 7.4 F-B: −0.45 Grp1-Grp2: 0.05
Goldstein, 2003^62^ | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glipizide Fixed Start: 15 mg bid | Grp1 B: 8.6 (1.2) F: 8.4 (0.1) F-B: −0.2 Grp2 B: 8.9 (1.1) F: 8.5 (0.1) F-B: −0.4 Grp1-Grp2: 0.2 | Grp1 B: 109.7 (35.2) F: 102.5 F-B: −7.2 (CI: −15, 0.6) Grp2 B: 111.2 (34.6) F: 110.8 F-B: −0.4 (CI: −6.7, 5.8) Grp1-Grp2: −6.8 | Grp1 B: 42.3 (9.7) F: 42.7 F-B: 0.4 p: NSG Grp2 B: 43.5 (9.8) F: 43.9 F-B: 0.4 p: NSG Grp1-Grp2: 0 | Grp1 B: 218.7 (120.2) F: 217.1 F-B: −1.6 (−25.3 to 22) Grp2 B: 213.8 (127.2) F: 273.6 F-B: 59.8 (22.5 to 97.1) p: <0.05 Grp1-Grp2: −60.4 | Grp1 B: 94.2 (16.7 F: 91.5 F-B: −2.7 (SE: 0.3) Grp2 B: 90 (17.4) F: 89.6 F-B: −0.4 (SE: 0.3) Grp1-Grp2: −2.3
Blonde, 2002^63^ | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glyburide Fixed Start: 10 mg bid | Grp1 B: 9.51 (1.34) F: 9.7 F-B: 0.39 Grp2 B: 9.64 (1.44) F: 9.5 F-B: −0.11 Grp1-Grp2: 0.5 | | Grp1-Grp2: p: NSG | Grp1 F-B: p: NSG Grp2 F-B: p: NSG | Grp1 B: 89.5 (16.9) F: 87.5 F-B: −2 Grp2 B: 88 (15.9) F: 88.5 F-B: 0.5 Grp1-Grp2: −2.5
Marre, 2002^64^ | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glibenclamide Varied Start: 5 mg, Max: 20 mg | Grp1 B: 8.09 (1.84) F: 7.89 F-B: −0.2 Grp2 B: 7.88 (1.65) F: 7.58 F-B: −0.3 Grp1-Grp2: 0.1 p: NSG | Grp1 B: 148.2 (SE: 39) F: 136.5 F-B: −11.7 (SE: 31.2) Grp2 B: 152.1 (SE: 42.9) F: 148.2 F-B: −3.9 (SE: 39) Grp1-Grp2: −7.8 p: NSG | Grp1 B: 46.8 (11.7) F: 47.97 F-B: 1.17 p: NSG Grp2 B: 46.8 (11.7) F: 47.19 F-B: 0.39 p: NSG Grp1-Grp2: 0.78 | Grp1 B: 204.7 (169.1) F: 186.9 F-B: −17.8 (89) Grp2 B: 204.7 (151.3) F: 204.7 (133.5) F-B: 0 Grp1-Grp2: −17.8 p: NSG | Grp1 B: 84.9 (17.6) F: 84.1 F-B: −0.8 Grp2 B: 82.5 (15.4) F: 83.4 F-B: 0.9 Grp1-Grp2: −1.7
Garber, 2002^65^ | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glyburide Varied Start: 2.5 mg, Max: 10 mg | Grp1 B: 8.26 (1.08) F: 7.23 F-B: −1.03 Grp2 B: 8.21 (1.09) F: 6.97 F-B: −1.24 Grp1-Grp2: 0.21 | | | | Grp1 F-B: −0.6 p: <0.05 Grp2 F-B: 1.7 Grp1-Grp2: −2.3
Amador-Licona, 2000^66^ | Grp1: Metformin Varied Start: 850 mg, Max: NR Grp2: Glibenclamide Varied Start: 5 mg, Max: NR | Grp1 B: 8.5 (1.5) F: 7.6 (0.8) F-B: −0.9 p: 0.003 Grp2 B: 8.4 (1.4) F: 7.6 (0.8) F-B: −0.8 p: 0.009 Grp1-Grp2: −0.1 | | Grp1 B: 31.98 (8.97) F: 35.49 (8.97) F-B: 3.51 p: 0.0001 Grp2 B: 36.66 (7.02) F: 39 (10.92) F-B: 2.34 p: 0.01 Grp1-Grp2: 1.17 | Grp1 B: 195.8 (81.88) F: 178 (65.86) F-B: −17.8 p: 0.04 Grp2 B: 174.44 (81.88) F: 166.43 (97.9) F-B: −8.01 p: 0.67 Grp1-Grp2: −10.68 | Grp1 B: 70.7 (14.8) F: 69.6 (14.3) F-B: −0.9 p: 0.07 Grp2 B: 73.2 (11.8) F: 74.1 (12.6) F-B: 0.9 p: 0.1 Grp1-Grp2: −1.7
Campbell, 1994^67^ | Grp1: Metformin Varied Start: 500 mg bid, Max: 3000 mg Grp2: Glipizide Varied Start: 5 mg, Max: 30 mg | Grp1 B: 11.46 (1.92) F: 8.64 (1.21) F-B: −2.57 Grp2 B: 11.75 (2.11) F: 9.72 (1.91) F-B: −1.93 Grp1-Grp2: −0.64 p: <0.05 | Grp1 B: 4.65 (1.07) F: 4.58 (1.19) F-B: −0.07 Grp2 B: 4.51 (1.26) F: 4.99 (1.16) F-B: 0.48 Grp1-Grp2: −0.55 p: NSG | Grp1 B: 35.88 (11.31) F: 37.05 (11.31) F-B: 1.17 Grp2 B: 36.27 (8.58) F: 36.27 (8.58) F-B: 0 Grp1-Grp2: 1.17 p: NSG | Grp1 B: 191.35 (130.83) F: 202.92 (163.76) F-B: 11.57 p: NSG Grp2 B: 183.34 (61.41) F: 205.59 (108.58) F-B: 22.25 Grp1-Grp2: −10.68 | Grp1 B: 78.2 (15.7) F: 76.23 F-B: −1.97 Grp2 B: 82.2 (16.8) F: 84.8 F-B: 2.67 Grp1-Grp2: −4.57 p: <0.001
Hermann, 1994^68^ | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Glyburide Varied Start: 3.5 mg, Max: 10.5 mg | Grp1 B: 6.9 (SE: 0.3) F: 5.8 (SE: 0.2) F-B: −0.9 (SE: 0.2) p: 0.001 Grp2 B: 6.7 (SE: 0.3) F: 5.3 (SE: 0.1) F-B: −1.3 (SE: 0.2) p: 0.001 Grp1-Grp2: 0.4 | Grp1 B: 142.74 (SE: 9.75) F: 131.82 (SE: 8.97) F-B: −5.85 (SE: 2.73) p: 0.052 Grp2 B: 153.27 (SE: 5.46) F: 157.56 (SE: 5.07) F-B: 4.68 (SE: 3.51) p: >0.1 Grp1-Grp2: −10.53 | Grp1 B: 31.59 (SE: 2.34) F: 30.03 (SE: 1.56) F-B: −0.78 (SE: 0.78) p: >0.1 Grp2 B: 34.71 (SE: 1.95) F: 35.88 (SE: 1.95) F-B: 1.17 (SE: 0.78) p: >0.1 Grp1-Grp2: −0.39 | Grp1 B: 179.78 (SE: 18.69) F: 173.55 (SE: 14.24) F-B: −6.23 (SE: 12.46) Grp2 B: 178.89 (SE: 32.93) F: 186.9 (SE: 31.15) F-B: 8.01 (SE: 11.57) Grp1-Grp2: −14.24 p: >0.1 | Grp1 B: 78.6 (SE: 2.9) F: 78.8 (SE: 2.9) F-B: −0.8 (SE: 0.5) p: >0.1 Grp2 B: 82.6 (SE: 2.7) F: 86.2 (SE: 3.3) F-B: 2.8 (SE: 0.7) p: 0.001 Grp1-Grp2: −3.6
Hermann, 1991^69^ | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Glibenclamide Varied Start: 3.5 mg, Max: 10.5 mg | Grp1 B: 6.7 (1.3) F: 5.8 (0.7) F-B: −0.9 p: <0.01 Grp2 B: 6.6 (1.3) F: 5.3 (0.5) F-B: −1.3 p: <0.001 Grp1-Grp2: 0.4 | Grp1 F-B: 0.78 (SE: 3.9) Grp2 F-B: 5.07 (SE: 7.41) Grp1-Grp2: −5.85 | | | Grp1 B: 76.5 (11.5) F: 76.1 (11.1) F-B: −0.4 p: NSG Grp2 B: 84.1 (13.2) F: 87.4 (14.8) F-B: 3.3 p: <0.01 Grp1-Grp2: 3.7
DeFronzo, 1995^70^ | Grp1: Metformin Varied Start: 500 mg, Max: 2500 mg Grp2: Glyburide Varied Start: 5 mg bid, Max: 10 mg bid | Grp1 B: 8.9 F: 8.5 F-B: −0.4 (SE: 0.1) Grp2 B: 8.5 F: 8.7 F-B: 0.2 (SE: 0.1) Grp1-Grp2: −0.6 p: <0.001 | Grp1 B: 134 (SE: 3) F: 129 (SE: 3) F-B: −6 (SE: 2) Grp2 B: 136 (SE: 3) F: 141 (SE: 3) F-B: 5 (SE: 2) Grp1-Grp2: −11 p: 0.009 | Grp1 B: 37 (SE: 1) F: 38 (SE: 1) F-B: 1 Grp2 B: 39 (SE: 1) F: 40 (SE: 1) F-B: 0 Grp1-Grp2: 1 (SE: 1.41) | Grp1 B: 231 (SE: 12) F: 221 (SE: 13) F-B: −16 (SE: 7) Grp2 B: 210 (SE: 8) F: 227 (SE: 11) F-B: 21 (SE: 9) Grp1-Grp2: −37 p: 0.001 | Grp1 B: 92.6 (14.5) F: 87.8 F-B: −3.8 (SE: 0.2) p: <0.001 Grp2 F-B: −0.3 (SE: 0.2) p: NSG Grp1-Grp2: −3.5
Charpentier, 2001^71^ | Grp1: Metformin Fixed Start: 850 mg tid Grp2: Glimepiride Varied Start: 1 mg, Max: 6 mg | Grp1 B: 6.79 (1.17) F: 6.86 (1.45) F-B: 0.07 (SE: 0.14) Grp2 B: 6.52 (1.13) F: 6.79 (1.43) F-B: 0.27 (SE: 0.09) Grp1-Grp2: −0.12 p: 0.369 | | Grp1 B: 46.41 (13.65) F: 48.36 F-B: 1.95 Grp2 B: 45.24 (12.87) F: 45.63 F-B: 0.39 Grp1-Grp2: 1.56 p: 0.14 across all treatment groups | Grp1 B: 171.77 (119.26) F: 185.12 F-B: 13.35 (104.13) Grp2 B: 189.57 (143.29) F: 200.25 F-B: 10.68 (108.58) Grp1-Grp2: 2.67 p: 0.029 across all treatment groups | Grp1 B: 82.2 F: 81.46 F-B: −0.74 (2.58) Grp2 B: 81 F: 81.78 F-B: 0.78 (2.98) Grp1-Grp2: −1.52
Metformin versus DPP-IV inhibitors
Jadzinsky, 2009^78^ | Grp1: Metformin Varied Start: 500 mg, Max: 1000 mg D: 1 Weeks Grp2: Saxagliptin Fixed | Grp1 F-B: −2 p: <0.0001 Grp2 F-B: −1.7 Grp1-Grp2: −0.3 | Grp1 B: 126.7 F: 118.5 F-B: −4 (SE: 1.44) (CI: −6.8, −1.1) Grp2 B: 125.8 F: 121.7 F-B: −0.5 (SE: 1.48) (CI: −3.4, −2.4) Grp1-Grp2: −3.5 | Grp1 B: 43.6 (SE: 0.66) F: 46.6 (SE: 0.71) F-B: 8.9 (SE: 1.36) (CI: 6.2, 11.5) Grp2 B: 43.4 (SE: 0.63) F: 44.4 (SE: 0.67) F-B: 3.9 (SE: 1.19) (CI: 1.6, 6.3) Grp1-Grp2: −3.5 | Grp1 B: 228.1 (SE: 13.92) F: 207.2 (SE: 14.71) F-B: −1.5 (SE: 2.72) (CI: −6.8, 3.9) Grp2 B: 213.2 (SE: 9.91) F: 180 (SE: 7.06) F-B: −3 (SE: 2.93) (CI: −8.8, 2.8) Grp1-Grp2: 1.5 | Grp1 F-B: −1.6 Grp2 F-B: −1.1 Grp1-Grp2: −0.5
Aschner, 2010^77^ | Grp1: Metformin Varied, prespecified target dose Start: 500 mg, Max: 2000 mg, Mean: 1903 D: 5 Weeks Grp2: Sitagliptin Fixed Mean: 100 mg | Grp1 F-B: −0.55 (CI: −0.61, −0.5) Grp2 F-B: −0.38 (CI: −0.43, −0.32) Grp1-Grp2: −0.18 (CI: −0.25, −0.1) | Grp1 F-B: 2.5 (CI: −0.8, 5.8) Grp2 F-B: 11.2 (CI: 8, 14.5) Grp1-Grp2: −8.7 (CI: 4.1, 13.3) | Grp1 F-B: 7 (CI: 5.4, 8.6) Grp2 F-B: 6.2 (CI: 4.7, 7.8) Grp1-Grp2: 0.8 (CI: −1.4, 3) | Grp1 F-B: −1.2 (CI: −5.2, 2.7) Grp2 F-B: −3.7 (CI: −7.2, −0.2) Grp1-Grp2: 3.8 (CI: −0.5, 8.2) | Grp1 F-B: −1.9 (CI: −2.2, −1.7) Grp2 F-B: −0.6 (CI: −0.9, −0.4) Grp1-Grp2: −1.3 p: <0.001
Williams-Herman, 2009^76^ | Grp1: Metformin Fixed Mean: 2000 mg Grp2: Sitagliptin Fixed Mean: 100 mg | Grp1 F-B: −1.3 (CI: −1.5, −1.2) Grp2 F-B: −0.8 (CI: −1, −0.6) Grp1-Grp2: −0.5 | Grp1 B: 105.3 (32.3) F: 102.3 (33.6) F-B: −3 Grp2 B: 115.1 (35.1) F: 113.5 (34.5) F-B: −1.6 Grp1-Grp2: −1.4 (SE: 8.25) | Grp1 B: 43.2 (9.4) F: 44.6 (10.4) F-B: 1.4 Grp2 B: 42.7 (9.5) F: 43.2 (10.1) F-B: 0.5 Grp1-Grp2: 0.9 (SE: 1.94) | Grp1 B: Median: 172 (113.5) F: Median: 179 (107) Grp2 B: Median: 149 (97.7) F: Median: 155 (113.5) | Grp1 F-B: −1.5 (CI: −2.2, −0.8) Grp2 F-B: 0.6 (CI: −0.2, 1.4)
Williams-Herman, 2009^76^ | Grp1: Metformin Fixed Mean: 1000 mg Grp2: Sitagliptin Fixed Mean: 100 mg | Grp1 F-B: −1 (CI: −1.2, −0.8) Grp2 F-B: −0.8 (CI: −1, −0.6) Grp1-Grp2: −0.2 | Grp1 B: 106.8 (34.2) F: 103.6 (31.5) F-B: −3.2 Grp2 B: 111.4 (35.1) F: 113 (35.3) F-B: 1.6 Grp1-Grp2: −4.8 (SE: 6.73) | Grp1 B: 42.7 (10.5) F: 45 (12.4) F-B: 2.3 Grp2 B: 42.7 (9.5) F: 43.2 (10.1) F-B: 0.5 Grp1-Grp2: 1.8 (SE: 2.09) | Grp1 B: Median: 167 (104.2) F: Median: 173 (120) Grp2 B: Median 147.5 (87.4 F: Median: 162.5 (94) | Grp1 F-B: −1 (CI: −1.7, −0.3) Grp2 F-B: 0.6 (CI: −0.2, 1.4)
Goldstein, 2007^75^ | Grp1: Metformin Varied, prespecified target dose Start: 500 mg, Max: 2000 mg D: 3 wks Grp2: Sitagliptin Varied, prespecified target dose Start: 50 mg, Max: 100 mg D: 1 wk | Grp1 F-B: −1.13 (CI: −1.29, −0.97) Grp2 F-B: −0.66 (CI: −0.83, −0.5) Grp1-Grp2: −0.47 | | | | Grp1 F-B: significant reduction relative to baseline Grp2 F-B: 0
Goldstein, 2007^75^ | Grp1: Metformin Varied, prespecified target dose Start: 500 mg, Max: 100 mg D: 1 wk Grp2: Sitagliptin Varied, prespecified target dose Start: 50 mg, Max: 100 mg D: 1 wk | Grp1 F-B: −0.82 (CI: −0.98, −0.66) Grp2 F-B: −0.66 (CI: −0.83, −0.5) Grp1-Grp2: −0.16 | | | | Grp1 F-B: significant reduction relative to baseline Grp2 F-B: 0
Metformin versus meglitinides
Lund, 2007^197^ | Grp1: Metformin Varied, prespecified target dose Start: 500 mg, Max: 2000 mg, Mean: 1629 mg D: 12 dys Grp2: Repaglinide Varied, prespecified target dose Start: 1 mg, Max: 6 mg, Mean: 4.72 mg D: 12 dys | | | | | Grp1 B: 74.81 (10.1) F: 73.94 (9.88) F-B: −0.88 (CI: −1.45, −0.3) Grp2 B: 75.57 (9.85) F: 75.47 (10.08) F-B: 0.7 (CI: 0.12, 1.28) Grp1-Grp2: −1.58 (CI: −2.17, −0.99) p: <0.001
Horton, 2004^80^ | Grp1: Metformin Fixed Start: 500 mg tid Grp2: Nateglinide Fixed Start: 120 mg qac | Grp1 F-B: −0.8 (SE: 0.1) p: <0.001 Grp2 F-B: −0.8 (SE: 0.1) p: <0.001 Grp1-Grp2: −0.8 (SE: 0.1) p: <0.005
Moses, 1999^82^ | Grp1: Metformin NR Grp2: Repaglinide Fixed Start: 0.5 mg, Max: 4.0 mg D: 12 to 28 days | Grp1 F-B: −0.33 (SE: 0.24; CI: −0.8, −0.5) Grp2 F-B: −0.38 (SE: 0.23; CI: −0.84, −0.08) Grp1-Grp2: 0.05 (SE: 0.33) | | | | Grp1 F-B: −0.86 (SE: 0.5) Grp2 F-B: 2.98 (SE: 0.49) p: <0.05 Grp1-Grp2: −3.84
Derosa, 2003^81^ | Grp1: Metformin Varied Start: 500 mg bid, Max: 2500 mg Grp2: Repaglinide Varied Start: 0.5 mg bid, Max: 4 mg | Grp1 B: 7.4 (0.9) F: 6.5 F-B: −0.9 p: <0.01 Grp2 B: 7.6 (0.9) F: 6.8 F-B: −0.8 p: <0.01 Grp1-Grp2: −0.1 p: NSG | Grp1 B: 132.21 (26.13) F: 117 F-B: −15.21 (CI: −34.32 to −8.19) p: <0.05 Grp2 B:127.14 (25.35) F: 115.05 F-B: −12.09 (CI: −29.05 to 20.28) p: <0.065 Grp1-Grp2: −3.12 | Grp1 B: 46.41 (8.19) F: 45.224 F-B: −1.17 Grp2 B: 42.51 (7.02) F: 45.63 F-B: 3.12 Grp1-Grp2: −4.29 p: NSG | Grp1 B: 176.22 (4.806) F: 152.19 F-B: −24.03 (−55.18 to −15.13) p: <0.05 Grp2 B: 156.64 (52.51) F: 140.62 F-B: −16.02 (−38.27 to 17.8) p: 0.065 Grp1-Grp2: −8.01 | Grp1 B: 72.3 (7.1) F: 70.3 F-B: −2 (CI: −6, 4) p: 0.14 Grp2 B: 70.0 (6.5) F: 69.6 F-B: −0.4 (CI: −0.8, 0.28) p: >0.2 Grp1-Grp2: −1.6 p: NSG
Horton, 2000^79^ | Grp1: Metformin Fixed Start: 500 mg tid Grp2: Nateglinide Fixed Start: 120 mg tid | Grp1 B: 8.4 (1.2) F: 7.6 F-B: −0.8 (SE: 0.1) p: 0.0001 Grp2 B: 8.3 (1.0) F: 7.8 F-B: −0.5 (SE: 0.1) p: 0.0001 Grp1-Grp2: −0.3 p: NSG
Metformin versus metformin + thiazolidinedione
Perez, 2009^56^ | Grp1: Metformin Fixed Start: 850 mg Grp2: Metformin + pioglitazone Fixed | Grp1 F-B: −0.99 Grp2 F-B: −1.83 p: <0.0001 Grp1-Grp2: 0.84 (SE: 0.17) | | | | Grp1 F-B: −1.28 Grp2 F-B: 0.69 Grp1-Grp2: −1.97
Derosa, 2009^46^ | Grp1: Metformin Varied, prespecified target dose Start: 1000 mg, Max: 3000 mg D: 3 mos Grp2: Metformin + pioglitazone Varied, prespecified target dose Start: 850 mg, Max: 2550 mg; Start: 15 mg, Max: 45 mg D: 3 mos | Grp1 B: 9.1 (1.2) F: 7.9 (0.5) p: <0.01 F-B: −1.1 (0.5) p: <0.01 Grp2 B: 9.3 (1.4) F: 7.2 (0.3) p: >0.001 F-B: −2.1 (0.3) p: <0.01 Grp1-Grp2: 1.0 (SE: 0.27) | | | | BMI Grp1 B: 27.2 (1.5) F: 26.7 (1.2) F-B: −1.8% Grp2 B: 27.4 (1.6) F: 26.9 (1.3) F-B: −1.8% Grp1-Grp2: 0
Rosenstock, 2006^49^ | Grp1: Metformin Varied, mean daily glucose <= 6.1 mmol/l Start: 500 mg, Max: 2000 mg, Mean: 1847 D: 32 wks Grp2: Metformin + rosiglitazone Varied, mean daily glucose <= 6.1 mmol/l Start: 500 mg, Max: 2000 mg, Mean: 1799 mg; Start: 2 mg, Max: 8 mg, Mean: 7.2 mg D: 32 wks | Grp1 B: 8.8 (1.0) F: (1.0) F-B: −1.8 Grp2 B: 8.9 (1.1) F: 6.6 (1.0) F-B: −2.3 Grp1-Grp2: 0.5 (SE: 0.20) p: 0.008 | Grp1 B: 116 (CV: 33.9) F: 103.6 (CV: 35.5) F-B: −12.4 Grp2 B: 113.8 (CV: 32.5) F: 113.5 (CV: 30.4) F-B: −0.3 Grp1-Grp2: −12.1 (SE: 8.1) | Grp1 B: 42.9 (CV: 23.8) F: 43 (CV: 23) F-B: 0.1 Grp2 B: 42.6 (CV: 21.8) F: 45 (CV: 25.5) F-B: 2.4 Grp1-Grp2: −2.3 (SE: 2.25) | Grp1 B: 175.7 (CV: 62.3) F: 148.7 (CV: 58.3) F-B: −27 Grp2 B: 180.3 (CV: 67.7) F: 146.6 (CV: 68.6) F-B: −33.7 Grp1-Grp2: 6.7 | Grp1 F-B: Median: −2.2 (IQR: −5.5, −0.5) Grp2 F-B: Median: 0.05 (IQR: −3.45, 3)
Leiter, 2005^83^ | Grp1: Metformin Varied, glucose: <7.0 mmol/L Start: 1500 mg, Max: 2500 mg D: 8 wks Grp2: Metformin + rosiglitazone Fixed; Varied, glucose: < 7 mmol/L Start: 1500 mg, Max: 1500 mg; Start: 4 mg, Max: 8 mg D: 8 wks | Grp1 F-B: −0.14 p: 0.93 Grp2 F-B: p: <0.001 Grp1-Grp2: −0.36 CI: 0.15 −0.56 | | | | Grp1 F-B: no significant weight change Grp2 F-B: 1.6 (CI: 0.9, 2.3)
Kaku, 2009^84^ | Grp1: Metformin Varied Start: 500 mg, Max: 750 mg D: Unclear Grp2: Metformin + pioglitazone Varied Start: 500 mg, Max: 750 mg; Start: 15 mg, Max: 30 mg D: Unclear; 16 wks | Grp1 F-B: 0.25 (0.92) (CI: 0.06, 0.45) p: 0.012 Grp2 F-B: −0.67 (0.8) (CI: −0.84, −0.49) p: <0.0001 Grp1-Grp2: 0.92 (SE: 0.13) | Grp1 F-B: 0.9 (20; CI: −3.34, 5.23) p: 0.6632 Grp2 F-B: 3.5 (23.2; CI: −1.59, 8.62) p: 0.1746 Grp1-Grp2: −2.6 (SE: 3.4) | Grp1 F-B: −1.1 (8.5; CI: −2.96, 0.68) p: 0.2175 Grp2 F-B: 5.3 (8.1; CI: 3.52, 7.09) p: <0.0001 Grp1-Grp2: −6.4 (SE: 1.30) | Grp1 F-B: −15.4 (93.8) (CI: −35.5, 4.7) p: 0.1316 Grp2 F-B: −9.3 (76.3) (CI: −26.1, 7.4) p: 0.2714 Grp1-Grp2: −6.1 | Grp1 F-B: −0.47 Grp2 F-B: 1.68 Grp1-Grp2: −2.15
Scott, 2008^85^ | Grp1: Metformin Fixed Start: >1500 mg Grp2: Metformin + rosiglitazone Fixed Start: >1500 mg; Start: 8 mg, Mean: 8 mg | Grp1 B: 7.68 (0.88) F: 7.47 (1.05) F-B: −0.22 (CI: −0.36, −0.08) Grp2 B: 7.73 (0.88) F: 6.94 (0.75) F-B: −0.79 (CI: −0.92, −0.65) Grp1-Grp2: 0.57 (CI: 0.37, 0.76) | Grp1 B: 95.6 (30.8) F: 108.4 (33.6) F-B: mean % change: 16.7 (CI: 10.2, 23.3) Grp2 B: 99.2 (29.4) F: 119.6 (37.6) F-B: mean % change: 26.2 (CI: 19.7, 32.7) Grp1-Grp2: −7.6 (SE: 8.8) | Grp1 B: 43.5 (10.5) F: 44.1 (12.1) F-B: mean % change: 1.8 (CI: −1.3, 4.9) Grp2 B: 42.2 (10) F: 45.7 (10.5) F-B: mean % change: 9.2 (CI: 6.1, 12.2) Grp1-Grp2: −2.9 (SE: 2.89) | Grp1 B: 171.1 (73.3) F: 191.5 (111.1) F-B: mean % change from baseline: 11.9 (CI: 3.9, 19.9) Grp2 B: 201.6 (126.2) F: 199.8 (108.4) F-B: mean % change from baseline: 13.1 (CI: 5.2 −21.1) Grp1-Grp2: 1.2 (CI: −10.1, 12.6) | Grp1 F-B: −0.8 (CI: −1.2, −0.4) Grp2 F-B: 1.5 (CI: 1.0, 1.9) Grp2-Grp1: 2.3 (CI: 1.7, −2.9)
Stewart, 2006^156^ | Grp1: Metformin Varied, prespecified target dose Start: 500 mg, Max: 3000 mg, Mean: 2627.9 mg D: 20 wks Grp2: Metformin + rosiglitazone Varied, prespecified target dose Start: 500 mg, Max: 2000 mg, Mean: 1812.2 mg; Start: 4 mg, Max: 8 mg, Mean: 6.8 mg D: 18 wks | | Grp1 B: 122.46 (CV: 34.53) F: 113.88 (CV: 35.66) F-B: −8.58 Grp2 B: 122.85 (CV: 37.08) F: 128.31 (CV: 34.06) F-B: 5.46 Grp1-Grp2: −14.0 (SE: 8.1) | Grp1 B: 45.63 (CV: 24.3) F: 46.41 (CV: 25.01) F-B: 0.78 Grp2 B: 45.63 (CV: 23.03) F: 48.75 (CV: 27.97) F-B: 3.12 Grp1-Grp2: −2.34 (SE: 0.05) | Grp1 B: 177.1 (CV: 55.39) F: 161.98 (CV: 55.08) F-B: −15.1 Grp2 B: 170.88 (CV: 53.65) F: 170.88 (CV: 57.35) F-B: Grp1-Grp2: −15.1 (SE: 16.9)
Weissman, 2005^86^ | Grp1: Metformin Varied Start: 1000 mg, Max: 2000 mg Grp2: Metformin + rosiglitazone Fixed; Varied Start: 1000 mg; Start: 4 mg, Max: 8 mg | Grp1 B: 7.97 (1.2) F: 7.26 F-B: −0.71 Grp2 B: 8.05 (1.2) F: 7.12 F-B: −0.93 Grp1-Grp2: 0.2 | Grp1 B: 105.1 (CI: 103.4, 106.8) F: 101.6 (CI: 99.7, 103.6) F-B: −3.5 Grp2 B: 106.3 (CI: 104.5, 108.2) F: 118.5 (CI: 116.3, 120.7) F-B: 12.2 Grp1-Grp2: −15.7 | Grp1 B: 43.7 F: 45.3 F-B: 1.6 Grp2 B: 45 F: 49.1 F-B: 4.1 Grp1-Grp2: −2.5 | Grp1 B: 179.2 F: 176.8 (170.9 to 182.9) F-B: −2.4 p: NSG Grp2 B: 184.8 F: 196.6 (189.2 to 204.2) p: NSG F-B: 11.8 Grp1-Grp2: −14.2
Bailey, 2005^87^ | Grp1: Metformin Varied Start: 2500 mg, Max: 3000 mg Grp2: Metformin + rosiglitazone Fixed; Varied Start: 2000 mg; Start: 4 mg, Max: 8 mg | Grp1 B: 7.5 (1.0) F: 7.4 (1.1) F-B: −0.13 Grp2 B: 7.4 (1.0) F: 7.1 (1.1) F-B: −0.33 Grp1-Grp2: 0.22 p: 0.001 | Grp1 B: 111.9 (CI: 109.7, 114.1) F: 114.9 (CI: 112.6, 117.2) F-B: 3 Grp2 B: 109.5 (CI: 107.1, 111.8) F: 125.9 (CI: 122.9, 128.9) F-B: 16.4 Grp1-Grp2: −13.4 | Grp1 B: 47.2 F: 46.4 F-B: −0.8 p: <0.05 Grp2 B: 45.3 F: 47.1 F-B: 1.8 p: <0.05 Grp1-Grp2: −2.6 | Grp1 B: 180.8 (175.5 to 186.3) F: 167.5 (161.8 to 173.4) p: <0.05 F-B: −13.3 Grp2 B: 189.3 (183.5 to 195.2) F: 189.4 (183.1 to 195.9) p: NSG F-B: 0.1 Grp1-Grp2: −13.4 | Grp1 B: 89.5 (14.4) F: 88.6 F-B: −0.9 (SE: 0.2) Grp2 B: 90.9 (15.6) F: 92.2 F-B: 1.3 (SE: 0.22) Grp1-Grp2: −2.2
Gomez-Perez, 2002^88^ | Grp1: Metformin Fixed Start: 2500 mg Grp2: Metformin + rosiglitazone Fixed Start: 2500 mg; Start: 2 mg bid | Grp1 B: 9.8 (SE: 0.3) F: 10.2 (SE: 0.3) F-B: 0.3 p: 0.2651 Grp2 B: 10.2 (SE: 0.2) F: 9.5 (SE: 0.3) F-B: −0.7 p: 0.052 Grp1-Grp2: 1 p: 0.0132 | Grp1 B: 116 (27.7) F: 115 F-B: −1 (20.9) Grp2 B: 106.9 (25.7) F: 123.5 F-B: 16.6 (24.7) Grp1-Grp2: −15.9 (CI: −4.73, −27) | Grp1 B: 49.4 (11.9) F: 48.9 F-B: −0.5 (7.2) Grp2 B: 51.5 (10) F: 56.7 F-B: 5.2 (7) Grp1-Grp2: −5.7 p: <0.05 | Grp1 B: 227.2 (126.8) F: 233.4 F-B: 6.2 Grp2 B: 204.4 (113.3) F: 199.9 F-B: −4.5 Grp1-Grp2: 10.7
Gomez-Perez, 2002^88^ | Grp1: Metformin Fixed Start: 2500 mg Grp2: Metformin + rosiglitazone Fixed Start: 2500 mg; Start: 4 mg bid | Grp1 B: 9.8 (SE: 0.3) F: 10.2 (SE: 0.3) F-B: 0.3 p: 0.2651 Grp2 B: 9.75 (SE: 0.2) F: 8.6 (SE: 0.4) F-B: −1.2 p: 0.008 Grp1-Grp2: 1.5 p: 0.0002 | Grp1 B: 116 (27.7) F: 115 F-B: −1 (20.9) Grp2 B: 108.2 (30) F: 114.3 F-B: 6.1 (22.5) Grp1-Grp2: −7.1 p: NSG | Grp1 B: 49.4 (11.9) F: 48.9 F-B: −0.5 (7.2) Grp2 B: 51.5 (10.9) F: 57.9 F-B: 6.4 (7) Grp1-Grp2: −6.9 p: <0.05 | Grp1 B: 227.2 (126.8) F: 233.4 F-B: 6.2 Grp2 B: 199.6 (133.2) F: 193.8 F-B: −5.8 Grp1-Grp2: 12
Einhorn, 2000^89^ | Grp1: Metformin NR Grp2: Metformin + pioglitazone NR; Fixed NR; Start: 30 mg | Grp1 B: 9.75 (SE: 1.3) F-B: p: <0.05 Grp2 B: 9.86 (SE: 1.4) F-B: p: <0.05 Grp1-Grp2: −0.83 p: <0.05 | Grp1 B: 119.3 (3.07) F: 128.5 F-B: 7.7% p: <0.05 Grp2 B: 118 (6.9) F: 132 F-B: 11.9% Grp1-Grp2: 4.20% | Grp1 B: 42.9 (0.95) F: 53.1 F-B: 10.2 Grp2 B: 42.1 (1) F: 43.6 F-B: 1.5 Grp1-Grp2: 8.7 p: ≤0.05 | Grp1 B: 298.9 (24.9) F: 289.2 F-B: −9.7 Grp2 B: 300.4 (25.86) F: 308.9 F-B: 8.5 Grp1-Grp2: −18.2 p: 0.05 | Grp1 F-B: −1.36 Grp2 F-B: 0.95 Grp1-Grp2: −2.31
Fonseca, 2000^90^ | Grp1: Metformin Fixed Start: 2500 mg Grp2: Metformin + rosiglitazone Fixed Start: 2500 mg; Start: 8 mg | Grp1 B: 8.6 (1.3) F: 9.05 F-B: 0.45 Grp2 B: 8.9 (1.5) F: 8.12 F-B: −0.78 Grp1-Grp2: 1.2 p: <0.001 | Grp1 B: 118.17 (34.32) F: 122.07 (37.83) F-B: 3.9 Grp2 B: 116.61 (30.42) F: 134.94 (33.54) F-B: 18.33 Grp1-Grp2: −14.04 | Grp1 B: 44.46 (10.92) F: 46.8 (11.31) F-B: 2.34 Grp2 B: 46.8 (14.43) F: 53.04 (16.38) F-B: 6.24 Grp1-Grp2: −3.9 p: 0.0002 | Grp1 B: 246.53 (194.91) F: 247.42 (159.31) F-B: 0.89 Grp2 B: 228.73 (184.23) F: 228.73 (166.43) F-B: 0 Grp1-Grp2: 0.89 p: 0.56 | Grp1 F-B: −1.2 Grp2 F-B: 0.7 Grp1-Grp2: −1.9 p: 0.0001
Fonseca, 2000^90^ | Grp1: Metformin Fixed Start: 2500 mg Grp2: Metformin + rosiglitazone Fixed Start: 2500 mg; Start: 4 mg | Grp1 B: 8.6 (1.3) F: 9.05 F-B: 0.45 Grp2 B: 8.9 (1.3) F: 8.34 F-B: −0.56 Grp1-Grp2: −1 p: <0.001 | Grp1 B: 118.17 (34.32) F: 122.07 (37.83) F-B: 3.9 Grp2 B: 113.49 (32.76) F: 134.55 (40.56) F-B: 21.06 Grp1-Grp2: −17.16 p: <0.0001 | Grp1 B: 44.4 (10.92) F: 46.8 (11.31) F-B: 2.4 Grp2 B: 46.02 (11.31) F: 51.48 (13.26) F-B: 5.46 Grp1-Grp2: −3.06 p: 0.0002 | Grp1 B: 246.53 (194.91) F: 247.42 (159.31) F-B: 0.89 Grp2 B: 226.06 (138.84) F: 233.18 (139.73) F-B: 7.12 Grp1-Grp2: −6.23 p: 0.73 | Grp1 F-B: −1.2 Grp2 F-B: 1.9 Grp1-Grp2: −3.1 p: 0.0001
Metformin versus metformin + sulfonylurea
Derosa, 2009^46^ | Grp1: Metformin Varied, prespecified target dose Start: 1000 mg, Max: 3000 mg D: 3 mos Grp2: Metformin + glimepiride Fixed Start: 850 mg, Max: 850 mg; Start: 2 mg, Max: 6 mg D: NR; 3 mos | Grp1 B: 9.1 (1.2) F: 7.9 (0.5) F-B: −1.1 (0.5) p: <0.01 Grp2 B: 9 (1.1) F: 7.8 (0.4) F-B: −1.2 (0.4) p: <0.01 Grp1-Grp2: 0.1 (SE: 0.29) | | | | BMI Grp1 B: 27.2 (1.5) F: 26.7 (1.2) F-B: −1.8% Grp2 B: 27.1 (1.4) F: 28.4 (2.2) F-B: 4.8% p: <0.05 Grp1-Grp2: −1.8
Nauck, 2009^92^ | Grp1: Metformin Varied Start: 2000 mg, Max: 2000 mg Grp2: Metformin + glimepiride Varied; Fixed Start: 2000 mg, Max: 2000 mg; Start: 1 mg, Max: 4 mg D: NR; 3 wks | Grp1 F-B: 0.1 (SE: 0.1) Grp2 F-B: −1 (SE: 0.1) Grp1-Grp2: 1.1 (SE: 0.14) | | | | Grp1 F-B: −1.5 (SE: 0.3) Grp2 F-B: 1 (SE: 0.2) Grp1-Grp2: −2.5
Chien, 2007^59^ | Grp1: Metformin Varied, glucose: <140 mg/dL Start: 1000 mg, Max: 2000 mg, Final mean: 1910 mg D: 4 wks Grp2: Metformin + glyburide Varied, glucose: <140 mg/dL Start: 1000 mg, Max: 2000 mg, Final mean: 1723 mg; Start: 10 mg, Max: 20 mg, Final mean: 17.2 mg D: 4 wks | Grp1-Grp2: −1.3 p: 0.005
Chien, 2007^59^ | Grp1: Metformin Varied, glucose: <140 mg/dL Start: 1000 mg, Max: 2000 mg, Final mean: 1910 mg D: 4 wks Grp2: Metformin + glyburide Varied, glucose: <140 mg/dL Start: 1000 mg, Max: 2000 mg, Final mean: 1680 mg; Start: 5mg, Max: 10 mg, Final mean: 8.4 mg D: 4 wks | Grp1-Grp2: −1.34 p: 0.002
Feinglos, 2005^91^ | Grp1: Metformin Fixed Start: at least 1000 mg Grp2: Metformin + glipizide Fixed Start: at least 1000 mg; Start: 2.5 mg | Grp1 B: 7.64 F: 7.46 (SE: 0.1) F-B: −0.19 Grp2 B: 7.45 F: 6.8 (SE: 0.1) F-B: −0.66 Grp1-Grp2: 0.47 p: <0.0002 | | Grp1 F-B: p: NSG Grp2 F-B: p: NSG | Grp1 F-B: p: NSG Grp2 F-B: p: NSG | Grp1 B: 90.8 (18.4) F: 89.1 F-B: −1.7 Grp2 B: 90 (18.7) F: 90.4 F-B: 0.4 Grp1-Grp2: −2.1 p: < 0.0001
Garber, 2003^61^ | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 250 mg, Max: 1000 mg; Start: 1.25 mg, Max: 5 mg | Grp1 B: 8.42 (1.4) F: 7.01 F-B: −1.53 Grp2 B: 8.78 (1.5) F: 6.43 F-B: −2.27 Grp1-Grp2: −0.74 p: 0.0003 | Grp1 B: 122.7 (3.2) F: 115 F-B: −5.7 p:<0.05 Grp2 B: 118.3 (3.5) F: 122.8 F-B: 4.5 p:<0.05 Grp1-Grp2: −10.2 | Grp1 B: 42.3 (0.9) F: 41.9 F-B: −0.4 p: NSG Grp2 B: 41.3 (0.9) F: 42.1 F-B: 0.8 p: NSG Grp1-Grp2: −1.2 | Grp1 B: 256.8 (26.7) F: 217.2 F-B: −39.6 p: NSG Grp2 B: 248.4 (26.2) F: 196.4 F-B: −52 p: <0.05 Grp1-Grp2: 12.4 | Grp1 B: 92.8 (15.6) F: 91.7 F-B: −1.1 p: <0.001 Grp2 B: 91.9 (17.4) F: 93.5 F-B: 1.6 p: NSG Grp1-Grp2: −2.7
Tosi, 2003^36^ | Grp1: Metformin Varied Start: 500 mg, Max: 3000 mg Grp2: Metformin + glibenclamide Varied Start: 400 mg, Max: 2400 mg; Start: 2.5 mg, Max: 15 mg | Grp1 B: 7.8 (1.4) F: 7.3 F-B: −0.5 Grp2 B: 7.8 (1.0) F: 5.9 F-B: −1.9 Grp1-Grp2: 1.4
Goldstein, 2003^62^ | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glipizide Varied Start: 500 mg, Max: 2000 mg; Start: 5 mg, Max: 20 mg | Grp1 B: 8.6 (1.2) F: 8.4 (0.1) F-B: −0.2 Grp2 B: 8.7 (1.2) F: 7.4 (0.1) F-B: −1.3 Grp1-Grp2: 1.06 p: <0.001 | Grp1 B: 109.7 (35.2) F: 102.5 F-B: −7.2 (CI: −15, 0.6) Grp2 B: 119.7 (29.5) F: 119.5 F-B: −0.2 (CI: − 6.7, 6.3) Grp1-Grp2: −7 | Grp1 B: 42.3 (9.7) F: 42.7 F-B: 0.4 p: NSG Grp2 B: 43.2 (10.0) F: 44.1 F-B: 0.9 p: NSG Grp1-Grp2: −0.5 | Grp1 B: 218.7 (120.2) F: 217.1 F-B: −1.6 (−25.3 to 22) p: NSG Grp2 B: 237.5 (192.2) F: 256 F-B: 18.5 (−16.8 to 53.7) p: NSG Grp1-Grp2: −20.1 | Grp1 B: 94.2 (16.7) F: 91.5 F-B: −2.7 (SE: 0.3) Grp2 B: 95.1 (17.8) F: 94.8 F-B: −0.3 (SE: 0.3) Grp1-Grp2: −2.4 p: <0.001
Blonde, 2002^63^ | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 2000 mg; Start: 5 mg, Max: 20 mg | Grp1 B: 9.51 (1.34) F: 9.7 F-B: 0.39 Grp2 B: 9.42 (1.24) F: 7.9 F-B: −1.38 Grp1-Grp2: 1.77 p: <0.001 | Grp1-Grp2: p: NSG | Grp1-Grp2: p: NSG | Grp1-Grp2: p: NSG
Blonde, 2002^63^ | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 2000 mg; Start: 2.5 mg, Max: 10 mg | Grp1 B: 9.51 (1.34) F: 9.7 F-B: 0.39 Grp2 B: 9.41 (1.47) F: 7.9 F-B: −1.64 Grp1-Grp2: 2.03 p: <0.001 | Grp1-Grp2: p: NSG | Grp1-Grp2: p: NSG | Grp1-Grp2: p: NSG
Marre, 2002^64^ | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glibenclamide Varied Start: 500 mg, Max: 2000 mg; Start: 2.5 mg, Max: 10 mg | Grp1 B: 8.09 (1.84) F: 7.89 F-B: −0.2 Grp2 B: 7.89 (1.62) F: 6.69 F-B: −1.2 Grp1-Grp2: 1 p: <0.05 | Grp1 B: 148.2 (39) F: 136.5 F-B: −11.7 (31.2) p: NSG Grp2 B: 152.1 (42.9) F: 144.3 F-B: −7.8 (27.3) p: NSG Grp1-Grp2: −3.9 | Grp1 B: 46.8 (11.7) F: 47.97 F-B: 1.17 p: NSG Grp2 B: 46.8 (15.6) F: 47.19 F-B: 0.39 p: NSG Grp1-Grp2: 0.78 | Grp1 B: 204.7 (169.1) F: 186.9 F-B: −17.8 (89) Grp2 B: 213.6 (160.2) F: 195.8 F-B: −17.8 (151.3) Grp1-Grp2: 0 p: NSG | Grp1 B: 84.9 (17.6) F: 84.1 F-B: −0.8 Grp2 B: 84.7 (15.1) F: 85.3 F-B: 0.6 Grp1-Grp2: −1.4
Marre, 2002^64^ | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glibenclamide Varied Start: 500 mg, Max: 2000 mg; Start: 5 mg, Max: 10 mg | Grp1 B: 8.09 (1.84) F: 7.89 F-B: −0.2 Grp2 B: 7.62 (1.61) F: 6.72 F-B: −0.9 Grp1-Grp2: 0.7 p: <0.05 | Grp1 B: 148.2 (39) F: 136.5 F-B: −11.7 (31.2) p:NSG Grp2 B: 152.1 (35.1) F: 144.3 F-B: −7.8 (27.3) p:NSG Grp1-Grp2: −3.9 | Grp1 B: 46.8 (11.7) F: 58.5 F-B: 1.17 p: NSG Grp2 B: 50.7 (11.7) F: 50.7 F-B: 0 p: NSG Grp1-Grp2: 1.17 | Grp1 B: 204.7 (169.1) F: 186.9 F-B: −17.8 (89) Grp2 B: 222.5 (284.8) F: 178 F-B: −44.5 (186.9) Grp1-Grp2: 26.7 p: NSG | Grp1 B: 84.9 (17.6) F: 84.1 F-B: −0.8 Grp2 B: 83.1 (13.3) F: 84.1 F-B: 1 Grp1-Grp2: −1.8
Garber, 2002^65^ | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 2000 mg; Start: 2.5 mg, Max: 10 mg | Grp1 B: 8.26 (1.08) F: 7.23 F-B: −1.03 Grp2 B: 8.18 (1.14) F: 6.65 F-B: −1.53 Grp1-Grp2: 0.5 p: <0.001 | | | | Grp1 F-B: −0.6 Grp2 F-B: 1.4 p: <0.05 Grp1-Grp2: −2
Garber, 2002^65^ | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 250 mg, Max: 1000 mg; Start: 1.25 mg, Max: 5 mg | Grp1 B: 8.26 (1.08) F: 7.23 F-B: −1.03 Grp2 B: 8.25 (1.11) F: 6.77 F-B: −1.48 Grp1-Grp2: 0.45 p: <0.001 | | | | Grp1 F-B: −0.6 Grp2 F-B: 1.9 p: <0.05 Grp1–Grp2: −2.5
Hermann, 1994^68^ | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Metformin + glyburide Varied Start: 1000 mg, Max: 3000 mg; Start: 10.5 mg, Max: 14.0 mg | Grp1 B: 6.9 (SE: 0.3) F: 5.8 (SE: 0.2) F-B: −0.9 (SE: 0.2) p: 0.001 Grp2 B: 7.8 (SE: 0.3) F: 5.7 (SE: 0.3) F-B: −2.0 (SE: 0.4) p: 0.001 Grp1-Grp2: 1.1 p: >0.1 across all treatment groups | Grp1 B: 142.74 (SE: 9.75) F: 131.82 (SE: 8.97) F-B: −5.85 (SE: 2.73) Grp2 B: 143.13 (SE: 5.46) F: 139.62 (SE: 4.68) F-B: −2.73 (SE: 2.34) Grp1-Grp2: −3.12 | Grp1 B: 31.59 (SE: 2.34) F: 30.03 (SE: 1.56) F-B: −0.78 (SE: 0.78) p: >0.1 Grp2 B: 35.49 (SE: 1.56) F: 37.05 (SE: 1.95) F-B: 1.56 (SE: 1.17) p: >0.1 Grp1-Grp2: −0.78 | Grp1 B: 179.78 (SE: 18.69) F: 173.55 (SE: 14.24) F-B: 8.01 (SE: 12.46) p: >0.1 Grp2 B: 175.33 (SE: 20.47) F: 168.21 (SE: 17.8) F-B: 5.34 (SE: 11.57) p: >0.1 Grp1-Grp2: 2.67 | Grp1 B: 78.6 (SE: 2.9) F: 78.8 (SE: 2.9) F-B: −0.2 (SE: 0.5) p: >0.1 Grp2 B: 80.2 (SE: 2.4) F: 81 (SE: 2.5) F-B: 0.7 (SE: 0.4) p: >0.1 Grp1-Grp2: −0.9
Hermann, 1994^68^ | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Metformin + glyburide Fixed; Varied Start: 3000 mg; Start: 3.5 mg, Max: 14.0 mg | Grp1 B: 6.9 (SE: 0.3) F: 5.8 (SE: 0.2) F-B: −0.9 (SE: 0.2) p: 0.001 Grp2 B: 7.8 (SE: 0.3) F: 5.4 (SE: 0.3) F-B: −2.3 (SE: 0.4) p: 0.001 Grp1-Grp2: 1.4 p: >0.1 across all treatment groups
Hermann, 1994^68^ | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Metformin + glyburide Varied Start: 2000 mg, Max: 3000 mg; Start: 7.0 mg, Max: 14.0 mg | Grp1 B: 6.9 (SE: 0.3) F: 5.8 (SE: 0.2) F-B: −0.9 (SE: 0.2) p: 0.001 Grp2 B: 8.4 (SE: 0.4) F: 6.2 (SE: 0.3) F-B: −2.2 (SE: 0.4) p: 0.001 Grp1-Grp2: 1.3 p: >0.1 across all treatment groups
Hermann, 1994^68^ | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 1500 mg; Start: 1.75 mg, Max: 5.25 mg | Grp1 B: 6.9 (SE: 0.3) F: 5.8 (SE: 0.2) F-B: −0.9 (SE: 0.2) p: 0.001 Grp2 B: 6.8 (SE: 0.1) F: 5.6 (SE: 0.1) F-B: −1.2 (SE: 0.1) p: 0.001 Grp1-Grp2: 0.3 p: >0.1 across all treatment groups
Hermann, 1991^155^ | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Metformin + glibenclamide Fixed; Varied Start: 3000 mg; Start: 3.5 mg, Max: 14 mg | Grp1 B: 6.7 (1.3) F: 5.8 (0.7) F-B: −0.9 p: <0.01 Grp2 B: 7.7 (1.1) F: 5.4 (0.9) F-B: −2.3 p: <0.001 Grp1-Grp2: 1.4 | Grp1 F-B: 0.78 (SE: 3.9) Grp2 F-B: −6.24 (SE: 2.34) Grp1-Grp2: 7.02 p:<0.05 | | | Grp1 B: 76.5 (11.5) F: 76.1 (11.1) F-B: −0.4 p: NSG Grp2 B: 87.3 (15.6) F: 87.3 (15.9) F-B: 0 p: NSG Grp1-Grp2: −0.4
Hermann, 1991^155^ | Grp1: Metformin + diet Varied Start: 1000 mg, Max: 3000 mg Grp2: Metformin + glibenclamide Varied Start: 1000 mg, Max: 3000 mg; Start: 10.5 mg, Max: 14 mg | Grp1 B: 6.7 (1.3) F: 5.8 (0.7) F-B: −0.9 p: <0.01 Grp2 B: 7.8 (1.4) F: 5.7 (0.8) F-B: −2.2 p: <0.001 Grp1-Grp2: 1.3 | | | | Grp1 B: 76.5 (11.5) F: 76.1 (11.1) F-B: −0.4 p: NSG Grp2 B: 74.4 (11.4) F: 76 (11.8) F-B: 1.6 p: <0.001 Grp1-Grp2: −2
Charpentier, 2001^71^ | Grp1: Metformin Fixed Start: 850 mg tid Grp2: Metformin + glimepiride Fixed; Varied Start: 850 mg tid; Start: 1 mg, Max: 6 mg | Grp1 B: 6.79 (1.17) F: 6.86 (1.45) F-B: 0.07 (SE: 0.14) Grp2 B: 6.42 (1.08) F: 5.68 (0.99) F-B: −0.74 (SE: 0.8) Grp1-Grp2: 0.92 p: <0.001 | | Grp1 B: 46.41 (13.65) F: 48.36 F-B: 1.95 (9.36) Grp2 B: 46.41 (12.09) F: 45.24 F-B: −1.17 (9.87) Grp1-Grp2: 3.12 p: 0.14 across all treatment groups | Grp1 B: 171.77 (119.26) F: 185.12 F-B: 13.35 (104.13) Grp2 B: 169.99 (110.36) F: 167.32 F-B: −2.67 (93.45) Grp1-Grp2: 16.02 p: 0.029 across all treatment groups | Grp1 B: 82.2 F: 81.46 F-B: −0.74 (2.58) Grp2 B: 81.2 F: 81.8 F-B: 0.6 (2.86) Grp1-Grp2: −1.34
DeFronzo, 1995^70^ | Grp1: Metformin Varied Start: 500 mg, Max: 2500 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 2500 mg; Start: 10 mg, Max: 20 mg | Grp1 B: 8.9 F: 8.5 F-B: −0.4 (SE: 0.1) Grp2 B: 8.8 F: 7.1 F-B: −1.7 (SE: 0.1) Grp1-Grp2: 1.3 p: <0.001 | Grp1 B: 134 (SE: 3) F: 129 (SE: 3) F-B: −6 (SE: 2) Grp2 B: 137 (SE: 3) F: 128 (SE: 3) F-B: −8 (SE: 2) Grp1-Grp2: 2 p: NSG | | Grp1 B: 231 (SE: 12) F: 221 (SE: 13) F-B: −16 (SE: 7) Grp2 B: 216 (SE: 10) F: 194 (SE: 9) F-B: −20 (SE: 7) Grp1-Grp2: 4 | Grp1 F-B: −3.8 (SE: 0.2) p: <0.001 Grp2 F-B: 0.4 (SE: 0.2) p: NSG Grp1-Grp2: −4.2
Metformin versus metformin + DPP-IV inhibitor
Jadzinsky, 2009^78^ | Grp1: Metformin Varied Start: 500 mg, Max: 1000 mg D: 1 Weeks Grp2: Metformin + saxagliptin Varied, prespecified target dose Start: 500 mg, Max: 1000 mg; Start: 5mg D: 1 Weeks | Grp1 F-B: −2 p: <0.0001 Grp2 F-B: −2.5 p: <0.0001 Grp1-Grp2: 0.5 p: <0.0001 | Grp1 B: 126.7 F: 118.5 F-B: −4 (SE: 1.44) (CI: −6.8, −1.1) Grp2 B: 124.4 F: 114.8 F-B: −3.8 (SE: 1.85) (CI: −7.4, −0.1) Grp1-Grp2: 1.4 | Grp1 B: 43.6 F: 46.6 F-B: 8.9 (SE: 1.36) (CI: 6.2, 11.5) Grp2 B: 43.9 F: 46 F-B: 6.2 (SE: 1.15) (CI: 3.9, 8.5) Grp1-Grp2: 0.9 | Grp1 B: 228.1 (SE: 13.92) F: 207.2 (SE: 14.71) F-B: −1.5 (SE: 2.72) (CI: −6.8, 3.9) Grp2 B: 225.5 (SE: 13.92) F: 184.4 (SE: 9.17) F-B: −4.5 (SE: 2.82) (CI: −10.1, 1) Grp1-Grp2: 0.2 | Grp1 F-B: −1.6 Grp2 F-B: −1.8 Grp1-Grp2: 0.2
Jadzinsky, 2009^78^ | Grp1: Metformin Varied Start: 500 mg, Max: 1000 mg D: 1 Weeks Grp2: Metformin + saxagliptin Varied, prespecified target dose Start: 500 mg, Max: 1000 mg; Mean: 10 mg D: 1 Weeks | Grp1 F-B: −2 p: <0.0001 Grp2 F-B: −2.5 p: <0.0001 Grp1-Grp2: 0.8 p: <0.0001 | Grp1 B: 126.7 F: 118.5 F-B: −4 (SE: 1.44) (CI: −6.8, −1.1) Grp2 B: 124.6 F: 114.2 F-B: −4.6 (SE: 1.73) (CI: −8.1, −1.2) Grp1-Grp2: 2.2 | Grp1 B: 43.6 F: 46.6 F-B: 8.9 (SE: 1.36) (CI: 6.2, 11.5) Grp2 B: 43.7 F: 45.6 F-B: 6.7 (SE: 1.26) (CI: 4.2, 9.2) Grp1-Grp2: 1.1 | Grp1 B: 228.1 (SE: 13.92) F: 207.2 (SE: 14.71) F-B: −1.5 (SE: 2.72) (CI: −6.8, 3.9) Grp2 B: 217.9 (SE: 10.23) F: 181.7 (SE: 8.86) F-B: −5.8 (SE: 3.55) (CI: −12.8, 1.2) Grp1-Grp2: 15.3 | Grp1 F-B: −1.6 Grp2 F-B: −1.4 Grp1-Grp2: −0.2
DeFronzo, 2009^95^ | Grp1: Metformin Fixed Grp2: Metformin + Saxagliptin Fixed NR; Mean: 2.5 mg | Grp1 F-B: Grp2 0 F-B: −0.59 (SE: 0.07) p: <0.0001 Grp1-Grp2: 0.73 (SE: 0.1) (CI: 0.53, 0.92) p: <0.0001
DeFronzo, 2009^95^ | Grp1: Metformin Fixed Grp2: Metformin + Saxagliptin Fixed NR; Mean: 5 mg | Grp1 F-B: 0 Grp2 F-B: −0.69 (SE: 0.07) p: <0.0001 Grp1-Grp2: 0.83 (SE: 0.1) (CI: 0.63, 1.02) p: <0.0001
DeFronzo, 2009^95^ | Grp1: Metformin Fixed Grp2: Metformin+ Saxagliptin Fixed NR; Mean: 10 mg | Grp1 F-B: 0 Grp2 F-B: −0.58 (SE: 0.07) p: <0.0001 Grp1-Grp2: 0.72 (SE: 0.1) (CI: 0.52, 0.91) p: <0.0001
Williams-Herman, 2009^76^ | Grp1: Metformin Fixed Mean: 2000 mg Grp2: Metformin + sitagliptin Fixed Mean: 2000 mg; Mean: 100 mg | Grp1 F-B: −1.3 (CI: −1.5, −1.2) Grp2 F-B: −1.8 (CI: -2, −1.7) Grp1-Grp2: 0.5 | Grp1 B: 105.3 (32.3) F: 102.3 (33.6) F-B: −3 Grp2 B: 115.1 (39.1) F: 110.1 (37.1) F-B: −5 Grp1-Grp2: 2 (SE: 7.8) | Grp1 B: 42.8 (9) F: 45.2 (11) F-B: 2.4 Grp2 B: 43.9 (11.1) F: 46.6 (13.5) F-B: 2.7 Grp1-Grp2: −0.3 (SE: 2.40) | Grp1 B: 150 (92.1) F: 174.5 (124.7) F-B: Median % change: 8.4 (CI: 0.5, 16.4) Grp2 B: 158 (97.7) F: 143 (94) F-B: Median % change: −7.1 (CI: −13.9, −0.2) Grp1-Grp2: 39.5 | Grp1 F-B: −1.5 (CI: −2.2, −0.8) Grp2 F-B: −1.7 (CI: −2.4, −1.1)
Williams-Herman, 2009^76^ | Grp1: Metformin Fixed Mean: 2000 mg Grp2: Metformin + sitagliptin Fixed Mean: 1000 mg; Mean: 100 mg | Grp1 F-B: −1.3 (CI: −1.5, −1.2) Grp2 F-B: −1.4 (CI: −1.6, −1.3) Grp1-Grp2: 0.1 | Grp1 B: 107.3 (33.4) F: 102.5 (36.7) F-B: −4.8 Grp2 B: 115.1 (39.1) F: 110.1 (37.1) F-B: −5 Grp1-Grp2: 0.2 (SE: 7.8) | Grp1 B: 43.3 (10.8) F: 46.4 (12) F-B: 3.1 Grp2 B: 43.7 (9.3) F: 45.4 (11.3) F-B: 1.7 Grp1-Grp2: 1.4 (SE: 2.31) | Grp1 B: 150 (92.1) F: 174.5 (124.7) F-B: Median % change: 8.4 (CI: 0.5, 16.4) Grp2 B: 155 (104.2) F: 147 (95.8) F-B: Median % change: −4.6 (CI: −11.9, 2.7) Grp1-Grp2: 32.5 | Grp1 F-B: −1.5 (CI: −2.2, −0.8) Grp2 F-B: −0.7 (CI: −1, 0) Grp1-Grp2: −0.8
Williams-Herman, 2009^76^ | Grp1: Metformin Fixed Mean: 1000 mg Grp2: Metformin + sitagliptin Fixed Mean: 2000 mg; Mean: 100 mg | Grp1 F-B: −1 (CI: −1.2, −0.8) Grp2 F-B: −1.8 (CI: −2, −1.7) Grp1-Grp2: 0.8 | Grp1 B: 106.8 (34.2) F: 103.6 (31.5) F-B: −3.2 Grp2 B: 114.7 (37.1) F: 111 (32.4) F-B: −3.7 Grp1-Grp2: 0.5 (SE: 6.5) | Grp1 B: 43.2 (9.4) F: 44.6 (10.4) F-B: 1.4 Grp2 B: 43.1 (9.2) F: 44.3 (10.4) F-B: 1.2 Grp1-Grp2: 0.2 (SE: 1.88) | Grp1 B: 167 (104.2) F: 173 (120) F-B: Median % change: 4.9 (CI: −3.3, 13) Grp2 B: 158 (97.7) F: 143 (94) F-B: Median % change: −7.1 (CI: −13.9, −0.2) Grp1-Grp2: 21 | Grp1 F-B: −1 (CI: −1.7, −0.3) Grp2 F-B: −1.7 (CI: −2.4, −1.1) Grp1-Grp2: 0.7
Williams-Herman, 2009^76^ | Grp1: Metformin Fixed Mean: 1000 mg Grp2: Metformin + sitagliptin Fixed Mean: 1000 mg; Mean: 100 mg | Grp1 F-B: −1 (CI: −1.2, −0.8) Grp2 F-B: −1.4 (CI: −1.6, −1.3) Grp1-Grp2: 0.4 | Grp1 B: 108.2 (34.4) F: 104.6 (33.8) F-B: −3.6 Grp2 B: 114.7 (37.1) F: 111 (32.4) F-B: −3.7 Grp1-Grp2: 0.1 (SE: 6.6) | Grp1 B: 43.2 (9.4) F: 44.6 (10.4) F-B: 1.4 Grp2 B: 44.2 (10.9) F: 46 (12.2) F-B: 1.8 Grp1-Grp2: −0.4 (SE: 2.06) | Grp1 B: 167 (104.2) F: 173 (120) F-B: Median % change: 4.9 (CI: −3.3, 13) Grp2 B: 155 (104.2) F: 147 (95.8) F-B: Median % change: −4.6 (CI: −11.9, 2.7) Grp1-Grp2: 14 | Grp1 F-B: −1 (CI: −1.7, −0.3) Grp2 F-B: −0.7 (CI: −1, 0) Grp1-Grp2: −0.3
Raz, 2008^93^ | Grp1: Metformin Fixed NR Grp2: Metformin + sitagliptin Fixed Max: 2550 mg; Mean: 100 mg | Grp1 F-B: 0 (CI: −0.2, 0.3) Grp2 F-B: −1 (CI: −1.3, −0.7) p: <0.001 Grp1-Grp2: −1 (CI: −1.4, −0.6) p: <0.001 | | | | Grp1 F-B: −0.5 Grp2 F-B: −0.5 Grp1-Grp2: 0
Goldstein, 2007^75^ | Grp1: Metformin Varied, prespecified target dose Start: 500 mg, Max: 100 mg D: 1 wk Grp2: Metformin + sitagliptin Varied, prespecified target dose Start: 500 mg, Max: 1000 mg; Start: 50 mg, Max: 100 mg D: 1 wk | Grp1 F-B: −0.82 (CI: −0.98, −0.66) Grp2 F-B: −1.4 (CI: −1.56, −1.24) Grp1-Grp2: 0.58 | | | | Grp1 F-B: significant reduction relative to baseline Grp2 F-B: significant reduction relative to baseline
Goldstein, 2007^75^ | Grp1: Metformin Varied, prespecified target dose Start: 500 mg, Max: 100 mg D: 1 wk Grp2: Metformin + sitagliptin Varied, prespecified target dose Start: 500 mg, Max: 2000 mg; Start: 50 mg, Max: 100 mg D: 3 wks; 1wk | Grp1 F-B: −0.82 (CI: −0.98, −0.66) Grp2 F-B: −1.9 (CI: −2.06, −1.74) Grp1-Grp2: 1.08 | | | | Grp1 F-B: significant reduction relative to baseline Grp2 F-B: significant reduction relative to baseline
Goldstein, 2007^75^ | Grp1: Metformin Fixed Start: 500 mg, Max: 2000 mg D: 3 wks Grp2: Metformin + sitagliptin Varied, prespecified target dose Start: 500 mg, Max: 1000 mg; Start: 50 mg, Max: 100 mg D: 1 wk | Grp1 F-B: −1.13 (CI: −1.29, −0.97) Grp2 F-B: −1.4 (CI: −1.56, −1.24) Grp1-Grp2: 0.27 | | | | Grp1 F-B: significant reduction relative to baseline Grp2 F-B: significant reduction relative to baseline
Goldstein, 2007^75^ | Grp1: Metformin Fixed Start: 500 mg, Max: 2000 mg D: 3 wks Grp2: Metformin + sitagliptin Varied, prespecified target dose Start: 500 mg, Max: 2000 mg; Start: 50 mg, Max: 100 mg D: 3 wks; 1 wk | Grp1 F-B: −1.13 (CI: −1.29, −0.97) Grp2 F-B: −1.9 (CI: −2.06, −1.74) Grp1-Grp2: 0.77 (SE: 0.12) | | | | Grp1 F-B: significant reduction relative to baseline Grp2 F-B: significant reduction relative to baseline
Charbonnel, 2006^94^ | Grp1: Metformin Varied, glucose:, HbA1c: 7% −10% Start: >=1500 mg D: 19 wks Grp2: Metformin + sitagliptin Varied; Fixed Start: >=1500 mg; Mean: 100 mg D: 19 wks | Grp1 B: 8.03 (0.82) F: 7.95 (1.1) F-B: −0.02 (CI: −0.15, 0.1) Grp2 B: 7.96 (0.81) F: 7.26 (0.97) F-B: −0.67 (CI: −0.77, −0.57) Grp1-Grp2: 0.65 (SE 0.08) | Grp1 B: 102.18 (31.6) F: 104.13 (32.8) F-B: 1.95 Grp2 B: 98.67 (30.8) F: 100.62 (32.0) F-B: 1.95 Grp1-Grp2: 0 (SE: 4.7) | Grp1 B: 44.85 (10.92) F: 45.63 (11.7) F-B: 0.78 Grp2 B: 45.63 (10.92) F: 46.8 (11.31) F-B: 1.17 Grp1-Grp2: −0.39 (SE: 1.65) | Grp1 F-B: 24.6 (CI: 16.8, 32.3) Grp2 F-B: 7.7 (CI: 1.5, 14) Grp1-Grp2: 16.9 | Grp1 F-B: 0.6–0.7 p: <0.05 Grp2 F-B: 0.6–0.7 p: <0.05 Grp1-Grp2: p=0.835
Scott, 2008^85^ | Grp1: Metformin Fixed Total starting dose: > 1500 mg Grp2: Metformin + sitagliptin Fixed Total starting dose: > 1500 mg; Start: 100 mg, Mean: 100 mg | Grp1 B: 7.68 (0.88) F: 7.47 (1.05) F-B: −0.22 (CI: −0.36, −0.08) Grp2 B: 7.75 (0.99) F: 7.01 (0.86) F-B: −0.73 (CI: −0.87, −0.6) Grp1-Grp2: −0.51 (CI: −0.7, −0.32) p: <0.001 | Grp1 B: 95.6 (30.8) F: 108.4 (33.6) F-B: Mean % change: 16.7 (CI: 10.2, 23.3) Grp2 B: 95.4 (30.8) F: 104.6 (35.1) F-B: Mean % change: 11.4 (CI: 5, 17.8) Grp1-Grp2: 3.6 (SE: 8.7) | Grp1 B: 43.5 (10.5) F: 44.1 (12.1) F-B: Mean % change: 1.8 (CI: −1.3, 4.9) Grp2 B: 43.9 (11.6) F: 45.7 (13.4) F-B: Mean % change: 4.3 (CI: 1.2, 7.3) Grp1-Grp2: −1.2 (SE: 3.18) | Grp1 B: 171.1 (73.3) F: 191.5 (111.1) F-B: Mean % change from baseline: 11.9 (CI: 3.9, 19.9) Grp2 B: 177.8 (80.7) F: 163.3 (74) F-B: Mean % change from baseline: −4.8 (CI: −12.7, 3.1) | Grp1 F-B: −0.8 (CI: −1.2, −0.4) Grp2 F-B: −0.4 (CI: −0.8, 0) Grp1-Grp2: −0.4
Metformin versus metformin + meglitinides
Horton, 2004^80^ | Grp1: Metformin Fixed Start: 500 mg tid Grp2: Metformin + nateglinide Fixed Start: 500 mg qac; Start: 120 mg qac | Grp1 F-B: −0.8 (SE: 0.1) p: <0.001 Grp2 F-B: −1.6 (SE: 0.1) p: <0.001 Grp1-Grp2: 0.8 (SE: 0.14)
Marre, 2002^96^ | Grp1: Metformin Fixed Start: 1000 mg bid Grp2: Metformin + nateglinide Fixed Start: 1000 mg bid; Start: 60 mg qac | Grp2-Grp1: −0.36 (CI: −0.59, −0.13) p: 0.003 | Grp1-Grp2: 0.0 (CI: −3.9, 7.8) p: NSG | Grp1-Grp2: 0.0 (CI: −0.0, 3.9) p: NSG | Grp1-Grp2: −3.9 (CI: −11.7, 7.8) p: NSG | Grp1 F-B: 0.1 Grp2 F-B: 0.4 Grp1-Grp2: −0.3 (CI: −0.8, 0.2) p: >0.05
Marre, 2002^96^ | Grp1: Metformin Fixed Start: 1000 mg bid Grp2: Metformin + nateglinide Fixed Start: 1000 mg bid; Start: 120 mg qac | Grp2-Grp1: −0.51 (CI: −0.82, −0.36) p: <0.001 | Grp1-Grp2: 3.9 (CI: −0.0, 11.7) p: NSG | Grp1-Grp2: 0.0 (CI: −0.0, 3.9) p: NSG | Grp1-Grp2: −7.8 (CI: −15.6, −0.0) p: <0.05 | Grp1 F-B: 0.1 Grp2 F-B: 1 Grp1-Grp2: −0.9 (CI: − 1.4, 0) p: <0.001
Moses, 1999^82^ | Grp1: Metformin NR Grp2: Metformin + repaglinide NR NR; Start: 0.5 mg tid, Max: 4.0 mg tid D: NR; 12 to 28 days | Grp1 F-B: −0.33 (SE: 0.24, CI: −0.8, −0.5) Grp2 F-B: −1.41 (SE: 0.23, CI: −1.87, −0.95) Grp1-Grp2: −1.08 (SE: 0.33, CI: −1.84, −0.33) p: 0.05 | | | | Grp1 F-B: −0.86 (SE: 0.51) Grp2 F-B: 2.41 (SE: 0.5) p: <0.05 Grp1-Grp2: −3.27
Horton, 2000^79^ | Grp1: Metformin Fixed Start: 500 mg tid Grp2: Metformin + nateglinide Fixed Start: 500 mg qac; Start: 120 mg qac | Grp1 B: 8.4 (1.2) F: 7.6 F-B: −0.8 p: ≤0.0001 Grp2 B: 8.4 (1.1) F: 7.1 F-B: −1.3 p: ≤0.0001 Grp1-Grp2: 0.5
Thiazolidinedione versus thiazolidinedione
Vijay, 2009^99^ | Grp1: Rosiglitazone Varied Start: 4 mg daily, Max: 4 mg bid D: NR Grp2: Pioglitazone Varied Start: 30 mg, Max: 45 mg D: NR | Grp1 F-B: −1.26 (SD: 0.72) p: 0 Grp2 F-B: −1.27 (SD: 0.17) p: 0 Grp1-Grp2: 0.01 | Grp1 F-B: 5.39 p: 0.39 Grp2 F-B: −13.66 (6.7) p: 0 Grp1-Grp2: 19.05 | Grp1 F-B: 3.25 p: 0.01 Grp2 F-B: 4.7 (1.4) p: 0 Grp1-Grp2: −1.45 | Grp1 F-B: −25.3 p: 0.013 Grp2 F-B: −33 (8.7) p: 0 Grp1-Grp2: 7.7 | Grp1 F-B: 0.7 (0.3) p: 0.8 Grp2 F-B: 1.15 (0.4) p: 0 Grp1-Grp2: −0.45
Goldberg, 2005^98^ | Grp1: Rosiglitazone Varied Start: 4 mg, Max: 8 mg Grp2: Pioglitazone Varied Start: 30 mg, Max: 45 mg | Grp1 B: 7.5 (SE: 0.1) F: 6.9 F-B: −0.6 (SE: 0.1) p:<.05 Grp2 B: 7.6 (SE: 0.1) F: 6.9 F-B: −0.7 (SE: 0.1) p: <.05 Grp1-Grp2: 0.1 | Grp1 B: 109.1 (SE: 1.4) F: 130.4 F-B: 21.3 (SE: 1.6) p: <0.05 Grp2 B: 107.1 (SE: 1.3) F: 119.4 F-B: 12.3 (SE: 1.6) p: <0.05 Grp1-Grp2: 9 | Grp1 B: 39.8 (SE: 0.6) F: 42.2 F-B: 2.4 (SE: 0.5) Grp2 B: 38.8 (SE: 0.5) F: 44 F-B: 5.2 (SE: 0.5) Grp1-Grp2: −2.8 p: <0.001 | Grp1 B: 235.3 (SE: 6.6) F: 248.4 F-B: 13.1 (SE: 7.8) p: NSG Grp2 B: 257.8 (SE: 8.2) F: 205.9 F-B: −51.9 (SE: 7.8) p: <0.05 Grp1-Grp2: 65
Khan, 2002^97^ | Grp1: Rosiglitazone Fixed Start: 2–8 mg Grp2: Pioglitazone Fixed Start: 15–45 mg | Grp1 B: 7.9 (1.9) F: 7.6 F-B: −0.3 Grp2 B: 8.0 (1.7) F: 7.8 F-B: −0.2 (SE: 0.1) Grp1-Grp2: −0.1 p: NSG | Grp1 B: 105.9 (29.7) F: 103.9 F-B: −2 p: NSG Grp2 B: 116.2 (38) F: 98.2 F-B: −18 p: <0.01 Grp1-Grp2: 16 | Grp1 B: 45.3 (15.2) F: 48.6 F-B: 1.5 p: NSG Grp2 B: 44.7 (15.6) F: 46.7 F-B: 2.0 p: NSG Grp1-Grp2: −0.5 | Grp1 B: 236 (222) F: 242 F-B: 6 p: NSG Grp2 B: 181 (110.1) F: 166 F-B: −15 p: NSG Grp1-Grp2: 21
Thiazolidinedione versus sulfonylurea
Nakamura, 2006^108^ | Grp1: Pioglitazone Fixed Mean: 30 mg D: 12 Months Grp2: Glibenclamide Fixed Mean: 5 mg D: 12 Months | Grp1 B: 8 (1.4) F: 6.4 (1.2) p:<0.01 F-B: −1.6 Grp2 B: 7.8 (1.3) F: 7 (6.2) p:<0.01 F-B: −0.8 Grp1-Grp2: −0.8 | | Grp1 B: 32 (10) F: 40 (12) p:<0.05 F-B: 8 Grp2 B: 34 (8) F: 34 (10) p:NSG F-B: 0 Grp1-Grp2: 8 | Grp1 B: 148 (42) F: 118 (28) p:<0.01 F-B: −30 Grp2 B: 144 (38) F: 146 (38) p: NSG F-B: 2 Grp1-Grp2: −32
Teramoto, 2007^41^ | Grp1: Pioglitazone Varied, glucose: <= 126 mg/dL Start: 15 mg, Max: 30 mg D: 15 wks Grp2: Glibenclamide Varied, glucose: <= 126 mg/dL Start: 1.25 mg, Max: 2.5 mg D: 15 wks | Grp1 F-B: −0.8 (1.14) p: <0.05 Grp2 F-B: −1.43 (1.09) p: <0.05 Grp1-Grp2: 0.63 (SE: 0.48) | Grp1 F-B: 8.65 (23.47) Grp2 F-B: −1.31 (24.94) Grp1-Grp2: 9.96 (SE: 2.25) | Grp1 F-B: 3.8 (8.2) p: <0.05 Grp2 F-B: −1.2 (6.3) Grp1-Grp2: 5 (SE: 1.23) | Grp1 F-B: −57.7 (111.5) p: <0.05 Grp2 F-B: 7.3 (112.7) Grp1-Grp2: −65 (SE: 4.8)
Hanefeld, 2007^100^ | Grp1: Rosiglitazone Fixed Mean: 4 mg Grp2: Glibenclamide Varied Start: 2.5 mg, Max: 15 mg D: 12 wks | Grp1 F-B: −0.3 p: 0.0003 Grp2 F-B: −0.7 p: <0.0001 Grp1-Grp2: 0.4 | Grp1 F-B: 7.8 (27.3) Grp2 F-B: −3.9 (27.3) Grp1-Grp2: 11.7 (SE: 1.66) | Grp1 F-B: Median: 0.12 CI: 0.09 − 0.15 p: <0.0001 Grp2 F-B: Median: 0.08 CI: 0.05 − 0.12 p: <0.0001 | Grp1 F-B: −10 (351) p: NSG Grp2 F-B: −3 (86) p: NSG Grp1-Grp2: −7 | Grp1 F-B: 1.75 Grp2 F-B: 1.9 Grp1-Grp2: −0.15
Hanefeld, 2007^100^ | Grp1: Rosiglitazone Fixed Mean: 8 mg Grp2: Glibenclamide Varied Start: 2.5 mg, Max: 15 mg D: 12 wks | Grp1 F-B: −0.5 p: <0.0001 Grp2 F-B: −0.7 p: <0.0001 Grp1-Grp2: 0.2 (SE: 0.24) | Grp1 F-B: 15.6 (35.1) Grp2 F-B: −3.9 (27.3) Grp1-Grp2: 19.5 (SE: 1.78) | Grp1 F-B: Median: 0.17 CI: 0.12 – 0.22 p: <0.0001 Grp2 F-B: Median: 0.08 CI: 0.05 – 0.12 p: <0.0001 | Grp1 F-B: 12 (92) p: NSG Grp2 F-B: −3 (86) p: NSG Grp1-Grp2: 15 | Grp1 F-B: 2.95 Grp2 F-B: 1.9 Grp1-Grp2: 1.05 p: 0.01
Kahn, 2006^38^ | Grp1: Rosiglitazone Varied, glucose: <140 mg/dL Start: 4 mg, Max: 8 mg Grp2: Glyburide Varied, glucose: <140 mg/dL Start: 2.5 mg, Max: 15 mg | Grp1-Grp2: −0.42 (CI: −0.5, −0.33) p: <0.001 | | | | Grp1-Grp2: −2.5 (CI: −3.1, −2) p: <0.001
Jain, 2006^101^ | Grp1: Pioglitazone Varied, glucose: FPG: 69–141 mg/dL Start: 15 mg, Max: 45 mg, Median: 45 mg D: 16 wks Grp2: Glyburide Varied, glucose: FPG: 69–141 mg/dL Start: 5 mg, Max: 15 mg, Median: 10 mg D: 16 wks | Grp1 B: 9.2 (1.26) F: 7.13 (1.26) F-B: −2.07 Grp2 B: 9.2 (1.20) F: 7.18 (1.20) F-B: −2.02 Grp1-Grp2: −0.05 p: 0.669 | | | | Grp1 F-B: 3.66 (6.14) p: <0.001 Grp2 F-B: 1.95 (5.35) Grp1-Grp2: 1.71
Smith, 2004^291^ | Grp1: Rosiglitazone Varied Start: 8 mg Grp2: Glyburide Varied Median: 7.5 mg D: 12 wks | Grp1 F-B: −0.4 Grp2 F-B: 0.72 Grp1-Grp2: −1.1 p: >0.05
Nakamura, 2004^102^ | Grp1: Pioglitazone Fixed Start: 30 mg Grp2: Glibenclamide Fixed Start: 5 mg | Grp1 F-B: 1.7 (1) p: <0.05 Grp2 F-B: 1.5 (1.1) p: <0.05 Grp1-Grp2: 0.2 (SE: 0.62)
Yamanouchi, 2005^50^ | Grp1: Pioglitazone Fixed Start: 30 mg for women and 45 mg for men Grp2: Glimepiride Varied Start: 1.0 mg, Max: 2.0 mg | Grp1 B: 10.2 (0.8) F: 7.9 (1.0) F-B: −2.3 p: <0.005 Grp2 B: 9.8 (0.7) F: 7.7 (0.9) F-B: −2.1 p: <0.005 Grp1-Grp2: −0.2 | | Grp1 B: 53.82 (4.68) F: 58.11 (3.51) F-B: 4.29 p: NSG Grp2 B: 52.65 (4.29) F: 52.26 (4.29) F-B: −0.39 p: NSG Grp1-Grp2: 4.68 | Grp1 B: 219.83 (112.14) F: 185.12 (96.12) F-B: −34.71 p: NSG Grp2 B: 234.07 (121.93) F: 229.62 (112.14) F-B: −4.45 p: NSG Grp1-Grp2: −30.26
Pfutzner, 2005^105^ Langenfeld, 2005^290^ | Grp1: Pioglitazone Fixed Start: 45 mg Grp2: Glimepiride Varied Start: 1 mg, Max: 6 mg | Grp1 B: 7.52 (0.85) F: 6.71 (0.89) F-B: −0.81 p: <0.05 Grp2 B: 7.44 (0.89) F: 6.83 (0.85) F-B: −0.61 p: <0.05 Grp1-Grp2: −0.2 | Grp1 B: 136 (29) F: 133 (31) F-B: −3 Grp2 B: 137 (25) F: 129 (27) F-B: −8 Grp1-Grp2: 5 p: NSG | Grp1 B: 46 (11) F: 54 (13) F-B: 8 Grp2 B: 46 (14) F: 47 (12) F-B: 1 Grp1-Grp2: 7 p: 0.001 | Grp1 B: 190 (109) F: 168 (102) F-B: −22 p: <0.005 Grp2 B: 202 (111) F: 185 (106) F-B: −17 p: <0.001 Grp1-Grp2: −5
Ramachandran, 2004^51^ | Grp1: Pioglitazone Varied Start: 15 mg, Max: 30 mg Grp2: Glimepiride Varied Start: 1 mg, Max: 2 mg | Grp1 B: 9.3 (1.8) F: 6.7 (1.3) F-B: −2.6 p: <0.01 Grp2 B: 10.2 (2.2) F: 7.7 (1.7) F-B: −2.5 p: <0.01 Grp1-Grp2: −0.1 | | Grp1 B: 38.22 (5.85) F: 42.9 (7.8) F-B: 4.68 p: <0.01 Grp2 B: 37.05 (11.7) F: 42.9 (7.8) F-B: 5.85 p: NSG e Grp1-Grp2: −1.17 | Grp1 B: 258.1 (213.6) F: 195.8 (124.6) F-B: −62.3 p: <0.05 Grp2 B: 195.8 (124.6) F: 151.3 (80.1) F-B: −44.5 p: <0.05 Grp1-Grp2: −17.8 | Grp1 B: 68.9 (9.1) F: 67.8 (7.9) F-B: −1.1 Grp2 B: 65.7 (9.1) F: 67.5 (9.2) F-B: 1.8 p: <0.05 Grp1-Grp2: −2.9
Tan, 2004^106^ | Grp1: Pioglitazone Varied Start: 30 mg, Max: 45 mg Grp2: Glibenclamide Varied Start: 1.75 mg, Max: 10.5 mg | Grp1 B: 8.4 (0.7) F: 7.9 F-B: −0.5 p: <0.005 Grp2 B: 8.5 (0.8) F: 8.1 F-B: −0.4 p: <0.005 Grp1-Grp2: −0.1 | Grp1 B: 141.18 F: 146.64 F-B: 5.46 p: NSG Grp2 B: 135.72 F: 134.55 F-B: −1.17 p: NSG Grp1-Grp2: 6.63 | | Grp1 B: 182.45 F: 150.45 F-B: −32.04 p: <0.05 Grp2 B: 202.03 F: 199.36 F-B: −2.67 p: NSG Grp1-Grp2: −29.37 | Grp1 B: 88.7 (17.4) F: 91.7 F-B: 3 p: <0.001 Grp2 B: 89.1 (16) F: 90.2 F-B: 1.1 p: 0.008 Grp1-Grp2: 1.9 p: 0.002
Tan, 2004^106^ | Grp1: Pioglitazone Varied Start: 15 mg, Max: 45 mg Grp2: Glimepiride Varied Start: 2 mg, Max: 8 mg | Grp1 B: 8.54 (0.903) F: 7.76 F-B: −0.78 (0.162) p: <0.001 Grp2 B: 8.45 (1.02) F: 7.77 F-B: −0.68 (0.169) p: <0.001 Grp1-Grp2: −0.1 p: 0.638 | | Grp1 B: 46.02 F: 54.21 F-B: 8.19 p: <0.001 Grp2 B: 43.68 F: 44.85 F-B: 1.17 p: NSG Grp1-Grp2: 7.02
Bakris, 2003^104^ | Grp1: Rosiglitazone Fixed Start: 4 mg bid Grp2: Glyburide Varied Start: NR, Max: 20 mg | Grp1 B: 9.1 (1.68) F: 8.2 F-B: −0.9 (1.38) Grp2 B: 9.5 (1.59) F: 8.6 F-B: −0.9 (1.39) Grp1-Grp2: 0 p: NSG
Nakamura, 2000^103^ | Grp1: Pioglitazone Fixed Start: 30 mg Grp2: Glibenclamide Fixed Start: 5 mg | Grp1 B: 7.7 (1.2) F: 6.8 (1.0) F-B: −0.9 p: <0.05 Grp2 B: 7.8 (1.1) F: 6.9 (1.2) F-B: −0.9 p: <0.05 Grp1-Grp2: 0
St John Sutton, 2002^149^ | Grp1: Rosiglitazone Fixed Start: 4 mg bid Grp2: Glyburide Varied Start: NR, Max: 20 mg | | Grp1 B: 140.2 F: 146.5 F-B: 6.3 to 7.7 Grp2 B: 135.4 F: 126.5 F-B: −8.9 Grp1-Grp2: 15.2 | Grp1 F-B: Median: 7.7 p: <0.05 Grp2 NR | Grp1 B: 226.6 F: 223.8 F-B: −2.8 p: NSG Grp2 B: 189.6 F: 175.8 F-B: −13.8 p: NSG Grp1-Grp2: 11 | Grp1 B: 86.2 (15.6) F: 91.2 F-B: 5 (CI: 3.7, 6.2) p: <0.05 Grp2 B: 85.1 (13.6) F: 88.5 F-B: 3.4 (CI: 2.7, 4.1) p: <0.05 Grp1-Grp2: 1.6
Thiazolidinedione versus meglitinides
Nakamura, 2006^108^ | Grp1: Pioglitazone Fixed Mean: 30 mg D: 12 Months Grp2: Nateglinide Fixed Mean: 270 mg D: 12 Months | Grp1 B: 8 (1.4) F: 6.4 (1.2) p:<0.01 F-B: −1.6 Grp2 B: 7.7 (1.2) F: 6.3 (1.3) p:<0.01 F-B: −1.4 Grp1-Grp2: −0.2 | | Grp1 B: 32 (10) F: 40 (12) p:<0.05 F-B: 8 Grp2 B: 35 (6) F: 36 (6) p:NSG F-B: 1 Grp1-Grp2: 7 | Grp1 B: 148 (42) F: 118 (28) p:<0.01 F-B: −30 Grp2 B: 146 (40) F: 148 (36) p: NSG F-B: 2 Grp1-Grp2: −32
Raskin, 2004^109^ | Grp1: Rosiglitazone Varied Start: 2 mg bid, Max: 4 mg bid Grp2: Repaglinide Varied Start: 0.5 mg tid if HbA1c <8% and 1 mg tid if HbA1c >8%, Max: 4 mg tid | Grp1 B: 9 F: 8.5 F-B: −0.56 (SE: 0.14) Grp2 B: 9.3 F: 9.1 F-B: −0.17 (SE: 0.14) Grp1-Grp2: −0.39 | Grp1 B: 125 (23.5) F: 139 (34.3) F-B: 14 Grp2 B: 124 (33.8) F: 123 (32.3) F-B: −1 Grp1-Grp2: 15 | Grp1 B: 39.9 (10.6) F: 42.5 (11.3) F-B: 2.6 Grp2 B: 39.2 (10.5) F: 40.5 (11.5) F-B: 1.3 Grp1-Grp2: 1.3 | Grp1 B: 245 (211) F: 246 (174) F-B: 1 Grp2 B: 306 (246) F: 284 (211) F-B: −22 Grp1-Grp2: 23 | Grp1 F-B: 2.3 Grp2 F-B: 1.6 Grp1-Grp2: 0.7
Jovanovic, 2004^110^ | Grp1: Pioglitazone Fixed Start: 30 mg Grp2: Repaglinide Varied Start: 0.5 mg tid if HbA1c <8% and 1 mg tid if HbA1c >8%, Max: 4 mg tid | Grp1 B: 9.1 F: 9.5 F-B: 0.32 (SE: 0.16) Grp2 B: 9 F: 8.9 F-B: −0.18 (SE: 0.17) Grp1-Grp2: 0.5 p: NSG | Grp1 B: 106 (37) F: 116 (42) F-B: 10 Grp2 B: 124 (36) F: 118 (38) F-B: −6 Grp1-Grp2: 16 | Grp1 B: 41 (8.8) F: 47.2 (9.4) F-B: 6.2 Grp2 B: 45.4 (12.5) F: 44.6 (11.8) F-B: −0.8 Grp1-Grp2: 7 | Grp1 B: 291 (232) F: 200 (99) F-B: −91 Grp2 B: 174 (80) F: 179 (78) F-B: 5 Grp1-Grp2: −96 | Grp1 F-B: 2 p: <0.05 Grp2 F-B: 0.3 Grp1-Grp2: 1.7
Sulfonylurea versus DPP-IV inhibitor
Scott, 2007^111^ | Grp1: Glipizide Varied, glucose: <160 mg/dl Start: 5 mg, Max: 20 mg D: 6 wks Grp2: Sitagliptin Fixed Start: 100 mg, Max: 100 mg | Grp1 B: 7.82 (0.95) F: 7.11 (0.91) F-B: −0.76 (CI: −0.9, −0.62) Grp2 B: 7.83 (0.95) F: 7.34 (1.01) F-B: −0.54 (CI: −0.68, −0.4) Grp1-Grp2: −0.22 | Grp1 B: 115.05 (39.39) F: 114.27 (35.1) F-B: −0.78 Grp2 B: 115.44 (30.42) F: 115.44 (31.2) F-B: 0 Grp1-Grp2: −0.78 | Grp1 B: 44.46 (9.75) F: 45.24 (10.92) F-B: 0.78 Grp2 B: 45.24 (10.53) F: 45.63 (11.31) F-B: 0.38 Grp1-Grp2: 0.4 | Grp1 B: 171.77 (85.44) F: 174.44 (83.66) F-B: 2.67 Grp2 B: 179.78 (98.79) F: 192.24 (129.94) F-B: 12.46 Grp1-Grp2: –9.79 | Grp1 F-B: 0.9 (CI: 0.5, 1.3) Grp2 F-B: no significant weight change
Scott, 2007^111^ | Grp1: Glipizide Varied, glucose: <160 mg/dl Start: 5 mg, Max: 20 mg D: 6 wks Grp2: Sitagliptin Fixed Start: 50 mg, Max: 50 mg | Grp1 B: 7.82 (0.95) F: 7.11 (0.91) F-B: −0.76 (CI: −0.9, −0.62) Grp2 B: 7.89 (0.94) F: 7.5 (1.14) F-B: −0.43 (CI: −0.56, −0.29) Grp1-Grp2: −0.33 | Grp1 B: 115.05 (39.39) F: 114.27 (35.1) F-B: −0.78 Grp2 B: 118.95 (31.98) F: 119.73 (32.76) F-B: 0.78 Grp1-Grp2: −1.56 | Grp1 B: 44.46 (9.75) F: 45.24 (10.92) F-B: 0.78 Grp2 B: 45.24 (10.53) F: 46.02 (10.14) F-B: 0.78 Grp1-Grp2: 0 | Grp1 B: 171.77 (85.44) F: 174.44 (83.66) F-B: 2.67 Grp2 B: 177.11 (105.91) F: 164.65 (88.11) F-B: −12.46 Grp1-Grp2: 15.13 | Grp1 F-B: 0.9 (CI: 0.5, 1.3) Grp2 F-B: no significant weight change
Scott, 2007^111^ | Grp1: Glipizide Varied, glucose: <160 mg/dl Start: 5 mg, Max: 20 mg D: 6 wks Grp2: Sitagliptin Fixed Start: 25 mg, Max: 25 mg | Grp1 B: 7.82 (0.95) F: 7.11 (0.91) F-B: −0.76 (CI: −0.9, −0.62) Grp2 B: 7.85 (0.88) F: 7.48 (0.98) F-B: −0.41 (CI: −0.55, −0.27) Grp1-Grp2: −0.35 | Grp1 B: 115.05 (39.39) F: 114.27 (35.1) F-B: −0.78 Grp2 B: 115.44 (31.2) F: 115.44 (33.15) F-B: 0 Grp1-Grp2: −0.78 | Grp1 B: 44.46 (9.75) F: 45.24 (10.92) F-B: 0.78 Grp2 B: 43.68 (9.75) F: 45.24 (10.14) F-B: 1.56 Grp1-Grp2: −0.78 | Grp1 B: 171.77 (85.44) F: 174.44 (83.66) F-B: 2.67 Grp2 B: 177.11 (85.44) F: 174.44 (83.66) F-B: −2.67 Grp1-Grp2: 5.34 | Grp1 F-B: 0.9 (CI: 0.5, 1.3) Grp2 F-B: no significant weight change
Scott, 2007^111^ | Grp1: Glipizide Varied, glucose: <160mg/dl Start: 5mg, Max: 20mg D: 6 wks Grp2: Sitagliptin Fixed Start: 10, Max: 10 | Grp1 B: 7.82 (0.95) F: 7.11 (0.91) F-B: −0.76 (CI: −0.9, −0.62) Grp2 B: 7.89 (0.94) F: 7.77 (1.22) F-B: −0.15 (CI: −0.29, −0.01) Grp1-Grp2: −0.61 | Grp1 B: 115.05 (39.39) F: 114.27 (35.1) F-B: −0.78 Grp2 B: 117 (38.22) F: 119.73 (37.83) F-B: 2.73 Grp1-Grp2: −3.51 | Grp1 B: 44.46 (9.75) F: 45.24 (10.92) F-B: 0.78 Grp2 B: 45.24 (8.97) F: 46.8 (9.36) F-B: 1.56 Grp1-Grp2: −0.78 | Grp1 B: 171.77 (85.44) F: 174.44 (83.66) F-B: 2.67 Grp2 B: 161.09 (88.11) F: 161.09 (88.11) F-B: 0 Grp1-Grp2: 2.67 | Grp1 F-B: 0.9 (CI: 0.5, 1.3) Grp2 F-B: no significant weight change
Sulfonylurea versus meglitinides
Nakamura, 2006^108^ | Grp1: Glibenclamide Fixed Mean: 5 mg D: 12 Months Grp2: Nateglinide Fixed Mean: 270 mg D: 12 Months | Grp1 B: 7.8 (1.3) F: 7 (6.2) p:<0.01 F-B: −0.8 Grp2 B: 7.7 (1.2) F: 6.3 (1.3) p:<0.01 F-B: −1.4 Grp1-Grp2: 0.6 | | Grp1 B: 34 (8) F: 34 (10) p:NSG F-B: 0 Grp2 B: 35 (6) F: 36 (6) p:NSG F-B: 1 Grp1-Grp2: −1 | Grp1 B: 144 (38) F: 146 (38) p: NSG F-B: 2 Grp2 B: 146 (40) F: 148 (36) p: NSG F-B: 2 Grp1-Grp2: 0
Jibran, 2006^112^ | Grp1: Glibenclamide Varied, glucose: fasting < 130 mg/dl, PP < 175 mg/dl Start: 5 mg, Max: 15 mg, Mean: 8.8 mg Grp2: Repaglinide Varied, glucose: fasting < 130 mg/dl, PP < 175 mg/dl Start: 0.5 mg tid, Max: 1.5 mg tid, Mean: 4.27 mg/day | Grp1 B: 10.2 (1.6) F: 9.4 (1.5) F-B: −0.7 (0.5) Grp2 B: 9.9 (1.6) F: 8.8 (1.7) F-B: −1.1 (0.3) Grp1-Grp2: 0.3 p: 0.001 | | | | Grp1 B: 72.7 (17.4) F: 71.7 (15.2) F-B: −1 Grp2 B: 65.8 (9.4) F: 66 (8.8) F-B: 0.2 Grp1-Grp2: −1.2
Derosa, 2003^113^ | Grp1: Glimepiride Varied Start: 1 mg, Mean: 3 mg Grp2: Repaglinide Varied Start: 1 mg, Mean: 2.5 mg | Grp1 B: 7.8 (1.2) F: 6.7 (0.9) F-B: −1.1 (CI: −5.6, −0.54) p: <0.01 Grp2 B: 8 (1.1) F: 6.8 (0.8) F-B: −1.2 (CI: −6.2, −0.48) p: <0.01 Grp1-Grp2: 0.1 p: NSG | Grp1 B: 142 (24) F: 136 (25) F-B: −6 Grp2 B: 139 (22) F: 132 (18) F-B: −7 Grp1-Grp2: 1 p: NSG | Grp1 B: 44 (5) F: 43 (6) F-B: −1 Grp2 B: 43 (7) F: 45 (7) F-B: 2 Grp1-Grp2: −3 p: NSG | Grp1 B: 170 (36) F: 155 (39) F-B: −15 Grp2 B: 153 (32) F: 135 (36) F-B: −18 Grp1-Grp2: 3 p: NSG | Grp1 B: 77.1 (5.9) F: 76.6 (5.3) F-B: −0.5 Grp2 B: 76.4 (5.2) F: 76.5 (5.3) F-B: 0.1 Grp1-Grp2: −0.6 p: NSG
Madsbad, 2001^114^ | Grp1: Glipizide Varied Start: 5 mg, Max: 15 mg Grp2: Repaglinide Varied Start: 0.5 mg, Max: 4 mg | Grp1 B: 7.2 (1.4) F: 7.7 (SE: 0.2) F-B: 0.78 (CI: 0.46, 1.1) Grp2 B: 7.3 (1.2) F: 7.4 (SE: 0.15) F-B: 0.19 (−0.02, 0.4) Grp1-Grp2: 0.59 p: <0.05 | | Grp1 F-B: 0.78 p: NSG Grp2 F-B: 0 p: NSG Grp1-Grp2: 1.17 (1.56 to 3.5) | Grp1 F-B: 3.56 (−23.14 to 29.37) Grp2 F-B: 3.56 (−14.24 to 20.47) Grp1-Grp2: 0 (−31.15 to 31.15) p: NSG
Landgraf, 1999^115^ | Grp1: Glibenclamide Varied Start: 1.75 mg, 3.5 mg, 7.0 mg, 10.5 mg, Max: 10.5 mg Grp2: Repaglinide Varied Start: 0.5 mg, 1.0 mg, 2.0 mg, 4.0 mg tid, Max: 4 mg tid | Grp1 B: 8 F: 7.6 (SE: 0.1) F-B: −0.4 Grp2 B: 7.8 F: 7.5 (SE: 0.1) F-B: −0.3 Grp1-Grp2: −0.1 | | Grp1 F-B: 1.11 (SE: 0.03) Grp2 F-B: 1.15 (SE: 0.03) Grp1-Grp2: −0.04 p: 0.005 | | Grp1 B: 78.9 (12.8) F: 77.5 F-B: −1.4 p: NSG Grp2 B: 79.6 (10.3) F: 78.9 F-B: −0.7 p: NSG Grp1-Grp2: −0.7 p: NSG
Wolffenbuttel, 1999^116^ | Grp1: Glyburide Varied Start: 1.75 mg, Max: 10.5 mg Grp2: Repaglinide Varied Start: 1.5 mg, Max: 12 mg | Grp1 B: 7 (1.2) F: 7.45 F-B: 0.45 (CI: 0.22, 0.69) Grp2 B: 7.1 (1.4) F: 7.68 F-B: 0.58 (CI: 0.41, 0.7) Grp1-Grp2: −0.13 p: NSG | | Grp1 B: 45.63 (12.48) F: 45.63 (12.48) F-B: 0 p: NSG Grp2 B: 44.85 (14.82) F: 46.02 (14.43) F-B: 1.17 p: NSG Grp1-Grp2: −1.17 | Grp1 B: 163.76 F: 174.44 F-B: 10.68 p: NSG Grp2 B: 170.88 F: 178 F-B: 7.12 p: NSG Grp1-Grp2: 3.56 | Grp1 B: 81.3 (12.2) F: 82 (11.9) F-B: 0.7 p: NSG Grp2 B: 81.5 (13.4) F: 81.5 (13.5) F-B: 0 p: NSG Grp1-Grp2: 0.7
Wolffenbuttel, 1993^118^ | Grp1: Glyburide Varied Start: 5 mg, Max: 15 mg Grp2: Repaglinide Varied Start: 0.5 mg, Max: 4 mg | Grp1 B: 8.7 (1.8) F: 8.5 (2.0) F-B: −0.2 Grp2 B: 9 (1.9) F: 8.8 (2.0) F-B: −0.2 Grp1-Grp2: 0 | | | | Grp1 B: 70.9 (10.8) F: 70.5 (10.2) F-B: −0.4 p: NSG Grp2 B: 74 (9.6) F: 72.3 (9.4) F-B: −1.7 p: <0.05 Grp1-Grp2: 1.3
Marbury, 1999^117^ | Grp1: Glyburide Varied Start: 2.5 mg, Max: 15 mg Grp2: Repaglinide Varied Start: 0.5 mg, Max: 12 mg | Grp1 B: 8.9 (1.6) F: 9.0 F-B: 0.1 (0.11) Grp2 B: 8.7 (1.7) F: 8.78 F-B: 0.08 (0.07) Grp1-Grp2: −0.02 | Grp1 F-B: −6.51 Grp2 F-B: −5.03 Grp1-Grp2: −1.48 (CI: −6.499, 3.532) p: NSG | Grp1 F-B: −0.13 p: NSG Grp2 F-B: −0.81 p: NSG e Grp1-Grp2: 0.68 (CI: −0.8, 2.15) | Grp1 F-B: −6.45 Grp2 F-B: 6.57 Grp1-Grp2: −13.02 (CI: −31.24, 57.28) p: NSG | Grp1 F-B: 0.05 (SE: 0.5) Grp2 F-B: −0.22 (SE: 0.5) Grp1-Grp2: 0.27 p: NSG
Vakkilainen, 2002^119^ | Grp1: Glibenclamide Varied Start: 5 mg, Max: 10 mg Grp2: Nateglinide Fixed Start: 120 mg tid | Grp1 B: 7.6 (7.2 to 8.1) F: 6.9 (6.5 to 7.3) F-B: −0.7 p: <0.001 Grp2 B: 7.6 (7.2 to 8.0) F: 7.4 (7.0 to 7.9) F-B: −0.2 Grp1-Grp2: −0.5 p: NSG | Grp1 F-B: p: NSG Grp2 F-B: p: NSG | Grp1 F-B: p: NSG Grp2 F-B: p: NSG | Grp1 F-B: p: NSG Grp2 F-B: p: NSG
Sulfonylurea versus GLP-1 agonist
Seino, 2010^121^ | Grp1: Glibenclamide Varied, prespecified target dose Start: 1.25 mg, Max: 2.5 mg D: 4 Weeks Grp2: Liraglutide Varied, prespecified target dose Start: 0.3 mg, Max: 0.9 mg D: 2 Weeks | Grp1 F-B: −1.88 (SE: 0.07) p: <0.0001 Grp2 F-B: −1.38 (SE: 0.09) p:<0.0001 Grp1-Grp2: 0.5 (CI: 0.3, 0.7) p<0.0001 | Grp1-Grp2: 0.07 (CI: −0.04, 0.17) p: 0.2107 | Grp1-Grp2: 0.01 (CI: −0.03, 0.05) p: 0.529 | Grp1-Grp2: 0.05 (CI: −0.11, 0.21) p: 0.5434 | Grp1 F-B: −0.92 (2.15) p: p<0.0001 Grp2 F-B: 0.99 (1.84) p: p<0.0001 Grp1-Grp2: 1.91 (CI: 1.48, 2.34) p: <0.0001
Garber, 2009^122^ | Grp1: Glimepiride Varied, prespecified target dose Start: 2 mg, Max: 8 mg D: 2 Weeks Grp2: Liraglutide Varied, prespecified target dose Start: 0.6 mg, Max: 1.2 mg D: 2 Weeks | Grp1 F-B: 0.51 (SD: 1.2) Grp2 F-B: 0.84 (SD: 1.23) Grp1-Grp2: 0.62 (CI: 0.42, 0.83) p<0.0001 | | | | Grp1 F-B: 1 (0.5) Grp2 F-B: −2 (0.5) Grp1-Grp2: 3
Garber, 2009^122^ | Grp1: Glimepiride Varied, prespecified target dose Start: 2 mg, Max: 8 mg D: 2 Weeks Grp2: Liraglutide Varied, prespecified target dose Start: 0.6 mg, Max: 1.8 mg D: 2 Weeks | Grp1 F-B: 0.51 (SD: 1.2) Grp2 F-B: 1.14 (SD: 1.24) Grp1-Grp2: 0.33 (CI: 0.13, 0.53) p: 0.0014 | | | | Grp1 F-B: 1 (0.5) Grp2 F-B: −2.5 (0.5) Grp1-Grp2: 3.5
Madsbad, 2004^120^ | Grp1: Glimepiride Varied, fasting glucose < 7mmol/L Start: 1 mg, Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.75 mg | Grp1 F-B: −0.74 p: 0.0001 Grp2 F-B: −0.75 p: <0.0001 Grp1-Grp2: 0.01 | | | | Grp1 F-B: 0.94 p: 0.0622 Grp2 F-B: −0.74 p: 0.1544 Grp1-Grp2: 1.68
Madsbad, 2004^120^ | Grp1: Glimepiride Varied, fasting glucose < 7mmol/L Start: 1 mg, Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.045 mg | Grp1 F-B: −0.74 p: 0.0001 Grp2 F-B: 0.25 p: 0.1905 Grp1-Grp2: −0.49 | | | | Grp1 F-B: 0.94 p: 0.0622 Grp2 F-B: −0.03 p: 0.9602 Grp1-Grp2: 0.97
Madsbad, 2004^120^ | Grp1: Glimepiride Varied, fasting glucose < 7mmol/L Start: 1 mg, Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.225 mg | Grp1 F-B: −0.74 p: 0.0001 Grp2 F-B: −0.34 p: 0.0877 Grp1-Grp2: −0.4 | | | | Grp1 F-B: 0.94 p: 0.0622 Grp2 F-B: −1.2 p: 0.0184 Grp1-Grp2: 2.14
Madsbad, 2004^120^ | Grp1: Glimepiride Varied, fasting glucose < 7mmol/L Start: 1 mg, Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.45 mg | Grp1 F-B: −0.74 p: 0.0001 Grp2 F-B: −0.3 p: 0.1131 Grp1-Grp2: −0.44 | | | | Grp1 F-B: 0.94 p: 0.0622 Grp2 F-B: 0.27 p: 0.5838 Grp1-Grp2: 0.67
Madsbad, 2004^120^ | Grp1: Glimepiride Varied, fasting glucose < 7mmol/L Start: 1 mg, Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.60 mg | Grp1 F-B: −0.74 p: 0.0001 Grp2 F-B: −0.7 p: 0.0002 Grp1-Grp2: −0.04 | | | | Grp1 F-B: 0.94 p: 0.0622 Grp2 F-B: −0.39 p: 0.4391 Grp1-Grp2: 1.33
Metformin + thiazolidinedione versus metformin + sulfonylurea
Home, 2009^16^ | Grp1: Metformin + rosiglitazone Varied, HbA1c: <=7.0% Max: 2550 mg; Start: 4 mg, Max: 8 mg D: 8 wks; NR Grp2: Metformin + sulfonylurea Varied, HbA1c: <=7.0% Max: 2550 mg; Unclear D: 8 wks | Grp1 F-B: −0.28 (SE: 0.03) Grp2 F-B: 0.01 (SE: 0.04) Grp1-Grp2: −0.29 (SE: 0.05) p: <0.0001 | Grp1 F-B: −12.87 (SE: 1.56) Grp2 F-B: −20.67 (SE: 1.17) Grp1-Grp2: 7.8 (SE: 1.95) | Grp1 F-B: 4.68 (SE: 0.39) Grp2 F-B: 2.73 (SE: 0.39) Grp1-Grp2: 1.95 (SE: 0.55) | Grp1 F-B: −0.14 (SE: 0.04) Grp2 F-B: −0.14 (SE: 0.04) Grp1-Grp2: 0 | Grp1 F-B: 3.8 (SE: 0.24) Grp2 F-B: 0 (SE: 0.2) and −1.5 (SE: 0.2) Grp1-Grp2: 3.8
Derosa, 2009^46^ | Grp1: Metformin + Pioglitazone Varied, prespecified target dose Start: 850 mg, Max: 2550 mg; Start: 15 mg, Max: 45 mg D: 3 mos Grp2: Metformin + glimepiride Fixed; Varied, prespecified target dose Start: 850 mg, Max: 850 mg; Start: 2 mg, Max: 6 mg D: NA; 3 mos | Grp1 B: 9.3 (1.4) F: 7.2 (0.3) p: >0.001 F-B: −2.1 (0.3) p: <0.01 Grp2 B: 9 (1.1) F: 7.8 (0.4) p: <0.01 F-B: −1.2 (0.4) p: <0.01 Grp1-Grp2: −0.9 (SE: 0.25)
Hamann, 2008^123^ | Grp1: Metformin + rosiglitazone Varied, glucose: 6.1 mmol/l Max: 2 g; Unclear D: 12 wks Grp2: Metformin + sulfonylurea Varied, glucose: 6.1 mmol/l Max: 2 g; Unclear D: 12 wks | Grp1 F-B: −0.78 (SE: 0.06) Grp2 F-B: −0.86 (SE: 0.06) Grp1-Grp2: 0.09 (CI: −0.08, 0.25) | Grp1 B: 111.15 (CV: 33.29) F: 116.22 (CV: 35.93) F-B: 5.07 Grp2 B: 114.27 (CV: 37.68) F: 108.03(CV: 37.3) F-B: −6.24 Grp1-Grp2: 11.31 (SE: 7.22) | Grp1 B: 46.8 (CV: 23.99) F: 51.48 (CV: 30.1) F-B: 4.68 Grp2 B: 46.41 (CV: 21.6) F: 47.58 (CV: 21.76) F-B: 1.17 Grp1-Grp2: 3.51 (SE: 2.02) | Grp1 B: 189.57 (CV: 56.4) F: 171.77 (CV: 65.97) F-B: −17.8 Grp2 B: 180.67 (CV: 47.72) F: 157.53 (CV: 42.82) F-B: −23.14 Grp1-Grp2: 5.34 | Grp1 F-B: 2.7 (SE: 0.3) Grp2 F-B: 1.6 (SE: 0.3) Grp1-Grp2: 1.1 p: 0.0016
Comaschi, 2007^129^ | Grp1: Metformin + pioglitazone Varied Max: 3 g; Start: 15 mg, Max: 30 mg D: NR; 22 wks Grp2: Metformin + sulfonylurea Varied, HbA1c: 7.50% Start: 400 mg, Max: 3 g; Start: 2.5 mg D: 22 wks | Grp1 F-B: −0.99 p: <0.001 Grp2 F-B: −1.29 p: 0.192 Grp1-Grp2: 0.31 p: 0.054
Comaschi, 2008^158^ | Grp1: Metformin + pioglitazone Varied Max: 3 g; Start: 15 mg, Max: 30 mg D: NR; 22 wks Grp2: Metformin + sulfonylurea Varied, HbA1c: 7.50%; Fixed Start: 400 mg; Start: 2.5 mg D: 22 wks | | | Grp1 B: 42.51 (SE: 12.09) F: 44.85 (SE: 10.92) F-B: 2.34 p: 0.009 Grp2 B: 45.63 (SE: 13.26) F: 42.12 (SE: 12.87) p: <0.001 F-B: −3.51 p: <0.001 Grp1-Grp2: 5.85 p: <0.001 | Grp1 B: 189.57 (SE: 97.9) F: 171.77 (SE: 101.46) F-B: −17.8 p: 0.067 Grp2 B: 178.89 (SE: 114.81) F: 181.56 (SE: 120.15) F-B: 2.67 p: 0.733 Grp1-Grp2: 2.67
Home, 2007^124^ | Grp1: Metformin + rosiglitazone Varied, HbA1c: <=7% Max: 2550 mg; Start: 4 mg, Max: 8 mg Grp2: Metformin + sulfonylurea Varied, HbA1c: <=7.0% Max: 2550 mg; Unclear D: 8 wks; NR | Grp1 F-B: −0.48 (CI: −0.59, −0.36) Grp2 F-B: −0.55 (CI: −0.66, −0.44) Grp1-Grp2: 0.07 (CI: −0.09, 0.23) | Grp1 F-B: 1.56 (CI: −2.73, 5.85) Grp2 F-B: −10.14 (CI: −14.04, −6.24) Grp1-Grp2: 11.7 (SE: 2.89) p: 0.01 | Grp1 F-B: 3.12 (CI: 1.95, 4.29) Grp2 F-B: 0.78 (CI: −0.39, 1.94) Grp1-Grp2: 2.34 (SE: 0.99) p: 0.016 | Grp1 F-B: 35.6 Grp2 F-B: 13.35 Grp1-Grp2: 23.14 | Grp1 F-B: 2.3 (CI: 1.7, 2.9) Grp2 F-B: 1.1 (CI: 0.6, 1.6) (cohort1), −0.9 (CI: −1.4, −0.4) (cohort2) Grp1-Grp2 (cohort 1): 1.2 (CI: 0.4, 2) p: 0.003; Grp1-Grp2 (cohort 2): 4.3 (CI: 3.6, 5.1) p: <0.001
Bakris, 2006^125^ | Grp1: Metformin + rosiglitazone Varied; Varied, glucose: <=6.6 mmol/L Unclear; Start: 4 mg D: 3 wks Grp2: Metformin + glyburide Varied; Glucose: <=6.6 mmol/L Unclear; Start: 5 mg D: 3 wks; NR | Grp1 F-B: 0.72 (SE: 0.1) Grp2 F-B: 0.92 (SE: 0.08) Grp1-Grp2: −0.2 (SE: 0.12) | | | | Grp1 F-B: 1.94 (4.63) Grp2 F-B: 1.5 (3.53) Grp1-Grp2: 0.44
Umpierrez, 2006^126^ | Grp1: Metformin + pioglitazone NR; Varied, glucose: <120 mg/dL, HbA1c: <8.0% Start: 1.54 g, Max: 1.57g; Start: 30 mg, Max: 45 mg D: NR; Unclear Grp2: Metformin + glimepiride NR; Glucose: <120 mg/dL Start: 1.47 g, Max: 1.49 g; Start: 2 mg, Max: 8 mg D: NR; 6 wks | Grp1 F-B: −1.23 (SE: 0.073) p: 0.4825 Grp2 F-B: −1.3 (SE: 0.077) Grp1-Grp2: 0.07 (SE: 0.11) | Grp1 F-B: 8.5 (SE: 2.81) Grp2 F-B: −0.1 (SE: 2.87) Grp1-Grp2: 8.5 (SE: 4.01) p: 0.0001 | Grp1 F-B: 4.8 (SE: 0.66) Grp2 F-B: −0.6 (SE: 0.7) p: 0.0001 Grp1-Grp2: 10 (SE: 9.53) p: 0.2953 | Grp1 F-B: −14.2 (SE: 6.57) Grp2 F-B: −4.2 (SE: 7.06) p: 0.2953 Grp1-Grp2: −10 (SE: 9.6) | Grp1 F-B: 1.85 (SE: 0.38) Grp2 F-B: 1.74 (SE: 0.41) Grp1-Grp2: 0.11
Derosa, 2005^127^ | Grp1: Metformin + rosiglitazone Fixed Start: 500 mg tid, Max: 500 mg tid; Start: 4 mg, Max: 4 mg Grp2: Metformin + glimepiride Fixed Start: 500 mg tid, Max: 500 mg tid; Start: 2 mg, Max: 2 mg | Grp1 B: 8 (0.7) F: 6.8 (0.6) p: <0.01 F-B: −1.2 Grp2 B: 7.9 (0.6) F: 7 (0.7) p: <0.05 F-B: −0.9 Grp1-Grp2: −0.3 (SE: 0.23)
Derosa, 2005^151^ | Grp1: Metformin + rosiglitazone Fixed Start: 500 mg tid; Start: 2 mg Grp2: Metformin + glimepiride Fixed Start: 500mg tid; Start: 4mg qday | | | | | Grp1 B: 74.2 (3.6) F: 68.3 (3) p: <0.01 F-B: −5.9 Grp2 B: 75.6 (4.2) F: 71.1 (3.2) p: <0.05 F-B: −4.5 Grp1-Grp2: −1.4
Derosa, 2006^157^ | Grp1: Metformin + rosiglitazone Fixed Start: 500 mg tid, Max: 500 mg tid; Start: 4 mg, Max: 4 mg Grp2: Metformin + glimepiride Fixed Start: 500 mg tid, Max: 500 mg tid; Start: 2 mg qday, Max: 2 mg qday | | Grp1 B: 116 (15) F: 120 (17) F-B: 4 Grp2 B: 118 (13) F: 102 (11) F-B: −16 p: <0.05 Grp1-Grp2: 20 p: <0.05 | Grp1 B: 42 (4) F: 44 (3) F-B: 2 Grp2 B: 43 (5) F: 43 (4) F-B: 0 Grp1-Grp2: 2 p: NSG
Garber, 2006^128^ | Grp1: Metformin + rosiglitazone Varied Start: 1500–2000 mg, Max: 2000 mg; Start: 4 mg, Max: 8 mg Grp2: Metformin + glibenclamide Varied Start: 1000 mg, Max: 2000 mg; Start: 5 mg, Max: 10 mg | | Grp1 B: 116 F: 125 F-B: 9 (35) Grp2 B: 119 F: 115 F-B: −4 (26) Grp1-Grp2: −14 (CI: −6, 22) p: NSG | Grp1 B: 45 F: 48 F-B: 3 (10) Grp2 B: 47 F: 45 F-B: −2 (10) Grp1-Grp2: 4 (CI: 1, 7) p: <0.05 | Grp1 B: 218 F: 238 F-B: 21 (113) Grp2 B: 226 F: 238 F-B: 12 (133) Grp1-Grp2: 9 (CI: −22, 40) p: NSG | Grp1 B: 94 F: 95.4 F-B: 1.4 Grp2 B: 92 F: 95 F-B: 3 Grp1-Grp2: −1.5 p: <0.001
Derosa, 2005^159^ | Grp1: Metformin + rosiglitazone Fixed Start: 1500 mg; Start: 4 mg Grp2: Metformin + glimepiride Fixed Start: 1500 mg, Start: 2 mg | | | | Grp1 B: 186 (28) F: 129 (18) F-B: −57 Grp2 B: 178 (23) F: 137 (20) F-B: −41 Grp1-Grp2: −16 p: NSG
Metformin + thiazolidinedione versus metformin + meglitinides
Raskin, 2009^131^ | Grp1: Metformin + rosiglitazone Varied, prespecified target dose; Varied Start: 1000 mg, Max: 2500 mg; Start: 4 mg, Max: 8 mg D: 4 wks Grp2: Metformin + repaglinide Varied Start: 1000 mg, Max: 2500 mg; Start: 4 mg, Max: 10 mg D: 4 wks | Grp1-Grp2: −0.21 (CI: −0.452, 0.031) | Grp1 B: 111.9 (SE: 2.88) F: 121.2 (SE: 3.51) F-B: 9.576 p:0.0008 Grp2 B: 108.2 (SE: 2.87) F: 104.6 (SE: 2.89) F-B: −2.604 p: 0.4637 Grp1-Grp2: 12.9 | Grp1 B: 44.8 (SE: 0.85) F: 49.4 (SE: 1.05) F-B: 4.479 p: <0.0001 Grp2 B: 44.3 (SE: 0.91) F: 44.2 (SE: 1.05) F-B: −0.151 p: NSG Grp1-Grp2: 4.63 p: <0.001 | Grp1 B: 208.8 (SE: 21.88) F: 208.2 (SE: 16.20) F-B: −0.6 p: 0.9493 Grp2 B: 190.3 (SE: 10.77) F: 194.9 (SE: 10.66) F-B: 4.6 p: 0.8607 Grp1-Grp2: −5.2 p: 0.6007 | Grp1-Grp2: not clinically relevant
Metformin + thiazolidinedione versus metformin + DPP-IV inhibitor
Scott, 2008^85^ | Grp1: Metformin + rosiglitazone NR; Fixed Start: >=1500 mg; Mean: 8 mg D: 10 wks; NA Grp2: Metformin + sitagliptin Fixed Start: > 1500 mg; Start: 100 mg, Mean: 100 mg | Grp1-Grp2: −0.06 (CI: −0.25, 0.14) | Grp1 B: 99.2 (29.4) F: 119.6 (37.6) F-B: Mean % change: 26.2 (CI: 19.7, 32.7) Grp2 B: 95.4 (30.8) F: 104.6 (35.1) F-B: Mean % change: 11.4 (CI: 5, 17.8) Grp1-Grp2: 11.2 (SE: 8.8) | Grp1 B: 42.2 (10) F: 45.7 (10.5) F-B: Mean % change: 9.2 (CI: 6.1, 12.2) Grp2 B: 43.9 (11.6) F: 45.7 (13.4) F-B: Mean % change: 4.3 (CI: 1.2, 7.3) Grp1-Grp2: 1.7 (SE: 3.03) | Grp1 B: 201.6 (126.2) F: 199.8 (108.4) F-B: Mean % change: 13.1 (CI: 5.2, 21.1) Grp2 B: 177.8 (80.7) F: 163.3 (74) F-B: Mean % change: −4.8 (CI: −12.7, 3.1) Grp1-Grp2: 12.7 | Grp1 F-B: 1.5 (CI: 1, 1.9) Grp2 F-B: −0.4 (CI: −0.8, 0) Grp1-Grp2: 1.9 (CI: 1.3, 2.5)
Rigby, 2009^130^ | Grp1: Metformin + rosiglitazone Fixed Mean: 4 mg Grp2: Metformin + sitagliptin Fixed Mean: 100 mg | Grp1 B: 8.09 F: 7.53 F-B: −0.6 (CI: −0.83, −0.32) p: <0.0001 Grp2 B: 8.19 F: 7.79 F-B: −0.4 (CI: −0.64, −0.13) p: 0.0087 Grp1-Grp2: −0.2 | | | | Grp1 F-B: 0.26 p: 0.5935 Grp2 F-B: −1.15 p: 0.0008 Grp1-Grp2: 1.41
Metformin + thiazolidinedione versus metformin + GLP-1 agonist
Defronzo, 2010^132^ | Grp1: Metformin + rosiglitazone Varied NR; Start: 4 mg, Max: 8 mg D: NR Grp2: Metformin + exenatide Varied Start: 0.010 mg, Max: 0.02 mg D: NR | Grp1 F-B: −1 (SD: 0.1) p: <0.05 Grp2 F-B: −0.9 (SD: 0.1) p: <0.05 Grp1-Grp2: −0.1 p: 0.72 | Grp1 F-B: 12.87 (3.9) p: <0.05 Grp2 F-B: −1.95 (3.9) p: >0.05 Grp1-Grp2: 14.82 p: 0.008 | Grp1 F-B: 2.34 (1.17) p:>0.05 Grp2 F-B: 0.78 (1.17) p:>0.05 Grp1-Grp2: 1.56 p: 0.445 | Grp1 F-B: 2.73 (6.63) p: >0.05 Grp2 F-B: −13.26 (6.63) p: <0.05 Grp1-Grp2: 15.99 p: 0.079 | Grp1 F-B: 1.5 (0.5) p: <0.05 Grp2 F-B: −2.8 (0.5) p: <0.05 Grp1-Grp2: 4.3 p: <0.001
Metformin + thiazolidinedione versus thiazolidinedione + sulfonylurea
Home, 2009^16^ | Grp1: Metformin + rosiglitazone Varied, HbA1c: <=7.0% Max: 2550 mg; Start: 4 mg, Max: 8 mg D: 8 wks; NR Grp2: Rosiglitazone + sulfonylurea Varied, HbA1c: <=7.0% Start: 4 mg, Max: 8 mg; NR D: Unclear; NR | Grp1 F-B: −0.28 (SE: 0.03) Grp2 F-B: −0.44 (SE: 0.03) Grp1-Grp2: 0.16 (SE: 0.04) p: <0.0001 | Grp1 F-B: −12.87 (SE: 1.56) Grp2 F-B: −8.58 (SE: 1.56) Grp1-Grp2: −4.29 (SE: 2.21) | Grp1 F-B: 4.68 (SE: 0.39) Grp2 F-B: 4.29 (SE: 0.39) Grp1-Grp2: 0.39 (0.55) | Grp1 F-B: −0.14 (SE: 0.04) Grp2 F-B: −0.13 (SE: 0.04) Grp1-Grp2: −0.01 p: 0.82 | Grp1 F-B: 3.8 (SE: 0.24) Grp2 F-B: 4.1 (SE: 0.2) Grp1-Grp2: −0.3
Comaschi, 2008^158^ | Grp1: Metformin + pioglitazone Varied, HbA1c: NR Max: 3 g; Start: 15 mg, Max: 30 mg Grp2: Pioglitazone + sulfonylurea Varied, HbA1c: <=7.5% Start: 15 mg, Max: 30 mg; NR D: 22wks | | Grp1-Grp2: p: 0.28 | Grp1 B: 42.51 (SE: 12.09) F: 44.85 (SE: 10.92) F-B: 2.34 p: 0.009 Grp2 B: 41.73 (SE: 12.87) F: 42.51 (SE: 13.26) F-B: 0.39 p: 0.617 Grp1-Grp2: 1.95 | Grp1 B: 189.57 (SE: 97.9) F: 171.77 (SE: 101.46) F-B: −17.8 p: 0.067 Grp2 B: 186.01 (SE: 120.15) F: 157.53 (SE: 83.66) F-B: −28.48 p: 0.017 Grp1-Grp2: 10.68 p: <0.05
Comaschi, 2007^129^ | Grp1: Metformin + pioglitazone Varied Max: 3 g; Start: 15 mg, Max: 30 mg D: NR; 22 wks Grp2: Pioglitazone + sulfonylurea Varied, HbA1c: 7.50%; Varied, NR Start: 15 mg, Max: 30 mg; Unclear D: 22 wks; NR | Grp1 F-B: −0.99 p: <0.001 Grp2 F-B: −1.29 p: <0.001 Grp1-Grp2: 0.3 p: 0.043
Home, 2007^124^ | Grp1: Metformin + rosiglitazone Varied, HbA1c: <=7% Max: 2550 mg; Start: 4 mg, Max: 8 mg Grp2: Rosiglitazone + sulfonylurea Varied, HbA1c: <=7.0% Start: 4 mg, Max: 8 mg; Unclear D: 8 wks | Grp1 F-B: −0.48 (CI: −0.59, −0.36) Grp2 F-B: −0.55 (CI: −0.67, −0.44) Grp1-Grp2: 0.06 (CI: −0.09, 0.2) | Grp1 F-B: 1.56 (CI: −2.73, 5.85) Grp2 F-B: 7.41 (CI: 3.12, 11.7) Grp1-Grp2: −18.72 (CI: −24.96, −12.48) | Grp1 F-B: 3.12 (CI: 1.95, 4.29) Grp2 F-B: 3.9 (CI: 2.73, 5.07) Grp1-Grp2: −0.78 | Grp1 F-B: 35.6 (CI: 22.25, 48.95) Grp2 F-B: 21.36 (CI: 5.34, 37.38) Grp1-Grp2: 5.34 (CI: −17.8, 28.48) | Grp1 F-B: 2.3 (CI: 1.7, 2.9) Grp2 F-B: 3.4 (CI: 2.9, 4) Grp1-Grp2: −1.1
Metformin + sulfonylurea versus metformin + meglitinides
Dimic, 2009^199^ | Grp1: Metformin + glimepiride Fixed Grp2: Metformin + repaglinide Fixed Mean: 2000 mg; Mean: 6 mg daily | Grp1 F-B: −1.04 p: <0.001 Grp2 F-B: −1.54 p: <0.001 Grp1-Grp2: 0.5 | Grp1 F-B: −0.55 p: <0.05 Grp2 F-B: −0.66 p: <0.05 Grp1-Grp2: 0.11 | Grp1 F-B: 0.01 p:>0.05 Grp2 F-B: −0.66 p:<0.05 Grp1-Grp2: 0.67 | Grp1 F-B: −0.4 p:>0.05 Grp2 F-B: −0.66 p:<0.05 Grp1-Grp2: 0.26
Derosa, 2009^135^ | Grp1: Metformin + glibenclamide Fixed Start: 1500 mg, Max: 3000 mg, Mean: 2500 mg; Start: 7.5 mg, Max: 15 mg, Mean: 12.5 mg D: 6 mos Grp2: Metformin + nateglinide Fixed Start: 1500 mg, Max: 3000 mg, Mean: 2500 mg; Start: 180 mg, Max: 360 mg, Mean: 300 mg D: 6 mos | Grp1 B: 8.2 (1.1) F: 7.3 (0.6) F-B: −0.9 p: <0.05 Grp2 B: 8.1 (1.0) F: 6.4 (0.4) F-B: −1.7 p: <0.01 Grp1-Grp2: 0.8 (SE: 0.18) p: 0.05 | Grp1 B: Median: 119 (12) F: Median: 104 (10) Grp2 B: Median: 121 (13) F: Median: 113 (11) | Grp1 B: Median: 42 (5) F: Median: 41 (4) Grp2 B: Median: 42 (5) F: Median: 43 (6) | Grp1 B: 161 (42) F: 140 (31) p: NSG F-B: −21 Grp2 B: 156 (40) F: 141 (33) p: NSG F-B: −15 Grp1-Grp2: −6 | BMI Grp1 B: 26.5 (1.5) F: 26.9 (1.7) F-B: 0.4 Grp2 B: 26.4 (1.4) F: 26.8 (1.6) F-B: 0.4 Grp1-Grp2: 0
Schwarz, 2008^152^ | Grp1: Metformin + glyburide Varied, glucose: <120 mg/dL Start: 500 mg, Max: 2000 mg; Start: 1.25 mg, Max: 10 mg D: 12 wks Grp2: Metformin + nateglinide Varied, glucose: <120 mg/dL Start: 500 mg, Max: 2000 mg; Start: 360 mg, Max: 360 mg D: 12 wks | Grp1 F-B: −1.2 (SE: 0.1) p: <0.001 Grp2 F-B: −1.2 (SE: 0.2) p: <0.001 Grp1-Grp2: 0 (SE: 0.22) | | | | Grp1-Grp2: no clinically relevant difference in weight
Gerich, 2005^136^ | Grp1: Metformin + glyburide Varied, glucose: FPG >=6.7 mmol/L; Fixed Start: 500 mg, Max: 2000 mg, Mean: 1459 mg; Start: 120 mg, Mean: 357 mg D: 12 wks; NA Grp2: Metformin + nateglinide Varied, glucose: FPG >=6.7 mmol/L Start: 500 mg, Max: 2000 mg, Mean: 1105 mg; Start: 1.25 mg, Max: 10 mg, Mean: 5.1 mg D: 12 wks | Grp1 B: 8.4 (1.2) F: 6.4 p: <0.0001 F-B: −1.5 (SE: 0.1) p: <0.0001 Grp2 B: 8.3 (1.1) F: 6.7 p: <0.0001 F-B: −1.2 (SE: 0.1) p: <0.0001 Grp1-Grp2: −0.3 (SE: 0.14) p: 0.173 | Grp1 F-B: 5% decrease Grp2 F-B: 5% decrease | Grp1 F-B: 5% increase Grp2 F-B: 5% increase | Grp1 F-B: 10% decrease Grp2 F-B: 10% decrease | Grp1 F-B: −0.4 (0.4) p: 0.8143 Grp2 F-B: 0.8 (0.5) p: 0.0011 Grp1-Grp2: −1.2 p: 0.0115
Metformin + sulfonylurea versus metformin + DPP-IV inhibitor
Seck, 2010^134^ | Grp1: Metformin + glipizide Fixed NR; Start: 5, Max: 20, Mean: 9.2 mg D: 2 Years Grp2: Metformin + sitagliptin Fixed NR D: 2 Years | Grp1 F-B: −0.35 (CI: −0.44, −0.26) Grp2 F-B: −0.33 (CI: −42, −0.25) Grp1-Grp2: −0.01 (CI: −0.1, 0.08) | | | | Grp1 F-B: 0.7 (CI: 0, 1.3) p: NSG Grp2 F-B: −1.6 (CI: −2.3, −1) p: NS Grp1-Grp2: 2.3 (1.6, 3) p: NSG
Nauck, 2007^133^ | Grp1: Metformin + glipizide Varied; Varied, glucose: <6.1 mmol/l NR; Start: 5 mg, Max: 20 mg D: Unclear; 18 wks Grp2: Metformin + sitagliptin Varied; Fixed NR | Grp1-Grp2: −0.01 (CI: −0.09, 0.08) | | | | Grp1-Grp2: −2.5 (CI: −3.1, −2) p: <.001
Metformin + sulfonylurea versus metformin + GLP-1 agonist
Derosa, 2010^44^ | Grp1: Metformin + glibenclamide NR Mean: 1500 mg; Start: 7.5 mg, Max: 15 mg D: NR Grp2: Metformin + exenatide NR NR; Start: 10 mcg, Max: 20 mcg D: NR | Grp1 B: 8.9 (0.8) F: 7.1 (0.2) p:NSG F-B: −1.8 p: <0.001 Grp2 B: 8.8 (0.7) F: 7.3 (0.3) F-B: −1.5 p: <0.001 Grp1-Grp2: −0.3 p: NSG | | | | Grp1 B: 82.4 (9.1) F: 86.7 (11.2) p: <0.05 F-B: 4.3 p: <0.05 Grp2 B: 82 (8.3) F: 74 (4.1) F-B: −8 p: <0.001 Grp1-Grp2: 12.3
Nauck, 2009^92^ | Grp1: Metformin + glimepiride Varied Start: 2000 mg, Max: 2000 mg; Start: 1 mg, Max: 4 mg Grp2: Metformin + liraglutide Fixed NR; Start: 0.6, Max: 1.2 | Grp1-Grp2: 1.1 (CI: 0.9, 1.3) | | | | Grp1 F-B: 1 (SE: 0.2) Grp2 F-B: −2.6 (SE: 0.2) Grp1-Grp2: 3.6 p: <0.01
Nauck, 2009^92^ | Grp1: Metformin + glimepiride Varied Start: 2000 mg, Max: 2000 mg; Start: 1 mg, Max: 4 mg Grp2: Metformin + liraglutide Fixed NR; Start: 0.6 mg, Max: 1.8 mg | Grp1-Grp2: 1.1 (CI: 0.9, 1.3) | | | | Grp1 F-B: 1 (SE: 0.2) Grp2 F-B: −2.8 (SE: 0.2) Grp1-Grp2: 3.8 p: <0.01
Pratley, 2010^143^ | Grp1: Metformin + sitagliptin Varied NR; Max: 100 mg D: NR Grp2: Metformin + liraglutide Varied, HbA1c: 7.5–10% NR; Start: 0.6 mg, Max: 1.2 mg D: NR | Grp1 F-B: −0.9 (CI: −1.03, −0.77) Grp2 F-B: −1.24 (CI: −1.37, −1.11) Grp1-Grp2: 0.34 (CI: 0.16, 0.51) p<0.0001 | Grp1 F-B: 0.13 (CI: 0.04, 0.22) Grp2 F-B: 0.05 (CI: −0.04, 0.17) Grp1-Grp2: 0.08 (CI: −0.04, 0.2) p: 0.2055 | Grp1 F-B: 0 (CI: −0.02, 0.02) Grp2 F-B: 0 (CI: −0.02, 0.03) Grp1-Grp2: 0 (CI: −0.03, 0.03) p:0.9225 | Grp1 F-B: −0.4 (CI: −0.58, −0.22) Grp2 F-B: −0.43 (CI: −0.61, −0.25) Grp1-Grp2: 0.03 (CI: −0.21, 0.28) p: 0.8021 | Grp1 F-B: −0.96 (CI: −1.5, −0.42) Grp2 F-B: −3.38 (CI: −3.91, −2.84) Grp1-Grp2: 2.42 (CI: 1.7, 3.14)
Pratley, 2010^143^ | Grp1: Metformin + sitagliptin Varied NR; Max: 100 mg D: NR Grp2: Metformin + liraglutide Varied, HbA1c: 7.5–10% Unclear; Start: 0.6 mg, Max: 1.8 mg D: NR | Grp1 F-B: −0.9 (CI: −1.03, −0.77) Grp2 F-B: −1.5 (CI: −1.63, −1.37) Grp1-Grp2: 0.6 (CI: 0.43, 0.77) p<0.0001 | Grp1 F-B: 0.13 (CI: 0.04, 0.22) Grp2 F-B: 0.08 (CI: −0.01, 0.17) Grp1-Grp2: 0.05 (CI: −0.07, 0.17) p: 0.4414 | Grp1 F-B: 0 (CI: −0.02, 0.02) Grp2 F-B: 0 (CI: −0.02, 0.02) Grp1-Grp2: 0 (CI: −0.03, 0.03) p:0.9507 | Grp1 F-B: −0.4 (CI: −0.58, −0.22) Grp2 F-B: −0.19 (CI: −0.38, 0) Grp1-Grp2: −0.21 (CI: −0.46, 0.04) p: 0.0962 | Grp1 F-B: −0.96 (CI: −1.5, −0.42) Grp2 F-B: −2.86 (CI: −3.39, −2.32) Grp1-Grp2: 1.9 (CI: 1.18, 2.61)
Metformin + sulfonylurea versus thiazolidinedione + sulfonylurea
Jonker, 2009^160^ | Grp1: Metformin + glimepiride Fixed Start: 500 mg BD, Max: 1000 mg BD; NR D: 2 Weeks Grp2: Pioglitazone + glimepiride Fixed Start: 15 mg OD, Max: 30 mg OD; NR D: 2 Weeks | Grp1 B: 7 (0.1) F: 6.3 (SE: 0.1) p:0.146 F-B: −0.7 Grp2 B: 7.1 (0.2) F: 6.5 (SE: 0.1) F-B: −0.6 Grp1-Grp2: −0.1 | | | Grp1 B: Median: 1.5 (IQR: 0.9, 2.1) F: Median: 1.7 (IQR: 0.9, 2.3) p: 0.596 Grp2 B: Median: 1.4 (IQR: 1, 2.2) F: Median: 1.4 (IQR: 0.9, 2.3)
Seufert, 2008^142^ | Grp1: Metformin + sulfonylurea Fixed Max: 2550 mg, Mean: 2081 mg; NR D: 12 wks Grp2: Pioglitazone + sulfonylurea Fixed Max: 45 mg, Mean: 37 mg; NR D: 12 wks | Grp1 B: 8.8 F: 7.64 F-B: −1.16 Grp2 B: 8.82 F: 7.79 F-B: −1.03 Grp1-Grp2: 0.13 (CI: −0.06 −0.31) p: 0.173 | | | | Grp1 F-B: −1.7 (4.5) Grp2 F-B: 3.2 (4.7) Grp1-Grp2: −4.9
Home, 2009^16^ | Grp1: Metformin + sulfonylurea Varied, HbA1c: <=7.0% Max: 2550 mg Grp2: Rosiglitazone + sulfonylurea Varied, HbA1c: <=7.0% Start: 4 mg, Max: 8 mg; NR D: Unclear; NR | Grp1 F-B: −0.18 (SE: 0.04) Grp2 F-B: −0.44 (SE: 0.03) Grp1-Grp2: 0.26 (SE: 0.05) p: <0.0001 | Grp1 F-B: −20.67 (SE: 1.17) Grp2 F-B: −8.58 (SE: 1.56) Grp1-Grp2: −12.09 (SE: 1.95) | Grp1 F-B: 2.73 (SE: 0.39) Grp2 F-B: 4.29 (SE: 0.39) Grp1-Grp2: 1.56 (SE: 0.55) | Grp1 F-B: −12.46 (SE: 3.56) Grp2 F-B: −11.57 (SE: 3.56) Grp1-Grp2: −0.89 (SE: 5.0) p: 0.82 | Grp1 F-B: −1.5 (SE: 0.2) Grp2 F-B: 4.1 (SE: 0.2) Grp1-Grp2: −5.6 p: <0.001
van der Meer, 2009^141^ | Grp1: Metformin + glimepiride Fixed; Varied Start: 1000 mg, Max: 2000 mg; NR D: NR; 8 wks Grp2: Pioglitazone + glimepiride Fixed; Varied Start: 15 mg, Max: 30 mg; NR D: 2 wks; NR | Grp1 B: 7 (SE: 0.1) F: 6.3 (SE: 0.1) p: <0.001 F-B: −0.7 Grp2 B: 7.1 (SE: 0.2) F: 6.5 (SE: 0.1) p: <0.001 F-B: −0.6 Grp1-Grp2: −0.1 (SE: 0.32) p: 0.146 | Grp1 B: 113.1 (SE: 3.9) F: 101.4 (SE: 7.8) p: 0.001 F-B: −11.7 Grp2 B: 97.5 (SE: 3.9) F: 97.5 (SE: 3.9) p: 0.38 F-B: 0 Grp1-Grp2: −11.7 (SE: 12.33) | Grp1 B: Median: 44.07 (IQR: 35.1, 55.38) F: Median: 39.78 (IQR: 33.54, 49.14) Grp2 B: Median: 41.73 (IQR: 36.66, 49.92) F: Median: 47.97 (IQR: 38.61, 56.94) | Grp1 B: Median: 133.5 (IQR: 80.1, 186.9) F: Median: 151.3 (IQR: 80.1, 204.7) p: 0.519 Grp2 B: Median: 124.6 (IQR: 89, 195.8) F: Median: 124.6 (IQR: 80.1, 204.7) p: 0.926 Grp1-Grp2: p:0.596 | Grp1 B: 92 (2) F: 92 (3) F-B: 0 Grp2 B: 91 (2) F: 94 (4) F-B: 3 Grp1-Grp2: −3 p: <0.001
Comaschi 2007^129^ | Grp1: Metformin + sulfonylurea Varied, HbA1c: 7.50% Start: 400 mg, Max: 3g; Start: 2.5 mg D: 22 wks Grp2: Pioglitazone + sulfonylurea Varied, HbA1c: 7.50%; Varied Start: 15 mg, Max: 30 mg; Unclear D: 22 wks; NR | Grp1 F-B: −1.29 p: 0.192 Grp2 F-B: −1.29 p: <0.001 Grp1-Grp2: 0.01 (SE: 0.27) p: 0.975
Comaschi, 2008^158^ | Grp1: Metformin + glibenclamide Varied, HbA1c: 7.50% Start: 400 mg; Start: 2.5 mg D: 22 wks Grp2: Pioglitazone + sulfonylurea Varied, HbA1c: 7.50% Start: 15 mg, Max: 30 mg; Unclear D: 22 wks | | | Grp1 B: 45.63 (SE: 13.26) F: 42.12 (SE: 12.87) p: <0.001 F-B: −3.51 p: <0.001 Grp2 B: 41.73 (SE: 12.87) F: 42.51 (SE: 13.26) F-B: 0.39 p: 0.617 Grp1-Grp2: −3.9 | Grp1 B: 178.89 (SE: 114.81) F: 181.56 (SE: 120.15) F-B: 2.67 p: 0.733 Grp2 B: 186.01 (SE: 120.15) F: 157.53 (SE: 83.66) F-B: −28.48 p: 0.017 Grp1-Grp2: 31.15 p: <0.05
Home, 2007^124^ | Grp1: Metformin + sulfonylurea Varied, HbA1c: <=7.0% Max: 2550 mg; Unclear D: 8 wks Grp2: Rosiglitazone + sulfonylurea Varied, HbA1c: <=7.0% Start: 4 mg, Max: 8 mg; Unclear | Grp1 F-B: −0.61 (CI: −0.7, −0.51) Grp2 F-B: −0.55 (CI: −0.67, −0.44) Grp1-Grp2: 0.06 (CI: −0.09, 0.2) | Grp1 F-B: −11.31 (CI: −15.6, −7.41) Grp2 F-B: 7.41 (CI: 3.12, 11.7) Grp1-Grp2: −18.72 (SE: 3.18) | Grp1 F-B: 3.12 (CI: 1.95, 4.29) Grp2 F-B: 3.9 (CI: 0.73, 5.07) Grp1-Grp2: −0.39 (CI: −1.95, 0.78) | Grp1 F-B: 15.13 (CI: −1.78, 32.04) Grp2 F-B: 21.36 (CI: 5.34, 37.68) Grp1-Grp2: 5.34 (CI: −17.8, 28.48) | Grp1 F-B: −0.9 (CI: −1.4, −0.4) Grp2 F-B: 3.4 (CI: 2.9, 4) Grp1-Grp2: 4.3 (CI: 3.6, 5.1) p: <0.001
Kim, 2007^42^ | Grp1: Metformin + glimepiride Fixed; Varied, glucose: 7.2 – 9.4 mmol/L Max: 1000 mg; Start: 2 mg, Max: 7 mg Grp2: Rosiglitazone + glimepiride Fixed; Varied, glucose: 7.2 – 9.4 mmol/L Max: 4 mg; Start: 2 mg, Max: 7 mg | Grp1 F-B: −1.1 (CI: −1.4, −0.8) p: <0.001 Grp2 F-B: −1.1 (CI: −1.5, −0.8) p: <0.001 Grp1-Grp2: 0 (SE: 0.24) p: 0.615 | Grp1 F-B: −6.24 (CI: −12.87, −0.78) p: 0.082 Grp2 F-B: −8.97 (CI: −1.56, 19.11) p: 0.158 Grp1-Grp2: 2.73 (SE: 6.11) | Grp1 F-B: −1.56 (CI: −0.39, 1.17) p: 0.246 Grp2 F-B: −4.29 (CI: −10.53, 1.56) p: 0.158 Grp1-Grp2: 2.73 p: 0.868 | Grp1 F-B: −8.9 (CI: −29.37, 11.57) p: 0.389 Grp2 F-B: −23.97 (CI: −47.17, −11.57) p: 0.002 Grp1-Grp2: 20.47 | Grp1 F-B: −0.5 (CI: −1.2, −0.2) p: 0.187 Grp2 F-B: 1.3 (CI: 0.8, 1.9) p: <0.00 Grp1-Grp2: −1.8 p: <0.001
Yang, 2003^139^ | Grp1: Metformin + sulfonylurea Fixed; NR Start: 1000 mg; NR Grp2: Rosiglitazone + sulfonylurea Fixed Start: 4 mg; NR | Grp1 B: 8.59 (1.78) F: 7.61 (1.47) p: <0.01 F-B: −0.95 (1.5) p: <0.01 Grp2 B: 8.61 (1.77) F: 7.46 (1.44) p: <0.01 F-B: −1.09 (1.65) p: <0.01 Grp1-Grp2: 0.14 (SE: 0.48)
Hanefeld, 2004^140^ | Grp1: Metformin + sulfonylurea Varied; NR Start: 850 mg, Max: 850 mg tid; NR Grp2: Pioglitazone + sulfonylurea Varied; NR Start: 15 mg, Max: 45 mg; NR | Grp1 B: 8.8 (0.97) F: 7.45 (0.06) F-B: −1.36 Grp2 B: 8.82 (0.98) F: 7.61 (0.06) F-B: −1.2 Grp1-Grp2: −0.16 p: 0.065 | Grp1 B: 139.23 (33.54) F: 142.74 (1.56) F-B: 3.12 Grp2 B: 139.62 (35.58) F: 132.99 (1.56) F-B: −6.24 Grp1-Grp2: 9.36 p: 0.0002 | Grp1 B: 42.51 (9.36) F: 48.75 (0.39) F-B: 6.24 Grp2 B: 43.29 (10.53) F: 46.41 (0.39) F-B: 3.12 Grp1-Grp2: 3.12 p: <0.0001 | Grp1 B: 219.83 (150.41) F: 178.89 (5.34) F-B: −40.94 Grp2 B: 211.82 (153.08) F: 191.35 (5.34) F-B: −20.47 Grp1-Grp2: −20.47 p: 0.008 | Grp1 B: 85.3 (15.1) F: 88.1 F-B: 2.8 Grp2 B: 84.9 (14.5) F: 83.9 F-B: −1 Grp1-Grp2: 3.8
Metformin + GLP-1 agonist versus metformin + basal insulin
Bunck, 2009^144^ | Grp1: Metformin + exenatide Fixed Mean: 2058 mg; Start: 5 ug b.i.d., Max: 20 micro g t.i.d. Grp2: Metformin + glargine Fixed Mean: 1798 mg; Start: 10 Units, Mean: 33.6 | Grp1 B: 7.6 (0.1) F: 6.8 F-B: −0.8 (SD: 0.1) Grp2 B: 7.4 (0.1) F: 6.8 F-B: −0.7 (SD: 0.2) p: 0.55 Grp1-Grp2: −0.1 | | | | Grp1-Grp2: −4.6 (1.1) p: 0.0001
Metformin + long-acting insulin versus metformin + premixed insulin
Robbins, 2007^145^ | Grp1: Metformin + glargine Fixed; Varied, glucose: <6.7 mmol/l Start: 500 mg tid, Max: 1000 mg tid, Mean: 1636 mg; Mean: 0.6 U/kg Start: QD, Final: QD Grp2: Metformin + insulin lispro 50/50 Fixed; Varied, glucose: <6.7 mmol/L Start: 500 mg tid, Max: 1000 mg tid, Mean: 1641 mg; Mean: 0.7 U/kg Start freq: NR, Final freq: tid | Grp1 F-B: −0.4 (0.9) Grp2 F-B: −0.7 (0.9) p: <0.001 Grp1-Grp2: 0.3 (SE: 0.32) p: <0.001 | | | | Grp1 B: 88.1 (19) F: 87.6 (19.3) p: 0.04 F-B: −0.5 Grp2 B: 89.1 (20.4) F: 90 (20.5) p: <0.001 F-B: 0.9 Grp1-Grp2: −1.4 p: <0.001
Raskin, 2007^146^ | Grp1: Metformin + glargine Fixed; Varied, glucose: 4.4 – 6.1 mmol/L before breakfast and dinner NR; Start: 12 U/day, Mean: 0.57 IU/kg Start freq: QD, Final freq: QD Grp2: Metformin + aspart 70/30 Fixed; Varied, glucose: 4.4 – 6.1 mmol/L NR; Start: 12 IU/day, Mean: 0.91 IU/kg Start freq: BID, Final freq: BID | Grp1 F-B: −2.46 (SE: 1.6) Grp2 F-B: −2.89 (SE: 1.6) Grp1-Grp2: 0.43 (SE: 2.26) p: 0.035 | | | | Grp1 F-B: 3 (4.3) Grp2 F-B: 5.6 (4.6) Grp1-Grp2: −2.6 p: 0.0004
Davies, 2007^147^ | Grp1: Metformin + NPH Varied NR; Start: 10, Mean: 0.58 IU/kg D: NR Grp2: Metformin + BHI 70/30 Varied NR; Start: 10 IU, Mean: 0.63 IU/kg D: NR | Grp1 B: 10 (2.2) F: 9.2 (1.4) F-B: −0.8 Grp2 B: 9 (1.1) F: 7.9 (1.1) F-B: −1.1 Grp1-Grp2: 0.3 | | | | Grp1-Grp2: 0.7
Metformin + premixed insulin versus metformin + sulfonylurea
Kvapil, 2006^138^ | Grp1: Metformin + aspart 70/30 Fixed; Varied, glucose: 5 – 8 mmol/L Mean: 1660 mg; Start: 0.2 U/kg, Mean: 0.30 U/kg Start freq: BID, Final freq: BID D: NA; Unclear Grp2: Metformin + glibenclamide Fixed; Varied Mean: 1660 mg; Start: 1.75 mg, Max: 10.5 mg, Mean: 6.58 mg D: NA; Unclear | Grp1 F-B: −1.7 Grp2 F-B: −1.7 Grp1-Grp2: 0.2 (SE: 0.15) p: >0.05 | | Grp1-Grp2: −1.95 (SE: 1.17) | Grp1 F: 204.7 (SE: 133.5) Grp2 F: 178 (SE: 97.9) F-B: 17.8 Grp1-Grp2: −13.35 (SE: 12.46) | Grp1 F-B: 0.8 Grp2 F-B: 0.1 Grp1-Grp2: −0.66 (0.41) p: 0.1
Malone, 2003^137^ | Grp1: Metformin + lispro 75/25 Varied; Varied, glucose: fasting and premeal glucose<7 mmol/L and 2-h post-prandial glucose <10 mmol/L Max: 2550 mg; Mean: 0.19U/kg in am and 0.14 U/kg in evening D: 4 wks; titrated throughout study period Grp2: Metformin + glibenclamide Varied; Varied, glucose: fasting and pre-meal goal <7mmol/L, 2- hour post-prandial goal <10 mmol/L Max: 2550 mg, Mean: 1968 mg; Mean: 14.2 mg D: 4 wks; titrated throughout study period | Grp2 B: 9.17 (1.5) F: 7.29 (1) F-B: −1.87 (1.35) p: <0.001 Grp1 B: 9.27 (1.55) p: 0.181 F: 7.33 (1.14) p: 0.661 F-B: −1.98 (1.28) p: <0.001 Grp1-Grp2: 011 (SE: 0.33) p: 0.288 | | | | Grp1 B: 83 (15.2) F: 84 (15.1) F-B: 1 Grp2 B: 81.7 (15.7) F: 82.2 (15.4) p: 0.33 F-B: 0.5 Grp1-Grp2: 0.5

ac or qac=before each meal ; ADA= American Diabetes Association; B=baseline; bid= twice a day; BMI=body mass index; CI=confidence interval; cv=coefficient of variation; D=duration of dose titration; dl=deciliter; F=final; F-B=mean difference from baseline to final; FPG=fasting plasma glucose; GLP-1 agonist = glucagon-like peptide-1 agonist; Grp1-Grp2=mean difference between the two groups; HDL=high density lipoprotein; IQR=inter quartile range; LDL=low density lipoprotein; Max=maximum; mg=milligram; mmol/l=millimoles per liter; mos=months; NA=not applicable; NR=not reported; NSG=not significant; PC= portion control; po=per oral; qday or qd=daily; SD=standard deviation; SE or SEM =standard error of the mean; tid= thrice a day; wks= weeks

All values for LDL, HDL, and triglycerides are reported in mg/dL. To convert to mmol/L, divide by 39 for LDL and HDL and divide by 89 for triglycerides.

Table 5 Number of studies, strength of evidence domains, magnitude of effect, and strength of evidence (KQ2)

Outcome: All-cause mortality
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/ Quality | Consistency | Directness | Precision | Magnitude and Direction of Effect
Met vs. TZD
4 RCTs | 4457 | Low | Consistent | Direct | Imprecise | Unclear | Low
Met vs. SU
5 RCTs, 8 obs | 50498 | Medium | Inconsistent | Direct | Precise | Small, favors metformin | Low
Met vs. DPP-4 Inhibitor
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met vs. Meg
1 RCT | 357 | Low | NA | Direct | Imprecise | Unclear | Low
Met vs. Met + TZD
5 RCTs | 2554 | Low | Consistent | Direct | Imprecise | Unclear | Low
Met vs. Met + SU
4 RCTs, 6 obs | 30211 | Medium | Consistent | Direct | Precise | Small, neither favored | Low
Met vs. Met + DPP-4 Inhibitor
1 RCT | 190 | Medium | NA | Direct | Imprecise | Unclear | Low
Met vs. Met + Meg
1 RCT | 350 | Low | NA | Direct | Imprecise | Unclear | Low
TZD vs. TZD
0 | NA | NA | NA | NA | NA | NA | Insufficient
TZD vs. SU
3 RCTs | 3986 | Low | Consistent | Direct | Imprecise | Unclear | Low
TZD vs. DPP-4 Inhibitor
0 | NA | NA | NA | NA | NA | NA | Insufficient
TZD vs. Meg
0 | NA | NA | NA | NA | NA | NA | Insufficient
SU vs. DPP-4 Inhibitor
0 | NA | NA | NA | NA | NA | NA | Insufficient
SU vs. Meg
1 RCT | 576 | Medium | NA | Direct | Imprecise | Unclear | Low
Sitagliptin vs. Meg
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and TZD vs. Met and SU
2 RCTs | 970 | Low | Consistent | Direct | Imprecise | Unclear | Low
Met and SU vs. Met and Meg
2 RCTs, 1 obs | 4432 | Low | Consistent | Direct | Imprecise | Unclear | Low
Met and SU vs Met and DPP-4 Inhibitor
1 RCT | 1172 | Low | NA | Direct | Imprecise | Unclear | Low
Met and Meg vs. Met and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and DPP-4 Inhibitor vs. Met and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and Exenatide vs. Met and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and Basal Insulin vs. Met and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and Premixed Insulin vs. Met and SU
2 RCTs | 819 | Low | Consistent | Direct | Imprecise | Unclear | Low
Met and TZD vs. TZD and SU
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and SU vs. TZD and SU
1 RCT | 639 | Medium | NA | Direct | Imprecise | Unclear | Low
Met and Meg vs. TZD and Met
1 RCT | 374 | Medium | NA | Direct | Imprecise | Unclear | Low
Met and Sitagliptin vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and Exenatide vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and Basal Insulin vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and Premixed Insulin vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient

Outcome: Cardiovascular disease mortality
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/ Quality | Consistency | Directness | Precision | Magnitude and Direction of Effect
Met vs. TZD
2 RCTs | 2950 | Medium | Consistent | Direct | Imprecise | Small. Neither favored. | Low
Met vs. SU
1 RCT 4 obs | 16788 | Medium | Consistent | Direct | Imprecise | Small. Met favored. | Low
Met vs. DPP-4 inhibitor
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met vs. Meg
1 RCT | 357 | Low | NA | Direct | Imprecise | Unclear | Low
Met vs. GLP-1 agonist
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met vs. Met + TZD
3 RCTs | 1479 | Low | Consistent | Direct | Imprecise | Small. Unclear. | Low
Met vs. Met + SU
2 obs | 4968 | Medium | Consistent | Direct | Imprecise | Unclear | Low
Met vs. Met + DPP-4 inhibitor
1 | 190 | Low | NA | Direct | Imprecise | Unclear. | Low
Met vs. Met + Meg
1 | 350 | Low | NA | Direct | Imprecise | Unclear | Low
TZD vs. TZD
0 | NA | NA | NA | NA | NA | NA | Insufficient
TZD vs. SU
1 | 2897 | Low | NA | Direct | Imprecise | Unclear | Low
TZD vs. DPP-4 inhibitor
0 | NA | NA | NA | NA | NA | NA | Insufficient
TZD vs. Meg
0 | NA | NA | NA | NA | NA | NA | Insufficient
TZD vs. GLP-1 agonist
0 | NA | NA | NA | NA | NA | NA | Insufficient
SU vs. DPP-4 inhibitor
0 | NA | NA | NA | NA | NA | NA | Insufficient
SU vs. Meg
1 | 576 | Low | NA | Direct | Imprecise | Unclear | Low
SU vs. GLP-1 agonist
0 | NA | NA | NA | NA | NA | NA | Insufficient
DPP-4 inhibitor vs. Meg
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and TZD vs. Met and Another Agent
1 RCT | 561 | Low | NA | Direct | Imprecise | Unclear | Low
Met and SU vs. Met and Another Agent
2 RCTs | 4447 | Low | Inconsistent | Direct | Imprecise | Unclear | Low
Met and Meg vs. Met and Another Agent
None | | | | | | | Insufficient
Met and DPP-4 inhibitor vs. Met and Another Agent
1 RCT | 1172 | Low | NA | Direct | Imprecise | Unclear | Low
Met and GLP-1 agonist vs. Met and Another Agent
1 RCT | 1172 | Low | NA | Direct | Imprecise | Unclear | Low
Met and Basal Insulin vs. Met and Another Agent
1 RCT | 91 | Low | NA | Direct | Imprecise | Unclear | Low
Met and Premixed Insulin vs. Met and Another Agent
2 | 438 | Low | Consistent | Direct | Imprecise | Unclear | Low
Met and TZD vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and SU vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and Meg vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and Sitagliptin vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and Exenatide vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and Basal Insulin vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and Premixed Insulin vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient

Outcome: Cardiovascular and cerebrovascular disease morbidity
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness | Precision | Magnitude and Direction of effect
Met vs. TZD
4 RCTs 9 obs | 640, 910 | Low | Inconsistent | Direct | Imprecise | Unclear | Low
Met vs. SU
2 RCTs, 5 obs | 609, 436 | Low | Inconsistent | Direct | Imprecise | Unclear. | Low
Met vs. DPP-4 inhibitor
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met vs. Meg
1 RCT | 701 | Low | NA | Indirect | Imprecise | Unclear | Low
Met vs. Met + TZD
6 RCTs 1 obs | 486,276 | Low | Consistent | Direct | Imprecise | Small. Met favored. | Low
Met vs. Met + SU
1 RCT, 1 obs | 10449 | Medium | Inconsistent | Direct | Imprecise | Small. Met favored. | Low
Met vs. Met + DPP-4 inhibitor
2 RCTs | 376 | Low | Consistent | Direct | Imprecise | Unclear. | Low
Met vs. Met + Meg
1 | 350 | Low | NA | Indirect | Imprecise | Unclear | Low
TZD vs. TZD
3 obs | 585,454 | High | Inconsistent | Direct | Imprecise | Unclear | Low
TZD vs. SU
3 RCTs 5 obs | 518914 | Low | Inconsistent | Direct | Imprecise | Unclear. | Low
TZD vs. DPP-4 inhibitor
0 | NA | NA | NA | NA | NA | NA | Insufficient
TZD vs. Meg
0 | NA | NA | NA | NA | NA | NA | Insufficient
SU vs. DPP-4 inhibitor
0 | NA | NA | NA | NA | NA | NA | Insufficient
SU vs. Meg
2 RCTs | 969 | Low | Inconsistent | Direct | Imprecise | Unclear | Low
SU vs. GLP-1 agonist
1 RCT | 411 | Low | NA | Direct | Imprecise | Unclear | Low
DPP-4 Inhibitor vs. Meg
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and TZD vs. Met and Another Agent
4 RCTs 1 obs | 474,644 | Low | Inconsistent | Direct | Imprecise | Unclear | Low
Met and SU vs. Met and Another Agent
3 RCTs | 6791 | Low | Inconsistent | Direct | Precise | Unclear | Low
Met and Meg vs. Met and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and DPP-4 inhibitor vs. Met and Another Agent
1 RCT | 665 | Low | NA | Indirect | Imprecise | Unclear | Low
Met and GLP-1 agonist vs. Met and Another Agent
1 RCT | 665 | Low | NA | Indirect | Imprecise | Unclear | Low
Met and Basal Insulin vs. Met and Another Agent
1 cross-over | 105 | Medium | NA | Direct | Imprecise | Unclear | Low
Met and Premixed Insulin vs. Met and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and TZD vs. TZD and Another Agent
2 RCTs, 2 obs | 488,535 | Low | Inconsistent | Direct | Imprecise | Unclear | Low
Met and SU vs. TZD and Another Agent
1 RCT | 639 | Low | NA | Indirect | Imprecise | Unclear | Low
Met and Meg vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and DPP-4 inhibitor vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and GLP-1 agonist vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and Basal Insulin vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient
Met and Premixed Insulin vs. TZD and Another Agent
0 | NA | NA | NA | NA | NA | NA | Insufficient

Outcome: Nephropathy
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: | Consistency | Directness | Precision | Magnitude and Direction of effect | Strength of Evidence
Met vs. TZD
2 RCT’s | 1715 | Low | Consistent | Indirect | Precise | Small. Favors pioglitazone | Moderate
Met vs. SU
1 RCT’s | 51 | High | NA | Indirect | Imprecise | Unclear | Low
TZD vs. SU
5 RCT’s | 375 | High | Inconsistent | Indirect | Imprecise | Unclear | Low
TZD vs. Meg
1 RCT | 68 | Low | NA | Indirect | Imprecise | Unclear | Low
Met and TZD vs. Met and Another Agent
1 RCT’s | 389 | Low | NA | Indirect | Imprecise | Unclear | Low

Outcome: Neuropathy
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: | Consistency | Directness | Precision | Magnitude and Direction of effect
Met vs. Met and TZD
1 RCT’s | 105 | Moderate | NA | Indirect | Imprecise | Unclear | Low
Met vs. Met and sitagliptin
1 RCT’s | 190 | High | NA | Indirect | Imprecise | Unclear | Low
Met and TZD vs. Met and Another Agent
1 RCT’s | 183 | High | NA | Indirect | Imprecise | Unclear | Low

Meg = meglitinides; Met = metformin; Nateg = nateglinide; Pio = pioglitazone; RCT, randomized controlled trial; Repag = repaglinide; Rosi = rosiglitazone; Sita = sitagliptin; SU = sulfonylurea; TZD = thiazolidinedione

All other comparisons were graded as insufficient since there were no studies of those comparisons.

The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable.

Table 6 Study design characteristics of studies reporting on the comparative effectiveness of diabetes medications on long term outcomes (KQ2)

Author, year Country | Study design | Enrollment period Followup duration | Run-in period | Planned interval of followup | Pharmaceutical support | Number screened/enrolled Source population | Exclusion criteria
Seino, 2010^121^ Japan | RCT | Neither year reported 24 weeks | Yes | <6 months | Yes | NR/464 NR | Age <20 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), retinopathy, HbA1c < 7% or >10%, BMI >35 kg/m^2^, treated with insulin within 12 weeks of the start of the study, receiving or expecting to receive systemic corticosteroids, known hypoglycemia unawareness or recurrent major hypoglycemia unawareness or recurrent major hypoglycemia, no Type 2 DM, treated with diet therapy for less than 8 weeks, on more than 1/2 of the recommended maximum dose of an SU (e.g., on more than 2.5 mg of glibenclamide)
Aschner, 2010^77^ Multi-continent | RCT | Neither year reported 24 weeks | Run-in period but number of participants excluded not reported | NR | Yes | 2068/1050 NR | Age <18 or >78 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <6.5% or >9%, treatment naive, no Type 2 DM, FPG <120 or >250 mg/dL, triglycerides >600 mg/dL, CK > 2x upper limit normal
Seck, 2010^134^ NR | RCT | Neither year reported 2 years | Run-in period but number of participants excluded not reported | < 6 months | Yes | 2141/1172 NR | Age <17 or >78 years
Pratley, 2010^143^ Multi-continent, Europe, USA and Canada | RCT | Neither year reported 2 years | No run-in period | >= 6 months | Yes | 1302/665 “office based”-possibly outpatient | Age <18 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c >7.5% or <10%, BMI >45 kg/m2, no Type 2 DM, cancer, contraindication to trial drugs, recurrent hypoglycemia or hypoglycemia unawareness, not on metformin for at least 3 months, on any non-metformin ODM in past 3 months
Brownstein, 2010^182^ United States | Cohort | Start year: 2000 End year: 2006 7 years | NA | NA | No | NA/34252 Inpatient/hospital, Outpatient: primary care, Outpatient: subspecialty care setting | Age ≤ 18 years, HbA1c ≤ 6.0%, no diagnosis of DM with ICD-9 code of 250.XX
Pantalone, 2009^174^ United States | Cohort | Start year: 1998 End year: 2006 8 years | NA | NA | Yes | NA/20450 Inpatient/hospital, Outpatient: primary care, Outpatient: subspecialty care setting | Age <18 years, history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), on dialysis, on combination ODM, on insulin or other injectible antidiabetics, history of CHF
Hsiao, 2009^173^ Taiwan | Cohort | Start year: 2000 End year: 2005 6 years | NA | NA | NR | NA/20450 Inpatient/hospital, Outpatient: primary care, Outpatient: subspecialty care setting | Type 1 DM, prescribed insulin only during study period, new diagnosis of Type 2 DM during the year before index date, switch between rosiglitazone and pioglitazone or combined use of both drugs during study period, prescribed ODM less than three times during study period
Tzoulaki, 2009^171^ United Kingdom | Cohort | Start year: 1990 End year: 2005 7.1 years (mean) | NA | NA | No | NA/91521 Inpatient/hospital, Outpatient: primary care, Outpatient: subspecialty care setting | Age <35 or >90 years, no diabetes, multiple or missing dates of death, missing information, no treatment with medications
Rigby, 2009^130^ United States, Multi-continent | RCT | Start year: 2007 End year: 2008 16 weeks | No run-in period | < 6 months | Yes | 356/169 NR | Age <18 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c >10% (9.5% if on metformin combination therapy), HbA1c < 7% (6.5% if on metformin combination therapy), BMI > 40 kg/m2, LDL<50mg/dl or TG > = 500 mg/dL, weight loss program with ongoing weight loss or starting an intensive exercise program within 4 weeks of screening, need for oral corticosteroids, bile acid sequestrants, or any antidiabetes medications other than metformin, >2 months insulin, not on metformin for >=3 months (1500–2550 mg/day, Type 1 DM and/or ketoacidosis, dysphagia/swallowing disorders, intestinal motility disorders, pancreatitis, HIV/AIDS, drug/alcohol abuse within 2 years, any serious disorder including pulmonary, hepatic, gastrointestinal, uncontrolled endocrine/metabolic, hematologic/oncologic (within 5 years), neurologic, or psychiatric diseases, current treatment with TZD/combo with metformin/colesevelam/fixed-dose combination product including metformin, hospitalization within 14 days of screening
Juurlink, 2009^210^ Canada | Cohort | Start year: 2002 End year: 2008 3 years | NA | NA | No | NA/39736 Outpatient: Primary care | Age <66 years, patients on rosiglitazone or pioglitazone before the index date, patients on insulin before the index date
Jadzinsky, 2009^78^ Multi-continent | RCT | Start year: 2006 End year: 2007 24 weeks | Fewer than 10% participants excluded | <6 months | Yes | 2936/1394 Outpatient: primary care, Outpatint: subspecialty care | Age <18 or >77 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g. "failed initial treatment"), HbA1c < 8% or >12%, BMI >40 kg/m^2^, prior treatment, diabetic ketoacidosis or nonketotic hyperosmolar coma, CVD events 6 months prior, LVEF <40%, psychiatric history, alcohol or drug abuse, abnormal metabolic or hematologic test
Home, 2009^16^ Multinational Europe | RCT | Start year: 2001 End year: 2003 7.5 years | Run-in period but number of participants excluded was NR | >= 6 months | Yes | 7428/4458 Outpatient: primary care | Age <40 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), contraindication or history of intolerance to metformin, HbA1c < 7% or >9%, BMI <25 kg/m^2^, pregnant, nursing, not using adequate contraception, recent CAD event, heart failure
Raskin, 2009^131^ NR | RCT | Neither year reported 26 weeks | No run-in period | < 6 months | Yes | 1093/383 Outpatient: primary care | Age <18 years, pregnant, nursing, currently not under monotherapy at least 2 months or dual therapy, FBG >260 mg/dL, any disease of abnormality as judged by the investigator, treatment with the investigational drug for 4 weeks, allergy to study drugs or related compounds, history of hypoglycemia unawareness or recurrent severe hyperglycemia
Scott, 2008^85^ Multi-continent | RCT | Neither year reported 18 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | 486/273 NR | Age <18 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), HbA1c < 7% or >11%, not on 10 weeks on stable dose of metformin, insulin use, Type 1 DM, glucose > 270 mg/dL
Raz, 2008^93^ Multi-continent | RCT | Neither year reported 30 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | 544/190 NR | Age <18 or >78 years, HbA1c <8% after run-in or HbA1c >11% after run-in, BMI <20 kg/m^2^ or >43 kg/m^2^, pregnant, nursing, insulin within 8 weeks prior to screening, PPAR-G or incretin mimetics within 12 weeks prior to screening, Type 1 DM, FPG <7.2 mmol/l or >15.6 mmol/L consistently during run-in, no Type 2 DM
Hamann, 2008^123^ Multinational Europe, Mexico | RCT | Neither year reported 52 weeks | Yes | < 6 months | NR | 818/596 NR | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <7% or >10%, BMI <25 kg/m^2^, used any ODM other than metformin in the prior 12 weeks, or insulin at any time other than during pregnancy or for emergency treatment, history of metabolic acidosis, edema requiring pharmacological treatment (either ongoing or within the prior 12 months), anemia (hemoglobin < 11.0 g/dl for men and < 10.0 g/dl for women), C-peptide <0.5nmol/L, SBP >170 mmHg, DBP >100 mmHg
Schwarz, 2008^152^ US | RCT | Neither year reported 104 weeks | Run-in period but number of participants excluded was NR | < 6 months | NR | 75/69 NR | Age <18 or >77 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), contraindication or history of intolerance to metformin, HbA1c <7.0% or >11.0%, BMI <22 or >45 kg/m^2^, FBG >270 mg/dL, history of lactic acidosis, congestive cardiac failure requiring pharmacologic treatment, Type 1 DM or secondary forms of DM
Monami, 2008^180^ Italy | Cohort | Start year: 1993 End year: 2001 28 months | NA | NR | NR | NA (for cohort studies, claims data, etc)/1108 Outpatient: primary care, Geriatric clinic | Insulin treatment was an exclusion, not Type 2 DM by WHO 1985 criteria
Hanefeld, 2007^100^ Multinational Europe | RCT | Neither year reported 52 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | NR/598 NR | Age <40 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), BMI <22 kg/m^2^ or >38 kg/m^2^, pregnant, patient on insulin therapy, patient with diabetic complications requiring treatment, hematologic impairment, FPG: <7 mmol/l or >15 mmol/l, C-peptide <0.27 nmol/l
Comaschi, 2007^129^ Italy | RCT | Neither year reported 6 Months | Run-in period but number of participants excluded was NR | < 6 months | Yes | 398/250 NR | Age <35 years, HbA1c <7.5% or >11%, had not received SU or metformin as a monotherapy at a stable dose for at least 3 months, fasting C-peptide <0.33 nmol/L
Nauck, 2007^133^ US, Multinational Europe, Multi-continent | RCT | Neither year reported 52 weeks | Yes | < 6 months | Yes | 2141/1172 NR | Age <18 or >78 years, any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), FPG >15 mmol/L, insulin use within 8 weeks of screening, history of Type 1 DM, other treatments for hypoglycemia
Kahler, 2007^175^ US | Cohort | Start year: 1998 End year: 2001 3 years | NA | NA | No | > 1500000/39721 VHA Medical facilities | Age <18 years, non-respondents to 1999 LHSVE survey, medical facilities that do not have assays certified by the National Glycohemoglobin Standardization Program, less than 15 month window period after 1 year exposure to drug, alive as of 31 December 2000, fixed one year window of drug exposure
McAfee, 2007^181^ US | Cohort | Start year: 2000 to 2004 End year: 2005 NR | NA | NA | Yes | NA (for cohort studies, claims data, etc)/31075 Ingenix research claims database | Age >18 years, less than 6 months in insurance plan, insulin or study drug given within 6 months prior to study, insulin or other drug given within 30 days after monotherapy initiation, no medical or pharmacy benefits
Nakamura, 2006^108^ Japan | RCT | Neither year reported 12 months | No run-in period | < 6 months | NR | NR/68 NR | HbA1c >6.5%, history of ketoacidosis, treatment other than by diet alone, fasting C-peptide level < 0.33 mmol/L, hematuria, non-diabetic renal disease, microalbuminura defined as a median urinary albumin excretion of 20 to 200 ug/min
Kahn, 2006^38^ Multi- continent | RCT | Start year: 2000 End year: 2006 6 Years | No run-in period | NR | Yes | 6676/4360 NR | Age <30 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), uncontrolled hypertension, FPG <126 or > 180 mg/dL, history of lactic acidosis
Rosenstock, 2006^49^ Multi-continent | RCT | Start year: 2003 to 2004 32 weeks | Yes | < 6 months | Yes | 1252/468 multicenter | Age <18 or >70 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c < 7% or > 11%, FPG >15 mmol/l, hematological disease, uncontrolled hypertension while on antihypertensive treatment, intermittent or chronic use of oral or intravenous corticosteroids, investigators discretion, use of investigational agent within 30 days of the study (or five half live of the investigational drug if longer than 30 days), previous history of severe edema or medically serious fluid related event associated with TZD, acute or chronic metabolic acidosis, history of diabetic ketoacidosis
Jain, 2006^101^ US, Puerto Rico | RCT | Neither year reported 56 weeks | Run-in period but number of participants excluded was NR | < 6 months | NR | NR/502 NR | Age <18 or >80 years, any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g. failed initial treatment), HbA1c< 7.5% or >11.5%, pregnant, nursing, duration of DM > than 2 years, intolerance to Rosi, Pio or Troglitazone, drug or alcohol abuse, previous treatment with meglitinide analog, alpha glucosidase inhibitor, metformin, insulin, SU for 3 months or more, use of hydrochlorothiazide, joint injections, niacin greater than 250 mg/day, oral antidiabetic drugs, concurrent participation in another investigational study, serum creatinine level > 1.5mg/dl of men, 1.4 mg/dl for women, 1 + proteinuria, anemia (< 10g/dl women, < 12g/dl men), BMI ≤ 20kg/m^2^ or >45kg/m^2^, hypertension, chronic pulmonary disease, history of cancer not in remission for at least 5 years
Bakris, 2006^125^ US, Multi- continent, South America, Europe | RCT | Neither year reported 32 weeks | Yes | < 6 months | Yes | 560/514 NR | Age <40 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), BMI < 22 kg/m^2^, use of any TZD in the 3 months prior to screening, use of insulin for ≥ 6 months at any time prior to screening, anemia, severe angina, SBP >159 mm Hg (can't adjust the BP meds during the trial), DBP >99 mm Hg
Kvapil, 2006^138^ Multinational Europe | RCT | Neither year reported 16 weeks | No run-in period | < 6 months | NR | NR/341 NR | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), retinopathy, recurrent severe hypoglycemia, anemia, change in dose of meds known to interfere with glucose metabolism, inclusion criteria includes not adequately controlled on metformin
Stewart, 2006^156^ Multinational Europe | RCT | Start year: 2003 to 2004 32 weeks | Yes | < 6 months | Yes | 1397/526 NR | Age <18 or >70 years, history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c < 7% or > 9%, drug naive patients with FPG <7 mmol/l or >9 mmol/l, patient on monotherapy with FPG < 6.0 mmol/l or > 8 mmol/l, prior history of exposure to thiazolidinediones within previous 6 months, use of insulin anytime in the past, uncontrolled hypertension
Simpson, 2006^166^ Canada | Cohort | Start year: 1991 End year: 1999 8 years | NA | NA | No | 12272/5795 Saskatchewan health databases | Age <30 years, patients on insulin, patients on two or more ODM
Rosak, 2006^183^ Germany | Cohort | Neither year reported 6 months | NA | < 6 months | Yes | NR/22808 Outpatient: primary care, Outpatient: subspecialty care setting | Not all treated with rosiglitazone
Malone, 2005^165^ Multinational Europe | RCT | Neither year reported 32 weeks | Yes | < 6 months | Yes | 119/97 NR | Age <30 or >75 years, HbA1c >2.0 times the upper limit of normal, HbA1c <1.3 times the upper limit of normal, used glitazones within 30 days prior to the study, used NPH QD or BID 30-days prior to entry, expected to benefit from prandial control
Weissman, 2005^86^ US | RCT | Neither year reported 24 weeks (planned duration) | Run-in period but number of participants excluded was NR | < 6 months | Yes | 1270/766 NR | Age <18 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <6.5% for subjects having received prior combination treatment (metformin + SU), HbA1c >8.5% for subjects having received prior combination treatment (Metformin + SU), BMI <27 kg/m^2^, HbA1c < 7% for drug naive or prior monotherapy subjects, HbA1c > 10% for drug naive or prior monotherapy subjects, FPG < 126 mg/dL or >270 mg/dL, anemia, severe edema, prior insulin use within 3 months of study start, non-compliant patient with metformin up-titration
Bailey, 2005^87^ UK, 14 European countries | RCT | 24 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <18 or >70 years, history of CVD, no Type 2 DM, other
Gerich, 2005^136^ US | RCT | Neither year reported 2 Years | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | 908/428 NR | Age <18 or >77 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), neuropathy, retinopathy, HbA1c < 7% or >11%, BMI <22kg/m^2^ and >45 kg/m^2^, not using adequate contraception, FPG ≥ 15mmol/L, if Type 1 DM, symptomatic hypoglycemia with >10% weight loss in previous 8 weeks, history of lactic acidosis or CHF requiring meds, other medical conditions that could interfere with interpretation of results or pose sig risk to the subject, had to be drug naive
Johnson, 2005^167^ Canada | Cohort | Median followup periods for each group ranged from 4.6 to 5.6 yeas | Not extracted | Not extracted | No | Not extracted | Age < 30 years, no Type 2 DM, other
Eurich, 2005^169^ Canada | Cohort | 2.1 years (mean followup) | Not extracted | Not extracted | No | Not extracted | History of CVD, treatment experienced, other
Evans, 2005^176^ Scotland | Cohort | Neither year reported 8 Years | Not extracted | NA | NR | 6089/5730 NR | Diagnosed under the age of 35 years, requirement for insulin within 90 days of diagnosis or their first ODM prescription, ODM users before January 1994
Agarwal, 2005^184^ US | RCT | Start year: 2001 End year: 2003 16 Weeks | No run-in period | < 6 months | Yes | 102/54 Outpatient: subspecialty care setting | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), BMI >40 kg/m^2^, class III or IV heart failure, NSAID use
Schernthaner, 2004^52^ Europe | RCT | 12 months (planned duration) | Not extracted | Not extracted | No | Not extracted | Age <35 or >75 years, treatment experienced, HbA1c <7.5% or >11%, no Type 2 DM
Lawrence, 2004^53^ U.K. | RCT | 12 titration, 12 week maintenance (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <45 or >80 years, any liver disease, any kidney disease, history of CVD, HbA1c for diet treated diabetes: <7% or >10% for low-dose ODM: >7.5%, no Type 2 DM, other
Nakamura, 2004^102^ Japan | RCT | Neither year reported 12 Months | No run-in period | >= 6 months | NR | NR/45 Inpatient/hospital | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c > 6.5%, BP <140/90 mm Hg, controlled on diet alone, no history ketoacidosis, c peptide <0.33mmol/L, creatinine <1.5, no BP meds, malignancy, no microalbuminuria, collagen vascular disease, non-diabetic renal disease
Hanefeld, 2004^140^ Canada, U.K., Hungary, Finland, Slovak Republic, Belgium, Estonia, Lithuania, Denmark, Italy, Greece, Sweden, and Netherlands | RCT | NR | Not extracted | Not extracted | Yes | Not extracted | Age <35 or >75 years, history of CVD, HbA1c <7.5% or >11%, no Type 2 DM, other
Malone, 2004^164^ U.S. | RCT | Neither year reported 32 weeks | Yes | < 6 months | Yes | 145/111 NR | Age <30 or >80 years, HbA1c <1.3 or >2.0 times normal, BMI >40 kg/m^2^, HbA1c value that is less than or greater than 1.3 and 2.0 times the ULN within 30 days before the study, while using 1 or more ODM without insulin for 30 or more days before study start
Gulliford, 2004^170^ U.K., Wales, Scotland, and Ireland | Cohort | Median followup for each group ranged from 1.67 to 3.49 years | Not extracted | Not extracted | No | Not extracted | Treatment experienced, no Type 2 DM, other,
Garber, 2003^61^ U.S. | RCT | 16 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age < 20 or >79 years, any liver disease, any kidney disease, treatment experienced, HbA1c >7% or <12%, no Type 2 DM, other
Goldstein, 2003^62^ U.S. | RCT | 18 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, history of CVD, HbA1c <7.5% or >12.0%, other
Bakris, 2003^104^ likely U.S. and U.K. | RCT | 52 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | NR
Malone, 2003^137^ 14 countries not specified | randomized, open-label, 2 arm parallel prospective study | Neither year reported 16 weeks | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | NR/597 subgroup completing test meals | Age <30 or >75 years, HbA1c <125% of upper limit of normal by local lab within 4 weeks prior to entry, BMI >40 kg/m^2^, not Type 2 DM, not use of single oral agent (metformin or SU) for 3 months prior to study at maximum clinically effective dose for previous 30 days
Jones, 2003^179^ U.S. | RCT | Neither year reported 6 months | Run-in period but number of participants excluded was NR | < 6 months | NR | NR | Age <40 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), neuropathy, CHF, history chronic insulin, FPG <140 or >300 mg/dL, prior rosiglitazone study, use on any investigational drug within 30 days
Hallsten, 2002^55^ Finland | RCT | 26 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, history of CVD, no Type 2 DM, other
Gomez-Perez, 2002^88^ Mexico | RCT | 26 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <40 or >80 years, any liver disease, any kidney disease, history of CVD, treatment experienced, no Type 2 DM, other
St John Sutton, 2002^149^ US | RCT | 52 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <40 or age >80 years, any liver disease, any kidney disease, history of CVD, no Type 2 DM, other
Johnson, 2002^168^ Canada | Cohort | 5.1 years (mean followup) | Not extracted | Not extracted | No | Not extracted | Age <30 years, other
Fisman, 2001^177^ Israel | Cohort | 7.7 years (mean followup) | Not extracted | Not extracted | No | Not extracted | Age < 45 or >74 years, any liver disease, any kidney disease, other
Amador-Licona, 2000^66^ Mexico | RCT | 12 weeks (planned duration) | Not extracted | Not extracted | No | Not extracted | Age >65 years, any liver disease, history of CVD, other
Horton, 2000^79^ US | RCT | 24 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <30 years, any kidney disease, HbA1c <6.8% or >11%, no Type 2 DM, other
Fonseca, 2000^90^ US | RCT | 26 weeks (planned duration) | Not extracted | Not extracted | No | Not extracted | Age <40 or >80 years, any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, no Type 2 DM, other
Nakamura, 2000^103^ Japan | RCT | 3 months (planned duration) | Not extracted | Not extracted | No | Not extracted | Any liver disease, history of CVD, treatment experienced, HbA1c <6.5%, no Type 2 DM, other
Wolffenbuttel, 1999^116^ Germany, Austria, and Netherlands | RCT | 12 months (planned duration) | Not extracted | Not extracted | No | Not extracted | Age <40 or >75 years, any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <6.5% if treated with diet only, HbA1c >12% if treated with diet plus oral, other
Marbury, 1999^117^ US and Canada | RCT | 12 months (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age >37 or <75 years, any liver disease, any kidney disease, history of CVD, treatment experienced, retinopathy, HbA1c <6.5% or >14.6%, no Type 2 DM, other
Fisman, 1999^178^ NR | Cohort | Neither year reported 6 years | NA | NA | NR | NR/14440 Community | Age < 45 and > 75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), pacemaker, hepatitis, renal disease, malignancy, insulin, estrogen replacement
DeFronzo, 1995^70^ U.S. | RCT | 29 weeks (planned duration) | Not extracted | Not extracted | No | Not extracted | Age <40 or >70 years, any liver disease, any kidney disease, history of CVD, treatment experienced, no Type 2 DM, other
Hermann, 1994^68^ Sweden | RCT | 6 months (planned duration) | Not extracted | Not extracted | Yes | Not extracted | No Type 2 DM, other

ALT = alanine aminotransferase; AST = asparate aminotransferase; BID = twice a day; BMI = body mass index; BP = blood pressure; CAD = coronary artery disease; CHF = congestive heart failure; CK = creatine kinase; CVD = cardiovascular diseases; DBP = diastolic blood pressure; DM = diabetes mellitus; FBG = fasting blood glucose; FPG = fasting plasma glucose; g/dl = grams per deciliter; GFR = glomerular filtration rate; HbA1c = hemoglobin A1c; ICD-9 = International Statistical Classification of Diseases and Related Health Problems-9; kg = kilogram; kg/m2 = kilogram per meter squared; LDL = low density lipoprotein; LHSVE = Large Health Survey of Veteran Enrollees; LVEF = left ventricular ejection fraction; mg/d = milligrams per day; mg/dl = milligrams/deciliter; mmHg = millimeters of mercury; mmol/L = millimoles per liter; NA = not applicable; nmol/L = nanomoles per liter; NPH = neutral protamine Hagedorn; NR = not reported; NSAID = non-steroidal anti-inflammatory drugs; ODM = oral diabetes medication; PPAR-G = peroxisome proliferator-activated receptor gamma; QD = once a day; RCT = randomized controlled trial; SBP = systolic blood pressure; SGOT = glutamyl oxaloacetic transaminase; SGPT = serum glutamyl pyruvic transaminase; SU = sulfonylurea; TG = triglycerides; TZD = thiazolidinedione; VHA = Veterans Health Administration; WHO = World Health Organization

Table 7 Population characteristics of the studies reporting on the comparative effectiveness of diabetes medications on long-term outcomes (KQ2)

Author, year | Group, N | Mean age (age range), Age categories(n;) in years | Male, % | Race, n % | Mean BMI in kg/m2 Mean weight in kg | Mean HbA1c (other measure) | Mean duration of diabetes in years | N of withdrawals
Brownstein, 2010^182^ | Pioglitazone, 806 | 63.7 | 52 | NR | NR NR | 8.1 | NR | NR
Brownstein, 2010^182^ | Rosiglitazone, 1879 | 64 | 51.7 | NR | NR NR | 8 | NR | NR
Brownstein, 2010^182^ | Metformin, 12490 | 61.7 | 49.9 | NR | NR NR | 7.8 | NR | NR
Brownstein, 2010^182^ | Any in the Sulfonylurea class, 11200 | 65.8 | 57.5 | NR | NR NR | 7.7 | NR | NR
Seino, 2010^121^ | Glibenclamide, 132 | 58.5 | 65 | Asian: 100 | 24.4 NR | 8.978 | 8.5 | 12
Seino, 2010^121^ | Liraglutide, 268 | 58.2 | 68 | NR | 24.5 NR | 8.92 | 8.1 | 22
Aschner, 2010^77^ | Metformin, 439 | 55.7 | 44 | NR | 30.9 NR | 7.2 | 2.1 | 75
Aschner, 2010^77^ | Sitagliptin, 455 | 56.3 | 48 | NR | 30.7 NR | 7.2 | 2.6 | 61
Seck, 2010^134^ | Metformin + sitagliptin, 248 | 57.6 | 57.3 | AA: 3.6, Asian: 9.3, C: 77.4, H: 5.6, Other: 4 | 30.9 88.5 kg | 7.3 | 5.8 | 231
Seck, 2010^134^ | Metformin + glipizide, 584 | 57 | 62.9 | AA: 5.1, Asian: 8.2, C: 78.5, H: 5.1, Other: 3.1 | 31.3 90.3 kg | 7.3 | 5.7 | 328
Pratley, 2010^143^ | Metformin + sitagliptin, 219 | 55 | 55 | AA: 5, Asian: 1, C: 91, H: 16, Other: 4 | 32.6 93.1 kg | 8.5 | 6.3 | 25
Pratley, 2010^143^ | Metformin + liraglutide, 221 | 55.9 | 52 | AA: 10, Asian: 3, C: 82, H: 17, Other: 5 | 32.6 93.7 kg | 8.4 | 6 | 27
Pratley, 2010^143^ | Metformin + liraglutide, 221 | 55 | 52 | AA: 7, Asian: 2, C: 87, H: 15, Other: 4 | 33.1 94.6 kg | 8.4 | 6.4 | 52
Pantalone, 2009^174^ | Rosiglitazone, 1079 | 61.4 | 45.5 | C: 86.8 | 32.7 NR | 7.3 | NR | NR
Pantalone, 2009^174^ | Any in the Sulfonylurea Class, 7427 | 66.1 | 49.5 | C: 78 | 31.1 NR | 7.6 | NR | NR
Pantalone, 2009^174^ | Pioglitazone, 1508 | 61.6 | 48.3 | C: 83.5 | 33 NR | 7.4 | NR | NR
Pantalone, 2009^174^ | Metformin, 10436 | 56.8 | 41.18 | C: 76.9 | 33.8 NR | 7.7 | NR | NR
Hsiao, 2009^173^ | Metformin, 46444 | 59 | 48.22 | NR | NR NR | NR | NR | NR
Hsiao, 2009^173^ | Rosiglitazone, 2093 | 61.24 | 53.46 | NR | NR NR | NR | NR | NR
Hsiao, 2009^173^ | Pioglitazone, 495 | 60.75 | 52.02 | NR | NR NR | NR | NR | NR
Hsiao, 2009^173^ | Any in the Sulfonylurea class, 97651 | 60.71 | 54.1 | NR | NR NR | NR | NR | NR
Hsiao, 2009^173^ | Metformin + sulfonylurea, 267754 | 57.17 | 54.45 | NR | NR NR | NR | NR | NR
Hsiao, 2009^173^ | Metformin + rosiglitazone, 2408 | 57.3 | 49.8 | NR | NR NR | NR | NR | NR
Tzoulaki, 2009^171^ | Metformin, 68181 | 66.3 | 50.6 | NR | 31.47 NR | 8.13 | 5.59 | NR
Tzoulaki, 2009^171^ | Rosiglitazone, 8442 | 65.7 | 50.5 | NR | 31.7 NR | 8.4 | 6.7 | NR
Tzoulaki, 2009^171^ | Any in the Sulfonylurea class, 58095 | 70.4 | 52.6 | NR | 28.5 NR | 8.2 | 6.6 | NR
Rigby, 2009^130^ | Metformin + rosiglitazone, 56 | 54.7 | 41.1 | AA: 3.6, Asian: 0, C: 28.6, H: 67.9, Other: 0 | NR 81.1 kg | 8.06 | 7.57 | 5
Rigby, 2009^130^ | Metformin + sitagliptin, 56 | 54.8 | 35.7 | AA: 1.8, Asian: 0, C: 23.2, H: 73.2, Unspecified: 1.8 | NR 79.6 kg | 8.17 | 8.35 | 11
Juurlink, 2009^210^ | Rosiglitazone, 22785 | 66–75 (69%) 76–85 (28%) >=86 (3%) | 53.1 | NR | NR NR | NR | NR | NR
Juurlink, 2009^210^ | Pioglitazone, 16951 | 66–75 (69%) 76–85 (28%) >=86 (3%) | 52.1 | NR | NR NR | NR | NR | NR
Jadzinsky, 2009^78^ | Metformin + saxagliptin, 320 | 52.4 | 51.6 | AA: 2.2, Asian: 15.9, C: 76.9, Other: 5 | 29.9 NR | 9.4 | 2 | NR
Jadzinsky, 2009^78^ | Metformin + saxagliptin, 323 | 52.1 | 45.2 | AA: 2.2, Asian: 16.7, C: 75.2, Other: 5.9 | 30.3 NR | 9.5 | 1.4 | NR
Jadzinsky, 2009^78^ | Metformin, 328 | 51.8 | 49.7 | AA: 1.2, Asian: 15.9, C: 76.5, Other: 6.4 | 30.2 NR | 9.4 | 1.7 | NR
Jadzinsky, 2009^78^ | Saxagliptin, 335 | 52 | 50.4 | AA: 1.8, Asian: 16.7, C: 76.1, Other: 5.4 | 30.2 NR | 9.6 | 1.7 | NR
Home, 2009^16^ | Rosiglitazone, 2220 | 58.4 | 51.4 | C: 99.1 | 31.6 NR | 7.9 | 7 | 218
Home, 2009^16^ | Rosiglitazone + sulfonylurea, 1103 | 59.8 | 49 | NR | 30.3 85.0 kg | 8 | 7.9 | NR
Home, 2009^16^ | Metformin + sulfonylurea, 1122 | 59.7 | 50.6 | C: 99.1 | NR 84.3 kg | 8 | 7.9 | NR
Home, 2009^16^ | Metformin + sulfonylurea, 1105 | 57.2 | 52.9 | C: 98.4 | NR 93.3 kg | 7.8 | 6.3 | NR
Home, 2009^16^ | Metformin + rosiglitazone, 1117 | 57 | 53.8 | C: 98.9 | NR 93.5 kg | 7.8 | 6.1 | NR
Home, 2009^16^ | Metformin + sulfonylurea, 2227 | 58.5 | 51.7 | C: 98.7 | 31.5 NR | 7.9 | 7.1 | 233
Raskin, 2009^131^ | Metformin + repaglinide, 187 | 54.5 | 58.8 | AA: 13.4, Asian: 4.8, C: 78.8, American Indian and Alaskan Native: .5, Other: 1.6 | 32.5 NR | 8.29 | 7.3 | 58
Raskin, 2009^131^ | Metformin + rosiglitazone, 187 | 55.5 | 50.8 | AA: 13.4, Asian: 2, C: 79.1, American Indian and Alaskan Native: 1.1, Others: 4.3 | 32.2 NR | 8.46 | 7.1 | 58
Raskin, 2009^131^ | Metformin + repaglinide, 187 | 54.8 | 57.8 | AA: 16, Asian: 4.3, C: 74.9, American Indian and Alaskan Native: 0.5, Others: 4.3 | 32.9 NR | 8.45 | 7.4 | 62
Scott, 2008^85^ | Metformin + rosiglitazone, 87 | 54.8 | 63 | Asian: 38, C: 59, Others: 3 | 30.4 84.9 kg | 7.7 | 4.6 | 2
Scott, 2008^85^ | Metformin + sitagliptin, 94 | 55.2 | 55 | Asian: 38, C: 61, Others: 1 | 30.3 83.1 kg | 7.8 | 4.9 | 9
Scott, 2008^85^ | Metformin, 92 | 55.3 | 59 | Asian: 39, C: 61 | 30 84.6 kg | 7.7 | 5.4 | 9
Raz, 2008^93^ | Metformin + sitagliptin, 96 | 53.6 | 51 | AA: 3, C: 42, H: 32, Multiracial: 22, Not Specified: 1 | 30.1 81.5 kg | 9.3 | 8.4 | 18
Raz, 2008^93^ | Metformin, 94 | 56.1 | 41.5 | AA: 1, C: 47, H: 25, Multiracial: 25, Not Specified: 2 | 30.4 81.2 kg | 9.1 | 7.3 | 16
Hamann, 2008^123^ | Metformin + rosiglitazone, 294 | 58.5 | 53 | C: 94 | 33 91.4 kg | 8 | 6.3 | 61
Hamann, 2008^123^ | Metformin + sulfonylurea, 302 | 59.3 | 52 | C: 95 | 32.2 88.9 kg | 8 | 6.4 | 71
Chien, 2007^59^ | Metformin + glyburide, 26 | 60 | 71 | NR | 24.2 63.8 kg | 8.71 | 9 | 5
Chien, 2007^59^ | Metformin + glyburide, 26 | 57 | 62 | NR | 24.2 61.3 kg | 8.85 | 6.6 | 5
Chien, 2007^59^ | Metformin, 25 | 59 | 41 | NR | 25.7 65.6 kg | 8.88 | 6.4 | 8
Chien, 2007^59^ | Glyburide, 25 | 63 | 53 | NR | 25.3 63.7 kg | 8.69 | 8.6 | 6
Schwarz, 2008^152^ | Metformin + glyburide, 40 | 70.4 | 50 | AA: 11.1, C: 77.8, Other: 11 | 33.5 NR | 7.7 | 2.5 | 18
Schwarz, 2008^152^ | Metformin + nateglinide, 35 | 70.1 | 51.5 | AA: 9.1, C: 78.8, Other: 12.1 | 30.4 NR | 7.8 | 1.7 | 14
Comaschi, 2007^129^ | Metformin + pioglitazone, 103 | 57 | 45.63 | NR | 32.2 85.8 kg | 8.4 | NR | 27
Comaschi, 2007^129^ | Metformin + sulfonylurea, 80 | 59.9 | 55 | NR | 29.9 81.9 kg | 8.6 | NR | 13
Comaschi, 2007^129^ | Pioglitazone + sulfonylurea, 67 | 62.2 | 56.72 | NR | 28.9 78.8 kg | 8.7 | NR | 14
McAfee, 2007^181^ | Any in the Sulfonylurea class, 8977 | 52 | 56 | NR | NR NR | NR | NR | NR
McAfee, 2007^181^ | Rosiglitazone + sulfonylurea, 1362 | 52 | 59 | NR | NR NR | NR | NR | NR
McAfee, 2007^181^ | Metformin + rosiglitazone, 1362 | 52 | 59 | NR | NR NR | NR | NR | NR
McAfee, 2007^181^ | Rosiglitazone, 8977 | 52 | 55 | NR | NR NR | NR | NR | NR
McAfee, 2007^181^ | Metformin, 8977 | 52 | 55 | NR | NR NR | NR | NR | NR
McAfee, 2007^181^ | Metformin + sulfonylurea, 1362 | 51 | 61 | NR | NR NR | NR | NR | NR
Monami, 2008^180^ | Metformin + repaglinide | NR | NR | NR | NR NR | NR | NR | 0
Monami, 2008^180^ | Metformin + sulfonylurea | NR | NR | NR | NR NR | NR | NR | 0
Kahler, 2007^175^ | Any in the Sulfonylurea class, 19053 | 68.2 | NR | AA: 12.6, C: 78.6, Other: 8.8 | 29.6 NR | 7.2 | (<1: 12.8, 1–3: 32.2, 4–10: 33.4, >11: 20) | NR
Kahler, 2007^175^ | Metformin, 2988 | 64.9 | 96.9 | AA: 12.7, C: 78.7, Other: 8.7 | 30.4 NR | 7 | (<1: 20.5, 1–3: 41.5, 4–10: 25.1, >11: 11.6) | NR
Kahler, 2007^175^ | Metformin + sulfonylurea, 13820 | 65.6 | 98.1 | AA: 13.2, C: 77.5, Other: 9.3 | 30.3 NR | 8 | (<1: 4.5, 1–3: 21.2, 4–10: 43.3, >11: 29.1) | NR
Kahler, 2007^175^ | TZD, 675 | 67.1 | 97.5 | AA: 8.7, C: 80.9, Other: 10.4 | 30.7 NR | 7.9 | (<1: 3.3, 1–3: 18.2, 4–10: 39.9, >11: 37.5) | NR
Nauck, 2007^133^ | Metformin + sitagliptin, 588 | 56.8 | 57.1 | AA: 7, Asian: 8.5, C: 73.5, H: 7.3, Other: 3.7 | NR NR | 7.7 | 6.5 | 202
Nauck, 2007^133^ | Metformin + glipizide, 584 | 56.6 | 61.3 | AA: 6, Asian: 8.4, C: 74.3, H: 7.9, Other: 3.4 | 31.3 89.7 kg | 7.6 | 6.2 | 172
Hanefeld, 2007^100^ | Rosiglitazone, 189 | 60.6 | 57.7 | AA: 0, C: 97, Other: 3 | 28.8 NR | 8.2 | 6 | 9
Hanefeld, 2007^100^ | Glibenclamide, 203 | 60.1 | 70.4 | AA: 0, C: 99, Other: 0.5 | 28.7 NR | 8.2 | 6.4 | 13
Hanefeld, 2007^100^ | Rosiglitazone, 195 | 60.4 | 68.2 | AA: 0, C: 98.5, Other: 1.5 | 28.7 NR | 8.1 | 5.9 | 12
Nakamura, 2006^108^ | Pioglitazone, 17 | 56 | 52.9 | NR | NR NR | 8.0 | 16 | NR
Nakamura, 2006^108^ | Glibenclamide, 18 | 53.5 | 55.6 | NR | NR NR | 7.8 | 16.5 | NR
Nakamura, 2006^108^ | Nateglinide, 16 | 53.5 | 56.3 | NR | NR NR | 7.7 | 16.6 | NR
Kahn, 2006^38^ | Rosiglitazone, 1456 | 56.3 | 55.7 | AA: 4.2, Asian: 2.7, C: 87.2, H: 5.2, Other: 0.7 | 32.2 91.5 kg | 7.36 | (<1: 651, 1–2: 758, >2: 47) | 539
Kahn, 2006^38^ | Glyburide, 1441 | 56.4 | 58 | AA: 4.2, Asian: 2.2, C: 89, H: 4.2, Other: 0.3 | 32.2 92 kg | 7.35 | (<1 year: 637, 1–2: 751, >2: 53) | 634
Kahn, 2006^38^ | Metformin, 1454 | 57.9 | 59.4 | AA: 3.7, Asian: 2.4, C: 89.1, H: 3.8, Other: 1 | 32.1 91.6 kg | 7.36 | (< 1 year: 673, 1–2: 724, >2: 57) | 551
Rosenstock, 2006^49^ | Rosiglitazone, 159 | 50.6 | 58 | AA: 5, Asian: 14, C: 59, H: 19, Other: 3 | 32.8 NR | 8.8 | 2.7 | 22
Rosenstock, 2006^49^ | Metformin + rosiglitazone, 155 | 50.1 | 57 | AA: 6, Asian: 12, C: 54, H: 26 | 33.2 NR | 8.9 | 2.3 | 19
Rosenstock, 2006^49^ | Metformin, 154 | 51.5 | 56 | AA: 5, Asian: 14, C: 58, H: 21, Other: <1 | 32.5 NR | 8.8 | 2.9 | 31
Jain, 2006^101^ | Pioglitazone, 251 | 52.1 | 53 | AA: 15.9, Asian: 1.6, C: 61, H: 20.7, Other: 0.4, Native American: 0.4 | 32.5 93.9 kg | 9.2 | 0.8 | 117
Jain, 2006^101^ | Glyburide, 251 | 52.1 | 56.2 | AA: 13.5, Asian: 0, C: 65.7, H: 19.9, Native American: 0.4, Other: 0.4 | 32.8 94.3 kg | 9.2 | 0.78 | 123
Stewart, 2006^156^ | Metformin, 272 | 59 | 56 | AA: <1, Asian: <1, C: 99, H: <1, Native Hawaiian/Other Pacific Islander: <1 | 30.6 87.2 kg | 7.2 | 3.7 | 54
Stewart, 2006^156^ | Metformin + rosiglitazone, 254 | 58.8 | 55 | AA: 0, Asian: 1, C: 98, H: <1, Native Hawaiian/Other Pacific Islander: 0 | 30.9 88.1 kg | 7.2 | 3.7 | 50
Bakris, 2006^125^ | Metformin + glyburide, 185 | 58.8 | 69 | C: 76 | 31.8 90.3 kg | 8.3 | 7.6 | 5
Bakris, 2006^125^ | Metformin + rosiglitazone, 204 | 60 | 63 | C: 78 | 31.6 89.2 kg | 8.5 | 8 | 10
Rosak, 2006^183^ | Metformin + rosiglitazone, 7705 | 60 | 50.2 | NR | 29.3 87.2 kg | 8.1 | 3.9 | 545
Rosak, 2006^183^ | Rosiglitazone + sulfonylurea, 5511 | 65 | 48.2 | NR | NR 81.3 kg | 8.3 | 5.3 | 478
Rosak, 2006^183^ | Rosiglitazone, 1559 | 62.0 | 47.7 | NR | 28.7 83.8 kg | 8.1 (median) | 4.5 | 542
Simpson, 2006^166^ | Metformin, 768 | 64.6 | 53 | NR | NR NR | NR | NR | NR
Simpson, 2006^166^ | Glyburide, 2067 | 67.8 | 60 | NR | NR NR | NR | NR | NR
Kvapil, 2006^138^ | Metformin + glibenclamide, 114 | 58.1 | 45.6 | NR | 30.5 84.0 kg | 9.4 | 8.1 | 5
Kvapil, 2006^138^ | Metformin + aspart 70/30, 116 | 56.4 | 45.7 | NR | 30.4 85.1 kg | 9.3 | 6.7 | 11
Malone, 2005^165^ | Metformin + lispro 75/25, 50 | 59.18 | 50 | NR | 29.41 77.82 kg | 8.5 | 13.52 | 3
Malone, 2005^165^ | Metformin + glargine, 47 | 59.63 | 38 | NR | 29.64 77.21 kg | 8.48 | 11.9 | 10
Gerich, 2005^136^ | Metformin + glyburide, 209 | 53.5 | 48 | AA: 16.7, Asian: 0.5, C: 65.2, Other: 17.7 | 33.5 NR | 8.3 | 2.0 | 87
Gerich, 2005^136^ | Metformin + nateglinide, 219 | 52.6 | 51 | AA: 13, Asian: 2.4, C: 64.4, Other: 20.2 | 33.3 NR | 8.4 | 1.5 | 78
Agarwal, 2005^184^ | Pioglitazone, 22 | 67 | 100 | AA: 14, C: 86 | 32 97 kg | 7.7 | 16 | 1
Agarwal, 2005^184^ | Glipizide, 22 | 64 | 100 | AA: 27, C: 73 | 34 102 kg | 7.7 | 14 | 3
Malone, 2004^164^ | Pooled arms | | 63 | NR | 30.9 91.5 kg | 8.7 | 9 | NR
Malone, 2004^164^ | Metformin + lispro 75/25 | NR | NR | NR | NR NR | NR | NR | 3 during this arm
Malone, 2004^164^ | Metformin + glargine | NR | NR | NR | NR NR | NR | NR | 7
Nakamura, 2004^102^ | Pioglitazone, 15 | 57 | 60 | NR | NR NR | 7.9 | 17.5 | NR
Nakamura, 2004^102^ | Glibenclamide, 15 | 55 | 53.3 | NR | NR NR | 7.8 | 19.2 | 0
Malone, 2003^137^ | Metformin + lispro 75/25, 296 | 58 | 57 | AA: 0.7, C: 88.9, H: 7.4, Other: 3 | 29.8 83.0 kg | 9.17 | 8.0 | 25
Malone, 2003^137^ | Metformin + glibenclamide, 301 | 59 | 49 | AA: 1, C: 89, H: 6, Other: 4 | 29.6 81.7 kg | 9.27 | 7.4 | 29
Jones, 2003^179^ | Metformin, 82 | 60 | 74 | NR | 28 NR | 8.8 | 6 | NR
Jones, 2003^179^ | Metformin, 22 | 64 | 9 | NR | 23 NR | 8.6 | 6.5 | NR
Jones, 2003^179^ | Metformin + rosiglitazone, 35 | 62 | 71 | NR | 23 NR | 9.3 | 8 | NR
Jones, 2003^179^ | Metformin + rosiglitazone, 141 | 58 | 69 | NR | 28 NR | 8.8 | 6 | NR
Jones, 2003^179^ | Metformin + rosiglitazone, 142 | 57 | 57 | NR | 34 NR | 8.8 | 5 | NR
Jones, 2003^179^ | Metformin, 121 | 58 | 70 | NR | 34 NR | 8.7 | 5 | 0
Fisman, 1999^178^ | Any in the Sulfonylurea class, 1041 | 60.5 | 76 | NR | 27 76 kg | NR | NR | NR
Fisman, 1999^178^ | Metformin + sulfonylurea, 266 | 60.9 | 66 | NR | 27 75 kg | NR | NR | 0
Fisman, 1999^178^ | Metformin, 78 | 59.5 | 65 | NR | 29 80 kg | NR | NR | NR
Evans, 2005^176^ | Metformin, 2286 | 60.2 | 51.20 | NR | 32.9 NR | 7.7 | 2.7 | NR
Evans, 2005^176^ | Sulfonylurea, 3331 | 65.9 | 56.30 | NR | 28.6 NR | 7.8 | 4.6 | NR
Evans, 2005^176^ | Metformin + sulfonylurea, 985 | 61.2 | 47.00 | NR | 33.2 NR | 8.1 | 4.4 | NR
Evans, 2005^176^ | Metformin + sulfonylurea, 1252 | 63.6 | 55.10 | NR | 30.2 NR | 8.2 | 4.8 | NR
Evans, 2005^176^ | Metformin + sulfonylurea,113 | 64 | 49.60 | NR | 30 NR | 8 | 8.8 | NR
Weissman, 2005^86^ | Metformin, 384 | 55.7 | NR | NR | 33.8 96.7 kg | 7.97 | NR | 95
Weissman, 2005^86^ | Metformin + rosiglitazone, 382 | 55.5 | NR | NR | 34.4 98.2 kg | 8.05 | NR | 76
Bailey, 2005^87^ | Metformin, 280 | 57.6 | 57 | AA: <1, Asian: 1, C: 98, Other: 1 | 32.1 89.5 kg | 7.5 | 6.1 | 44
Bailey, 2005^87^ | Metformin + rosiglitazone, 288 | 58.1 | 58 | AA: 1, C: 97, Asian: 1, H: 0, Other: 1 | 32.2 90.9 kg | 7.4 | 6 | 30
Eurich, 2005^169^ | Unspecified Sulfonylurea, 773 | 74.8 | 58 | NR | NR NR | NR | NR | NR
Eurich, 2005^169^ | Metformin, 208 | 72.5 | 59 | NR | NR NR | NR | NR | NR
Eurich, 2005^169^ | Metformin + unspecified Sulfonylurea, 852 | 70 | 55 | NR | NR NR | NR | NR | NR
Johnson, 2005^167^ | Unspecified Sulfonylurea, 2138 | 67.8 | 59 | NR | NR NR | NR | NR | NR
Johnson, 2005^167^ | Metformin, 923 | 64.3 | 52 | NR | NR NR | NR | NR | NR
Johnson, 2005^167^ | Metformin + unspecified Sulfonylurea, 1081 | 62 | 54 | NR | NR NR | NR | NR | NR
Schernthaner, 2004^52^ | Placebo + diet + Metformin, 597 | 56 | 57.8 | NR | 31.4 89.7 kg | 8.7 | 3.1 | 96
Schernthaner, 2004^52^ | Placebo + diet + pioglitazone, 597 | 57 | 52.6 | NR | 31.2 88.2 kg | 8.7 | 3.4 | 98
Gulliford, 2004^170^ | Unspecified Sulfonylurea, 6620 | 67 | 55 | NR | NR NR | NR | NR | NR
Gulliford, 2004^170^ | Metformin + unspecified Sulfonylurea, 1868 | 61 | 51 | NR | NR NR | NR | NR | NR
Gulliford, 2004^170^ | Metformin, 2232 | 61 | 50 | NR | NR NR | NR | NR | NR
Gulliford, 2004^170^ | Metformin + unspecified Sulfonylurea, 867 | 58 | 45 | NR | NR NR | NR | NR | NR
Hanefeld, 2004^140^ | Placebo + unspecified Sulfonylurea + pioglitazone, 319 | 60 | 53.6 | AA: 0.6, C: 99.4, Asian: 0, H: 0, Other: 0 | 30.2 85.3 kg | 8.82 | 7 | 259
Hanefeld, 2004^140^ | Placebo + Metformin + unspecified Sulfonylurea, 320 | 60 | 54.7 | AA: 0.9, C: 98.4, Asian: 0, H: 0 Other: 0.6 | 30 84.9 kg | 8.8 | 7.1 | 279
Lawrence, 2004^53^ | Metformin, 20 | 59.5 | 60 | NR | 29.2 NR | NR | NR | NR
Lawrence, 2004^53^ | Pioglitazone, 20 | 60.4 | 70 | NR | 30.6 NR | NR | NR | NR
Garber, 2003^61^ | Metformin + glyburide, 171 | 55.6 | 44 | AA: 10.5, C: 77.2, Asian: 0, H: 8.8, Other: 3.5 | 31.4 91.9 kg | 8.8 | 3 | NR
Garber, 2003^61^ | Glyburide, 151 | 55.3 | 43.7 | AA: 7.3, C: 81.5, Asian: 0, H: 7.9, Other: 3.3 | 31.1 91 kg | 8.7 | 3 | NR
Garber, 2003^61^ | Metformin, 164 | 54.7 | 43.3 | AA: 6.7, C: 80.5, Asian: 0, H: 9.1, Other: 3.7 | 31.4 92.8 kg | 8.5 | 2.6 | NR
Goldstein, 2003^62^ | Metformin + glipizide, 87 | 54.6 | 58.60 | AA: 11.5, C: 72.4, Asian: 0, H: 16.1, Other: 0 | 31.7 94 kg | 8.7 | 5.9 | NR
Goldstein, 2003^62^ | Glipizide, 84 | 57.4 | 64.30 | AA: 11.9, C: 71.4, Asian: 2.4, H: 14.3, Other: 0 | 30.6 89.9 kg | 8.9 | 6.5 | NR
Goldstein, 2003^62^ | Metformin, 76 | 56.6 | 61.80 | AA: 15.8, C: 65.8, Asian: 1.3, H: 17.1, Other: 0 | 31.6 93.8 kg | 8.7 | 7.3 | NR
Bakris, 2003^104^ | Rosiglitazone, 104 | 55.1 | 72.1 | NR | NR NR | 9.1 | NR | NR
Bakris, 2003^104^ | Glyburide, 99 | 56.1 | 71.7 | NR | NR NR | 9.5 | NR | NR
Johnson, 2002^168^ | Unspecified Sulfonylurea, 3033 | 67.2 | 59 | NR | NR NR | NR | NR | NR
Johnson, 2002^168^ | Metformin, 1150 | 63.8 | 54 | NR | NR NR | NR | NR | NR
Johnson, 2002^168^ | Metformin + unspecified Sulfonylurea, 4683 | 62.1 | 54.3 | NR | NR NR | NR | NR | NR
Hallsten, 2002^55^ | Diet + rosiglitazone, 14 | 58.6 | 71.4 | NR | 29.3 NR | 6.8 | NR | NR
Hallsten, 2002^55^ | Placebo + diet, 14 | 57.7 | 71.4 | NR | 30.3 NR | 6.3 | NR | NR
Hallsten, 2002^55^ | Diet + Metformin, 13 | 57.8 | 61.5 | NR | 29.9 NR | 6.9 | NR | NR
St John Sutton, 2002^149^ | Rosiglitazone, 104 | 55.1 | 75 | AA: 5, C: 73, Asian: 0, H: 0, Other: 22 | 67.3% >=27kg/m^2^ 86.2 kg | 9.1 | 5.3 | NR
St John Sutton, 2002^149^ | Glyburide, 99 | 56.1 | 71 | AA: 3, C: 76, Asian: 0, H: 0, Other: 21 | 65.7% >=27 kg/m^2^ 85.1 kg | 9.5 | 6.2 | NR
Gomez-Perez, 2002^88^ | Placebo + Metformin, 34 | 53.4 | 29.4 | C: 2.9, H: 76.5, Mestizo: 20.6 | 28.5 NR | NR | 9.1 | NR
Gomez-Perez, 2002^88^ | Metformin + rosiglitazone, 35 | 51.7 | 28.6 | C: 0, H: 80, Mestizo: 20 | 28 NR | NR | 11.1 | NR
Gomez-Perez, 2002^88^ | Metformin + rosiglitazone, 36 | 54.2 | 19.4 | C: 11.1, H: 72.2, Mestizo: 16.7 | 27.6 NR | NR | 10.7 | NR
Fisman, 2001^177^ | Glyburide, 953 | 59.8 | 76 | NR | 27 77 kg | NR | NR | NR
Fisman, 2001^177^ | Metformin, 79 | 59.5 | 66 | NR | 29 81 kg | NR | NR | NR
Fisman, 2001^177^ | Metformin + glyburide, 253 | 60.7 | 66 | NR | 27 75 kg | NR | NR | NR
Amador-Licona, 2000^66^ | Glibenclamide, 23 | 48.2 | 30.4 | NR | 30.4 73.2 kg | 8.4 | 4 | NR
Amador-Licona, 2000^66^ | Metformin, 28 | 49.3 | 39.3 | NR | 26.8 70.7 kg | 8.5 | 4.5 | NR
Fonseca, 2000^90^ | Metformin + rosiglitazone, 113 | 58.3 | 68.2 | AA: 10, C: 77.3, Asian: 0, H: 0, Other: 12.7 | 29.8 NR | 8.9 | 8.3 | 18
Fonseca, 2000^90^ | Placebo + Metformin, 116 | 58.8 | 74.3 | AA: 3.5, C: 81.4, Asian: 0, H: 0, O: 15 | 30.3 NR | 8.6 | 7.3 | 22
Fonseca, 2000^90^ | Metformin + rosiglitazone, 119 | 57.5 | 62.1 | AA: 6.9, C: 80.2, Asian: 0, H: 0, Other: 12.9 | 30.2 NR | 8.9 | 7.5 | 18
Nakamura, 2000^103^ | Pioglitazone, 15 | 60 | 46.7 | NR | NR NR | 7.7 | 16 | NR
Nakamura, 2000^103^ | Glibenclamide, 15 | 61 | 53.3 | NR | NR NR | 7.8 | 14 | NR
Horton, 2000^79^ | Nateglinide, 179 | 58.6 | 61.5 | AA: 9.5, C: 82.1, Asian: 2.8, H: 0, Other: 5.6 | 29.6 NR | 8.3 | 4.7 | NR
Horton, 2000^79^ | Metformin, 178 | 56.8 | 68 | AA: 9.6, C: 79.2, Asian: 2.2, H: 0, Other: 9 | 29.6 NR | 8.4 | 7.5 | NR
Horton, 2000^79^ | Metformin + nateglinide, 172 | 58.4 | 58.7 | AA: 11.6, C: 82.6, Asian: 0.6, H: 0, Other: 5.2 | 30 NR | 8.4 | 4.5 | NR
Wolffenbuttel, 1999^116^ | Repaglinide, 286 | 61 | 62 | NR | 28.4 81.5 kg | 7.1 | Median 6 | NR
Wolffenbuttel, 1999^116^ | Placebo + glyburide, 139 | 61 | 68 | NR | 28 81.3 kg | 7 | Median 6 | NR
DeFronzo, 1995^70^ | Metformin, 143 | 53 | 43.4 | NR | 29.9 94.4 kg | 8.4 | 6 | NR
DeFronzo, 1995^70^ | Metformin + glyburide, 213 | 55 | 46.0 | NR | 29 92.1 kg | 8.8 | 7.8 | NR
DeFronzo, 1995^70^ | Placebo + glyburide, 209 | 56 | 49.3 | NR | 29.1 92.6 kg | 8.5 | 8.7 | NR
DeFronzo, 1995^70^ | Placebo + Metformin, 210 | 55 | 45.7 | NR | 29.4 92.6 kg | 8.9 | 8.4 | NR
Hermann, 1994^68^ | Diet + Metformin, 25 | 60 | 63 | NR | NR 78.6 kg | 6.9 | 4 | NR
Hermann, 1994^68^ | Diet + glibenclamide, 21 | NR | NR | NR | NR NR | NR | NR | NR
Hermann, 1994^68^ | Diet + Metformin + glibenclamide + Other, 54 | NR | 80.2 | NR | NR NR | NR | NR | NR
Marbury, 1999^117^ | Repaglinide, 362 | 58.3 | 67 | AA: 9, C: 77, Asian: 0, H: 0, Other: 14 | 29.4 NR | 8.7 | 7.2 | NR
Marbury, 1999^117^ | Placebo + glyburide, 182 | 58.7 | 66 | AA: 9, C: 79, Asian: 0, H: 0, Other: 12 | 29.1 NR | 8.9 | 8.3 | NR

AA= African American; C= Caucasian; H=Hispanic; Kg=kilogram; Met=Metformin; NR=Not reported; Repa=Repaglinide; Rosi=Rosiglitazone; Sita=Sitagliptin; SU=Sulfonylurea

Table 8 Comparative effectiveness of diabetes medications on long-term clinical outcomes (KQ2)

Author, year | Study design | Intervention | Overall mortality, n (%) | CVD mortality, n (%) | CVD morbidity, n (%) | Cerebrovascular disease, n (%)
Metformin versus thiazolidinedione
Hsiao, 2009^173^ | Cohort | Grp1: Metformin NS Grp2: Pioglitazone NS | | | Def: Angina pectoris defined by ICD-9-CM diagnostic codes for hospitalization Grp1: 1367 (2.97) Grp2: 22 (4.51) HR: 1.15 (CI: 0.6 to 2.21) p: 0.6753 Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 484 (1.02) Grp2: 44 (8.89) HR: 1.0 (CI: 0.26 to 3.89) p: 0.9954 | Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 116 (0.25) Grp2: 2 (0.41) Def: TIA defined by ICD-9-CM diagnostic codes of hospitalization Grp1: 285 (0.63) Grp2: 5 (1.03)
Hsiao, 2009^173^ | Cohort | Grp1: Metformin NS Grp2: Rosiglitazone NS | | | Def: Angina pectoris defined by ICD-9-CM diagnostic codes for hospitalization Grp1: 1367 (2.97) Grp2: 154 (7.52) HR: 1.79 (CI: 1.39 to 2.3) Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 484 (1.02) Grp2: 266 (12.71) HR: 2.09 (CI: 1.36 to 3.24) p: 0.0007 | Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 116 (0.25) Grp2: 16 (0.8) Def: TIA defined by ICD-9-CM diagnostic codes of hospitalization Grp1: 285 (0.63) Grp2: 23 (1.14)
Brownstein, 2010^182^ | Cohort | Grp1: Metformin NS Grp2: Rosiglitazone NS | | | Def: Hospitalization for acute MI Grp1: ref Grp2: HR: 3.0 (CI: 2.4–3.7)
Tzoulaki, 2009^171^ | Cohort | Grp1: Metformin NS Grp2: Rosiglitazone NS | Grp1: ref Grp2: 34 (<1) HR: 1.07 (CI: 0.77 to 1.49) p: 0.74 | | Def: Incident MI Grp1: ref Grp2: 9 (<1) HR: 0.79 (CI: 0.41 to 1.53) p: 0.485
Pantalone, 2009^174^ | Cohort | Grp1: Metformin NR Grp2: Rosiglitazone NR | Grp1: ref Grp2: HR: 1.33 (CI: 0.93 to 1.91) p: 0.11 | | Def: CABG, PTCA, MI, or diagnosis of CAD by ICD-9 after baseline Grp1: ref Grp2: HR: 0.96 (CI: 0.76 to 1.21) p: 0.74
Pantalone, 2009^174^ | Cohort | Grp1: Metformin NR Grp2: Pioglitazone NR | Grp1: ref Grp2: HR: 1.08 (CI: 0.78 to 1.51) p: 0.64 | | Def: CABG, PTCA, MI, or diagnosis of CAD by ICD-9 after baseline Grp1: ref Grp2: HR: 1.11 (CI: 0.91 to 1.34) p: 0.32
McAfee, 2007^181^ | Cohort | Grp1: Metformin NR Grp2: Rosiglitazone NR | | | Def: Inpatient MI and coronary revascularization using ICD-9 and CPT codes Grp1: 149 (2) Grp2: 152 (2)
McAfee, 2007^181^ | Cohort | Grp1: Metformin NR Grp2: Rosiglitazone NR | | | Def: MI based on ICD-9 diagnosis codes (could be fatal or nonfatal MI since not specified but likely nonfatal mostly) Grp1: 62 (1) Grp2: 70 (1)
Lawrence, 2004^53^ | RCT | Grp1: Metformin Varied Start: 500 mg bid, Max: 1000 mg tid Grp2: Pioglitazone Varied Start: 30 mg, Max: 45 mg | Grp1: 1 (5) Grp2: 0 (0) | Def: CVD mortality/Fatal MI Grp1: 1 (5) Grp2: 0 (0) | Def: CVD morbidity/MI (non-fatal) Grp1: 0 (0) Grp2: 0 (0)
Rosenstock, 2006^49^ | RCT | Grp1: Metformin Varied, glucose: 6.1 mmol/l Start: 500 mg, Mean: 1847 mg, Max: 2000 mg D: 32 wks Grp2: Rosiglitazone Varied, glucose: 6.1 mmol/l Start: 4 mg, Mean: 7.7 mg, Max: 8 mg D: 32 wks | Grp1: 0 (0) Grp2: 0 (0) | | Def: Not defined ischemic heart disease Grp1: 2 (1) Grp2: 2 (1)
Kahn, 2006^38^ | RCT | Grp1: Metformin Varied, glucose: 140 mg/dL Start: 500 mg, Max: 2000 mg Grp2: Rosiglitazone Varied, glucose: 140 mg/dL Start: 4 mg, Max: 8 mg | Grp1: 31 (2) Grp2: 34 (2) | Def: Fatal MI Grp1: 2 (0.1) Grp2: 2 (0.1) | Grp1: 21 (1.4) Grp2: 25 (1.7) | Def: Stroke not defined Grp1: 19 (1.3) Grp2: 16 (1.1)
Schernthaner, 2004^52^ | RCT | Grp1: Metformin Varied Max: 850 mg tid Grp2: Pioglitazone Varied Start: 30 mg, Max: 45 mg | Grp1: 2 (0.3) Grp2: 3 (0.5)
Metformin versus sulfonylurea
Hsiao, 2009^173^ | Cohort | Grp1: Metformin NS Grp2: Sulfonylurea NS | | | Def: Angina pectoris defined by ICD-9-CM diagnostic codes for hospitalization Grp1: 1367 (2.97) Grp2: 3721 (3.87) Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 484 (1.02) Grp2: 1678 (1.76) | Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 116 (0.25) Grp2: 318 (0.34) Def: TIA defined by ICD-9-CM diagnostic codes of hospitalization Grp1: 285 (0.63) Grp2: 940 (0.99)
Tzoulaki, 2009^171^ | Cohort | Grp1: Metformin NS Grp2: Sulfonylurea NS | Grp1: ref Grp2: 1379 (2) HR: 1.24 (CI: 1.14 to 1.35) p: <0.001 | | Def: Incident MI Grp1: ref Grp2: 365 (1) HR: 1.09 (CI: 0.94 to 1.27) p: 2.66
Pantalone, 2009^174^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea NR | Grp1: HR: 0.54 (CI: 0.46 to 0.64) p: <0.001 Grp2: ref | | Def: CABG, PTCA, MI, or diagnosis of CAD by ICD-9 after baseline Grp1: HR: 0.94 (CI: 0.85 to 1.05) p: 0.23 Grp2: ref
Simpson, 2006^166^ | Cohort | Grp1: Metformin NR Grp2: Glyburide NR | Grp1: 39.6/1000 person-years Grp2: 61.4/1000 person-years | Def: Fatal MI Grp1: 11.5/1000 person-years Grp2: 17.6/1000 person-years
Eurich, 2005^169^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea NR | Grp1: 69 (33) Adjusted HR 0.70 Grp2: 404 (52)
Fisman, 2001^177^ | Cohort | Grp1: Metformin NR Grp2: Glyburide NR | Grp1: 25 (32) Grp2: 324 (34) | Def: CVD mortality/CVD mortality + ICD-9 codes 410–414 + matched the patients ID number with their life status in the population registry + ischemic heart disease Grp1: Age-adjusted IR 30/1000 person-years Grp2: Age-adjusted IR 24.5/1000 person-years
Johnson, 2005^167^ | Cohort | Grp1: Metformin Varied Min: 250 mg Grp2: Sulfonylurea Varied | | Def: CVD mortality/CVD mortality registry + CVD mortality + ICD-9 codes 410, 411–414, 420–427, 429, 428, 430–432, 433–434, 436–438, 440 Grp1: 14.4/1000 patient-years Grp2: 25.5/1000 patient-years | Def: Non-fatal cardiovascular hospitalization/used ICD-9 codes 410–414, 420–427, 429, 428, 440, 430–432, 433–434, 436–438 Grp1: 53.7/1000 patient-years Grp2: 75.3/1000 patient-years
Johnson, 2002^168^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea NR | Grp1: 159 (14) Grp2: 750 (25) | Def: CVD mortality/Fatal MI + fatal stroke + CVD mortality + ICD-9 codes 390–398, 401–417, 420–438, 440–444, 446–448, 451–459 Grp1: 80 (7) Grp2: 351 (11.6)
McAfee, 2007^181^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea NR | | | Def: Inpatient MI and coronary revascularization using ICD-9 and CPT codes Grp1: 149 (2) Grp2: 152 (2)
McAfee, 2007^181^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea NR | | | Def: MI based on ICD-9 diagnosis codes (could be fatal or nonfatal MI since not specified but likely nonfatal mostly) Grp1: 62 (1) Grp2: 94 (1)
Evans, 2006^176^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea NR | Grp1: (4.7) Adjusted RR: 1.43 Grp2: (17.9) | Grp1: Adjusted HR: 1.7 Grp2: ref
Kahler, 2007^175^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea NR | Grp1: 82 (2.7) Grp2: 1005 (5.3)
Hermann, 1994^68^ | RCT | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Glyburide Varied Start: 3.5 mg, Max: 10.5 mg | | | Def: CVD morbidity/unclear CHD Grp1: 2 (5) Grp2: 3 (9)
Goldstein, 2003^62^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glipizide Fixed Start: 15mg bid | Grp1: 0 (0) Grp2: 0 (0)
Garber, 2003^61^ | RCT | Grp1: Metformin Varied Start: 500 mg, max: 2000 mg Grp2: Glyburide Varied Start: 2.5 mg, max: 10 mg | Grp1: 0 (0) Grp2: 0 (0)
DeFronzo, 1995^70^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2500 mg Grp2: Glyburide Varied Start: 5 mg bid, Max: 10 mg bid | Grp1: 1 (0.5) Grp2: 0 (0) | Def: CVD mortality/Fatal MI Grp1: 1 (0.5) Grp2: 0 (0)
Chien, 2007^59^ | RCT | Grp1: Metformin Varied, glucose: 140 mg/dL Start: 1000mg, Mean: 1910 mg, Max: 2000 mg D: 4 wks Grp2: Glyburide Varied, glucose: 140 Start: 10 mg, Mean: 19 mg, Max: 20 mg D: 4 wks | Grp1: 0 (0) Grp2: 0 (0)
Kahn, 2006^38^ | RCT | Grp1: Metformin Varied, glucose: 140 mg/dL Start: 500 mg, Max: 2000 mg Grp2: Glyburide Varied, glucose: 140 mg/dL Start: 2.5 mg, Max: 15 mg | Grp1: 31 (2) Grp2: 31 (2) | Def: Fatal MI Grp1: 2 (0.1) Grp2: 3 (0.2) | Def: Not defined Grp1: 21 (1.4) Grp2: 15 (1) | Def: Stroke not defined Grp1: 19 (1.3) Grp2: 17 (1.2)
Gulliford, 2004^170^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea NR | Grp1: 144 (7) Grp2: 1030 (16)
Fisman, 1999^178^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea NR | Grp1: 78 (26) Grp2: 234 (23)
Metformin versus DPP-4 inhibitors
Aschner, 2010^77^ | RCT | Grp1: Metformin Varied, prespecified target dose Start: 500 mg, Max: 2000 mg, Mean: 1903 D: 5 weeks Grp2: Sitagliptin Fixed Mean: 100 mg | Grp1: 0 (0) Grp2: 1 (<1)
Jadzinsky, 2009^78^ | RCT | Grp1: Metformin Varied, NS Start: 500 mg, Max: 1000 mg D: 1 week Gpr2: Saxagliptin Fixed | Grp1: 3 (1) Grp2: 0 (0)
Metformin versus meglitinide
Horton, 2000^79^ | RCT | Grp1: Metformin Fixed Start: 500 mg tid Grp2: Nateglinide Fixed Start: 120 mg tid | Grp1: 1 (0.6) Grp2: 0 (0) | Def: CVD mortality/due to arteriolosclerotic and hypertensive heart disease + unclear CHD Grp1: 1 (0.6) Grp2: 0 (0) | Def: CVD morbidity/electrocardiogram abnormalities Grp1: 0 (0) Grp2: 0 (0)
Metformin versus metformin + thiazolidinedione
Hsiao, 2009^173^ | Cohort | Grp1: Metformin NS Grp2: Metformin + rosiglitazone NS | | | Def: Angina pectoris defined by ICD-9-CM diagnostic codes for hospitalization Grp1: 1367 (2.97) Grp2: 103 (4.26) Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 484 (1.02) Grp2: 25 (1.03) | Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 116 (0.25) Grp2: 12 (0.49) Def: TIA defined by ICD-9-CM diagnostic codes of hospitalization Grp1: 285 (0.63) Grp2: 11 (0.45)
McAfee, 2007^181^ | Cohort | Grp1: Metformin NR Grp2: Metformin + rosiglitazone NR | | | Def: Composite outcome Grp1: 149 (2) Grp2: 24 (2)
McAfee, 2007^181^ | Cohort | Grp1: Metformin NR Grp2: Metformin + rosiglitazone NR | | | Def: Non-fatal MI Grp1: 62 (1) Grp2: 6 (<1)
McAfee, 2007^181^ | Cohort | Grp1: Metformin NR Grp2: Metformin + rosiglitazone NR | | | Def: Inpatient MI and coronary revascularization using ICD-9 and CPT codes Grp1: OR: 6.1 Grp2: ref
Weissman, 2005^86^ | RCT | Grp1: Metformin Varied Start: 1000mg, Max: 2000mg Grp2: Metformin + rosiglitazone Fixed; Varied Start: 1000 mg; Start: 4 mg, Max: 8 mg | Grp1: 0 (0) Grp2: 1 (<1) | | Def: CVD morbidity/MI (non-fatal) Grp1: 0 (0) Grp2: 2 (1)
Weissman, 2005^86^ | RCT | Grp1: Metformin Varied Start: 1000mg, Max: 2000mg Grp2: Metformin + rosiglitazone Fixed; Varied Start: 1000 mg; Start: 4 mg, Max: 8 mg | | | Def: CVD morbidity/MI (non-fatal) + pulmonary edema with MI Grp1: 3 + 1 withdrew (1) Grp2: 5 (1)
Gomez-Perez, 2002^88^ | RCT | Grp1: Metformin Fixed Start: 2500 mg Grp2: Metformin + rosiglitazone Fixed Start: 2500 mg; Start: 2 mg bid | | | Def: CVD morbidity/ischemic heart disease + bundle branch block + tachycardia Grp1: 1 (3) Grp2: 1 (3)
Gomez-Perez, 2002^88^ | RCT | Grp1: Metformin Fixed Start: 2500 mg Grp2: Metformin + rosiglitazone Fixed Start: 2500 mg; Start: 4 mg bid | | | Def: CVD morbidity/ischemic heart disease + bundle branch block + tachycardia Grp1: 1 (3) Grp2: 2 (5)
Fonseca, 2000^90^ | RCT | Grp1: Metformin Fixed Start: 2500 mg Grp2: Metformin + rosiglitazone Fixed Start: 2500 mg; Start: 8 mg | Grp1: 0 (0) Grp2: 1 (1) | Def: CVD mortality/unclear mortality + Fatal MI Grp1: 0 (0) Grp2: 0 (0)
Bailey, 2005^87^ | RCT | Grp1: Metformin Varied Start: 2500 mg, Max: 3000 mg Grp2: Metformin + rosiglitazone Fixed; Varied Start: 2500mg; Start: 4 mg, Max: 8 mg | Grp1: 0 (0) Grp2: 1 (<1) | Def: CVD mortality/sudden cardiac death Grp1: 0 (0) Grp2: 1 (<1) | Def: CVD morbidity/MI (non-fatal) + pulmonary edema with MI Grp1: 0 (0) Grp2: 1 (<1)
Stewart, 2006^156^ | RCT | Grp1: Metformin Varied Start: 500 mg, Mean: 2627.9 mg, Max: 3000 mg D: 20wks Grp2: Metformin + rosiglitazone Varied Start: 500 mg, Mean: 1812.9 mg, Max: 2000 mg D: 18 wks | | | Def: MI, angina pectoris, myocardial ischemic, coronary artery insufficiency Grp1: 0 (0) Grp2: 4 (2)
Rosenstock, 2006^49^ | RCT | Grp1: Metformin Varied, glucose: 6.1 mmol/l Start: 500 mg, Max: 2000 mg, Mean: 1847 mg D: 32 wks Grp2: Metformin + rosiglitazone Varied, glucose: 6.1 mmol/l Start: 500 mg, Mean: 1799 mg, Max: 2000 mg; Start: 2 mg, Max: 8 mg, Mean: 7.2mg D: 32 wks | Grp1: 0 (0) Grp2: 0 (0) | | Def: Not defined ischemic heart disease Grp1: 2 (1) Grp2: 1 (1)
Jones, 2003^179^ | RCT | Grp1: Metformin Fixed Start: 2.5 g Grp2: Metformin + rosiglitazone Fixed; Varied, NS Start: 2.5 g; Max: 8 mg | Grp1: 0 (0) Grp2: 1 (1)
Metformin versus metformin + sulfonylurea
Hsiao, 2009^173^ | Cohort | Grp1: Metformin NS Grp2: Metformin + sulfonylurea NS | | | Def: Angina pectoris defined by ICD-9-CM diagnostic codes for hospitalization Grp1: 1367 (2.97) Grp2: 5910 (2.2) Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 484 (1.02) Grp2: 11435 (4.27) | Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 116 (0.25) Grp2: 588 (0.22) Def: TIA defined by ICD-9-CM diagnostic codes of hospitalization Grp1: 285 (0.63) Grp2: 1637 (0.61)
Fisman, 1999^178^ | Cohort | Grp1: Metformin NR Grp2: Metformin + sulfonylurea NR | Grp1: 20 (26) Grp2: 84 (32) | Def: Fatal MI Grp1: 39.3/1000 person-years Grp2: 35.3/1000 person-years | Def: CVD mortality/CVD mortality + ICD-9 codes 410–414 + matched the patients ID number with their life status in the population registry + ischemic heart disease Grp1: IR: 30/1000 person-years Grp2: IR: 31.2/1000 person-years
Gulliford, 2004^170^ | Cohort | Grp1: Metformin NR Grp2: Metformin + sulfonylurea NR | Grp1: 144 (5) Grp2: 159 (6)
Kahler, 2007^175^ | Cohort | Grp1: Metformin NR Grp2: Metformin + sulfonylurea NR | Grp1: 82 (2.7) Grp2: 468 (3.4)
Evans, 2006^176^ | Cohort | Grp1: Metformin NR Grp2: Metformin + later addition of sulfonylurea NR | | Def: Cardiovascular mortality Grp1: Adjusted RR 2.29 (CI: 1.45–3.61) Grp2: ref
Evans, 2006^176^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea + later addition of metformin NR | | Def: Cardiovascular mortality Grp1: Adjusted RR 2.43 (CI: 1.61–3.66) Grp2: ref
McAfee, 2007^181^ | Cohort | Grp1: Metformin NR Grp2: Metformin + sulfonylurea NR | | | Def: Inpatient MI and coronary revascularization using ICD-9 and CPT codes Grp1: 149 (2) Grp2: 36 (3)
McAfee, 2007^181^ | Cohort | Grp1: Metformin NR Grp2: Metformin + sulfonylurea NR | | | Def: MI based on ICD-9 diagnosis codes (could be fatal or nonfatal MI since not specified but likely nonfatal mostly) Grp1: 62 (1) Grp2: 17 (1)
Garber, 2003^61^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 2000 mg; Start: 1.25 mg, Max: 20 mg | Grp1: 0 (0) Grp2: 2 (1)
Goldstein, 2003^62^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glipizide Varied Start: 500 mg, Max: 2000 mg; Start: 5 mg, Max: 20 mg | Grp1: 0 (0) Grp2: 0 (0)
DeFronzo, 1995^70^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2500 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 2500 mg; Start: 10 mg, Max: 20 mg | Grp1: 1 (1)) Grp2: 0 (0)
Hermann, 1994^68^ | RCT | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 1500 mg; Start: 1.75mg, Max: 5.25 mg | | | Def: CVD morbidity/unclear CHD Grp1: 2( 5) Grp2: 10 (14)
Chien, 2007^59^ | RCT | Grp1: Metformin Varied, glucose: <140 mg/dL Start: 1000 mg, Max: 2000 mg, Final mean: 1910 mg D: 4 wks Grp2: Metformin + glyburide Varied, glucose: <140 mg/dL Start: 1000 mg, Max: 2000 mg, Final mean: 1680 mg; Start: 5 mg, Max: 10 mg, Final mean: 8.4 mg D: 4 wks | Grp1: 0 (0) Grp2: 0 (0)
Johnson, 2002^168^ | Cohort | Grp1: Metformin NR Grp2: Metformin + sulfonylurea NR | Grp1: 159 (14) Grp2: 635 (14)
Eurich, 2005^169^ | Cohort | Grp1: Metformin NR Grp2: Metformin + sulfonylurea NR | Grp1: 69 (33) Grp2: 263 (31)
Fisman, 2001^177^ | Cohort | Grp1: Metformin NR Grp2: Metformin + Glyburide NR | Grp1: 25 (32) Grp2: 111 (44)
Metformin versus metformin + DPP-IV inhibitor
Raz, 2008^93^ | RCT | Grp1: Metformin Fixed Grp2: Metformin + sitagliptin Fixed Max: 2550 mg; Mean: 100 mg | Grp1: 1 (1) Grp2: 0 (0) | Def: Fatal MI Grp1: 1 (1) Grp2: 0 (0)
Jadzinsky, 2009^78^ | RCT | Grp1: Metformin + saxagliptin Varied, prespecified target dose; Fixed Start: 500 mg, Max: 1000 mg; Mean: 10 mg D: 1 week Grp2: Metformin Varied, NS Start: 500 mg, Max: 1000 mg D: 1 week | Grp1: 0 (0) Grp2: 3 (1)
Jadzinsky, 2009^78^ | RCT | Grp1: Metformin + saxagliptin Varied, prespecified target dose; Fixed Start: 500 mg, Max: 1000 mg; Mean: 5 mg Grp2: Metformin Varied, NS Start: 500 mg, Max: 1000 mg D: 1 week | Grp1: 0 (0) Grp2: 3 (1)
Thiazolidinedione versus thiazolidinedione
Juurlink, 2009^210^ | Cohort | Grp1: Rosiglitazone Varied, NS Grp2: Pioglitazone Varied, NS | Grp1: 645 (3) Grp2: 377 (2) HR: 0.86 (CI: 0.75 to 0.98) | Def: Death or admission to hospital Grp1: 1563 events Grp2: 895 events HR: 0.83 (CI: 0.76 to 0.9) | Def: Acute MI Grp1: 425 events Grp2: 273 events HR: 0.95 (CI: 0.81 to 1.11) Def: Hospitalization Grp1: 869 events Grp2: 461 events HR: 0.77 (CI: 0.69 to 0.87)
Hsiao, 2009^173^ | Cohort | Grp1: Rosiglitazone NS Grp2: Pioglitazone NS | | | Def: Angina pectoris defined by ICD-9-CM diagnostic codes for hospitalization Grp1: 154 (7.52) Grp2: 22 (4.51) Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 266 (12.71) Grp2: 44 (8.89) | Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 16 (0.8) Grp2: 2 (0.41) Def: TIA defined by ICD-9-CM diagnostic codes of hospitalization Grp1: 23 (1.14) Grp2: 5 (1.03)
Pantalone, 2009^174^ | Cohort | Grp1: Rosiglitazone NR Grp2: Pioglitazone NR | Grp1: ref Grp2: HR: 0.81 (CI: 0.52 to 1.27) p: 0.36 | | Def: CABG, PTCA, MI, or diagnosis of CAD by ICD-9 after baseline Grp1: ref Grp2: HR: 1.15 (CI: 0.87 to 1.53) p: 0.32
Thiazolidinedione versus sulfonylurea
Hsiao, 2009^173^ | Cohort | Grp1: Pioglitazone NS Grp2: Sulfonylurea NS | | | Def: Angina pectoris defined by ICD-9-CM diagnostic codes for hospitalization Grp1: 22 (4.51) Grp2: 3721 (3.87) Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 44 (8.89) Grp2: 1678 (1.76) | Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 2 (0.41) Grp2: 318 (0.34) Def: TIA defined by ICD-9-CM diagnostic codes of hospitalization Grp1: 5 (1.03) Grp2: 940 (0.99)
Hsiao, 2009^173^ | Cohort | Grp1: Rosiglitazone NS Grp2: Sulfonylurea NS | | | Def: Angina pectoris defined by ICD-9-CM diagnostic codes for hospitalization Grp1: 154 (7.52) Grp2: 3721 (3.87) Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 266 (12.71) Grp2: 1678 (1.76) | Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 16 (0.8) Grp2: 318 (0.34) Def: TIA defined by ICD-9-CM diagnostic codes of hospitalization Grp1: 23 (1.14) Grp2: 940 (0.99)
Brownstein, 2010^182^ | Cohort | Grp1: Rosiglitazone NS Grp2: Sulfonylurea | | | Def: Hospitalization for acute MI Grp1: HR: 1.3 (CI: 1.0-1.7) Grp2: ref
Tzoulaki, 2009^174^ | Cohort | Grp1: Rosiglitazone NS Grp2: Sulfonylurea NS | Grp1: 34 (<1) Grp2: 1379 (2) | | Def: Incident MI Grp1: 9 (<1) Grp2: 365 (1)
Pantalone, 2009^174^ | Cohort | Grp1: Rosiglitazone NR Grp2: Sulfonylurea NR | Grp1: HR: 0.73 (CI: 0.51 to 1.02) p: 0.08 Grp2: ref | | Def: CABG, PTCA, MI, or diagnosis of CAD by ICD-9 after baseline Grp1: HR: 0.90 (CI: 0.71 to 1.14) p: 0.41 Grp2: ref
Pantalone, 2009^174^ | Cohort | Grp1: Pioglitazone NR Grp2: Sulfonylurea NR | Grp1: HR: 0.59 (CI: 0.43 to 0.81) p: <0.001 Grp2: ref | | Def: CABG, PTCA, MI, or diagnosis of CAD by ICD-9 after baseline Grp1: HR: 1.04 (CI: 0.86 to 1.26) p: 0.69 Grp2: ref
McAfee, 2007^181^ | Cohort | Grp1: Rosiglitazone NR Grp2: Sulfonylurea NR | | | Def: Inpatient MI and coronary revascularization using ICD-9 and CPT codes Grp1: 152 (2) Grp2: 191 (2)
McAfee, 2007^181^ | Cohort | Grp1: Rosiglitazone NR Grp2: Sulfonylurea NR | | | Def: MI based on ICD -9 diagnosis codes (could be fatal or nonfatal MI since not specified but likely nonfatal mostly) Grp1: 70 (1) Grp2: 94 (1)
Hanefeld, 2007^100^ | RCT | Grp1: Rosiglitazone Fixed Start: 4 mg D: 12 wks Grp2: Glibenclamide Varied Start: 2.5 mg, Max: 15 mg D: 12 wks | Grp1: 0 (0) Grp2: 0 (0)
Hanefeld, 2007^100^ | RCT | Grp1: Rosiglitazone Fixed Start: 8 mg D: 12 wks Grp2: Glibenclamide Varied Start: 2.5 mg, Max: 15 mg D: 12 wks | Grp1: 0 (0) Grp2: 0 (0)
Kahn, 2006^38^ | RCT | Grp1: Rosiglitazone Varied, glucose: 140 mg/dL Start: 4 mg, Max: 8 mg Grp2: Glyburide Varied, glucose: 140 mg/dL Start: 2.5 mg, Max: 15 mg | Grp1: 34 (2) Grp2: 31 (2) | Def: Fatal MI Grp1: 2 (0.1) Grp2: 3 (0.2) | Def: Non-fatal MI Grp1: 25 (1.7) Grp2: 15 (1) | Def: Stroke not defined Grp1: 16 (1.1) Grp2: 17 (1.2)
Jain, 2006^101^ | RCT | Grp1: Pioglitazone Varied, glucose: 69–141 mg/dL Start: 15 mg, Median: 45 mg, Max: 45 mg D: 12 wks Grp2: Glyburide Varied, glucose: 69–141 mg/dL Start: 5 mg, Median: 10 mg, Max: 15 mg D: 12 wks | Grp1: 0 (0) Grp2: 2 (0.8) | | Def: Non-fatal MI Grp1: 2 (0.8) Grp2: 2 (0.8)
St John Sutton, 2002^149^ | RCT | Grp1: Rosiglitazone Fixed Start: 4 mg bid Grp2: Glyburide Varied Max: 20 mg | | | Def: CVD morbidity/heart disease Grp1: 9 (9) Grp2: 5 (5)
Sulfonylurea versus meglitinide
Marbury, 1999^117^ | RCT | Grp1: Glyburide Varied Start: 2.5 mg, Max: 4 mg bid Grp2: Repaglinide Varied Start: 0.5 mg, Max: 12 mg | Grp1: 1 (1) Grp2: 3 (1) | | Def: CVD morbidity/unclear CHD Grp1: 4 (2) Grp2: 19 (5)
Wolffenbuttel, 1999^116^ | RCT | Grp1: Glyburide Varied Start: 1.75 mg, Max: 10.5 mg bid Grp2: Repaglinide Varied Start: 1.5 mg, Max: 12 mg | | | Def: Cardiac events NOS Authors stated similar frequencies in each group but no data given
Sulfonylurea versus GLP-1 agonists
Seino, 2010^121^ | RCT | Grp1: Glibenclamide Varied, prespecified target dose Start: 1.25 mg, Max: 2.5 mg D: 4 weeks Grp2: Liraglutide Varied, prespecified target dose Start: 0.3 mg, Max: 0.9 mg D: 2 weeks | Grp1: 0 (0) Grp2: 1 (<1) | | Grp1: 9 (6.8) Grp2: 9 (3.4)
Metformin + thiazolidinedione versus metformin + sulfonylurea
Hsiao, 2009^173^ | Cohort | Grp1: Metformin + rosiglitazone NS Grp2: Metformin + sulfonylurea NS | | | Def: Angina pectoris defined by ICD-9-CM diagnostic codes for hospitalization Grp1: 103 (4.26) Grp2: 5910 (2.2) Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 25 (1.03) Grp2: 11435 (4.27) | Def: ICD-9-CM diagnostic codes of hospitalization Grp1: 12 (0.49) Grp2: 588 (0.22) Def: TIA defined by ICD-9-CM diagnostic codes of hospitalization Grp1: 11 (0.45) Grp2: 1637 (0.61)
McAfee, 2007^181^ | Cohort | Grp1: Metformin + rosiglitazone NR Grp2: Metformin + sulfonylurea NR | | | Def: Inpatient MI and coronary revascularization using ICD-9 and CPT codes Grp1: 24 (2) HR: 0.61 (0.37 to 1.03) Grp2: 36 (3)
McAfee, 2007^181^ | Cohort | Grp1: Metformin + rosiglitazone NR Grp2: Metformin + sulfonylurea NR | | | Def: MI based on ICD -9 diagnosis codes (could be fatal or nonfatal MI since not specified but likely nonfatal mostly) Grp1: 6 (<1) Grp2: 17 (1)
Hamann, 2008^123^ | RCT | Grp1: Metformin + rosiglitazone Varied, glucose: 6.1 mmol/l Start: 2 g; Start: 4 mg D: 12 wks Grp2: Metformin + sulfonylurea Varied, glucose: 6.1 mmol/l Start: 2 g; Start: 5 mg D: 12 wks | Grp1: 2 (1) Grp2: 2 (1)
Bakris, 2006^125^ | RCT | Grp1: Metformin + rosiglitazone Varied, NS; Varied, glucose: ≤ 6.6 mmol/L Unclear; Start: 4mg D: 3 wks Grp2: Metformin + glyburide Varied, NS; Varied, glucose: ≤ 6.6mmol/L Unclear; Start: 5 mg D: 3 wks | Grp1: 1 (1) Grp2: 0 (0)
Metformin + thiazolidinediones versus metformin + DPP-4 inhibitors
Rigby, 2009^130^ | RCT | Grp1: Metformin + rosiglitazone Fixed NS; Mean: 4 mg Grp2: Metformin + sitagliptin NS: Mean: 100 mg | | | Def: Transient ischemic cerebrovascular accident Grp1: 1 (2) Grp2: 0 (0)
Metformin + thiazolidinediones versus metformin + meglitinides
Raskin, 2009^131^ | RCT | Grp1: Metformin + rosiglitazone Varied, prespecified target dose Start: 1000 mg, Max: 2500 mg; Start: 4 mg, Max: 8 mg D: 4 wks Grp2: Metformin + repaglinide Varied Start: 1000 mg, Max: 2500 mg; Start: 4 mg, Max: 10 mg D: 4 wks | Grp1: 0 (0) Grp2: 1 (1) | Def: Sudden cardiac death Grp1: 0 (0) Grp2: 1 (1)
Metformin + thiazolidinedione versus thiazolidinedione + sulfonylurea
McAfee, 2007^181^ | Cohort | Grp1: Metformin + rosiglitazone NR Grp2: Rosiglitazone + sulfonylurea NR | | | Def: Inpatient MI and coronary revascularization using ICD-9 and CPT codes Grp1: 24 (2) HR: 0.61 (0.37 to 1.03) Grp2: 6 (<1)
McAfee, 2007^181^ | Cohort | Grp1: Metformin + rosiglitazone NR Grp2: Rosiglitazone + sulfonylurea NR | | | Def: MI based on ICD-9 diagnosis codes (could be fatal or nonfatal MI since not specified but likely nonfatal mostly) Grp1: 6 (<1) Grp2: 21 (2)
Rosak, 2006^183^ | RCT | Grp1: Metformin + rosiglitazone Varied Grp2: Rosiglitazone + sulfonylurea Varied NS; Start: 4 mg, Max: 8 mg | | | Def: Not defined Grp1: 0.08/100 patient-years (0.04) Grp2: 0.22/100 patient-years (0.11) | Def: Not defined Grp1: 0.03/100 patient years (0.36) Grp2: 0.01/100 patient-years (0.18)
Metformin + sulfonylurea versus metformin + meglitinide
Monami, 2008^180^ | Cohort | Grp1: Metformin + sulfonylurea NR Grp2: Metformin + repaglinide NR | Grp1: 35/6344 person-months Grp2: 5/2013 person-months
Schwarz, 2008^152^ | RCT | Grp1: Metformin + glyburide Varied, glucose: 6.7mmol/l Start: 500 mg, Max: 2000 mg D: 12 wks Grp2: Metformin + nateglinide Varied, glucose: 6.7mmol/l Start: 500 mg; Max: 2000 mg D: 12 wks | Grp1: 1 (3) Grp2: 0 (0)
Gerich, 2005^136^ | RCT | Grp1: Metformin + glyburide Varied, glucose: 6.7 mmol/l Start: 500 mg, Max: 2000 mg, Mean: 1105mg D: 12 wks Grp2: Metformin + nateglinide Varied, glucose: 6.7 mmol/l Start: 500 mg, Max: 2000 mg, Mean: 1459 mg D: 12 wks | Grp1: 1 (1) Grp2: 1 (1)
Metformin + sulfonylurea versus metformin + DPP-IV inhibitors
Seck, 2010^134^ | RCT | Grp1: Metformin + sitagliptin Fixed Grp2: Metformin + glipizide Fixed; Varied, glucose > 110 mg/dl NR; Start: 5 mg, Max: 20 mg, Mean: 9.2 mg | Grp1: 8 (1.4) Grp2: 1 (0.2) | Def: Sudden cardiac death Grp1: 2 (<1) Grp2: 0 (0)
Nauck, 2007^133^ | RCT | Grp1: Metformin + glipizide NR Grp2: Metformin + sitagliptin NR | Grp1: 2 (0.3) Grp2: 1 (0.2) | Def: Fatal MI Grp1: 1 (0.2) Grp2: 0 (0)
Metformin + sulfonylurea versus metformin + GLP-1 agonists
Pratley, 2010^143^ | RCT | Grp1: Metformin + sitagliptin NS; Max: 100 mg Grp2: Metformin + liraglutide Varied, HgbA1c: 7.5–10% NS; Start: 0.6 mg, Max: 1.8 mg | | Def: Fatal cardiac arrest Grp1: 1 (<1) Grp2: 0 (0)
Pratley, 2010^143^ | RCT | Grp1: Metformin + sitagliptin NS; Max: 100 mg Grp2: Metformin + liraglutide Varied, HgbA1c: 7.5–10% NS; Start: 0.6 mg, Max: 1.2 mg | | Def: Fatal cardiac arrest Grp1: 1 (<1) Grp2: 0 (0)
Metformin + sulfonylurea versus thiazolidinedione + sulfonylurea
McAfee, 2007^181^ | Cohort | Grp1: Metformin + sulfonylurea NR Grp2: Rosiglitazone + sulfonylurea NR | | | Def: Inpatient MI and coronary revascularization using ICD-9 and CPT codes Grp1: 36/1852 person-years Grp2: 39/1474 person-years
McAfee, 2007^181^ | Cohort | Grp1: Metformin + sulfonylurea NR Grp2: Rosiglitazone + sulfonylurea NR | | | Def: MI based on ICD-9 diagnosis codes (could be fatal or nonfatal MI since not specified but likely nonfatal mostly) Grp1: 17/1865 person-years Grp2: 21/1495 person-years
Hanefeld, 2004^140^ | RCT | Grp1: Metformin + sulfonylurea Varied; NR Start: 850 mg, Max: 850 mg tid; NR Grp2: Pioglitazone + sulfonylurea Varied; NR Start: 15 mg, Max: 45 mg; NR | Grp1: 2 (1) Grp2: 1 (<1) | | Def: Coronary heart diseases/cardiac disorders Grp1: (3.1) Grp2: (4.1)
van der Meer, 2009^141^ | RCT | Grp1: Metformin + glimepiride Fixed Start: 1000 mg, Max: 2000 mg; Start: 15 mg, Max: 30 mg D: 8 wks Grp2: Pioglitazone + glimepiride Varied Not specified D: 8 weeks | | Def: CVD event Grp1: 0 (0) Grp2: 0 (0)
Metformin + sulfonylurea versus metformin + premixed insulin
Kvapil, 2006^138^ | RCT | Grp1: Metformin + sulfonylurea Fixed; Varied Start: 1660 mg; Start: 1.75 mg, Max: 10.5, Mean: 6.58 Grp2: Metformin + aspart 70/30 Fixed; Varied Start: 1660 mg; Start: 0.2 U/kg BID, Mean: 0.3 BID | Grp1: 0 (0) Grp2: 1 | Def: Fatal MI Grp1: 0 (0) Grp2: 1
Malone, 2003^137^ | RCT | Grp1: Metformin + glibenclamide Varied; Varied, fasting and pre-meal goal <7mmol/L, 2- hour post-prandial goal <10mmol/L Max: 2550 mg, Mean: 1968 mg; Mean: 14.2 mg D: 4 wks; 16 wks Grp2: Metformin + lispro 75/25 Varied; Varied, fasting and pre-meal goal <7mmol/L, 2- hour post-prandial goal <10mmol/L Max: 2550 mg; Mean: 0.19 U/kg in am and 0.14 U/kg in evening D: 4 wks; 16 wks | Grp1: 0 (0) Grp2: 1 (<1)
Metformin + sulfonylureas versus metformin or sulfonylureas + thiazolidinediones
Home, 2009^16^ | RCT | Grp1: Metformin + sulfonylurea Varied, HgbA1c: ≤7.0% Max: 2550 mg; Glibenclamide, Max: 15 mg, Glimepiride, Max: 4 mg D: 8 wks Grp2: Rosiglitazone + metformin or sulfonylurea Varied, HgbA1c: ≤7.0% Start: 4 mg, Max: 8 mg; Metformin, Max: 2550 mg, Glibenclamide, Max: 15 mg, Glimepiride, Max: 4 mg D: 8 wks | Grp1: 157 Grp2: 136 HR: 0.86 (CI: 0.68 to 1.08), p: 0.19 | Grp1: 71 Grp2: 60 HR: 0.84 (CI: 0.59 to 1.18), p: 0.32 | Def: Fatal and non-fatal MI Grp1: 56 Grp2: 64 HR: 1.14 (CI: 0.80 to 1.63), p: 0.47 | Def: Fatal and nonfatal stroke Grp1: 63 Grp2: 46 HR: 0.72 (CI: 0.49 to 1.06), p: 0.10
Metformin + basal insulin versus metformin + premixed insulin
Malone, 2005^165^ | RCT | Grp1: Metformin + lispro 75/25 Varied, premeal glucose 90–126 mg/dL; 2-hr postprandial 144–180 mg/dL Start: 1500 mg, Max: 2550 mg, Mean: 2146 mg; Mean: 0.42 U/kg BID D: 4 wks, 16 wks Grp2: Metformin + glargine Varied, pre-meal glucose 90–126 mg/dL Start: 1500 mg, Max: 2500 mg, Mean: 2146 mg; Mean: 0.36 U/Kg QD D: 4 wks, 16 wks | Grp1: 1 (2) Grp2: 1 (2) | Grp1: 1 (2) Grp2: 0 (0)

Author, year | Study design | Intervention | Nephropathy, n (%) | Neuropathy, n (%)
Metformin versus thiazolidinedione
Schernthaner, 2004^52^ | RCT | | Def: urinary albumin/creatinine ratio
Schernthaner, 2004^52^ | RCT | Grp1: Metformin Varied Start: 850 mg, Max: 2550 mg | Grp1: 1%
Schernthaner, 2004^52^ | RCT | Grp2: Pioglitazone Varied Start: 30 mg, Max: 45 mg | Grp2: 19%, p: 0.002 vs. Grp2
Metformin versus sulfonylurea
Amador-Licona, 2000^66^ | RCT | | Def: change in glomerular filtration rate
Amador-Licona, 2000^66^ | RCT | Grp1: Metformin Varied Start: 850mg, Max: NR | Grp1: B: 138 mL/min F: 134 mL/min, p=0.46 vs. baseline
Amador-Licona, 2000^66^ | RCT | Grp2: Glibenclamide Varied Start: 5mg, Max: NR | Grp2: B: 136 mL/min F: 151 mL/min, p=0.04 vs. baseline
Amador-Licona, 2000^66^ | RCT | | Def: change in microalbumin (mg/d)
Amador-Licona, 2000^66^ | RCT | Grp1: Metformin Varied Start: 850 mg, Max: NR | Grp1: B: 74 mg/d F: 49 mg/d, p=0.008 vs. baseline
Amador-Licona, 2000^66^ | RCT | Grp2: Glibenclamide Varied Start: 5 mg, Max: NR | Grp2: B: 83 mg/d F: 102 mg/d, p=0.09 vs. baseline
Metformin versus metformin + thiazolidinedione
Gomez-Perez, 2002^88^ | RCT | | | Def: Unclear neuropathy
Gomez-Perez, 2002^88^ | RCT | Grp1: Metformin Fixed Start: 2500 mg | | Grp1: 1
Gomez-Perez, 2002^88^ | RCT | Grp2: Metformin + rosiglitazone Fixed Start: 2500 mg; Start: 2 mg bid | | Grp2: 0 (0)
Gomez-Perez, 2002^88^ | RCT | | | Def: Unclear neuropathy
Gomez-Perez, 2002^88^ | RCT | Grp1: Metformin Fixed Start: 2500 mg | | Grp1: 1
Gomez-Perez, 2002^88^ | RCT | Grp2: Metformin + rosiglitazone Fixed Start: 2500mg; Start: 4mg bid | | Grp2: 0 (0)
Metformin versus metformin + DPP-IV inhibitors
Raz, 2008^93^ | RCT | | | Def: NR
Raz, 2008^93^ | RCT | Grp1: Metformin Fixed NR | | Grp1: 2 (2.1)
Raz, 2008^93^ | RCT | Grp2: Metformin + sitagliptin Fixed Max: 2550 mg; Mean: 100 mg | | Grp2: 4 (4.2)
Thiazolidinedione versus sulfonylurea
Nakamura, 2006^108^ | RCT | | Def: Urine albumin excretion ( microgram/min), mean (SD)
Nakamura, 2006^108^ | RCT | Grp1: Pioglitazone Fixed Mean: 30 mg | Grp1: Baseline: 142.5 (46.5); 12 mos: 40.5 (20.5) p<0.001
Nakamura, 2006^108^ | RCT | Grp2: Glibenclamide Fixed Mean: 5 mg | Grp2: Baseline: 136.5 (40.8); 12 mos: 146.0 (48.8)
Nakamura, 2006^108^ | RCT | | Grp1–Grp2: −111.5
Nakamura, 2004^102^ | RCT | | Def: Urine albumin excretion ( microgram/min), mean (SD)
Nakamura, 2004^102^ | RCT | Grp1: Pioglitazone Fixed Start: 30 mg | Grp1: 6 mos: 86.5 (24.5); 12 mos: 44.5 (16.4)
Nakamura, 2004^102^ | RCT | Grp2: Glibenclamide Fixed Start: 5 mg | Grp2: 6 mos: 142.5 (42.5); 12 mos: 146.8 (38.5)
Nakamura, 2004^102^ | RCT | | Grp1–Grp2: 6 mos, p: <0.05; 12 mos: <0.01
Agarwal, 2005^184^ | RCT | | Def: Proteinuria
Agarwal, 2005^184^ | RCT | Grp1: Pioglitazone Varied, glucose: 140 mg/dL, HgbA1c: 8% Start: 15 mg, Mean: 33 mg, Max: 41 mg D: 3.8 mos | Grp1: % mean reduction: 7.2, CI: −24.9 – 10.6
Agarwal, 2005^184^ | RCT | Grp2: Glipizide Varied, glucose: 140 mg/dL, HgbA1c: 8% Start: 5 mg, Mean: 16 mg, Max: 19 mg D: 3.7 mos | Grp2: % mean increase: 6.1, CI: −11.7–23.8
Agarwal, 2005^184^ | RCT | | Grp1–Grp2: % reduction: 13.2, CI: −38.4 –11.9, p: 0.294
Bakris, 2003^104^ | RCT | | Def: n (%) with normal albuminuria at baseline who progressed to microalbuminuria by study end
Bakris, 2003^104^ | RCT | Grp1: Rosiglitazone Fixed Start: 4 mg bid | Grp1: 3 (7)
Bakris, 2003^104^ | RCT | Grp2: Glyburide Varied Start: NR, Max: 20 mg | Grp2: 5 (10.6)
Bakris, 2003^104^ | RCT | | Def: albumin/creatinine ratio
Bakris, 2003^104^ | RCT | Grp1: Rosiglitazone Fixed Start: 4 mg bid | Grp1: (−45 to −4) p: NSG vs. Grp2
Bakris, 2003^104^ | RCT | Grp2: Glyburide Varied Start: NR, Max: 20 mg | Grp2: (−22 to 4)
Nakamura, 2000^103^ | RCT | | Def: urinary albumin excretion
Nakamura, 2000^103^ | RCT | Grp1: Pioglitazone Fixed Start: 30 mg bid | Grp1: B: 142.8 ug/min F: 48.4 ug/min, p: < 0.05
Nakamura, 2000^103^ | RCT | Grp2: Glibenclamide Fixed Start: 5 mg | Grp2: B: NR F: NR, p: > 0.05
Thiazolidinedione versus meglitinide
Nakamura, 2006^108^ | RCT | | Def: Urine albumin excretion ( microgram/min), mean (SD)
Nakamura, 2006^108^ | RCT | Grp1: Pioglitazone Fixed Mean: 30 mg | Grp1: Baseline: 142.5 (46.5); 12 mos: 40.5 (20.5) p<0.001
Nakamura, 2006^108^ | RCT | Grp2: Nateglinide Fixed Mean: 270 mg | Grp2: Baseline: 134.6 (42.8); 12 mos: 140.8 (44.4)
Nakamura, 2006^108^ | RCT | | Grp1–Grp2: −108.2
Metformin + thiazolidinedione versus metformin + sulfonylurea
Bakris, 2006^125^ | RCT | | Def: % change in UACR (urine albumin: creatinine ratio >=30), Mean (SD)
Bakris, 2006^125^ | RCT | Grp1: Metformin + rosiglitazone Varied; Varied, glucose: ≤ 6.6 mmol/L NS; Start: 4mg D: 3 wks | Grp1: −22.7 (15), p: <0.01
Bakris, 2006^125^ | RCT | Grp2: Metformin + Glyburide Varied; Varied, glucose: ≤6.6 NR; Start: 5 mg D: 3 wks | Grp2: −5.5 (14.5), p: NSG
Bakris, 2006^125^ | RCT | | Grp1–Grp2: −15.5%, p: 0.07
Comaschi, 2007^129^ | RCT | Grp1: Metformin + pioglitazone Varied, NR Max: 3 g; Start: 15 mg, Max: 30 mg D: NR; 22 wks | | Grp1: 1
Comaschi, 2007^129^ | RCT | Grp2: Metformin + glibenclamide Varied, HgbA1c: 7.50% Start: 400mg, Max: 3g; Start: 2.5mg D: 22 wks | | Grp2: 0 (0)
Metformin + sulfonylurea versus thiazolidinedione + sulfonylurea
Hanefeld, 2004^140^ | RCT | | Def: albumin/creatinine ratio
Hanefeld, 2004^140^ | RCT | Grp1: Metformin + unspecified sulfonylurea + placebo Varied Start: 850 mg, Max: 2550 mg; NR | Grp1:
Hanefeld, 2004^140^ | RCT | Grp2: Pioglitazone + unspecified sulfonylurea + placebo Varied Start: 15 mg, Max: 45 mg; NR | Grp2: CI: 0.73–0.97, p: 0.017 vs. Grp1
Hanefeld, 2004^140^ | RCT | | Def: microalbuminuria resolved
Hanefeld, 2004^140^ | RCT | Grp1: Metformin + unspecified sulfonylurea + placebo Varied Start: 850 mg, Max: 2550 mg; NR | Grp1: 7.7%
Hanefeld, 2004^140^ | RCT | Grp2: Pioglitazone + unspecified sulfonylurea + placebo Varied Start: 15 mg, Max: 45 mg; NR | Grp2: 10.2%

bid= twice; CHD= coronary heart disease; CPT=current procedural terminology; CVD=cardiovascular disease; Def=definition; D=duration of titration; g = grams per day; Grp= group; HbA1c = hemoglobin A1c; HR= hazard ratio; ICD=International Classification of Diseases; ID= identification; IR= incidence ratio; Met= metformin; mg = milligram; MI= myocardial infarction; mmol/l = millimoles/liter; NOS= not otherwise specified; NR= not reported; OR= odds ratio; RCT= randomized controlled trial; RR=risk ratio; SU= sulfonylurea; tid = thrice; U/kg = unit per kilogram; wks = weeks

B=Baseline; bid=twice; CI= Confidence interval; Def=Definition; D= Duration of titration; F=Final; Grp=Group; HgbA1c = hemoglobin A1c; mos=Months; mg = milligram; mL/min = milliliter per minute; mmol/l = millimoles/liter; NR=Not reported; NSG=Not significant; RCT = Randomized controlled trial; ug/min= micrograms per minute; UACR= Urine albumin: creatinine ratio; wks=weeks

Table 9 Number of studies, strength of evidence domains, magnitude of effect, and strength of evidence

Outcome: Hypoglycemia
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^*^ | Precision | Magnitude and direction of effect
Met vs. TZD
1 trial | 2910 | Medium | Unknown | Direct | Precise | Small, No favorite | Moderate
Met vs. SU
11 RCTs | 6679 | Medium | Consistent | Direct | Precise | Large, Favors metformin | High
Met vs. DPP-4 Inhibitor
3 RCTs | 1918 | Medium | Consistent | Direct | Precise | Small, No favorite | High
Met vs. Meg
5 RCTs | 914 | Medium | Consistent | Direct | Imprecise | Small, Favors Met | Moderate
Met vs. Met + TZD
8 RCTs | 3073 | Medium | Consistent | Direct | Precise | Small, Favors Met alone | Moderate
Met vs. Met + SU
9 RCTs | 2141 | Medium | Consistent | Direct | Imprecise | Large, Favors Met alone | Moderate
Met vs. Met + DPP-4 Inhibitor
4 RCTs (in 5 reports) | 1448 | High | Consistent | Direct | Precise | Small, No favorite | Moderate
Met vs. Met + Meg
3 RCTs | 559 | Medium | Inconsistent | Direct | Imprecise | Large, Favors Met alone | Low
Rosi vs. Pio
1 obs. | 202 | High | Unknown | Direct | Imprecise | Small, Favors Rosi | Low
TZD vs. SU
8 RCTs, 1 obs | 10680 | Medium | Consistent | Direct | Precise | Large, Favors TZD | High
TZD vs. Meg
2 RCTs | 248 | High | Consistent | Direct | Precise | Small, Favors TZD | Low
SU vs. DPP-4 Inhibitor
1 RCT | 245 | Low | Unknown | Direct | Precise | Large, Favors DPP-4 inhibitor | Moderate
SU vs. Meg
8 RCTs | 1846 | Medium | Consistent | Direct | Precise | Small Favors Meg | Low
SU vs. GLP-1 Agonist
3 RCTs | 1310 | Low | Consistent | Direct | Precise | Medium, Favors liraglutide | High
Met + TZD vs. Met + Another Agent (mostly SU)
6 RCTs, 1 obs | 2543 | Medium | Consistent | Direct | Precise | Large, Favors Met + TZD | High
Met + TZD vs. TZD + SU
1 obs | 22808 | High | Unknown | Direct | Precise | Large, Favors Met + TZD | Low
Met + SU vs. Met + Another Agent
9 RCTs | 3409 | Low | Inconsistent | Direct | Imprecise | Small, Unclear, Depends on “other agent” | Low
Met + SU vs. TZD + SU
1 RCT | 441 | High | Unknown | Direct | Precise | Small, Favors TZD + SU | Low
Met + GLP-1 Agonist vs. Met + Basal Insulin
1 RCT | 69 | Low | Unknown | Direct | Imprecise | Large, Favors Met + exenatide | Low
Met + Basal Insulin vs. Met + Another Insulin
5 RCTs | 826 | Medium | Consistent | Direct | Precise | Medium, Favors Met + basal insulin | Moderate

Outcome: Liver injury
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^*^ | Precision | Magnitude and direction of effect
Met vs. TZD
1 RCt 1 Obs | 1194 | Low | Consistent | Direct | Precise | Small, no favorite | Moderate
Met vs. SU
1 RCT | 1194 | Low | Unknown | Direct | Imprecise | Unclear. | Low
Rosi vs. Pio
1 Obs | 3694 | Low | Unknown | Direct | Precise | Unclear | Low
TZD vs. SU
1 Obs, 2 RCT | 7764 | Moderate | Consistent | Direct | Precise | Small, no favorite | High
Met + TZD vs. Met + Another agent
1 RCT | 95 | Low | Unknown | Direct | Imprecise | No difference | Low
Met + SU vs. TZD + SU
2 RCT | 837 | High | Unknown | Direct | Precise | No difference | Low

Outcome: Congestive heart failure
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^*^ | Precision | Magnitude and Direction of Effect
Met vs. TZD
3 RCTS 4 Obs | 178691 | Medium | Inconsistent | Direct | Imprecise | Small. No favorite | Moderate
Met vs. SU
5 Obs | 189610 | Medium | Consistent | Direct | Precise | Small. Increase risk with SU | Moderate
Rosi vs. Pio
4 Obs | 45114 | High | Unknown | Direct | Imprecise | Unclear. | Low
TZD vs. SU
4 RCTs 5 Obs | 274880 | Medium | Consistent | Direct | Imprecise | Small. Increase risk with TZD | Moderate
Met + TZD vs. TZD + SU
1 Obs | 12193 | High | Unknown | Direct | Imprecise | Small. Increase risk with TZD + SU combination | Low
Met + SU vs. TZD + other
1 RCT | 2200 | Low | Unknown | Direct | Imprecise | Favors SU + Met | Low
Met + Basal Insulin vs. Met + Another Insulin
1 RCT | 67 | Low | Inconsistent | Direct | Imprecise | Unclear | Low

Outcome: Lactic acidosis
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^*^ | Precision | Magnitude and Direction of Effect
Met vs. SU
2 RCTs | 160 | Low | Consistent | Direct | Imprecise | Weak; no increased risk with Metformin | Moderate
Met vs. Met +SU
2 RCTs | 163 | Low | Consistent | Direct | Imprecise | Weak; no favorite | Moderate

Outcome: Cancer
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^*^ | Precision | Magnitude and Direction of Effect
Met vs. SU
1 Obs | 38860 | High | Unknown | Direct | Imprecise | Weak; favors Met | Low
Met vs. Meg
1 RCT | 96 | Low | Unknown | Direct | Imprecise | Weak; favors Meg | Low
Met vs. Met + SU
1 Obs | 45303 | High | Unknown | Direct | Imprecise | Weak; favors Met | Low
Met vs. Met +DPP-4 Inhibitor
1 RCT | 190 | Low | Unknown | Direct | Imprecise | Weak; favors Met + DPP-4 inhibitor | Low
TZD vs. SU
1 RCT | 502 | Low | Unknown | Direct | Imprecise | Weak; favors TZDs | Low

Outcome: Fractures
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^*^ | Precision | Magnitude and Direction of Effect
Met vs. TZD
1 RCT 1 Obs | 79533 | Medium | Unknown | Direct | Precise | Small. Favors metformin | High
Met vs. SU
2 RCTs 1 Obs | 135258 | Medium | Consistent | Direct | Imprecise | Unclear | Low
Met vs. Met+ TZD
1 RCT 2 Obs | 78275 | Medium | Unknown | Direct | Imprecise | Small, favors metformin | Low
Met vs. Met + SU
1 RCT | 59 | Medium | Unknown | Direct | Imprecise | Unclear | Low
Met vs. Met + DPP-4 Inhibitor
1 RCT | 190 | Medium | Unknown | Direct | Imprecise | Unclear | Low
TZD vs. SU
2 RCT 1 Obs | 87738 | Medium | Unknown | Direct | Imprecise | Small, favors SU | High
Met + SU vs. TZD + Another agent
1 RCT | 3325 | Low | Unknown | Direct | Precise | Small. Favors metformin + SU | High

Outcome: Pancreatitis
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^*^ | Precision | Magnitude and Direction of Effect
Met vs. Met +SU
1 RCT | 366 | Low | Unknown | Direct | Imprecise | Small, favors metformin | Low
DPP-4 Inhibitors vs. GLP-1 Agonists
1 RCT | 665 | Low | Unknown | Direct | Imprecise | Unclear, no favorite | Low
Sulfonylureas vs. GLP-1 Agonists
2 RCT | 1156 | Low | Unknown | Direct | Imprecise | Small, favors SU | Low

Outcome: Cholecystitis
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^*^ | Precision | Magnitude and Direction of Effect
Met vs. TZD
1 RCT | 205 | Low | Unknown | Direct | Imprecise | Small, favors metformin | Low
Met vs. Met + TZD
1 RCT | 569 | Low | Unknown | Direct | Imprecise | Small, favors TZD | Low
TZD vs. SU
1 RCT | 2120 | Low | Unknown | Direct | Imprecise | Small, no favorite | Low

Outcome: Macular edema
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^*^ | Precision | Magnitude and Direction of Effect
Met + TZD vs. Met + Another agent
1 RCT | 561 | Low | Unknown | Direct | Imprecise | Small, increased risk with metformin + TZD | Low

Outcome: Gastrointestinal effects
Number of Studies | Total N | Domains Pertaining to Strength of Evidence | | | | | Strength of Evidence
| | Risk of Bias: Design/Quality | Consistency | Directness^*^ | Precision | Magnitude and Direction of Effect
Met vs. TZD
5 RCTs | 5021 | Low | Consistent | Direct | Precise | Large; Favors TZD | High
Met vs. SU
11 RCTs, 1 Obs. | 10666 | Medium | Consistent | Direct | Precise | Large; Favors SU | Moderate
Met vs. DPP-4 Inhibitor
2 RCTs | 1028 | High | Unknown | Direct | Imprecise | Large; Favors Sitagliptin | Low
Met vs. Meg
4 RCTs | 776 | Medium | Inconsistent | Direct | Imprecise | Small; Unclear for “any GI effect”; favors MEG for diarrhea | Low
Met vs. Met + TZD
8 RCTs | 2977 | Medium | Consistent | Direct | Imprecise | Small; Unclear for “any GI effect”; favors Met+TZD for diarrhea | Moderate
Met vs. Met + SU
10 RCTs | 2786 | Medium | Consistent | Direct | Imprecise | Small; Unclear favorite; favors combination arm when combination dose of metformin lower | Moderate
Met vs. Met + DPP-4 Inhibitor
6 RCTs | 3355 | Medium | Consistent | Direct | Precise | Small; Unclear favorite | Low
Met vs. Met + Meg
1 RCT | 193 | Low | Unknown | Direct | Imprecise | Small; Unclear favorite | Low
TZD vs. SU
4 RCTs | 6083 | Low | Consistent | Direct | Precise | Small; Unclear favorite | High
TZD vs. Meg
1 RCT | 123 | Medium | Unknown | Direct | Imprecise | Small; Unclear favorite | Low
SU vs. GLP-1 Agonist
| | | | | | Favors SU | Low
Met + TZD vs. Met + SU
4 RCTs | 1212 | Low | Inconsistent | Direct | Imprecise | Small; Favors neither | Low
Met + TZD vs. Met + DPP-4 Inhibitor
1 RCT | 181 | Low | Unknown | Direct | Imprecise | Small; Favors neither | Low
Met + TZD vs. Met + GLP-1 Agonist
| | | | | | Favors met + TZD | Low
Met + SU vs. Met + DPP-4 Inhibitor
1 RCT | 1172 | Low | Unknown | Direct | Imprecise | Small; Favors neither | Low
Met + SU vs. Met + MEG
1 RCT | 66 | Low | Unknown | Direct | Imprecise | Small; Unclear favorite for “any GI side effects”; Favors Met + MEG for abdominal dyspepsia | Low
Met + basal insulin vs. Met + another insulin
1 RCT | 317 | Low | Unknown | Direct | Imprecise | Small; Unclear favorite | Low
Met + SU vs. TZD + SU
2 RCTs | 1591 | Medium | Consistent | Direct | Precise | Small; Favors TZD combination arm | Moderate

DPP-4 = dipeptidyl peptidase-4; GLP-1 = glucagon-like peptide-1; Meg = meglitinides; Met = metformin; NA = not applicable; Nateg = nateglinide; obs = observational study; Pio = pioglitazone; RCT = randomized controlled trial; Repag = repaglinide; Rosi = rosiglitazone; Sita = sitagliptin; SU = sulfonylurea; TZD = thiazolidinedione. All other comparisons were graded as insufficient since there were no studies of those comparisons. The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable. N=total N for all studies in each comparison. This is not necessarily the N for analysis because the N for analysis often was not stated for each outcome.

Table 10 Study design characteristics of studies reporting on the comparative effectiveness of diabetes medications on adverse events (KQ3)

Author, year Country | Study design | Enrollment period Followup duration | Run-in period | Planned interval of follow- up | Pharmaceutical support | Number screened/enrolled Source population | Exclusion criteria
Seino, 2010^121^ Japan | RCT | Neither year reported 24 weeks | Yes | < 6 months | Yes | NR/464 NR | Age <20 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), retinopathy, HbA1c <7% or >10%, BMI >35 kg/m^2^, treated with insulin within 12 weeks of the start of the study, receiving or expecting to receive systemic corticosteroids, known hypoglycemia unawareness or recurrent major hypoglycemia unawareness or reccurent major hypoglycemia, no Type 2 DM, treated with diet therapy for less than 8 weeks, on more than 1/2 of the recommended maximum dose of an SU (e.g., on more than 2.5 mg of glibenclamide)
Derosa, 2010^44^ Italy | RCT | Neither year reported 12 months | No run-in period | < 6 months | No | 128/128 | Age <18 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), neuropathy, retinopathy, HbA1c < 8%, BMI <25 kg/m^2^ or ≥30 kg/m^2^, pregnant, nursing, not using adequate contraception, history of ketoacidosis, severe anemia, not intolerant to metformin at maximum dosage (3,000 mg/day), not on metformin, diabetic neuropathy
Defronzo, 2010^132^ United States | RCT | Start year: 2006 End year: 2008 20 weeks | None | < 6 months | Yes | NR/137 NR | Age <18 or >75 years, HbA1c <6.8% or >10%, BMI <25 kg/m^2^ or >40 kg/m^2^, not on stable dose of metformin for at least 6 weeks, body weight stable for past 6 months, islet cell auto-antibodies, treatment with any other antidiabetic medication (other than metformin)
Aschner, 2010^77^ Multicontinent | RCT | Neither year reported 24 weeks | Run-in period but number of participants excluded was NR | NR | Yes | 2068/1050 NR | Age <18 and > 78 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c < 6.5% or >9%, treatment naive, no Type 2 DM, FPG <120 mg/dL or >250 mg/dL, triglycerides >600 mg/dL, CK > 2 times normal upper limit
Seck, 2010^134^ NR | RCT | Neither year reported 2 years | Run-in period but number of participants excluded was NR | < 6 months | Yes | 2141/1172 NR | Age <17 years or >78 years
Komajda, 2010^292^ Multicontinent | RCT | Start year: 2001 End year: 2003 5.5 years | None | NR | Yes | NR/4447 | Age <40 or > 75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c ≤7% or > 9%, BMI ≤25 kg/m^2^, planned cardiovascular intervention, uncontrolled hypertension, no Type 2 DM, current use of other anti-DM medications, hospitalization within last 3 months for CVD event, heart failure
Pratley, 2010^143^ Multi-continent, Europe, USA and Canada | RCT | Start year: 2008 End year: 2009 26 months | None | >= 6 months | Yes | 1302/665 | Age <18 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <7.5% or >10%, BMI >45 kg/m^2^, no Type 2 DM, cancer, contraindication to trial drugs, recurrent hypoglycemia or hypoglycemia unawareness, not on metformin for at least 3 months, on any non-metformin anti-hypoglycemic in past 3 months
Pantalone, 2009^174^ United States | Prospective or retrospective cohort | Start year: 1998 End year: 2006 8 years | NA | NA | Yes | NR/20450 Inpatient/hospital, Outpatient: primary care, Outpatient: subspecialty care setting | Age <18 years, history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), on dialysis, on combination ODM, on insulin or other injectible antidiabetics, history of CHF
Currie, 2009^173^ Taiwan | Prospective or retrospective cohort | Start year: 2000 End year: 2005 6 years | NA | NA | NR | 1432850/473483 Inpatient/hospital, Outpatient: primary care, Outpatient: subspecialty care setting | Type 1 DM, prescribed insulin only during study period, new diagnosis of Type 2 DM during the year before index date, switch between rosiglitazone and pioglitazone or combined use of both drugs during study period, prescribed ODM less than three times during study period
Currie, 2009^212^ United Kingdom | Prospective or retrospective cohort | Start year: 2000 5 years | NA | NA | No | 170000/62809 Outpatient: primary care, General Practices | Age <40 years at diabetes onset, <6 sequential prescriptions of ODM, secondary causes of DM
Tzoulaki, 2009^171^ United Kingdom | Prospective or retrospective cohort | Start year: 1990 End year: 2005 Mean 7.1 years | NA | NA | No | NR/91,521 Inpatient/hospital, Outpatient: primary care, Outpatient: subspecialty care setting | Age < 35 or > 90 years, no DM, multiple or missing dates of death, missing information, no treatment with medications
Perez, 2009^56^ United States, Multinational Europe | RCT | Neither year reported 24 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | 1436/600 NR | Age <18 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g. “failed initial treatment”), contraindication or history of intolerance to metformin, HbA1c <7.5% or >10%, BMI >45 kg/m^2^, pregnant, nursing, triglyceride level 500, if they were NOT discontinued metformin and TZD therapy due to lack of efficacy
Juurlink, 2009^210^ Canada | Prospective or retrospective cohort | Start year: 2002 End year: 2008 3 years | NA | NA | No | NA/39736 Outpatient: primary care | Age <66 years, patients on rosiglitazone or pioglitazone before the index date, patients on insulin before the index date
Dormuth, 2009^215^ Canada | Prospective or retrospective cohort | Start year: 1998 End year: 2007 11 years | NA | NR | No | 127581/84339 Community | Had received insulin or other ODMs besides metformin, SU or TZD, gestational DM, fractures, admitted to long term facility
Rigby, 2009^130^ United States, Multicontinent | RCT | Start year: 2007 End year: 2008 | NA | < 6 months | Yes | 169/356 NR | Age <18 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c >10% (9.5% if on metformin combination therapy), HbA1c <7% (6.5% if on metformin combination therapy), BMI> 40 kg/m^2^, LDL<50mg/dl or TG ≥500 mg/dL, weight loss program with ongoing weight loss or starting an intensive exercise program within 4 weeks of screening, need for oral corticosteroids, bile acid sequestrants, or any antidiabetes medications other than metformin, >2 months insulin, not on metformin for ≥3 months (1500–2550 mg/day), Type 1 DM and/or ketoacidosis, dysphagia/swallowing disorders, intestinal motility disorders, pancreatitis, HIV/AIDS, drug/alcohol abuse within 2 years, any serious disorder including pulmonary, hepatic, gastrointestinal, uncontrolled endocrine/metabolic, hematologic/oncologic (within 5 years), neurologic, or psychiatric diseases, current treatment with TZD/combo with metformin/colesevelam/fixed-dose combination product including metformin, hospitalization within 14 days of screening
Mancini, 2009^214^ Italy | Cross-sectional study | Neither year reported NR | NA | NA | Yes | 65/65 Outpatient: primary care, Outpatient: subspecialty care setting | History of significant trauma, neoplastic disorder or diseases affecting the bone, prolonged immobilization, use of anti-osteoporotic drug
Tolman, 2009^150^ United States | RCT | Start year: 2000 End year: 2005 3 years | None | < 6 months | Yes | NR/2120 NR | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <7%, BMI <20kg/m^2^ or >48 kg/m^2^, not taking metformin and/or SU, history of ketoacidosis, history of TZD use other than troglitazone before 4/00
Dimic, 2009^199^ Serbia | Non-randomized trial | Neither year reported 12 weeks | None | < 6 months | NR | NR/60 NR | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g. “failed initial treatment”), HbA1c <7.5%, glucocorticoids
Jadzinsky, 2009^78^ Multi-continent | RCT | Start year: 2006 End year: 2007 24 weeks | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | 2936/1394 Outpatient: primary care, Outpatient: subspecialty care setting, Community | Age <18 or >77 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g. “failed initial treatment”), HbA1c< 8% >12%, BMI >40 kg/m^2^, prior treatment, diabetic ketoacidosis or nonketotic hyperosmolar coma, CVD events 6 months prior, LVEF <40%, psychiatric history, alcohol or drug abuse, abnormal metabolic or hematologic test
DeFronzo, 2009^95^ NR | RCT | Neither year reported 24 weeks | Yes | < 6 months | Yes | 1462/743 NR | Age >18 and <77 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g. “failed initial treatment”), contraindication or history of intolerance to metformin, neuropathy, retinopathy, HbA1c < 7% or >10%, BM >40 kg/m^2^, pregnant, nursing, alcohol or drug abuse, NYHA III and IV, LVEF <40
Bunck, 2009^144^ Sweden, Finland, Netherlands | RCT | Start year: 2004 End year: 2007 56 weeks | None | < 6 months | Yes | 150/69 NR | Age <30 and >75 years, HbA1c<6.5% or >9.5%, BMI <25 kg/m^2^ or BMI >40 kg/m^2^, metformin treatment not at a stable dose for at least 2 months, no other blood glucose lowering medications allowed in 3 months prior to study, no changes in other medications known to affect B cell function (ACEI, B Blockers)
Garber, 2009^122^ United States, Mexico | RCT | Start year: 2006 End year: 2007 52 weeks | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | NR/746 NR | Age <18 or >80 years, HbA1c <7% or >11% if prior treatment was diet; >10% if prior treatment was drug, BMI >45 kg/m^2^, either not treated with diet and exercise or up to half the highest dose of ODM monotherapy for at least 2 months prior to trial, insulin treatment during the previous 3 months (except short-term treatment for intercurrent illness), treatment with systemic corticosteroids, hypoglycemia unawareness or recurrent severe hypoglycemia, impaired liver function (aspartate aminotransferase or alanine aminotransferase concentrations 5 times upper normal range)
Derosa, 2009^46^ Italy | RCT | Neither year reported 15 months | Fewer than 10% of participants were excluded during run-in | < 6 months | NR | 271/252 Outpatient: primary care, computerized clinic registry | Age <18 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), neuropathy, retinopathy, HbA1c < 6.5%, BMI <25 kg/m2 or >30 kg/m2, pregnant, nursing, not using adequate contraception, no Type 2 DM, history of ketoacidosis, severe anemia
Williams-Herman, 2009^76^ NR | RCT | Neither year reported 54 weeks | Run-in period but number of participants excluded was NR | NR | Yes | 3544/1091 NR | Age <18 or >78 years, HbA1c ≤7.5% or ≥11% after screening diet/exercise run-in (which included a wash-out period), lack of adequate compliance (≥75% by tablet count) during 2-week single-blind placebo run-in period, no Type 2 DM
Kaku, 2009^84^ Japan | RCT | Start year: 2005 40 weeks | Yes | < 6 months | Yes | NR/236 NR | Age ≤20 or ≥65 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g. failed initial treatment), HbA1c <6.5% or >10%, other pre-existing conditions that potentially require hospitalization such as cancer, severe lung, gastrointestinal, pancreatic and hematological disorders, history of lactic acidosis, ketoacidosis, diabetic coma, or pre coma within the preceding 26 weeks, if on any medications that might affect glycemic control, drug or alcohol dependency
Nauck, 2009^92^ Multi-continent | RCT | Neither year reported 26 weeks | Run-in period but number of participants excluded was NR | >= 6 months | Yes | 1662/1087 NR | Age <18 or >80 years, HbA1c > 11% if on monotherapy; 10% if on combination therapy (both greater than 3 months), HbA1c < 7%, BMI >40 kg/m^2^, used insulin in last 3 months
Raskin, 2009^131^ NR | RCT | Neither year reported 26 weeks | No run-in period | < 6 months | Yes | 1093/383 Outpatient: primary care | Age <18 years, pregnant, nursing, currently not under monotherapy at least 2 months or dual therapy, FBG >260 mg/dL, any disease of abnormality as judged by the investigator, treatment with the investigational drug for 4 weeks, allergy to study drugs or related compounds, history of hypoglycemia unawareness or recurrent severe hyperglycemia
van der Meer, 2009^141^ Netherlands | RCT | Neither year reported 24 weeks | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | 173/80 NR | Age <45 or >65 years, female, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <6.5% or >8.5%, BMI <25 kg/m^2^ or >32 kg/m^2^, SBP <150 mm Hg, DBP <85 mm Hg, prior TZD or insulin use
Scott, 2008^85^ Multi-continent | RCT | Neither year reported 18 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | 486/273 NR | Age <18 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), HbA1c <7% or >11%, not on 10 weeks on stable dose of metformin, insulin use, Type 1 DM, glucose > 270 mg/dL
Raz, 2008^93^ Multicontinent | RCT | Neither year reported 30 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | 544/190 NR | Age <18 or >78 years, HbA1c <8% after run-in, HbA1c >11% after run-in, BMI <20 or >43 kg/m^2^, pregnant, nursing, insulin within 8 weeks prior to screening, PPAR-G or incretin mimetics within 12 weeks prior to screening, Type 1 DM, FPG <7.2 or >15.6 mmol/L consistently during run-in, no Type 2 DM
Hamann, 2008^123^ Multinational Europe, Mexico | RCT | Neither year reported 52 weeks | Yes | < 6 months | NR | 818/596 NR | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <7% or >10%, BMI <25 kg/m^2^, used any ODM other than metformin in the prior 12 weeks, or insulin at any time other than during pregnancy or for emergency treatment, history of metabolic acidosis, edema requiring pharmacological treatment (either ongoing or within the prior 12 months), anemia (hemoglobin < 11.0 g/dl for men and < 10.0 g/dl for women), C-peptide <0.5nmol/L, SBP >170mmHg, DBP >100mmHg
Seufert, 2008^142^ Multicontinent | randomized but does not no control; comparative study | Neither year reported 104 weeks | No run-in period | NR | Yes | NR/1269 NR | Age < 35 or >75 years, history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g. failed initial treatment), HbA1c < 7.5% or > 11%, pregnant, nursing, fasting c-peptide >1.5, ketoacidosis, symptomatic heart failure, acute malabsorption, chronic pancreatitis, familial polyposis coli, malignant disease in the previous 10 years
Schwarz, 2008^152^ US | RCT | Neither year reported 104 weeks | Run-in period but number of participants excluded was NR | < 6 months | NR | 75/69 NR | Age <18 or >77 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), contraindication or history of intolerance to metformin, HbA1c <7.0% or >11.0%, BMI <22 or >45 kg/m^2^, FBG >270 mg/dL, history of lactic acidosis, congestive cardiac failure requiring pharmacologic treatment, Type 1 DM or secondary forms of DM
Asche, 2008^200^ US | Cohort | Start year: 1996 End year: 2005 395 days NA | NA | NA | Yes | 1129573/5438 General Electric Research Database | Age <65 years, took any ODM within 395 days prior to first prescription for monotherapy with metformin, SU, or TZD, less than two HbA1c levels (first recorded within 90 days prior to index date or 30 days post-index date and the second level drawn either (longer of the two) 90 days after index date or baseline A1c), no Type 2 DM (defined by ICD-9, FBG ≥125 mg/dL, on ODM, or prescription for injectable incretic mimetic)
McAlister, 2008^208^ Canada | Cohort | Start year: 1991 End year: 1996 9 years | NA | NA | No | NR/5631 Saskatchewan Health database | Age <30 years, treatment with insulin, did not receive at least one new prescription for an oral antidiabetic medication (metformin or SU) between 01/01/1991 and 12/31/96, not eligible for prescription drug benefits, less than one year of coverage in the provincial health plan, history of heart failure (by ICD-9 for hospitalization for heart failure) in last 3 years prior to starting first ODM, receipt of more than one ODM at any time (concurrently or not)
Kahn, 2008^213^ U.S., Multinational Europe | RCT | Neither year reported 4 years | No run-in period | NR | Yes | 4360/4351 NR | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), history of lactic acidosis, uncontrolled hypertension, corticosteroid use
Davies, 2007^147^ United Kingdom | RCT | Neither year reported 4 months | Run-in period but number of participants excluded was NR | < 6 months | NR | 82/NR NR | Age <30 or >80 years, history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), contraindication or history of intolerance to metformin, HbA1c <7.0%, BMI >43 kg/m^2^, not using adequate contraception, history of previous insulin use for >2weeks, duration of Type 2 DM <12 months, C-peptide levels <0.33, severe concurrent disease, serum creatine >150umol/l
Chien, 2007^59^ Taiwan, Multi-center | RCT | Neither year reported 16 weeks | No run-in period | < 6 months | Yes | 166/100 5 medical centers. Does not specify inpatient or outpatient | Age <30 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), contraindication or history of intolerance to metformin, retinopathy, HbA1c >12% and FPG>250 mg/dL at screening visit, HbA1c <7% and FPG<140 mg/dL at screening visit, BMI <18.5 or >35 kg/m^2^, current significant GI disorder, hyperosmolar nonketotic coma, hypersensitivity to glyburide or metformin, current infection, treatment with insulin in last 6 months, surgery in past 4 weeks, history of cancer in 5 years, on concurrent drugs affect sugar metabolism, FPG < 140 mg/dl at second visit, not on a stable dose of SU at baseline or dose of metformin>1000mg/day or SU dose too low (glyburide or glicazide<10 mg/day, glimepiride<4mg/d, glicazide<160mg/d)
Goldstein, 2007^75^ Multicontinent | RCT | Neither year reported 24 weeks | Run-in period but number of participants excluded was NR | NR | Yes | 3544/1091 NR | Age <18 or >78 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), patient with < 75% compliance during placebo run in period, patient with HbA1c <7.5% or >11 % after diet/exercise run in/wash-out period, patients with fasting glucose > 280 mg/dl after run-in period, no Type 1 DM or Type 2 DM
Hanefeld, 2007^100^ Multinational Europe | RCT | Neither year reported 52 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | NR/598 NR | Age <40 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), BMI <22 kg/m^2^ or >38 kg/m^2^, pregnant, patient on insulin therapy, patient with diabetic complications requiring treatment, hematologic impairment, FPG <7mmol/l or > 15mmol/l, C-peptide <0.27 nmol/l
Scott, 2007^111^ U.S. | RCT | Neither year reported 12 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | 2186/743 NR | Age <21 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), Type 1 DM, gall bladder disease, elevated CK
Comaschi, 2007^129^ Italy | RCT | Neither year reported 6 months | Run-in period but number of participants excluded was NR | < 6 months | Yes | 398/250 NR | Age <35 years, HbA1c <7.5% or >11%, had not received SU or metformin as a monotherapy at a stable dose for at least 3 months, fasting C-peptide <0.33nmol/L
Nauck, 2007^133^ U.S., Multinational Europe, Multi-continent | RCT | Neither year reported 52 weeks | Yes | < 6 months | Yes | 2141/1172 NR | Age <18 or >78 years, any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), FPG >15 mmol/L, insulin use within 8 weeks of screening, history of Type 1 DM, other treatments for hypoglycemia
Robbins, 2007^145^ US, Multinational Europe, Multi-continent, India, Australia | RCT | Neither year reported 24 weeks | Run-in period but number of participants excluded was NR | < 6 months | NR | 433/317 NR | Age <35 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), HbA1c <6.5% or >11%, pregnant, nursing, not using adequate contraception, patients who were receiving continuous SC insulin injections or a total daily insulin of >2.0 U/kg or who had a change in type or dose of lipid-altering medications or TZD use up to 3 months before the study, fasting triglyceride level >4.5 mmol/L, serum creatinine >134 micromol/L (men) or >109 micromol/L (women)
Raskin, 2007^146^ US | RCT | Neither year reported 28 weeks | Run-in period but number of participants excluded was NR | < 6 months | NR | N:/NR NR | Age <18 or >75 years, HbA1c ≤8.0%, BMI >40 kg/m^2^ or weight >125 kg (275 lbs.), pregnant, nursing, not using adequate contraception, if not on metformin ≥1,000mg/day as a single agent or in ODM combination therapy for at least 3 months before the trial, history of insulin use
Lund, 2007^197^ Denmark | RCT | Start year: 2001 End year: 2002 8 months | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | 127/96 Outpatient: subspecialty care setting | Age <40 years for onset of diabetes diagnosis, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c >9.5% with ongoing ODMs prior to study start; 10.5 on 2 visits with >1 month interval, HbA1c <6.5% after run in period, BMI >27 kg/m^2^, pregnant, insulin treated Type 2 DM, secondary DM, Factor II, VII, X <0.7, ongoing co-existing illness with life shortening prognosis, mental retardation or reduced intellectual behavior, history of drug abuse, weight loss of >5 kg in past 6 months prior to study start, fasting C peptide <300 of non fasting glucagon stimulated C peptide <600, ketonuria; ketoacidosis
Kahn, 2006^38^ Multi-continent | RCT | Start year: 2000 End year: 2006 6 years | No run-in period | NR | Yes | 6676/4360 NR | Age < 30 or > 75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), uncontrolled hypertension, fasting plasma glucose <126 or > 180 mg/dL, history of lactic acidosis
Rosenstock, 2006^49^ Multi-continent | RCT | Start year: 2003 to 2004 32 weeks | Yes | < 6 months | Yes | 1252/468 multicenter | Age <18 or >70 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c < 7% or > 11%, FPG >15mmol/l, hematological disease, uncontrolled hypertension while on antihypertensive treatment, intermittent or chronic use of oral or intravenous corticosteroids, investigators discretion, use of investigational agent within 30 days of the study (or five half lives of the investigational drug if longer than 30 days), previous history of severe edema or medically serious fluid related event associated with TZD, acute or chronic metabolic acidosis, history of diabetic ketoacidosis
Charbonnel, 2006^94^ Multi-continent | RCT | Neither year reported 24 weeks | Run-in period but number of participants excluded was NR | NR | Yes | 1464/701 NR | Age < 18 or >78 years, any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), HbA1c <7% or >10%, Type 1 DM, insulin use within 8 weeks of screening, FPG > 14.4mmol/l
Jain, 2006^101^ US, Puerto Rico | RCT | Neither year reported 56 weeks | Run-in period but number of participants excluded was NR | < 6 months | NR | NR/502 NR | Age <18 or >80 years, any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g. failed initial treatment), HbA1c < 7.5% or >11.5%, pregnant, nursing, duration of DM > than 2 years, intolerance to rosiglitazone, pioglitazone or troglitazone, drug or alcohol abuse, previous treatment with meglitinide analog, alpha glucosidase inhibitor, metformin, insulin, SU for 3 months or more, use of hydrochlorothiazide, joint injections, niacin > 250 mg/day, ODM, concurrent participation in another investigational study, serum creatinine level > 1.5mg/dl of men, 1.4 mg/dl for women, 1 + proteinuria, anemia(<10g/dl women, < 12g/dl men, BMI <20 kg/m^2^ or >45 kg/m^2^; hypertension, chronic pulmonary disease, history of cancer not in remission for at least 5 years
Jibran, 2006^112^ Pakistan | Randomized, open-label, 2 arm parallel prospective study | Start year: 2000 End year: 2001 12 months | NA | < 6 months | NR | NR/100 Outpatient: subspecialty care setting | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), poorly controlled on prior treatments (e.g. failed initial treatment), no Type 2 DM, on insulin
Bakris, 2006^125^ U.S., Multi-continent, South America, Europe | RCT | Neither year reported 32 weeks | Yes | < 6 months | Yes | 560/514 NR | Age <40 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), BMI < 22 kg/m^2^, use of any TZD in the 3 months prior to screening, use of insulin for ≥ 6 months at any time prior to screening, anemia, severe angina, SBP >159 mm Hg (can’t adjust the BP meds during the trial), DBP >99 mm Hg
Umpierrez, 2006^126^ U.S. | RCT | Neither year reported 28 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | 538/210 Outpatient: primary care, Outpatient: subspecialty care setting | Age <18 or >79 years, HbA1c <7.5% or >10%, BMI <24 kg/m^2^, diagnosis of Type 2 DM <6 months, no taking stable doses of metformin (1–2.5g/day) or extended-release metformin (0.5 –2.0g/day) as their only ODM for at least 2 months prior to the study, C- peptide <0.27nmol/L, subjects treated with insulin, TZDs or SU within 3 months prior to study enrollment, history of substance abuse, severe hypoglycemia, acute metabolic complications, clinically significant abnormal baseline laboratory values including hematology, blood chemistry or urinalysis
Garber, 2006^128^ U.S. | RCT | 24 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <20 or >78 years, any liver disease, any kidney disease, history of CVD, HbA1c ≤7.0% or ≥12.0%, no Type 2 DM, other
Kvapil, 2006^138^ Multinational Europe | RCT | Neither year reported 16 weeks | No run-in period | < 6 months | NR | NR/341 NR | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), retinopathy, recurrent severe hypoglycemia, anemia, change in dose of meds known to interfere with glucose metabolism, adequately controlled on metformin
Stewart, 2006^156^ Multinational Europe | RCT | Start year: 2003 to 2004 32 weeks | Yes | < 6 months | Yes | 1397/526 NR | Age <18 or >70 years, history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <7% or >9%, drug naive patients with FPG <7 mmol/l or >9mmol/l, patient on monotherapy with FPG < 6.0mmol/l or >8 mmol/l, prior history of exposure to TZDs within previous 6 months, use of insulin anytime in the past, uncontrolled hypertension
Rosak, 2006^183^ Germany | Cohort | Neither year reported 6 months | NA | < 6 months | Yes | NR/22808 Outpatient: primary care, Outpatient: subspecialty care setting | Not all treated with rosiglitazone
Wright, 2006^198^ U.K. | RCT | Start year: 1977 End year: 1991 6 years | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | 7616/4191 23 clinical Center | Age <25 or >65 years, any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), FPG ≤6 mmol/l x2 after being diagnosed with diabetes, ketonuria> 3 mmol/l, mixed ethnicity, severe previous illness that would limit life expectancy or require systemic treatment, serum creatinine>175 umol/l, if on same treatment for <6 years
Hanefeld, 2006^201^ Germany | Cohort | Neither year reported 42 months | NA | >= 6 months | Yes | NR/500 Outpatient: primary care | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), pregnant, known hypersensitivity to pioglitazone, glibenclamide, or their metabolites, ketoacidosis, diabetic coma, pre-coma, Type 1 DM, serious impairment of adrenocortical function
Malone, 2005^165^ Multinational Europe | RCT | Neither year reported 32 weeks | Yes | < 6 months | Yes | 97/119 NR | Age <30 or>75 years, HbA1c >2.0 times the upper limit of normal, HbA1c <1.3 times the upper limit of normal, used glitazones within 30 days prior to the study, used NPH QD or BID 30-days prior to entry, expected to benefit from prandial control
Yamanouchi, 2005^50^ Japan | RCT | 12 months (Planned duration) | Not extracted | Not extracted | No | Not extracted | Any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, retinopathy, HbA1c <7.0%, no Type 2 DM, other
Leiter, 2005^83^ Canada | RCT | Neither year reported 32 weeks | No run-in period | < 6 months | Yes | 720/613 Outpatient: primary care | Age <20 or >80 years, HbA1c < 9.5%, no Type 2 DM, FBG <7 but >14mmol/L
Weissman, 2005^86^ U.S. | RCT | Neither year reported 24 weeks (Planned duration) | Run-in period but number of participants excluded was NR | < 6 months | Yes | 1270/766 NR | Age <18 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c <6.5% or >8.5% for subjects having received prior combination treatment (metformin + SU), HbA1c < 7% or > 10% for drug naive or prior monotherapy subjects, BMI <27 kg/m2, FPG < 126mg/dL or >270mg/dL, anemia, severe edema, prior insulin use within 3 months of study start, non-compliant patient with metformin up-titration
Bailey, 2005^87^ U.K., 14 European Countries | RCT | 24 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <18 or >70 years, history of CVD, no Type 2 DM, other
Feinglos, 2005^91^ U.S. | RCT | 16 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <30 or >81 years, any liver disease, any kidney disease, history of CVD, HbA1c <7.0% or >8.5%, no Type 2 DM, other
Derosa, 2005^127^ Italy | RCT | Neither year reported 12 months | No run-in period | < 6 months | NR | NR/99 case notes and/or clinic registers | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g., failed initial treatment), neuropathy, retinopathy, HbA1c < 7%, pregnant, nursing, not using adequate contraception, no type 2 DM by ADA criteria for at least 6 mo, fasting c-peptide <1.0ng/ml, no metabolic syndrome with at least 3 components (based on NCEP ATP III), ketoacidosis, anemia, cerebrovascular conditions within 6 months, consumption of glimepiride or TZDs or prior intolerance to these medications
Gerich, 2005^136^ US | RCT | Neither year reported 2 years | Fewer than 10% of participants were excluded during run-in | < 6 months | Yes | 908/428 NR | Age <18 or >77 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), neuropathy, retinopathy, HbA1c <7% or >11%, BMI < 22 kg/m2 or >45 kg/m2, not using adequate contraception, FPG ≥15mmol/L, if Type 1 DM, symptomatic hypoglycemia with >10% weight loss in previous 8 weeks, history of lactic acidosis or CHF requiring meds, other medical conditions that could interfere with interpretation of results or pose sign risk to the subject, had to be drug naive
Derosa, 2005^159^ Italy | RCT | 12 months (planned duration) | Not extracted | Not extracted | No | Not extracted | Age <18 years, any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c <7.5%, no Type 2 DM, other
Agarwal, 2005^184^ US | RCT | Start year: 2001 End year: 2003 16 weeks | No run-in period | < 6 months | Yes | 102/54 Outpatient: subspecialty care setting | Any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), BMI >40 kg/m^2^ <7.5 kg/m^2^, class III or IV heart failure, NSAID use
Rajagopalan, 2005^194^ US | Cohort | | Not extracted | Not extracted | Yes | Not extracted | Age <18 years, any liver disease, no Type 2 DM, other
Maru, 2005^195^ UK | Cohort | 130 (mean followup) | Not extracted | Not extracted | Yes | Not extracted | Age <35, treatment experienced, no Type 2 DM, other
Nichols, 2005^196^ US | Cohort | | Not extracted | Not extracted | Yes | Not extracted | Other
Rajagopalan, 2005^206^ US | Cohort | Start year: 1999 End year: 2001 Duration: NA | NA | NA | Yes | NA (for cohort studies, claims data, etc)/1123645 pharmacy database | Age <18 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), use of troglitazone, in cohort <12 months prior to study, follow up <3 months after study started, prior treated with rosiglitazone, metformin, pioglitazone, or SU, not continuously having insurance or medication coverage
Karter, 2005^207^ US | Cohort | Start year: 1999 End year: 2001 10 months | NA | NA | No | NA (for cohort studies, claims data, etc)/23440 managed care organization | CHF, no pharmacy benefit, Type 1 DM, >80% pill adherence, filled a refill of index medication, member of health plan >1 year, any utilization of the index therapy in the 12 months prior to initiation of the study
Madsbad, 2004^120^ Multinational Europe | RCT | Start year: 2000 End year: 2001 12 weeks | No run-in period | < 6 months | Yes | 311/193 Outpatient: primary care, Outpatient: subspecialty care setting, Community | Age <30 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), poorly controlled on prior treatments (e.g., “failed initial treatment”), HbA1c < 7.5% or >10% on diet treatment, BMI >40 kg/m^2^, pregnant, nursing, not using adequate contraception, no Type 2 DM, no treatment for DM with ODM or diet, HbA1c >9.5% on ODM, history of CHF, NYHA class III, IV, use of TZDs or other investigational drugs
Schernthaner, 2004^52^ Europe | RCT | 12 months (planned duration) | Not extracted | Not extracted | No | Not extracted | Age <35 or >75 years, treatment experienced, HbA1c <7.5% or >11%, no Type 2 DM
Derosa, 2004^60^ Italy | RCT | 12 months (planned duration) | Not extracted | Not extracted | No | Not extracted | Age <46 or >67 years, any liver disease, any kidney disease, history of CVD, treatment experienced, no Type 2 DM, other
Horton, 2004^80^ NR | RCT | Neither year reported 24 weeks | Yes | < 6 months | Yes | 701/401 NR | Age >30 years, any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), neuropathy, retinopathy, HbA1c < 6.8% or >11%, Type 1 or 2 DM, diabetes> 3 months duration, FPG <15mmol/L, diabetic complication, on corticosteroids, non treatment naive
Tan, 2004^106^ Denmark, Finland, Norway, and Sweden. | RCT | 52 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Treatment experienced, HbA1c <7.5% or >11% for patients not receiving ODM, <7.5% or > 9.5% for patients receiving ODM, no Type 2 DM, other
Raskin, 2004^109^ U.S. | RCT | 12 titration and 12 maintenance weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <18 years, HbA1c <7% or >12% during previous monotherapy with SU or metformin at 50% or more of maximal recommended dose for at least 3 months, no Type 2 DM, other
Jovanovic, 2004^110^ U.S. | RCT | 12 week titration then 12 week maintenance (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <18 years, HbA1c <7% or >12%, no Type 2 DM, other
Hanefeld, 2004^140^ Canada, U.K., Hungary, Finland, U.K., Slovak Republic, Belgium, Estonia, Lithuania, Denmark, Italy, Greece, Sweden, and the Netherlands | RCT | NR | Not extracted | Not extracted | Yes | Not extracted | Age <35 or >75 years, history of CVD, HbA1c <7.5% or >11%, no Type 2 DM, other
Malone, 2004^164^ US | RCT | Neither year reported 32 weeks | Yes | < 6 months | Yes | 145/111 NR | Age <30 OR >80 years, HbA1c <1.3 or >2.0 times normal, BMI >40 kg/m^2^, HbA1c value that is less than or greater than 1.3 and 2.0 times the ULN within 30 days before the study, while using 1 or more ODM without insulin for 30 or more days before study start
Hussein, 2004^202^ Australia | Cohort | Start year: 2000 End year: 2002 30 months | NA | NA | No | 2500/203 Outpatient: subspecialty care setting | HbA1c < 8%, treated at Melbourne Hospital, treated with rosiglitazone or pioglitazone >2 months
Tosi, 2003^36^ Italy | RCT, cross-over | 6 months (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <6.3%, no Type 2 DM, other
Pavo, 2003^54^ Russia and Hungary | RCT | 32 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <40 years, any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <7.5% or >11.0%, no Type 2 DM, other
Garber, 2003^61^ US | RCT | 16 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | NR
Goldstein, 2003^62^ US | RCT | 18 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, history of CVD, HbA1c <7.5 and >12.0, other
Derosa, 2003^81^ Italy | RCT | 12 months (planned duration) | Not extracted | Not extracted | No | Not extracted | Any kidney disease, history of CVD, treatment experienced, HbA1c < 7%, no Type 2 DM, other
Yang, 2003^139^ China | RCT | Neither year reported 12 weeks | Run-in period but number of participants excluded was NR | < 6 months | Yes | NR/211 NR | Age <35 or >70 years, poorly controlled on prior treatments (e.g. failed initial treatment), no Type 2 DM as defined by WHO, not treated with diet and sulfonylurea for 6-months
Malone, 2003^137^ 14 countries not specified | randomized, open-label, 2 arm parallel prospective study | Neither year reported 16 weeks | Fewer than 10% of participants were excluded during run- in | < 6 months | Yes | NR/597 subgroup completing test meals | Age < 30 or >75 years, HbA1c <125% of upper limit of normal by local lab within 4 weeks prior to entry, BMI >40 kg/m^2^, not Type 2 DM, not use of single oral agent (metformin or SU) for 3 months prior to study at max clinically effective dose for previous 30 days
Jones, 2003^179^ US | RCT | Neither year reported 6 months | Run-in period but number of participants excluded was NR | < 6 months | NR | NR/N: NR | Age <40 or >80 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), neuropathy, CHF, history of chronic insulin, FPG <140 or >300 mg/dL, prior rosiglitazone study, use on any investigational drug within 30 days
Blonde, 2002^63^ US | RCT | 16 weeks (planned duration) | Not extracted | Not extracted | Yes | | Age <30 or >75 years, any liver disease, any kidney disease, history of CVD, HbA1c <7.4%, no Type 2 DM, other
Marre, 2002^64^ Netherlands, Denmark, Portugal, France, Belgium | RCT | 4 months (planned duration) | Not extracted | Not extracted | Yes | | Age <18 years, any liver disease, any kidney disease, history of CVD, other
Garber, 2002^65^ US | RCT | 20 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, treatment experienced, HbA1c <7% or >11%, no Type 2 DM, other
Gomez-Perez, 2002^88^ Mexico | RCT | 26 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <40 or >80 years, any liver disease, any kidney disease, history of CVD, treatment experienced, no Type 2 DM, other
Marre, 2002^96^ Multi-continent | RCT | Neither year reported 24 weeks | Yes | < 6 months | Yes | 680/467 NR | Age < 30 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g. myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), HbA1c < 6.8% or >11%, BMI <20 kg/m2 or >35 kg/m2, DM at least 6 months, FPG>15mmol/l, gastroparesis, change in body weight during run-in, treated with diabetes meds other than metformin 3 months before study
Vakkilainen, 2002^119^ Finland | RCT | 12 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <18 or >75 years, any liver disease, any kidney disease, HbA1c <6.5% or >10%, no Type 2 DM, other
St John Sutton, 2002^149^ US | RCT | 52 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <40 or >80 years, any liver disease, any kidney disease, history of CVD, no type 2 DM, other
Charpentier, 2001^71^ France | RCT | 20 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age ≤ 34 or ≥ 71 years, any kidney disease, history of CVD, no Type 2 DM, other
Madsbad, 2001^114^ Denmark, Scandinavia | RCT | 12 months (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age ≤ 39 or ≥ 76 years, any liver disease, any kidney disease, HbA1c <6.5% or >10%, no Type 2 DM, other
Amador-Licona, 2000^66^ Mexico | RCT | 12 weeks (planned duration) | Not extracted | Not extracted | No | Not extracted | Age >65 years, any liver disease, history of CVD, other
Horton, 2000^79^ US | RCT | 24 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age <30 years, any kidney disease, HbA1c <6.8% or >11%, no Type 2 DM, other
Einhorn, 2000^89^ US | RCT | 16 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c <8.0%, no Type 2 DM, other
Fonseca, 2000^90^ US | RCT | 26 weeks (planned duration) | Not extracted | Not extracted | No | Not extracted | Age <40 or >80 years, any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, no type 2 DM, other
Moses, 1999^82^ Australia | RCT | Neither year reported 4 to 5 months | No run-in period | NR | NR | 108/83 NR | Age <40 or >75 years, any liver disease (such as elevated aminotransferases (ALT, AST, SGOT, SGPT)), any kidney disease (such as microalbuminuria, macroalbuminuria or elevated creatinine, low GFR or creatinine clearance), history of cardiovascular disease (e.g., myocardial infarction, stroke, transient ischemic attack, coronary artery disease, angina), contraindication or history of intolerance to metformin, HbA1c < 7.1%, BMI <21 kg/m^2^, no Type 2 DM, not on metformin for more than 6 months, alcohol abuse, drug use, intention to become pregnant, history of lactic acidosis, vitamin B12 <150 pmol/l with anemia
Landgraf, 1999^115^ Germany, Austria, and Netherlands | RCT | 14 weeks (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, history of CVD, treatment experienced, no Type 2 DM, other
Wolffenbuttel, 1999^116^ Germany, Austria, Netherlands | RCT | 12 months (planned duration) | Not extracted | Not extracted | No | Not extracted | Age <40 or >75 years, any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <6.5% if treated with diet only, >12% if treated with diet plus oral, other
Marbury, 1999^117^ US, Canada | RCT | 12 months (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Age >37 or <75 years, any liver disease, any kidney disease, history of CVD, treatment experienced, retinopathy, HbA1c <6.5% or 14.6%, no Type 2 DM, other
DeFronzo, 1995^70^ +US | RCT | 29 weeks (planned duration) | Not extracted | Not extracted | No | Not extracted | Age <40 or >70 years, any liver disease, any kidney disease, history of CVD, treatment experienced, no Type 2 DM, other
Hermann, 1994^68^ Sweden | RCT | 6 months (planned duration) | Not extracted | Not extracted | Yes | Not extracted | No Type 2 DM, other
Wolffenbuttel, 1993^118^ Netherlands | RCT | 12 (4 week titration, 8 week treatment) (planned duration) | Not extracted | Not extracted | Yes | Not extracted | Any liver disease, any kidney disease, HbA1c <7.0% or >12.0%, no Type 2 DM, other

ACEI = angiotensin-converting enzyme inhibitors; ALT = alanine aminotransferase; AST = asparate aminotransferase; BID = twice a day; BMI = body mass index; CAD = coronary artery disease; CHF = congestive heart failure; CK = creatine kinase; CVD = cardiovascular diseases; DBP = diastolic blood pressure; DKA = diabetic ketoacidosis; DM = diabetes mellitus; FBG = fasting blood glucose; FPG = fasting plasma glucose; GFR = glomerular filtration rate; GI = gastrointestinal; HbA1c = hemoglobin A1c; HONK = hyper osmolar non ketotic; HTN = hypertension; ICD = International classification disease;kg/m2 = kilograms per meters squared; LDL = low density lipoprotein; LVEF = left ventricular ejection fraction; mg/d = milligrams per day; mg/dl = milligrams/deciliter; MHS = Military health system; mmHg = millimeters of mercury; mmol = millimoles; mmol/L = millimoles per liter; NA = not applicable; NPH = neutral protamine Hagedorn; NR = not reported; NSAID = nonsteroidal antiinflammatory drug; NYHA = New York Health Association; OAD = oral antidiabetic; OAM = oral antihyperglycemic medications; PPAR-G = peroxisome proliferator-activated receptors-gamma; PPG = postprandial glucose; QD = once a day; RCT = randomized controlled trial; SBP = systolic blood pressure; SC = subcutaneous; SGOT = serum glutamyl oxaloacetic transaminase; SGPT = serum glutamyl pyruvic transaminase; SU = sulfonylurea; TG = triglycerides; TZD = thiazolidinedione; U/kg = unit per kilogram; y = years

Table 11 Population characteristics of the studies reporting on the comparative effectiveness of diabetes medications on adverse events (KQ3)

Author, year | Group, N | Mean age (age range), | Male, % | Race, % | Mean BMI in kg/m^2^ Mean weight in kg | Mean HbA1c in % | Mean duration of diabetes in years | N of withdrawals
Seino, 2010^121^ | Glibenclamide, 132 | 58.5 | 65 | Asian: 100 | 24.4 NR | 8.978 | 8.5 | 12
Seino, 2010^121^ | Liraglutide, 268 | 58.2 | 68 | NR | 24.5 NR | 8.92 | 8.1 | 22
Derosa, 2010^44^ | Metformin + glibenclamide, 65 | 56 | 51 | NR | 28.5 NR | 8.9 | NR | 8
Derosa, 2010^44^ | Metformin + exenatide, 63 | 57 | 48 | NR | 28.7 NR | 8.8 | NR | 4
Defronzo, 2010^132^ | Metformin + rosiglitazone, 45 | NR | NR | NR | NR NR | 7.9 | NR | 11
Defronzo, 2010^132^ | Metformin + exenatide, 45 | NR | NR | NR | NR NR | 7.8 | NR | 12
Aschner, 2010^77^ | Metformin, 439 | 55.7 | 44 | NR | 30.9 NR | 7.2 | 2.1 | 75
Aschner, 2010^77^ | Sitagliptin, 455 | 56.3 | 48 | NR | 30.7 NR | 7.2 | 2.6 | 61
Seck, 2010^134^ | Metformin + sitagliptin, 248 | 57.6 | 57.3 | AA: 3.6, Asian: 9.3, C: 77.4, H: 5.6, Other: 4 | 30.9 88.5 kg | 7.3 | 5.8 | 231
Seck, 2010^134^ | Metformin + glipizide, 584 | 57 | 62.9 | AA: 5.1, Asian: 8.2, C: 78.5, H: 5.1, other: 3.1 | 31.3 90.3 kg | 7.3 | 5.7 | 328
Komajda, 2010^292^ | Metformin + rosiglitazone, 2220 | NR | NR | NR | NR NR | NR | NR | NR
Komajda, 2010^292^ | Metformin + sulfonylurea, 2227 | NR | NR | NR | NR NR | NR | NR | NR
Pratley, 2010^143^ | Metformin + sitagliptin, 219 | 55 | 55 | AA: 5, Asian: 1, C: 91, H: 16, Other: 4 | 32.6 93.1 kg | 8.5 | 6.3 | 25
Pratley, 2010^143^ | Metformin + liraglutide, 221 | 55.9 | 52 | AA: 10, Asian: 3, C: 82, H: 17, Other: 5 | 32.6 93.7 kg | 8.4 | 6 | 27
Pratley, 2010^143^ | Metformin + liraglutide, 221 | 55 | 52 | AA: 7, Asian: 2, C: 87, H: 15, Other: 4 | 33.1 94.6 kg | 8.4 | 6.4 | 52
Raskin, 2009^131^ | Metformin + repaglinide, 187 | 54.8 | 58 | AA: 16, Asian: 4, C: 75, American Indian/Alaska Native: 1, Other: 4 | 32.9 NR | 8.45 | 7.4 | 62
Raskin, 2009^131^ | Metformin + repaglinide, 187 | 54.5 | 59 | AA: 13, Asian: 5, C: 80, American Indian/Alaska Native: 1, Other: 2 | 32.5 NR | 8.29 | 7.3 | 58
Raskin, 2009^131^ | Metformin + rosiglitazone, 187 | 55.5 (28 to 83) | 51 | AA: 13, Asian: 2, C: 79, American Indian/Alaska Native: 1, Other: 4 | 32.2 NR | 8.46 | 7.1 | 58
Derosa, 2009^46^ | Metformin, 67 | 55 | 51 | C: 100 | 27.2 77.7 kg | 9.1 | NR | 7
Derosa, 2009^46^ | Metformin + glimepiride, 66 | 57.7 | 48 | C: 100 | 27.1 77.4 kg | 9 | NR | 6
Derosa, 2009^46^ | Metformin + pioglitazone, 69 | 57 | 49 | C: 100 | 27.4 76.4 | 9.3 | NR | 9
Derosa, 2009^46^ | Pioglitazone, 69 | 54 | 46 | C: 100 | 27.5 76.7 kg | 9.2 | NR | 9
van der Meer, 2009^141^ | Metformin + glimepiride, 39 | 56.4 | 100 | NR | 29.3 NR | 7 | 3 | 2
van der Meer, 2009^141^ | Pioglitazone + glimepiride, 39 | 56.8 | 100 | NR | 28.2 NR | 7.1 | 4 | 5
Kaku, 2009^84^ | Metformin, 86 | 53 | 57 | NR | 25.4 NR | 7.55 | 5.6 | 7
Kaku, 2009^84^ | Metformin + pioglitazone, 83 | 52 | 66 | NR | 25.6 NR | 7.58 | 4.5 | 9
Williams-Herman, 2009^76^ | Metformin, 182 | 54.2 | 45 | NR | 32 NR | 8.5 | 4.1 | 46
Williams-Herman, 2009^76^ | Metformin, 182 | 53.7 | 48 | NR | 32 NR | 8.7 | 4.1 | 56
Williams-Herman, 2009^76^ | Metformin + sitagliptin, 182 | 53.6 | 41 | NR | 32 NR | 8.7 | 4.6 | 41
Williams-Herman, 2009^76^ | Metformin + sitagliptin, 190 | 53.7 | 53 | NR | 32 NR | 8.8 | 4.1 | 42
Williams-Herman, 2009^76^ | Sitagliptin, 179 | 53.5 | 52 | NR | 31 NR | 8.7 | 3.9 | 57
Pantalone, 2009^174^ | Rosiglitazone, 1079 | 61.4 | 45.5 | C: 86.8, Non- Caucasian: 13.2 | 32.7 NR | 7.3 | NR | NR
Pantalone, 2009^174^ | Any in the SU class, 7427 | 66.1 | 49.5 | C: 78, Non- Caucasian: 22 | 31.1 NR | 7.6 | NR | NR
Pantalone, 2009^174^ | Pioglitazone, 1508 | 61.6 | 48.3 | C: 83.5, Non- Caucasian: 16.5 | 33 NR | 7.3 | NR | NR
Pantalone, 2009^174^ | Metformin, 10436 | 56.8 | 41.8 | C: 76.9, Non- Caucasian: 23.1 | 33.8 NR | 7.7 | NR | NR
Nauck, 2009^92^ | Metformin, 122 | 56 | 60 | AA: 3, Asian: 7, C: 88, other: 3 | 31.6 NR | 8.4 | 8 | 48
Nauck, 2009^92^ | Metformin + glimepiride, 244 | 57 | 57 | AA: 2, Asian: 9, C: 89, other: 1 | 31.2 NR | 8.4 | 8 | 34
Nauck, 2009^92^ | Metformin + liraglutide, 242 | 57 | 59 | AA: 2, Asian: 7, C: 88, Other: 2 | 30.9 NR | 8.4 | 8 | 51
Nauck, 2009^92^ | Metformin + liraglutide, 241 | 57 | 54 | AA: 4, Asian: 8, C: 88, Other:1 | 31.1 NR | 8.3 | 7 | 44
Hsiao, 2009^173^ | Metformin, 46444 | 59 | 48.22 | NR | NR NR | NR | NR | NR
Hsiao, 2009^173^ | Rosiglitazone, 2093 | 61.24 | 53.46 | NR | NR NR | NR | NR | NR
Hsiao, 2009^173^ | Pioglitazone, 495 | 60.75 | 52.02 | NR | NR NR | NR | NR | NR
Hsiao, 2009^173^ | Any in the SU class, 97651 | 60.71 | 54.1 | NR | NR NR | NR | NR | NR
Hsiao, 2009^173^ | Metformin + sulfonylurea, 267754 | 57.17 | 54.45 | NR | NR NR | NR | NR | NR
Hsiao, 2009^173^ | Metformin + rosiglitazone, 2408 | 57.3 | 49.8 | NR | NR NR | NR | NR | NR
Currie, 2009^212^ | Metformin + sulfonylurea, 13882 | 64.4 | 57.9 | NR | NR 90.9 kg for men 79.7 kg for women | 8.6 | 4.4 | NA
Currie, 2009^212^ | Metformin, 31421 | 58.6 | 51.1 | NR | NR 95.9 kg for men 86.2 kg for women | 8.4 | 1.5 | NA
Currie, 2009^212^ | Any in the SU class, 7439 | 70 | 54.9 | NR | NR 80.4 kg for men 68 kg for women | 8.4 | 1.9 | NA
Tzoulaki, 2009^171^ | Metformin, 68181 | 66.3 | 50.6 | NR | 31.47 NR | 8.13 | 5.59 | NR
Tzoulaki, 2009^171^ | Rosiglitazone, 8442 | 65.7 | 50.5 | NR | 31.7 NR | 8.4 | 6.7 | NR
Tzoulaki, 2009^171^ | Any in the SU class, 58095 | 70.4 | 52.6 | NR | 28.5 NR | 8.2 | 6.6 | NR
Perez, 2009^56^ | Metformin, 210 | 53.7 | 46.7 | AA: 6.7, Asian: 2.4, C: 88.1, H: 26.2 | 30.8 NR | 8.65 | NR | 68
Perez, 2009^56^ | Metformin + pioglitazone, 201 | 54.7 | 44.8 | AA: 6, Asian: 1.5, C: 91.5, H: 24.4 | 30.8 NR | 8.89 | NR | 44
Perez, 2009^56^ | Pioglitazone, 189 | 54 | 34.9 | AA: 6.9, Asian: 2.6, C: 87.3, H: 25.9 | 31.2 NR | 8.69 | NR | 64
Rigby, 2009^130^ | Metformin + rosiglitazone, 56 | 54.7 | 41 | AA: 3.6, Asian: 0, C: 28.6, H: 67.9, other: 0 | NR 81.1 kg | 8.06 | 7.57 | 5
Rigby, 2009^130^ | Metformin + sitagliptin, 56 | 54.8 | 35.7 | AA: 1.8, Asian: 0, C: 23.2, H: 73.2, unspecified: 1.8 | NR 79.6 kg | 8.17 | 8.35 | 11
Juurlink, 2009^210^ | Rosiglitazone, 22785 | NR | 53.1 | NR | NR NR | NR | (<2 years: 6%, 2–5 years: 11%, >5 years: 83%) | NR
Juurlink, 2009^210^ | Pioglitazone, 16951 | NR | 52.1 | NR | NR NR | NR | (<2 years: 7%, 2–5 years: 11%, >5 years: 82%) | NR
Dormuth, 2009^215^ | TZD, 10476 | 56 | 48 | NR NR | NR NR | NR | 4.6 | NR
Dormuth, 2009^215^ | Rosiglitazone, 6880 | 56 | 48 | NR NR | NR NR | NR | 4.6 | NR
Dormuth, 2009^215^ | Pioglitazone, 3596 | 57 | 48 | NR NR | NR NR | NR | 4.7 | NR
Dormuth, 2009^215^ | Any in the SU class, 73863 | 60 | 47 | NR NR | NR NR | NR | 4 | NR
Mancini, 2009^214^ | Metformin, 22 | Median: 73 (61–78) | 100 | NR | Median: 30 (Range: 25–38) NR | Median: 7.2 (Range: 6.0–9.3) | Median: 15 (Range: 4–30) | NA
Mancini, 2009^214^ | Metformin + rosiglitazone, 21 | Median: 69 (47–77) | 100 | NR | Median: 34 (Range: 27–40) NR | Median: 7.4 (Range: 5.8–10) | Median: 14 (Range: 5–30) | NA
Tolman, 2009^150^ | Pioglitazone, 1063 | 54 (20–82) | 57.2 | AA: 14.5, Asian: 3.4, C: 59.8, H: 19.1 | 32.5 NR | 9.5 | 5.86 | 649
Tolman, 2009^150^ | Glibenclamide, 1057 | 55 (19–81) | 55.5 | AA: 13.2, Asian: 2.5, C: 62.1, H: 18.7 | 32.5 NR | 9.5 | 5.61 | 641
Dimic, 2009^199^ | Metformin + glimepiride, 30 | 59 | 47 | NR | 29.21 NR | 8.63 | 3.21 | 0
Dimic, 2009^199^ | Metformin + repaglinide, 30 | 57 | 43 | NR | 29.63 NR | 8.67 | 3.63 | 0
Jadzinsky, 2009^78^ | Metformin + saxagliptin, 320 | 52.4 | 51.6 | AA: 2.2, Asian: 15.9, C: 76.9, other: 5 | 29.9 NR | 9.4 | 2 | 58
Jadzinsky, 2009^78^ | Metformin + saxagliptin, 323 | 52.1 | 45.2 | AA: 2.2, Asian: 16.7, C: 75.2, other: 5.9 | 30.3 NR | 9.5 | 1.4 | 62
Jadzinsky, 2009^78^ | Metformin, 328 | 51.8 | 49.7 | AA: 1.2, Asian: 15.9, C: 76.5, other: 6.4 | 30.2 NR | 9.4 | 1.7 | 85
Jadzinsky, 2009^78^ | Saxagliptin, 335 | 52 | 50.4 | AA: 1.8, Asian: 16.7, C: 76.1, other: 5.4 | 30.2 NR | 9.6 | 1.7 | 110
DeFronzo, 2009^95^ | Metformin + saxagliptin, 192 | 54.7 | 43.2 | AA: 3.9, Asian: 4.2, C: 79.7, other: 12 | 31.7 86 kg | 8.1 | 6.7 | 44
DeFronzo, 2009^95^ | Metformin + saxagliptin, 191 | 54.7 | 53.9 | AA: 5.8, Asian: 1.6, C: 83.2, other: 9.4 | 31.2 87.3 kg | 8.1 | 6.4 | 48
DeFronzo, 2009^95^ | Metformin + saxagliptin, 181 | 54.2 | 52.5 | AA: 7.7, Asian: 2.8, C: 79.6, other: 9.9 | 31.1 87.8 kg | 8.0 | 6.3 | 41
DeFronzo, 2009^95^ | Metformin, 179 | 54.8 | 53.6 | AA: 3.9, Asian: 2.2, C: 83.8, other: 10.1 | 31.6 87.1 kg | 8.1 | 6.7 | 40
Bunck, 2009^144^ | Metformin + exenatide, 36 | 58.4 | 63.9 | NR | 30.9 90.6 kg | 7.6 | 5.7 | 6
Bunck, 2009^144^ | Metformin + glargine, 33 | 58.3 | 66.7 | NR | 30.1 92.4 kg | 7.4 | 4 | 3
Garber, 2009^122^ | Glimepiride, 248 | 53.4 | 54 | AA: 12, Asian: 4, C: 77, H: 38, other: 7 | 33.2 93.4 kg | 8.4 | 5.6 | 96
Garber, 2009^122^ | Liraglutide, 247 | 52 | 49 | AA: 12, Asian: 6, C: 75, H: 35, other: 7 | 32.8 92.8 kg | 8.3 | 5.3 | 74
Garber, 2009^122^ | Liraglutide, 251 | 53.7 | 47 | AA: 14, Asian: 2, C: 80, H: 32, Other: 5 | 33.2 92.5 kg | 8.3 | 5.2 | NR
Asche, 2008^200^ | Any in the sulfonylurea class, 2117 | NR | NR | NR | NR NR | NR | NR | NA
Asche, 2008^200^ | Metformin, 2138 | NR | NR | NR | NR NR | NR | NR | NA
Asche, 2008^200^ | Thiazolidinedione, 702 | NR | NR | NR | NR NR | NR | NR | NA
McAlister, 2008^208^ | Any in the sulfonylurea class, 4162 | 66.59 | 58.1 | NR | NR NR | NR | NR | 0
McAlister, 2008^208^ | Metformin, 1469 | 63.37 | 53.8 | NR | NR NR | NR | NR | 0
Kahn, 2008^213^ | Glyburide, 1441 | NR | 58 | NR | NR NR | NR | NR | 0
Kahn, 2008^213^ | Metformin, 1454 | NR | 59.4 | NR | NR NR | NR | NR | 0
Kahn, 2008^213^ | Rosiglitazone, 1456 | NR | 56 | NR | NR NR | NR | NR | 0
Scott, 2008^85^ | Metformin, 92 | 55.3 | 59 | Asian: 39, C: 61 | 30 84.6 kg | 7.7 | 5.4 | 9
Scott, 2008^85^ | Metformin + rosiglitazone, 87 | 54.8 | 63 | Asian: 38, C: 59, Other: 3 | 30.4 84.9 kg | 7.7 | 4.6 | 2
Scott, 2008^85^ | Metformin + sitagliptin, 94 | 55.2 | 55 | Asian: 38, C: 61, Other: 1 | 30.3 83.1 | 7.8 | 4.9 | 9
Raz, 2008^93^ | Metformin, 94 | 56.1 (36 to 77) | 41 | AA: 1, C: 47, H: 25, multiracial: 25, not specified: 2 | 30.4 81.2 kg | 9.1 | 7.3 | 16
Raz, 2008^93^ | Metformin + sitagliptin, 96 | 53.6 (29 to 73) | 51 | AA: 3, C: 42, H: 32, multiracial: 22, not specified: 1 | 30.1 81.5 kg | 9.3 | 8.4 | 18
Seufert, 2008^142^ | Metformin + sulfonylurea, 320 | 60 | 54.7 | NR | 30 NR | 8.8 | 7.1 | 58
Seufert, 2008^142^ | Pioglitazone + sulfonylurea, 319 | 60 | 53.6 | NR | 30.2 NR | 8.81 | 7 | 38
Robbins, 2007^145^ | Metformin + glargine, 159 | 58.1 | 49.4 | AA: 5.7, Asian: 14.6, C: 63.3, H: 16.4 | 32 88.1kg | 7.8 | 12.5 | 22
Robbins, 2007^145^ | Metformin + insulin lispro 50/50, 158 | 57.4 | 50.3 | AA: 5.7, Asian: 14, C: 65, H: 15.3 | 32.1 89.1kg | 7.8 | 11.3 | 15
Hamann, 2008^123^ | Metformin + rosiglitazone, 294 | 58.5 | 53 | C: 94 | 33 91.4kg | 8 | 6.3 | 61
Hamann, 2008^123^ | Metformin + sulfonylurea, 302 | 59.3 | 52 | C: 95 | 32.2 88.9kg | 8 | 6.4 | 71
Chien, 2007^59^ | Glyburide, 25 | 63 | 53 | NR | 25.3 63.7 kg | 8.69 | 8.6 | 6
Chien, 2007^59^ | Metformin, 25 | 59 | 41 | NR | 25.7 65.6 kg | 8.88 | 6.4 | 8
Chien, 2007^59^ | Metformin + glyburide, 26 | 60 | 71 | NR | 24.2 63.8 kg | 8.71 | 9 | 5
Chien, 2007^59^ | Metformin + glyburide, 26 | 57 | 62 | NR | 24.2 61.3 kg | 8.85 | 6.6 | 5
Schwarz, 2008^152^ | Metformin + glyburide, 40 | 70.4 | 50 | AA: 11.1, C: 77.8, Other: 11 | 33.5 NR | 7.7 | 2.5 | 18
Schwarz, 2008^152^ | Metformin + nateglinide, 35 | 70.1 | 51.5 | AA: 9.1, C: 78.8, Other: 12.1 | 30.4 NR | 7.8 | 1.7 | 14
Comaschi, 2007^129^ | Metformin + pioglitazone, 103 | 57 | 45.63 | NR | 32.2 85.8 kg | 8.4 | NR | 27
Comaschi, 2007^129^ | Metformin + sulfonylurea, 80 | 59.9 | 55 | NR | 29.9 81.9 kg | 8.6 | NR | 13
Comaschi, 2007^129^ | Pioglitazone + sulfonylurea, 67 | 62.2 | 56.72 | NR | 28.9 78.8 kg | 8.7 | NR | 14
Goldstein, 2007^75^ | Metformin, 182 | 53.4 | 48.9 | AA: 6.6, Asian: 7.7, C: 47.8, H: 30.2, not specified: 7.7 | 32.1 NR | 8.9 | 4.5 | 29
Goldstein, 2007^75^ | Metformin, 182 | 53.2 | 45.1 | AA: 4.9, Asian: 5.5, C: 58.2, H: 21.4, not specified: 9.9 | 32.2 NR | 8.7 | 4.4NR | 182
Goldstein, 2007^75^ | Metformin + sitagliptin, 182 | 53.3 | 42.3 | AA: 7.7, Asian: 6, C: 52.2, H: 26.9, not specified: 7.1 | 32.4 NR | 8.7 | 4.4 | 18
Goldstein, 2007^75^ | Metformin + sitagliptin, 190 | 54.1 | 55.3 | AA: 6.8, Asian: 4.7, C: 53.7, H: 28.9, not specified: 5.8 | 32.1 NR | 8.8 | 4.5 | 26
Goldstein, 2007^75^ | Sitagliptin, 179 | 53.3 | 52 | AA: 6.1, Asian: 3.4, C: 52, H: 29.1, not specified: 9.5 | 31.2 NR | 8.9 | 4.4 | 37
Davies, 2007^147^ | Metformin + NPH, 29 | 57.9 | 48.28 | AA: 0, Asian: 21, C: 66 | 32.6 90.4kg | 10 | 7.3 | 5
Davies, 2007^147^ | Metformin + BHI 70/30, 27 | 57.4 | 80 | AA: 4, Asian: 22, C: 70 | 30.2 82.2 kg | 9 | 9.1 | 0
Lund, 2007^197^ | Metformin, 48 | 59.45 | 77 | C: 100 | 24.71 74.81 kg | 7.34 | (Median: 3 years) | 12^*^
Lund, 2007^197^ | Repaglinide, 48 | 63.31 | 75 | C: 100 | 24.82 75.57 kg | 7.57 | (Median: 5 years) | 8^†^
Nauck, 2007^133^ | Metformin + glipizide, 584 | 56.6 | 61.3 | AA: 6, Asian: 8.4, C: 74.3, H: 7.9, other: 3.4 | 31.3 89.7 kg | 7.6 | 6.2 | 172
Nauck, 2007^133^ | Metformin + sitagliptin, 588 | 56.8 | 57.1 | AA: 7, Asian: 8.5, C: 73.5, H: 7.3, other: 3.7 | NR NR | 7.7 | 6.5 | 202
Raskin, 2007^146^ | Metformin + aspart 70/30, 79 | 52 | 52 | AA: 13, Asian: 3, C: 52, H: 32, Other: 1 | 31.2 88.7 kg | 9.9 | NR | 12
Raskin, 2007^146^ | Metformin + glargine, 78 | 51.7 | 54 | AA: 15, Asian: 4, C: 47, H: 32, other: 1 | 30.8 86.2 kg | 9.9 | NR | 6
Hanefeld, 2007^100^ | Glibenclamide, 203 | 60.1 | 70 | AA: 0, C: 99, other: <1 | 28.7 NR | 8.2 | 6.4 | 13
Hanefeld, 2007^100^ | Rosiglitazone, 189 | 60.6 | 58 | AA: 0, C: 97, other: 3 | 28.8 NR | 8.2 | 6 | 9
Hanefeld, 2007^100^ | Rosiglitazone, 195 | 60.4 | 68 | AA: 0, C: 98, other: 2 | 28.7 NR | 8.1 | 5.9 | 12
Scott, 2007^111^ | Glipizide, 123 | 54.7 (21 to 76) | 56.9 | AA: 3.3, Asian: 4.9, C: 61, other: 24.4, Multiracial: 6.5 | 30.6 NR | 7.9 | 4.7 | 23
Scott, 2007^111^ | Sitagliptin, 123 | 56.2 (34 to 75) | 48 | AA: 4.9, Asian: 4.9, C: 63.4, multiracial: 5.7, other: 21.1 | 30.5 NR | 7.9 | 4.9 | 7
Scott, 2007^111^ | Sitagliptin, 123 | 55.6 (34 to 76) | 57.7 | AA: 8.9, Asian: 4.9, C: 61, Multiracial: 6.5, Other: 18.7 | 31.4 NR | 7.9 | 5 | 15
Scott, 2007^111^ | Sitagliptin, 124 | 55.1 (28 to 75) | 52.4 | AA: 4.8, Asian: 2.4, C: 69.4, Multiracial: 7.3, Other: 16.1 | 30.4 NR | 7.8 | 4.2 | 12
Scott, 2007^111^ | Sitagliptin, 125 | 55.1 (30 to 76) | 62 49.6 | AA: 6.4, Asian: 5.6, C: 68.8, multiracial: 6.4, other: 12.8 | 30.8 NR | 7.9 | 4.3 | 18
Kahn, 2006^38^ | Glyburide, 1441 | 56.4 | 58 | AA: 4.2, Asian: 2.2, C: 89, H: 4.2, Other: 0.3 | 32.2 92 kg | 7.35 | (<1: 44, 1–2: 52, >2: 4) | 634
Kahn, 2006^38^ | Metformin, 1454 | 57.9 | 59.4 | AA: 3.7, Asian: 2.4, C: 89.1, H: 3.8, Other: 1 | 32.1 91.6 kg | 7.36 | (<1: 46, 1–2: 50, >2: 4) | 551
Kahn, 2006^38^ | Rosiglitazone, 1456 | 56.3 | 55.7 | AA: 4.2, Asian: 2.7, C: 87.2, H: 5.2, other: 0.7 | 32.2 91.5 kg | 7.36 | (<1: 45, 1–2: 52, >2: 3) | 539
Charbonnel, 2006^94^ | Metformin, 237 | 54.7 | 59.5 | AA: 5.9, Asian: 11, C: 67.1, H: 11.8, other: 4.2 | 31.5 NR | (<8: 54, 8–8.9: 30, ≥ 9: 15) | 6.6 | 45
Charbonnel, 2006^94^ | Metformin + sitagliptin, 464 | 54.4 | 55.8 | AA: 6.7, Asian: 10.6, C: 63.1, H: 15.5 | 30.9 NR | (<8: 55, 8–8.9: 31, ≥ 9: 14) | 6 | 48
Wright, 2006^198^ | Any in the sulfonylurea class, 1687 | NR | NR | NR | NR NR | NR | NR | NR
Wright, 2006^198^ | Metformin, 336 | NR | NR | NR | NR NR | NR | NR | NR
Wright, 2006^198^ | Total, 5063 | 52.4 | 59 | AA: 8, Asian: 9, C: 83 | 27.5 NR | 6.9 | NR | NR
Rosenstock, 2006^49^ | Metformin, 154 | 51.5 | 56 | AA: 5, Asian: 14, C: 58, H: 21, other: <1 | 32.5 NR | 8.8 | 2.9 | 31
Rosenstock, 2006^49^ | Metformin + rosiglitazone, 155 | 50.1 | 57 | AA: 6, Asian: 12, C: 54, H: 26 | 33.2 NR | 8.9 | 2.3 | 19
Rosenstock, 2006^49^ | Rosiglitazone, 159 | 50.6 | 58 | AA: 5, Asian: 14, C: 59, H: 19, Other: 3 | 32.8 NR | 8.8 | 2.7 | 22
Jain, 2006^101^ | Glyburide, 251 | 52.1 | 56.2 | AA: 13.5, Asian: 0, C: 65.7, H: 19.9, Native American: 0.4, Other: 0.4 | 32.8 94.3kg | 9.2 | 0.78 | 123
Jain, 2006^101^ | Pioglitazone, 251 | 52.1 | 53 | AA: 15.9, Asian: 1.6, C: 61, H: 20.7, Other: 0.4, Native American: 0.4 | 32.5 93.9kg | 9.2 | 0.8 | 117
Stewart, 2006^156^ | Metformin, 272 | 59 | 56 | AA: <1, Asian: <1, C: 99, H: <1, Native Hawaiian/other Pacific Islander: <1 | 30.6 87.2 kg | 7.2 | 3.7 | 54
Stewart, 2006^156^ | Metformin + rosiglitazone, 254 | 58.8 | 55 | AA: 0, Asian: 1, C: 98, H: <1, Native Hawaiian/other pacific islander: 0 | 30.9 88.1 kg | 7.2 | 3.7 | 50
Bakris, 2006^125^ | Metformin + glyburide, 185 | 58.8 | 69 | C: 76 | 31.8 90.3 kg | 8.3 | 7.6 | 5
Bakris, 2006^125^ | Metformin + rosiglitazone, 204 | 60 | 63 | C: 78 | 31.6 89.2 kg | 8.5 | 8 | 10
Rosak, 2006^183^ | Metformin + rosiglitazone, 7705 | 60 | 50.2 | NR | 29.3 87.2 | 8.1 (median) | 3.9 | 545
Rosak, 2006^183^ | Rosiglitazone, 1559 | 62 | 47.7 | NR | 28.7 83.8 | 8.1 (median) | 4.5 | 542
Rosak, 2006^183^ | Rosiglitazone + sulfonylurea, 5511 | 65 | 48.2 | NR | 27.7 81.3kg | 8.3 (median) | 5.3 | 478
Hanefeld, 2006^201^ | Metformin + glibenclamide, 250 | 61 | 55 | NR | 32 91.8kg | 8.6 | 4.6 | 138
Hanefeld, 2006^201^ | Metformin + pioglitazone, 250 | 61 | 54 | NR | 32 90.2kg | 8.5 | 4.8 | 55
Umpierrez, 2006^126^ | Metformin + glimepiride, 96 | 51.6 | 55.2 | AA: 13.5, Asian: 1.0, C: 79.2, H: 5.2, Other: 1.0 | 34.54 NR | 8.4 | 4.9 | 11
Umpierrez, 2006^126^ | Metformin + pioglitazone, 109 | 55.7 | 52.3 | AA: 15.9, Asian: 3.7, C: 78.5, H: 1.9, Other: 0 | 33.81 NR | 8.31 | 5.9 | 17
Kvapil, 2006^138^ | Metformin + aspart 70/30, 116 | 56.4 | 46 | NR | 30.4 85.1 kg | 9.3 | 6.7 | 11
Kvapil, 2006^138^ | Metformin + glibenclamide, 114 | 58.1 | 46 | NR | 30. 84.0 kg | 9.4 | 8.1 | 5
Gerich, 2005^136^ | Metformin + glyburide, 209 | 53.5 | 48 | AA: 16.7, Asian: 0.5, C: 65.2, other: 17.7 | 33.5 NR | 8.3 | 2.0 | 87
Gerich, 2005^136^ | Metformin + nateglinide, 219 | 52.6 | 51 | AA: 13, Asian: 2.4, C: 64.4, other: 20.2 | 33.3 NR | 8.4 | 1.5 | 78
Karter, 2005^207^ | Any in the sulfonylurea class, 5921 | 59.9 | 54.8 | NR | NR NR | 8.9 | NR | 0
Karter, 2005^207^ | Metformin, 11937 | 59.9 | 52.5 | NR | NR NR | 9.6 | NR | 0
Karter, 2005^207^ | Pioglitazone, 3556 | 60.2 | 51.1 | NR | NR NR | 9.6 | NR | 0
Agarwal, 2005^184^ | Glipizide, 22 | 64 | 100 | AA: 27, C: 73 | 34 102 kg | 7.7 | 14 | 3
Agarwal, 2005^184^ | Pioglitazone, 22 | 67 | 100 | AA: 14, C: 86 | 32 97 kg | 7.7 | 16 | 1
Derosa, 2005^127^ | Metformin + glimepiride, 49 | 52 | 47 | NR | 26.8 NR | 7.9 | 4 | 2
Derosa, 2005^127^ | Metformin + rosiglitazone, 50 | 54 | 50 | NR | 26.6 NR | 8.0 | 5 | 2
Malone, 2004^164^ | Metformin + glargine, | NR | NR | NR | NR NR | NR | NR | 7
Malone, 2004^164^ | Metformin + lispro 75/25, | NR | NR | NR | NR NR | NR | NR | 3
Malone, 2004^164^ | Pooled arms | NR | 63 | NR | 30.9 91.5kg | 8.7 | 9 | NR
Malone, 2005^165^ | Metformin + lispro 75/25, 50 | 59.18 | 50 | NR | 29.41 77.82 kg | 8.5 | 13.52 | 3
Malone, 2005^165^ | Metformin + glargine, 47 | 59.63 | 38 | NR | 29.64 77.21 kg | 8.48 | 11.9 | 10
Madsbad, 2004^120^ | Glimepiride, 27 | 57 | 59 | NR | 30.2 NR | 7.8 | 3.8 | 0
Madsbad, 2004^120^ | Liraglutide, 26 | 53 | 85 | NR | 30.2 NR | 7.4 | 4.1 | 3
Madsbad, 2004^120^ | Liraglutide, 25 | 58 | 60 | NR | 32 NR | 7.9 | 4.4 | 3
Madsbad, 2004^120^ | Liraglutide, 27 | 57 | 67 | NR | 30.1 NR | 7.7 | 4.5 | 7
Madsbad, 2004^120^ | Liraglutide, 30 | 57 | 67 | NR | 30.4 NR | 7.4 | 4.6 | 2
Madsbad, 2004^120^ | Liraglutide, 29 | 58 | 55 | NR | 31.9 NR | 7.4 | 6.1 | 2
Rajagopalan, 2005^206^ | Any in the sulfonylurea class, 1474 | 54.5 | 52.9 | NR | NR NR | NR | NR | NR
Rajagopalan, 2005^206^ | Metformin, 1137 | 52.5 | 49.6 | NR | NR NR | NR | NR | NR
Rajagopalan, 2005^206^ | Pioglitazone, 1137 | 52.7 | 50 | NR | NR NR | NR | NR | NR
Rajagopalan, 2005^206^ | Pioglitazone, 1474 | 54.6 | 54.3 | NR | NR NR | NR | NR | 0
Rajagopalan, 2005^206^ | Pioglitazone, 1847 | 54.3 | 52.4 | NR | NR NR | NR | NR | 0
Rajagopalan, 2005^206^ | Rosiglitazone, 1847 | 54.3 | 51.8 | NR | NR NR | NR | NR | 0
Hussein, 2004^202^ | Pioglitazone, 107 | 64.4 (36 to 86) | 48 | NR | NR 84.3 | 9.5 | 17 | 0
Hussein, 2004^202^ | Rosiglitazone, 96 | 64.6 (41 to 82) | 55 | NR | NR 82.3 | 9.6 | 14.5 | 0
Horton, 2004^80^ | Metformin, 104 | 55.4 | 67.3 | NR | 29.9 NR | 8.3 | 3.7 | NR
Horton, 2004^80^ | Metformin + nateglinide, 89 | 57.7 | 65.2 | NR | 30.6 NR | 8.2 | 3.4 | NR
Horton, 2004^80^ | Nateglinide, 104 | 57.9 | 56.7 | NR | 29.9 NR | 8.1 | 4.7 | NR
Malone, 2003^137^ | Metformin + glibenclamide, 301 | 59 | 49 | AA: 1, C: 89, H: 6, other: 4 | 29.6 81.7 kg | 9.27 | 7.4 | 29
Malone, 2003^137^ | Metformin + lispro 75/25, 296 | 58 | 57 | AA: 0.7, C: 88.9, H: 7.4, other: 3 | 29.8 83.0 kg | 9.17 | 8.0 | 25
Yang, 2003^139^ | Metformin + sulfonylurea | NR | NR | NR | NR NR | 8.59 | NR | NR
Yang, 2003^139^ | Rosiglitazone + sulfonylurea | NR | NR | NR | NR NR | 8.61 | NR | NR
Jones, 2003^179^ | Metformin, 121 | 58 (38 to 78) | 70 | NR | 34 NR | 8.7 | 5 | 0
Jones, 2003^179^ | Metformin, 22 | 64 (46 to 81) | 9 | NR | 23 NR | 8.6 | 6.5 | NR
Jones, 2003^179^ | Metformin, 82 | 60 (40 to 81) | 74 | NR | 28 NR | 8.8 | 6 | NR
Jones, 2003^179^ | Metformin + rosiglitazone, 141 | 58 (36 to 82) | 69 | NR | 28 NR | 8.8 | 6 | NR
Jones, 2003^179^ | Metformin + rosiglitazone, 142 | 57 (39 to 80) | 57 | NR | 34 NR | 8.8 | 5 | NR
Jones, 2003^179^ | Metformin + rosiglitazone, 35 | 62 (42 to 78) | 71 | NR | 23 NR | 9.3 | 8 | NR
Marre, 2002^96^ | Metformin, 152 | 56.4 | 55.3 | AA: 3.3, Asian: 2.6, C: 30.8 | 29.6 NR | 8.25 | 6.5 | 16
Marre, 2002^96^ | Metformin + nateglinide, 155 | 57.9 | 61.3 | AA: 4.5, Asian: 3.2, C: 90.3 | 29.4 NR | 7.99 | 7.2 | 18
Marre, 2002^96^ | Metformin + nateglinide, 160 | 57.3 | 61.3 | AA: 3.8, Asian: 3.1, C: 91.3 | 29.3 NR | 8.18 | 6.8 | 15
Moses, 1999^82^ | Metformin, 27 | 57.8 | 63 | Asian: 7, C: 85, not specified: 7 | 31.8 NR | 8.6 | 8 | 0
Moses, 1999^82^ | Metformin + repaglinide, 27 | 57.2 | 67 | C: 96, not specified: 4 | 33.2 NR | 8.3 | 5.9 | 0
Moses, 1999^82^ | Repaglinide, 28 | 60.3 | 54 | Asian: 7, C: 93 | 31.3 NR | 8.6 | 7 | 0
Jibran, 2006^112^ | Glibenclamide, 50 | 45.8 | 10 | NR | 30.4 72.7 kg | 10.2 | 0 | 0
Jibran, 2006^112^ | Repaglinide, 50 | 46.6 | 16 | NR | 27.1 65.8 kg | 9.9 | 0 | 0
Leiter, 2005^83^ | Metformin, 78 | 60 | 56 | C: 86, Others: 22 | 32.2 NR | 7.5 | 5.7 | 13
Leiter, 2005^83^ | Metformin + rosiglitazone, 158 | 58 | 65 | C: 76, Others: 24 | 33 NR | 7.5 | 5.3 | 18
Garber, 2006^128^ | Diet + metformin + glibenclamide, 160 | 56 (31–78) | 56 | AA: 5, C: 80, Asian: 3, H: 11, O: 2 | 32 93 kg | 8.5 | 5 | NR
Garber, 2006^128^ | Diet + metformin + rosiglitazone, 158 | 56 (24–78) | 65 | AA: 6, C: 79, Asian: 3, H: 10, O: 3 | 32 94 kg | 8.4 | 6 | NR
Weissman, 2005^86^ | Metformin, 384 | 55.7 | NR | NR | 33.8 96.7kg | 7.97 | NR | 95
Weissman, 2005^86^ | Metformin + rosiglitazone, 382 | 55.5 | NR | NR | 34.4 98.2kg | 8.05 | NR | 76
Weissman, 2005^86^ | Metformin + rosiglitazone, 358 | 55.5 | NR | NR | 34.4 98.2kg | 8.05 | NR | 95
Weissman, 2005^86^ | Metformin, 351 | 55.7 | NR | NR | 33.8 96.7kg | 7.97 | NR | 76
Bailey, 2005^87^ | Metformin, 280 | 57.6 | 57 | AA: <1, Asian: 1, C: 98, Other: 1 | 32.1 89.5kg | 7.5 | 6.1 | 44
Bailey, 2005^87^ | Metformin + rosiglitazone, 289 | 58.1 | 58 | AA: 1, C: 97, Asian: 1, H: 0, O: 1 | 32.2 90.9kg | 7.4 | 6 | 30
Bailey, 2005^87^ | Metformin + rosiglitazone, 288 | 58.1 | 58 | AA: 1, Asian: 1, C: 97, other: 1 | 32.2 90.9kg | 7.4 | 6 | 30
Yamanouchi, 2005^50^ | Diet + exercise + glimepiride, 37 | 55.6 (46.3– 64.9) | 51 | AA: 0, C: 0, Asian: 0, H: 0, O: 100 | 25.6 NR | 9.8 | 3.3 months | 3
Yamanouchi, 2005^50^ | Diet + exercise + metformin, 39 | 54.7 (44.9–64.5) | 51 | AA: 0, C: 0, Asian: 0, H: 0, O: 100 | 26.2 NR | 9.9 | 3 months | 2
Yamanouchi, 2005^50^ | Diet + exercise + pioglitazone, 38 | 55.2 (46–64.4) | 47 | AA: 0, C: 0, Asian: 0, H: 0, O: 100 | 25.8 NR | 10.2 | 3.2 months | 2
Yamanouchi, 2005^50^ | Glimepiride, 37 | 55.6 | 51 | NR | 25.6 NR | 9.8 | 3.3 | 3
Yamanouchi, 2005^50^ | Metformin, 39 | 54.7 | 51 | NR | 26.2 NR | 9.9 | 3 | 2
Yamanouchi, 2005^50^ | Pioglitazone, 38 | 55.2 | 47 | NR | 25.8 NR | 10.2 | 3.2 | 3
Derosa, 2005^159^ | Diet + exercise + behavioral therapy + metformin + glimepiride, 47 | 52 (47–57) | 49 | NR | 26.8 NR | 7.9 | 4 | NR
Derosa, 2005^159^ | Diet + exercise + behavioral therapy + metformin + rosiglitazone, 48 | 54 (50–58) | 52 | NR | 26.6 NR | 8 | 5 | NR
Rajagopalan, 2005^194^ | Metformin, 1137 | 52.5 (19–88) | 49.6 | NR | NR NR | NR | NR | NR
Rajagopalan, 2005^194^ | Pioglitazone, 1847 | 54.3 (18–91) | 52.4 | NR | NR NR | NR | NR | NR
Rajagopalan, 2005^194^ | Unspecified sulfonylurea, 1474 | 54.5 (19–94) | 52.9 | NR | NR NR | NR | NR | NR
Rajagopalan, 2005^194^ | Pioglitazone, 1137 | 52.7 (18–90) | 50 | NR | NR NR | NR | NR | NR
Rajagopalan, 2005^194^ | Pioglitazone, 1474 | 54.6 (18–91) | 54.3 | NR | NR NR | NR | NR | NR
Rajagopalan, 2005^194^ | Rosiglitazone, 1847 | 54.3 (18–92) | 51.8 | NR | NR NR | NR | NR | NR
Feinglos, 2005^91^ | Metformin + glipizide, 61 | 57.7 (30–80) | 46 | AA: 8.2, C: 78.7, Asian: 3.3, H: 8.2, O: 1.6 | 31.7 90 kg | 7.45 | 6.5 | NR
Feinglos, 2005^91^ | Placebo + metformin, 61 | 58.8 (40–81) | 41 | AA: 16.4, C: 68.9, Asian: 3.3, H: 8.2, O: 3.3 | 32.1 90.8 kg | 7.64 | 4.6 | NR
Maru, 2005^195^ | Unspecified sulfonylurea, 11350 | 64 | 52.5 | NR | (BMI>=30: 21%) NR | NR | NR | NR
Maru, 2005^195^ | Metformin, 4579 | 59 | 48.2 | NR | (BMI>=30: 48%) NR | NR | NR | NR
Schernthaner, 2004^52^ | Metformin, 597 | 56 (35 to 75) | 58 | NR | 31.4 89.7kg | 8.7 | 3.1 | 96
Schernthaner, 2004^52^ | Pioglitazone, 597 | 57 (35 to 75) | 53 | NR | 31.2 88.2kg | 8.7 | 3.4 | 98
Schernthaner, 2004^52^ | Placebo + diet + metformin, 597 | 56 | 57.8 | NR | 31.4 89.7kg | 8.7 | 3.1 | NR
Schernthaner, 2004^52^ | Placebo + diet + pioglitazone, 597 | 57 | 52.6 | NR | 31.2 88.2kg | 8.7 | 3.4 | NR
Nichols, 2005^196^ | Unspecified sulfonylurea, 1085 | 62 | 55.9 | NR | NR NR | 8 | 4 | NR
Nichols, 2005^196^ | Metformin + unspecified sulfonylurea, 1834 | 61.1 | 52.4 | NR | NR NR | 8.3 | 5.8 | NR
Nichols, 2005^196^ | Metformin, 272 | 60 | 51.1 | NR | NR NR | 7.8 | 4.3 | NR
Derosa, 2004^60^ | Placebo + diet + exercise + glimepiride, 81 | 56 | 47 | NR | 27.6 NR | 8.5 | NR | NR
Derosa, 2004^60^ | Placebo + diet + exercise + metformin, 83 | 58 | 51 | NR | 28.1 NR | 8.4 | NR | NR
Tan, 2004^106^ | Glibenclamide, 109 | 57.9 | 73 | AA: 0, C: 100, Asian: 0, H: 0, O: 0 | 29.6 89 kg | 8.5 | 5.22 | 41
Tan, 2004^106^ | Pioglitazone, 91 | 60 | 62 | C: 99, Unspecified: 1 | 30.2 88.4 kg | 8.4 | 4.76 | 36
Raskin, 2004^109^ | Repaglinide, 63 | 58.5 | 62 | AA: 16, C: 63, H: 2, Unspecified: 19 | 30.4 NR | 9.3 | 7.2 | 25
Raskin, 2004^109^ | Rosiglitazone, 62 | 56.6 | 53 | AA: 13, C: 68, H: 0, Unspecified: 19 | 31.4 NR | 9 | 7.4 | 25
Jovanovic, 2004^110^ | Pioglitazone, 62 | 56.2 | 50 | AA: 11, C: 82, H: 3, other: 3 | 32.1 NR | 9.1 | 6.1 | 36
Jovanovic, 2004^110^ | Pioglitazone + repaglinide, 123 | 58.9 | 68.3 | AA: 15, C: 82, H: 1, others: 2.4 | 32.3 NR | 9.3 | 7.1 | 18
Jovanovic, 2004^110^ | Repaglinide, 61 | 57.8 | 58 | AA: 11, C: 75, H: 4.9, other: 8.1 | 31.2 NR | 9 | 6.9 | 25
Hanefeld, 2004^140^ | Metformin + sulfonylurea, 320 | 60 (36 to 75) | 54.7 | AA: 0.9, C: 98.4, other: 0.6 | 30 84.9 kg | 8.8 | 7.1 | 279
Hanefeld, 2004^140^ | Pioglitazone + sulfonylurea, 319 | 60 (36 to 75) | 53,6 | AA: 0.6, C: 99.4, other: 0 | 30.2 85.3 kg | 8.82 | 60 | 259
Hanefeld, 2004^140^ | Placebo + metformin + unspecified sulfonylurea, 320 | 60 (36 to 75) | 54.7 | AA: 0.9, C: 98.4, Asian: 0, H: 0, O: 0.6 | 30 84.9 kg | 8.8 | 7.1 | NR
Hanefeld, 2004^140^ | Placebo + unspecified sulfonylurea + pioglitazone, 31 | 60 (36 to 75) | 53.6 | AA: 0.6, C: 99.4, Asian: 0, H: 0, O: 0 | 30.2 85.3 kg | 8.82 | 7 | NR
Garber, 2003^61^ | Metformin + glyburide, 171 | 55.6 | 44 | AA: 10.5, C: 77.2, Asian: 0, H: 8.8, O: 3.5 | 31.4 91.9 kg | 8.8 | 3 | NR
Garber, 2003^61^ | Metformin, 164 | 54.7 | 43.3 | AA: 6.7, C: 80.5, Asian: 0, H: 9.1, O: 3.7 | 31.4 92.8 kg | 8.5 | 2.6 | NR
Garber, 2003^61^ | Glyburide, 151 | 55.3 | 43.7 | AA: 7.3, C: 81.5, Asian: 0, H: 7.9, O: 3.3 | 31.1 91 kg | 8.7 | 3 | NR
Tosi, 2003^36^ | Glibenclamide, 20 | NR | NR | NR | NR NR | NR | NR | NR
Tosi, 2003^36^ | Metformin + glibenclamide, 41 | NR | NR | NR | NR NR | NR | NR | NR
Tosi, 2003^36^ | Metformin, 19 | NR | NR | NR | NR NR | NR | NR | NR
Goldstein, 2003^62^ | Metformin + glipizide, 87 | 54.6 | 58.6 | AA: 11.5, C: 72.4, Asian: 0, H: 16.1, O: 0 | 31.7 94 kg | 8.7 | 5.9 | NR
Goldstein, 2003^62^ | Glipizide, 84 | 57.4 | 64.3 | AA: 11.9, C: 71.4, Asian: 2.4, H: 14.3, O: 0 | 30.6 89.9 kg | 8.9 | 6.5 | NR
Goldstein, 2003^62^ | Metformin, 76 | 56.6 | 61.8 | AA: 15.8, C: 65.8, Asian: 1.3, H: 17.1, O: 0 | 31.6 93.8 kg | 8.7 | 7.3 | NR
Derosa, 2003^81^ | Diet + exercise + metformin, 56 | 52 | 48 | NR | 24.7 72.3 kg | 7.4 | 5 | NR
Derosa, 2003^81^ | Diet + exercise + repaglinide, 56 | 55 | 52 | NR | 25.2 70.2 kg | 7.6 | 4 | NR
Pavo, 2003^54^ | Metformin, 100 | 55.8 | 56 | NR | 31.1 88.9 kg | 8.6 | 6.3 | 9
Pavo, 2003^54^ | Pioglitazone, 105 | 54.2 | 56.2 | NR | 31.3 86.6 kg | 8.6 | 5.6 | 5
Vakkilainen, 2002^119^ | Placebo + glibenclamide, 20 | 63 | NR | AA: 0, C: 100, Asian: 0, H: 0, O: 0 | 28.8 NR | 7.6 | NR | NR
Vakkilainen, 2002^119^ | Placebo + nateglinide, 23 | 63 | NR | AA: 0, C: 100, Asian: 0, H: 0, O: 0 | 27.8 NR | 7.6 | NR | NR
Blonde, 2002^63^ | Metformin + glyburide, 162 | 55.6 | 63.6 | AA: 9.3, C: 67.9, Asian: 0, H: 19.1, O: 3.7 | 30.6 89.6 kg | 9.42 | 6.97 | NR
Blonde, 2002^63^ | Glyburide, 164 | 55.8 | 57.3 | AA: 12.2, C: 66.5, Asian: 0, H: 17.1, O: 4.3 | 30.3 88 kg | 9.64 | 7.01 | NR
Blonde, 2002^63^ | Metformin + glyburide, 160 | 55.4 | 55.6 | AA: 12.5, C: 70, Asian: 0, H: 15.6, O: 1.9 | 30.7 89.4 kg | 9.41 | 7.36 | NR
Blonde, 2002^63^ | Metformin, 153 | 57.6 | 62.1 | AA: 10.5, C: 69.3, Asian: 0, H: 17, O: 3.3 | 30.6 89.5 kg | 9.51 | 8.18 | NR
St John Sutton, 2002^149^ | Glyburide, 99 | 56.1 | 72 | AA: 3, C: 76, others: 21 | NR 85.1 kg | 9.5 | 6.2 | NR
St John Sutton, 2002^149^ | Rosiglitazone, 104 | 55.1 | 72 | AA: 5, C: 73, others: 22 | NR 82.6 kg | 9.1 | 5.3 | NR
Marre, 2002^64^ | Glibenclamide, 103 | 58.7 | 55 | NR | 29.3 82.5 kg | 7.88 | 6.6 | NR
Marre, 2002^64^ | Metformin, 104 | 57.5 | 60 | NR | 29.9 84.9 kg | 8.09 | 5.4 | NR
Marre, 2002^64^ | Metformin + glibenclamide, 101 | 58 | 50 | NR | 30.1 84.7 kg | 7.89 | 5.9 | NR
Marre, 2002^64^ | Metformin + glibenclamide, 103 | 60.7 | 54 | NR | 29.7 83.1 kg | 7.62 | 6.7 | NR
Garber, 2002^65^ | Metformin + glyburide, 165 | 58.1 | 58 | AA: 6, C: 79, Asian: 0, H: 10, O: 5 | 29.6 86.7 kg | 8.18 | 3.3 | NR
Garber, 2002^65^ | Glyburide, 161 | 56.5 | 51 | AA: 9, C: 78, Asian: 0, H: 9, O: 4 | 30.3 87.2 kg | 8.21 | 2.81 | NR
Garber, 2002^65^ | Metformin + glyburide, 158 | 56.9 | 58 | AA: 13, C: 74, Asian: 0, H: 11, O: 2 | 30.1 88.8 kg | 8.25 | 3.52 | NR
Garber, 2002^65^ | Metformin, 161 | 56 | 58 | AA: 4, C: 81, Asian: 0, H: 12, O: 2 | 30.4 88.6 kg | 8.26 | 2.98 | NR
Gomez-Perez, 2002^88^ | Metformin, 34 | 53.4 (40 – 68) | 29.4 | C: 2.9, H: 76.5, Mestizo: 20.6 | 28.5 NR | NR | 9.1 | NR
Gomez-Perez, 2002^88^ | Metformin + rosiglitazone, 35 | 51.7 (40 – 73) | 28.6 | C: 0, H: 80, Mestizo: 20 | 28.0 NR | NR | 11.1 | NR
Gomez-Perez, 2002^88^ | Metformin + rosiglitazone, 36 | 54.2 (42–76) | 40 | C: 11.1, H: 72.2, Mestizo: 16.7 | 27.6 NR | NR | 10.7 | NR
Charpentier, 2001^71^ | Metformin + glimepiride, 147 | 56.8 (36–70) | 59 | NR | 29.5 81.2 kg | 6.4 | 5.6 | NR
Charpentier, 2001^71^ | Placebo + glimepiride, 150 | 55.4 (35–70) | 58 | NR | 29.3 81 kg | 6.5 | 5.3 | NR
Charpentier, 2001^71^ | Placebo + metformin, 75 | 56.7 (36–69) | 60 | NR | 29.2 82.2 kg | 6.8 | 7 | NR
Madsbad, 2001^114^ | Repaglinide, 175 | 60.2 | 61 | NR | 28 82.9 kg | 7.3 | 8.1 | NR
Madsbad, 2001^114^ | Placebo + glipizide, 81 | 62 | 64 | NR | 28 83.6 kg | 7.2 | 7 | NR
Amador-Licona, 2000^66^ | Metformin, 28 | 49.3 | 39 | NR | 26.8 70.7 kg | 8.5 | 4.5 | NR
Amador-Licona, 2000^66^ | Glibenclamide, 23 | 48.2 | 30 | NR | 30.4 73.2 kg | 8.4 | 4 | NR
Einhorn, 2000^89^ | Diet + metformin + pioglitazone, 168 | 55.5 | 54.8 | AA: 8.3, C: 81, Asian: 0, H: 10.1, O: 0.6 | 32.11 NR | 9.86 | NR | NR
Einhorn, 2000^89^ | Metformin, 160 | 55.7 | 60 | AA: 6.3, C: 86.9, H: 3.8, Others: 3.1 | 32.12 NR | 9.75 | NR | 37
Einhorn, 2000^89^ | Metformin + pioglitazone, 168 | 55.5 | 54.8 | AA: 8.3, C: 81, H: 10.1, Others: 0.6 | 32.11 NR | 9.86 | NR | 21
Einhorn, 2000^89^ | Placebo + diet + metformin, 160 | 55.7 | 60 | AA: 6.3, C: 86.9, Asian: 0, H: 3.8, O: 3.1 | 32.12 NR | 9.75 | NR | NR
Fonseca, 2000^90^ | Metformin, 116 | 58.8 | 74.3 | AA: 3.5, C: 81.4, other: 15 | 30.3 NR | 8.6 | 7.3 | 22
Fonseca, 2000^90^ | Metformin + rosiglitazone, 113 | 58.3 | 68.2 | AA: 10, C: 77.3, others: 12.7 | 29.8 NR | 8.9 | 8.3 | 18
Fonseca, 2000^90^ | Metformin + rosiglitazone, 119 | 57.5 | 62.1 | AA: 6.9, C: 80.2, others: 12.9 | 30.2 NR | 8.9 | 7.5 | 18
Horton, 2000^79^ | Metformin, 178 | 56.8 | 68 | AA: 9.6, C: 79.2, Asian: 2.2, H: 0, O: 9 | 29.6 NR | 8.4 | 7.5 | NR
Horton, 2000^79^ | Nateglinide, 179 | 58.6 | 61 | AA: 9.5, C: 82.1, Asian: 2.8, H: 0, O: 5.6 | 29.6 NR | 8.3 | 4.7 | NR
Landgraf, 1999^115^ | Repaglinide, 94 | 61 | 60 | AA: 0, C: 96, Asian: 0, H: 0, O: 4 | 27.6 80 kg | 7.8 | 10 | NR
Landgraf, 1999^115^ | Placebo + glibenclamide, 100 | 63 | 57 | AA: 6, C: 93, Asian: 0, H: 0, O: 1 | 27.5 79 kg | 8 | 10 | NR
Marbury, 1999^117^ | Placebo + glyburide, 182 | 58.7 | 66 | AA: 9, C: 79, Asian: 0, H: 0, O: 12 | 29.1 NR | 8.9 | 8.3 | NR
Marbury, 1999^117^ | Repaglinide, 362 | 58.3 | 67 | AA: 9, C: 77, Asian: 0, H: 0, O: 14 | 29.4 NR | 8.7 | 7.2 | NR
Wolffenbuttel, 1999^116^ | Placebo + glyburide, 139 | 61 | 68 | NR | 28 81.3 kg | 7 | Median: 6 | NR
Wolffenbuttel, 1999^116^ | Repaglinide, 286 | 61 | 62 | NR | 28.4 81.5 kg | 7.1 | Median: 6 | NR
DeFronzo, 1995^70^ | Metformin, 143 | 53 | 43 | NR | 29.9 94.4 kg | 8.4 | 6 | NR
DeFronzo, 1995^70^ | Metformin + glyburide, 213 | 55 | 46 | NR | 29 92.1 kg | 8.8 | 7.8 | NR
DeFronzo, 1995^70^ | Placebo + glyburide, 209 | 56 | 49 | NR | 29.1 92.6 kg | 8.5 | 8.7 | NR
DeFronzo, 1995^70^ | Placebo + metformin, 210 | 55 | 46 | NR | 29.4 92.6 kg | 8.9 | 8.4 | NR
Hermann, 1994^68^ | Diet + metformin + glibenclamide, 54 | NR | NR | NR | NR 80.2 kg | 6.8 | NR | NR
Hermann, 1994^68^ | Diet + metformin, 25 | NR | NR | NR | NR 78.6 kg | 6.9 | NR | NR
Hermann, 1994^68^ | Diet + metformin + glibenclamide, 13 | NR | NR | NR | NR 84.6 kg | 7.8 | NR | NR
Hermann, 1994^68^ | Diet + metformin + glibenclamide, 13 | NR | NR | NR | NR 76 kg | 7.8 | NR | NR
Hermann, 1994^68^ | Diet + metformin + glibenclamide, 18 | NR | NR | NR | NR 83.2 kg | 8.4 | NR | NR
Hermann, 1994^68^ | Diet + glibenclamide, 21 | NR | NR | NR | NR 82.6 kg | 6.7 | NR | NR
Wolffenbuttel, 1993^118^ | Glibenclamide, 15 | 62 (45–75) | 25 | NR | 26.1 70.9 kg | Range 7.0–12.0 | 9 | NR
Wolffenbuttel, 1993^118^ | Repaglinide, 29 | 62 (45–75) | 25 | NR | 26.1 74 kg | Range 7.0–12.0 | 9 | NR

Author, year | Study design | Intervention | Hypoglycemia, n (%) | Liver failure, n (%) | Congestive heart failure, n (%) | Fractures, n (%) | GI side effects, n (%) | Other, n (%)
Metformin versus thiazolidinediones
Tzoulaki, 2009^171^ | Cohort | Grp1: Metformin NR Grp2: Rosiglitazone NR | | | Def: First episode of CHF Grp1: ref Grp2: 0.61 (CI: 0.33 to 1.15) | Non-hip fractures Grp1: ref Grp2: HR: 1.09 (CI: 0.72 to 1.68)
Tzoulaki, 2009^171^ | Cohort | Grp1: Metformin NR Grp2: Pioglitazone NR | | | Def: First episode of CHF Grp1: ref Grp2: 1.17 (CI: 0.77 to 1.77) | Non-hip fractures Grp1: ref Grp2: HR: 1.28 (CI: 0.93 to 1.77)
Perez, 2009^56^ | RCT | Grp1: Metformin Fixed Mean: 850 mg Grp2: Pioglitazone Fixed | | | | Def: Wrist fractures Coll: Active Timing: Specified ITT: NR Grp1: 1 (<1) Grp2: 0 (0) | Def: Diarrhea Coll: Active Timing: Specified ITT: NR Grp1: (15.3) Grp2: (2.6)
Pantalone, 2009^174^ | Cohort | Grp1: Metformin NR Grp2: Rosiglitazone NR | | | Def: ICD-9 codes Coll: NR Timing: NA ITT: NA Grp1: ref Grp2: HR: 1.16 (CI: 0.78 to 1.73)
Pantalone, 2009^174^ | Cohort | Grp1: Metformin NR Grp2: Pioglitazone NR | | | Def: ICD-9 codes Coll: NR Timing: NA ITT: NA Grp1: ref Grp2: HR: 1.38 (CI: 1.00 to 1.90)
Hsiao, 2009^173^ | Cohort | Grp1: Metformin NR Grp2: Rosiglitazone NR | | | Def: ICD-9-CM diagnostic codes of hospitalization Coll: NR Timing: Unspecified ITT: NA Grp1: 578 (1.26); ref Grp2: 67 (3.33); HR: 1.30 (CI: 0.89 to 1.89)
Hsiao, 2009^173^ | Cohort | Grp1: Metformin NR Grp2: Pioglitazone NR | | | Def: ICD-9-CM diagnostic codes of hospitalization Coll: NR Timing: Unspecified ITT: NA Grp1: 578 (1.26); ref Grp2: 13 (2.66); HR: 1.54 (CI: 0.65 to 3.64)
Karter, 2005^207^ | Cohort | Grp1: Metformin NR Grp2: Pioglitazone NR | | | Def: ICD-9-CM codes for primary discharge diagnosis (HR relative to sulfonylurea use) Coll: Passive Timing: Unspecified ITT: NR Grp1: HR: 0.7 (CI: 0.49–0.99), p: 0.05 Grp2: HR: 1.28 (CI: 0.85–1.92), p: 0.2
Asche, 2008^200^ | Cohort | Grp1: Metformin NR Grp2: Thiazolidinediones NR | | | Def: NR Coll: NR Timing: Unspecified ITT: NR Grp1: NR Grp2: 18 (2.6) | | Def: Nausea & vomiting; diarrhea; dyspepsia Coll: NR Timing: NR ITT: NR Grp1: (1.3%; 1.6%; 2.8%) Grp2: NR | Def: Lactic acidosis Coll: NR Timing: Unspecified ITT: NR Grp1: 6 (0.3) Grp2: NR
Kawai, 2008^221^ | Non- randomized | Grp1: Metformin NR Start: 500–750mg, Max: 750mg Grp2: Pioglitazone Fixed NR | Def: Mild, moderate and severe Coll: NR Timing: Unspecified ITT: Yes Grp1: 0 (0) Grp2: 0 (0)
Rosenstock, 2006^49^ | RCT | Grp1: Metformin Varied, mean daily glucose ≤ 6.1 mmol/l Start: 500 mg, Max: 2000 mg, Mean: 1847 mg D: 32 wks Grp2: Rosiglitazone Varied, mean daily glucose ≤ 6.1 mmol/l Start: 4 mg, Max: 8 mg, Mean: 7.7 mg D: 32 wks | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 14 (9) Grp2: 13 (8) | | | | Def: Diarrhea, nausea, vomiting, dyspepsia Coll: Active Timing: Specified ITT: Yes Grp1: (51) Grp2: (35)
Kahn, 2006^38^ | RCT | Grp1: Metformin Varied, glucose: <140 mg Start: 500 mg, Max: 2000 mg Grp2: Rosiglitazone Varied, glucose: <140 mg Start: 4 mg, Max: 8 mg | Def: Self reported Coll: NR Timing: Unspecified ITT: Yes Grp1: All: 168 (11.6), Severe: 1 (0.1) Grp2: All: 142 (9.8), Severe: 1 (0.1) | | Def: Investigator reported Grp1: 19 (1.3) Grp2: 22 (1.5) | | Def: Nausea, vomiting, diarrhea, abdominal discomfort Coll: NR Timing: Unspecified ITT: Yes Grp1: (38.3) Grp2: (23)
Yamanouchi, 2005^50^ | RCT | Grp1: Metformin Fixed Start: 750 mg Grp2: Pioglitazone Fixed Start: 30 mg women, 45 mg men | Def: NR Grp1: 0 (0) Grp2: 0 (0)
Pavo, 2003^54^ | RCT | Grp1: Metformin Varied, glucose: < 126 mg/dl Start: 850 mg, Max: 2550 mg, Mean: 2292 mg D: 8 wks Grp2: Pioglitazone Varied, glucose: < 126 mg/dl Start: 35 mg, Max: 45 mg, Mean: 41.5 mg D: 8 wks | | | | | Def: Diarrhea Grp1: (16) Grp2: (3) | Def: Cholecystitis Coll: Active Timing: Unspecified ITT: NR Grp1: 0 (0) Grp2: 1 (1)
Schernthaner, 2004^52^ | RCT | Grp1: Metformin Varied Start: 850 mg, Max: 2550 mg Grp2: Pioglitazone Varied Start: 35 mg, Max: 45 mg | | | | | Def: Diarrhea; Nausea Grp1: (11.1); (4.2) Grp2: (3.2); (2.3)
Leiter 2005^83^ | RCT | Grp1: Metformin Varied, glucose: <7.0 mmol/L Start: 1500 mg, Max: 2500 mg D: 8 wks Grp2: Rosiglitazone Varied, glucose: <7.0 mmol/L Start: 4 mg, Max: 8 mg D: 8 wks | | | Grp1: 0 (0) Grp2: 3 (1)
Rajagopalan, 2005^206^ | Cohort | Grp1: Metformin NR Grp2: Pioglitazone NR | | Def: ICD9 code liver failure or hepatitis Coll: Passive Timing: Unspecified ITT: NR Grp1: 0.8% incidence Grp2: 0.5% incidence HR: 1.139 (CI: 0.439–2.96)
Rajagopalan, 2005^206^ | Cohort | Grp1: Metformin NR Grp2: Rosiglitazone NR | | Def: ICD9 code ‘liver failure’ or ‘hepatitis’ Coll: Passive Timing: Unspecified ITT: NR Grp1: 0.8% incidence Grp2: 0.4% incidence
Kahn, 2008^213^ | RCT | Grp1: Metformin Varied, glucose: < 140 Start dose: 500g, Max: 2g Grp2: Rosiglitazone Varied, glucose: < 140 Start dose: 4mg, Max: 8mg | | | | Def: Fractures (NS) Coll: NR Timing: Unspecified ITT: Yes Grp1: 1.2/ 100 patient- years Grp2: 1.86/ 100 patient- years HR: 1.57 (CI: 1.13 – 2.17), p: 0.0073
Metformin versus sulfonylurea
Pantalone, 2009^174^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea NR | | | Def: ICD-9 codes Coll: NR Timing: NA ITT: NA Grp1: HR: 0.76 (CI: 0.64 to 0.91) Grp2: ref
Tzoulaki, 2009^171^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea NR | | | Def: First episode of CHF Grp1: ref Grp2: 1.18 (CI: 1.04 to 1.34) | Non-hip fractures Grp1: ref Grp2: HR: 1.09 (CI: 0.97 to 1.23)
Currie, 2009^212^ | Cohort | Grp1: Metformin NR Grp1: Sulfonylurea | | | | | | Def: Cancer Coll: Passive Timing: Unspecified ITT: NA Grp1: ref Grp2: HR: 1.36 (CI: 1.19 to 1.54)
Asche, 2008^200^ | Cohort | Grp1: Metformin NR Grp2: Any drug in the sulfonylurea class NR | | | | | Def: Nausea/ vomiting; Diarrhea; Dyspepsia Coll: NR Timing: No ITT: NR Grp1: (1.3; 1.6; 2.8) Grp2: NR | Def: Lactic acidosis Coll: NR Timing: Unspecified ITT: NR Grp1: 6 (0.3) Grp2: NR
McAlister, 2008^208^ | Cohort | Grp1: Metformin NR Median: 726 mg Grp2: Any sulfonylurea Varied Median: 4 mg for glyburide, 198 mg for chlorpropamide, 425 mg for tolbutamide | | | Def: Primary, secondary or most responsible diagnosis of HF using ICD-9 codes Coll: Passive ITT: NR Grp1: 3.3 cases/100yrs Grp2: 4.4 cases/100 yrs, aHR: 1.16 (CI: 0.96-1.41)
Karter, 2005^207^ | Cohort | Grp1: Metformin NR Grp2: Any sulfonylurea NR | | | Def: ICD-9-CM codes for primary discharge diagnosis Coll: Passive Timing: Unspecified ITT: NR Grp1: HR: 0.7 (CI: 0.49-0.99), p: 0.05 Grp2: ref
Chien, 2007^59^ | RCT | Grp1: Metformin Varied, glucose: <140 mg/dL Start: 1000 mg, Max: 2000 mg, Mean: 1910 mg D: 4 wks Grp2: Glyburide Varied, glucose: <140 mg/dL Start: 10 mg, Max: 20 mg, Mean: 19 mg D: 4 wks | Def: Mild or moderate Coll: Passive Timing: Unspecified ITT: Yes Grp1: 0 (0) Grp2: 0 (0) | | | | Def: Diarrhea, dry mouth, increased appetite, GI disease Coll: Passive Timing: Unspecified ITT: Yes Grp1: (32) Grp2: (13)
Kahn, 2006^38^ | RCT | Grp1: Metformin Varied, glucose: <140 mg/dL Start: 500 mg, Max: 2000 mg Grp2: Glyburide Varied, glucose: <140 mg/dL Start: 2.5 mg, Max: 15 mg | Def: Self reported events Coll: NR Timing: Unspecified ITT: Yes Grp1: All: 168 (11.6), Severe: 1 (0.1) Grp2: All: 557 (38.7), Severe: 8 (0.6) | | Def: Investigator reported events Coll: NR Timing: Unspecified ITT: Yes Grp1: All: 19 (1.3), Serious: 12 (0.8) Grp2: All: 9 (0.6), Serious: 3 (0.2) | | Def: Nausea, vomiting, diarrhea, abdominal discomfort Coll: NR Timing: Unspecified ITT: Yes Grp1: (38.3) Grp2: (21.9)
Wright, 2006^198^ | RCT | Grp1: Metformin Varied, glucose: <6 mmol/L Max: 2550 mg Grp2: Sulfonylurea Varied, glucose: <6 mmol/L Max: glipizide 40 mg, chlorpropramide 500 mg, glibenclamide 20 mg | Def: Mean annual % Coll: Active Timing: Specified ITT: NR Grp1: Substantive hypo: 0.3, (CI: 0.1-1.1); Any: 1.7, (CI: 1-3) Grp2: Substantive hypo: 1.2, (CI: 0.4-3.4); Any: 7.9, (CI: 5.1–11.9)
Yamanouchi, 2005^50^ | RCT | Grp1: Metformin Fixed 750 mg Grp2: Glimepiride Varied Start: 1.0 mg, Max: 2.0 after 1 month in 8 cases. Rest on 1 mg | Grp1: Severe: 0 (0); Mild/moderate: 0 (0) Grp2: Severe: 0 (0); Mild/moderate: 1 (2.7)
Derosa, 2004^60^ | RCT | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Glimepiride Varied Start: 1 mg, Max: 4 mg | Grp1: 0 (0) Grp2: 0 (0) | | | | Def: Nausea + diarrhea Grp1: 2 (2.4) Grp2: NR
Garber, 2003^61^ | RCT | Grp1: Metformin Varied Start: 500 mg (adjusted to patient response), Max: 2000 mg Grp2: Glyburide Varied Start: 2.5 (adjusted to patient response), Max: 10 mg | Def: Mild or moderate Grp1: Symptomatic: 29 (17.7), Fingerstick: 1 (0.6) Grp2: Symptomatic: 98 (57.6), Fingerstick: 16 (10.6) | | | | Def: Abdominal pain; Nausea & Vomiting; Diarrhea Grp1: (6.1; 10.4; 18.3) Grp2: (4; 6.6; 5.3)
Blonde, 2002^63^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glyburide Fixed Start: 10 mg | Def: Mild or moderate, Fsg≤60mg/dl + symptomatic Grp1: 1 (<1) Grp2: 3 (1.8) | | | | Def: Dyspepsia and heartburn; Nausea + vomiting; Flatulence Grp1: (4.6); (12.4); (2) Grp2: (3); (5.5); (0)
Marre, 2002^64^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glibenclamide Varied Start: 5 mg, Max: 20 mg | Def: Symptoms or labs Grp1: Serious: 1 (1.0), Mild or moderate: 0 (0) Grp2: Serious: 1 (1.0), Mild or moderate: 7 (7)
Garber, 2002^65^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glyburide Varied Start: 2.5 mg, Max: 10mg | Def: Mild or moderate Grp1: 0 (0) Grp2: 10 (6) | | | | Def: Nausea + vomiting + diarrhea + dyspepsia Grp1: (43) Grp2: (24)
Charpentier, 2001^71^ | RCT | Grp1: Metformin Fixed Start: 850 mg tid Grp2: Glimepiride Fixed or Varied 1 mg (either fixed or increased stepwise to 2, 4, 6 mg od depending on clinical symptoms of hypoglycemia) | Def: Clinical symptoms Grp1: Serious: 0 (0), Mild or moderate: 8 (11) Grp2: Serious: 3 (2), Mild or moderate: 17 (11) | | | | Def: Diarrhea Grp1: (7) Grp2: (1)
DeFronzo, 1995^70^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2500 mg Grp2: Glyburide Varied Start: 10 mg, Max: 20 mg | Def: Mild or moderate Grp1: 4 (2) Grp2: 6 (3) | | | | Def: Nausea + diarrhea Grp1: (1.4) Grp2: (1)
Hermann, 1994^68^ | RCT | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Glyburide Varied Start: 3.5 mg, Max: 10.5 mg | Def: Serious Grp1: 8 (21) Grp2: 12 (35) | | | | Def: Nausea + diarrhea + dyspepsia and digestive Grp1: (63) Grp2: (32)
Maru, 2005^195^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea NR | | | Def: CHF/clinical diagnosis + validated a small sample via questionnaires to Grp to confirm the diagnosis + oxmis and read codes similar to ICD-9 codes Grp1: IR: 18.8/1000 person-years Grp2: IR: 26.6/1000 person-years
Nichols, 2005^196^ | Cohort | Grp1: Metformin NR Grp2: Sulfonylurea NR | | | Def: Medical record for CHF + ICD-9 code for CHF + clinical diagnosis + first record Grp1: IR: 10.5 (6.7–16.2) Grp2: IR: 13.8 (11.4-16.6)
Rajagopalan, 2005^206^ | Cohort | Grp1: Metformin NR Grp2: Any drug in SU class NR | | Def: ICD9 code liver failure or hepatitis Coll: Passive Timing: Unspecified ITT: NR Grp1: (0.8) Grp2: (1)
Kahn, 2008^213^ | RCT | Grp1: Metformin Varied, glucose: < 140 mg/dL Start dose: 500 mg, Max: 2 g Grp2: Glyburide Varied, glucose: < 140 mg/dL Start dose: 2.5 mg, Max: 15 mg | | | | Def: Fractures (NS) Coll: NR Timing: Unspecified ITT: Yes Grp1: 1.2/100 patient- years Grp2: 1.15/100 patient- years
Chien, 2007^59^ | RCT | Grp1: Metformin Varied, glucose: <140 mg/dL Start dose: 1000 mg, Max: 2000 mg, Mean: 1910 mg D: 4 wks Grp2: Glyburide Varied, glucose: <140 mg/dL Start dose: 10 mg, Max: 20 mg, Mean: 19 mg D: 4 wks | | | | Def: Right metacarpal bone fracture Coll: passive Timing: Unspecified ITT: Yes Grp1: 0 Grp2: 1 (6)
Amador- Licona, 2000^66^ | RCT | Grp1: Metformin Varied Start: 850 mg Grp2: Glibenclamide Varied Start: 5 mg | | | | | Def: Diarrhea + Diffuse abdominal pain Grp1: 4 (14.3) Grp2: NR
Goldstein, 2003^62^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glipizide Varied Start: 30 mg, Max: 30 mg | | | | | Def: Diarrhea Grp1: (17.3) Grp2: (13.1)
Metformin versus DPP-IV inhibitors
Aschner, 2010^77^ | RCT | Grp1: Metformin Varied, prespecified dose Start: 500 mg, Max: 2000 mg; Mean: 1903 mg D: 5 weeks Grp2: Sitagliptin Fixed Mean: 100 mg | Coll: Passive Timing: Unspecified ITT: No Grp1: Severe: 0 (0) Mild/moderate: 17 (3.3); 23 events Grp2: Severe: 2 (<1) Mild/moderate: 9 (1.7); 17 events | | | | Def: Combined GI events; Nausea; Diarrhea; Vomiting; Abdominal pain Coll: NR Timing: Unspecified ITT: No Grp1: (20.7, 3.1, 10.9, 1.3, 3.8) Grp2: (11.6, 1.1, 3.6, 0.4, 2.1)
Jadzinsky, 2009^78^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 1000 mg D: 1 week Grp2: Saxagliptin Fixed Mean: 10 mg | Coll: Active Timing: Unspecified ITT: Yes Grp1: Severe: 0 (0) Mild/moderate: 13 (4) Grp2: Severe: 0 (0) Mild/moderate: 5 (1) | | | | Def: Diarrhea Coll: Active Timing: Unspecified ITT: Yes Grp1: 24 (7) Grp2: 10 (3)
Williams- Herman, 2009^76^ | RCT | Grp1: Metformin Fixed Mean: 1000 mg or 2000 mg Grp2: Sitagliptin Fixed Mean: 100 mg | Def: Coll: Active Timing: Unspecified ITT: No Grp1: 2 (1) Grp2: 2 (1) | | | | Def: Nausea; Diarrhea; Abdominal pain; Vomiting; Nausea/ Vomiting Coll: NR Timing: Unspecified ITT: No Grp1: (3; 7; 4; 0; 20 for 1000 mg and 10; 12; 6; 3; 31 for 2000 mg) Grp2: (1; 4; 5; 1; 20)
Goldstein, 2007^75^ | RCT | Grp1: Metformin Varied, prespecified target Start: 500 mg, Max: 2000 mg Grp2: Sitagliptin Varied, prespecified target Start: 50 mg, Max: 100 mg | Grp1: 3 (2) Grp2: 1 (1)
Metformin versus meglitinides
Lund, 2007^197^ | RCT | Grp1: Metformin Varied, prespecified target Start: 500 mg, Max: 2000 mg, Mean: 1629 mg D: 12 days Grp2: Repaglinide Varied, prespecified target Start: 1 mg, Max: 6 mg, Mean: 4.72 mg D: 12 days | Coll: Active Timing: Specified ITT: Yes Grp1: Serious: 1 (1), Mild or moderate: 22 (23) Grp2: Serious: 1 (1), Mild or moderate: 45 (47) | | | | Def: NR Coll: Active Timing: Specified ITT: Yes Grp1: (65.7) Grp2: (42.7) | Def: Cancer Grp1: 2 (2) Grp2: 0 (0)
Horton, 2004^80^ | | Grp1: Metformin Fixed Start: 500 mg Grp2: Nateglinide Fixed Start: 120 qac | Def: Mild/ moderate, plasma glucose <2.8 mmol/l Coll: Active Timing: Specified ITT: Yes Grp1: 1 (1) Grp2: 2 (2) | | | | Def: Diarrhea Coll: Active Timing: Specified ITT: Yes Grp1: (20.2) Grp2: (3.8)
Moses, 1999^82^ | RCT | Grp1: Metformin NR Grp2: Repaglinide Fixed Start: 0.5 mg, Max: 4.0 mg D: 12-28 days | Def: Mild or moderate Coll: Passive Timing: Unspecified ITT: No Grp1: 1 (4) Grp2: 3 (11)
Derosa, 2003^81^ | RCT | Grp1: Metformin Varied Start: 500 mg bid, Max: 2500 mg D: 8 weeks Grp2: Repaglinide Varied Start: 0.5 mg bid, Max: 4 mg tid D: 8 weeks | Def: Mild or moderate Grp1: 0 (0) Grp2: 0 (0) | | | | Def: Nausea + diarrhea (withdrawn due to) Grp1: (3.6) Grp2: (0)
Horton, 2000^79^ | RCT | Grp1: Metformin Fixed Start: 500 mg Grp2: Nateglinide Fixed Start: 120 mg tid | Def: Mild or moderate Grp1: 19 (11) Grp2: 22 (12) | | | | Def: Nausea + diarrhea (withdrawn due to) Grp1: (3.4) Grp2: (0.6)
Metformin versus metformin + thiazolidinedione
Mancini, 2009^214^ | Cross- sectional | Grp1: Metformin Median: 1700 mg Grp2: Metformin + rosiglitazone Median: 1850 mg; Median: 8 mg | | | | Def: Vertebral fractures Coll: NR Timing: NA ITT: NA Grp1: ref Grp2: OR: 6.5 (CI: 1.3 to 38.1)
Perez, 2009^56^ | RCT | Grp1: Metformin Fixed Mean: 850 mg Grp2: Metformin + pioglitazone Fixed | | | | Def: Wrist fractures Coll: Active Timing: Specified ITT: NR Grp1: 1 (<1) Grp2: 1 (<1) | Def: Diarrhea Coll: Active Timing: Specified ITT: NR Grp1: (15.3) Grp2: (9)
Kawai, 2008^221^ | Non- randomized | Grp1: Metformin NR Start: 500–750 mg, Max: 750 mg Grp2: Metformin + pioglitazone NR; Fixed Start: 500–750 mg, Max: 750 mg; NR | Def: Mild, moderate and severe Coll: NR Timing: Unspecified ITT: No Grp1: 0 (0) Grp2: 0 (0)
Kaku, 2009^84^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 750 mg Grp2: Metformin + pioglitazone Varied Start: 500 mg, Max: 750 mg; Start: 15 mg, Max: 30 mg D: NR; 16 wks | Def: Mild or moderate Grp1: 0 (0) Grp2: 1 (1) | | | | Def: abdominal pain and constipation Grp1: (2.3) Grp2: (2.4)
Scott, 2008^85^ | RCT | Grp1: Metformin Fixed Start: >1500 mg D: 10 wks Grp2: Metformin + rosiglitazone Fixed Start: >1500 mg; Start: 8 mg, Mean: 8 mg D: 10 wks | Def: Mild or moderate Coll: NR Timing: Unspecified Grp1: 2 (2) Grp2: 1 (1) | | | | Def: Diarrhea, nausea, abdominal pain, vomiting Coll: NR Timing: Unspecified ITT: No Grp1: (9) Grp2: (7)
Rosenstock, 2006^49^ | RCT | Grp1: Metformin Varied, mean daily glucose ≤6.1 mmol/l Start: 500 mg, Max: 2000 mg, Mean: 1847 mg D: 32 wks Grp2: Metformin + rosiglitazone Varied, mean daily glucose ≤6.1 mmol/l Start: 500 mg, Max: 2000 mg, Mean: 1799 mg; Start: 2 mg, Max: 8 mg, Mean: 7.2 mg D: 32 wks | Def: Self reported mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 14 (9) Grp2: 19 (12) | | | | Def: Diarrhea, nausea, vomiting Dyspepsia Coll: Active Timing: Specified ITT: Yes Grp1: (51) Grp2: (47)
Stewart, 2006^156^ | RCT | Grp1: Metformin Varied, prespecified Start: 500 mg, Max: 3000 mg, Mean: 2627.9 mg D: 20 wks Grp2: Metformin + rosiglitazone Varied, prespecified Start: 500 mg, Max: 2000 mg, Mean: 1812.2 mg; Start: 4 mg, Max: 8 mg, Mean: 6.8 mg D: 18 wks; 16 wks | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 10 (4) Grp2: 17 (7) | | | | Def: Diarrhea Grp1: (18) Grp2: (8)
Jones, 2003^179^ | RCT | Grp1: Metformin Fixed Max: 2.5 g Grp2: Metformin + rosiglitazone Fixed; Varied, prespecified target Max: 2.5 g; Max: 8 mg | Def: Symptomatic hypoglycemia Grp1: All: (0.4), Obese: (1.7) Grp2: All: (2.1), Obese: (1.9)
Weissman, 2005^86^ | RCT | Grp1: Metformin Varied Start: 500 mg bid, Max: 1000 mg bid Grp2: Metformin + rosiglitazone Fixed Start: 2500 mg; Start: 12 mg | Def: Mild or moderate Grp1: 4 (1) Grp2: 4 (1) | | | | Def: Withdrawn due to GI Grp1: (6.8) Grp2: (3.1)
Bailey, 2005^87^ | RCT | Grp1: Metformin Varied Start: 2500 mg, Max: 3000 mg D: 24 wks Grp2: Metformin + rosiglitazone Fixed; Varied Start: 2000 mg; Start: 4 mg, Max: 8 mg D: 24 wks | Grp1: Serious: 0, Mild or moderate: 1 (<1) Grp2: Serious: 0, Mild or moderate: 3 (1) | | | | Def: diarrhea and abdominal pain Grp1: (5.4) Grp2: (3.2) | Def: acute cholecystitis, serious cholelithiasis and cholestatic jaundice Coll: Active Timing: Specified ITT: Yes Grp1: 1 (<1) Grp2: 0 (0)
Fonseca, 2000^90^ | RCT | Grp1: Metformin Fixed Start: 2500 mg Grp2: Metformin + rosiglitazone Fixed Start: 2500 mg; Start: 4–8 mg | Def: mild or moderate Grp1: 2 (2) Grp2: 5 (4)
Einhorn, 2000^89^ | RCT | Grp1: Metformin NR Grp2: Metformin + pioglitazone NR; Fixed NR; 30 mg | Grp1: 1 (0.6) Grp2: 1 (0.6)
Gomez-Perez, 2002^88^ | RCT | Grp1: Metformin Fixed Start: 2.5 g Grp2: Metformin + rosiglitazone Fixed Start: 2.5 g; Start: 2–4 mg bid | | | | | Def: Nausea + vomiting + diarrhea + flatulence and abdominal pain Grp1: (15.4) Grp2: (16.8)
Metformin versus metformin + sulfonylurea
Currie, 2009^212^ | Cohort | Grp1: Metformin NR Grp1: Metformin + sulfonylurea | | | | | | Def: Cancer Coll: Passive Timing: Unspecified ITT: NA Grp1: ref Grp2: HR: 1.8 (CI: 0.96 to 1.21)
Nauck, 2009^92^ | RCT | Grp1: Metformin Varied Start: 2000 mg, Max: 2000 mg Grp2: Metformin + glimepiride Varied; Fixed Start: 2000 mg, Max: 2000 mg; Start: 1 mg, Max: 4 mg D: NR; 3 wks | Def: Serious Coll: NR Timing: Unspecified ITT: NR Grp1: 0 (0) Grp2: 0 (0) | | | | Def: nausea, vomiting, and diarrhea Coll: NR Timing: NR ITT: NR Grp1: (17) Grp2: (17) | Def: acute pancreatitis Coll: NR Timing: Unspecified ITT: NR Grp1: 0 (0) Grp2: 1 (<1)
Feinglos, 2005^91^ | RCT | Grp1: Metformin Fixed Start: ≥1000 mg Grp2: Metformin + glipizide Fixed Start: ≥1000 mg; 2.5 mg | Def: FSG <60 mg/dl w/ symptoms or FSG <50 mg/dl w/o symptoms or FPG<55 mg/dl w/o symptoms Grp1: Serious: 0, Mild or moderate: 2 (3.3) Grp2: Serious: 0, Mild or moderate: 9 (14.8)
Garber, 2003^61^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 250 mg, Max: 1000 mg; Start: 1.25 mg, Max: 5 mg | Def: Mild or moderate Grp1: Symptomatic: 29 (17.7), Fingerstick: 1 (0.6) Grp2: Symptomatic: 59 (39.1), Fingerstick: 19 (11.2) | | | | Def: Abdominal pain; nausea + vomiting; Diarrhea Grp1: (6.1; 10.4; 18.3) Grp2: (4.1; 4.7; 7.6)
Tosi, 2003^36^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 3000 mg Grp2: Metformin + glibenclamide Varied Start: 500 mg, Max: 2000; Start: 2.5 mg, Max: 10mg | Grp1: Severe: 2 (10.5), Mild or moderate: 1 (5) Grp2: NR | | | | Def: Diarrhea + constipation + discomfort and abdominal pain and anorexia Grp1: (10.5) Grp2: (2.6)
Blonde, 2002^63^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 2000 mg; Start: 5 mg, Max: 20 mg | Def: FSG≤60mg/dl + symptomatic Grp1: Mild or moderate: 1 (<1) Grp2: Mild or moderate: 22 (6.8) | | | | Def: Dyspepsia and heartburn; Nausea + vomiting; Flatulence Grp1: (4.6; 12.4; 2) Grp2: (3.7; 6.8; 2.5)
Blonde, 2002^63^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 2000 mg; Start: 2.5 mg, Max: 10 mg | Def: FSG≤ 60mg/dl + symptomatic Grp1: Mild or moderate: 1 (<1) Grp2: Mild or moderate: 22 (6.8) | | | | Def: Dyspepsia and heartburn; Nausea + vomiting; Flatulence Grp1: (4.6; 12.4; 2) Grp2: (5; 10; 6.3)
Marre, 2002^64^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glibenclamide Varied Start: 500 mg, Max: 2000 mg; Start: 2.5 mg, Max: 10 mg | Def: Symptoms or labs Grp1: Serious: 1 (1.0), Mild or moderate: 0 Grp2: Serious: 0, Mild or moderate: 11 (10.9) | | | | Def: Not specified Grp1: (14.4) Grp2: (6.9)
Marre, 2002^64^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glibenclamide Varied Start: 500 mg, Max: 2000 mg; Start: 2.5 mg, Max: 10 mg | Def: Symptoms or labs Grp1: Serious: 1 (1.0), Mild or moderate: 0 Grp2: Serious: 2 (1.9), Mild or moderate: 12 (11.4)
Garber, 2002^65^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 250 mg; Start: 1.25 mg | Def: Mild or moderate Grp1: NR Grp2: 18 (11.4) | | | | Def: Nausea + vomiting + diarrhea + dyspepsia Grp1: IR − 43 Grp2: IR − 32
Garber, 2002^65^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 500 mg; Start: 2.5 mg | Def: Mild or moderate Grp1: NR Grp2: 61 (37.7) | | | | Def: Nausea + vomiting + diarrhea + dyspepsia Grp1: IR − 43 Grp2: IR − 38
Charpentier, 2001^71^ | RCT | Grp1: Metformin Fixed Start: 850 mg tid Grp2: Metformin + glimepiride Fixed Start: 850 mg tid; Start: 1 mg | Def: Clinical symptoms Grp1: Serious: 0 (0), Mild or moderate: 8 (11) Grp2: Serious: 2 (1.4), Mild or moderate: 30 (21) | | | | Def: diarrhea Grp1: (7) Grp2: (3)
DeFronzo, 1995^70^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2500 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 2500 mg; Start: 10 mg, Max: 20mg | Def: Mild or moderate Grp1: 4 (2) Grp2: 38 (18) | | | | Def: Nausea + diarrhea Grp1: (1.4) Grp2: (0.9)
Hermann, 1994^68^ | RCT | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 3000 mg; Start: 1.75 mg, Max: 14 mg | Def: Mild or moderate Grp1: 8 (21) Grp2: 24 (33)
Chien, 2007^59^ | RCT | Grp1: Metformin Varied, glucose: <140 mg/dL Start: 1000 mg, Max: 2000 mg, Mean: 1910 mg D: 4 wks Grp2: Metformin + glyburide Varied, glucose: <140 mg/dL Start: 1000 mg, Max: 2000 mg, Mean: 1680 mg; Start: 5 mg, Max: 10 mg, Mean: 8.4 mg D: 4 wks | Def: Mild or moderate Coll: Passive Timing: Unspecified ITT: Yes Grp1: 0 (0) Grp2: 0 (0) | | | Def: Right metacarpal bone fracture Coll: passive Timing: Unspecified ITT: Yes Grp1: 0 (0) Grp2: 0 (0) | Def: Diarrhea, dry mouth, increased appetite, GI disease Coll: Passive Timing: Unspecified ITT: NR Grp1: (32) Grp2: (13)
Nichols, 2005^196^ | Cohort | Grp1: Metformin NR Grp2: Metformin + unspecified sulfonylurea NR | | | Def: Medical record for CHF + ICD-9 code for CHF + clinical diagnosis + first record Grp1: IR: 10.5 (CI: 6.7–16.2) Grp2: IR: 13.4 (CI: 11.6–15.5)
Goldstein, 2003^62^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glipizide Varied Start: 500 mg, Max: 2000 mg; Start: 5 mg, Max: 20 mg | | | | | Def: Diarrhea Grp1: (17.3) Grp2: (13.1)
Metformin versus metformin + DPP-IV inhibitors
Jadzinsky, 2009^78^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 1000 mg D: 1 week Grp2: Metformin + saxagliptin Varied, prespecified dose Start: 500 mg, Max: 1000 mg; Start: 5 mg | Coll: Active Timing: Unspecified ITT: Yes Grp1: Severe: 0 (0) Mild/moderate: 13 (4) Grp2: Severe: 0 (0) Mild/moderate: 11 (3) | | | | Def: Diarrhea Coll: Active Timing: Unspecified ITT: Yes Grp1: 24 (7) Grp2: 22 (7)
Jadzinsky, 2009^78^ | RCT | Grp1: Metformin Varied Start: 500 mg, Max: 1000 mg D: 1 week Grp2: Metformin + saxagliptin Varied, prespecified dose Start: 500 mg, Max: 1000 mg; Start: 10 mg | Coll: Active Timing: Unspecified ITT: Yes Grp1: Severe: 0 (0) Mild/moderate: 13 (4) Grp2: Severe: 2 (1) Mild/moderate: 16 (5) | | | | Def: Diarrhea Coll: Active Timing: Unspecified ITT: Yes Grp1: 24 (7) Grp2: 31 (10)
DeFronzo, 2009^95^ | RCT | Grp1: Metformin Fixed Grp2: Metformin + saxagliptin Fixed NR; Mean: 10 mg | Grp1: Severe: 1 (1) Mild/moderate: 9 (5) Grp2: Severe: 1 (1) Mild/moderate: 7 (4) | | | | Def: Diarrhea Coll: Active Timing: Unspecified ITT: Yes Grp1: 20 (11) Grp2: 10 (6)
DeFronzo, 2009^95^ | RCT | Grp1: Metformin Fixed Grp2: Metformin + saxagliptin Fixed NR; Mean: 5 mg | Grp1: Severe: 1 (1) Mild/moderate: 9 (5) Grp2: Severe: 1 (1) Mild/moderate: 10 (5) | | | | Def: Diarrhea Coll: Active Timing: Unspecified ITT: Yes Grp1: 20 (11) Grp2: 11 (6)
DeFronzo, 2009^95^ | RCT | Grp1: Metformin Fixed Grp2: Metformin + saxagliptin Fixed NR; Mean: 2.5 mg | Grp1: Severe: 1 (1) Mild/moderate: 9 (5) Grp2: Severe: 1 (1) Mild/moderate: 15 (8) | | | | Def: Diarrhea Coll: Active Timing: Unspecified ITT: Yes Grp1: 20 (11) Grp2: 19 (10)
Williams- Herman, 2009^76^ | RCT | Grp1: Metformin Fixed Mean: 1000 mg bid Grp2: Metformin + sitagliptin Fixed Mean: 500 mg bid; Mean: 50 mg bid | Def: Mild or moderate Coll: Active Timing: Unspecified ITT: No Grp1: 2 (1) Grp2: 4 (2) | | | | Def: Nausea; vomiting; diarrhea; abdominal pain; Nausea/ Vomiting Coll: NR Timing: Unspecified ITT: No Grp1: (3; 0; 7; 4; 31) Grp2: (5; 2; 9; 3; 26)
Williams- Herman, 2009^76^ | RCT | Grp1: Metformin Fixed Mean: 1000 mg bid Grp2: Metformin + sitagliptin Fixed Mean: 1000 mg bid; Mean: 50 mg bid | Def: Mild or moderate Coll: Active Timing: Unspecified ITT: No Grp1: 2 (1) Grp2: 5 (3) | | | | Def: Nausea; vomiting; diarrhea; abdominal pain; Nausea/ Vomiting Coll: NR Timing: Unspecified ITT: No Grp1: (3; 0; 7; 4; 31) Grp2: (NR; 4; 13; 4; 29)
Scott, 2008^85^ | RCT | Grp1: Metformin Fixed Start: ≥1500 mg Grp2: Metformin + sitagliptin Fixed Start: ≥1500 mg; Start: 100 mg | Def: Mild or moderate Coll: NR Timing: Unspecified ITT: No Grp1: 2 (2) Grp2: 1 (1) | | | | Def: Diarrhea, nausea, abdominal pain, vomiting Coll: NR Timing: Unspecified ITT: No Grp1: (9) Grp2: (1)
Raz, 2008^93^ | RCT | Grp1: Metformin Fixed Start: ≥1500 mg Grp2: Metformin + sitagliptin Fixed Start: ≥ 1500 mg; Start: 100 mg | Def: Mild or moderate Coll: NR Timing: Unspecified ITT: No Grp1: 0 (0) Grp2: 1 (1) | | | Def: Limb fracture Coll: NR Timing: Unspecified ITT: No Grp1: 1 (1) Grp2: 0 (0) | Def: abdominal pain, nausea, vomiting, or diarrhea Coll: NR Timing: Unspecified ITT: No Grp1: (7.4) Grp2: (10.4) | Def: Neoplasms Coll: NR Timing: Unspecified ITT: No Grp1: 3 (3) Grp2: 0 (0)
Goldstein, 2007^75^ | RCT | Grp1: Metformin Fixed Start: 500 mg or 1000 mg bid Grp2: Metformin + sitagliptin Fixed Start: 500 mg or 1000 mg bid; Start: 50 mg bid | Def: Mild or moderate Grp1: 3 (2) Grp2: 6 (3)
Charbonnel, 2006^94^ | RCT | Grp1: Metformin Varied, HbA1c: 7 − 10% Start: ≥1500 mg D: 19 wks Grp2: Metformin + sitagliptin Varied; Fixed Start: ≥1500 mg; Mean: 100 mg D: 19 wks | Def: Mild or moderate Grp1: 5 (2.1) Grp2: 6 (1.3) | | | | Def: Abdominal pain, nausea, vomiting, or diarrhea Coll: NR Timing: Unspecified ITT: No Grp1: (10.5) Grp2: (11.9)
Metformin versus metformin + meglitinides
Horton, 2004^80^ | RCT | Grp1: Metformin Fixed Start: 500 mg tid Grp2: Metformin + nateglinide Fixed Start: 500 mg tid; Start: 120 mg ac | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: Symptomatic: 11 (0.6), Confirmed ≤2.8 mmol/l: 1 (1.0) Grp2: Symptomatic: 26 (29.2), Confirmed ≤ 2.8mmol/l: 3 (3.4) | | | | Def: Diarrhea Coll: Active Timing: Specified ITT: Yes Grp1: (20.2) Grp2: (16.9)
Marre, 2002^96^ | RCT | Grp1: Metformin Fixed Start: 1000 mg bid Grp2: Metformin + nateglinide Fixed Start: 1000 mg bid; Start: 60 mg ac | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: Symptomatic: 6 (3.9), Confirmed: 1 (0.7) Grp2: Symptomatic: 13 (8.4), Confirmed: 0
Marre, 2002^96^ | RCT | Grp1: Metformin Fixed Start: 1000 mg bid Grp2: Metformin + nateglinide Fixed Start: 1000 mg bid; Start: 120 mg ac | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: Symptomatic: 6 (3.9), Confirmed: 1 (0.7) Grp2: Symptomatic: 25 (15.6), Confirmed: 5 (3.1)
Moses, 1999^82^ | RCT | Grp1: Metformin NR Grp2: Metformin + repaglinide NR; Varied, glucose: 4.4–7.8 mmol/l NR; Start: 0.5 mg, Max: 4 mg | Def: Mild or moderate Coll: NR Timing: Unspecified ITT: NR Grp1: 0 Grp2: 9 (33.3)
Thiazolidinedione versus thiazolidinedione
Pantalone, 2009^174^ | Cohort | Grp1: Rosiglitazone NR Grp2: Pioglitazone NR | | | Def: ICD-9 codes Coll: NR Timing: NA ITT: NA Grp1: ref Grp2: HR: 1.19 (CI: 0.74 to 1.91)
Hsiao, 2009^173^ | Cohort | Grp1: Rosiglitazone NR Grp2: Pioglitazone NR | | | Def: ICD-9-CM diagnostic codes of hospitalization Coll: NR Timing: Unspecified ITT: NA Grp1: 67 (3.33) Grp2: 13 (2.66)
Juurlink, 2009^210^ | Cohort | Grp1: Rosiglitazone NR Grp2: Pioglitazone NR | | | Def: Congestive cardiac failure or heart failure hospitalization Coll: NR Timing: Unspecified ITT: NA Grp1: ref Grp2: HR: 0.77 (CI: 0.69 to 0.87)
Hussein, 2004^202^ | Cohort | Grp1: Rosiglitazone Fixed Start: 15–45 mg Grp2: Pioglitazone Fixed Start: 4–8 mg | Def: Mild or moderate Coll: Passive Timing: Unspecified Grp1: 11 (11) Grp2: 18 (17) Grp1-Grp2: p: NSG | | Def: Pulmonary edema Coll: Passive Timing: Unspecified ITT: NR Grp1: 3 (3) Grp2: 2 (2)
Rajagopalan, 2005^206^ | Cohort | Grp1: Rosiglitazone NR Grp2: Pioglitazone NR | | Def: ICD9 code liver failure or hepatitis Coll: Passive Timing: Unspecified ITT: NR Grp1: (0.4) Grp2: (0.5)
Thiazolidinedione versus sulfonylurea
Pantalone, 2009^174^ | Cohort | Grp1: Rosiglitazone NR Grp2: Sulfonylurea NR | | | Def: ICD-9 codes Coll: NR Timing: NA ITT: NA Grp1: HR: 0.88 (CI: 0.60 to 1.31) Grp2: ref
Pantalone, 2009^174^ | Cohort | Grp1: Pioglitazone NR Grp2: Sulfonylurea NR | | | Def: ICD-9 codes Coll: NR Timing: NA ITT: NA Grp1: HR: 1.05 (95% CI 0.77 to 1.43) Grp2: ref
Hsiao, 2009^173^ | Cohort | Grp1: Rosiglitazone NR Grp2: Sulfonylurea NR | | | Def: ICD-9-CM diagnostic codes of hospitalization Coll: NR Timing: Unspecified ITT: NA Grp1: 67 (3.33); Grp2: 1872 (1.97)
Hsiao, 2009^173^ | Cohort | Grp1: Pioglitazone NR Grp2: Sulfonylurea NR | | | Def: ICD-9-CM diagnostic codes of hospitalization Coll: NR Timing: Unspecified ITT: NA Grp1: 13 (2.66) Grp2: 1872 (1.97)
Dormuth, 2009^215^ | Cohort | Grp1: Thiazolidinedione NR Grp2: Sulfonylurea NR | | | | Def: Hip fractures Coll: Passive Timing: Unspecified ITT: NA Grp1: HR: 1.28 (CI: 1.12 to 1.45) Grp2: ref
Tolman, 2009^150^ | RCT | Grp1: Pioglitazone Varied, HbA1c < 7.5% Max: 45 mg Grp2: Glibenclamide Max: 15 mg | Coll: Active Timing: Specified ITT: Yes Grp1: 40 (4) Grp2: 119 (11) | Def: ALT > 3x ULN with repeat confirmation Coll: Active Timing: Specified ITT: Yes Grp1: 0 (0) Grp2: 4 (<1) | Coll: Active Timing: Specified ITT: Yes Grp1: 12 (1) Grp2: 11 (1) | | Def: Diarrhea Coll: Active Timing: Specified ITT: Yes Grp1: 93 (9) Grp2: 80 (8) | Def: Cholecystitis Coll: Active Timing: Specified ITT: Yes Grp1: 4 (<1) Grp2: 4 (<1)
Jain, 2006^101^ | RCT | Grp1: Pioglitazone Varied, glucose: FPG (69–141 mg/dl) Start: 15 mg, Max: 45 mg, Median: 45 mg Grp2: Glyburide Varied, glucose: FPG: 69–141 mg/dl Start: 5 mg, Max: 15 mg, Median: 10 mg | Def: Mild or moderate Coll: Active Timing: Unspecified ITT: Yes Grp1: 11 (4.4) Grp2: 61 (24.3) | | | Def: Ankle Coll: Active Timing: No ITT: Yes Grp1: (0) Grp2: (0.8) | Def: diarrhea Coll: active Timing: Unspecified ITT: Yes Grp1: (6) Grp2: (6.4) | Def: stage IV colon ca Coll: active Timing: Unspecified ITT: Yes Grp1: 0 (0) Grp2: 2 (0.8)
Yamanouchi, 2005^50^ | RCT | Grp1: Pioglitazone Fixed Start: 30 mg for women and 45 mg for men Grp2: Glimepiride Varied Start: 1.0 mg, Max: 2.0 | Grp1: Serious: 0 (0), Mild or moderate: 0 (0) Grp2: Serious: 0 (0), Mild or moderate: 1 (2.7)
Tan, 2004^106^ | RCT | Grp1: Pioglitazone Varied Start: 30 mg, Max: 45 mg Grp2: Glibenclamide Varied Start: 1.75 mg, Max: 10.5 mg | Def: Symptoms or SMBG < 50 mg/dl Grp1: 4 (4) Grp2: 32 (29)
Hanefeld, 2007^100^ | RCT | Grp1: Rosiglitazone Fixed Start: 4 mg Grp2: Glibenclamide Varied Start: 2.5 mg, Max: 15 mg | Coll: NR Timing: Unspecified ITT: Yes Grp1: 1 (0.5) Grp2: Serious: 2 (<1), Mild or moderate: 23 (11) | | | | Def: Unspecified Coll: NR Timing: Unspecified ITT: Yes Grp1: 11 (5.5) Grp2: 7 (3.4)
Hanefeld, 2007^100^ | RCT | Grp1: Rosiglitazone Fixed Start: 8 mg Grp2: Glibenclamide Varied Start: 2.5 mg, Max: 15 mg D: 12 wks | Coll: NR Timing: Unspecified ITT: Yes Grp1: 3 (1.6) Grp2: Serious: 2 (<1), Mild or moderate: 23 (11) | | | | Def: Unspecified Coll: NR Timing: Unspecified ITT: Yes Grp1: 5 (2.6) Grp2: 7 (3.4)
St John Sutton, 2002^149^ | RCT | Grp1: Rosiglitazone Fixed Start: 4 mg Grp2: Glyburide Varied Start: NR, Max: 20 mg D: 8 weeks | Def: Signs and symptoms Grp1: (1.9) Grp2: (7.1) | | Def: NR Grp1: 1 (1.0) Grp2: 0 (0)
Asche, 2008^200^ | Cohort | Grp1: Thiazolidinedione NR Grp2: Any in the Sulfonylurea class NR | Def: Mild or moderate Coll: NR Timing: Unspecified ITT: NR Grp1: 12 (1.7) Grp2: 55 (2.6) | | Coll: NR Timing: Unspecified ITT: NR Grp1: 18 (2.6) Grp2: NR
Kahn, 2006^38^ | RCT | Grp1: Rosiglitazone Varied, glucose: <140 mg/dl Start: 4 mg, Max: 8 mg Grp2: Glyburide Varied, glucose: <140 mg/dl Start: 2.5 mg, Max: 15 mg | Def: Self reported events Coll: NR Timing: Unspecified ITT: Yes Grp1: Serious events: 1 (0.1), Mild or moderate events: 142 (9.8) Grp2: Serious events: 8 (0.6), Mild or moderate events: 557 (38.7) | | Def: Investigator reported events Coll: NR Timing: Unspecified ITT: Yes Grp1: All: 22 (1.5), Serious: 12 (0.8) Grp2: All: 9 (0.6), Serious: 3 (0.2), p: ≤ 0.05 | | Def: Nausea, vomiting, diarrhea, abdominal discomfort Grp1: (23) Grp2: (21.9)
Agarwal, 2005^184^ | RCT | Grp1: Pioglitazone Varied, glucose: 140 mg/dL, HbA1c: 8% Start: 15 mg D: 16 wks Grp2: Glipizide Varied, glucose: 140 mg/dL, HbA1c: 8% Start: 5 mg D: 16 wks | Grp1: 2 events Grp2: 3 events | | Grp1: 2 (2) Grp2: 2 (2)
Karter, 2005^207^ | Cohort | Grp1: Pioglitazone NR Grp2: Any sulfonylurea NR | | | Def: ICD-9-CM codes for primary discharge diagnosis Coll: Passive Timing: Unspecified ITT: NR Grp1: HR: 1.28 (CI: 0.85–1.92), p: 0.2 Grp2: ref
Rajagopalan, 2005^206^ | Cohort | Grp1: Rosiglitazone NR Grp2: Sulfonylurea NR | | Def: ICD9 code liver failure or hepatitis Coll: Passive Timing: Unspecified ITT: NR Grp1: (0.4) Grp2: (1)
Rajagopalan, 2005^206^ | Cohort | Grp1: Pioglitazone NR Grp2: Sulfonylurea NR | | Def: visit with ICD9 code liver failure or hepatitis Coll: Passive Timing: Unspecified ITT: NR Grp1: (0.5) Grp2: (1)
Thiazolidinedione versus meglitinides
Jovanovic, 2004^110^ | RCT | Grp1: Pioglitazone Fixed Start: 30 mg Grp2: Repaglinide Varied Start: 0.5 mg if HbA1c<8% or 1 mg if HbA1c >8%, Max: 4 mg per meal D: 12 weeks | Def: Severe: needed assistance, Mild or moderate: <50mg/dl Grp1: Severe: 0, Mild or moderate: 2 (3) Grp2: Severe: 0, Mild or moderate: 5 (8) | | | | Def: Diarrhea Grp1: (3) Grp2: (5)
Raskin, 2004^109^ | RCT | Grp1: Rosiglitazone Varied Start: 2 mg bid, Max: 4 mg bid D: 12 weeks Grp2: Repaglinide Varied Start: 0.5 mg per meal if HbA1c≤8% or 1 mg if >8%, Max: 4 mg per meal D: 12 weeks | Grp1: Severe: 0, Mild or moderate: 1 (2) Grp2: Severe: 0, Mild or moderate: 4 (6)
Kahn, 2008^213^ | RCT | Grp1: Rosiglitazone Varied, glucose: <140 mg/dL Start dose: 4 mg, Max: 8 mg Grp2: Glyburide Varied, glucose: <140 mg/dL Start dose: 2.5 mg, Max: 15 mg | | | | Def: Fractures (NS) Coll: NR Timing: Unspecified ITT: Yes Grp1: 1.86/100 patient- years HR: 1.61 (CI: 1.14–2.28), p: 0.0069 Grp2: 1.15/100 patient- years
Sulfonylurea versus DPP-IV inhibitors
Scott, 2007^111^ | RCT | Grp1: Glipizide Varied, glucose: <160 mg/dl Start: 5 mg, Max: 20 mg D: 6 wks Grp2: Sitagliptin Fixed Start: 5 mg bid to 50 mg bid | Def: Mild or moderate Grp1: 21 (17.1) Grp2: 0 (0)
Sulfonylurea versus meglitinides
Jibran, 2006^112^ | RCT | Grp1: Glibenclamide Varied, FPG < 130 mg/dl, PPG < 175 mg/dl Start: 5 mg, Max: 15 mg Grp2: Repaglinide Varied, FPG < 130 mg/dl, PPG < 175 mg/dl Start: 0.5 mg TDS, Max: 1.5 mg TDS | Def: Mild, moderate or severe Grp1: 0 (0) Grp2: 0 (0)
Vakkilainen, 2002^119^ | RCT | Grp1: Glibenclamide Varied Start: 5 mg, Max: 10 mg Grp2: Nateglinide Fixed Start: 120 mg tid | Grp1: 3 (12.5) Grp2: 0 (0)
Madsbad, 2001^114^ | RCT | Grp1: Glipizide Varied Start: 5 mg, Max: 15 mg Grp2: Repaglinide Varied Start: 0.5 mg, Max: 4.0 mg tid | Def: Severe Grp1: 0 (0) Grp2: 0 (0)
Landgraf, 1999^115^ | RCT | Grp1: Glibenclamide Varied Max: 10.5 mg Grp2: Repaglinide Varied Max: 4.0 mg tid | Def: Mild or moderate Grp1: 9 (9.0) Grp2: 9 (9.6)
Marbury, 1999^117^ | RCT | Grp1: Glyburide Varied Start: 2.5 mg, Max: 15mg Grp2: Repaglinide Varied Start: 0.5 mg, Max: 12 mg | Grp1: Severe: 2 (1), Mild or moderate: 35 (18) Grp2: Severe: 5 (1), Mild or moderate: 54 (14)
Wolffenbuttel, 1999^116^ | RCT | Grp1: Glyburide Varied Start: 1.75 mg, Max: 10.5 mg D: 6–8 weeks Grp2: Repaglinide Varied Start: 1.5 mg, Max: 12.0 mg D: 6–8 weeks | Def: Mild or moderate Grp1: 13 (9) Grp2: 26 (9)
Wolffenbuttel, 1993^118^ | RCT | Grp1: Glibenclamide Varied Start: 5 mg, Max: 15 mg Grp2: Repaglinide Varied Start: 0.5 mg, Max: 4 mg tid | Grp1: Severe: 0 (0), Mild or moderate: 1 (7) Grp2: Severe: 0 (0), Mild or moderate: 0 (0)
Sulfonylurea versus GLP-1 agonists
Seino, 2010^121^ | RCT | Grp1: Glibenclamide Varied, prespecified dose Start: 1.25 mg; Max: 2.5 mg D: 4 weeks Grp2: Liraglutide Varied, prespecified dose Start: 0.3 mg; Max: 0.9 mg D: 2 weeks | Coll: Passive Timing: Unspecified ITT: No Grp1: Symptoms: 45 (34.1); 228 events; IR: 3.927/year Severe: 0 (0) Grp2: Symptoms: 36 (13.4) 61 events; IR: 0.525/year Severe: 0 (0) | | | | Def: Diarrhea; Constipation Coll: NR Timing: Unspecified ITT: No Grp1: (3.8; 3.8) Grp2: (6.3; 5.6) | Def: Pancreatitis Coll: NR Timing: Unspecified ITT: No Grp1: 0 (0) Grp2: 0 (0)
Garber, 2009^122^ | RCT | Grp1: Glimepiride Varied, prespecified dose Start: 2 mg, Max: 8 mg D: 2 weeks Grp2: Liraglutide Varied, prespecified dose Start: 0.6 mg, Max 1.8 mg D: 2 weeks | Def: Not requiring assistance, PG < 3.1 mmol/L Coll: NR Timing: Unspecified ITT: No Grp1: 24 events Grp2: 8 events | | | | Def: Total GI events; Nausea and vomiting Coll: Passive Timing: Unspecified ITT: No Grp1: (26, 51) Grp2: (12, 38) | Def: Pancreatitis Coll: Passive Timing: Unspecified ITT: No Grp1: 0 (0) Grp2: 1 (<1)
Garber, 2009^122^ | RCT | Grp1: Glimepiride Varied, prespecified dose Start: 2 mg, Max: 8 mg D: 2 weeks Grp2: Liraglutide Varied, prespecified dose Start: 0.6 mg, Max 1.2 mg D: 2 weeks | Def: Not requiring assistance, PG < 3.1 mmol/L Coll: NR Timing: Unspecified ITT: No Grp1: 24 events Grp2: 12 events | | | | Def: Total GI events; Nausea and vomiting Coll: Passive Timing: Unspecified ITT: No Grp1: (26, 49) Grp2: (12, 39) | Def: Pancreatitis Coll: Passive Timing: Unspecified ITT: No Grp1: 0 (0) Grp2: 1 (<1)
Madsbad, 2004^120^ | RCT | Grp1: Glimepiride Varied, FPG < 7 mmol/L Start: 1 mg; Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.75 mg | Def: Glucose < 2.8 mmol/L Coll: Active Timing: Specified ITT: Yes Grp1: 4 (15) Grp2: 0 (0)
Madsbad, 2004^120^ | RCT | Grp1: Glimepiride Varied, FPG < 7 mmol/L Start: 1 mg; Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.60 mg | Def: Glucose < 2.8 mmol/L Coll: Active Timing: Specified ITT: Yes Grp1: 4 (15) Grp2: 1 (3)
Madsbad, 2004^120^ | RCT | Grp1: Glimepiride Varied, FPG < 7 mmol/L Start: 1 mg; Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.45 mg | Def: Glucose < 2.8 mmol/L Coll: Active Timing: Specified ITT: Yes Grp1: 4 (15) Grp2: 0 (0)
Madsbad, 2004^120^ | RCT | Grp1: Glimepiride Varied, FPG < 7 mmol/L Start: 1 mg; Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.225 mg | Def: Glucose < 2.8 mmol/L Coll: Active Timing: Specified ITT: Yes Grp1: 4 (15) Grp2: 0 (0)
Madsbad, 2004^120^ | RCT | Grp1: Glimepiride Varied, FPG < 7 mmol/L Start: 1 mg; Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.045 mg | Def: Glucose < 2.8 mmol/L Coll: Active Timing: Specified ITT: Yes Grp1: 4 (15) Grp2: 0 (0)
Metformin + thiazolidinedione versus metformin + sulfonylurea
Hamann, 2008^123^ | RCT | Grp1: Metformin + rosiglitazone Varied, glucose: 6.1 mmol/l Max: 2 g; Start: 4 mg, Max: 8 mg D: 12 wks Grp2: Metformin + sulfonylurea Varied, glucose: 6.1 mmol/l Max: 2 g; Start: 5 mg, Max: 15 mg D: 12 wks | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 18 (6) Grp2: 90 (30) | | | | Coll: Active Timing: Specified ITT: Yes Grp1: (13) Grp2: (18)
Comaschi, 2007^129^ | RCT | Grp1: Metformin + pioglitazone Varied Max: 3 g; Start: 15 mg, Max: 30 mg D: NR, 22 wks Grp2: Metformin + sulfonylurea Varied, HbA1c: 7.50% Start: 400 mg, Max: 3 g; Start: 2.5 mg D: 22 wks | Def: Mild or moderate Grp1: 0 (0) Grp2: 1 (1)
Bakris, 2006^125^ | RCT | Grp1: Metformin + rosiglitazone Varied, glucose: ≤6.6 mmol/L Unclear; Start: 4 mg D: 3 wks Grp2: Metformin + glyburide Varied, glucose:≤ 6.6 mmol/L Unclear; Start: 5 mg D: 3 wks | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 2 (1) Grp2: 22 (12)
Umpierrez, 2006^126^ | RCT | Grp1: Metformin + pioglitazone Varied, glucose: <120 mg/dl, HbA1c: <8.0% Start: 1.54 g, Max: 1.57 g; Start: 30 mg, Max: 45 mg Grp2: Metformin + glimepiride Varied, glucose: <120 mg/dL Start: 1.47 g, Max: 1.49 g; Start: 2 mg, Max: 8 mg D: NR, 6 wks | Def: mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 10 (9) Grp2: 32 (33) | | | | Def: Diarrhea Coll: Active Timing: Specified ITT: Yes Grp1: (4.7) Grp2: (6)
Garber, 2006^128^ | RCT | Grp1: Metformin + rosiglitazone Varied Start: 1500 or 2000 mg, Max: 2000 mg; Start: 4 mg, Max: 8 Grp2: Metformin + glibenclamide Varied Start: 1000 mg, Max: 2000; Start: 5 mg, Max: 10 mg | Grp1: Severe: 0 (0), Mild or moderate: 2 (1) Grp2: Severe: 7 (4), Mild or moderate: 53 (33) | | | | Def: Diarrhea + abdominal pain + other GI symptoms; Diarrhea; Abdominal pain Grp1: (10; 3; 4) Grp2: (11; 6; 6)
Hanefeld, 2006^201^ | RCT | Grp1: Metformin + pioglitazone Fixed; Varied Mean: 1900 mg; Start: 30 mg, Max: 45 mg Grp2: Metformin + glibenclamide NR; Varied Mean: 1900 mg; Start: 3.5 mg, Max: 5 mg | Def: Severe Coll: NR Timing: Unspecified ITT: NR Grp1: 5 (2) Grp2: 34 (14)
Yang, 2003^139^ | RCT | Grp1: Metformin + sulfonylurea Fixed Grp2: Rosiglitazone + sulfonylurea Fixed | | Def: AST or ALT 3 x ULN Coll: NR Timing: Unspecified ITT: NR Grp1: 0 (0) Grp2: 0 (0)
Derosa, 2005^159^ | RCT | Grp1: Metformin + rosiglitazone Fixed Start: 1500 mg; Start: 4 mg Grp2: Metformin + glimepiride Fixed Start: 1500 mg; Start: 2 mg | | | | | Def: Transient flatulence Grp1: (4.2) Grp2: (2.1)
Metformin + thiazolidinedione versus metformin + meglitinides
Raskin, 2009^131^ | RCT | Grp1: Metformin + rosiglitazone Varied, prespecified target dose Start: 1000 mg, Max: 2500 mg; Start: 4, Max: 8 mg D: 4 wks Grp2: Metformin + repaglinide Varied Start: 1000 mg, Max: 2500 mg; Start: 4 mg, Max: 10 mg D: 4 wks | Coll: Active Timing: Specified ITT: NR Grp1: Severe: 0 (0), Mild or moderate: 1 (1) Grp2: Severe: 0 (0), Mild or moderate: 8 (4) | | | | | Def: Macular edema Grp1: 2 (1) Grp2: 0 (0)
Metformin + thiazolidinedione versus metformin + DPP-IV inhibitors
Scott, 2008^85^ | RCT | Grp1: Metformin + rosiglitazone Fixed Start: > 1500 mg; Mean: 8 mg D: 10 wks Grp2: Metformin + sitagliptin Fixed Start: > 1500 mg; Mean: 100 mg D: 10 wks | Def: Mild or moderate Coll: NR Timing: Unspecified ITT: No Grp1: 1 (1) Grp2: 1 (1) | | | | Def: Diarrhea, nausea, abdominal pain, vomiting Coll: NR Timing: Unspecified ITT: No Grp1: (7) Grp2: (1)
Metformin + thiazolidinedione versus metformin + GLP-1 agonists
Defronzo, 2010^132^ | RCT | Grp1: Metformin + rosiglitazone Varied, prespecified dose NR: Start: 4 mg; Max: 8 mg Grp2: Metformin + exenatide Varied, prespecified dose NR: Start: 0.010 mg; Max: 0.02 mg BID D: 2 months | Coll: NR Timing: Unspecified ITT: No Grp1: Severe: 0 (0); Mild/moderate: 0 (0) Grp2: Severe: 0 (0); Mild/moderate: 2 (4) | | | | Def: Vomiting; Diarrhea Coll: NR Timing: Unspecified ITT: No Grp1: (0; 9) Grp2: (49; 16)
Metformin + thiazolidinedione versus thiazolidinedione + sulfonylurea
Comaschi, 2007^129^ | RCT | Grp1: Metformin + pioglitazone Varied Max: 3 g; Start: 15 mg, Max: 30 mg D: NR; 22 wks Grp2: Pioglitazone + sulfonylurea Varied, HbA1c: 7.50% Start: 15 mg, Max: 30 mg; Unclear D: 22 wks; NR | Def: Mild or moderate Grp1: 0 (0) Grp2: 0 (0)
Rosak, 2006^183^ | Cohort | Grp1: Metformin + rosiglitazone NR Unclear; Start: 4mg, Max: 8mg Grp2: Rosiglitazone + sulfonylurea Varied Start: 4mg, Max: 8mg; NR | Def: Hypoglycemic events Coll: Active Timing: Specified ITT: Yes Grp1: 0.05/100 patient-years Grp2: 0.47/100 patient-years | | Def: Investigator reported Coll: Active Timing: Specified ITT: Yes Grp1: 0.13/100 patient-years Grp2: 0.47/100 patient-years
Derosa, 2005^127^ | RCT | Grp1: Metformin + rosiglitazone Fixed Start dose: 500 mg tid, Max: 500 mg tid; Start dose: 4mg, Max: 4 mg Grp2: Metformin + glimepiride Fixed Start dose: 500 mg tid, Max: 500 mg tid; Start dose: 2 mg, Max: 2 mg | | Def: Transiently elevated LFT to 1.5 times upper limit of normal Coll: NR Timing: Unspecified ITT: NR Grp1: 3 events out of 48 participants Grp2: NR
Metformin + sulfonylurea versus metformin + meglitinides
Dimic, 2009^199^ | Non- randomized trial | Grp1: Metformin + glimepiride Fixed NR Grp2: Metformin + repaglinide Fixed Mean: 2000 mg; Mean: 6 mg | Coll: Active Timing: Specified ITT: NR Grp1: 7 (23) Grp2: 5 (17)
Schwarz, 2008^152^ | RCT | Grp1: Metformin + glyburide Varied, glucose: <120 mg/dL Start: 500 mg, Max: 2000 mg; Start: 1.25 mg, Max: 10 mg D: 12 wks Grp2: Metformin + nateglinide Varied, glucose: <120 mg/dL Start: 500 mg, Max: 2000 mg; Start: 360 mg, Max: 360 mg D: 12 wks | Def: Severe Coll: Active Timing: Specified ITT: Yes Grp1: 1 (3) Grp2: 0 (0) | | | | Def: Diarrhea Coll: Active Timing: Specified ITT: Yes Grp1: (20) Grp2: (22.9)
Gerich, 2005^136^ | RCT | Grp1: Metformin + glyburide Varied, glucose: FPG≥6.7 mmol/L Start: 500 mg, Max: 2000 mg, Mean: 1105 mg; Start: 1.25 mg, Max: 10 mg, Mean: 5.1 mg D: 12 wks Grp2: Metformin + nateglinide Varied, glucose: FPG≥6.7 mmol/L; Fixed Start: 500 mg, Max: 2000 mg, Mean: 1459 mg; Start: 120 mg, Mean: 357 mg D: 12 wks | Def: Severe Coll: NR Timing: Unspecified ITT: Yes Grp1: Mild or moderate:38 (18); Severe: 2 (1) Grp2: Mild or moderate:18 (8); Severe: 0 (0)
Metformin + sulfonylurea versus metformin + DPP-IV inhibitors
Seck, 2010^134^ | RCT | Grp1: Metformin + sitagliptin Fixed NR Grp2: Metformin + glipizide Fixed; Varied NR; Start: 5 mg, Max: 20 mg; Mean: 9.2 mg | Coll: Active Timing: Specified ITT: Yes Grp1: Severe: 18 (3) Mild/moderate: 31 (5.3) Grp2: Severe: 2 (<1) Mild/moderate: 199 (34.1)
Nauck, 2007^133^ | RCT | Grp1: Metformin + glipizide Varied; Varied, glucose: <6.1 mmol/l NR; Start: 5 mg, Max: 20 mg D: NR, 18 wks Grp2: Metformin + sitagliptin Varied; Fixed NR | Def: Severe Coll: Active Timing: Specified ITT: Yes Grp1: 7 (1) Grp2: 1 (<1) | | | | Def: Diarrhea, abdominal pains, nausea, vomiting Coll: Active Timing: Specified ITT: Yes Grp1: 69 (12) Grp2: 70 (12)
Metformin + sulfonylurea versus metformin + GLP-1 agonists
Derosa, 2010^44^ | RCT | Grp1: Metformin + glibenclamide NR Mean: 1500 mg; Start: 7.5 mg; Max: 15 mg Grp2: Metformin + exenatide NR NR; Start: 10 mcg; Max: 20 mcg | Def: FPG < 60 mg/dL Coll: Active Timing: Specified ITT: No Grp1: 3 (5) Grp2: 0 (0) | | | | Def: Vomiting; Diarrhea Coll: Active Timing: Specified ITT: No Grp1: (2; 2) Grp2: (2; 3)
Nauck, 2009^92^ | RCT | Grp1: Metformin + glimepiride Fixed; Varied Mean: 2000 mg; Start: 1 mg; Max: 4 mg Grp2: Metformin + liraglutide Fixed; Varied Start: 0.6 mg; Max: 1.8 mg | Coll: Passive Timing: Unspecified ITT: Yes Grp1: Severe: 0 (0) Mild/moderate: (17) Grp2: Grp1: Severe: 0 (0) Mild/moderate: (3) | | | | Def: Nausea, vomiting, and diarrhea Coll: Passive Timing: Unspecified ITT: Yes Grp1: (17) Grp2: (44)
Nauck, 2009^92^ | RCT | Grp1: Metformin + glimepiride Fixed; Varied Mean: 2000 mg; Start: 1 mg; Max: 4 mg Grp2: Metformin + liraglutide Fixed; Varied Start: 0.6 mg; Max: 1.2 mg | Coll: Passive Timing: Unspecified ITT: Yes Grp1: Severe: 0 (0) Mild/moderate: (17) Grp2: Grp1: Severe: 0 (0) Mild/moderate: (3) | | | | Def: Nausea, vomiting, and diarrhea Coll: Passive Timing: Unspecified ITT: Yes Grp1: (17) Grp2: (40)
Metformin + sulfonylurea versus metformin + premixed insulin
Malone, 2003^137^ | RCT | Grp1: Metformin + glibenclamide Varied, glucose: fasting and pre-meal <7mmol.L, 2-hour post-prandial <10mmol/L Max: 2550 mg, Mean: 1968 mg; Mean: 14.2 mg D: 4 wks Grp2: Metformin + lispro 75/25 fasting and pre-meal <7mmol.L, 2-hour post-prandial <10mmol/L Max: 2550 mg; Mean: 0.19U/kg in am and 0.14 U/kg in evening D: 4 wks | Def: Symptomatic or BG <3.5mmol/l Timing: Unspecified ITT: NR Grp1: (1) Grp2: (1.3)
Kvapil, 2006^138^ | RCT | Grp1: Metformin + glibenclamide Fixed; Varied Mean: 1660 mg; Start: 1.75 mg, Max: 10.5 mg, Mean: 6.58 mg Grp2: Metformin + aspart 70/30 Fixed; Varied, glucose: 5 – 8 mmol/L Mean: 1660 mg; Start: 0.2 U/kg bid, Mean: 0.30 U/kg bid | Coll: NR Timing: Unspecified ITT: Yes Grp1: Severe: 0, Mild or moderate: 9 (8) Grp2: Severe: 0, Mild or moderate: 13 (12)
Metformin + sulfonylurea versus thiazolidinedione + sulfonylurea
van der Meer, 2009^141^ | RCT | Grp1: Metformin + glimepiride Fixed; Varied Start: 1000 mg, Max: 2000 mg; NR D: NR; 8 wks Grp2: Pioglitazone + glimepiride Fixed, Varied Start: 15 mg, Max: 30 mg; NR D: 2 wks; NR | | | Grp1: 0 (0) Grp2: 0 (0)
Seufert, 2008^142^ | RCT | Grp1: Metformin + sulfonylurea Fixed Max: 2550 mg, Mean: 2081 mg; NR D: 12 wks Grp2: Pioglitazone + sulfonylurea Fixed Max: 45 mg, Mean: 37 mg; NR D: 12 wks | Coll: NR Timing: Unspecified ITT: NR Grp1: 50 (22) Grp2: 36 (17) | | | | Def: Diarrhea Coll: NR Timing: Unspecified ITT: NR Grp1: (14.4) Grp2: (3.4)
Hanefeld, 2004^140^ | RCT | Grp1: Metformin + sulfonylurea Varied; Fixed Start: 850 mg, Max: 2550 mg; NR D: 12 wks Grp2: Pioglitazone + sulfonylurea Varied; Fixed Start: 15 mg (, Max: 45 mg; NR D: 12 wks | Def: Serious Grp1: 0 (0) Grp2: 0 (0) | | | | Def: Diarrhea Grp1: (12.2) Grp2: (23.4)
Yang, 2003^139^ | RCT | Grp1: Metformin + sulfonylurea Fixed Start: 1000 mg; NR Grp2: Rosiglitazone + sulfonylurea Fixed Start: 4mg; NR | | | | | Def: Diarrhea Grp1: NR Grp2: 2 cases
Metformin + DPP-IV inhibitor versus metformin + GLP-1 agonist
Pratley, 2010^143^ | RCT | Grp1: Metformin + sitagliptin Varied, HbA1c : 7.5% – 10% NS; Max: 100 mg Grp2: Metformin + liraglutide Varied, HbA1c: 7.5% – 10% NS; Start: 0.6 mg Max: 1.2 mg | | | | | Def: GI events Coll: NR Timing: Unspecified ITT: No Grp1: 4 (2) Grp2: 3 (1) | Def: Neoplasm Coll: NR Timing: Unspecified ITT: No Grp1: 1 (<1) Grp2: 0 (0) Def: Pancreatitis Grp1: 0 (0) Grp2: 0 (0)
Pratley, 2010^143^ | RCT | Grp1: Metformin + sitagliptin Varied, HbA1c : 7.5% – 10% NS; Max: 100 mg Grp2: Metformin + liraglutide Varied, HbA1c: 7.5% – 10% NS; Start: 0.6 mg Max: 1.8 mg | | | | | Def: GI events Coll: NR Timing: Unspecified ITT: No Grp1: 4 (2) Grp2: 3 (1) | Def: Neoplasm Coll: NR Timing: Unspecified ITT: No Grp1: 1 (<1) Grp2: 1 (<1) Def: Pancreatitis Grp1: 0 (0) Grp2: 0 (0)
Metformin + GLP-1 agonist versus metformin + basal insulin
Bunck, 2009^144^ | RCT | Grp1: Metformin + exenatide Fixed; Varied, HbA1c: 7.1%–7.5% Mean: 2058 mg; Start: 5 ug bid, 20 ug tid Grp2: Metformin + glargine Fixed; Varied, SMBG: 4.5–5.5 mmol/L Mean: 1798 mg; Start: 10 U, Mean: 33.6 U qd | Def: <3.3mmol/L Coll: Active Timing: Unspecified ITT: NR Grp1: (8.3) Grp2: (24.2) | | | | Def: Mild to moderate nausea, vomiting, diarrhea Grp1: NR Grp2: (50) | Def: Pancreatitis Grp1: 1 (3) Grp2: 0 (0)
Metformin + basal insulin versus metformin + premixed insulin
Davies, 2007^147^ | RCT | Grp1: Metformin + NPH Varied, glucose < 6.0 mmol/L NR; Start: 10 IU/kg; Mean: 0.58 IU/kg D: 6 weeks Grp2: Metformin + BHI 70/30 Varied, glucose < 6.0 mmol/L NR; Start: 10 IU bid, Mean: 0.63 IU bid | Def: Clinical hypoglycemia Coll: Active Timing: Specified ITT: NR Grp1: (25) Grp2: (29.6)
Raskin, 2007^146^ | RCT | Grp1: Metformin + glargine Fixed; Varied, premeal glucose: 4.4 – 6.1mmol/L NR; Start: 12 U/kg QD, Mean: 0.57 IU/kg QD Grp2: Metformin + aspart 70/30 Fixed; Varied, premeal glucose: 4.4 – 6.1mmol/L NR; Start: 12 IU/kg BID, Mean: 0.91 IU/kg | Def: mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 11 (14) Grp2: 33 (42)
Robbins, 2007^145^ | RCT | Grp1: Metformin + glargine Fixed; Varied, glucose: <6.7 mmol/l Start: 500 mg bid, Max: 1000 mg bid, Mean: 1636 mg; Mean: 0.6 U/kg QD Grp2: Metformin + insulin lispro 50/50 Fixed; Varied, glucose: <6.7 mmol/l Start: 500 mg bid, Max: 1000 mg bid, Mean: 1641 mg; Mean: 0.7 U/kg tid | Def: Coll: Active Timing: Specified ITT: Yes Grp1: Severe: 2 (1), Mild or moderate: 75 (47) Grp2: Severe: 3 (2), Mild or moderate: 79 (50) | | | | Def: Diarrhea Coll: Active Timing: Specified ITT: Yes Grp1: (5.7) Grp2: (6.4)
Malone, 2005^165^ | RCT | Grp1: Metformin + lispro 75/25 Varied, pre-meal glucose 90–126 mg/dL 2-hr PPG 144–180 mg/dL Start: 1500 mg; Max: 2550 mg; Mean: 2146 mg; Mean: 0.42 U/kg bid D: 4 weeks; 16 weeks Grp2: Metformin + glargine Varied, glucose 90–126 mg/dL Start: 1500 mg; Max: 2550 mg; Mean: 2146 mg; Mean: 0.36 U/kg qd D: 4 weeks; 16 weeks | Def: Overall Coll: Active Timing: Specified ITT: NR Grp1: 0.61 episodes/patient/30 days Grp2: 0.44 episodes/patient/30 days
Malone, 2004^164^ | RCT | Grp1: Metformin + glargine Fixed; Varied, glucose: 90 – 126 mg/dL Start: 1500 mg, Max: 2550 mg; Mean: 0.57 U/kg qd Grp2: Metformin + lispro 75/25 Varied, glucose: 90 – 126 mg/dL Start: 1500 mg, Max: 2550 mg; Mean: 0.62 U/kg bid | Def: Coll: Active Timing: Specified ITT: Yes Grp1: Severe: 0 (0), Mild or moderate: 40 (40) Grp2: Severe: 0 (0), Mild or moderate: 57 (57) | | Coll: Active Timing: Specified ITT: Yes Grp1: 0 (0) Grp2: 1 (1)

AA=African American; C=Caucasian; H=Hispanic; kg=kilogram; NR=not reported; O = other

* 5 while on metformin prior to second crossover; 2 during washout period; and 5 while on repaglinide after crossover

† 2 excluded on repaglinide prior to first crossover; 1 during washout, and 5 after first crossover while on metformin

D = duration; Def = definition; DPP-4 = dipeptidyl peptidase-4; dys = days; fsg = fasting serum glucose; GLP-1 = glucagon-like peptidase-1; Grp = group; HR = hazard ratio; ICD = International Classification Disease; IR = incident rates; ITT = intention to treat; mg/day = milligram per day; mg/dl = milligrams/deciliter; mg = milligram; mmol/l = millimoles per liter; NR = not reported; NSG = non significant; od = once a day; SU = sulfonylurea; tid = twice a day; wks = weeks

Table 12 Comparative effectiveness of diabetes medications on adverse events (KQ3)

Author, year | | Study design | | Intervention | | Hypoglycemia, n (%) | | Liver failure, n (%) | | Congestive heart failure, n (%) | | Fractures, n (%) | | GI side effects, n (%) | | Other, n (%)
Metformin versus thiazolidinediones
Tzoulaki, 2009^171^ | | Cohort | | Grp1: Metformin NR Grp2: Rosiglitazone NR | | | | | | Def: First episode of CHF Grp1: ref Grp2: 0.61 (CI: 0.33 to 1.15) | | Non-hip fractures Grp1: ref Grp2: HR: 1.09 (CI: 0.72 to 1.68)
Tzoulaki, 2009^171^ | | Cohort | | Grp1: Metformin NR Grp2: Pioglitazone NR | | | | | | Def: First episode of CHF Grp1: ref Grp2: 1.17 (CI: 0.77 to 1.77) | | Non-hip fractures Grp1: ref Grp2: HR: 1.28 (CI: 0.93 to 1.77)
Perez, 2009^56^ | | RCT | | Grp1: Metformin Fixed Mean: 850 mg Grp2: Pioglitazone Fixed | | | | | | | | Def: Wrist fractures Coll: Active Timing: Specified ITT: NR Grp1: 1 (<1) Grp2: 0 (0) | | Def: Diarrhea Coll: Active Timing: Specified ITT: NR Grp1: (15.3) Grp2: (2.6)
Pantalone, 2009^174^ | | Cohort | | Grp1: Metformin NR Grp2: Rosiglitazone NR | | | | | | Def: ICD-9 codes Coll: NR Timing: NA ITT: NA Grp1: ref Grp2: HR: 1.16 (CI: 0.78 to 1.73)
Pantalone, 2009^174^ | | Cohort | | Grp1: Metformin NR Grp2: Pioglitazone NR | | | | | | Def: ICD-9 codes Coll: NR Timing: NA ITT: NA Grp1: ref Grp2: HR: 1.38 (CI: 1.00 to 1.90)
Hsiao, 2009^173^ | | Cohort | | Grp1: Metformin NR Grp2: Rosiglitazone NR | | | | | | Def: ICD-9-CM diagnostic codes of hospitalization Coll: NR Timing: Unspecified ITT: NA Grp1: 578 (1.26); ref Grp2: 67 (3.33); HR: 1.30 (CI: 0.89 to 1.89)
Hsiao, 2009^173^ | | Cohort | | Grp1: Metformin NR Grp2: Pioglitazone NR | | | | | | Def: ICD-9-CM diagnostic codes of hospitalization Coll: NR Timing: Unspecified ITT: NA Grp1: 578 (1.26); ref Grp2: 13 (2.66); HR: 1.54 (CI: 0.65 to 3.64)
Karter, 2005^207^ | | Cohort | | Grp1: Metformin NR Grp2: Pioglitazone NR | | | | | | Def: ICD-9-CM codes for primary discharge diagnosis (HR relative to sulfonylurea use) Coll: Passive Timing: Unspecified ITT: NR Grp1: HR: 0.7 (CI: 0.49 - 0.99), p: 0.05 Grp2: HR: 1.28 (CI: 0.85 - 1.92), p: 0.2
Asche, 2008^200^ | | Cohort | | Grp1: Metformin NR Grp2: Thiazolidinediones NR | | | | | | Def: NR Coll: NR Timing: Unspecified ITT: NR Grp1: NR Grp2: 18 (2.6) | | | | Def: Nausea & vomiting; diarrhea; dyspepsia Coll: NR Timing: NR ITT: NR Grp1: (1.3%; 1.6%; 2.8%) Grp2: NR | | Def: Lactic acidosis Coll: NR Timing: Unspecified ITT: NR Grp1: 6 (0.3) Grp2: NR
Kawai, 2008^221^ | | Non-randomized | | Grp1: Metformin NR Start: 500-750mg, Max: 750mg Grp2: Pioglitazone Fixed NR | | Def: Mild, moderate and severe Coll: NR Timing: Unspecified ITT: Yes Grp1: 0 (0) Grp2: 0 (0)
Rosenstock, 2006^49^ | | RCT | | Grp1: Metformin Varied, mean daily glucose ≤ 6.1 mmol/l Start: 500 mg, Max: 2000 mg, Mean: 1847 mg D: 32 wks Grp2: Rosiglitazone Varied, mean daily glucose ≤ 6.1 mmol/l Start: 4 mg, Max: 8 mg, Mean: 7.7 mg D: 32 wks | | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 14 (9) Grp2: 13 (8) | | | | | | | | Def: Diarrhea, nausea, vomiting, dyspepsia Coll: Active Timing: Specified ITT: Yes Grp1: (51) Grp2: (35)
Kahn, 2006^38^ | | RCT | | Grp1: Metformin Varied, glucose: <140 mg Start: 500 mg, Max: 2000 mg Grp2: Rosiglitazone Varied, glucose: <140 mg Start: 4 mg, Max: 8 mg | | Def: Self reported Coll: NR Timing: Unspecified ITT: Yes Grp1: All: 168 (11.6), Severe: 1 (0.1) Grp2: All: 142 (9.8), Severe: 1 (0.1) | | | | Def: Investigator reported Grp1: 19 (1.3) Grp2: 22 (1.5) | | | | Def: Nausea, vomiting, diarrhea, abdominal discomfort Coll: NR Timing: Unspecified ITT: Yes Grp1: (38.3) Grp2: (23)
Yamanouchi, 2005^50^ | | RCT | | Grp1: Metformin Fixed Start: 750 mg Grp2: Pioglitazone Fixed Start: 30 mg women, 45 mg men | | Def: NR Grp1: 0 (0) Grp2: 0 (0)
Pavo, 2003^54^ | | RCT | | Grp1: Metformin Varied, glucose: < 126 mg/dl Start: 850 mg, Max: 2550 mg, Mean: 2292 mg D: 8 wks Grp2: Pioglitazone Varied, glucose: < 126 mg/dl Start: 35 mg, Max: 45 mg, Mean: 41.5 mg D: 8 wks | | | | | | | | | | Def: Diarrhea Grp1: (16) Grp2: (3) | | Def: Cholecystitis Coll: Active Timing: Unspecified ITT: NR Grp1: 0 (0) Grp2: 1 (1)
Schernthaner, 2004^52^ | | RCT | | Grp1: Metformin Varied Start: 850 mg, Max: 2550 mg Grp2: Pioglitazone Varied Start: 35 mg, Max: 45 mg | | | | | | | | | | Def: Diarrhea; Nausea Grp1: (11.1); (4.2) Grp2: (3.2); (2.3)
Leiter 2005^83^ | | RCT | | Grp1: Metformin Varied, glucose: <7.0 mmol/L Start: 1500 mg, Max: 2500 mg D: 8 wks Grp2: Rosiglitazone Varied, glucose: <7.0 mmol/L Start: 4 mg, Max: 8 mg D: 8 wks | | | | | | Grp1: 0 (0) Grp2: 3 (1)
Rajagopalan, 2005^206^ | | Cohort | | Grp1: Metformin NR Grp2: Pioglitazone NR | | | | Def: ICD9 code liver failure or hepatitis Coll: Passive Timing: Unspecified ITT: NR Grp1: 0.8% incidence Grp2: 0.5% incidence HR: 1.139 (CI: 0.439 - 2.96)
Rajagopalan, 2005^206^ | | Cohort | | Grp1: Metformin NR Grp2: Rosiglitazone NR | | | | Def: ICD9 code 'liver failure' or 'hepatitis' Coll: Passive Timing: Unspecified ITT: NR Grp1: 0.8% incidence Grp2: 0.4% incidence
Kahn, 2008^213^ | | RCT | | Grp1: Metformin Varied, glucose: < 140 Start dose: 500g, Max: 2g Grp2: Rosiglitazone Varied, glucose: < 140 Start dose: 4mg, Max: 8mg | | | | | | | | Def: Fractures (NS) Coll: NR Timing: Unspecified ITT: Yes Grp1: 1.2/ 100 patient-years Grp2: 1.86/ 100 patient-years HR: 1.57 (CI: 1.13 - 2.17), p: 0.0073
Metformin versus sulfonylurea
Pantalone, 2009^174^ | | Cohort | | Grp1: Metformin NR Grp2: Sulfonylurea NR | | | | | | Def: ICD-9 codes Coll: NR Timing: NA ITT: NA Grp1: HR: 0.76 (CI: 0.64 to 0.91) Grp2: ref
Tzoulaki, 2009^171^ | | Cohort | | Grp1: Metformin NR Grp2: Sulfonylurea NR | | | | | | Def: First episode of CHF Grp1: ref Grp2: 1.18 (CI: 1.04 to 1.34) | | Non-hip fractures Grp1: ref Grp2: HR: 1.09 (CI: 0.97 to 1.23)
Currie, 2009^212^ | | Cohort | | Grp1: Metformin NR Grp1: Sulfonylurea | | | | | | | | | | | | Def: Cancer Coll: Passive Timing: Unspecified ITT: NA Grp1: ref Grp2: HR: 1.36 (CI: 1.19 to 1.54)
Asche, 2008^200^ | | Cohort | | Grp1: Metformin NR Grp2: Any drug in the sulfonylurea class NR | | | | | | | | | | Def: Nausea/ vomiting; Diarrhea; Dyspepsia Coll: NR Timing: No ITT: NR Grp1: (1.3; 1.6; 2.8) Grp2: NR | | Def: Lactic acidosis Coll: NR Timing: Unspecified ITT: NR Grp1: 6 (0.3) Grp2: NR
McAlister, 2008^208^ | | Cohort | | Grp1: Metformin NR Median: 726 mg Grp2: Any sulfonylurea Varied Median: 4 mg for glyburide, 198 mg for chlorpropamide, 425 mg for tolbutamide | | | | | | Def: Primary, secondary or most responsible diagnosis of HF using ICD-9 codes Coll: Passive ITT: NR Grp1: 3.3 cases/100yrs Grp2: 4.4 cases/100 yrs, aHR: 1.16 (CI: 0.96-1.41)
Karter, 2005^207^ | | Cohort | | Grp1: Metformin NR Grp2: Any sulfonylurea NR | | | | | | Def: ICD-9-CM codes for primary discharge diagnosis Coll: Passive Timing: Unspecified ITT: NR Grp1: HR: 0.7 (CI: 0.49-0.99), p: 0.05 Grp2: ref
Chien, 2007^59^ | | RCT | | Grp1: Metformin Varied, glucose: <140 mg/dL Start: 1000 mg, Max: 2000 mg, Mean: 1910 mg D: 4 wks Grp2: Glyburide Varied, glucose: <140 mg/dL Start: 10 mg, Max: 20 mg, Mean: 19 mg D: 4 wks | | Def: Mild or moderate Coll: Passive Timing: Unspecified ITT: Yes Grp1: 0 (0) Grp2: 0 (0) | | | | | | | | Def: Diarrhea, dry mouth, increased appetite, GI disease Coll: Passive Timing: Unspecified ITT: Yes Grp1: (32) Grp2: (13)
Kahn, 2006^38^ | | RCT | | Grp1: Metformin Varied, glucose: <140 mg/dL Start: 500 mg, Max: 2000 mg Grp2: Glyburide Varied, glucose: <140 mg/dL Start: 2.5 mg, Max: 15 mg | | Def: Self reported events Coll: NR Timing: Unspecified ITT: Yes Grp1: All: 168 (11.6), Severe: 1 (0.1) Grp2: All: 557 (38.7), Severe: 8 (0.6) | | | | Def: Investigator reported events Coll: NR Timing: Unspecified ITT: Yes Grp1: All: 19 (1.3), Serious: 12 (0.8) Grp2: All: 9 (0.6), Serious: 3 (0.2) | | | | Def: Nausea, vomiting, diarrhea, abdominal discomfort Coll: NR Timing: Unspecified ITT: Yes Grp1: (38.3) Grp2: (21.9)
Wright, 2006^198^ | | RCT | | Grp1: Metformin Varied, glucose: <6 mmol/L Max: 2550 mg Grp2: Sulfonylurea Varied, glucose: <6 mmol/L Max: glipizide 40 mg, chlorpropramide 500 mg, glibenclamide 20 mg | | Def: Mean annual % Coll: Active Timing: Specified ITT: NR Grp1: Substantive hypo: 0.3, (CI: 0.1-1.1); Any: 1.7, (CI: 1-3) Grp2: Substantive hypo: 1.2, (CI: 0.4-3.4); Any: 7.9, (CI: 5.1-11.9)
Yamanouchi, 2005^50^ | | RCT | | Grp1: Metformin Fixed 750 mg Grp2: Glimepiride Varied Start: 1.0 mg, Max: 2.0 after 1 month in 8 cases. Rest on 1 mg | | Grp1: Severe: 0 (0); Mild/moderate: 0 (0) Grp2: Severe: 0 (0); Mild/moderate: 1 (2.7)
Derosa, 2004^60^ | | RCT | | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Glimepiride Varied Start: 1 mg, Max: 4 mg | | Grp1: 0 (0) Grp2: 0 (0) | | | | | | | | Def: Nausea + diarrhea Grp1: 2 (2.4) Grp2: NR
Garber, 2003^61^ | | RCT | | Grp1: Metformin Varied Start: 500 mg (adjusted to patient response), Max: 2000 mg Grp2: Glyburide Varied Start: 2.5 (adjusted to patient response), Max: 10 mg | | Def: Mild or moderate Grp1: Symptomatic: 29 (17.7), Fingerstick: 1 (0.6) Grp2: Symptomatic: 98 (57.6), Fingerstick: 16 (10.6) | | | | | | | | Def: Abdominal pain; Nausea & Vomiting; Diarrhea Grp1: (6.1; 10.4; 18.3) Grp2: (4; 6.6; 5.3)
Blonde, 2002^63^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glyburide Fixed Start: 10 mg | | Def: Mild or moderate, Fsg≤60mg/dl + symptomatic Grp1: 1 (<1) Grp2: 3 (1.8) | | | | | | | | Def: Dyspepsia and heartburn; Nausea + vomiting; Flatulence Grp1: (4.6); (12.4); (2) Grp2: (3); (5.5); (0)
Marre, 2002^64^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glibenclamide Varied Start: 5 mg, Max: 20 mg | | Def: Symptoms or labs Grp1: Serious: 1 (1.0), Mild or moderate: 0 (0) Grp2: Serious: 1 (1.0), Mild or moderate: 7 (7)
Garber, 2002^65^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glyburide Varied Start: 2.5 mg, Max: 10mg | | Def: Mild or moderate Grp1: 0 (0) Grp2: 10 (6) | | | | | | | | Def: Nausea + vomiting + diarrhea + dyspepsia Grp1: (43) Grp2: (24)
Charpentier, 2001^71^ | | RCT | | Grp1: Metformin Fixed Start: 850 mg tid Grp2: Glimepiride Fixed or Varied 1 mg (either fixed or increased stepwise to 2, 4, 6 mg od depending on clinical symptoms of hypoglycemia) | | Def: Clinical symptoms Grp1: Serious: 0 (0), Mild or moderate: 8 (11) Grp2: Serious: 3 (2), Mild or moderate: 17 (11) | | | | | | | | Def: Diarrhea Grp1: (7) Grp2: (1)
DeFronzo, 1995^70^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2500 mg Grp2: Glyburide Varied Start: 10 mg, Max: 20 mg | | Def: Mild or moderate Grp1: 4 (2) Grp2: 6 (3) | | | | | | | | Def: Nausea + diarrhea Grp1: (1.4) Grp2: (1)
Hermann, 1994^68^ | | RCT | | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Glyburide Varied Start: 3.5 mg, Max: 10.5 mg | | Def: Serious Grp1: 8 (21) Grp2: 12 (35) | | | | | | | | Def: Nausea + diarrhea + dyspepsia and digestive Grp1: (63) Grp2: (32)
Maru, 2005^195^ | | Cohort | | Grp1: Metformin NR Grp2: Sulfonylurea NR | | | | | | Def: CHF/clinical diagnosis + validated a small sample via questionnaires to Grp to confirm the diagnosis + oxmis and read codes similar to ICD-9 codes Grp1: IR: 18.8/1000 person-years Grp2: IR: 26.6/1000 person-years
Nichols, 2005^196^ | | Cohort | | Grp1: Metformin NR Grp2: Sulfonylurea NR | | | | | | Def: Medical record for CHF + ICD-9 code for CHF + clinical diagnosis + first record Grp1: IR: 10.5 (6.7-16.2) Grp2: IR: 13.8 (11.4-16.6)
Rajagopalan, 2005^206^ | | Cohort | | Grp1: Metformin NR Grp2: Any drug in SU class NR | | | | Def: ICD9 code liver failure or hepatitis Coll: Passive Timing: Unspecified ITT: NR Grp1: (0.8) Grp2: (1)
Kahn, 2008^213^ | | RCT | | Grp1: Metformin Varied, glucose: < 140 mg/dL Start dose: 500 mg, Max: 2 g Grp2: Glyburide Varied, glucose: < 140 mg/dL Start dose: 2.5 mg, Max: 15 mg | | | | | | | | Def: Fractures (NS) Coll: NR Timing: Unspecified ITT: Yes Grp1: 1.2/100 patient-years Grp2: 1.15/100 patient-years
Chien, 2007^59^ | | RCT | | Grp1: Metformin Varied, glucose: <140 mg/dL Start dose: 1000 mg, Max: 2000 mg, Mean: 1910 mg D: 4 wks Grp2: Glyburide Varied, glucose: <140 mg/dL Start dose: 10 mg, Max: 20 mg, Mean: 19 mg D: 4 wks | | | | | | | | Def: Right metacarpal bone fracture Coll: passive Timing: Unspecified ITT: Yes Grp1: 0 Grp2: 1 (6)
Amador-Licona, 2000^66^ | | RCT | | Grp1: Metformin Varied Start: 850 mg Grp2: Glibenclamide Varied Start: 5 mg | | | | | | | | | | Def: Diarrhea + Diffuse abdominal pain Grp1: 4 (14.3) Grp2: NR
Goldstein, 2003^62^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Glipizide Varied Start: 30 mg, Max: 30 mg | | | | | | | | | | Def: Diarrhea Grp1: (17.3) Grp2: (13.1)
Metformin versus DPP-IV inhibitors
Aschner, 2010^77^ | | RCT | | Grp1: Metformin Varied, prespecified dose Start: 500 mg, Max: 2000 mg; Mean: 1903 mg D: 5 weeks Grp2: Sitagliptin Fixed Mean: 100 mg | | Coll: Passive Timing: Unspecified ITT: No Grp1: Severe: 0 (0) Mild/moderate: 17 (3.3); 23 events Grp2: Severe: 2 (<1) Mild/moderate: 9 (1.7); 17 events | | | | | | | | Def: Combined GI events; Nausea; Diarrhea; Vomiting; Abdominal pain Coll: NR Timing: Unspecified ITT: No Grp1: (20.7, 3.1, 10.9, 1.3, 3.8) Grp2: (11.6, 1.1, 3.6, 0.4, 2.1)
Jadzinsky, 2009^78^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 1000 mg D: 1 week Grp2: Saxagliptin Fixed Mean: 10 mg | | Coll: Active Timing: Unspecified ITT: Yes Grp1: Severe: 0 (0) Mild/moderate: 13 (4) Grp2: Severe: 0 (0) Mild/moderate: 5 (1) | | | | | | | | Def: Diarrhea Coll: Active Timing: Unspecified ITT: Yes Grp1: 24 (7) Grp2: 10 (3)
Williams-Herman, 2009^76^ | | RCT | | Grp1: Metformin Fixed Mean: 1000 mg or 2000 mg Grp2: Sitagliptin Fixed Mean: 100 mg | | Def: Coll: Active Timing: Unspecified ITT: No Grp1: 2 (1) Grp2: 2 (1) | | | | | | | | Def: Nausea; Diarrhea; Abdominal pain; Vomiting; Nausea/ Vomiting Coll: NR Timing: Unspecified ITT: No Grp1: (3; 7; 4; 0; 20 for 1000 mg and 10; 12; 6; 3; 31 for 2000 mg) Grp2: (1; 4; 5; 1; 20)
Goldstein, 2007^75^ | | RCT | | Grp1: Metformin Varied, prespecified target Start: 500 mg, Max: 2000 mg Grp2: Sitagliptin Varied, prespecified target Start: 50 mg, Max: 100 mg | | Grp1: 3 (2) Grp2: 1 (1)
Metformin versus meglitinides
Lund, 2007^197^ | | RCT | | Grp1: Metformin Varied, prespecified target Start: 500 mg, Max: 2000 mg, Mean: 1629 mg D: 12 days Grp2: Repaglinide Varied, prespecified target Start: 1 mg, Max: 6 mg, Mean: 4.72 mg D: 12 days | | Coll: Active Timing: Specified ITT: Yes Grp1: Serious: 1 (1), Mild or moderate: 22 (23) Grp2: Serious: 1 (1), Mild or moderate: 45 (47) | | | | | | | | Def: NR Coll: Active Timing: Specified ITT: Yes Grp1: (65.7) Grp2: (42.7) | | Def: Cancer Grp1: 2 (2) Grp2: 0 (0)
Horton, 2004^80^ | | | | Grp1: Metformin Fixed Start: 500 mg Grp2: Nateglinide Fixed Start: 120 qac | | Def: Mild/ moderate, plasma glucose <2.8 mmol/l Coll: Active Timing: Specified ITT: Yes Grp1: 1 (1) Grp2: 2 (2) | | | | | | | | Def: Diarrhea Coll: Active Timing: Specified ITT: Yes Grp1: (20.2) Grp2: (3.8)
Moses, 1999^82^ | | RCT | | Grp1: Metformin NR Grp2: Repaglinide Fixed Start: 0.5 mg, Max: 4.0 mg D: 12-28 days | | Def: Mild or moderate Coll: Passive Timing: Unspecified ITT: No Grp1: 1 (4) Grp2: 3 (11)
Derosa, 2003^81^ | | RCT | | Grp1: Metformin Varied Start: 500 mg bid, Max: 2500 mg D: 8 weeks Grp2: Repaglinide Varied Start: 0.5 mg bid, Max: 4 mg tid D: 8 weeks | | Def: Mild or moderate Grp1: 0 (0) Grp2: 0 (0) | | | | | | | | Def: Nausea + diarrhea (withdrawn due to) Grp1: (3.6) Grp2: (0)
Horton, 2000^79^ | | RCT | | Grp1: Metformin Fixed Start: 500 mg Grp2: Nateglinide Fixed Start: 120 mg tid | | Def: Mild or moderate Grp1: 19 (11) Grp2: 22 (12) | | | | | | | | Def: Nausea + diarrhea (withdrawn due to) Grp1: (3.4) Grp2: (0.6)
Metformin versus metformin + thiazolidinedione
Mancini, 2009^214^ | | Cross-sectional | | Grp1: Metformin Median: 1700 mg Grp2: Metformin + rosiglitazone Median: 1850 mg; Median: 8 mg | | | | | | | | Def: Vertebral fractures Coll: NR Timing: NA ITT: NA Grp1: ref Grp2: OR: 6.5 (CI: 1.3 to 38.1)
Perez, 2009^56^ | | RCT | | Grp1: Metformin Fixed Mean: 850 mg Grp2: Metformin + pioglitazone Fixed | | | | | | | | Def: Wrist fractures Coll: Active Timing: Specified ITT: NR Grp1: 1 (<1) Grp2: 1 (<1) | | Def: Diarrhea Coll: Active Timing: Specified ITT: NR Grp1: (15.3) Grp2: (9)
Kawai, 2008^221^ | | Non-randomized | | Grp1: Metformin NR Start: 500-750 mg, Max: 750 mg Grp2: Metformin + pioglitazone NR; Fixed Start: 500-750 mg, Max: 750 mg; NR | | Def: Mild, moderate and severe Coll: NR Timing: Unspecified ITT: No Grp1: 0 (0) Grp2: 0 (0)
Kaku, 2009^84^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 750 mg Grp2: Metformin + pioglitazone Varied Start: 500 mg, Max: 750 mg; Start: 15 mg, Max: 30 mg D: NR; 16 wks | | Def: Mild or moderate Grp1: 0 (0) Grp2: 1 (1) | | | | | | | | Def: abdominal pain and constipation Grp1: (2.3) Grp2: (2.4)
Scott, 2008^85^ | | RCT | | Grp1: Metformin Fixed Start: >1500 mg D: 10 wks Grp2: Metformin + rosiglitazone Fixed Start: >1500 mg; Start: 8 mg, Mean: 8 mg D: 10 wks | | Def: Mild or moderate Coll: NR Timing: Unspecified Grp1: 2 (2) Grp2: 1 (1) | | | | | | | | Def: Diarrhea, nausea, abdominal pain, vomiting Coll: NR Timing: Unspecified ITT: No Grp1: (9) Grp2: (7)
Rosenstock, 2006^49^ | | RCT | | Grp1: Metformin Varied, mean daily glucose ≤6.1 mmol/l Start: 500 mg, Max: 2000 mg, Mean: 1847 mg D: 32 wks Grp2: Metformin + rosiglitazone Varied, mean daily glucose ≤6.1 mmol/l Start: 500 mg, Max: 2000 mg, Mean: 1799 mg; Start: 2 mg, Max: 8 mg, Mean: 7.2 mg D: 32 wks | | Def: Self reported mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 14 (9) Grp2: 19 (12) | | | | | | | | Def: Diarrhea, nausea, vomiting Dyspepsia Coll: Active Timing: Specified ITT: Yes Grp1: (51) Grp2: (47)
Stewart, 2006^156^ | | RCT | | Grp1: Metformin Varied, prespecified Start: 500 mg, Max: 3000 mg, Mean: 2627.9 mg D: 20 wks Grp2: Metformin + rosiglitazone Varied, prespecified Start: 500 mg, Max: 2000 mg, Mean: 1812.2 mg; Start: 4 mg, Max: 8 mg, Mean: 6.8 mg D: 18 wks; 16 wks | | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 10 (4) Grp2: 17 (7) | | | | | | | | Def: Diarrhea Grp1: (18) Grp2: (8)
Jones, 2003^179^ | | RCT | | Grp1: Metformin Fixed Max: 2.5 g Grp2: Metformin + rosiglitazone Fixed; Varied, prespecified target Max: 2.5 g; Max: 8 mg | | Def: Symptomatic hypoglycemia Grp1: All: (0.4), Obese: (1.7) Grp2: All: (2.1), Obese: (1.9)
Weissman, 2005^86^ | | RCT | | Grp1: Metformin Varied Start: 500 mg bid, Max: 1000 mg bid Grp2: Metformin + rosiglitazone Fixed Start: 2500 mg; Start: 12 mg | | Def: Mild or moderate Grp1: 4 (1) Grp2: 4 (1) | | | | | | | | Def: Withdrawn due to GI Grp1: (6.8) Grp2: (3.1)
Bailey, 2005^87^ | | RCT | | Grp1: Metformin Varied Start: 2500 mg, Max: 3000 mg D: 24 wks Grp2: Metformin + rosiglitazone Fixed; Varied Start: 2000 mg; Start: 4 mg, Max: 8 mg D: 24 wks | | Grp1: Serious: 0, Mild or moderate: 1 (<1) Grp2: Serious: 0, Mild or moderate: 3 (1) | | | | | | | | Def: diarrhea and abdominal pain Grp1: (5.4) Grp2: (3.2) | | Def: acute cholecystitis, serious cholelithiasis and cholestatic jaundice Coll: Active Timing: Specified ITT: Yes Grp1: 1 (<1) Grp2: 0 (0)
Fonseca, 2000^90^ | | RCT | | Grp1: Metformin Fixed Start: 2500 mg Grp2: Metformin + rosiglitazone Fixed Start: 2500 mg; Start: 4-8 mg | | Def: mild or moderate Grp1: 2 (2) Grp2: 5 (4)
Einhorn, 2000^89^ | | RCT | | Grp1: Metformin NR Grp2: Metformin + pioglitazone NR; Fixed NR; 30 mg | | Grp1: 1 (0.6) Grp2: 1 (0.6)
Gomez-Perez, 2002^88^ | | RCT | | Grp1: Metformin Fixed Start: 2.5 g Grp2: Metformin + rosiglitazone Fixed Start: 2.5 g; Start: 2-4 mg bid | | | | | | | | | | Def: Nausea + vomiting + diarrhea + flatulence and abdominal pain Grp1: (15.4) Grp2: (16.8)
Metformin versus metformin + sulfonylurea
Currie, 2009^212^ | | Cohort | | Grp1: Metformin NR Grp1: Metformin + sulfonylurea | | | | | | | | | | | | Def: Cancer Coll: Passive Timing: Unspecified ITT: NA Grp1: ref Grp2: HR: 1.8 (CI: 0.96 to 1.21)
Nauck, 2009^92^ | | RCT | | Grp1: Metformin Varied Start: 2000 mg, Max: 2000 mg Grp2: Metformin + glimepiride Varied; Fixed Start: 2000 mg, Max: 2000 mg; Start: 1 mg, Max: 4 mg D: NR; 3 wks | | Def: Serious Coll: NR Timing: Unspecified ITT: NR Grp1: 0 (0) Grp2: 0 (0) | | | | | | | | Def: nausea, vomiting, and diarrhea Coll: NR Timing: NR ITT: NR Grp1: (17) Grp2: (17) | | Def: acute pancreatitis Coll: NR Timing: Unspecified ITT: NR Grp1: 0 (0) Grp2: 1 (<1)
Feinglos, 2005^91^ | | RCT | | Grp1: Metformin Fixed Start: ≥1000 mg Grp2: Metformin + glipizide Fixed Start: ≥1000 mg; 2.5 mg | | Def: FSG <60 mg/dl w/ symptoms or FSG <50 mg/dl w/o symptoms or FPG<55 mg/dl w/o symptoms Grp1: Serious: 0, Mild or moderate: 2 (3.3) Grp2: Serious: 0, Mild or moderate: 9 (14.8)
Garber, 2003^61^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 250 mg, Max: 1000 mg; Start: 1.25 mg, Max: 5 mg | | Def: Mild or moderate Grp1: Symptomatic: 29 (17.7), Fingerstick: 1 (0.6) Grp2: Symptomatic: 59 (39.1), Fingerstick: 19 (11.2) | | | | | | | | Def: Abdominal pain; nausea + vomiting; Diarrhea Grp1: (6.1; 10.4; 18.3) Grp2: (4.1; 4.7; 7.6)
Tosi, 2003^36^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 3000 mg Grp2: Metformin + glibenclamide Varied Start: 500 mg, Max: 2000; Start: 2.5 mg, Max: 10mg | | Grp1: Severe: 2 (10.5), Mild or moderate: 1 (5) Grp2: NR | | | | | | | | Def: Diarrhea + constipation + discomfort and abdominal pain and anorexia Grp1: (10.5) Grp2: (2.6)
Blonde, 2002^63^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 2000 mg; Start: 5 mg, Max: 20 mg | | Def: FSG≤60mg/dl + symptomatic Grp1: Mild or moderate: 1 (<1) Grp2: Mild or moderate: 22 (6.8) | | | | | | | | Def: Dyspepsia and heartburn; Nausea + vomiting; Flatulence Grp1: (4.6; 12.4; 2) Grp2: (3.7; 6.8; 2.5)
Blonde, 2002^63^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 2000 mg; Start: 2.5 mg, Max: 10 mg | | Def: FSG≤60mg/dl + symptomatic Grp1: Mild or moderate: 1 (<1) Grp2: Mild or moderate: 22 (6.8) | | | | | | | | Def: Dyspepsia and heartburn; Nausea + vomiting; Flatulence Grp1: (4.6; 12.4; 2) Grp2: (5; 10; 6.3)
Marre, 2002^64^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glibenclamide Varied Start: 500 mg, Max: 2000 mg; Start: 2.5 mg, Max: 10 mg | | Def: Symptoms or labs Grp1: Serious: 1 (1.0), Mild or moderate: 0 Grp2: Serious: 0, Mild or moderate: 11 (10.9) | | | | | | | | Def: Not specified Grp1: (14.4) Grp2: (6.9)
Marre, 2002^64^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glibenclamide Varied Start: 500 mg, Max: 2000 mg; Start: 2.5 mg, Max: 10 mg | | Def: Symptoms or labs Grp1: Serious: 1 (1.0), Mild or moderate: 0 Grp2: Serious: 2 (1.9), Mild or moderate: 12 (11.4)
Garber, 2002^65^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 250 mg; Start: 1.25 mg | | Def: Mild or moderate Grp1: NR Grp2: 18 (11.4) | | | | | | | | Def: Nausea + vomiting + diarrhea + dyspepsia Grp1: IR - 43 Grp2: IR - 32
Garber, 2002^65^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glyburide Varied Start: 500 mg; Start: 2.5 mg | | Def: Mild or moderate Grp1: NR Grp2: 61 (37.7) | | | | | | | | Def: Nausea + vomiting + diarrhea + dyspepsia Grp1: IR - 43 Grp2: IR - 38
Charpentier, 2001^71^ | | RCT | | Grp1: Metformin Fixed Start: 850 mg tid Grp2: Metformin + glimepiride Fixed Start: 850 mg tid; Start: 1 mg | | Def: Clinical symptoms Grp1: Serious: 0 (0), Mild or moderate: 8 (11) Grp2: Serious: 2 (1.4), Mild or moderate: 30 (21) | | | | | | | | Def: diarrhea Grp1: (7) Grp2: (3)
DeFronzo, 1995^70^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2500 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 2500 mg; Start: 10 mg, Max: 20mg | | Def: Mild or moderate Grp1: 4 (2) Grp2: 38 (18) | | | | | | | | Def: Nausea + diarrhea Grp1: (1.4) Grp2: (0.9)
Hermann, 1994^68^ | | RCT | | Grp1: Metformin Varied Start: 1000 mg, Max: 3000 mg Grp2: Metformin + glyburide Varied Start: 500 mg, Max: 3000 mg; Start: 1.75 mg, Max: 14 mg | | Def: Mild or moderate Grp1: 8 (21) Grp2: 24 (33)
Chien, 2007^59^ | | RCT | | Grp1: Metformin Varied, glucose: <140 mg/dL Start: 1000 mg, Max: 2000 mg, Mean: 1910 mg D: 4 wks Grp2: Metformin + glyburide Varied, glucose: <140 mg/dL Start: 1000 mg, Max: 2000 mg, Mean: 1680 mg; Start: 5 mg, Max: 10 mg, Mean: 8.4 mg D: 4 wks | | Def: Mild or moderate Coll: Passive Timing: Unspecified ITT: Yes Grp1: 0 (0) Grp2: 0 (0) | | | | | | Def: Right metacarpal bone fracture Coll: passive Timing: Unspecified ITT: Yes Grp1: 0 (0) Grp2: 0 (0) | | Def: Diarrhea, dry mouth, increased appetite, GI disease Coll: Passive Timing: Unspecified ITT: NR Grp1: (32) Grp2: (13)
Nichols, 2005^196^ | | Cohort | | Grp1: Metformin NR Grp2: Metformin + unspecified sulfonylurea NR | | | | | | Def: Medical record for CHF + ICD-9 code for CHF + clinical diagnosis + first record Grp1: IR: 10.5 (CI: 6.7-16.2) Grp2: IR: 13.4 (CI: 11.6-15.5)
Goldstein, 2003^62^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 2000 mg Grp2: Metformin + glipizide Varied Start: 500 mg, Max: 2000 mg; Start: 5 mg, Max: 20 mg | | | | | | | | | | Def: Diarrhea Grp1: (17.3) Grp2: (13.1)
Metformin versus metformin + DPP-IV inhibitors
Jadzinsky, 2009^78^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 1000 mg D: 1 week Grp2: Metformin + saxagliptin Varied, prespecified dose Start: 500 mg, Max: 1000 mg; Start: 5 mg | | Coll: Active Timing: Unspecified ITT: Yes Grp1: Severe: 0 (0) Mild/moderate: 13 (4) Grp2: Severe: 0 (0) Mild/moderate: 11 (3) | | | | | | | | Def: Diarrhea Coll: Active Timing: Unspecified ITT: Yes Grp1: 24 (7) Grp2: 22 (7)
Jadzinsky, 2009^78^ | | RCT | | Grp1: Metformin Varied Start: 500 mg, Max: 1000 mg D: 1 week Grp2: Metformin + saxagliptin Varied, prespecified dose Start: 500 mg, Max: 1000 mg; Start: 10 mg | | Coll: Active Timing: Unspecified ITT: Yes Grp1: Severe: 0 (0) Mild/moderate: 13 (4) Grp2: Severe: 2 (1) Mild/moderate: 16 (5) | | | | | | | | Def: Diarrhea Coll: Active Timing: Unspecified ITT: Yes Grp1: 24 (7) Grp2: 31 (10)
DeFronzo, 2009^95^ | | RCT | | Grp1: Metformin Fixed Grp2: Metformin + saxagliptin Fixed NR; Mean: 10 mg | | Grp1: Severe: 1 (1) Mild/moderate: 9 (5) Grp2: Severe: 1 (1) Mild/moderate: 7 (4) | | | | | | | | Def: Diarrhea Coll: Active Timing: Unspecified ITT: Yes Grp1: 20 (11) Grp2: 10 (6)
DeFronzo, 2009^95^ | | RCT | | Grp1: Metformin Fixed Grp2: Metformin + saxagliptin Fixed NR; Mean: 5 mg | | Grp1: Severe: 1 (1) Mild/moderate: 9 (5) Grp2: Severe: 1 (1) Mild/moderate: 10 (5) | | | | | | | | Def: Diarrhea Coll: Active Timing: Unspecified ITT: Yes Grp1: 20 (11) Grp2: 11 (6)
DeFronzo, 2009^95^ | | RCT | | Grp1: Metformin Fixed Grp2: Metformin + saxagliptin Fixed NR; Mean: 2.5 mg | | Grp1: Severe: 1 (1) Mild/moderate: 9 (5) Grp2: Severe: 1 (1) Mild/moderate: 15 (8) | | | | | | | | Def: Diarrhea Coll: Active Timing: Unspecified ITT: Yes Grp1: 20 (11) Grp2: 19 (10)
Williams-Herman, 2009^76^ | | RCT | | Grp1: Metformin Fixed Mean: 1000 mg bid Grp2: Metformin + sitagliptin Fixed Mean: 500 mg bid; Mean: 50 mg bid | | Def: Mild or moderate Coll: Active Timing: Unspecified ITT: No Grp1: 2 (1) Grp2: 4 (2) | | | | | | | | Def: Nausea; vomiting; diarrhea; abdominal pain; Nausea/ Vomiting Coll: NR Timing: Unspecified ITT: No Grp1: (3; 0; 7; 4; 31) Grp2: (5; 2; 9; 3; 26)
Williams-Herman, 2009^76^ | | RCT | | Grp1: Metformin Fixed Mean: 1000 mg bid Grp2: Metformin + sitagliptin Fixed Mean: 1000 mg bid; Mean: 50 mg bid | | Def: Mild or moderate Coll: Active Timing: Unspecified ITT: No Grp1: 2 (1) Grp2: 5 (3) | | | | | | | | Def: Nausea; vomiting; diarrhea; abdominal pain; Nausea/ Vomiting Coll: NR Timing: Unspecified ITT: No Grp1: (3; 0; 7; 4; 31) Grp2: (NR; 4; 13; 4; 29)
Scott, 2008^85^ | | RCT | | Grp1: Metformin Fixed Start: ≥1500 mg Grp2: Metformin + sitagliptin Fixed Start: ≥1500 mg; Start: 100 mg | | Def: Mild or moderate Coll: NR Timing: Unspecified ITT: No Grp1: 2 (2) Grp2: 1 (1) | | | | | | | | Def: Diarrhea, nausea, abdominal pain, vomiting Coll: NR Timing: Unspecified ITT: No Grp1: (9) Grp2: (1)
Raz, 2008^93^ | | RCT | | Grp1: Metformin Fixed Start: ≥1500 mg Grp2: Metformin + sitagliptin Fixed Start: ≥ 1500 mg; Start: 100 mg | | Def: Mild or moderate Coll: NR Timing: Unspecified ITT: No Grp1: 0 (0) Grp2: 1 (1) | | | | | | Def: Limb fracture Coll: NR Timing: Unspecified ITT: No Grp1: 1 (1) Grp2: 0 (0) | | Def: abdominal pain, nausea, vomiting, or diarrhea Coll: NR Timing: Unspecified ITT: No Grp1: (7.4) Grp2: (10.4) | | Def: Neoplasms Coll: NR Timing: Unspecified ITT: No Grp1: 3 (3) Grp2: 0 (0)
Goldstein, 2007^75^ | | RCT | | Grp1: Metformin Fixed Start: 500 mg or 1000 mg bid Grp2: Metformin + sitagliptin Fixed Start: 500 mg or 1000 mg bid; Start: 50 mg bid | | Def: Mild or moderate Grp1: 3 (2) Grp2: 6 (3)
Charbonnel, 2006^94^ | | RCT | | Grp1: Metformin Varied, HbA1c: 7 -10% Start: ≥1500 mg D: 19 wks Grp2: Metformin + sitagliptin Varied; Fixed Start: ≥1500 mg; Mean: 100 mg D: 19 wks | | Def: Mild or moderate Grp1: 5 (2.1) Grp2: 6 (1.3) | | | | | | | | Def: Abdominal pain, nausea, vomiting, or diarrhea Coll: NR Timing: Unspecified ITT: No Grp1: (10.5) Grp2: (11.9)
Metformin versus metformin + meglitinides
Horton, 2004^80^ | | RCT | | Grp1: Metformin Fixed Start: 500 mg tid Grp2: Metformin + nateglinide Fixed Start: 500 mg tid; Start: 120 mg ac | | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: Symptomatic: 11 (0.6), Confirmed ≤2.8 mmol/l: 1 (1.0) Grp2: Symptomatic: 26 (29.2), Confirmed ≤ 2.8mmol/l: 3 (3.4) | | | | | | | | Def: Diarrhea Coll: Active Timing: Specified ITT: Yes Grp1: (20.2) Grp2: (16.9)
Marre, 2002^96^ | | RCT | | Grp1: Metformin Fixed Start: 1000 mg bid Grp2: Metformin + nateglinide Fixed Start: 1000 mg bid; Start: 60 mg ac | | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: Symptomatic: 6 (3.9), Confirmed: 1 (0.7) Grp2: Symptomatic: 13 (8.4), Confirmed: 0
Marre, 2002^96^ | | RCT | | Grp1: Metformin Fixed Start: 1000 mg bid Grp2: Metformin + nateglinide Fixed Start: 1000 mg bid; Start: 120 mg ac | | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: Symptomatic: 6 (3.9), Confirmed: 1 (0.7) Grp2: Symptomatic: 25 (15.6), Confirmed: 5 (3.1)
Moses, 1999^82^ | | RCT | | Grp1: Metformin NR Grp2: Metformin + repaglinide NR; Varied, glucose: 4.4-7.8 mmol/l NR; Start: 0.5 mg, Max: 4 mg | | Def: Mild or moderate Coll: NR Timing: Unspecified ITT: NR Grp1: 0 Grp2: 9 (33.3)
Thiazolidinedione versus thiazolidinedione
Pantalone, 2009^174^ | | Cohort | | Grp1: Rosiglitazone NR Grp2: Pioglitazone NR | | | | | | Def: ICD-9 codes Coll: NR Timing: NA ITT: NA Grp1: ref Grp2: HR: 1.19 (CI: 0.74to 1.91)
Hsiao, 2009^173^ | | Cohort | | Grp1: Rosiglitazone NR Grp2: Pioglitazone NR | | | | | | Def: ICD-9-CM diagnostic codes of hospitalization Coll: NR Timing: Unspecified ITT: NA Grp1: 67 (3.33) Grp2: 13 (2.66)
Juurlink, 2009^210^ | | Cohort | | Grp1: Rosiglitazone NR Grp2: Pioglitazone NR | | | | | | Def: Congestive cardiac failure or heart failure hospitalization Coll: NR Timing: Unspecified ITT: NA Grp1: ref Grp2: HR: 0.77 (CI: 0.69 to 0.87)
Hussein, 2004^202^ | | Cohort | | Grp1: Rosiglitazone Fixed Start: 15-45 mg Grp2: Pioglitazone Fixed Start: 4-8 mg | | Def: Mild or moderate Coll: Passive Timing: Unspecified Grp1: 11 (11) Grp2: 18 (17) Grp1-Grp2: p: NSG | | | | Def: Pulmonary edema Coll: Passive Timing: Unspecified ITT: NR Grp1: 3 (3) Grp2: 2 (2)
Rajagopalan, 2005^206^ | | Cohort | | Grp1: Rosiglitazone NR Grp2: Pioglitazone NR | | | | Def: ICD9 code liver failure or hepatitis Coll: Passive Timing: Unspecified ITT: NR Grp1: (0.4) Grp2: (0.5)
Thiazolidinedione versus sulfonylurea
Pantalone, 2009^174^ | | Cohort | | Grp1: Rosiglitazone NR Grp2: Sulfonylurea NR | | | | | | Def: ICD-9 codes Coll: NR Timing: NA ITT: NA Grp1: HR: 0.88 (CI: 0.60 to 1.31) Grp2: ref
Pantalone, 2009^174^ | | Cohort | | Grp1: Pioglitazone NR Grp2: Sulfonylurea NR | | | | | | Def: ICD-9 codes Coll: NR Timing: NA ITT: NA Grp1: HR: 1.05 (95% CI 0.77 to 1.43) Grp2: ref
Hsiao, 2009^173^ | | Cohort | | Grp1: Rosiglitazone NR Grp2: Sulfonylurea NR | | | | | | Def: ICD-9-CM diagnostic codes of hospitalization Coll: NR Timing: Unspecified ITT: NA Grp1: 67 (3.33); Grp2: 1872 (1.97)
Hsiao, 2009^173^ | | Cohort | | Grp1: Pioglitazone NR Grp2: Sulfonylurea NR | | | | | | Def: ICD-9-CM diagnostic codes of hospitalization Coll: NR Timing: Unspecified ITT: NA Grp1: 13 (2.66) Grp2: 1872 (1.97)
Dormuth, 2009^215^ | | Cohort | | Grp1: Thiazolidinedione NR Grp2: Sulfonylurea NR | | | | | | | | Def: Hip fractures Coll: Passive Timing: Unspecified ITT: NA Grp1: HR: 1.28 (CI: 1.12 to 1.45) Grp2: ref
Tolman, 2009^150^ | | RCT | | Grp1: Pioglitazone Varied, HbA1c < 7.5% Max: 45 mg Grp2: Glibenclamide Max: 15 mg | | Coll: Active Timing: Specified ITT: Yes Grp1: 40 (4) Grp2: 119 (11) | | Def: ALT > 3x ULN with repeat confirmation Coll: Active Timing: Specified ITT: Yes Grp1: 0 (0) Grp2: 4 (<1) | | Coll: Active Timing: Specified ITT: Yes Grp1: 12 (1) Grp2: 11 (1) | | | | Def: Diarrhea Coll: Active Timing: Specified ITT: Yes Grp1: 93 (9) Grp2: 80 (8) | | Def: Cholecystitis Coll: Active Timing: Specified ITT: Yes Grp1: 4 (<1) Grp2: 4 (<1)
Jain, 2006^101^ | | RCT | | Grp1: Pioglitazone Varied, glucose: FPG (69-141 mg/dl) Start: 15 mg, Max: 45 mg, Median: 45 mg Grp2: Glyburide Varied, glucose: FPG: 69-141 mg/dl Start: 5 mg, Max: 15 mg, Median: 10 mg | | Def: Mild or moderate Coll: Active Timing: Unspecified ITT: Yes Grp1: 11 (4.4) Grp2: 61 (24.3) | | | | | | Def: Ankle Coll: Active Timing: No ITT: Yes Grp1: (0) Grp2: (0.8) | | Def: diarrhea Coll: active Timing: Unspecified ITT: Yes Grp1: (6) Grp2: (6.4) | | Def: stage IV colon ca Coll: active Timing: Unspecified ITT: Yes Grp1: 0 (0) Grp2: 2 (0.8)
Yamanouchi, 2005^50^ | | RCT | | Grp1: Pioglitazone Fixed Start: 30 mg for women and 45 mg for men Grp2: Glimepiride Varied Start: 1.0 mg, Max: 2.0 | | Grp1: Serious: 0 (0), Mild or moderate: 0 (0) Grp2: Serious: 0 (0), Mild or moderate: 1 (2.7)
Tan, 2004^106^ | | RCT | | Grp1: Pioglitazone Varied Start: 30 mg, Max: 45 mg Grp2: Glibenclamide Varied Start: 1.75 mg, Max: 10.5 mg | | Def: Symptoms or SMBG < 50 mg/dl Grp1: 4 (4) Grp2: 32 (29)
Hanefeld, 2007^100^ | | RCT | | Grp1: Rosiglitazone Fixed Start: 4 mg Grp2: Glibenclamide Varied Start: 2.5 mg, Max: 15 mg | | Coll: NR Timing: Unspecified ITT: Yes Grp1: 1 (0.5) Grp2: Serious: 2 (<1), Mild or moderate: 23 (11) | | | | | | | | Def: Unspecified Coll: NR Timing: Unspecified ITT: Yes Grp1: 11 (5.5) Grp2: 7 (3.4)
Hanefeld, 2007^100^ | | RCT | | Grp1: Rosiglitazone Fixed Start: 8 mg Grp2: Glibenclamide Varied Start: 2.5 mg, Max: 15 mg D: 12 wks | | Coll: NR Timing: Unspecified ITT: Yes Grp1: 3 (1.6) Grp2: Serious: 2 (<1), Mild or moderate: 23 (11) | | | | | | | | Def: Unspecified Coll: NR Timing: Unspecified ITT: Yes Grp1: 5 (2.6) Grp2: 7 (3.4)
St John Sutton, 2002^149^ | | RCT | | Grp1: Rosiglitazone Fixed Start: 4 mg Grp2: Glyburide Varied Start: NR, Max: 20 mg D: 8 weeks | | Def: Signs and symptoms Grp1: (1.9) Grp2: (7.1) | | | | Def: NR Grp1: 1 (1.0) Grp2: 0 (0)
Asche, 2008^200^ | | Cohort | | Grp1: Thiazolidinedione NR Grp2: Any in the Sulfonylurea class NR | | Def: Mild or moderate Coll: NR Timing: Unspecified ITT: NR Grp1: 12 (1.7) Grp2: 55 (2.6) | | | | Coll: NR Timing: Unspecified ITT: NR Grp1: 18 (2.6) Grp2: NR
Kahn, 2006^38^ | | RCT | | Grp1: Rosiglitazone Varied, glucose: <140 mg/dl Start: 4 mg, Max: 8 mg Grp2: Glyburide Varied, glucose: <140 mg/dl Start: 2.5 mg, Max: 15 mg | | Def: Self reported events Coll: NR Timing: Unspecified ITT: Yes Grp1: Serious events: 1 (0.1), Mild or moderate events: 142 (9.8) Grp2: Serious events: 8 (0.6), Mild or moderate events: 557 (38.7) | | | | Def: Investigator reported events Coll: NR Timing: Unspecified ITT: Yes Grp1: All: 22 (1.5), Serious: 12 (0.8) Grp2: All: 9 (0.6), Serious: 3 (0.2), p: ≤ 0.05 | | | | Def: Nausea, vomiting, diarrhea, abdominal discomfort Grp1: (23) Grp2: (21.9)
Agarwal, 2005^184^ | | RCT | | Grp1: Pioglitazone Varied, glucose: 140 mg/dL, HbA1c: 8% Start: 15 mg D: 16 wks Grp2: Glipizide Varied, glucose: 140 mg/dL, HbA1c: 8% Start: 5 mg D: 16 wks | | Grp1: 2 events Grp2: 3 events | | | | Grp1: 2 (2) Grp2: 2 (2)
Karter, 2005^207^ | | Cohort | | Grp1: Pioglitazone NR Grp2: Any sulfonylurea NR | | | | | | Def: ICD-9-CM codes for primary discharge diagnosis Coll: Passive Timing: Unspecified ITT: NR Grp1: HR: 1.28 (CI: 0.85-1.92), p: 0.2 Grp2: ref
Rajagopalan, 2005^206^ | | Cohort | | Grp1: Rosiglitazone NR Grp2: Sulfonylurea NR | | | | Def: ICD9 code liver failure or hepatitis Coll: Passive Timing: Unspecified ITT: NR Grp1: (0.4) Grp2: (1)
Rajagopalan, 2005^206^ | | Cohort | | Grp1: Pioglitazone NR Grp2: Sulfonylurea NR | | | | Def: visit with ICD9 code liver failure or hepatitis Coll: Passive Timing: Unspecified ITT: NR Grp1: (0.5) Grp2: (1)
Thiazolidinedione versus meglitinides
Jovanovic, 2004^110^ | | RCT | | Grp1: Pioglitazone Fixed Start: 30 mg Grp2: Repaglinide Varied Start: 0.5 mg if HbA1c<8% or 1 mg if HbA1c >8%, Max: 4 mg per meal D: 12 weeks | | Def: Severe: needed assistance, Mild or moderate: <50mg/dl Grp1: Severe: 0, Mild or moderate: 2 (3) Grp2: Severe: 0, Mild or moderate: 5 (8) | | | | | | | | Def: Diarrhea Grp1: (3) Grp2: (5)
Raskin, 2004^109^ | | RCT | | Grp1: Rosiglitazone Varied Start: 2 mg bid, Max: 4 mg bid D: 12 weeks Grp2: Repaglinide Varied Start: 0.5 mg per meal if HbA1c≤8% or 1 mg if >8%, Max: 4 mg per meal D: 12 weeks | | Grp1: Severe: 0, Mild or moderate: 1 (2) Grp2: Severe: 0, Mild or moderate: 4 (6)
Kahn, 2008^213^ | | RCT | | Grp1: Rosiglitazone Varied, glucose: <140 mg/dL Start dose: 4 mg, Max: 8 mg Grp2: Glyburide Varied, glucose: <140 mg/dL Start dose: 2.5 mg, Max: 15 mg | | | | | | | | Def: Fractures (NS) Coll: NR Timing: Unspecified ITT: Yes Grp1: 1.86/100 patient-years HR: 1.61 (CI: 1.14-2.28), p: 0.0069 Grp2: 1.15/100 patient-years
Sulfonylurea versus DPP-IV inhibitors
Scott, 2007^111^ | | RCT | | Grp1: Glipizide Varied, glucose: <160 mg/dl Start: 5 mg, Max: 20 mg D: 6 wks Grp2: Sitagliptin Fixed Start: 5 mg bid to 50 mg bid | | Def: Mild or moderate Grp1: 21 (17.1) Grp2: 0 (0)
Sulfonylurea versus meglitinides
Jibran, 2006^112^ | | RCT | | Grp1: Glibenclamide Varied, FPG < 130 mg/dl, PPG < 175 mg/dl Start: 5 mg, Max: 15 mg Grp2: Repaglinide Varied, FPG < 130 mg/dl, PPG < 175 mg/dl Start: 0.5 mg TDS, Max: 1.5 mg TDS | | Def: Mild, moderate or severe Grp1: 0 (0) Grp2: 0 (0)
Vakkilainen, 2002^119^ | | RCT | | Grp1: Glibenclamide Varied Start: 5 mg, Max: 10 mg Grp2: Nateglinide Fixed Start: 120 mg tid | | Grp1: 3 (12.5) Grp2: 0 (0)
Madsbad, 2001^114^ | | RCT | | Grp1: Glipizide Varied Start: 5 mg, Max: 15 mg Grp2: Repaglinide Varied Start: 0.5 mg, Max: 4.0 mg tid | | Def: Severe Grp1: 0 (0) Grp2: 0 (0)
Landgraf, 1999^115^ | | RCT | | Grp1: Glibenclamide Varied Max: 10.5 mg Grp2: Repaglinide Varied Max: 4.0 mg tid | | Def: Mild or moderate Grp1: 9 (9.0) Grp2: 9 (9.6)
Marbury, 1999^117^ | | RCT | | Grp1: Glyburide Varied Start: 2.5 mg, Max: 15mg Grp2: Repaglinide Varied Start: 0.5 mg, Max: 12 mg | | Grp1: Severe: 2 (1), Mild or moderate: 35 (18) Grp2: Severe: 5 (1), Mild or moderate: 54 (14)
Wolffenbuttel, 1999^116^ | | RCT | | Grp1: Glyburide Varied Start: 1.75 mg, Max: 10.5 mg D: 6-8 weeks Grp2: Repaglinide Varied Start: 1.5 mg, Max: 12.0 mg D: 6-8 weeks | | Def: Mild or moderate Grp1: 13 (9) Grp2: 26 (9)
Wolffenbuttel, 1993^118^ | | RCT | | Grp1: Glibenclamide Varied Start: 5 mg, Max: 15 mg Grp2: Repaglinide Varied Start: 0.5 mg, Max: 4 mg tid | | Grp1: Severe: 0 (0), Mild or moderate: 1 (7) Grp2: Severe: 0 (0), Mild or moderate: 0 (0)
Sulfonylurea versus GLP-1 agonists
Seino, 2010^121^ | | RCT | | Grp1: Glibenclamide Varied, prespecified dose Start: 1.25 mg; Max: 2.5 mg D: 4 weeks Grp2: Liraglutide Varied, prespecified dose Start: 0.3 mg; Max: 0.9 mg D: 2 weeks | | Coll: Passive Timing: Unspecified ITT: No Grp1: Symptoms: 45 (34.1); 228 events; IR: 3.927/year Severe: 0 (0) Grp2: Symptoms: 36 (13.4) 61 events; IR: 0.525/year Severe: 0 (0) | | | | | | | | Def: Diarrhea; Constipation Coll: NR Timing: Unspecified ITT: No Grp1: (3.8; 3.8) Grp2: (6.3; 5.6) | | Def: Pancreatitis Coll: NR Timing: Unspecified ITT: No Grp1: 0 (0) Grp2: 0 (0)
Garber, 2009^122^ | | RCT | | Grp1: Glimepiride Varied, prespecified dose Start: 2 mg, Max: 8 mg D: 2 weeks Grp2: Liraglutide Varied, prespecified dose Start: 0.6 mg, Max 1.8 mg D: 2 weeks | | Def: Not requiring assistance, PG < 3.1 mmol/L Coll: NR Timing: Unspecified ITT: No Grp1: 24 events Grp2: 8 events | | | | | | | | Def: Total GI events; Nausea and vomiting Coll: Passive Timing: Unspecified ITT: No Grp1: (26, 51) Grp2: (12, 38) | | Def: Pancreatitis Coll: Passive Timing: Unspecified ITT: No Grp1: 0 (0) Grp2: 1 (<1)
Garber, 2009^122^ | | RCT | | Grp1: Glimepiride Varied, prespecified dose Start: 2 mg, Max: 8 mg D: 2 weeks Grp2: Liraglutide Varied, prespecified dose Start: 0.6 mg, Max 1.2 mg D: 2 weeks | | Def: Not requiring assistance, PG < 3.1 mmol/L Coll: NR Timing: Unspecified ITT: No Grp1: 24 events Grp2: 12 events | | | | | | | | Def: Total GI events; Nausea and vomiting Coll: Passive Timing: Unspecified ITT: No Grp1: (26, 49) Grp2: (12, 39) | | Def: Pancreatitis Coll: Passive Timing: Unspecified ITT: No Grp1: 0 (0) Grp2: 1 (<1)
Madsbad, 2004^120^ | | RCT | | Grp1: Glimepiride Varied, FPG < 7 mmol/L Start: 1 mg; Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.75 mg | | Def: Glucose < 2.8 mmol/L Coll: Active Timing: Specified ITT: Yes Grp1: 4 (15) Grp2: 0 (0)
Madsbad, 2004^120^ | | RCT | | Grp1: Glimepiride Varied, FPG < 7 mmol/L Start: 1 mg; Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.60 mg | | Def: Glucose < 2.8 mmol/L Coll: Active Timing: Specified ITT: Yes Grp1: 4 (15) Grp2: 1 (3)
Madsbad, 2004^120^ | | RCT | | Grp1: Glimepiride Varied, FPG < 7 mmol/L Start: 1 mg; Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.45 mg | | Def: Glucose < 2.8 mmol/L Coll: Active Timing: Specified ITT: Yes Grp1: 4 (15) Grp2: 0 (0)
Madsbad, 2004^120^ | | RCT | | Grp1: Glimepiride Varied, FPG < 7 mmol/L Start: 1 mg; Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.225 mg | | Def: Glucose < 2.8 mmol/L Coll: Active Timing: Specified ITT: Yes Grp1: 4 (15) Grp2: 0 (0)
Madsbad, 2004^120^ | | RCT | | Grp1: Glimepiride Varied, FPG < 7 mmol/L Start: 1 mg; Max: 4 mg D: 4 weeks Grp2: Liraglutide Fixed Mean: 0.045 mg | | Def: Glucose < 2.8 mmol/L Coll: Active Timing: Specified ITT: Yes Grp1: 4 (15) Grp2: 0 (0)
Metformin + thiazolidinedione versus metformin + sulfonylurea
Hamann, 2008^123^ | | RCT | | Grp1: Metformin + rosiglitazone Varied, glucose: 6.1 mmol/l Max: 2 g; Start: 4 mg, Max: 8 mg D: 12 wks Grp2: Metformin + sulfonylurea Varied, glucose: 6.1 mmol/l Max: 2 g; Start: 5 mg, Max: 15 mg D: 12 wks | | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 18 (6) Grp2: 90 (30) | | | | | | | | Coll: Active Timing: Specified ITT: Yes Grp1: (13) Grp2: (18)
Comaschi, 2007^129^ | | RCT | | Grp1: Metformin + pioglitazone Varied Max: 3 g; Start: 15 mg, Max: 30 mg D: NR, 22 wks Grp2: Metformin + sulfonylurea Varied, HbA1c: 7.50% Start: 400 mg, Max: 3 g; Start: 2.5 mg D: 22 wks | | Def: Mild or moderate Grp1: 0 (0) Grp2: 1 (1)
Bakris, 2006^125^ | | RCT | | Grp1: Metformin + rosiglitazone Varied, glucose: ≤6.6 mmol/L Unclear; Start: 4 mg D: 3 wks Grp2: Metformin + glyburide Varied, glucose: ≤ 6.6 mmol/L Unclear; Start: 5 mg D: 3 wks | | Def: Mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 2 (1) Grp2: 22 (12)
Umpierrez, 2006^126^ | | RCT | | Grp1: Metformin + pioglitazone Varied, glucose: <120 mg/dl, HbA1c: <8.0% Start: 1.54 g, Max: 1.57 g; Start: 30 mg, Max: 45 mg Grp2: Metformin + glimepiride Varied, glucose: <120 mg/dL Start: 1.47 g, Max: 1.49 g; Start: 2 mg, Max: 8 mg D: NR, 6 wks | | Def: mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 10 (9) Grp2: 32 (33) | | | | | | | | Def: Diarrhea Coll: Active Timing: Specified ITT: Yes Grp1: (4.7) Grp2: (6)
Garber, 2006^128^ | | RCT | | Grp1: Metformin + rosiglitazone Varied Start: 1500 or 2000 mg, Max: 2000 mg; Start: 4 mg, Max: 8 Grp2: Metformin + glibenclamide Varied Start: 1000 mg, Max: 2000; Start: 5 mg , Max: 10 mg | | Grp1: Severe: 0 (0), Mild or moderate: 2 (1) Grp2: Severe: 7 (4), Mild or moderate: 53 (33) | | | | | | | | Def: Diarrhea + abdominal pain + other GI symptoms; Diarrhea; Abdominal pain Grp1: (10; 3; 4) Grp2: (11; 6; 6)
Hanefeld, 2006^201^ | | RCT | | Grp1: Metformin + pioglitazone Fixed; Varied Mean: 1900 mg; Start: 30 mg, Max: 45 mg Grp2: Metformin + glibenclamide NR; Varied Mean: 1900 mg; Start: 3.5 mg, Max: 5 mg | | Def: Severe Coll: NR Timing: Unspecified ITT: NR Grp1: 5 (2) Grp2: 34 (14)
Yang, 2003^139^ | | RCT | | Grp1: Metformin + sulfonylurea Fixed Grp2: Rosiglitazone + sulfonylurea Fixed | | | | Def: AST or ALT 3 x ULN Coll: NR Timing: Unspecified ITT: NR Grp1: 0 (0) Grp2: 0 (0)
Derosa, 2005^159^ | | RCT | | Grp1: Metformin + rosiglitazone Fixed Start: 1500 mg; Start: 4 mg Grp2: Metformin + glimepiride Fixed Start: 1500 mg; Start: 2 mg | | | | | | | | | | Def: Transient flatulence Grp1: (4.2) Grp2: (2.1)
Metformin + thiazolidinedione versus metformin + meglitinides
Raskin, 2009^131^ | | RCT | | Grp1: Metformin + rosiglitazone Varied, prespecified target dose Start: 1000 mg, Max: 2500 mg; Start: 4, Max: 8 mg D: 4 wks Grp2: Metformin + repaglinide Varied Start: 1000 mg, Max: 2500 mg; Start: 4 mg, Max: 10 mg D: 4 wks | | Coll: Active Timing: Specified ITT: NR Grp1: Severe: 0 (0), Mild or moderate: 1 (1) Grp2: Severe: 0 (0), Mild or moderate: 8 (4) | | | | | | | | | | Def: Macular edema Grp1: 2 (1) Grp2: 0 (0)
Metformin + thiazolidinedione versus metformin + DPP-IV inhibitors
Scott, 2008^85^ | | RCT | | Grp1: Metformin + rosiglitazone Fixed Start: > 1500 mg; Mean: 8 mg D: 10 wks Grp2: Metformin + sitagliptin Fixed Start: > 1500 mg; Mean: 100 mg D: 10 wks | | Def: Mild or moderate Coll: NR Timing: Unspecified ITT: No Grp1: 1 (1) Grp2: 1 (1) | | | | | | | | Def: Diarrhea, nausea, abdominal pain, vomiting Coll: NR Timing: Unspecified ITT: No Grp1: (7) Grp2: (1)
Metformin + thiazolidinedione versus metformin + GLP-1 agonists
Defronzo, 2010^132^ | | RCT | | Grp1: Metformin + rosiglitazone Varied, prespecified dose NR: Start: 4 mg; Max: 8 mg Grp2: Metformin + exenatide Varied, prespecified dose NR: Start: 0.010 mg; Max: 0.02 mg BID D: 2 months | | Coll: NR Timing: Unspecified ITT: No Grp1: Severe: 0 (0); Mild/moderate: 0 (0) Grp2: Severe: 0 (0); Mild/moderate: 2 (4) | | | | | | | | Def: Vomiting; Diarrhea Coll: NR Timing: Unspecified ITT: No Grp1: (0; 9) Grp2: (49; 16)
Metformin + thiazolidinedione versus thiazolidinedione + sulfonylurea
Comaschi, 2007^129^ | | RCT | | Grp1: Metformin + pioglitazone Varied Max: 3 g; Start: 15 mg, Max: 30 mg D: NR; 22 wks Grp2: Pioglitazone + sulfonylurea Varied, HbA1c: 7.50% Start: 15 mg, Max: 30 mg; Unclear D: 22 wks; NR | | Def: Mild or moderate Grp1: 0 (0) Grp2: 0 (0)
Rosak, 2006^183^ | | Cohort | | Grp1: Metformin + rosiglitazone NR Unclear; Start: 4mg, Max: 8mg Grp2: Rosiglitazone + sulfonylurea Varied Start: 4mg, Max: 8mg; NR | | Def: Hypoglycemic events Coll: Active Timing: Specified ITT: Yes Grp1: 0.05/100 patient-years Grp2: 0.47/100 patient-years | | | | Def: Investigator reported Coll: Active Timing: Specified ITT: Yes Grp1: 0.13/100 patient-years Grp2: 0.47/100 patient-years
Derosa, 2005^127^ | | RCT | | Grp1: Metformin + rosiglitazone Fixed Start dose: 500 mg tid, Max: 500 mg tid; Start dose: 4mg, Max: 4 mg Grp2: Metformin + glimepiride Fixed Start dose: 500 mg tid, Max: 500 mg tid; Start dose: 2 mg, Max: 2 mg | | | | Def: Transiently elevated LFT to 1.5 times upper limit of normal Coll: NR Timing: Unspecified ITT: NR Grp1: 3 events out of 48 participants Grp2: NR
Metformin + sulfonylurea versus metformin + meglitinides
Dimic, 2009^199^ | | Non-randomized trial | | Grp1: Metformin + glimepiride Fixed NR Grp2: Metformin + repaglinide Fixed Mean: 2000 mg; Mean: 6 mg | | Coll: Active Timing: Specified ITT: NR Grp1: 7 (23) Grp2: 5 (17)
Schwarz, 2008^152^ | | RCT | | Grp1: Metformin + glyburide Varied, glucose: <120 mg/dL Start: 500 mg, Max: 2000 mg; Start: 1.25 mg, Max: 10 mg D: 12 wks Grp2: Metformin + nateglinide Varied, glucose: <120 mg/dL Start: 500 mg, Max: 2000 mg; Start: 360 mg, Max: 360 mg D: 12 wks | | Def: Severe Coll: Active Timing: Specified ITT: Yes Grp1: 1 (3) Grp2: 0 (0) | | | | | | | | Def: Diarrhea Coll: Active Timing: Specified ITT: Yes Grp1: (20) Grp2: (22.9)
Gerich, 2005^136^ | | RCT | | Grp1: Metformin + glyburide Varied, glucose: FPG ≥6.7 mmol/L Start: 500 mg, Max: 2000 mg, Mean: 1105 mg; Start: 1.25 mg, Max: 10 mg, Mean: 5.1 mg D: 12 wks Grp2: Metformin + nateglinide Varied, glucose: FPG ≥6.7 mmol/L; Fixed Start: 500 mg, Max: 2000 mg, Mean: 1459 mg; Start: 120 mg, Mean: 357 mg D: 12 wks | | Def: Severe Coll: NR Timing: Unspecified ITT: Yes Grp1: Mild or moderate:38 (18); Severe: 2 (1) Grp2: Mild or moderate:18 (8); Severe: 0 (0)
Metformin + sulfonylurea versus metformin + DPP-IV inhibitors
Seck, 2010^134^ | | RCT | | Grp1: Metformin + sitagliptin Fixed NR Grp2: Metformin + glipizide Fixed; Varied NR; Start: 5 mg, Max: 20 mg; Mean: 9.2 mg | | Coll: Active Timing: Specified ITT: Yes Grp1: Severe: 18 (3) Mild/moderate: 31 (5.3) Grp2: Severe: 2 (<1) Mild/moderate: 199 (34.1)
Nauck, 2007^133^ | | RCT | | Grp1: Metformin + glipizide Varied; Varied, glucose: <6.1 mmol/l NR; Start: 5 mg, Max: 20 mg D: NR, 18 wks Grp2: Metformin + sitagliptin Varied; Fixed NR | | Def: Severe Coll: Active Timing: Specified ITT: Yes Grp1: 7 (1) Grp2: 1 (<1) | | | | | | | | Def: Diarrhea, abdominal pains, nausea, vomiting Coll: Active Timing: Specified ITT: Yes Grp1: 69 (12) Grp2: 70 (12)
Metformin + sulfonylurea versus metformin + GLP-1 agonists
Derosa, 2010^44^ | | RCT | | Grp1: Metformin + glibenclamide NR Mean: 1500 mg; Start: 7.5 mg; Max: 15 mg Grp2: Metformin + exenatide NR NR; Start: 10 mcg; Max: 20 mcg | | Def: FPG < 60 mg/dL Coll: Active Timing: Specified ITT: No Grp1: 3 (5) Grp2: 0 (0) | | | | | | | | Def: Vomiting; Diarrhea Coll: Active Timing: Specified ITT: No Grp1: (2; 2) Grp2: (2; 3)
Nauck, 2009^92^ | | RCT | | Grp1: Metformin + glimepiride Fixed; Varied Mean: 2000 mg; Start: 1 mg; Max: 4 mg Grp2: Metformin + liraglutide Fixed; Varied Start: 0.6 mg; Max: 1.8 mg | | Coll: Passive Timing: Unspecified ITT: Yes Grp1: Severe: 0 (0) Mild/moderate: (17) Grp2: Grp1: Severe: 0 (0) Mild/moderate: (3) | | | | | | | | Def: Nausea, vomiting, and diarrhea Coll: Passive Timing: Unspecified ITT: Yes Grp1: (17) Grp2: (44)
Nauck, 2009^92^ | | RCT | | Grp1: Metformin + glimepiride Fixed; Varied Mean: 2000 mg; Start: 1 mg; Max: 4 mg Grp2: Metformin + liraglutide Fixed; Varied Start: 0.6 mg; Max: 1.2 mg | | Coll: Passive Timing: Unspecified ITT: Yes Grp1: Severe: 0 (0) Mild/moderate: (17) Grp2: Grp1: Severe: 0 (0) Mild/moderate: (3) | | | | | | | | Def: Nausea, vomiting, and diarrhea Coll: Passive Timing: Unspecified ITT: Yes Grp1: (17) Grp2: (40)
Metformin + sulfonylurea versus metformin + premixed insulin
Malone, 2003^137^ | | RCT | | Grp1: Metformin + glibenclamide Varied, glucose: fasting and pre-meal <7mmol.L, 2-hour post-prandial <10mmol/L Max: 2550 mg, Mean: 1968 mg; Mean: 14.2 mg D: 4 wks Grp2: Metformin + lispro 75/25 fasting and pre-meal <7mmol.L, 2-hour post-prandial <10mmol/L Max: 2550 mg; Mean: 0.19U/kg in am and 0.14 U/kg in evening D: 4 wks | | Def: Symptomatic or BG <3.5mmol/l Timing: Unspecified ITT: NR Grp1: (1) Grp2: (1.3)
Kvapil, 2006^138^ | | RCT | | Grp1: Metformin + glibenclamide Fixed; Varied Mean: 1660 mg; Start: 1.75 mg, Max: 10.5 mg, Mean: 6.58 mg Grp2: Metformin + aspart 70/30 Fixed; Varied, glucose: 5 - 8 mmol/L Mean: 1660 mg; Start: 0.2 U/kg bid, Mean: 0.30 U/kg bid | | Coll: NR Timing: Unspecified ITT: Yes Grp1: Severe: 0, Mild or moderate: 9 (8) Grp2: Severe: 0, Mild or moderate: 13 (12)
Metformin + sulfonylurea versus thiazolidinedione + sulfonylurea
van der Meer, 2009^141^ | | RCT | | Grp1: Metformin + glimepiride Fixed; Varied Start: 1000 mg, Max: 2000 mg; NR D: NR; 8 wks Grp2: Pioglitazone + glimepiride Fixed, Varied Start: 15 mg, Max: 30 mg; NR D: 2 wks; NR | | | | | | Grp1: 0 (0) Grp2: 0 (0)
Seufert, 2008^142^ | | RCT | | Grp1: Metformin + sulfonylurea Fixed Max: 2550 mg, Mean: 2081 mg; NR D: 12 wks Grp2: Pioglitazone + sulfonylurea Fixed Max: 45 mg, Mean: 37 mg; NR D: 12 wks | | Coll: NR Timing: Unspecified ITT: NR Grp1: 50 (22) Grp2: 36 (17) | | | | | | | | Def: Diarrhea Coll: NR Timing: Unspecified ITT: NR Grp1: (14.4) Grp2: (3.4)
Hanefeld, 2004^140^ | | RCT | | Grp1: Metformin + sulfonylurea Varied; Fixed Start: 850 mg, Max: 2550 mg; NR D: 12 wks Grp2: Pioglitazone + sulfonylurea Varied; Fixed Start: 15 mg (, Max: 45 mg; NR D: 12 wks | | Def: Serious Grp1: 0 (0) Grp2: 0 (0) | | | | | | | | Def: Diarrhea Grp1: (12.2) Grp2: (23.4)
Yang, 2003^139^ | | RCT | | Grp1: Metformin + sulfonylurea Fixed Start: 1000 mg; NR Grp2: Rosiglitazone + sulfonylurea Fixed Start: 4mg; NR | | | | | | | | | | Def: Diarrhea Grp1: NR Grp2: 2 cases
Metformin + DPP-IV inhibitor versus metformin + GLP-1 agonist
Pratley, 2010^143^ | | RCT | | Grp1: Metformin + sitagliptin Varied, HbA1c : 7.5% - 10% NS; Max: 100 mg Grp2: Metformin + liraglutide Varied, HbA1c: 7.5% - 10% NS; Start: 0.6 mg Max: 1.2 mg | | | | | | | | | | Def: GI events Coll: NR Timing: Unspecified ITT: No Grp1: 4 (2) Grp2: 3 (1) | | Def: Neoplasm Coll: NR Timing: Unspecified ITT: No Grp1: 1 (<1) Grp2: 0 (0) Def: Pancreatitis Grp1: 0 (0) Grp2: 0 (0)
Pratley, 2010^143^ | | RCT | | Grp1: Metformin + sitagliptin Varied, HbA1c : 7.5% - 10% NS; Max: 100 mg Grp2: Metformin + liraglutide Varied, HbA1c: 7.5% - 10% NS; Start: 0.6 mg Max: 1.8 mg | | | | | | | | | | Def: GI events Coll: NR Timing: Unspecified ITT: No Grp1: 4 (2) Grp2: 3 (1) | | Def: Neoplasm Coll: NR Timing: Unspecified ITT: No Grp1: 1 (<1) Grp2: 1 (<1) Def: Pancreatitis Grp1: 0 (0) Grp2: 0 (0)
Metformin + GLP-1 agonist versus metformin + basal insulin
Bunck, 2009^144^ | | RCT | | Grp1: Metformin + exenatide Fixed; Varied, HbA1c: 7.1%-7.5% Mean: 2058 mg; Start: 5 ug bid, 20 ug tid Grp2: Metformin + glargine Fixed; Varied, SMBG: 4.5-5.5 mmol/L Mean: 1798 mg; Start: 10 U, Mean: 33.6 U qd | | Def: <3.3mmol/L Coll: Active Timing: Unspecified ITT: NR Grp1: (8.3) Grp2: (24.2) | | | | | | | | Def: Mild to moderate nausea, vomiting, diarrhea Grp1: NR Grp2: (50) | | Def: Pancreatitis Grp1: 1 (3) Grp2: 0 (0)
Metformin + basal insulin versus metformin + premixed insulin
Davies, 2007^147^ | | RCT | | Grp1: Metformin + NPH Varied, glucose < 6.0 mmol/L NR; Start: 10 IU/kg; Mean: 0.58 IU/kg D: 6 weeks Grp2: Metformin + BHI 70/30 Varied, glucose < 6.0 mmol/L NR; Start: 10 IU bid, Mean: 0.63 IU bid | | Def: Clinical hypoglycemia Coll: Active Timing: Specified ITT: NR Grp1: (25) Grp2: (29.6)
Raskin, 2007^146^ | | RCT | | Grp1: Metformin + glargine Fixed; Varied, premeal glucose: 4.4 - 6.1mmol/L NR; Start: 12 U/kg QD, Mean: 0.57 IU/kg QD Grp2: Metformin + aspart 70/30 Fixed; Varied, premeal glucose: 4.4 - 6.1mmol/L NR; Start: 12 IU/kg BID, Mean: 0.91 IU/kg | | Def: mild or moderate Coll: Active Timing: Specified ITT: Yes Grp1: 11 (14) Grp2: 33 (42)
Robbins, 2007^145^ | | RCT | | Grp1: Metformin + glargine Fixed; Varied, glucose: <6.7 mmol/l Start: 500 mg bid, Max: 1000 mg bid, Mean: 1636 mg; Mean: 0.6 U/kg QD Grp2: Metformin + insulin lispro 50/50 Fixed; Varied, glucose: <6.7 mmol/l Start: 500 mg bid, Max: 1000 mg bid, Mean: 1641 mg; Mean: 0.7 U/kg tid | | Def: Coll: Active Timing: Specified ITT: Yes Grp1: Severe: 2 (1), Mild or moderate: 75 (47) Grp2: Severe: 3 (2), Mild or moderate: 79 (50) | | | | | | | | Def: Diarrhea Coll: Active Timing: Specified ITT: Yes Grp1: (5.7) Grp2: (6.4)
Malone, 2005^165^ | | RCT | | Grp1: Metformin + lispro 75/25 Varied, pre-meal glucose 90-126 mg/dL 2-hr PPG 144-180 mg/dL Start: 1500 mg; Max: 2550 mg; Mean: 2146 mg; Mean: 0.42 U/kg bid D: 4 weeks; 16 weeks Grp2: Metformin + glargine Varied, glucose 90-126 mg/dL Start: 1500 mg; Max: 2550 mg; Mean: 2146 mg; Mean: 0.36 U/kg qd D: 4 weeks; 16 weeks | | Def: Overall Coll: Active Timing: Specified ITT: NR Grp1: 0.61 episodes/ patient/30 days Grp2: 0.44 episodes/ patient/30 days
Malone, 2004^164^ | | RCT | | Grp1: Metformin + glargine Fixed; Varied, glucose: 90 – 126 mg/dL Start: 1500 mg, Max: 2550 mg; Mean: 0.57 U/kg qd Grp2: Metformin + lispro 75/25 Varied, glucose: 90 – 126 mg/dL Start: 1500 mg, Max: 2550 mg; Mean: 0.62 U/kg bid | | Def: Coll: Active Timing: Specified ITT: Yes Grp1: Severe: 0 (0), Mild or moderate: 40 (40) Grp2: Severe: 0 (0), Mild or moderate: 57 (57) | | | | Coll: Active Timing: Specified ITT: Yes Grp1: 0 (0) Grp2: 1 (1)

D = duration; Def = definition; DPP-4 = dipeptidyl peptidase-4; dys = days; fsg = fasting serum glucose; GLP-1 = glucagon-like peptidase-1; Grp = group; HR = hazard ratio; ICD = International Classification Disease; IR = incident rates; ITT = intention to treat; mg/day = milligram per day; mg/dl = milligrams/deciliter; mg = milligram; mmol/l = millimoles per liter; NR = not reported; NSG = non significant; od = once a day; SU = sulfonylurea; tid = twice a day; wks = weeks

Table 13 Study quality of randomized controlled trials reporting of the comparative effectiveness and safety of diabetes medications

Table 14 Study quality of observational studies reporting of the comparative safety of diabetes medications