# Excluded Articles

Aaboe K, Knop FK, Vilsboll T, et al. Twelve weeks treatment with the DPP-4 inhibitor sitagliptin improves glycaemic control, but does not improve GLP-1 secretion, in patients with type 2 diabetes - A randomised trial. Diabetologia: Diabetologia. 2009;52(S1):S294. Other reason.
Abbasi AA, Kasmikha R, Sotingeanu DG. Metformin-induced lacticacidemia in patients with type 2 diabetes mellitus. Endocr Pract. 2000;6(6):442-6. Does not have a drug comparison of interest. [pmid: 11155215].
Abbatecola AM, Paolisso G. Rosiglitazone and cognitive stability in older persons with type 2 diabetes and mild cognitive impairment. Diabetologia: Diabetologia. 2009;52(S1):S67. Does not meet the study design criteria.
Abbatecola AM, Rizzo MR, Barbieri M, et al. Postprandial plasma glucose excursions and cognitive functioning in aged type 2 diabetics. Neurology. 2006;67(2):235-40. Does not apply. [pmid: 16864814].
Abe M, Okada K, Kikuchi F, Matsumoto K. Clinical investigation of the effects of pioglitazone on the improvement of insulin resistance and blood pressure in type 2-diabetic patients undergoing hemodialysis. Clin Nephrol. 2008;70(3):220-8. Does not apply. [pmid: 18793563].
Abraira C, Duckworth WC, Moritz T. Glycaemic separation and risk factor control in the Veterans Affairs Diabetes Trial: an interim report. Diabetes Obes Metab. 2009;11(2):150-6. No original data. [pmid: 18671796].
Agarwal R. Anti-inflammatory effects of short-term pioglitazone therapy in men with advanced diabetic nephropathy. Am J Physiol Renal Physiol. 2006;290(3):F600-5. Does not apply. [pmid: 16159895].
Agrawal A, Sautter MC, Jones NP. Effects of rosiglitazone maleate when added to a sulfonylurea regimen in patients with type 2 diabetes mellitus and mild to moderate renal impairment: a post hoc analysis. Clin Ther. 2003;25(11):2754-64. Does not have a drug comparison of interest. [pmid: 14693302].
Aguilar C, Reza A, Garcia JE, Rull JA. Biguanide related lactic acidosis: incidence and risk factors. Arch Med Res. 1992;23(1):19-24. Does not have a drug comparison of interest. [pmid: 1308787].
Ahren B, Lundquist I, Schersten B. Effects of glipizide on various consecutive insulin secretory stimulations in patients with type 2 diabetes. Diabetes Res. 1986;3(6):293-300. Less than 40 subjects with type 2 diabetes. [pmid: 3530592].
Ahren B, Simonsson E, Larsson H, et al. Inhibition of dipeptidyl peptidase IV improves metabolic control over a 4-week study period in type 2 diabetes. Diabetes Care. 2002;25(5):869-75. Study duration less than 3 months. [pmid: 11978683].
Akanuma Y, Kosaka K, Kanazawa Y, Kasuga M, Fukuda M, Aoki S. Long-term comparison of oral hypoglycemic agents in diabetic retinopathy. Gliclazide vs. other sulfonylureas. Diabetes Res Clin Pract. 1988;5(2):81-90. Does not have a drug comparison of interest. [pmid: 3416710].
Alba M, Ahren B, Inzucchi SE, et al. Initial combination therapy with sitagliptin and pioglitazone: Complementary effects on postprandial glucose and islet cell function. Can J Diabetes. 2009;33(3):319-20. Does not meet the study design criteria.
Albertini JP, McMorn SO, Chen H, Mather RA, Valensi P. Effect of rosiglitazone on factors related to endothelial dysfunction in patients with type 2 diabetes mellitus. Atherosclerosis. 2007;195(1):e159-66. Does not have a drug comparison of interest. [pmid: 17280678].
Alfonso A, Koops MK, Mong DP, Vigersky RA. Glycemic control with regular versus lispro insulin sliding scales in hospitalized Type 2 diabetics. J Diabetes Complications. 2006;20(3):153-7. Does not have a drug comparison of interest. [pmid: 16632234].
Aljabri K, Kozak SE, Thompson DM. Addition of pioglitazone or bedtime insulin to maximal doses of sulfonylurea and metformin in type 2 diabetes patients with poor glucose control: a prospective, randomized trial. Am J Med. 2004;116(4):230-5. Does not have a drug comparison of interest. [pmid: 14969650].
Allen KV, McAulay V, Sommerfield AJ, Frier BM. Hypoglycaemia is uncommon with a combination of antidiabetic drugs and bedtime NPH insulin for type 2 diabetes. Pract Diabetes Int. 2004;21(5):179-82. Does not meet the study design criteria.
Alvarez Guisasola F, Mavros P, Nocea G, Alemao E, Alexander CM, Yin D. Glycaemic control among patients with type 2 diabetes mellitus in seven European countries: findings from the Real-Life Effectiveness and Care Patterns of Diabetes Management (RECAP-DM) study. Diabetes Obes Metab. 2008;10(Suppl 1):8-15. Does not apply. [pmid: 18435669].
Ambrosius WT, Danis RP, Goff DC Jr, et al. Lack of association between thiazolidinediones and macular edema in type 2 diabetes: the ACCORD eye substudy. Arch Ophthalmol. 2010;128(3):312-8. Does not have a drug comparison of interest. [pmid: 20212201].
“PROactive” study shows Takeda’s ACTOS® (pioglitazone HCl) reduces heart attacks, strokes and deaths in patients with type 2 diabetes. Publ. Takeda Res. Lab. 2005. Other reason.
A randomised, multi-centre, phase IV, double-blind, parallel group study comparing the effects of 52Ć weeks administration of AVANDAMET and metformin plus sulphonylurea on change in HbA1c from baseline in overweight type 2 diabetics poorly controlled on metformin. Other reason.
A randomized double-blind trial of acarbose in type 2 diabetes shows improved glycemic control over 3 years (Diabetes Care 1999;22:960–964). Diabetes Care. 1999;22(11):1922. No original data.
Clinical news updates from the 2005 AHA Scientific Sessions. Formulary. 2006;41(1):18-26. No original data.
Comparison of the Blood Sugar Lowering Effect Between Repaglinide Plus Metformin and Repaglinide Alone in Type 2 Diabetics Not Previously Treated With Oral Sugar-lowering Drugs. ClinicalTrials.gov identifier: NCT00819741. Other reason.
Diabetes drugs may cause heart-failure hazard. Health News. 2004;10(1):15. Does not meet the study design criteria.
DPP-IV inhibitor better tolerated than metformin. Pharm. J. 2005;275(7370):436. No original data.
Drugs for type 2 diabetes. Treat Guidel Med Lett. 2008;6(71):47-54. No original data. [pmid: 18583949].
Dual PPAR agonist improves glycemic control, lipids in type 2 diabetes. Geriatrics. 2005;60(8):12. No original data. [pmid: 16104078].
Effect of AC2993 (synthetic exendin-4) compared with insulin glargine in patients with type 2 diabetes also using combination therapy with sulfonylurea and metformin. Eli Lilly Clinical Trial Registry Summary. 2007. Does not have a drug comparison of interest.
Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). UK Prospective Diabetes Study (UKPDS) Group. Lancet. 1998;352(9131):854-65. Does not have a drug comparison of interest. [pmid: 9742977].
Effect of Repaglinide and Metformin Combination Tablet or Rosiglitazone and Metformin in Fixed Dose Combination on Blood Glucose Control in Patients With Type 2 Diabetes. ClincalTrials.gov identifier: NCT00399711. Other reason.
Effects of metformin or repaglinide therapy for diabetes on serum markers for CVD. Nat Clin. Pract Endocrinol Metab. 2008;4(8):427. No original data.
Efficacy and safety of pioglitazone. Aust J Pharm. 2008;89(1064):62-3. No original data.
Efficacy and Safety of Repaglinide and Metformin Combination Therapy in Type 2 Diabetes Failing on OAD. ClinicalTrials.gov identifier: NCT00491725. Other reason.
Efficacy and Safety of Repaglinide and Metformin Combined in Type 2 Diabetes. ClinicalTrials.gov identifier: NCT00491725. Other reason.
Efficacy of exenatide [AC2993, synthetic exendin-4, LY2148568] compared with twice-daily biphasic insulin aspart in patients with type 2 diabetes using sulfonylurea and metformin. Eli Lilly Clinical Trial Registry Summary 2007. 2007. Other reason.
Erratum: Saxagliptin added to a submaximal dose of sulphonylurea improves glycaemic control compared with uptitration of sulphonylurea in patients with type 2 diabetes: A randomised controlled trial (International Journal of Clinical Practice 2009;63;1395–1406). Int J Clin Pract. 2010;64(2):277. Other reason.
Exenatide (Byetta) for type 2 diabetes. Med Lett Drugs Ther. 2005;47(1210):45-6. No original data. [pmid: 15933616].
First reports of serious adverse drug reactions in recent weeks. Drugs Ther Perspect. 2006;22(3):20-1. No original data.
Improved risk profile with pioglitazone. Br J Diabetes Vasc Dis. 2003;3(6):446. No original data.
Inhaled insulin superior to rosiglitazone in patients with uncontrolled type 2 diabetes. Formulary. 2003;38(7):408. No original data.
Insulin sensitizer affects lipids. Health News. 2005;11(1):2. No original data.
Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group. Lancet. 1998;352(9131):837-53. Does not have a drug comparison of interest. [pmid: 9742976].
Janumet. JAAPA. 2007;20(6):14. No original data.
Landmark PROactive trial investigates effect of ACTOS (pioglitazone HCl) on cardiovascular disease progression: More than 5,000 patients with type 2 diabetes studied. Publ. Takeda Res. Lab. 2004. 2004(-). Other reason.
New data shows Takeda’s ACTOS(registered trademark) (pioglitazone HCl) reduced heart attacks by 28 percent in people with type 2 diabetes. Publ. Takeda Res. Lab. 2005. 2005(-). Other reason.
Oral agents for type 2 diabetes reduce HbA1c, are weight neutral. Geriatrics: Geriatrics. 2006;61(9):2-13. No original data.
PERISCOPE: pioglitazone offers the right cluster of effects to confer benefit in type 2 diabetes. Cardiovasc J Afr. 2008;19(3):159-62. No original data. [pmid: 18568180].
Pre-meal inhaled insulin lowers HbA1c levels more effectively than rosiglitazone. Formulary. 2005;40(11):396. No original data.
Primary prevention of cerebrovascular and cardiovascular events with an oral antidiabetic agent in patients with type 2 diabetes at high risk for cerebral infarction, UMIN CTR. [Https://Center.Umin.Ac.Jp]. 2009. Not written in English.
PROactive study shows reduced heart attacks and strokes in type 2 diabetics on pioglitazone HCI (Actos) therapy. Cardiovasc J S Afr. 2005;16(5):286-7. discussion 287. No original data. [pmid: 16307165].
Rosiglitazone decreases coronary restenosis. Cardiol Rev. 2003;20(8):11. No original data.
Rosiglitazone increased heart failure but did not differ from metformin plus sulphonylurea for other CV outcomes at interim analysis. Evid.-Based Med. 2007;12(6):170. No original data. [pmid: 18063730].
Rosiglitazone plus metformin combination improves glycaemic control in diabetes. Pharm J. 2004;273(7317):375. No comparison group.
Sitagliptin combined with sulphonylureas: new indication. Other treatments are preferable. Prescrire Int. 2009;18(99):14-5. No original data.
Summaries for patients. A comparison of three insulin regimens (morning glargine, bedtime glargine, or bedtime neutral protamine Hagedorn) in addition to a pill for treating type 2 diabetes. Ann Intern Med. 2003;138(12):I33. No original data.
Summaries for patients. Comparison of two types of insulin added to diabetes pills in poorly controlled type 2 diabetes. Ann Intern Med. 2008;149(8):I-46. No original data. [pmid: 18794555].
The effect of adding exenatide to a thiazolidinedione in suboptimally controlled type 2 diabetes: A randomized trial (Annals of Internal Medicine 2007; 146:477–485). Ann Intern Med. 2007;146(12):896. No original data.
The efficacy and safety of glimepiride in the management of type 2 diabetes in Muslim patients during Ramadan. Diabetes Care. 2005;28(2):421-2. No comparison group. [pmid: 15677804].
Thiazolidinediones could exacerbate BMD loss in elderly women. Nat Clin Pract Endocrinol Metab. 2006;2(12):654-5. No original data.
RAS - Rosiglitazone and Atherosclerosis Study: a 1 year randomised, double-blind. parallel group, placebo controlled study to evaluate the efficacy of rosiglitazone on the progression of intima-media thickness in the carotid artery in subjects with insulin resistance syndrome and/or type 2 diabetes mellitus. Http://Ctr.Gsk.Co.Uk/Summary/Rosiglitazone/IV_049653_334.Pdf. 2004. No original data.
Anwar A, Azmi KN, Hamidon BB, Khalid BA. An open label comparative study of glimepiride versus repaglinide in type 2 diabetes mellitus Muslim subjects during the month of Ramadan. Med J Malaysia. 2006;61(1):28-35. Other reason. [pmid: 16708731].
Arauz-Pacheco C, Ramirez LC, Rios JM, Raskin P. Hypoglycemia induced by angiotensin-converting enzyme inhibitors in patients with non-insulin-dependent diabetes receiving sulfonylurea therapy. Am J Med. 1990;89(6):811-3. Does not meet the study design criteria. [pmid: 2123605].
Aronoff S, Rosenblatt S, Braithwaite S, Egan JW, Mathisen AL, Schneider RL. Pioglitazone hydrochloride monotherapy improves glycemic control in the treatment of patients with type 2 diabetes: a 6-month randomized placebo-controlled dose-response study. The Pioglitazone 001 Study Group. Diabetes Care. 2000;23(11):1605-11. Does not have a drug comparison of interest. [pmid: 11092281].
Asche CV, McAdam-Marx C, Shane-McWhorter L, Sheng X, Plauschinat CA. Association between oral antidiabetic use, adverse events and outcomes in patients with type 2 diabetes. Diabetes Obes Metab. 2008;10(8):638-45. Does not have a drug comparison of interest. [pmid: 17645555].
Ascic-Buturovic B. The effects of combined insulin and metformin therapy in obese patients with diabetes mellitus type 2 in the early stage of the disease. Bosn J Basic Med Sci. 2006;6(2):54-8. Does not meet the study design criteria. [pmid: 16879115].
Avery MA, Chittiboyina A, Patny A. Novel Tricyclic (alpha)-Alkoxyphenyl Propanoic Acid Derivatives: Dual PPAR(alpha)/(gamma) Agonists with Hypolipidemic and Antidiabetic Activity. Chemtracts. 2003;16(11):653-9. No original data.
Baba S, Nakagawa S, Takebe K, et al. Comparison of gliclazide and glibenclamide treatment in non-insulin-dependent diabetes. Tohoku J Exp Med. 1983;141(Suppl):693-706. Does not have a drug comparison of interest. [pmid: 6440313].
Babich MM, Pike I, Shiffman ML. Metformin-induced acute hepatitis. Am J Med. 1998;104(5):490-2. No comparison group. [pmid: 9626034].
Bachmann W, Sieger C, Haslbeck M, Lotz N. Combination of insulin and glibenclamide (gl) in the treatment of adult-onset diabetes (type 2). Diabetologia. 1981;21(3):21. Less than 40 subjects with type 2 diabetes.
Bahadori B, Trinker M, Wallner SJ, Yazdani-Biuki B, Wascher TC. Diabetes mellitus and weight control: Differences of respiratory quotient in type 2 diabetic obese subjects receiving sulfonylureas and non-diabetic obese controls. Nutrition. 2003;19(2):159-60. Does not have a drug comparison of interest. [pmid: 12591550].
Bain SC, Stella P, Cao A. Significantly reduced body mass index with liraglutide 1.2 mg treatment versus glimepiride may have an impact on cardiovascular risk in patients with type 2 diabetes. Diabetic Medicine: Diabet Med. 2010;27(Suppl 1):79. No original data.
Baksi A, James RE, Zhou B, Nolan JJ. Comparison of uptitration of gliclazide with the addition of rosiglitazone to gliclazide in patients with type 2 diabetes inadequately controlled on half-maximal doses of a sulphonylurea. Acta Diabetol. 2004;41(2):63-9. Does not have a drug comparison of interest. [pmid: 15224207].
Balkrishnan R, Rajagopalan R, Shenolikar RA, Camacho FT, Anderson RT. Outcomes associated with introduction of thiazolidinedione therapy in Medicaid enrolled patients with type 2 diabetes: an updated and expanded retrospective analysis. Curr Med Res Opin. 2006;22(3):551-9. Does not have a drug comparison of interest. [pmid: 16574038].
Ballani P, Tran MT, Navar MD, Davidson MB. Clinical experience with U-500 regular insulin in obese, markedly insulin-resistant type 2 diabetic patients. Diabetes Care. 2006;29(11):2504-5. Less than 40 subjects with type 2 diabetes. [pmid: 17065692].
Ballary C, Desai A. Efficacy and safety of a combination of metformin and rosiglitaone in patients with type 2 diabetes mellitus--a postmarketing study. J Indian Med Assoc. 2003;101(2):113-4. 123. No comparison group. [pmid: 12841496].
Barnes DJ, et al. Microalbuminuria in type 2 diabetic patients: a cross sectional study. Ann Clin Biochem. 1994;31:588-9. No original data. [pmid: 7880085].
Barnett AH, et al. Multicentre study to assess quality of life and glycaemic control of Type 2 diabetic patients treated with insulin compared with oval hypoglycaemic agents. Practical Diabetes International. 1996;13(6):179-83. Does not have a drug comparison of interest.
Barnett AH, Burger J, Johns D, et al. Tolerability and efficacy of exenatide and titrated insulin glargine in adult patients with type 2 diabetes previously uncontrolled with metformin or a sulfonylurea: a multinational, randomized, open-label, two-period, crossover noninferiority trial. Clin Ther. 2007;29(11):2333-48. Does not have a drug comparison of interest. [pmid: 18158075].
Barnett AH, Burger J, Johns D, et al. Tolerability and efficacy of exenatide and titrated insulin glargine in adult patients with type 2 diabetes previously uncontrolled with metformin or a sulfonylurea: a multinational, randomized, open-label, two-period, crossover noninferiority trial. Clin Ther. 2007;29(11):2333-48. Does not have a drug comparison of interest. [pmid: 18158075].
Barnett AH, Dreyer M, Lange P, Serdarevic-Pehar M. An open, randomized, parallel-group study to compare the efficacy and safety profile of inhaled human insulin (Exubera) with glibenclamide as adjunctive therapy in patients with type 2 diabetes poorly controlled on metformin. Diabetes Care. 2006;29(8):1818-25. Does not have a drug comparison of interest. [pmid: 16873786].
Barnett AH, Grant PJ, Hitman GA, et al. Rosiglitazone in Type 2 diabetes mellitus: an evaluation in British Indo-Asian patients. Diabet Med. 2003;20(5):387-93. Does not have a drug comparison of interest. [pmid: 12752488].
Barranco C. Pioglitazone improves cardiovascular risk markers for patients with diabetes. Nat. Clin. Pract. Cardiovasc. Med. 2005;2(9):438. No original data.
Barzilay JI, et al. Coronary artery disease and coronary artery bypass grafting in diabetic patients aged > or = 65 years (report from the Coronary Artery Surgery Study [CASS] Registry). Am J Cardiol. 1994;74(4):334-9. Does not apply. [pmid: 8059694].
Baynes C, Feher MD, Elkeles RS. The effect of treatment of non-insulin-dependent diabetes mellitus (NIDDM) on serum lipids and lipoproteins. Q J MED. 1989;72(267):579-87. No original data. [pmid: 2692063].
Bech P, Moses R, Gomis R. The effect of prandial glucose regulation with repaglinide on treatment satisfaction, wellbeing and health status in patients with pharmacotherapy naive Type 2 diabetes: a placebo-controlled, multicentre study. Qual Life Res. 2003;12(4):413-25. Does not have a drug comparison of interest. [pmid: 12797714].
Beck-Nielsen H, Lindskov HO, Richelsen B. Mechanism of action of glibenclamide in type 2 (non-insulin dependent) diabetes during long-term treatment. Diabetologia. 1982;23(2). 16. Does not apply.
Belcher G, Matthews DR. Safety and tolerability of pioglitazone. Exp Clin Endocrinol Diabetes. 2000;108:267-73. Does not meet the study design criteria.
Belden H. First in DPP-4 inhibitor class cleared for diabetes. Drug Topics. 2006;150(22). No original data.
Belden H. New diabetes treatment combines two drugs into one. Drug Topics. 2006;150(17). No original data.
Bell DS, Mayo MS. Improved glycemic control with use of oral hypoglycemic therapy with or without insulin. Endocr Pract. 1998;4(2):82-5. Does not apply. [pmid: 15251750].
Bell DS, Mayo MS. Outcome of metformin-facilitated reinitiation of oral diabetic therapy in insulin-treated patients with non-insulin-dependent diabetes mellitus. Endocr Pract. 1997;3(2):73-6. Does not apply. [pmid: 15251479].
Bell DS, Mayo MS. Weight loss in patients with diabetes treated with a metformin-sulfonylurea combination in comparison with twice-daily mixed insulin. Endocr Pract. 1998;4(6):360-4. Does not meet the study design criteria. [pmid: 15251708].
Bell DS, Yumuk V. Frequency of severe hypoglycemia in patients with non-insulin-dependent diabetes mellitus treated with sulfonylureas or insulin. Endocr Pract. 1997;3(5):281-3. Does not apply. [pmid: 15251781].
Bell DSH, Wyne KL. Use of fixed-dose oral combinations. Postgrad. Med. 2006;119(2). No original data.
Ben-Ami H, Nagachandran P, Mendelson A, Edoute Y. Drug-induced hypoglycemic coma in 102 diabetic patients. Arch Intern Med. 1999;159(3):281-4. Does not apply. [pmid: 9989540].
Bengel FM, Abletshauser C, Neverve J, et al. Effects of nateglinide on myocardial microvascular reactivity in Type 2 diabetes mellitus--a randomized study using positron emission tomography. Diabet Med. 2005;22(2):158-63. Does not have a drug comparison of interest. [pmid: 15660732].
Bergenstal R, Wysham C, Yan P, MacConell L, Malloy J, Porter L. Duration-2: Exenatide once weekly demonstrated significant glycaemic control and weight reduction compared to sitagliptin or pioglitazone after 26 weeks of treatment. Diabetic Medicine. Diabet. Med. 2010;27(2):5. No original data.
Berger W. Incidence of severe sideeffects during therapy with sulfonylureas and biguanides. Horm Metab Res Suppl. 1985;15:111-5. No original data. [pmid: 3865878].
Berghout LM, Gorter KJ, Rutten GEHM. Course of glycaemia in poorly controlled type 2 diabetes patients 2.5 years after optimizing oral treatment in general practice. Eur J Gen Pract. 2006;12(2):80-2. Does not apply. [pmid: 16945883].
Bergman AJ, Cote J, Yi B, et al. Effect of renal insufficiency on the pharmacokinetics of sitagliptin, a dipeptidyl peptidase-4 inhibitor. Diabetes Care. 2007;30(7):1862-4. No subjects with type 2 diabetes. [pmid: 17468348].
Bermudez-Pirela VJ, Cano C, Medina MT, et al. Metformin plus low-dose glimeperide significantly improves Homeostasis Model Assessment for insulin resistance (HOMA(IR)) and beta-cell function (HOMA(beta-cell)) without hyperinsulinemia in patients with type 2 diabetes mellitus. Am J Ther. 2007;14(2):194-202. Does not have a drug comparison of interest. [pmid: 17414590].
Berria R, Rosenstock J, Silberman C, Davis KL, Horton ES. Weight loss and associated changes in glycaemic control and cardiovascular biomarkers in patients with type 2 diabetes mellitus receiving incretin therapies in a large cohort database. Diabetologia: Diabetologia. 2009;52(S1):S297. No original data.
Best JD, Drury P, Davis T, Taskinen M-R, Kesaniemi A, Keech A. Metformin, sulphonylurea and insulin therapies maintain glycaemic control over five years in 4900 people with type 2 diabetes. Diabetologia: Diabetologia. 2009;52(S1):S93. No original data.
Best JH, Yan P, Malloy J. DURATION 2: Weight-related quality of life, psychological well-being, and satisfaction with exenatide once weekly compared to sitagliptin or piaglitazone after 26 weeks of treatment. Diabetologia: Diabetologia. 2009;52(S1):S292-293. Other reason.
Bhansali A, Masoodi SR. Efficacy of once - or twice-daily extended release metformin compared with thrice-daily immediate release metformin in type 2 diabetes mellitus. J Assoc Physicians India. 2005;53:441-5. Does not have a drug comparison of interest. [pmid: 16124352].
Bhushan R, Elkind-Hirsch KE, Bhushan M, Butler WJ, Duncan K, Marrioneaux O. Improved glycemic control and reduction of cardiometabolic risk factors in subjects with type 2 diabetes and metabolic syndrome treated with exenatide in a clinical practice setting. Diabetes Technol Ther. 2009;11(6):353-9. No comparison group. [pmid: 19459763].
Biesenbach G, Bodlaj G, Pieringer H. Weight gain and metabolic control in newly insulin-treated patients with type 2 diabetes with different insulin regimens. Can J Diabetes. 2006;30(4):384-9. Does not have a drug comparison of interest.
Birkeland KI, Furuseth K, Melander A, Mowinckel P, Vaaler S. Long-term randomized placebo-controlled double-blind therapeutic comparison of glipizide and glyburide. Glycemic control and insulin secretion during 15 months. Diabetes Care. 1994;17(1):45-9. Does not have a drug comparison of interest. [pmid: 8112188].
Blonde L, Klein EJ, Han J, et al. Interim analysis of the effects of exenatide treatment on A1C, weight and cardiovascular risk factors over 82 weeks in 314 overweight patients with type 2 diabetes. Diabetes Obes Metab. 2006;8(4):436-47. Does not have a drug comparison of interest. [pmid: 16776751].
Blonde L, Rosenstock J, Sesti G, Schmidt WE, Montanya E, Brett J, et al. Liraglutide: superior glycemic control vs exenatide when added to metformin and/or SU in Type 2 diabetes. Can J Diabetes. 2008;32. Abstract 107. No original data.
Bloomgarden ZT. Pharmacologic treatment of type 2 diabetes. Diabetes Care. 2003;26(2):526-33. No original data. [pmid: 12547894].
Bloomgren G, Dore D, Patterson R, Noel R, Braun D, Seeger J. Incidence of acute pancreatitis in exenatide initiators compared to other antidiabetic drug initiators: A retrospective, cohort study. Diabetologia: Diabetologia. 2009;52(S1):S9. No original data.
Bodmer M, Meier C, Krahenbuhl S, Jick SS, Meier CR. Metformin, sulfonylureas, or other antidiabetes drugs and the risk of lactic acidosis or hypoglycemia: a nested case-control analysis. Diabetes Care. 2008;31(11):2086-91. Does not have a drug comparison of interest. [pmid: 18782901].
Bokhari SU, Gopal UM, Duckworth WC. Beneficial effects of a glyburide/metformin combination preparation in type 2 diabetes mellitus. Am J Med Sci. 2003;325(2):66-9. Does not meet the study design criteria. [pmid: 12589230].
Boord JB, Graber AL, Christman JW, Powers AC. Practical management of diabetes in critically III patients. Am J Respir Crit Care Med. 2001;164:1763-7. No original data. [pmid: 11734423].
Boucher M, McAuley L, Brown A, Keely E, Skidmore B. Comparative clinical and budget evaluations of rosiglitazone and pioglitazone with other anti-diabetic agents. Ottawa. Canadian Coordinating Office for Health Technology Assessment. 2003. Technology overview no. 9. No original data.
Bowker SL, Majumdar SR, Veugelers P, Johnson JA. Increased cancer-related mortality for patients with type 2 diabetes who use sulfonylureas or insulin. Diabetes Care. 2006;29(2):254-8. Does not have a drug comparison of interest. [pmid: 16443869].
Boyd K, Rogers C, Boreham C, Andrews WJ, Hadden DR. Insulin, glibenclamide or metformin treatment for non insulin dependent diabetes: heterogenous responses of standard measures of insulin action and insulin secretion before and after differing hypoglycaemic therapy. Diabetes Res. 1992;19(2):69-76. Less than 40 subjects with type 2 diabetes. [pmid: 1286541].
Boyle J, Fisher M. The addition of insulin to metformin and sulphonylureas: Results of the 4-T study. Practical Diabetes International: Pract Diabetes Int. 2010;27(1):5-6. No original data.
Boyle PJ, King AB, Olansky L, et al. Effects of pioglitazone and rosiglitazone on blood lipid levels and glycemic control in patients with type 2 diabetes mellitus: a retrospective review of randomly selected medical records. Clin Ther. 2002;24(3):378-96. Does not meet the study design criteria. [pmid: 11952022].
Brewer D. Are alpha-glucosidase inhibitors effective for control of type 2 diabetes. Am Fam Physician. 2006;73(3):433-4. No original data. [pmid: 16477889].
Brixner D, McAdam-Marx C, Ye X, Misurski D, Wintle M, Fabunmi R. 18 Month A1C and weight outcomes of exenatide therapy in patients with type-2 diabetes in a real-world study. Value Health. 2009;12(3):A97. Other reason.
Brodows R, Milton D, Ridge TD, et al. Exenatide monotherapy improves glycemic control and is well tolerated over 24 weeks in drug-na∩ve patients with type 2 diabetes. Diabetes. 2008;57(Suppl 1):A145 (abstr 485-P). No original data.
Brown JB, Nichols GA, Perry A. The burden of treatment failure in type 2 diabetes. Diabetes Care. 2004;27(7):1535-40. Does not apply. [pmid: 15220224].
Brown JB, Pedula KL. Metformin as secondary therapy in a defined population with type 2 diabetes. Clin Ther. 1999;21(10):1678-87. Does not have a drug comparison of interest. [pmid: 10566564].
Brown RR. Cost-effectiveness and clinical outcomes of metformin or insulin add-on therapy in adults with type 2 diabetes. Am J Health Syst Pharm. 1998;55:S24-7. Does not have a drug comparison of interest. [pmid: 9872692].
Brunelli SM, Thadhani R, Ikizler TA, Feldman HI. Thiazolidinedione use is associated with better survival in hemodialysis patients with non-insulin dependent diabetes. Kidney Int. 2009;75(9):961-8. Does not meet the study design criteria. [pmid: 19190679].
Bruns W, et al. Treatment of type II diabetics (non-insulin-dependent) for sulphonylurea secondary failure - combined therapy, using glibenclamid and insulin. Zeitschrift F^n^r Klinische Medizin. 1990;45(11):983-6. Does not apply.
Bu S, et al. Evaluation of the efficacy and safety of once daily injection of glargine combined with glipizide GITS in the treatment of type 2 diabetes mellitus. Chinese Journal of Evidence-Based Medicine. 2004;4(7):464-7. Not written in English.
Bunck MC, Mari A, Comer A, et al. One-year exenatide treatment improves beta cell response in metformin treated patients with type 2 diabetes which is sustained after 5 weeks discontinuation of treatment. Diabetologia: Diabetologia. 2009;52(S1):S7. No original data.
Buse J, Sesti G, Schmidt WE, et al. A switch from twice-daily exenatide to once -daily liraglutide further improves glycaemic control in patients with type 2 diabetes on oral agents. Diabetologia: Diabetologia. 2009;52(S1):S7-8. Other reason.
Buse JB, Rosenstock J, Sesti G, et al. Liraglutide. once. a day versus exenatide twice a day for type 2 diabetes: a 26-week randomised, parallel-group, multinational, open-label trial (LEAD-6). Lancet. 2009;374(9683):39-47. Other reason. [pmid: 19515413].
Buse JB, Sesti G, Schmidt WE, et al. Switching to once -daily liraglutide from twice-daily exenatide further improves glycemic control in patients with type 2 diabetes using oral agents. Diabetes Care. 2010. Does not have a drug comparison of interest.
Buysschaert M, Hermans MP. Glycaemic and blood pressure controls achieved in a cohort of 318 patients with type 2 diabetes. Acta Clin Belg. 1999;54(6):328-33. Does not have a drug comparison of interest. [pmid: 10686705].
Bytzer P, Talley NJ, Jones MP, Horowitz M. Oral hypoglycaemic drugs and gastrointestinal symptoms in diabetes mellitus. Aliment Pharmacol Ther. 2001;15(1):137-42. Does not have a drug comparison of interest. [pmid: 11136287].
Calle-Pascual A, et al. Influence of 16-week monotherapy with acarbose on cardiovascular risk factors in obese subjects with non-insulin-dependent diabetes mellitus: a controlled, double-blind comparison study with placebo. Diabetes & Metabolism. 1996;22(3):201-2. Does not have a drug comparison of interest. [pmid: 8697309].
Calvert MJ, McManus RJ, Freemantle N. The management of people with type 2 diabetes with hypoglycaemic agents in primary care: retrospective cohort study. Fam Pract. 2007;24(3):224-9. Does not meet the study design criteria. [pmid: 17488736].
Campbell IW, Chalmers J, Herlihy OM. Sulphonylurea-induced hypoglycaemia in elderly people with diabetes. Pract Diabetes. 1994;11(3):102-3. No original data.
Campbell IW, Menzies DG, McBain AM, Brown IRF. Effects of metformin on blood pressure and microalbuminuria in diabetes mellitus. Diabete & Metabolism. 1988;14:613-7. Other reason.
Campbell IW. Metformin and glibenclamide: comparative risks. Br Med J (Clin Res Ed). 1984;289(6440):289. No original data.
Cardiovascular risk reduction with pioglitazone. Cardiovasc J S Afr. 2002;13(4):218. No original data.
Carlson RF, Isley WL, Ogrinc FG, Klobucar TR. Efficacy and safety of reformulated, micronized glyburide tablets in patients with non-insulin-dependent diabetes mellitus: a multicenter, double-blind, randomized trial. Clin Ther. 1993;15(5):788-96. Does not have a drug comparison of interest. [pmid: 8269445].
Casscells SW, Granger E, Swedorske J, et al. A comparison of select cardiovascular outcomes by antidiabetic prescription drug classes used to treat type 2 diabetes among Military Health System beneficiaries, fiscal year 2003–2006. Am J Ther. 2008;15(3):198-205. Other reason. [pmid: 18496256].
Cathelineau G, et al. Management of newly diagnosed non-insulin-dependent diabetes mellitus in the primary care setting: effects of 2 years of gliclazide treatment--the Diadem Study. Metabolism. 1997;46:31-4. No comparison group. [pmid: 9439556].
Cefalu WT, Schneider DJ, Carlson HE, et al. Effect of combination glipizide GITS/metformin on fibrinolytic and metabolic parameters in poorly controlled type 2 diabetic subjects. Diabetes Care. 2002;25(12):2123-8. No comparison group. [pmid: 12453948].
Cesur M, Corapcioglu D, Gursoy A, et al. A comparison of glycemic effects of glimepiride, repaglinide, and insulin glargine in type 2 diabetes mellitus during Ramadan fasting. Diabetes Res Clin Pract. 2007;75(2):141-7. Study duration less than 3 months. [pmid: 16815586].
Chalasani N, Teal E, Hall SD. Effect of rosiglitazone on serum liver biochemistries in diabetic patients with normal and elevated baseline liver enzymes. Am J Gastroenterol. 2005;100(6):1317-21. No comparison group. [pmid: 15929763].
Chalmers J, Hunter JE, Robertson SJ, et al. Effects of early use of pioglitazone in combination with metformin in patients with newly diagnosed type 2 diabetes. Curr Med Res Opin. 2007;23(8):1775-81. Does not meet the study design criteria. [pmid: 17712875].
Chalmers J, McBain AM, Brown IRF, Campbell IW. Metformin: Is its use contraindicated in the elderly. Pract Diabetes. 1992;9(2):51-3. Does not have a drug comparison of interest.
Chan JC, Scott R, Arjona Ferreira JC, et al. Safety and efficacy of sitagliptin in patients with type 2 diabetes and chronic renal insufficiency. Diabetes Obes Metab. 2008;10(7):545-55. Does not have a drug comparison of interest. [pmid: 18518892].
Chan JC, Scott R, Arjona Ferreira JC, et al. Safety and efficacy of sitagliptin in patients with type 2 diabetes and chronic renal insufficiency. Diabetes Obes Metab. 2008;10(7):545-55. Does not have a drug comparison of interest. [pmid: 18518892].
Chan KA, Truman A, Gurwitz JH, et al. A cohort study of the incidence of serious acute liver injury in diabetic patients treated with hypoglycemic agents. Arch Intern Med. 2003;163(6):728-34. Does not have a drug comparison of interest. [pmid: 12639207].
Chan NN, Feher MD, Bridges NA. Metformin therapy for diabetes in Prader-Willi syndrome. J R Soc Med. 1998;91(11):598. No comparison group. [pmid: 10325882].
Chandalia HB, Lamba PS, Chandalia SH, Singh DK, Modi SV, Shaikh SA. Weight gain in type 2 diabetics with different treatment modalities. Metab Syndr Relat Disord. 2005;3(2):130-6. Does not have a drug comparison of interest. [pmid: 18370720].
Chandrasekharan S, Rao PP, Jayaram S, Jain SD, Ganesan R, Desai A. Efficacy and safety of nateglinide in the treatment of type II diabetes mellitus. J Indian Med Assoc. 2002;100(7):467-8. No comparison group. [pmid: 12674176].
Charbonnel B, Roden M, Urquhart R, et al. Pioglitazone elicits long-term improvements in insulin sensitivity in patients with type 2 diabetes: comparisons with gliclazide-based regimens. Diabetologia. 2005;48(3):553-60. Does not have a drug comparison of interest. [pmid: 15739120].
Charbonnel B. Oral combination therapy with thiazolidinediones and sulfonylureas in type 2 diabetes. Int J Clin Pract Suppl. 2007:1-2. No original data. [pmid: 17594387].
Charbonnel BH, Matthews DR, Schernthaner G, Hanefeld M, Brunetti P. A long-term comparison of pioglitazone and gliclazide in patients with Type 2 diabetes mellitus: a randomized, double-blind, parallel-group comparison trial. Diabet Med. 2005;22(4):399-405. Does not have a drug comparison of interest. [pmid: 15787663].
Charpentier G, Vaur L, Halimi S, et al. Predictors of response to glimepiride in patients with type 2 diabetes mellitus. Diabetes Metab. 2001;27:563-71. No comparison group. [pmid: 11694855].
Chen HS, et al. Beneficial effects of insulin on glycemic control and beta-cell function in newly diagnosed type 2 diabetes with severe hyperglycemia after short-term intensive insulin therapy. Diabetes Care. 2008;31(10):1927-32. Does not have a drug comparison of interest. [pmid: 18556343].
Chen R, Xu Z, Duan Y, Apanovitch A. Reaching HbA1c goals with saxagliptin in combination with metformin or sulfonylurea. Diabetologia: Diabetologia. 2009;52(S1):S296. No original data.
Chiasson JL, Josse RG, Hunt JA, et al. The efficacy of acarbose in the treatment of patients with non-insulin-dependent diabetes mellitus. A multicenter controlled clinical trial. Ann Intern Med. 1994;121(12):928-35. Does not have a drug comparison of interest. [pmid: 7734015].
Chogtu B, Singh NP, Chawla S, Gupta U. Impact of glitazones on metabolic and haemodynamic parameters in patients with type 2 diabetes mellitus. Singapore Med J. 2009;50(4):395-9. Does not have a drug comparison of interest. [pmid: 19421684].
Choi D, Kim SK, Choi SH, et al. Preventative effects of rosiglitazone on restenosis after coronary stent implantation in patients with type 2 diabetes. Diabetes Care. 2004;27(11):2654-60. Does not have a drug comparison of interest. [pmid: 15505001].
Chokrungvaranon N, Chentanez T, Arakaki RF. Clinical experience with exenatide in predominantly Asian and Pacific Islander patients with type 2 diabetes. Endocrine. 2007;32(3):311-6. Does not apply. [pmid: 18266113].
Chou HS, Palmer JP, Jones AR, et al. Initial treatment with fixed-dose combination rosiglitazone/glimepiride in patients with previously untreated type 2 diabetes. Diabetes Obes Metab. 2008;10(8):626-37. Does not have a drug comparison of interest. [pmid: 17645558].
Chu JW, Abbasi F, McLaughlin TL, et al. Lipoprotein risk factors for cardiovascular disease in patients with type 2 diabetes mellitus treated with oral antihyperglycaemic agents. Diabetes Obes Metab. 2003;5(5):333-7. Does not meet the study design criteria. [pmid: 12940871].
Chuang L-M, Lu C, Su R-J, Wu H-P, Tai T-Y, Lin BJ. Bedtime intermediate-acting insulin in the treatment of secondary failure to oral hypoglycemic agents. J FORMOS MED ASSOC. 1992;91(2):185-9. Less than 40 subjects with type 2 diabetes. [pmid: 1364216].
Ciardullo AV, Brunetti M, Daghio MM, et al. Characteristics of type 2 diabetic patients cared for by general practioners either with medical nutrition therapy alone or with hypoglycaemic drugs. Diabetes Nutr Metab Clin Exp. 2004;17(2):120-3. Does not meet the study design criteria.
Cohen M, Crosbie C, Cusworth L, Zimmet P. Insulin - not always a life sentence: Withdrawal of insulin therapy in non-insulin dependent diabetes. DIABETES RES. 1984;1(1):31-4. Does not apply. [pmid: 6397285].
Cohen O, Norymberg C, Neumann E, Dekel H. Weight gain in type 2 diabetes mellitus-Not all uphill. Diabetes Res Clin Pract. 2008;79(1):128-32. Does not have a drug comparison of interest. [pmid: 17720273].
Coppack SW, Lant AF, McIntosh CS, Rodgers AV. Pharmacokinetic and pharmacodynamic studies of glibenclamide in non-insulin dependent diabetes mellitus. Br J Clin Pharmacol. 1990;29(6):673-84. Less than 40 subjects with type 2 diabetes. [pmid: 2116159].
Corsonello A, Pedone C, Corica F, et al. Concealed renal failure and adverse drug reactions in older patients with type 2 diabetes mellitus. J Gerontol Ser A Biol Sci Med Sci. 2005;60(9):1147-51. Does not apply. [pmid: 16183954].
Courreges JP, Zdravkovic M, Le-Thi T, Krarup T, Schmitz O, Vilsb°ll T, et al. Liraglutide treatment improves glycaemic control, blood pressure and biomarkers of cardiovascular risk in patients with type 2 diabetes. Diabetologia. 2006;49(Suppl 1):A0003. Other reason.
Courrges JP, Vilsbll T, Zdravkovic M, et al. Beneficial effects of once-daily liraglutide, a human glucagon-like peptide-1 analogue, on cardiovascular risk biomarkers in patients with Type 2 diabetes. Diabetic Medicine: a Journal of the British Diabetic Association. 2008;25(9):1129-31. Does not have a drug comparison of interest. [pmid: 19183322].
Cryer DR, Nicholas SP, Henry DH, Mills DJ, Stadel BV. Comparative outcomes study of metformin intervention versus conventional approach the COSMIC Approach Study. Diabetes Care. 2005;28(3):539-43. Does not have a drug comparison of interest. [pmid: 15735184].
Dailey G, et al. Insulin glulisine provides improved glycemic control in patients with type 2 diabetes. Diabetes Care. 2004;27(10):2363-8. Does not have a drug comparison of interest. [pmid: 15451901].
Dandona P, Fonseca V, Mier A, Beckett AG. Diarrhea and metformin in a diabetic clinic. Diabetes Care. 1983;6(5):472-4. Study duration less than 3 months. [pmid: 6336343].
Dargie HJ, Hildebrandt PR, Riegger GA, et al. A randomized, placebo-controlled trial assessing the effects of rosiglitazone on echocardiographic function and cardiac status in type 2 diabetic patients with New York Heart Association Functional Class I or II Heart Failure. J Am Coll Cardiol. 2007;49(16):1696-704. Does not have a drug comparison of interest. [pmid: 17448371].
Davidson J, Howlett H. New prolonged-release metformin improves gastrointestinal tolerability. Br J Diabetes Vasc Dis. 2004;4(4):273-7. No original data.
Davidson J, Koro C, Arondekar B, Lee BH, Fedder D. A retrospective analysis of the fasting plasma glucose and glycosylated hemoglobin and pharmacotherapy change patterns among type 2 diabetes mellitus patients. Clin Ther. 2008;30(2):287-93. Does not apply. [pmid: 18343267].
Davidson JA, Scheen AJ, Hewlett HCS. Tolerability profile of metformin/glibenclamide combination tablets (Glucovance(registered trademark)): A new treatment for the management of type 2 diabetes mellitus. Drug Saf. 2004;27(15):1205-16. No original data. [pmid: 15588116].
Davidson JK, Vander Zwaag R, Cox CL. The Memphis and Atlanta continuing care programs for diabetes. II. Comparative analyses of demographic characteristics, treatment methods, and outcomes over a 9-10-year follow-up period. Diabetes Care. 1984;7(1):25-31. No comparison group. [pmid: 6368150].
Davies M, Nauck M, Bailey T, et al. Better glycaemic control and weight reduction with liraglutide, a once-daily human GLP-1 analogue, compared with sitagliptin, a DPP-4 inhibitor, both in combination with metformin in type 2 diabetes. Diabetic Medicine: Diabet Med. 2010;27:4-5. No original data.
Davies MJ, Donnelly R, Barnett AH, Jones S, Nicolay C, Kilcoyne A. Exenatide compared with long-acting insulin to achieve glycaemic control with minimal weight gain in patients with type 2 diabetes: results of the Helping Evaluate Exenatide in patients with diabetes compared with Long-Acting insulin (HEELA) study. Diabetes Obes Metab. 2009;11(12):1153-62. Does not have a drug comparison of interest. [pmid: 19930005].
Davis PJ, Davis FB. Control of blood sugar level in elderly diabetic patients. PRIM CARE CLIN OFF PRACT. 1982;9(1):45-51. No original data.
Davis SN, Johns D, Maggs D, Xu H, Northrup JH, Brodows RG. Exploring the substitution of exenatide for insulin in patients with type 2 diabetes treated with insulin in combination with oral antidiabetes agents. Diabetes Care. 2007;30(11):2767-72. Does not have a drug comparison of interest. [pmid: 17595353].
Davis TM, Cull CA, Holman RR. Relationship between ethnicity and glycemic control, lipid profiles, and blood pressure during the first 9 years of type 2 diabetes: U.K. Prospective Diabetes Study (UKPDS 55). Diabetes Care. 2001;24(7):1167-74. Does not have a drug comparison of interest. [pmid: 11423497].
Davis TM, Jackson D, Davis WA, Bruce DG, Chubb P. The relationship between metformin therapy and the fasting plasma lactate in type 2 diabetes: The Fremantle Diabetes Study. Br J Clin Pharmacol. 2001;52(2):137-44. Does not apply. [pmid: 11488769].
de Fine Olivarius N, Andreasen AH, Siersma V, Richelsen B, Beck-Nielsen H. Changes in patient weight and the impact of antidiabetic therapy during the first 5 years after diagnosis of diabetes mellitus. Diabetologia. 2006;49(9):2058-67. Does not meet the study design criteria. [pmid: 16841232].
De Jager J, Kooy A, Lehert P, et al. Effects of short-term treatment with metformin on markers of endothelial function and inflammatory activity in type 2 diabetes mellitus: a randomized, placebo-controlled trial. J Intern Med. 2005;257(1):100-9. Does not have a drug comparison of interest. [pmid: 15606381].
De Luis DA, Cuellar L, Terroba C, et al. Effect of metformin on cardiovascular risk factors in obese type 2 diabetic patients. Endocrinologia Nutr. 2001;48(4):110-3. Does not have a drug comparison of interest.
Deeg MA, Buse JB, Goldberg RB, et al. Pioglitazone and rosiglitazone have different effects on serum lipoprotein particle concentrations and sizes in patients with type 2 diabetes and dyslipidemia. Diabetes Care. 2007;30(10):2458-64. Other reason. [pmid: 17595355].
Dejgaard A, Madshad S, Kilhovd B, Larger I, Mustajoki P. Repaglinide compared to glipizide in the treatment of type 2 diabetic patients. Diabetologia. 1998;41(1):A236. Other reason.
Del Prato S, Erkelens DW, Leutenegger M. Six-month efficacy of benfluorex vs. placebo or metformin in diet-failed type 2 diabetic patients. Acta Diabetol. 2003;40(1):20-7. Does not have a drug comparison of interest. [pmid: 12682825].
Delea TE, Edelsberg JS, Hagiwara M, Oster G, Phillips LS. Use of thiazolidinediones and risk of heart failure in people with type 2 diabetes: a retrospective cohort study. Diabetes Care. 2003;26(11):2983-9. Does not have a drug comparison of interest. [pmid: 14578227].
Dembe K, Pieniqzek A, Niebisz A, Karnafel W. An evaluation of hypoglycaemia in patients with diabetes mellitus hospitalised at the Department of Gastroenterology and Metabolic Diseases, Medical University of Warsaw, Poland. Diabetol Dosw Klin. 2008;8(4):169-72. Other reason.
Derosa G, Cicero AF, Dangelo A, et al. Thiazolidinedione effects on blood pressure in diabetic patients with metabolic syndrome treated with glimepiride. Hypertens Res. 2005;28(11):917-24. Does not have a drug comparison of interest. [pmid: 16555581].
Derosa G, Cicero AF, Gaddi A, et al. A comparison of the effects of pioglitazone and rosiglitazone combined with glimepiride on prothrombotic state in type 2 diabetic patients with the metabolic syndrome. Diabetes Res Clin Pract. 2005;69(1):5-13. Does not have a drug comparison of interest. [pmid: 15955382].
Derosa G, Cicero AF, Gaddi A, et al. Metabolic effects of pioglitazone and rosiglitazone in patients with diabetes and metabolic syndrome treated with glimepiride: a twelve-month, multicenter, double-blind, randomized, controlled, parallel-group trial. Clin Ther. 2004;26(5):744-54. Does not have a drug comparison of interest. [pmid: 15220018].
Derosa G, Salvadeo SA, D’Angelo A, et al. Rosiglitazone therapy improves insulin resistance parameters in overweight and obese diabetic patients intolerant to metformin. Arch Med Res. 2008;39(4):412-9. Does not meet the study design criteria. [pmid: 18375253].
Desouza C, Fonseca VA. Insulin sensitizer combination therapy for type 2 diabetes. Cardiol Rev. 2001;18(1):11-5. Other reason.
Deutsch JC, Santhosh-Kumar CR, Kolhouse JF. Efficacy of metformin in non-insulin-dependent diabetes mellitus. N Engl J Med. 1996;334(4):269. discussion 269–270. No original data. [pmid: 8532011].
Diamant M, et al. Long-term treatment with pioglitazone improves markers of liver function in patients with type 2 diabetes: results from PROactive. 42nd Annual Meeting of the European Association for the Study of Diabetes 2006. 2006. Other reason.
Dickinson PJ, Dornhorst A, Frost GS. A retrospective case-control study of initiating insulin therapy in type 2 diabetes. Pract Diabetes Int. 2002;19(3):67-70. Does not have a drug comparison of interest.
Diez JJ. Perioperative management of type 2 diabetes mellitus by two techniques of insulin infusion. A randomized clinical study. Endocrinologia. 1991;38(4):108-12. Less than 40 subjects with type 2 diabetes.
Dills DG, Schneider J. Clinical evaluation of glimepiride versus glyburide in NIDDM in a double-blind comparative study. Glimepiride/Glyburide Research Group. Horm Metab Res. 1996;28(9):426-9. Does not have a drug comparison of interest. [pmid: 8911977].
Doering PL, Boothby LA. CE: New drug update 2005-Part 2. Drug Topics. 2006;150(4). No original data.
Doggrell SA. Is liraglutide or exenatide better in type 2 diabetes? Expert Opinion on Pharmacotherapy: Expert Opin. Pharmacother. 2009;10(16):2769-72. Other reason.
Doggrell SA. Recent evidence of sustained benefit with exenatide in Type 2 diabetes. Expert Opin Pharmacother. 2006;7(14):2003-6. No original data. [pmid: 17020425].
Donadon V, Balbi M, Ghersetti M, et al. Antidiabetic therapy and increased risk of hepatocellular carcinoma in chronic liver disease. World J Gastroenterol. 2009;15(20):2506-11. Does not apply. [pmid: 19469001].
Donatelli M, Verga S, Terrizzi C, Vaccaro M, Bompiani GD. Long-term clinical experience with antidiabetic drugs in the treatment of noninsulin-dependent diabetes mellitus. Curr Ther Res Clin Exp. 1987;42(6):1166-70. Does not have a drug comparison of interest.
Donnan PT, Steinke DT, Newton RW, Morris AD. Changes in treatment after the start of oral hypoglycaemic therapy in Type 2 diabetes: a population-based study. Diabet Med. 2002;19(7):606-10. Other reason. [pmid: 12099966].
Donnelly LA, Doney AS, Hattersley AT, Morris AD, Pearson ER. The effect of obesity on glycaemic response to metformin or sulphonylureas in Type 2 diabetes. Diabet Med. 2006;23(2):128-33. Does not meet the study design criteria. [pmid: 16433709].
Dore DD, Seeger JD, Chan KA. Use of a claims-based active drug safety surveillance system to assess the risk of acute pancreatitis with exenatide or sitagliptin compared to metformin or glyburide. Curr Med Res Opin. 2009;25(4):1019-27. Does not have a drug comparison of interest. [pmid: 19278373].
Dormandy J, Bhattacharya M, van Troostenburg de Bruyn AR. Safety and tolerability of pioglitazone in high-risk patients with type 2 diabetes: an overview of data from PROactive. Drug Saf. 2009;32(3):187-202. Does not have a drug comparison of interest. [pmid: 19338377].
Dormandy JA, Betteridge DJ, Schernthaner G, Pirags V, Norgren L. Impact of peripheral arterial disease in patients with diabetes--results from PROactive (PROactive 11). Atherosclerosis. 2009;202(1):272-81. Does not have a drug comparison of interest. [pmid: 18538774].
Draeger KE, Wernicke-Panten K, Lomp HJ, Schuler E, Rosskamp R. Long-term treatment of type 2 diabetic patients with the new oral antidiabetic agent glimepiride (Amaryl): a double-blind comparison with glibenclamide. Horm Metab Res. 1996;28(9):419-25. Does not have a drug comparison of interest. [pmid: 8911976].
Drown DJ. Metformin: effective in the prevention of new-onset type 2 diabetes. Prog Cardiovasc Nurs. 2008;23(2):93-4. No original data. [pmid: 18843833].
Drzewoski J, Czupryniak L. Long-term efficacy of steady-dose metformin in type 2 diabetes mellitus: a retrospective study. Med Sci Monit. 2003;9(6):CR240-3. Does not meet the study design criteria. [pmid: 12824953].
Duane J, Conway W. Weight change in intensive insulin therapy for type 2 diabetes mellitus as a function of glycosylated hemoglobin (A1C) level achieved: The deep south diabetes program. Insulin. 2008;3(4):219-31. Does not have a drug comparison of interest.
Duckworth W, Abraira C, Moritz T, et al. Glucose control and vascular complications in veterans with type 2 diabetes. N Engl J Med. 2009;360(2):129-39. Does not have a drug comparison of interest. [pmid: 19092145].
Duncan AI, Koch CG, Xu M, et al. Recent metformin ingestion does not increase in-hospital morbidity or mortality after cardiac surgery. Anesth Analg. 2007;104(1):42-50. Does not have a drug comparison of interest. [pmid: 17179241].
Dworacka M, Abramczyk M, Winiarska H, Kuczynski S, Borowska M, Szczawinska K. Disproportionately elevated proinsulin levels in type 2 diabetic patients treated with sulfonylurea. Int J Clin Pharmacol Ther. 2006;44(1):14-21. Does not meet the study design criteria. [pmid: 16425966].
Ebell MH. Insulin monotherapy vs. combination therapy. Am Fam Physician. 2005;71(5):899. No original data. [pmid: 15768618].
Eeley EA, Stratton IM, Hadden DR, Turner RC, Holman RR. UKPDS 18: estimated dietary intake in type 2 diabetic patients randomly allocated to diet, sulphonylurea or insulin therapy. UK Prospective Diabetes Study Group. Diabet Med. 1996;13(7):656-62. Does not have a drug comparison of interest. [pmid: 8840101].
Emanuele N, Azad N, Abraira C, et al. Effect of intensive glycemic control on fibrinogen, lipids, and lipoproteins: Veterans Affairs Cooperative Study in Type II Diabetes Mellitus. Arch Intern Med. 1998;158(22):2485-90. Does not have a drug comparison of interest. [pmid: 9855387].
Engel-Nitz NM, Martin S, Sun P, Buesching D, Fonseca V. Cardiovascular events and insulin therapy: A retrospective cohort analysis. Diabetes Res Clin Pract. 2008;81(1):97-104. Does not have a drug comparison of interest. [pmid: 18417242].
Erdmann E, et al. Pioglitazone treatment in patients with type 2 diabetes and a history of MI: subgroup analysis from PROactive stratified by gender, age and duration of diabetes. 42nd Annual Meeting of the European Association for the Study of Diabetes 2006. 2006. Other reason.
Erdmann E, Charbonnel B, Wilcox RG, et al. Pioglitazone use and heart failure in patients with type 2 diabetes and preexisting cardiovascular disease: data from the PROactive study (PROactive 08). Diabetes Care. 2007;30(11):2773-8. Does not have a drug comparison of interest. [pmid: 17666462].
Erdmann E, Dormandy JA, Charbonnel B, Massi-Benedetti M, Moules IK, Skene AM. The effect of pioglitazone on recurrent myocardial infarction in 2,445 patients with type 2 diabetes and previous myocardial infarction: results from the PROactive (PROactive 05) Study. J Am Coll Cardiol. 2007;49(17):1772-80. Does not have a drug comparison of interest. [pmid: 17466227].
Erle G, Lovise S, Stocchiero C, et al. A comparison of preconstituted, fixed combinations of low-dose glyburide plus metformin versus high-dose glyburide alone in the treatment of type 2 diabetic patients. Acta Diabetol. 1999;36(1-2):61-5. Does not have a drug comparison of interest. [pmid: 10436254].
Esposito K, Ciotola M, Maiorino MI, et al. Addition of neutral protamine lispro insulin or insulin glargine to oral type 2 diabetes regimens for patients with suboptimal glycemic control: a randomized trial. Ann Intern Med. 2008;149(8):531-9. Does not meet the study design criteria. [pmid: 18936501].
Eurich DT, Simpson SH, Majumdar SR, Johnson JA. Secondary failure rates associated with metformin and sulfonylurea therapy for type 2 diabetes mellitus. Pharmacotherapy. 2005;25(6):810-6. Does not apply. [pmid: 15927899].
Ezenwaka CE. Metabolic control of type-2 diabetic patients commonly treated with sulphonylureas in a developing country. East Afr Med J. 2003;80(4):175-80. Does not have a drug comparison of interest. [pmid: 12918799].
Fabunmi R, Nielsen LL, Quimbo R, et al. Patient characteristics, drug adherence patterns, and hypoglycemia costs for patients with type 2 diabetes mellitus newly initiated on exenatide or insulin glargine *. Curr Med Res Opin. 2009. Does not have a drug comparison of interest.
Fabunmi R, Wade R, Quimbo RA, Hou L, Pawaskar MD, Misurski D. Administrative claims analysis of patients with type-2 diabetes initiating sitagliptin therapy. Value Health. 2009;12(3):A98. Other reason.
Fakhoury W, Lockhart I, Kotchie RW, Aagren M, LeReun C. Indirect comparison of once daily insulin detemir and glargine in reducing weight gain and hypoglycaemic episodes when administered in addition to conventional oral anti-diabetic therapy in patients with type-2 diabetes. Pharmacology. 2008;82(2):156-63. Does not apply. [pmid: 18679040].
Famuyiwa OO, Sulimani RA, Laajam MA, Al-Jasser SJ, Mekki MO. Diabetes mellitus in Saudi Arabia: The clinical pattern and complications in 1,000 patients. Ann Saudi Med. 1992;12(2):140-51. Does not meet the study design criteria. [pmid: 17589143].
Fang CC, Ng Jao YT, Yi-Chen, Yu CL, Chen CL, Wang SP. Angiographic and clinical outcomes of rosiglitazone in patients with type 2 diabetes mellitus after percutaneous coronary interventions: a single center experience. Angiology. 2007;58(5):523-34. Does not have a drug comparison of interest. [pmid: 18024934].
Farquhar D. A new option in oral hypoglycemic therapy for type 2 diabetes mellitus. Can. Med. Assoc. J. 2000;163(9):1186. Other reason.
Feinbock C, Luger A, Klingler A, et al. Prospective multicentre trial comparing the efficacy of, and compliance with, glimepiride or acarbose treatment in patients with type 2 diabetes not controlled with diet alone. Diabetes Nutr Metab. 2003;16(4):214-21. Does not have a drug comparison of interest. [pmid: 14768770].
Feldman L, Shani M, Efrati S, et al. Association between rosiglitazone use and decline in renal function in patients with type 2 diabetes mellitus. J Nephrol. 2010. Does not have a drug comparison of interest.
Finn AV, Oh JS, Hendricks M, et al. Predictive factors for in-stent late loss and coronary lesion progression in patients with type 2 diabetes mellitus randomized to rosiglitazone or placebo. Am Heart J. 2009;157(2):383.e1-8. Does not have a drug comparison of interest. [pmid: 19185649].
Flint A, Kapitza C, Hindsberger C, Zdravkovic M. The once-daily human GLP-1 analogue liraglutide improves both absolute and baseline corrected postprandial glucose levels. Diabetes. 2008;57(Suppl 1):A165. No original data.
Flores-Murrieta FJ, Aguilar-Cota ME, Camacho A, Reyes-Garcia G, Herrera JE, Medina-Santillan R. Comparative bioavailability of two oral formulations manufactured in Mexico containing glyburide and metformin in diabetic patients. Proc West Pharmacol Soc. 2003;46:82-4. Less than 40 subjects with type 2 diabetes. [pmid: 14699894].
Florkowski CM, Scott RS, Coope PA, Moir CL. Predictors of mortality from type 2 diabetes mellitus in Canterbury, New Zealand; a ten-year cohort study. Diabetes Res Clin Pract. 2001;53(2):113-20. Does not have a drug comparison of interest. [pmid: 11403860].
Fong DS, Contreras R. Glitazone use associated with diabetic macular edema. Am J Ophthalmol. 2009;147(4):583-6. e1. Does not have a drug comparison of interest. [pmid: 19181303].
Fonseca V, Grunberger G, Gupta S, Shen S, Foley JE. Addition of nateglinide to rosiglitazone monotherapy suppresses mealtime hyperglycemia and improves overall glycemic control. Diabetes Care. 2003;26(6):1685-90. Does not have a drug comparison of interest. [pmid: 12766094].
Fonseca VA, Theuma P, Mudaliar S, Leissinger CA, Clejan S, Henry RR. Diabetes treatments have differential effects on nontraditional cardiovascular risk factors. J Diabetes Complications. 2006;20(1):14-20. Does not have a drug comparison of interest. [pmid: 16389162].
Forst T, Lubben G, Hohberg C, et al. Influence of glucose control and improvement of insulin resistance on microvascular blood flow and endothelial function in patients with diabetes mellitus type 2. Microcirculation. 2005;12(7):543-50. Other reason. [pmid: 16207627].
Fowler MJ. Diabetes treatment, Part 2: Oral agents for glycemic management. Clin Diabetes. 2007;25(4):131-4. No original data.
Frenchman IB. Treatment and treatment-related adverse events of type 2 diabetes mellitus in residents of long-term care facilities: A retrospective study. Curr Ther Res Clin Exp. 2003;64(1):1-9. Other reason.
Fresco C. Pioglitazone vs glimepiride in the PERISCOPE trial. JAMA. 2008;300(7):787. author reply 788. No original data. [pmid: 18714055].
Fujioka K, Pans M, Joyal S. Glycemic control in patients with type 2 diabetes mellitus switched from twice-daily immediate-release metformin to a once-daily extended-release formulation. Clin Ther. 2003;25(2):515-29. Does not have a drug comparison of interest. [pmid: 12749511].
Furlong NJ, McNulty SJ, O’Brien SV, Hardy KJ. Comparison of metformin versus sulphonylurea in combination with daily NPH insulin in patients with type 2 diabetes inadequately controlled on oral hypoglycaemic agents; Median follow-up 29 months. Pract Diabetes Int. 2002;19(8):245-9. Does not have a drug comparison of interest.
Gaede P, et al. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. 1999;353(9153):617-22. Does not have a drug comparison of interest. [pmid: 10030326].
Gaede P, Parving HH, Pedersen O. PROactive study. Lancet. 2006;367(9504):23-24. author reply 26–27. No original data. [pmid: 16399142].
Galeone F, Saba P, Saponati G. Gliquidone (Glurenor) in long-term treatment of type II diabetes mellitus. CLIN TRIALS J. 1989;26(2):108-18. Does not have a drug comparison of interest.
Gallwitz B, Dotta F, Kazda C, et al. Changes in adipokines in type 2 diabetic patients treated with exenatide versus glimipiride on metformin background - Results of a prospective, randomized controlled study over 9 months. Diabetologia: Diabetologia. 2009;52(S1):S313. Other reason.
Gallwitz B, Vaag A, Falahati A, Madsbad S. Adding liraglutide to oral antidiabetic drug therapy: onset of treatment effects over time. Int J Clin Pract. 2010;64(2):267-76. Other reason. [pmid: 19925617].
Garber A, Henry R, Ratner R, Hale P, Chang CT, Bode B. Liraglutide, a human GLP-1 analogue, offers sustained and greater reduction in HbA1c, fasting plasma glucose and weight compared with glimepiride over 2 years, with lower hypoglycaemic risk, in patients with Type 2 diabetes: LEAD-3 extension study. Diabetic Medicine: Diabet. Med. 2010;27(Suppl 1):78. No original data.
Garber A, Henry R, Ratner RE, Hae P, Chang CT, Bode B. Two years of treatment with liraglutide, a human GLP-1 analogue, offers sustained and greater reduction with HbA1c, FPG, PPG and weight compared with glimepiride, with lower glycaemic risk, in patients with type 2 diabetes: LEAD-3 extension study. Canadian Journal of Diabetes: Can. J Diabetes. 2009;33(3):289. Other reason.
Garber AJ, Duncan TG, Goodman AM, Mills DJ, Rohlf JL. Efficacy of metformin in type II diabetes: results of a double-blind, placebo-controlled, dose-response trial. Am J Med. 1997;103(6):491-7. Does not have a drug comparison of interest. [pmid: 9428832].
Garber AJ, Henry R, Ratner R, Hale P, Chang CT, Bode B. Liraglutide, a human GLP-1 analogue, maintains greater reductions in HbA1c, FPG and weight than glimepiride over 2 years in patients with type 2 diabetes: LEAD-3 extension study. Diabetologia: Diabetologia. 2009;52(S1):S287-288. Other reason.
Garber AJ. Benefits of combination therapy of insulin and oral hypoglycemic agents. Arch Intern Med. 2003;163(15):1781-2. +1785. No original data. [pmid: 12912710].
Garratt KN, Brady PA, Hassinger NL, Grill DE, Terzic A, Holmes DR Jr. Sulfonylurea drugs increase early mortality in patients with diabetes mellitus after direct angioplasty for acute myocardial infarction. J Am Coll Cardiol. 1999;33(1):119-24. Does not have a drug comparison of interest. [pmid: 9935017].
Gastaldelli A, Ferrannini E, Miyazaki Y, Matsuda M, Mari A, DeFronzo RA. Thiazolidinediones improve beta-cell function in type 2 diabetic patients. Am J Physiol Endocrinol Metab. 2007;292(3):E871-83. Does not meet the study design criteria. [pmid: 17106061].
Gegick CG, Altheimer MD. Comparison of effects of thiazolidinediones on cardiovascular risk factors: observations from a clinical practice. Endocr Pract. 2001;7(3):162-9. Does not have a drug comparison of interest. [pmid: 11421562].
Gegick CG, Altheimer MD. Thiazolidinediones: comparison of long-term effects on glycemic control and cardiovascular risk factors. Curr Med Res Opin. 2004;20(6):919-30. Does not meet the study design criteria. [pmid: 15200751].
Gerrits CM, Bhattacharya M, Manthena S, Baran R, Perez A, Kupfer S. A comparison of pioglitazone and rosiglitazone for hospitalization for acute myocardial infarction in type 2 diabetes. Pharmacoepidemiol Drug Saf. 2007;16(10):1065-71. Does not have a drug comparison of interest. [pmid: 17674425].
Gerstein HC, Garon J, Joyce C, Rolfe A, Walter CM. Pre-prandial vs. post-prandial capillary glucose measurements as targets for repaglinide dose titration in people with diet-treated or metformin-treated Type 2 diabetes: a randomized controlled clinical trial. Diabet Med. 2004;21(11):1200-3. Does not apply. [pmid: 15498086].
Gerstein HC, Ratner RE, Cannon CP, et al. Effect of rosiglitazone on progression of coronary atherosclerosis in patients with type 2 diabetes mellitus and coronary artery disease: the assessment on the prevention of progression by rosiglitazone on atherosclerosis in diabetes patients with cardiovascular history trial. Circulation. 2010;121(10):1176-87. Does not have a drug comparison of interest. [pmid: 20194881].
Gerstein HC, Riddle MC, Kendall DM, et al. Glycemia treatment strategies in the Action to Control Cardiovascular Risk in Diabetes (ACCORD) trial. Am J Cardiol. 2007;99:34i-43i. No original data.
Gerstein HC, Yale JF, Harris SB, Issa M, Stewart JA, Dempsey E. A randomized trial of adding insulin glargine vs. avoidance of insulin in people with Type 2 diabetes on either no oral glucose-lowering agents or submaximal doses of metformin and/or sulphonylureas. The Canadian INSIGHT (Implementing New Strategies with Insulin Glargine for Hyperglycaemia Treatment) Study. Diabet Med. 2006;23(7):736-42. Does not have a drug comparison of interest. [pmid: 16842477].
Gerstein HC, Miller ME. Effects of intensive glucose lowering in type 2 diabetes. Action to Control Cardiovascular Risk in Diabetes Study Group. N Engl J Med. 2008;358(24):2545-59. Does not apply. [pmid: 18539917].
Giles TD, Miller AB, Elkayam U, Bhattacharya M, Perez A. Pioglitazone and heart failure: results from a controlled study in patients with type 2 diabetes mellitus and systolic dysfunction. J Card Fail. 2008;14(6):445-52. Does not have a drug comparison of interest. [pmid: 18672190].
Gill GV, Huddle KR. Hypoglycaemic admissions among diabetic patients in Soweto, South Africa. Diabet Med. 1993;10(2):181-3. Does not have a drug comparison of interest. [pmid: 8458198].
Glass LC, Qu Y, Lenox S, et al. Effects of exenatide versus insulin analogues on weight change in subjects with type 2 diabetes: a pooled post-hoc analysis. Curr Med Res Opin. 2008;24(3):639-44. Does not have a drug comparison of interest. [pmid: 18218179].
Glass LC, Triplitt C, Lewis MS, et al. Effects of exenatide plus rosiglitazone on measures of beta cell function and insulin sensitivity in subjects with type 2 diabetes previously treated with metformin. Diabetologia: Diabetologia. 2009;52(S1):S286. Other reason.
GlaxoSmithKline: Study no 049653/211: a 52-week double blind study of the effect of rosiglitazone on cardiovascular structure and function in subjects with type 2 diabetes and congestive heart failure [article online]. Does not have a drug comparison of interest
Glimepiride--well tolerated in daily practice. Cardiovasc J S Afr. 2002;13(4):214-5. No original data. [pmid: 12402929].
Glitazones linked to heart failure. Pharm. J. 2003;271(7266):312. No original data.
Glyburide/metformin (Glucovance) for type 2 diabetes. Med Lett Drugs Ther. 2000;42(1092):105-6. No original data. [pmid: 11077467].
Go EH, Kyriakidou-Himonas M, Berelowitz M. Effects of glipizide GITS and glibenclamide on metabolic control, hepatic glucose production, and insulin secretion in patients with type 2 diabetes. Diabetes Metab Res Rev. 2004;20(3):225-31. Does not have a drug comparison of interest. [pmid: 15133754].
Goke B. Improved glycemic control and lipid profile in a randomized study of pioglitazone compared with acarbose in patients with type 2 diabetes mellitus. Treat Endocrinol. 2002;1(5):329-36. Does not have a drug comparison of interest. [pmid: 15832486].
Goldberg RB, Einhorn D, Lucas CP, et al. A randomized placebo-controlled trial of repaglinide in the treatment of type 2 diabetes. Diabetes Care. 1998;21(11):1897-903. Does not have a drug comparison of interest. [pmid: 9802740].
Goldberg RB, Holvey SM, Schneider J. A dose-response study of glimepiride in patients with NIDDM who have previously received sulfonylurea agents. The Glimepiride Protocol #201 Study Group. Diabetes Care. 1996;19(8):849-56. Does not have a drug comparison of interest. [pmid: 8842603].
Goldstein BJ, Weissman PN, Wooddell MJ, Waterhouse BR, Cobitz AR. Reductions in biomarkers of cardiovascular risk in type 2 diabetes with rosiglitazone added to metformin compared with dose escalation of metformin: an EMPIRE trial sub-study. Curr Med Res Opin. 2006;22(9):1715-23. Does not apply. [pmid: 16968575].
Gonzalez-Ortiz M, et al. Efficacy and safety of glimepiride plus metformin in a single presentation, as combined therapy, in patients with type 2 diabetes mellitus and secondary failure to glibenclamide, as monotherapy. Revista De Investigaci≤n Clϕnica; Organo Del Hospital De Enfermedades De La Nutrici≤n. 2004;56(3):327-33. Not written in English.
Gore MO, McGuire DK. The 10-year post-trial follow-up of the United Kingdom Prospective Diabetes Study (UKPDS): Cardiovascular observations in context. Diabets Vasc Dis Res. 2009;6(1):53-5. No original data.
Gosmanova EO, Canada RB, Mangold TA, Rawls WN, Wall BM. Effect of metformin-containing antidiabetic regimens on all-cause mortality in veterans with type 2 diabetes mellitus. Am J Med Sci. 2008;336(3):241-7. Does not have a drug comparison of interest. [pmid: 18794619].
Gottschalk M, Danne T, Vlajnic A, Cara JF. Glimepiride versus metformin as monotherapy in pediatric patients with type 2 diabetes: a randomized, single-blind comparative study. Diabetes Care. 2007;30(4):790-4. No subjects >18 years old. [pmid: 17392540].
Goudswaard AN, Stolk RP, Zuithoff P, de Valk HW, Rutten GE. Starting insulin in type 2 diabetes: continue oral hypoglycemic agents? A randomized trial in primary care. J Fam Pract. 2004;53(5):393-9. Does not have a drug comparison of interest. [pmid: 15125825].
Gough S, Zinman B, Falahati A, Toft A. The proportion of patients reaching the composite outcome of HbA1c <7.0%, no hypoglycaemia and no weight gain with different Type 2 diabetes therapies in the Liraglutide Effect and Action in Diabetes (LEAD) programme. Diabetic Medicine: Diabet. Med. 2010;27(Suppl 1):77. No original data.
Govindarajan R, Ratnasinghe L, Simmons DL, et al. Thiazolidinediones and the risk of lung, prostate, and colon cancer in patients with diabetes. J Clin Oncol. 2007;25(12):1476-81. Does not apply. [pmid: 17442990].
Goyal A, Crook ED. Thiazolidinediones and progression of renal disease in patients with diabetes. J Investig Med. 2006;54(2):56-61. Does not have a drug comparison of interest.
Grant PJ. The effects of high- and medium-dose metformin therapy on cardiovascular risk factors in patients with type II diabetes. Diabetes Care. 1996;19(1):64-6. Does not have a drug comparison of interest. [pmid: 8720537].
Grant PJ. The effects of metformin on cardiovascular risk factors. Diabetes Metab Rev. 1995;11(Suppl 1):S43-50. No original data. [pmid: 8529484].
Greco D, Angileri G. Drug-induced severe hypoglycaemia in Type 2 diabetic patients aged 80 years or older. Diabetes Nutr Metab. 2004;17(1):23-6. Does not meet the study design criteria. [pmid: 15163121].
Gregorio F, et al. Body mass index, blood lactate and therapeutic effectiveness of metformin in type II diabetes mellitus. Medicina (Florence, Italy). 1989;9(2):200-4. Not written in English.
Gregorio F, et al. Metformin-sulphonylurea combination therapy: the influence of regional adiposity on biguanide-induced haemostatic improvement. Balance in type II diabetic patients. Annals of Experimental and Clinical Medicine. 1994;2:136-45. Other reason.
Gregorio F, Ambrosi F, Filipponi P, Manfrini S, Testa I. Is metformin safe enough for ageing type 2 diabetic patients. Diabetes Metab. 1996;22(1):43-50. No comparison group. [pmid: 8697295].
Gregorio F, Ambrosi F, Manfrini S, et al. Poorly controlled elderly Type 2 diabetic patients: the effects of increasing sulphonylurea dosages or adding metformin. Diabet Med. 1999;16(12):1016-24. Does not have a drug comparison of interest. [pmid: 10656230].
Gregorio F, Manfrini S, Testa I, Filipponi P. Metformin treatment in elderly type II diabetic patients. Arch Gerontol Geriatr. 1996;22(Suppl 1):261-70. Does not have a drug comparison of interest. [pmid: 18653042].
Groop L, Widen E, Franssila-Kallunki A, Ekstrand A. Sulfonylureas and/or insulin in Type 2 diabetes. Less than 40 subjects with type 2 diabetes.
Groop PH, Groop L, Totterman KJ, Pelkonen R. Metabolic effects of glibenclamide and glipizide in patients with type 2 diabetes. ACTA ENDOCRINOL. SUPPL. 1982;100(Suppl 247):25. No subjects >18 years old.
Grossman E. Rosiglitazone reduces blood pressure and urinary albumin excretion in type 2 diabetes: G Bakris et al. J Hum Hypertens. 2003;17(1):5-6. No original data. [pmid: 12571610].
Grossman LD, Parlan G, Bailey AL, Yee G, Yu M, Chan JY. Tolerability outcomes of a multicenter, observational, open-label, drug-surveillance study in patients with type 2 diabetes mellitus treated with pioglitazone for 2 years. Clin Ther. 2009;31(1):74-88. Does not have a drug comparison of interest. [pmid: 19243708].
Guillausseau PJ. PROactive study. Lancet. 2006;367(9504):23. author reply 26–27. No original data. [pmid: 16399140].
Guler S, Cakir B, Demirbas B, Gursoy G, Serter R, Aral Y. Leptin concentrations are related to glycaemic control, but do not change with short-term oral antidiabetic therapy in female patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2000;2(5):313-6. Study duration less than 3 months. [pmid: 11225747].
Guler S, Sharma SK, Almustafa M, et al. Improved Glycaemic Control with Biphasic Insulin Aspart 30 in Type 2 Diabetes Patients Failing Oral Antidiabetic Drugs: PRESENT Study Results. Arch Drug Inf. 2009;2(2):23-33. Does not have a drug comparison of interest. [pmid: 19684847].
Gupta AK, Bray GA, Greenway FL, Martin CK, Johnson WD, Smith SR. Pioglitazone, but not metformin, reduces liver fat in Type-2 diabetes mellitus independent of weight changes. J Diabetes Complications. 2009. Other reason.
Gupta M, Braga MB, Verma S. A randomized, controlled trial of the effects of rosiglitazone on adipokines, and inflammatory and fibrinolytic markers in diabetic patients: study design and protocol. Can J Cardiol. 2008;24(10):e65-9. Other reason. [pmid: 18841263].
Habib SS, Aslam M, Naveed AK, Razi MS. Comparison of lipid profiles and lipoprotein a levels in patients with type 2 diabetes mellitus during oral hypoglycemic or insulin therapy. Saudi Med J. 2006;27(2):174-80. Does not meet the study design criteria. [pmid: 16501671].
Habib ZA, Tzogias L, Havstad SL, et al. Relationship between thiazolidinedione use and cardiovascular outcomes and all-cause mortality among patients with diabetes: a time-updated propensity analysis. Pharmacoepidemiol Drug Saf. 2009;18(6):437-47. Does not have a drug comparison of interest. [pmid: 19235778].
Haffner SM, Greenberg AS, Weston WM, Chen H, Williams K, Freed MI. Effect of rosiglitazone treatment on nontraditional markers of cardiovascular disease in patients with type 2 diabetes mellitus. Circulation. 2002;106(6):679-84. Does not have a drug comparison of interest. [pmid: 12163427].
Hammer H, Klinge A. Patients with type 2 diabetes inadequately controlled on premixed insulin: Effect of initiating insulin glargine plus oral antidiabetic agents on glycaemic control in daily practice. Int J Clin Pract. 2007;61(12):2009-18. No comparison group. [pmid: 17997807].
Hanefeld M, et al. Risk factors for myocardial infarction and death in newly detected NIDDM: the Diabetes Intervention Study, 11-year follow-up. Diabetologia. 1996;39(12):1577-83. Does not have a drug comparison of interest. [pmid: 8960845].
Hanefeld M, Bouter KP, Dickinson S, Guitard C. Rapid and short-acting mealtime insulin secretion with nateglinide controls both prandial and mean glycemia. Diabetes Care. 2000;23(2):202-7. Does not have a drug comparison of interest. [pmid: 10868832].
Hanefeld M, Goke B. Combining pioglitazone with a sulphonylurea or mefformin in the management of type 2 diabetes. Exp Clin Endocrinol Diabetes. 2000;108:256-66. No original data.
Hanefeld M, Herman G, Mickel C. Effect of MK-0431, a dipeptidyl peptidase IV (DPP-4) inhibitor, on glycemic control after 12 weeks in patients with type 2 diabetes. Diabetologia. 2005;48:287-8. Other reason.
Hanefeld M, Temelkova-Kurktschiev T, Kohler C. Effect of oral antidiabetics and insulin on lipids and coronary heart disease in non-insulin-dependent diabetes mellitus. ANN NEW YORK ACAD SCI. 1997;827:246-68. No original data. [pmid: 9329759].
Hao Y, et al. Effects of pioglitazone on elderly patients with type 2 diabetes mellitus. Medical Journal of Wuhan University. 2006;27(1):104-7. Not written in English.
Harashima K, Hayashi J, Miwa T, Tsunoda T. Long-term pioglitazone therapy improves arterial stiffness in patients with type 2 diabetes mellitus. Metabolism. 2009;58(6):739-45. Does not meet the study design criteria. [pmid: 19446110].
Harris S, Yale J-F, Dempsey E, Gerstein H. Can family physicians help patients initiate basal insulin therapy successfully?: Randomized trial of patient-titrated insulin glargine compared with standard oral therapy: Lessons for family practice from the Canadian INSIGHT trial. Can Fam Phys. 2008;54(4):550-8. Does not apply.
Harrower AD. Comparison of diabetic control in type 2 (non-insulin dependent) diabetic patients treated with different sulphonylureas. Curr Med Res Opin. 1985;9(10):676-80. Does not have a drug comparison of interest. [pmid: 3935376].
Hartung DM, Touchette DR, Bultemeier NC, Haxby DG. Risk of hospitalization for heart failure associated with thiazolidinedione therapy: a medicaid claims-based case-control study. Pharmacotherapy. 2005;25(10):1329-36. Does not have a drug comparison of interest. [pmid: 16185176].
Hasche H, Mertes G, Bruns C, et al. Effects of acarbose treatment in Type 2 diabetic patients under dietary training: a multicentre, double-blind, placebo-controlled, 2-year study. Diabetes Nutr Metab. 1999;12(4):277-85. Does not have a drug comparison of interest. [pmid: 10782754].
Hasslacher C. Safety and efficacy of repaglinide in type 2 diabetic patients with and without impaired renal function. Diabetes Care. 2003;26(3):886-91. No comparison group. [pmid: 12610054].
Haupt E, Knick B, Koschinsky T, Liebermeister H, Schneider J, Hirche H. Oral antidiabetic combination therapy with sulphonylureas and metformin. Diabete Metab. 1991;17:224-31. No comparison group. [pmid: 1936481].
Hays JH, Gorman RT, Shakir KM. Results of use of metformin and replacement of starch with saturated fat in diets of patients with type 2 diabetes. Endocr Pract. 2002;8(3):177-83. Does not apply. [pmid: 12113629].
Hayward RA, Manning WG, Kaplan SH, Wagner EH, Greenfield S. Starting insulin therapy in patients with type 2 diabetes: effectiveness, complications, and resource utilization. JAMA. 1997;278(20):1663-9. Does not have a drug comparison of interest. [pmid: 9388085].
Hegele RA, et al. Differential response of plasma lipoprotein(a) and apolipoprotein B in NIDDM subjects treated with acarbose. Diabetes Care. 1995;18(2):272-3. Does not have a drug comparison of interest. [pmid: 7729310].
Heine R, Van Gaal L, Johns D, et al. Exenatide achieved equivalent glycaemic control to insulin glargine in metformin and sulphonylurea-treated type 2 diabetics: blood pressure results. JEI. 2006;29(Suppl 4):28. Other reason.
Heine RJ, Van Gaal LF, Johns D. Exenatide achieved equivalent glycaemic control to insulin glargine with weight reduction, independently from baseline BMI, in metformin and sulphonylurea-treated type 2 diabetes. JEI. 2007;30(Suppl 4):105. Other reason.
Heliovaara MK, Herz M, Teppo AM, Leinonen E, Ebeling P. Pioglitazone has anti-inflammatory effects in patients with Type 2 diabetes. J Endocrinol Invest. 2007;30(4):292-7. Other reason. [pmid: 17556865].
Hellgren M, Melander A, Ostgren CJ, Rastam L, Lindblad U. Inverse association between plasma homocysteine, sulphonylurea exposure and physical activity: a community-based sample of type 2 diabetes patients in the Skaraborg hypertension and diabetes project. Diabetes Obes Metab. 2005;7(4):421-9. Does not apply. [pmid: 15955129].
Hendra TJ, TC. A randomised trial of insulin on well-being and carer strain in elderly type 2 diabetic subjects. J Diabetes Complications. 2004;18(3):148-54. Does not apply. [pmid: 15145325].
Henriksen JH, Ring-Larsen H. Rosiglitazone: Possible complications and treatment of non-alcoholic steatohepatitis (NASH). J Hepatol. 2008;48(1):174-6. No original data. [pmid: 18022724].
Hermann LS, Lindberg G, Lindblad U, Melander A. Efficacy, effectiveness and safety of sulphonylurea-metformin combination therapy in patients with type 2 diabetes. Diabetes Obes Metab. 2002;4(5):296-304. No original data. [pmid: 12190992].
Hermann LS, Schersten B, Melander A. Antihyperglycaemic efficacy, response prediction and dose-response relations of treatment with metformin and sulphonylurea, alone and in primary combination. Diabet Med. 1994;11(10):953-60. Other reason. [pmid: 7895460].
Hermansen K, Davies M, Derezinski T, Ravn GM, Clauson P, Home P. A 26-week, randomized, parallel, treat-to-target trial comparing insulin detemir with NPH insulin as add-on therapy to oral glucose-lowering drugs in insulin-Naive people with type 2 diabetes. Diabetes Care. 2006;29(6):1269-74. Does not have a drug comparison of interest. [pmid: 16732007].
Herz M, Johns D, Reviriego J, et al. A randomized, double-blind, placebo-controlled, clinical trial of the effects of pioglitazone on glycemic control and dyslipidemia in oral antihyperglycemic medication-naive patients with type 2 diabetes mellitus. Clin Ther. 2003;25(4):1074-95. Does not have a drug comparison of interest. [pmid: 12809958].
Hettihewa LM, et al. Correlation between changes of blood pressure with insulin resistance in type 2 diabetes mellitus with 4 weeks of pioglitazone therapy. International Journal of Diabetes in Developing Countries. 2008;28(1):26-30. Does not meet the study design criteria. [pmid: 19902036].
Higginbotham L, Martin FIR. Double-blind trial of metformin in the therapy of non-ketotic diabetics. Med J Aust. 1979;2:154-6. Less than 40 subjects with type 2 diabetes.
Hinke SA, McIntosh CH, Hoffmann T, et al. On combination therapy of diabetes with metformin and dipeptidyl peptidase IV inhibitors. Diabetes Care. 2002;25(8):1490-1. author reply 1491. No original data. [pmid: 12145269].
Hiralal R, Koo KK, Gerstein HC. Does pioglitazone prevent macrovascular events in patients with type 2 diabetes. CMAJ. 2006;174(8):1090-1. No original data. [pmid: 16606956].
Hoffmann JK. Adjustment of metabolism and eating behaviour of type II diabetics. Results of a six-months treatment with glibenclamide, respectively with acarbose. Zeitschrift F^n^r Allgemeinmedizin. 1992;68(29):970-7. Not written in English.
Hohberg C, Pfutzner A, Forst T, et al. Successful switch from insulin therapy to treatment with pioglitazone in type 2 diabetes patients with residual beta-cell function: results from the PioSwitch study. Diabetes Obes Metab. 2009;11(5):464-71. No comparison group. [pmid: 19422402].
Hollander PA, Schwartz SL, Gatlin MR, et al. Importance of early insulin secretion: comparison of nateglinide and glyburide in previously diet-treated patients with type 2 diabetes. Diabetes Care. 2001;24(6):983-8. Does not have a drug comparison of interest. [pmid: 11375357].
Holleman F, et al. Trial of pioglitazone for the secondary prevention of cardiovascular events in patients with diabetes mellitus type 2: insufficient evidence. Ned Tijdschr Geneeskd. 2006;150(7):358-60. Not written in English. [pmid: 16523797].
Holman RR, Cull CA, Turner RC. A randomized double-blind trial of acarbose in type 2 diabetes shows improved glycemic control over 3 years (U.K. Prospective Diabetes Study 44). Diabetes Care. 1999;22(6):960-4. Does not have a drug comparison of interest. [pmid: 10372249].
Holman RR, Farmer AJ, Davies MJ, et al. Three-year efficacy of complex insulin regimens in type 2 diabetes. N Engl J Med. 2009;361(18):1736-47. Does not have a drug comparison of interest. [pmid: 19850703].
Holman RR, Paul SK, Bethel MA, Matthews DR, Neil HA. 10-year follow-up of intensive glucose control in type 2 diabetes. N Engl J Med. 2008;359(15):1577-89. Does not have a drug comparison of interest. [pmid: 18784090].
Holman RR, Retnakaran R, Farmer A, Stevens R. PROactive study. Lancet. 2006;367(9504):25-26. author reply 26–27. No original data. [pmid: 16399144].
Holman RR, Thorne KI, Farmer AJ, et al. Addition of biphasic, prandial, or basal insulin to oral therapy in type 2 diabetes. N Engl J Med. 2007;357(17):1716-30. Does not apply. [pmid: 17890232].
Holstein A, Plaschke A, Egberts EH. Lower incidence of severe hypoglycaemia in patients with type 2 diabetes treated with glimepiride versus glibenclamide. Diabetes Metab Res Rev. 2001;17(6):467-73. Does not have a drug comparison of interest. [pmid: 11757083].
Home P, Gubb J. Rosiglitazone evaluated for cardiac outcomes and regulation of glycemia in diabetes (RECORD): a long-term cardiovascular outcome study. Diabetes. 2002;51(Suppl 2):A487. Other reason.
Home P, Komajada M, Beck-Nielsen H, Curtis P, Zambanini A, Dargie H. Twelve months sustained efficacy of rosiglitazone combination therapy on ambulatory blood pressure (ABP) in people with type 2 diabetes mellitus. Diabetes. 2005;54(Suppl 1):A134. Other reason.
Home PD, Pocock SJ, Beck-Nielsen H, et al. Rosiglitazone evaluated for cardiovascular outcomes--an interim analysis. N Engl J Med. 2007;357(1):28-38. Does not have a drug comparison of interest. [pmid: 17551159].
Honisett S, et al. Rosiglitazone improves vascular function in postmenopausal women with Type 2 diabetes mellitus and hormonal therapy attenuates this improvement. The 6th Australasian Menopause Society Congress 2002. Other reason.
Hoogeveen EK, Kostense PJ, Jakobs C, Bouter LM, Heine RJ, Stehouwer CD. Does metformin increase the serum total homocysteine level in non-insulin-dependent diabetes mellitus. J Intern Med. 1997;242(5):389-94. Does not meet the study design criteria. [pmid: 9408068].
Horowitz M, Vilsboll T, Zdravkovic M, Hammer M, Madsbad S. Patient-reported rating of gastrointestinal adverse effects during treatment of type 2 diabetes with the once-daily human GLP-1 analogue, liraglutide. Diabetes, Obesity and Metabolism: Diabestes Obes Metab. 2008;10(7):593-6. Does not have a drug comparison of interest.
Horsdal HT, Johnsen SP, Sondergaard F, Rungby J. Type of preadmission glucose-lowering treatment and prognosis among patients hospitalised with myocardial infarction: a nationwide follow-up study. Diabetologia. 2008;51(4):567-74. Does not have a drug comparison of interest. [pmid: 18283428].
Hotta N, et al. Diabetic neuropathy: effects of intensified glycaemic control with multiple insulin injections. Diabetic Medicine: a Journal of the British Diabetic Association. 1993;10(Suppl 2):91S-4S. Other reason. [pmid: 8334854].
Houlden R, Ross S, Harris S, Yale J-F, Sauriol L, Gerstein HC. Treatment satisfaction and quality of life using an early insulinization strategy with insulin glargine compared to an adjusted oral therapy in the management of Type 2 diabetes: The Canadian INSIGHT Study. Diabetes Res Clin Pract. 2007;78(2):254-8. Does not apply. [pmid: 17490781].
Howes LG. Cardiovascular effects of sulphonylureas: role of K(ATP) channels. Diabetes Obes Metab. 2000;2(2):67-73. No original data. [pmid: 11220526].
Hristov V, Sheinkova G, Simeonov S, Botushanov N, Valkov Y, Tzinlikov I. Clinical assessment of glimepiride (Amaril(registered trademark)) in the treatment of type 2 diabetes mellitus patients (results of a multicenter study). Endocrinologia (Bulgaria). 2002;7(1):30-5. Not written in English.
Hsiao FY, Mullins CD. The association between thiazolidinediones and hospitalisation for fracture in type 2 diabetic patients: a Taiwanese population-based nested case-control study. Diabetologia. 2009. Does not have a drug comparison of interest.
Huang Z, et al. Effects of rosiglitazone on the IMTc and serum MMP-9 levels in newly diagnosed Type 2 diabetic patients. Zhong Nan Da Xue Xue Bao Yi Xue Ban (Journal of Central South University Medical Sciences). 2006;31(3):367-72. Not written in English. [pmid: 16859126].
Hulisz DT, Bonfiglio MF, Murray RD. Metformin-associated lactic acidosis. J Am Board Fam Pract. 1998;11(3):233-6. No comparison group. [pmid: 9625516].
Iavicoli M, Cucinotta D, De Mattia G, et al. Blood glucose control and insulin secretion improved with combined therapy in type 2 diabetic patients with secondary failure to oral hypoglycaemic agents. Diabetic Med. 1988;5(9):849-55. Does not have a drug comparison of interest. [pmid: 2976646].
Inukai K, Watanabe M, Nakashima Y, et al. Efficacy of glimepiride in Japanese type 2 diabetic subjects. Diabetes Res Clin Pract. 2005;68(3):250-7. Does not have a drug comparison of interest. [pmid: 15936468].
Inzucchi S, Leiter LA, Rosenstock J. Type 2 diabetes and TZDs (thiazolidinediones): Diabetes de tipo 2 y las TZD (tiazolidinedionas). J. Clin. Endocrinol. Metab. 2009;94(11). No original data.
Inzucchi SE, Masoudi FA, Wang Y, et al. Insulin-sensitizing antihyperglycemic drugs and mortality after acute myocardial infarction: Insights from the national heart care project. Diabetes Care. 2005;28(7):1680-9. Does not have a drug comparison of interest. [pmid: 15983320].
Iozzo P, Hallsten K, Oikonen V, et al. Effects of metformin and rosiglitazone monotherapy on insulin-mediated hepatic glucose uptake and their relation to visceral fat in type 2 diabetes. Diabetes Care. 2003;26(7):2069-74. Less than 40 subjects with type 2 diabetes. [pmid: 12832315].
Isley WL, Oki JC. Hepatotoxicity of thiazolidinediones. Diab Obesity Metabol. 2001;3(6):389-92. No original data.
Ito H. Japanese Elderly Diabetes Intervention Trial (J-EDIT). Nippon Rinsho. 2006;64(1):21-6. Not written in English. [pmid: 16408442].
Jackson M, Nussey S, Mudan S. Metformin induced lactic acidosis. Clin Intensive Care. 2000;11(4):209-13. No comparison group.
Janssen PG, et al. Randomised controlled trial of intensive multifactorial treatment for cardiovascular risk in patients with screen-detected type 2 diabetes: 1-year data from the ADDITION Netherlands study. The British Journal of General Practice : the Journal of the Royal College of General Practitioners. 2009;59(558):43-8. Does not apply. [pmid: 19105915].
Jendle J, Nauck MA, Matthews DR, et al. Weight loss with liraglutide, a once-daily human glucagon-like peptide-1 analogue for type 2 diabetes treatment as monotherapy or added to metformin, is primarily as a result of a reduction in fat tissue. Diabetes Obes Metab. 2009;11(12):1163-72. Other reason. [pmid: 19930006].
Jennings AM, Wilson RM, Ward JD. Symptomatic hypoglycemia in NIDDM patients treated with oral hypoglycemic agents. Diabetes Care. 1989;12(3):203-8. Does not meet the study design criteria. [pmid: 2702912].
Jermendy G, Erdesz D, Nagy L, et al. Outcomes of adding second hypoglycemic drug after metformin monotherapy failure among type 2 diabetes in Hungary. Health Qual Life Outcomes. 2008;6:88. Does not meet the study design criteria. [pmid: 18976457].
Jerums G, Murray RML, Seeman E. Lack of effect of gliclazide on early diabetic nephropathy and retinopathy: A two-year controlled study. Diabetes Res Clin Pract. 1987;3(2):71-80. Does not have a drug comparison of interest. [pmid: 3552537].
Jialal I, Joubert SM. The effect of oral hypoglycaemic agents on lipid levels in non-insulin-dependent diabetes in the young. S AFR MED J. 1982;62(11):348-9. No original data. [pmid: 7112299].
Johnsen SP, Monster TB, Olsen ML, et al. Risk and short-term prognosis of myocardial infarction among users of antidiabetic drugs. Am J Ther. 2006;13(2):134-40. Does not have a drug comparison of interest. [pmid: 16645430].
Jones N, Jones T, Menci L. Rosiglitazone in combination with glimenclamide plus metformin is effective and well tolerated in type 2 diabetes patients. Diabetologia. 2001;44(Suppl 1):A235. Other reason.
Jonsson A, Hallengren B, Rydberg T, Melander A. Effects and serum levels of glibenclamide and its active metabolites in patients with type 2 diabetes. Diabetes Obes Metab. 2001;3(6):403-9. Less than 40 subjects with type 2 diabetes. [pmid: 11903411].
Josse RG. Acarbose for the treatment of type II diabetes: the results of a Canadian multi-centre trial. Diabetes Res Clin Pract. 1995;28(Suppl):S167-72. Does not have a drug comparison of interest. [pmid: 8529510].
Jovanovic L, Dailey G 3rd, Huang WC, Strange P, Goldstein BJ. Repaglinide in type 2 diabetes: a 24-week, fixed-dose efficacy and safety study. J Clin Pharmacol. 2000;40(1):49-57. Does not have a drug comparison of interest. [pmid: 10631622].
Jun JK, Gong WC, Mathur R. Effects of pioglitazone on diabetes-related outcomes in Hispanic patients. Am J Health Syst Pharm. 2003;60(5):469-73. No comparison group. [pmid: 12635453].
Jung W, Jung S. Effects of pioglitazone and insulin on tight glycaemic control assessed by the continuous glucose monitoring system: A monocentric, parallel-cohort study. Clin Drug Invest. 2005;25(5):347-52. Less than 40 subjects with type 2 diabetes.
Kabadi MU, Kabadi UM. Efficacy of sulfonylureas with insulin in type 2 diabetes mellitus. Ann Pharmacother. 2003;37(11):1572-6. Does not have a drug comparison of interest. [pmid: 14565810].
Kacerovsky-Bielesz G, Dressler A, Freunscht R. Long-term glycaemic control with insulin glargine in Type 2 diabetes. Diabetes Res Clin Pract. 2006;71(2):184-91. No comparison group. [pmid: 16112241].
Kadoglou NP, Iliadis F, Liapis CD, Perrea D, Angelopoulou N, Alevizos M. Beneficial effects of combined treatment with rosiglitazone and exercise on cardiovascular risk factors in patients with type 2 diabetes. Diabetes Care. 2007;30(9):2242-4. Does not have a drug comparison of interest. [pmid: 17586747].
Kahn CR, Chen L, Cohen SE. Unraveling the mechanism of action of thiazolidinediones. J Clin Invest. 2000;106(11):1305-7. No original data. [pmid: 11104782].
Kahn SE, Haffner SM, Viberti G, et al. Rosiglitazone decreases C-reactive protein to a greater extent relative to glyburide and metformin over 4 years despite greater weight gain: observations from a Diabetes Outcome Progression Trial (ADOPT). Diabetes Care. 2010;33(1):177-83. Does not have a drug comparison of interest. [pmid: 19808911].
Kahn SE, Zinman B, Lachin JM, et al. Rosiglitazone-associated fractures in type 2 diabetes. Diabetes Care. 2008;31(5):845-51. Other reason. [pmid: 18223031].
Kamber N, Davis WA, Bruce DG, Davis TM. Metformin and lactic acidosis in an Australian community setting: the Fremantle Diabetes Study. Med J Aust. 2008;188(8):446-9. No comparison group. [pmid: 18429709].
Kanazawa I, Yamaguchi T, Yano S, et al. Baseline atherosclerosis parameter could assess the risk of bone loss during pioglitazone treatment in type 2 diabetes mellitus. Osteoporos Int. 2010. Does not have a drug comparison of interest.
Kane MP, Busch RS, Bakst G, Hamilton RA. Substitution of pioglitazone for troglitazone in patients with type 2 diabetes. Endocr Pract. 2004;10(1):18-23. Does not have a drug comparison of interest. [pmid: 15251617].
Kanzer-Lewis G. Early combination therapy with a thiazolidinedione for the treatment of type 2 diabetes. Diabetes Educ. 2003;29(6):954-8. 961. No original data. [pmid: 14692369].
Karagiannis E, Pfutzner A, Forst T, et al. The IRIS V study: pioglitazone improves systemic chronic inflammation in patients with type 2 diabetes under daily routine conditions. Diabetes Technol Ther. 2008;10(3):206-12. No comparison group. [pmid: 18473695].
Karalliedde J, Smith A, Viberti G. Determinants of response to insulin therapy following failure of oral agents in type 2 diabetes. Diabetes Care. 2005;28(10):2589-90. No comparison group. [pmid: 16186308].
Karasik A, Wu M, Williams-Herman D. Sitagliptin added to ongoing metformin therapy provides sustained glycemic control over 54 weeks, with a low incidence of hypoglycaemia and weight loss. American Diabetes Association Congress. 2007;P05:23. Other reason.
Kardas P. The DIACOM study (effect of DosIng frequency of oral Antidiabetic agents on the COMpliance and biochemical control of type 2 diabetes). Diabetes Obes Metab. 2005;7(6):722-8. Does not have a drug comparison of interest. [pmid: 16219016].
Karter AJ, Moffet HH, Liu J, et al. Achieving good glycemic control: initiation of new antihyperglycemic therapies in patients with type 2 diabetes from the Kaiser Permanente Northern California Diabetes Registry. Am J Manag Care. 2005;11(4):262-70. Does not meet the study design criteria. [pmid: 15839186].
Karter AJ, Moffet HH, Liu J, et al. Glycemic response to newly initiated diabetes therapies. Am J Manag Care. 2007;13(11):598-606. Does not meet the study design criteria. [pmid: 17988185].
Kasliwal R, Wilton LV, Shakir SA. Monitoring the safety of pioglitazone : results of a prescription-event monitoring study of 12,772 patients in England. Drug Saf. 2008;31(10):839-50. Does not apply. [pmid: 18759508].
Kaur RH, et al. Management of type 2 diabetes mellitus : Gliclazide v/s glimepride [abstract no:16]. J Assoc Physicians India. 2002:50. Other reason.
Kaushal S, Chopra SC, Arora S. Exenatide: An incretin-mimetic agent. Indian J Pharmacol. 2006;38(1):76-8. No original data.
Kawamori R, et al. Determination of the glycemic threshold for the regression or prevention of diabetic microangiopathies, and the insulin injection regimen to establish strict glycemic control in NIDDM. Jpn J Med. 1991;30(6):618-21. Does not have a drug comparison of interest. [pmid: 1798230].
Kawamori R, Kadowaki T, Onji M, Seino Y, Akanuma Y. Hepatic safety profile and glycemic control of pioglitazone in more than 20,000 patients with type 2 diabetes mellitus: postmarketing surveillance study in Japan. Diabetes Res Clin Pract. 2007;76(2):229-35. Does not meet the study design criteria. [pmid: 17109986].
Kennedy L, Herman WH. Renal status among patients using metformin in a primary care setting. Diabetes Care. 2005;28(4):922-4. No comparison group. [pmid: 15793196].
Kerenyi Z, Samer H, James R, Yan Y, Stewart M. Combination therapy with rosiglitazone and glibenclamide compared with upward titration of glibenclamide alone in patients with type 2 diabetes mellitus. Diabetes Res Clin Pract. 2004;63(3):213-23. Does not have a drug comparison of interest. [pmid: 14757293].
Khandekar S, Sethi BK, Dash RJ. Effect of sulphonylurea therapy on insulin sensitivity in non insulin dependent diabetics. J Assoc Physicians India. 1990;38(7):469-71. Study duration less than 3 months. [pmid: 2127273].
Kiayias JA, Vlachou ED, Theodosopoulou E, Lakka-Papadodima E. Rosiglitazone in combination with glimepiride plus metformin in type 2 diabetic patients. Diabetes Care. 2002;25(7):1251-2. Less than 40 subjects with type 2 diabetes. [pmid: 12087036].
Kilo C, Williamson JR. The controversial American University Group Diabetes Study--a look at sulfonylurea and biguanide therapy. Horm Metab Res Suppl. 1985;15:102-4. No original data. [pmid: 3908276].
Kilo C. Multicenter comparison of glyburide and glipizide in the treatment of non-insulin-dependent diabetes mellitus. Clin Ther. 1988;10(3):294-302. Does not have a drug comparison of interest. [pmid: 3152586].
Kim YM, Cha BS, Kim DJ, et al. Predictive clinical parameters for therapeutic efficacy of rosiglitazone in Korean type 2 diabetes mellitus. Diabetes Res Clin Pract. 2005;67(1):43-52. Does not have a drug comparison of interest. [pmid: 15620433].
King AB, Armstrong DU, Chinnapongse S. Comparison of glycemic and lipid response to pioglitazone treatment in Mexican-Americans and non-Hispanic Caucasians with type 2 diabetes. Diabetes Care. 2003;26(1):245-6. Does not meet the study design criteria. [pmid: 12502690].
King AB. A comparison in a clinical setting of the efficacy and side effects of three thiazolidinediones. Diabetes Care. 2000;23(4):557. Does not have a drug comparison of interest. [pmid: 10857952].
King KA, Levi VE. Prevalence of edema in patients receiving combination therapy with insulin and thiazolidinedione. Am. J. Health-Syst Pharm. 2004;61(4):390-3. Does not apply. [pmid: 15011768].
Kipnes MS, Krosnick A, Rendell MS, Egan JW, Mathisen AL, Schneider RL. Pioglitazone hydrochloride in combination with sulfonylurea therapy improves glycemic control in patients with type 2 diabetes mellitus: a randomized, placebo-controlled study. Am J Med. 2001;111(1):10-7. Does not have a drug comparison of interest. [pmid: 11448655].
Klamann A, Sarfert P, Launhardt V, Schulte G, Schmiegel WH, Nauck MA. Myocardial infarction in diabetic vs non-diabetic subjects. Survival and infarct size following therapy with sulfonylureas (glibenclamide). Eur Heart J. 2000;21(3):220-9. Does not apply. [pmid: 10639304].
Klonoff DC, Buse JB, Nielsen LL, et al. Exenatide effects on diabetes, obesity, cardiovascular risk factors and hepatic biomarkers in patients with type 2 diabetes treated for at least 3 years. Curr Med Res Opin. 2008;24(1):275-86. Does not have a drug comparison of interest. [pmid: 18053320].
Klonoff DC, Buse JB, Nielsen LL, et al. Exenatide effects on diabetes, obesity, cardiovascular risk factors and hepatic biomarkers in patients with type 2 diabetes treated for at least 3 years. Curr Med Res Opin. 2008;24(1):275-86. Does not have a drug comparison of interest. [pmid: 18053320].
Knight PV, Semple CG, Kesson CM. The use of metformin in the older patient. J Clin Exp Gerontol. 1986;8(1-2):51-8. Does not have a drug comparison of interest.
Ko GT, Chan WB, Chan JC, Tsang LW, Cockram CS. Gastrointestinal symptoms in Chinese patients with Type 2 diabetes mellitus. Diabet Med. 1999;16(8):670-4. Does not have a drug comparison of interest. [pmid: 10477212].
Ko GT, Tsang PC, Wai HP, Kan EC, Chan HC. Rosiglitazone versus bedtime insulin in the treatment of patients with conventional oral antidiabetic drug failure: a 1-year randomized clinical trial. Adv Ther. 2006;23(5):799-808. Does not have a drug comparison of interest. [pmid: 17142216].
Ko SH, Song KH, Ahn YB, et al. The effect of rosiglitazone on serum lipoprotein(a) levels in Korean patients with type 2 diabetes mellitus. Metabolism. 2003;52(6):731-4. Does not have a drug comparison of interest. [pmid: 12800099].
Kolterman OG, Scarlett JA, Gray RS. The effect of glyburide treatment on insulin binding, insulin responsiveness, and insulin secretion in type II diabetes mellitus (NIDDM). Clin Re. 1982;30(2):397A. No subjects >18 years old.
Komajda M, Curtis P, Hanefeld M, et al. Effect of the addition of rosiglitazone to metformin or sulfonylureas versus metformin/sulfonylurea combination therapy on ambulatory blood pressure in people with type 2 diabetes: a randomized controlled trial (the RECORD study). Cardiovasc Diabetol. 2008;7:10. Does not apply. [pmid: 18435852].
Konrad T, Lubben G, Franzen C. Pioglitazone lowers blood pressure in hypertensive patients with type 2 diabetes mellitus: an open, multicentre, observational study. Clin Drug Investig. 2005;25(5):337-40. Does not apply.
Koppel H, et al. Observations on the effect of glibenclamide on noninvasive clinical parameters of myocardial ischemia. Cardiovascular Drugs and Therapy / Sponsored by the International Society of Cardiovascular Pharmacotherapy. 1998;12(4):383-5. Less than 40 subjects with type 2 diabetes. [pmid: 9825184].
Koro C, Barrett S, Qizilbash N. Cancer risks in thiazolidinedione users compared to other anti-diabetic agents. Pharmacoepidemiol Drug Saf. 2007;16(5):485-92. Does not apply. [pmid: 17192841].
Koro CE, Bowlin SJ, Weiss SR. Antidiabetic therapy and the risk of heart failure in type 2 diabetic patients: an independent effect or confounding by indication. Pharmacoepidemiol Drug Saf. 2005;14(10):697-703. Other reason. [pmid: 15654719].
Koro CE, Fu Q, Stender M. An assessment of the effect of thiazolidinedione exposure on the risk of myocardial infarction in type 2 diabetic patients. Pharmacoepidemiol Drug Saf. 2008;17(10):989-96. Does not have a drug comparison of interest. [pmid: 18759378].
Kosachunhanun N, Benjasuratwong Y, Mongkolsomlit S, et al. Thailand diabetes registry project: glycemic control in Thai type 2 diabetes and its relation to hypoglycemic agent usage. J Med Assoc Thai. 2006;89(Suppl 1):S66-71. Does not meet the study design criteria. [pmid: 17715836].
Koshiyama H, Shimono D, Kuwamura N, Minamikawa J, Nakamura Y. Rapid communication: inhibitory effect of pioglitazone on carotid arterial wall thickness in type 2 diabetes. J Clin Endocrinol Metab. 2001;86(7):3452-6. Does not have a drug comparison of interest. [pmid: 11443224].
Kreider M, Heise M. Rosiglitazone in the management of older patients with type 2 diabetes mellitus. Int J Clin Pract. 2002;56(7):538-41. Does not have a drug comparison of interest. [pmid: 12296617].
Kristensen JS, Clauson P, Bayer T, Frandsen KB. The frequency of severe hypoglycaemia is reduced with repaglinide treatment compared with sulphonylurea treatment. Eur J Endocrinology. 1999;140(Suppl 1):19. Other reason.
Ksela U, Zemljic E, Rakusa M, Cokolic M. Glycemic control before and after starting insulin therapy in obese and other type 2 diabetics. Diabetol Croat. 2007;35(3):59-62. No comparison group.
Kubo K. Effect of pioglitazone on blood proinsulin levels in patients with type 2 diabetes mellitus. Endocr J. 2002;49(3):323-8. Does not have a drug comparison of interest. [pmid: 12201216].
Kudva YC, Basu A. Adjunctive inhaled insulin before meals improved glycaemic control more than adjunctive metformin in type 2 diabetes mellitus. Evid-Based Med. 2006;11(6):176. No original data. [pmid: 17213170].
Kunte H, Schmidt S, Eliasziw M, et al. Sulfonylureas improve outcome in patients with type 2 diabetes and acute ischemic stroke. Stroke. 2007;38(9):2526-30. Does not have a drug comparison of interest. [pmid: 17673715].
Kure J. Glipizide and glyburide. N C Med J. 1986;47(3):149-53. No original data. [pmid: 3083269].
Kuusi T, Yki-Jarvinen H, Kauppinen-Makelin R, et al. Effect of insulin treatment on serum lipoprotein(a) in non-insulin-dependent diabetes. Eur J Clin Invest. 1995;25(3):194-200. Does not meet the study design criteria. [pmid: 7781667].
Labrousse-Lhermine F, Cazals L, Ruidavets JB, Hanaire H. Long-term treatment combining continuous subcutaneous insulin infusion with oral hypoglycaemic agents is effective in type 2 diabetes. Diabetes Metab. 2007;33(4):253-60. Does not have a drug comparison of interest. [pmid: 17475531].
Lacknauth S, Patel R, Rappa L, Branch E III. Metformin/glyburide combination therapy for 2 type diabetes. P T. 2001;26(5):268-72. No original data.
Lalau JD, Race JM. Metformin and lactic acidosis in diabetic humans. Diabetes Obes Metab. 2000;2(3):131-7. No original data. [pmid: 11220548].
Landman GW, Kleefstra N, van Hateren KJ, Groenier KH, Gans RO, Bilo HJ. Metformin associated with lower cancer mortality in type 2 diabetes (ZODIAC-16). Diabetes Care. 2009. Does not have a drug comparison of interest.
Lapina IuV, et al. [Efficacy and safety of the use of metformin in patients with chronic heart failure and type 2 diabetes mellitus. results of the study. Not written in English.
Lautamaki R, Airaksinen KEJ, Seppanen M, et al. Insulin improves myocardial blood flow in patients with type 2 diabetes and coronary artery disease. Diabetes. 2006;55(2):511-6. Does not apply. [pmid: 16443788].
Lautamaki R, Nuutila P, Airaksinen KE, et al. The effect of PPARgamma-agonism on LDL subclass profile in patients with type 2 diabetes and coronary artery disease. Rev Diabet Stud. 2006;3(1):31-8. Does not have a drug comparison of interest. [pmid: 17491710].
Lebovitz HE, Dole JF, Patwardhan R, Rappaport EB, Freed MI. Rosiglitazone monotherapy is effective in patients with type 2 diabetes. J Clin Endocrinol Metab. 2001;86(1):280-8. Does not have a drug comparison of interest. [pmid: 11232013].
Lebovitz HE, Kreider M, Freed MI. Evaluation of liver function in type 2 diabetic patients during clinical trials: evidence that rosiglitazone does not cause hepatic dysfunction. Diabetes Care. 2002;25(5):815-21. Does not have a drug comparison of interest. [pmid: 11978674].
Leese GP, Wang J, Broomhall J, et al. Frequency of severe hypoglycemia requiring emergency treatment in type 1 and type 2 diabetes: a population-based study of health service resource use. Diabetes Care. 2003;26(4):1176-80. Does not have a drug comparison of interest. [pmid: 12663593].
Levin F, Kazim M, Smith TJ, Marcovici E. Rosiglitazone-induced proptosis. Arch Ophthalmol. 2005;123(1):119-21. No comparison group. [pmid: 15642828].
Lewis JD, Capra AM, Achacoso NS, et al. Medical therapy for diabetes is associated with increased use of lower endoscopy. Pharmacoepidemiol Drug Saf. 2007;16(11):1195-202. Does not apply. [pmid: 17603822].
Li H, Li W, Gu Y, et al. Comparison of continual insulin or secretagogue treatment in type 2 diabetic patients with alternate insulin-secretagogue administration. Diabetes Res Clin Pract. 2009;84(2):158-62. Does not have a drug comparison of interest. [pmid: 19268383].
Li K, Li L, Yang M, Zong H, Liu H, Yang G. Effects of rosiglitazone on fasting plasma fibroblast growth factor-21 levels in patients with type 2 diabetes mellitus. Eur J Endocrinol. 2009;161(3):391-5. Does not apply. [pmid: 19528204].
Libby G, Donnelly LA, Donnan PT, Alessi DR, Morris AD, Evans JM. New users of metformin are at low risk of incident cancer: a cohort study among people with type 2 diabetes. Diabetes Care. 2009;32(9):1620-5. Does not have a drug comparison of interest. [pmid: 19564453].
Lin KD, Chang YH, Wang CL, et al. Thiazolidinedione addition reduces the serum retinol-binding protein 4 in type 2 diabetic patients treated with metformin and sulfonylurea. Transl Res. 2008;151(6):309-14. No comparison group. [pmid: 18514142].
Lindner J, et al. Presentation of an insulin-treated patient group within the scope of a 5-year study of the Diabetes Intervention Study (DIS). Zeitschrift F^n^r Die Gesamte Innere Medizin Und Ihre Grenzgebiete. 1987;42(7):198-200. Not written in English.
Lipid effects of pioglitazone studied. Br. J. Diabetes Vasc. Dis. 2004;4(3):209. No original data.
Lipscombe LL, Gomes T, Levesque LE, Hux JE, Juurlink DN, Alter DA. Thiazolidinediones and cardiovascular outcomes in older patients with diabetes. JAMA. 2007;298(22):2634-43. Does not have a drug comparison of interest. [pmid: 18073359].
Loebstein R, Vasterman-Landes J, Silverman B, et al. Database evaluation of adverse cardiovascular outcomes, related to rosiglitazone (RSG), in the treatment of type 2 diabetes mellitus (T2DM) patients in the community. Clinical Pharmacology and Therapeutics: Clin Pharmacol Ther. 2009;85:S7. No original data.
Lomuscio A, Fiorentini C. Influence of oral antidiabetic treatment on electrocardiac alterations induced by myocardial infarction. Diabetes Res Clin Pract. 1996;31(Suppl):S21-6. Does not have a drug comparison of interest. [pmid: 8864637].
Lopez-GarciA F, Borras J, Verdu C, et al. Cholestatic hepatitis associated with repaglinide. Diabetes Care. 2005;28(3):752-3. No comparison group. [pmid: 15735221].
Lowry FS, Bevivino MV, Salzman A, Yan Y, Patwardhan R. Rosiglitazone: BRL 49653: a 26- week randomized, double-blind, double dummy, multicenter study to evaluate the efficacy, safety and tolerability of rosiglitazone 4 mg bd when administered to patients with non-insulin dependent diabetes mellitus (NIDDM) who are inadequately controlled on a maintenance dose (2.5g/day) of metformin: report 093 phase IIIA: final clinical report, The Clinical Effectiveness and Cost-Effectiveness of Rosiglitazone for Type 2 Diabetes Mellitus. National Institute for Clinical Excellence. London, England. 08. 2000. Other reason.
Luis Bautista J, Bugos C, Dirnberger G, Atherton T. Efficacy and safety profile of glimepiride in Mexican American Patients with type 2 diabetes mellitus: a randomized, placebo-controlled study. Clin Ther. 2003;25(1):194-209. Does not have a drug comparison of interest. [pmid: 12637120].
Lund SS, Tarnow L, Frandsen M, et al. Erratum: Impact of metformin versus the prandial insulin secretagogue, repaglinide, on fasting and postprandial glucose and lipid responses in non-obese patients with type 2 diabetes (European Journal of Endocrinology vol. 158 (1) : 35–46). Eur J Endocrinol. 2008;158(3):443-5. No original data.
Lund SS, Tarnow L, Stehouwer CD, et al. Impact of metformin versus repaglinide on non-glycaemic cardiovascular risk markers related to inflammation and endothelial dysfunction in non-obese patients with type 2 diabetes. Eur J Endocrinol. 2008;158(5):631-41. Does not apply. [pmid: 18426821].
Lundquist I, Ahren B, Schersten B. Insulin secretagogues. Possible modulators of glucose and non-glucose stimuli. Acta Endocrinol Suppl. 1984;105(262):51-9. No original data.
Lysy J, Israeli E, Goldin E. The prevalence of chronic diarrhea among diabetic patients. Am J Gastroenterol. 1999;94(8):2165-70. No comparison group. [pmid: 10445544].
Mafauzy M. Repaglinide versus glibenclamide treatment of Type 2 diabetes during Ramadan fasting. Diabetes Res Clin Pract. 2002;58(1):45-53. Study duration less than 3 months. [pmid: 12161056].
Maheux P, Doucet J, Allen E, et al. Efficacy and safety of saxagliptin 5 mg once-daily therapy in elderly patients with type 2 diabetes mellitus. Diabetologia: Diabetologia. 2009;52(S1):S302. Other reason.
Manalo GG Jr, Villareal DT, Anel-Quimpo J, Go RT, Litonjua AD. Body weight as a predictor of response to sulfonylurea therapy. Philipp J Intern Med. 1993;31(3):135-43. Other reason.
Manley HJ, Allcock NM. Thiazolidinedione safety and efficacy in ambulatory patients receiving hemodialysis. Pharmacotherapy. 2003;23(7):861-5. Does not have a drug comparison of interest. [pmid: 12885099].
Mannucci E, Monami M, Masotti G, Marchionni N. All-cause mortality in diabetic patients treated with combinations of sulfonylureas and biguanides. Diabetes Metab Res Rev. 2004;20(1):44-7. Does not have a drug comparison of interest. [pmid: 14737744].
Mansour AA, Habib OS. Metformin discontinuation rate among patients with type-2 diabetes mellitus in Basrah, Iraq. Saudi Med J. 2007;28(12):1919-21. No comparison group. [pmid: 18060234].
Manzato E, Zambon A, Lapolla A, et al. Lipoprotein abnormalities in well-treated type II diabetic patients. Diabetes Care. 1993;16(2):469-75. Does not have a drug comparison of interest. [pmid: 8432219].
Manzella D, Grella R, Esposito K, Giugliano D, Barbagallo M, Paolisso G. Blood pressure and cardiac autonomic nervous system in obese type 2 diabetic patients: effect of metformin administration. Am J Hypertens. 2004;17(3):223-7. Does not have a drug comparison of interest. [pmid: 15001195].
Mari A, Nielsen LL, Nanayakkara N, DeFronzo RA, Ferrannini E, Halseth A. Mathematical modeling shows exenatide improved beta-cell function in patients with type 2 diabetes treated with metformin or metformin and a sulfonylurea. Horm Metab Res. 2006;38(12):838-44. Does not apply. [pmid: 17163361].
Marks JB. How do detemir and glargine compare when added to oral agents in insulin-nave patients with type 2 diabetes mellitus. Nat Clin Pract Endocrinol Metab. 2008;4(9):490-1. No original data. [pmid: 18594486].
Marrett E, Zhang Q, Radican L. The impact of frequency and severity of self-reported hypoglycemia on quality of life in patients with type 2 diabetes mellitus treated with oral anti-hyperglycemic agents. Value Health. 2009;12(3):A104. Other reason.
Marshall SM. Oral hypoglycaemic agents. Pract Diabetes Int. 2003;20(7):S1-4. No original data.
Marx N. PERISCOPE and the effect of pioglitazone on the progression of coronary artery disease in patients with diabetes. Diab Vasc Dis Res. 2008;5(4):345-6. No original data. [pmid: 18958845].
Masoudi FA, Inzucchi SE, Wang Y, Havranek EP, Foody JM, Krumholz HM. Thiazolidinediones, metformin, and outcomes in older patients with diabetes and heart failure: an observational study. Circulation. 2005;111(5):583-90. Does not have a drug comparison of interest. [pmid: 15699279].
Massi Benedetti M, Humburg E, Dressler A, Ziemen M. A one-year, randomised, multicentre trial comparing insulin glargine with NPH insulin in combination with oral agents in patients with Type 2 diabetes. Horm Metab Res. 2003;35(3):189-96. Does not have a drug comparison of interest. [pmid: 12734781].
Masud F, Abaidullah S, Rehman AU, Hasan M. Insulin sparing effect of glibenclamide in poorly controlled type-II diabetics and its effect on the Body Mass Index (BMI). SPECIALIST. 1993;9(2):105-8. Does not have a drug comparison of interest.
Masud F, Hasan M, Abaidullah S, Intekhab. Assessment of metabolic profile and body mass index (BMI) in type II diabetics treated with metformin and insulin. Specialist. 1992;9(1):29-34. Less than 40 subjects with type 2 diabetes.
Matsumoto K, Sera Y, Abe Y, Tominaga T, Yeki Y, Miyake S. Metformin attenuates progression of carotid arterial wall thickness in patients with type 2 diabetes. Diabetes Res Clin Pract. 2004;64(3):225-8. Less than 40 subjects with type 2 diabetes. [pmid: 15126012].
Matthews DR, Charbonnel BH, Hanefeld M, Brunetti P, Schernthaner G. Long-term therapy with addition of pioglitazone to metformin compared with the addition of gliclazide to metformin in patients with type 2 diabetes: a randomized, comparative study. Diabetes Metab Res Rev. 2005;21(2):167-74. Does not have a drug comparison of interest. [pmid: 15386821].
Mazzone T, Meyer PM, Feinstein SB, et al. Effect of pioglitazone compared with glimepiride on carotid intima-media thickness in type 2 diabetes: a randomized trial. JAMA. 2006;296(21):2572-81. Other reason. [pmid: 17101640].
McCall AL, Cox DJ, Brodows R, Crean J, Johns D, Kovatchev B. Reduced daily risk of glycemic variability: comparison of exenatide with insulin glargine. Diabetes Technol Ther. 2009;11(6):339-44. No comparison group. [pmid: 19459761].
McCall T, Bron M, Liu J, Manthena S, Spanheimer R. High-density lipoprotein cholesterol effects of pioglitazone compared with non-TZD oral medications in a US managed care cohort. Diabetologia: Diabetologia. 2009;52(S1):S495. No original data.
McCluskey D, Touger MS, Melis R, Schleusener DS, McCluskey D. Results of a randomized, double-blind, placebo-controlled study administering glimepiride to patients with type 2 diabetes mellitus inadequately controlled with rosiglitazone monotherapy. Clin Ther. 2004;26(11):1783-90. Does not have a drug comparison of interest. [pmid: 15639690].
McEwen J, Durnin CJ, Moreland TA, Qureshi MZ, Kai PL, McEwan SR. Improved glucose control with pre-prandial glipizide: Differences between patients and healthy volunteers. Eur J Pharmacol. 1990;183(3):1017. Less than 40 subjects with type 2 diabetes.
McNally PG, et al. Using continuous glucose monitoring to measure the frequency of low glucose values when using biphasic insulin aspart 30 compared with biphasic human insulin 30: a double-blind crossover study in individuals with type 2 diabetes. Diabetes Care. 2007;30(5):1044-8. Does not have a drug comparison of interest. [pmid: 17277042].
Medina Santillan R, Reyes-Garcia G, Mateos-Garcia E. Metformin plus glyburide combination as therapy in failure to monotherapy in type 2 diabetic patients: one month follow-up. Proc West Pharmacol Soc. 2002;45:139-40. No comparison group. [pmid: 12434559].
Medina Santillan R, Reyes-Garcia G, Mateos-Garcia E. Metformin plus glyburide combination as initial therapy in type 2 diabetes: one month follow-up. Proc West Pharmacol Soc. 2002;45:137-8. Study duration less than 3 months. [pmid: 12434558].
Meier C, Kraenzlin ME, Bodmer M, Jick SS, Jick H, Meier CR. Use of thiazolidinediones and fracture risk. Arch Intern Med. 2008;168(8):820-5. Does not have a drug comparison of interest. [pmid: 18443256].
Meier JJ, Deifuss S, Klamann A, Schmiegel W, Nauck MA. Influence of an antidiabetic treatment with sulfonylurea drugs on long-term survival after acute myocardial infarction in patients with type 2 diabetes. The LAngendreer Myocardial infarction and Blood glucose in Diabetic patients Assessment (LAMBDA). Exp Clin Endocrinol Diabetes. 2003;111(6):344-50. Does not have a drug comparison of interest. [pmid: 14520601].
Meigs JB, Singer DE, Sullivan LM, et al. Metabolic control and prevalent cardiovascular disease in non-insulin-dependent diabetes mellitus (NIDDM): The NIDDM Patient Outcome Research Team. Am J Med. 1997;102(1):38-47. Does not apply. [pmid: 9209199].
Mellbin LG, Malmberg K, Norhammar A, Wedel H, Ryden L. The impact of glucose lowering treatment on long-term prognosis in patients with type 2 diabetes and myocardial infarction: a report from the DIGAMI 2 trial. Eur Heart J. 2008;29(2):166-76. Does not have a drug comparison of interest. [pmid: 18156614].
Memisogullari R, Turkeli M, Bakan E, Akcay F. Effect of metformin or gliclazide on lipid peroxidation and antioxidant levels in patients with diabetes mellitus. Turk J Med Sci. 2008;38(6):545-8. Does not meet the study design criteria.
Menard J, Payette H, Baillargeon JP, et al. Efficacy of intensive multitherapy for patients with type 2 diabetes mellitus: a randomized controlled trial. CMAJ. 2005;173(12):1457-66. Does not apply. [pmid: 16293781].
Meneghini L, et al. The usage of a simplified self-titration dosing guideline (303 Algorithm) for insulin detemir in patients with type 2 diabetes--results of the randomized, controlled PREDICTIVE 303 study. Diabetes, Obesity & Metabolism. 2007;9(6):902-13. Does not apply.
Meneghini LF, Traylor L, Schwartz S. Improved Glycemic Control with Insulin Glargine Vs Pioglitazone as ADD-ON Therapy to Sulfonylurea or Metformin in Patients with Uncontrolled Type 2 Diabetes. Endocr Pract. 2010:1-6. Does not have a drug comparison of interest.
Mercker SK, Maier C, Neumann G, Wulf H. Lactic acidosis as a serious perioperative complication of antidiabetic biguanide medication with metformin. Anesthesiology. 1997;87(4):1003-5. No comparison group. [pmid: 9357911].
Mertes G. Safety and efficacy of acarbose in the treatment of Type 2 diabetes: data from a 5-year surveillance study. Diabetes Res Clin Pract. 2001;52(3):193-204. Does not have a drug comparison of interest. [pmid: 11323089].
Metformin less effective than sensible diet. J. Endocrinol. Metab. Diabetes S. Afr. 2001;6(3):82. No original data.
Mewborne JD, Ricci PE, Appel RG. Cranial CT findings in metformin (Glucophage)-induced lactic acidosis. J Comput Assist Tomogr. 1998;22(4):528-9. No comparison group. [pmid: 9676440].
Meymeh RH, Wooltorton E. Diabetes drug pioglitazone (Actos): risk of fracture. CMAJ. 2007;177(7):723-4. No original data. [pmid: 17823139].
Migdalis IN, Iliopoulou V, Kalogeropoulou K, Koutoulidis K, Samartzis M. Correlation between high density lipoprotein cholesterol and C-peptide in sulfonylurea-treated diabetic patients. J Med. 1989;20(5-6):349-55. Does not have a drug comparison of interest. [pmid: 2628517].
Mikhail N, Wali S. Insulin combination therapy in type 2 diabetes mellitus. Ann Intern Med. 2004;140(8):666-7. author reply 667. No original data. [pmid: 15096347].
Milenkovic T, Percan V, Vesov G. 20-week multicentre, prospective, open-label study of the efficacy, safety and applicability of repaglinide as a first line therapy in treating type 2 diabetes patients in Diabetes Centres in Macedonia. Endocrinologia. 2005;10:28-34. No comparison group.
Miyazaki Y, DeFronzo RA. Rosiglitazone and pioglitazone similarly improve insulin sensitivity and secretion, glucose tolerance and adipocytokines in type 2 diabetic patients. Diabetes Obes Metab. 2008;10(12):1204-11. Does not have a drug comparison of interest. [pmid: 18476983].
Mohan V, Yang W, Son HY, et al. Efficacy and safety of sitagliptin in the treatment of patients with type 2 diabetes in China, India, and Korea. Diabetes Res Clin Pract. 2009;83(1):106-16. Does not have a drug comparison of interest. [pmid: 19097665].
Monami M, Lamanna C, Balzi D, Marchionni N, Mannucci E. Sulphonylureas and cancer: a case-control study. Acta Diabetol. 2008. Does not have a drug comparison of interest.
Monami M, Lamanna C, Pala L, et al. Treatment with insulin secretagogues and cancer-related mortality in type 2 diabetic patients a retrospective cohort study. Exp Clin Endocrinol Diabetes. 2008;116(3):184-9. Does not have a drug comparison of interest. [pmid: 18273755].
Monami M, Luzzi C, Lamanna C, et al. Three-year mortality in diabetic patients treated with different combinations of insulin secretagogues and metformin. Diabetes Metab Res Rev. 2006;22(6):477-82. Other reason. [pmid: 16634115].
Monnier L, Grimaldi A, Charbonnel B, et al. Management of French patients with type 2 diabetes mellitus in medical general practice: Report of the Mediab observatory. Diabetes Metab. 2004;30(1):35-42. Does not apply. [pmid: 15029096].
Montanana CF, Herrero CH, Fernandez MR. Less weight gain and hypoglycaemia with once-daily insulin detemir than NPH insulin in intensification of insulin therapy in overweight Type 2 diabetes patients - The PREDICTIVE(trademark) BMI clinical trial. Diabetic Med. 2008;25(8):916-23. Does not have a drug comparison of interest. [pmid: 18959604].
Moon JH, Kim HJ, Kim SK, et al. Fat redistribution preferentially reflects the anti-inflammatory benefits of pioglitazone treatment. Metabolism. 2010. Does not apply.
Moran EG, Salzman A, Yan Y, Patwardhan R. Rosiglitazone. BRL 49653. A 26-week Randomized, Double-blind, Double-Dummy, Multicentered Study toEvaluate the Efficacy, Safety and Tolerability of Rosiglitazone WhenAdministered to Patients with Non-Insulin Dependent Diabetes Mellitus (NIDDM) Who Are Inadequately Controlled on a Maximal Dose (20-mg/day) of Glyburide. Report 079 Phase IIIA. Final Clinical Report. SB Document Number: BRL-049653/RSD-100SLN/2. 23-9-1998. SmithKline Beecham. Other reason.
Moses R. Repaglinide in combination therapy with metformin in Type 2 diabetes. Exp Clin Endocrinol Diabetes. 1999;107(Suppl 4):S136-9. Other reason. [pmid: 10522839].
Moses RG, Gomis R, Frandsen KB, Schlienger JL, Dedov I. Flexible meal-related dosing with repaglinide facilitates glycemic control in therapy-naive type 2 diabetes. Diabetes Care. 2001;24(1):11-5. Does not have a drug comparison of interest. [pmid: 11194214].
Mozersky RP, Patel H, Bahl VK, Bahl S, Mook W. Efficacy of combination therapy with insulin and oral hypoglycemic agents in patients with type II diabetes during a 1-year period. J Am Osteopath Assoc. 1996;96(6):346-51. Does not meet the study design criteria. [pmid: 8690621].
Mukhtar R, Reckless JP. Dyslipidaemia in type 2 diabetes: effects of the thiazolidinediones pioglitazone and rosiglitazone. Diabet Med. 2005;22(Suppl 3):6-10. No original data. [pmid: 15960775].
Naderi N, May HT, Horne BD, et al. Association of rosiglitazone and pioglitazone to death and myocardial infarction among diabetic patients with coronary artery disease. Journal of the American College of Cardiology: J. Am. Coll. Cardiol. 2009;53(10):A377. No original data.
Nagasaka S, Taniguchi A, Aiso Y, et al. Effect of glimepiride on serum adiponectin level in subjects with type 2 diabetes. Diabetes Care. 2003;26(7):2215-6. Less than 40 subjects with type 2 diabetes. [pmid: 12832345].
Nakamura T, et al. Effect of pioglitazone on dyslipidemia in hemodialysis patients with type 2 diabetes. Ren Fail. 2001;23(6):863-4. Less than 40 subjects with type 2 diabetes. [pmid: 11777327].
Nakano K, Hasegawa G, Fukui M, et al. Effect of pioglitazone on various parameters of insulin resistance including lipoprotein subclass according to particle size by a gel-permeation high-performance liquid chromatography in newly diagnosed patients with type 2 diabetes. Endocr J. 2010. Does not have a drug comparison of interest.
Narain VS, Puri A, Ahuja A. 10 Years of clinical trials in diabetic patient with coronary artery disease. J Intern Med India. 2006;9(1):20-6. No original data.
Narce M, Poisson JP. Novel PPAR(gamma)-dependent and independent effects for thiazolidinediones. Curr Opin Lipidology. 2003;14(6):651-2. No original data.
Nateglinide improves postprandial glucose as monotherapy or in combination with metformin. Geriatrics. 2002;57(8):35. No original data.
Nauck M, Duran S, Kim D, Johns D, Festa A, Trautman M. Effects of exenatide compared with twice-daily biphasic insulin aspart in patients with type 2 diabetes using metformin and a sulphonylurea. Diabetologia. 2006;49(Suppl 1(3)):Abstract 0001. Other reason.
Nauck M, Marre M. Adding liraglutide to oral antidiabetic drug monotherapy: efficacy and weight benefits. Postgrad Med. 2009;121(3):5-15. Other reason. [pmid: 19491535].
Nauck MA, Ellis GC, Fleck PR, Wilson CA, Mekki Q. Efficacy and safety of adding the dipeptidyl peptidase-4 inhibitor alogliptin to metformin therapy in patients with type 2 diabetes inadequately controlled with metformin monotherapy: a multicentre, randomised, double-blind, placebo-controlled study. Int J Clin Pract. 2009;63(1):46-55. Does not have a drug comparison of interest. [pmid: 19125992].
Nauck MA, Hompesch M, Filipczak R, Le TD, Zdravkovic M, Gumprecht J. Five weeks of treatment with the GLP-1 analogue liraglutide improves glycaemic control and lowers body weight in subjects with type 2 diabetes. Exp Clin Endocrinol Diabetes. 2006;114(8):417-23. Study duration less than 3 months. [pmid: 17039422].
Neeser K, Lubben G, Siebert U, Schramm W. Cost effectiveness of combination therapy with pioglitazone for type 2 diabetes mellitus from a german statutory healthcare perspective. Pharmacoeconomics. 2004;22(5):321-41. No original data. [pmid: 15061682].
Negro R, Dazzi D, Hassan H, Pezzarossa A. Pioglitazone reduces blood pressure in non-dipping diabetic patients. Minerva Endocrinol. 2004;29(1):11-7. Study duration less than 3 months. [pmid: 15258553].
Nelson P, Poon T, Guan X, Schnabel C, Wintle M, Fineman M. The incretin mimetic exenatide as a monotherapy in patients with type 2 diabetes. Diabetes Technol Ther. 2007;9(4):317-26. No comparison group. [pmid: 17705687].
Ng JM, Ramlall M, Mellor D, Allan BJ. Severe hypoglycaemia: Are patients correctly selected for sulphonylurea therapy?. Diabetologia: Diabetologia. 2009;52(S1):S353. No original data.
Nichols GA, Alexander CM, Girman CJ, Kamal-Bahl SJ, Brown JB. Treatment escalation and rise in HbA1c following successful initial metformin therapy. Diabetes Care. 2006;29(3):504-9. Does not apply. [pmid: 16505496].
Nichols GA, Glauber HS, Javor K, Brown JB. Achieving further glycemic control in type 2 diabetes mellitus. West J Med. 2000;173(3):175-9. Does not have a drug comparison of interest. [pmid: 10986179].
Nichols GA, Gomez-Caminero A. Weight changes following the initiation of new anti-hyperglycaemic therapies. Diabetes Obes Metab. 2007;9(1):96-102. Other reason. [pmid: 17199724].
Nishio K, Sakurai M, Kusuyama T, et al. A randomized comparison of pioglitazone to inhibit restenosis after coronary stenting in patients with type 2 diabetes. Diabetes Care. 2006;29(1):101-6. Does not have a drug comparison of interest. [pmid: 16373904].
Nissen SE, Nicholls SJ, Wolski K, et al. Comparison of pioglitazone vs glimepiride on progression of coronary atherosclerosis in patients with type 2 diabetes: the PERISCOPE randomized controlled trial. JAMA. 2008;299(13):1561-73. Does not have a drug comparison of interest. [pmid: 18378631].
Noh J-H, Kim S-K, Cho Y-J, et al. Current status of diabetes management in elderly Koreans with diabetes. Diabetes Res Clin Pract. 2007;77:S71-75. Does not apply. [pmid: 17481770].
Nonaka K, Kakikawa T, Sato A, et al. Efficacy and safety of sitagliptin monotherapy in Japanese patients with type 2 diabetes. Diabetes Res Clin Pract. 2008;79(2):291-8. Does not have a drug comparison of interest. [pmid: 17933414].
Nonaka K, Kakikawa T, Sato A. Twelve-week efficacy and tolerability of sitagliptin, a dipleptidyl peptidase-IV (DPP4) inhibitor, in Japanese patients with T2DM. Diabetes. 2006;55(Suppl 1):A128. Other reason.
Noury J, Nandeuil A. Comparative three-month study of the efficacies of metformin and gliclazide in the treatment of NIDD. Diabete Metab. 1991;17:209-12. Does not have a drug comparison of interest. [pmid: 1936478].
Novials A, Gomis R, Coves MJ, Conget I, Malaisse WJ. Improvement by insulin treatment of the early phase of glucose-stimulated insulin release in non-insulindependent diabetics explored after restoration of hyperglycemia. Med Sci Res. 1989;17(8):381-2. Less than 40 subjects with type 2 diabetes.
Noyon R, Pagano Mirani-Oostdijk C, van Gent CM, Frolich M, Hillebrand I, Terpstra J. Long-term effect of acarbose on diurnal serum triglyceride, glucose, insulin and adipose tissue lipoprotein lipase levels in patients with primary endogenous hypertriglyceridaemia, with or without type II diabetes. Neth J Med. 1986;29(5):157-64. Less than 40 subjects with type 2 diabetes. [pmid: 3520362].
Odom J, Williamson B, Carter L. Rosiglitazone and pioglitazone in the treatment of diabetes mellitus. Am J Health Syst Pharm. 2008;65(19):1846-50. No original data. [pmid: 18796427].
Okura H, Takagi T, Toda I. Pioglitazone affects left ventricular filling pressure in patients with ischemic heart disease and type 2 diabetes who underwent coronary intervention: An echo doppler sub-analysis from the prevention of in-stent neointimal proliferation by pioglitazone study (POPPS). J Am Coll Cardiol. 2010;55(10):A16.E150. Does not apply.
Olansky L, Marchetti A, Lau H. Multicenter retrospective assessment of thiazolidinedione monotherapy and combination therapy in patients with type 2 diabetes: comparative subgroup analyses of glycemic control and blood lipid levels. Clin Ther. 2003;25(Suppl B):B64-80. Does not meet the study design criteria. [pmid: 14553867].
Olansky L, Reasner CA, Seck T, et al. A strategy implementing initial therapy with a fixed-dose combination tablet of sitagliptin and metformin in patients with type 2 diabetes provides superior glycaemic control compared with a strategy using initial metformin monotherapy over 44 weeks. Can J Diabetes. 2009;33(3):208-9. Other reason.
Olsson J, Lindberg G, Gottsater M, et al. Increased mortality in Type II diabetic patients using sulphonylurea and metformin in combination: a population-based observational study. Diabetologia. 2000;43(5):558-60. Does not have a drug comparison of interest. [pmid: 10855529].
O’Meara NM, Shapiro ET, Van Cauter E, Polonsky KS. Effect of glyburide on beta cell responsiveness to glucose in non-insulin-dependent diabetes mellitus. Am J Med. 1990;89:11S-6S. discussion. 51S. 53S. Does not have a drug comparison of interest. [pmid: 2117385].
Ong CR, Molyneaux LM, Constantino MI, Twigg SM, Yue DK. Long-term efficacy of metformin therapy in nonobese individuals with type 2 diabetes. Diabetes Care. 2006;29(11):2361-4. Other reason. [pmid: 17065668].
Oz Gul O, Tuncel E, Yilmaz Y, et al. Comparative effects of pioglitazone and rosiglitazone on plasma levels of soluble receptor for advanced glycation end products in type 2 diabetes mellitus patients. Metabolism. 2010;59(1):64-9. Less than 40 subjects with type 2 diabetes. [pmid: 19709689].
Ozbek M, Erdogan M, Karadeniz M, et al. Preprandial repaglinide decreases exogenous insulin requirements and HbA1c levels in type 2 diabetic patients taking intensive insulin treatment. Acta Diabetol. 2006;43(4):148-51. Does not have a drug comparison of interest. [pmid: 17211567].
Pala L, Monami M, Lamanna C, et al. Failure to metformin and insulin secretagogue monotherapy: an observational cohort study. Acta Diabetol. 2009. Does not meet the study design criteria.
Palmer AJ, Roze S, Lammert M, et al. Comparing the long-term cost-effectiveness of repaglinide plus metformin versus nateglinide plus metformin in type 2 diabetes patients with inadequate glycaemic control: an application of the CORE Diabetes Model in type 2 diabetes. Curr Med Res Opin. 2004;20(Suppl 1):S41-51. Study duration less than 3 months. [pmid: 15324515].
Pan CY, Landen H. Post-marketing surveillance of acarbose treatment in patients with type 2 diabetes mellitus and subjects with impaired glucose tolerance in China. Clin Drug Investig. 2007;27(6):397-405. No comparison group.
Panelo A, Wing JR. Repaglinide/bedtime NPH insulin is comparable to twice-daily NPH insulin. Diabetes Care. 2005;28(7):1789-90. Does not have a drug comparison of interest. [pmid: 15983336].
Panzram G. Mortality and survival in type 2 (non-insulin-dependent) diabetes mellitus. Diabetologia. 1987;30(3):123-31. No original data. [pmid: 3556287].
Papa G, Fedele V, Chiavetta A, et al. Therapeutic options for elderly diabetic subjects: open label, randomized clinical trial of insulin glargine added to oral antidiabetic drugs versus increased dosage of oral antidiabetic drugs. Acta Diabetol. 2008;45(1):53-9. Does not have a drug comparison of interest. [pmid: 18180864].
Papa G, Fedele V, Rizzo MR, et al. Safety of type 2 diabetes treatment with repaglinide compared with glibenclamide in elderly people: A randomized, open-label, two-period, crossover trial. Diabetes Care. 2006;29(8):1918-20. Other reason. [pmid: 16873803].
Park JS, Cho MH, Lee KY, et al. The effects of pioglitazone on cerebrovascular resistance in patients with type 2 diabetes mellitus. Metabolism. 2007;56(8):1081-6. Does not have a drug comparison of interest. [pmid: 17618953].
Pastromas S, Koulouris S. Thiazolidinediones: Antidiabetic drugs with cardiovascular effects. Hell J Cardiol. 2006;47(6):352-60. No original data.
Patasi B, MacNair D, Marble RJ, Conway JR. Rosiglitazone in Canada: experience in clinical practice. Expert Opin Drug Metab Toxicol. 2009;5(4):441-8. No comparison group. [pmid: 19368494].
Patel J, Anderson RJ, Rappaport EB. Rosiglitazone monotherapy improves glycaemic control in patients with type 2 diabetes: a twelve-week, randomized, placebo-controlled study. Diabetes Obes Metab. 1999;1(3):165-72. Does not have a drug comparison of interest. [pmid: 11220295].
Pawaskar MD, Anderson J, Zagar AJ. A retrospective analysis of medication use, resource utilization, and clinical effectiveness of exenatide compared to glargine in patients with type 2 diabetes. Value Health. 2009;12(7):A414. Other reason.
Perciaccante A, Mas MD, Balbi M. Relevance of diabetes mellitus and antidiabetic therapy in patients with cirrhosis and hepatocellular carcinoma. Hepatol Int. 2009;3(1):148. No original data.
Perez A, Zhao Z, Spanheimer R. Effect of pioglitazone and metformin fixed-dose combination on biomarkers of inflammation and dyslipidemia in patients with type 2 diabetes. Canadian Journal of Diabetes: Can J Diabetes. 2009;33(3):246. No original data.
Perez A, Zhao Z, Spanheimer R. Effect of pioglitazone and metformin fixed-dose combination on hs-CRP and adiponectin in patients with type 2 diabetes. Diabetologia: Diabetologia. 2009;52(S1):S339-340. No original data.
Perfetti R. Nateglinide. Drugs. 2000;60(3):616. No original data.
Perriello G, Pampanelli S, Brunetti P, di Pietro C, Mariz S. Long-term effects of pioglitazone versus gliclazide on hepatic and humoral coagulation factors in patients with type 2 diabetes. Diab Vasc Dis Res. 2007;4(3):226-30. Does not have a drug comparison of interest. [pmid: 17907113].
Peters Harmel AL, Kendall DM, Buse JB, Boyle PJ, Marchetti A, Lau H. Impact of adjunctive thiazolidinedione therapy on blood lipid levels and glycemic control in patients with type 2 diabetes. Curr Med Res Opin. 2004;20(2):215-23. Other reason. [pmid: 15006017].
Petersen KU. Complementary mode of action of rosiglitazone and metformin in a single tablet for the treatment of diabetes mellitus type 2. Arzneimittelforschung. 2004;54(1):20-30. No original data. [pmid: 14979605].
Petzholdt R, Rosak C, Stammer H. Rosiglitazone plus metformin is effective and safe in daily practise [Abstract]. Diabetes. 2004;53(9 Suppl 2):A 142. Other reason.
Pfutzner A, Lubben G, Forst T. Pioglitazone decreases carotid intima-media thickness in diabetes mellitus. Cardiol Rev. 2005;22(10):30-3. Other reason.
Pfutzner A, Schondorf T, Seidel D, et al. Impact of rosiglitazone on beta-cell function, insulin resistance, and adiponectin concentrations: results from a double-blind oral combination study with glimepiride. Metabolism. 2006;55(1):20-5. Does not have a drug comparison of interest. [pmid: 16324915].
Philis-Tsimikas A, Charpentier G, Clauson P, Ravn GM, Roberts VL, Thorsteinsson B. Comparison of once-daily insulin detemir with NPH insulin added to a regimen of oral antidiabetic drugs in poorly Controlled Type 2 Diabetes. Clin Ther. 2006;28(10):1569-81. Does not have a drug comparison of interest. [pmid: 17157113].
Phillips LS, Grunberger G, Miller E, Patwardhan R, Rappaport EB, Salzman A. Once - and twice-daily dosing with rosiglitazone improves glycemic control in patients with type 2 diabetes. Diabetes Care. 2001;24(2):308-15. Does not have a drug comparison of interest. [pmid: 11213884].
Pioglitazone ineffective in secondary prevention of macrovascular complications (PROactive). J Natl Med Assoc. 2006;98(1):102-3. No original data.
Pioglitazone of benefit in high-risk diabetes patients. Pharm J. 2005;275(7367):330. No original data.
Pioglitazone reduces stroke, MI, and death but increases HF. Geriatr Aging. 2006;9(1):48. No original data.
Pioglitazone shows anti-atherosclerotic effect in type 2 diabetes. Geriatrics. 2007;62(2):14. No original data.
Pioglitazone/glimepiride (Duetact) for diabetes. Med Lett Drugs Ther. 2007;49(1253):9-11. No original data.
Pioglitazone: Fractures in women. WHO Drug Inf. 2007;21(3):207. No original data.
Pisu E, Marena S, Arcari R, et al. Depressed insulin secretion in response to different stimuli is a feature of secondary failure in normal-weight non-insulin dependent diabetics on sulphonylureas. Diabetes Nutr Metab Clin Exp. 1996;9(1):22-8. Less than 40 subjects with type 2 diabetes.
Pogatsa G, Koltai MZ, Jermendy G, Simon J, Aranyi Z, Ballagi-Pordany G. The effect of sulphonylurea therapy on the outcome of coronary heart diseases in diabetic patients. Acta Med Hung. 1992-1993;49(1-2):39-51. Does not have a drug comparison of interest. [pmid: 1296186].
Polonsky WH, et al. Integrating medical management with diabetes self-management training: a randomized control trial of the Diabetes Outpatient Intensive Treatment program. Diabetes Care. 2003;26(11):3048-53. Does not apply. [pmid: 14578238].
Ponchner M, Taylor R, Heine R, Alberti KG. The effect of sulphonylurea therapy on in vivo insulin sensitivity in non-insulin dependent diabetics. Horm Metab Res. 1984;16(4):208. Less than 40 subjects with type 2 diabetes. [pmid: 6373546].
Pongchaidecha M, Srikusalanukul V, Chattananon A, Tanjariyaporn S. Effect of metformin on plasma homocysteine, vitamin B12 and folic acid: a cross-sectional study in patients with type 2 diabetes mellitus. J Med Assoc Thai. 2004;87(7):780-7. Does not apply. [pmid: 15521233].
Pradhan AD, Everett BM, Cook NR, Rifai N, Ridker PM. Effects of initiating insulin and metformin on glycemic control and inflammatory biomarkers among patients with type 2 diabetes: the LANCET randomized trial. JAMA. 2009;302(11):1186-94. Does not have a drug comparison of interest. [pmid: 19755697].
Prager R, Schernthaner G, Matha R. Metformin does not alter insulin receptor binding in non insulin dependent diabetes mellitus. ACTA Endocrinol Suppl. 1983;102(253):76-7. Less than 40 subjects with type 2 diabetes.
Prando R, Buzzo P, Cheli V, Melga PL, Accoto S, Rebaudo S. A short period of insulin therapy can restore the sensitivity to hypoglycaemic agents in poorly controlled type 2 diabetes. Med Sci Res. 1988;16(23):1245. No original data.
Qu S, et al. The efficacy of glipizide XL in the treatment of type 2 diabetic patients unresponding to sulfaurea drugs. Pharmaceutical Care & Research (Yaoxue Fuwu Yu Yanjiu). 2005;5(1):32-4. Not written in English.
Rachmani R, Slavachevski I, Levi Z, Zadok B, Kedar Y, Ravid M. Metformin in patients with type 2 diabetes mellitus: reconsideration of traditional contraindications. Eur J Intern Med. 2002;13(7):428. Does not apply. [pmid: 12384131].
Rajagopalan R, Perez A, Ye Z, Khan M, Murray FT. Pioglitazone is effective therapy for elderly patients with type 2 diabetes mellitus. Drugs Aging. 2004;21(4):259-71. Does not have a drug comparison of interest. [pmid: 15012171].
Rajagopalan R, Xu Y, Abbadessa M. The effect of pioglitazone on glycemic and lipid parameters and adverse events in elderly patients with type 2 diabetes mellitus: a post hoc analysis of four randomized trials. Am J Geriatr Pharmacother. 2006;4(2):123-33. No original data. [pmid: 16860259].
Rajeswaran C, Scott EM. Thiazolidinedione induced gross scrotal oedema?. Pract. Diabetes Int. 2006;23(7):286. No comparison group.
Ramachandran A, Mohan V, Snehalatha MC, Chinnikrishnudu M, Viswanathan M. Use of metformin in selected cases of NIDDM. A clinical trial. J Diabetic Assoc India. 1988;28(4):137-9. No comparison group.
Ramos-Nino ME, MacLean CD, Littenberg B. Association between cancer prevalence and use of thiazolidinediones: results from the Vermont Diabetes Information System. BMC Med. 2007;5:17. Does not apply. [pmid: 17584937].
Raptis AE, Tountas N, Yalouris AG, et al. Comparative study of the therapeutic effects of glibenclamide or the fixed combination of glibenclamide-phenformin with those of gliclazide or chlorpropamide. Acta Diabetol Lat. 1990;27(1):11-22. Does not have a drug comparison of interest. [pmid: 2110711].
Raskin P, Lewin A, Reinhardt R, Lyness W. Twice-daily and three-times-daily dosing of a repaglinide/metformin fixed-dose combination tablet provide similar glycaemic control. Diabetes Obes Metab. 2009;11(10):947-52. Does not apply. [pmid: 19531054].
Ratner RE, Maggs D, Nielsen LL, et al. Long-term effects of exenatide therapy over 82 weeks on glycaemic control and weight in over-weight metformin-treated patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2006;8(4):419-28. Does not have a drug comparison of interest. [pmid: 16776749].
Ravichandran S, DeFronzo R, Garber AJ, et al. Once-daily saxagliptin added to metformin is well tolerated and provides sustained glycaemic control over 102 weeks in patients with type 2 diabetes. Diabetologia: Diabetologia. 2009;52(S1):S60. Other reason.
Raz I, Gilhar D, Hoffman A. Prolonged response to glibenclamide in NIDDM patients in a normoglycemic state. Isr J Med Sci. 1994;30(10):775-8. Less than 40 subjects with type 2 diabetes. [pmid: 7960692].
Reasner CA, Olansky L, Seck T, et al. Initial therapy with the Fixed-Dose Combination (FDC) of sitagliptin and metformin (JANUMET(trademark)) in patients with type 2 diabetes mellitus provides superior glycaemic control and HbA1c goal attainment with lower rates of abdominal pain and diarrhea vs metformin alone. Diabetologia: Diabetologia. 2009;52(S1):S295. Other reason.
Reblin T. Thiazolidinedione use and the risk of fractures. CMAJ. 2009;180(8):841. No original data. [pmid: 19364797].
Repaglinide improves blood glucose control in patients with type 2 diabetes. Formulary. 2004;39(11):528. No original data.
Retnakaran R, Zinman B. Thiazolidinediones and clinical outcomes in type 2 diabetes. Lancet. 2009. Study duration less than 3 months.
Ribowsky J, Covino J. Do thiazolidinediones increase the risk of cardiovascular events. JAAPA. 2008;21(8):53-4. No original data. [pmid: 18795550].
Riddle MC, Henry RR, Poon TH, et al. Exenatide elicits sustained glycaemic control and progressive reduction of body weight in patients with type 2 diabetes inadequately controlled by sulphonylureas with or without metformin. Diabetes Metab Res Rev. 2006;22(6):483-91. No original data. [pmid: 16634116].
Riddle MC. Combined insulin and sulfonylurea therapy for type 2 diabetes mellitus. Diabetes Res Clin Pract. 1991;11(1):3-8. No original data. [pmid: 2019232].
Riddle MC. The Treat-to-Target trial and related studies. Endocr Pract. 2006;12:71-9. No original data. [pmid: 16627386].
Riedel AA, Heien H, Wogen J, Plauschinat CA. Loss of glycemic control in patients with type 2 diabetes mellitus who were receiving initial metformin, sulfonylurea, or thiazolidinedione monotherapy. Pharmacotherapy. 2007;27(8):1102-10. Does not meet the study design criteria. [pmid: 17655510].
Riedel AA, Heien H, Wogen J, Plauschinat CA. Secondary failure of glycemic control for patients adding thiazolidinedione or sulfonylurea therapy to a metformin regimen. Am J Manag Care. 2007;13(8):457-63. Does not meet the study design criteria. [pmid: 17685826].
Rijzewijk LJ, Van Der Meer RW, Lubberink M, et al. Differential action of pioglitazone and metformin on hepatic fat, substrate metabolism and perfusion in type 2 diabetic patients. Diabetologia: Diabetologia. 2009;52(S1):S336. No original data.
Ristic S, Collober-Maugeais C, Cressier F, Tang P, Pecher E. Nateglinide or gliclazide in combination with metformin for treatment of patients with type 2 diabetes mellitus inadequately controlled on maximum doses of metformin alone: 1-year trial results. Diabetes Obes Metab. 2007;9(4):506-11. Does not have a drug comparison of interest. [pmid: 17587393].
Ristic S, Collober-Maugeais C, Pecher E, Cressier F. Comparison of nateglinide and gliclazide in combination with metformin, for treatment of patients with Type 2 diabetes mellitus inadequately controlled on maximum doses of metformin alone. Diabet Med. 2006;23(7):757-62. Does not have a drug comparison of interest. [pmid: 16842480].
Robb GH, Lowe SM. Lack of weight gain with gliclazide treatment for 30 months in Type II diabetes. CURR MED RES OPIN. 1984;9(1):7-9. No comparison group. [pmid: 6723350].
Roden M, Laakso M, Johns D, et al. Long-term effects of pioglitazone and metformin on insulin sensitivity in patients with Type 2 diabetes mellitus. Diabet Med. 2005;22(8):1101-6. Does not apply. [pmid: 16026380].
Roden M, Mariz S, Brazzale AR, Pacini G. Free fatty acid kinetics during long-term treatment with pioglitazone added to sulfonylurea or metformin in Type 2 diabetes. J Intern Med. 2009;265(4):476-87. Other reason. [pmid: 19298459].
Rogowicz A, Litwinowicz M, Pilacinski S, Zozulinska D, Wierusz-Wysocka B. Does early insulin treatment decrease the risk of microangiopathy in non-obese adults with diabetes. Arch Med Sci. 2007;3(2):129-35. Does not have a drug comparison of interest.
Rosenbaum P, Peres RB, Zanella MT, Ferreira SR. Improved glycemic control by acarbose therapy in hypertensive diabetic patients: effects on blood pressure and hormonal parameters. Braz J Med Biol Res. 2002;35(8):877-84. Does not have a drug comparison of interest. [pmid: 12185379].
Rosenblatt J. Combination sulfonylurea-insulin therapy in the treatment of noninsulin-dependent diabetes mellitus. Conn Med. 1991;55(11):634-6. No original data. [pmid: 1790695].
Rosenblatt S, Miskin B, Glazer NB, Prince MJ, Robertson KE. The impact of pioglitazone on glycemic control and atherogenic dyslipidemia in patients with type 2 diabetes mellitus. Coron Artery Dis. 2001;12(5):413-23. Does not have a drug comparison of interest. [pmid: 11491207].
Rosenstock J, Corrao PJ, Goldberg RB, Kilo C. Diabetes control in the elderly: a randomized, comparative study of glyburide versus glipizide in non-insulin-dependent diabetes mellitus. Clin Ther. 1993;15(6):1031-40. Does not have a drug comparison of interest. [pmid: 8111800].
Rosenstock J, Davies M, Home PD, Larsen J, Koenen C, Schernthaner G. A randomised, 52-week, treat-to-target trial comparing insulin detemir with insulin glargine when administered as add-on to glucose-lowering drugs in insulin-naive people with type 2 diabetes. Diabetologia. 2008;51(3):408-16. Does not have a drug comparison of interest. [pmid: 18204830].
Rosenstock J, Einhorn D, Hershon K, Glazer NB, Yu S. Efficacy and safety of pioglitazone in type 2 diabetes: a randomised, placebo-controlled study in patients receiving stable insulin therapy. Int J Clin Pract. 2002;56(4):251-7. Does not have a drug comparison of interest. [pmid: 12074206].
Rosenstock J, Goldstein BJ, Vinik AI, et al. Effect of early addition of rosiglitazone to sulphonylurea therapy in older type 2 diabetes patients (>60 years): the Rosiglitazone Early vs. SULphonylurea Titration (RESULT) study. Diabetes Obes Metab. 2006;8(1):49-57. Does not have a drug comparison of interest. [pmid: 16367882].
Rosenstock J, Hassman DR, Madder RD, et al. Repaglinide versus nateglinide monotherapy: a randomized, multicenter study. Diabetes Care. 2004;27(6):1265-70. Does not have a drug comparison of interest. [pmid: 15161773].
Rosenstock J, Meisel A, Raskin P. Conversion from low-dose insulin therapy to glipizide in patients with non-insulin-dependent diabetes mellitus. Am J Med. 1987;83:10-5. No comparison group. [pmid: 3307402].
Rosenstock J, Samols E, Muchmore DB, Schneider J. Glimepiride, a new once-daily sulfonylurea. A double-blind placebo-controlled study of NIDDM patients. Glimepiride Study Group. Diabetes Care. 1996;19(11):1194-9. Does not have a drug comparison of interest. [pmid: 8908379].
Rosskamp R. Safety and efficacy of insulin glargine (HOE 901) versus NPH insulin in combination with oral treatment in Type 2 diabetic patients. Diabetic Med. 2003;20(7):545-51. Does not have a drug comparison of interest. [pmid: 12823235].
Roy R, Navar M, Palomeno G, Davidson MB. Real world effectiveness of rosiglitazone added to maximal (tolerated) doses of metformin and a sulfonylurea agent: a systematic evaluation of triple oral therapy in a minority population. Diabetes Care. 2004;27(7):1741-2. Does not apply. [pmid: 15220256].
Russell-Jones D, Vaag A, Schmitz O, Sethi B, Lalic NM, Antic S, et al. Significantly better glycaemic control/weight reduction with human GLP-1 analogue liraglutide, than with insulin glargine: all as add-on to metformin + sulphonylurea in Type 2 diabetes. Diabetologia. 2008;51:S68. No original data.
Russell-Jones D, Vaag A, Schmitz O, Sethi BK, Lalic N, Antic S, et al. Significantly better glycemic control and weight reduction with liraglutide, a once-daily human GLP-1 analog, compared with insulin glargine: all as add-on to metformin and a sulphonylurea in Type 2 diabetes. Diabetes. 2008;57:P536. No original data.
Russell-Jones D, Vaag A, Schmitz O, et al. Significantly better glycaemic control and weight reduction with liraglutide, a once-daily human GLP-1 analogue, compared with insulin glargine: all as add-on to metformin and a sulfonylurea in type 2 diabetes. Diabetes. 2008;57(Suppl 1):A159. No original data.
Ryan EH Jr, Han DP, Ramsay RC, et al. Diabetic macular edema associated with glitazone use. Retina. 2006;26(5):562-70. No comparison group. [pmid: 16770264].
Saad MF, Greco S, Osei K, et al. Ragaglitazar improves glycemic control and lipid profile in type 2 diabetic subjects: a 12-week, double-blind, placebo-controlled dose-ranging study with an open pioglitazone arm. Diabetes Care. 2004;27(6):1324-9. Does not have a drug comparison of interest. [pmid: 15161783].
Sadikot SM, Mogensen CE. Risk of coronary artery disease associated with initial sulphonylurea treatment of patients with type 2 diabetes: a matched case-control study. Diabetes Res Clin Pract. 2008;82(3):391-5. Does not have a drug comparison of interest. [pmid: 18945509].
Nobuo SAKAMOTO, et al. Usefulness of Prolonged Administration of BAY g 5421 (Acarbose) in Patients with Non-Insulin-Dependent Diabetes Mellitus: A Double-Blind Placebo-Controlled Study. Rinsho to Kenkyu (The Japanese Journal of Clinical and Experimental Medicine). 1990;67(1):219-33. Not written in English.
Saloranta C, Hershon K, Ball M, Dickinson S, Holmes D. Efficacy and safety of nateglinide in type 2 diabetic patients with modest fasting hyperglycemia. J Clin Endocrinol Metab. 2002;87(9):4171-6. Does not have a drug comparison of interest. [pmid: 12213867].
Salpeter S, Greyber E, Pasternak G, Salpeter E. Risk of fatal and nonfatal lactic acidosis with metformin use in type 2 diabetes mellitus. Cochrane Database Syst Rev. 2006;(1):CD002967. No original data. [pmid: 16437448].
Salsali A, Pratley RE. Does addition of sitagliptin to metformin monotherapy improve glycemic control in patients with type 2 diabetes mellitus. Nat Clin Pract Endocrinol Metab. 2007;3(6):450-1. No original data. [pmid: 17457306].
Sari R, Balci MK, Akbas SH, Avci B. The effects of diet, sulfonylurea, and Repaglinide therapy on clinical and metabolic parameters in type 2 diabetic patients during Ramadan. Endocr Res. 2004;30(2):169-77. Study duration less than 3 months. [pmid: 15473127].
Satoh N, Ogawa Y, Usui T, et al. Antiatherogenic effect of pioglitazone in type 2 diabetic patients irrespective of the responsiveness to its antidiabetic effect. Diabetes Care. 2003;26(9):2493-9. Does not have a drug comparison of interest. [pmid: 12941708].
Savage S, et al. Increased complications in noninsulin-dependent diabetic patients treated with insulin versus oral hypoglycemic agents: a population study. Proc Assoc Am Physicians. 1997;109(2):181-9. Does not apply. [pmid: 9069587].
Scemons D. Are you up-to-date on diabetes medications?. Nursing (Lond). 2007;37(7):45-9. quiz. 49. 50. Does not meet the study design criteria.
Schade DS, Jovanovic L, Schneider J. A placebo-controlled, randomized study of glimepiride in patients with type 2 diabetes mellitus for whom diet therapy is unsuccessful. J Clin Pharmacol. 1998;38(7):636-41. Does not have a drug comparison of interest. [pmid: 9702849].
Schatz H, Schoppel K, Lehwalder D, Schandry R. Efficacy, tolerability and safety of nateglinide in combination with metformin. Results from a study under general practice conditions. Exp Clin Endocrinol Diabetes. 2003;111(5):262-6. No comparison group. [pmid: 12951631].
Scheen A, et al. Reduced insulin requirements and improved glycaemic control with pioglitazone in insulin-treated patients with type 2 diabetes: Results from PROactive. 19th World Diabetes Conference 2006. 2006. Other reason.
Scheen AJ, Tan MH, Betteridge DJ, Birkeland K, Schmitz O, Charbonnel B. Long-term glycaemic effects of pioglitazone compared with placebo as add-on treatment to metformin or sulphonylurea monotherapy in PROactive (PROactive 18). Diabet Med. 2009;26(12):1242-9. Does not have a drug comparison of interest. [pmid: 20002476].
Scherbaum WA, Goke B. Metabolic efficacy and safety of once-daily pioglitazone monotherapy in patients with type 2 diabetes: a double-blind, placebo-controlled study. Horm Metab Res. 2002;34(10):589-95. Does not have a drug comparison of interest. [pmid: 12439788].
Schernthaner G, Grimaldi A, Di Mario U, et al. GUIDE study: double-blind comparison of once-daily gliclazide MR and glimepiride in type 2 diabetic patients. Eur J Clin Invest. 2004;34(8):535-42. Does not have a drug comparison of interest. [pmid: 15305887].
Schmidt WE, Christiansen JS, Hammer M, Zychma MJ, Buse J. Patient reported outcomes are superior in patients with type 2 diabetes treated with liraglutide as compared to exenatide,when added to metformin,sulfonylurea or both. Value in Health: Value Health. 2009;12(3):A105. Other reason.
Schmitz O, et al. Pioglitazone reduces insulin requirements and improves glycaemic control in insulin-treated patients with type 2 diabetes: results from PROactive. 42nd Annual Meeting of the European Association for the Study of Diabetes 2006. 2006. Other reason.
Schofl C, Lubben G. Postmarketing surveillance study of the efficacy and tolerability of pioglitazone in insulin-resistant patients with type 2 diabetes mellitus in general practice. Clin Drug Investig. 2003;23(11):725-34. Does not have a drug comparison of interest.
Schofl C, Luebben G. Pioglitazone Improves Diabetic Dyslipidaemia in Patients with Type 2 Diabetes Mellitus with or without Lipid-Lowering Therapy. Clin Drug Investig. 2005;25(5):341-5. Does not meet the study design criteria.
Scholz GH, Schneider K, Knirsch W, Becker G. Efficacy and tolerability of glimepiride in daily practice: A non-interventional observational cohort study. Clin Drug Invest. 2001;21(9):597-604. Study duration less than 3 months.
Schondorf T, Forst T, Seidel D. Impact of rosiglitazone on metabolic control of B-cell function and insulin resistance-results from a double-blind oral combination study. Diabetes. 2005;54(Suppl 1):A150. Other reason.
Schwartz AV, Sellmeyer DE, Vittinghoff E, et al. Thiazolidinedione use and bone loss in older diabetic adults. J Clin Endocrinol Metab. 2006;91(9):3349-54. Does not apply. [pmid: 16608888].
Schwartz AV, Vittinghoff E, Sellmeyer DE, et al. Diabetes-related complications, glycemic control, and falls in older adults. Diabetes Care. 2008;31(3):391-6. Does not apply. [pmid: 18056893].
Scorpiglione N, Belfiglio M, Carinci F, et al. The effectiveness, safety and epidemiology of the use of acarbose in the treatment of patients with type II diabetes mellitus. A model of medicine-based evidence. Eur J Clin Pharmacol. 1999;55(4):239-49. Does not have a drug comparison of interest. [pmid: 10424314].
Seino Y, Rasmussen MF, Katayama Y, Kaku K. The human GLP-1 analogue liraglutide given once daily provides excellent metabolic control in Japanese patients either as monotherapy or in combination with SU during 52 weeks of treatment. Diabetologia. 2009;52(S1):S292. No original data.
Selby JV, Ettinger B, Swain BE, Brown JB. First 20 months’ experience with use of metformin for type 2 diabetes in a large health maintenance organization. Diabetes Care. 1999;22(1):38-44. Does not have a drug comparison of interest. [pmid: 10333901].
Seshiah V, Harinarayana CV, Venkataraman S, et al. Platelet aggregation study in diabetes mellitus; effect of antidiabetic therapy - A preliminary study. J Diabetic Assoc India. 1990;30(3):62-5. Does not apply.
Sevinc A. Should diabetic patients treated long-term with sulfonylureas be switched to nateglinide?. Arch. Intern. Med. 2003;163(14):1741. No comparison group. [pmid: 12885691].
Shah M, Kolandaivelu A, Fearon WF. Pioglitazone-induced heart failure despite normal left ventricular function. Am J Med. 2004;117(12):973-4. No comparison group. [pmid: 15629744].
Shah R. Pioglitazone vs glimepiride in the PERISCOPE trial. JAMA. 2008;300(7):787-8. author reply 788. No original data. [pmid: 18714054].
Shargorodsky M, Michaelova K, Boaz M, Gavish D, Zimlichman R. Effect of long-term treatment with rosiglitazone on arterial elasticity and metabolic parameters in patients with Type 2 diabetes mellitus: a 2-year follow-up study. Diabet Med. 2007;24(11):1254-60. Does not have a drug comparison of interest. [pmid: 17725634].
Shargorodsky M, Wainstein J, Gavish D, Leibovitz E, Matas Z, Zimlichman R. Erratum: Treatment with rosiglitazone reduces hyperinsulinemia and improves arterial elasticity in patients with type 2 diabetes mellitus (American Journal of Hypertension 2003; 16:617–622). Am. J. Hypertens. 2003;16(10):894. Does not have a drug comparison of interest.
Shaw KM. Medical treatment of non-insulin-dependent diabetes. Pract Diabetes. 1986;3(6):277-8. No original data.
Shaya FT, Lu Z, Sohn K, Weir MR. Thiazolidinediones and cardiovascular events in high-risk patients with type-2 diabetes mellitus: a comparison with other oral antidiabetic agents. P T. 2009;34(9):490-501. Does not have a drug comparison of interest. [pmid: 20140111].
Shen LQ, Child A, Weber GM, Folkman J, Aiello LP. Rosiglitazone and delayed onset of proliferative diabetic retinopathy. Arch Ophthalmol. 2008;126(6):793-9. Does not have a drug comparison of interest. [pmid: 18541841].
Shiga Microalbuminuria Reduction Trial (SMART) Group. Reduction of microalbuminuria in patients with type 2 diabetes: the Shiga Microalbuminuria Reduction Trial (SMART). Diabetes Care. 2007;30(6):1581-3. Does not apply. [pmid: 17363751].
Shorr RI, Ray WA, Daugherty JR, Griffin MR. Individual sulfonylureas and serious hypoglycemia in older people. J Am Geriatr Soc. 1996;44(7):751-5. Does not have a drug comparison of interest. [pmid: 8675920].
Shoukry M, Jayyab AK. Plasma HDL in non-insulin-dependent diabetes and the effect of various types of treatment. Atherosclerosis. 1983;49(3):333-8. Does not have a drug comparison of interest. [pmid: 6661271].
Signorini AM, Fondelli C, Renzoni E, Puccetti C, Gragnoli G, Giorgi G. Antioxidant effects of gliclazide, glibenclamide, and metformin in patients with type 2 diabetes mellitus. Curr Ther Res Clin Exp. 2002;63(7):411-20. Does not apply.
Simon S, Stephenson S, Whyte K, et al. Prevalence of chronic renal failure in the diabetic population at the University Hospital of the West Indies. West Indian Med J. 2004;53(2):85-8. Does not apply. [pmid: 15199717].
Simons WR, Vinod HD, Gerber RA, Bolinder B. Does rapid transition to insulin therapy in subjects with newly diagnosed type 2 diabetes mellitus benefit glycaemic control and diabetes-related complications? A German population-based study. Exp Clin Endocrinol Diabetes. 2006;114(9):520-6. Does not apply. [pmid: 17115350].
Simonson D, Smith D, Ferrannini E. Effect of glyburide (GLY) on insulin-mediated glucose metabolism and insulin secretion in non-insulin dependent diabetics (NIDD) and controls. Clin Res. 1982;30(2):404A. Does not apply.
Simonson DC, Kourides IA, Feinglos M, Shamoon H, Fischette CT. Efficacy, safety, and dose-response characteristics of glipizide gastrointestinal therapeutic system on glycemic control and insulin secretion in NIDDM. Results of two multicenter, randomized, placebo-controlled clinical trials. The Glipizide Gastrointestinal Therapeutic System Study Group. Diabetes Care. 1997;20(4):597-606. Does not have a drug comparison of interest. [pmid: 9096986].
Simonson DC. Glyburide improves glycemic control and reduces insulin requirement in insulin-treated NIDDM patients. Adv Ther. 1987;4(4):204. Less than 40 subjects with type 2 diabetes.
Sinagra D, Scarpitta AM, Amato M. Effects of insulin-oral hypoglycemic agents combined therapy in outpatients with type 2 diabetes. Eur Rev Med Pharmacol Sci. 1998;2(5-6):175-9. Does not meet the study design criteria. [pmid: 10710815].
Singhal P, Caumo A, Cobelli C, Taylor R. Effect of repaglinide and gliclazide on postprandial control of endogenous glucose production. Metabolism. 2005;54(1):79-84. Does not have a drug comparison of interest. [pmid: 15562384].
Sitprija S, Vajanamurhutue C, Bunnag S. Blood lactate and pyruvate levels in diabetic patients treated with sulphonylureas with and without biguanides. J Med Assoc Thailand. 1982;65(2):63-71. Does not apply.
Sivitz WI, Wayson SM, Bayless ML, et al. Leptin and body fat in type 2 diabetes and monodrug therapy. J Clin Endocrinol Metab. 2003;88(4):1543-53. Less than 40 subjects with type 2 diabetes. [pmid: 12679437].
Smith NL, Heckbert SR, Bittner VA, et al. Antidiabetic treatment trends in a cohort of elderly people with diabetes: The Cardiovascular Health Study, 1989–1997. Diabetes Care. 1999;22(5):736-42. Does not apply. [pmid: 10332674].
Smith SR, De Jonge L, Volaufova J, Li Y, Xie H, Bray GA. Effect of pioglitazone on body composition and energy expenditure: a randomized controlled trial. Metabolism. 2005;54(1):24-32. Does not have a drug comparison of interest. [pmid: 15562376].
Smits P. Cardiovascular effects of sulphonylurea derivatives. Diabetologia. 1997;40(Suppl 2):S160-1. No original data. [pmid: 9248730].
Sonnenberg GE, Garg DC, Weidler DJ, et al. Short-term comparison of once - versus twice-daily administration of glimepiride in patients with non-insulin-dependent diabetes mellitus. Ann Pharmacother. 1997;31(6):671-6. Does not have a drug comparison of interest. [pmid: 9184703].
Southwell A, Eckland D. Limitations of treatments available for the management of Type 2 diabetes: Results from an international survey of physicians. Pract Diabetes Int. 1998;15(4):112-6. Does not meet the study design criteria.
Spanheimer R, Betteridge DJ, Tan MH, Ferrannini E, Charbonnel B. Long-term lipid effects of pioglitazone by baseline anti-hyperglycemia medication therapy and statin use from the PROactive experience (PROactive 14). Am J Cardiol. 2009;104(2):234-9. Does not have a drug comparison of interest. [pmid: 19576353].
Spanheimer R, Zhao Z, Perez A. Evaluating effect of insulin resistance and beta cell function in a pioglitazone and metformin fixed-dose combination study. Diabetologia: Diabetologia. 2009;52(S1):S212. No original data.
Spanheimer R, Zhao Z, Perez A. Improvement of glycaemic control via reducing insulin resistance with pioglitazone and metformin fixed-dose combination therapy. Canadian Journal of Diabetes: Can. J Diabetes. 2009;33(3):273. Does not meet the study design criteria.
Stades AM, Heikens JT, Holleman F, Hoekstra JB. Effect of metformin on glycaemic control in type 2 diabetes in daily practice: a retrospective study. Neth J Med. 2000;56(3):86-90. Does not meet the study design criteria. [pmid: 10759019].
Stalhammar J, Bergman U, Boman K, Dahlen M. Metabolic control in diabetic subjects in three Swedish areas with high, medium, and low sales of antidiabetic drugs. Diabetes Care. 1991;14(1):12-9. Does not meet the study design criteria. [pmid: 1899368].
Standl E, Maxeiner S, Raptis S, Karimi-Anderesi Z, Schweitzer MA. Good glycemic control with flexibility in timing of basal insulin supply: A 24-week comparison of insulin glargine given once daily in the morning or at bedtime in combination with morning glimepiride. Diabetes Care. 2005;28(2):419-20. Does not have a drug comparison of interest. [pmid: 15677803].
Stang M, Wysowski DK, Butler-Jones D. Incidence of lactic acidosis in metformin users. Diabetes Care. 1999;22(6):925-7. No comparison group. [pmid: 10372243].
Stargardt T, Yin DD, Alexander CM. Treatment choice and effectiveness of adding sulphonylurea or glitazones to metformin for the treatment of type 2 diabetes mellitus. Diabetes Obes Metab. 2009;11(5):491-7. Does not meet the study design criteria. [pmid: 19236437].
Starner CI, Schafer JA, Heaton AH, Gleason PP. Rosiglitazone and pioglitazone utilization from January 2007 through May 2008 associated with five risk-warning events. J Manag Care Pharm. 2008;14(6):523-31. Does not apply. [pmid: 18693776].
Stocker DJ, Taylor AJ, Langley RW, Jezior MR, Vigersky RA. A randomized trial of the effects of rosiglitazone and metformin on inflammation and subclinical atherosclerosis in patients with type 2 diabetes. Am Heart J. 2007;153(3):445.e1-6. Does not have a drug comparison of interest. [pmid: 17307426].
Stockl KM, Le L, Zhang S, Harada AS. Risk of acute myocardial infarction in patients treated with thiazolidinediones or other antidiabetic medications. Pharmacoepidemiol Drug Saf. 2009;18(2):166-74. Does not have a drug comparison of interest. [pmid: 19109802].
Strock E, Mazze RS, Cuddihy R, Idrogo M, Wesley D, Morgan B. Multinational study examining the association between diabetes therapy and glycaemic control in patients with type 2 diabetes. Canadian Journal of Diabetes: Can. J. Diabetes. 2009;33(3):316. No original data.
Strojek K, Bebakar WM, Khutsoane DT, et al. Once. -daily initiation with biphasic insulin aspart 30 versus insulin glargine in patients with type 2 diabetes inadequately controlled with oral drugs: an open-label, multinational RCT. Curr Med Res Opin. 2009;25(12):2887-94. Does not have a drug comparison of interest. [pmid: 19821654].
Stroup J, Kane MP, Busch RS, Bakst G, Hamilton RA. The utility of insulin glargine in the treatment of diabetes mellitus. Pharmacotherapy. 2004;24(6):736-42. Does not have a drug comparison of interest. [pmid: 15222663].
Strowig SM, Aviles-Santa ML, Raskin P. Comparison of insulin monotherapy and combination therapy with insulin and metformin or insulin and troglitazone in type 2 diabetes. Diabetes Care. 2002;25(10):1691-8. Does not have a drug comparison of interest. [pmid: 12351463].
Sugihara S, Sasaki N, Kohno H, Amemiya S, Tanaka T, Matsuura N. Survey of current medical treatments for childhood-onset type 2 diabetes mellitus in Japan. Clin Pediatr Endocrinol. 2005;14(2):65-75. Does not meet the study design criteria.
Sultan A, Avignon A, Galtier F, et al. Osteoprotegerin, thiazolidinediones treatment, and silent myocardial ischemia in type 2 diabetic patients. Diabetes Care. 2008;31(3):593-5. Does not apply. [pmid: 18083791].
Sundar PS. Short term hypoglycemic response of ‘Minidiab’(R) (glipizide) in 40 type II diabetics. J DIABETIC ASSOC INDIA. 1982;22(3):73-7. Does not meet the study design criteria.
Suzuki M, Takamisawa I, Yoshimasa Y, Harano Y. Association between insulin resistance and endothelial dysfunction in type 2 diabetes and the effects of pioglitazone. Diabetes Res Clin Pract. 2007;76(1):12-7. No comparison group. [pmid: 17007957].
Svobodova H, Stulc T, Kasalova Z, et al. The effect of rosiglitazone on the expression of thrombogenic markers on leukocytes in type 2 diabetes mellitus. Physiol Res. 2008. Does not meet the study design criteria.
Swislocki AL, Khuu Q, Liao E, et al. Safety and efficacy of metformin in a restricted formulary. Am J Manag Care. 1999;5(1):62-8. No comparison group. [pmid: 10345968].
Tahrani AA, Varughese GI, Scarpello JH, Hanna FW. Metformin, heart failure, and lactic acidosis: is metformin absolutely contraindicated. BMJ. 2007;335(7618):508-12. No original data. [pmid: 17823192].
Takagi T, Yamamuro A, Tamita K, et al. Pioglitazone reduces neointimal tissue proliferation after coronary stent implantation in patients with type 2 diabetes mellitus: an intravascular ultrasound scanning study. Am Heart J. 2003;146(2):E5. Does not have a drug comparison of interest. [pmid: 12891212].
Takagi T, Yamamuro A, Tamita K, Katayama M, Morioka S. Thiazolidinedione treatment attenuates diffuse neointimal hyperplasia in restenotic lesions after coronary stent implantation in type 2 diabetic patients: an intravascular ultrasound study. J Cardiol. 2005;45(4):139-47. Does not have a drug comparison of interest. [pmid: 15875535].
Takeda Pharmaceuticals North America Inc. Observation of an increased risk of fractures in female patients who received long-term treatment with ACTOS (pioglitazone HCl) tablets for type II diabetes mellitus. Deerfield, Illinois. Takeda Pharmaceuticals North America, Inc. 2007. No original data.
Tan MH, Baksi A, Krahulec B, et al. Comparison of pioglitazone and gliclazide in sustaining glycemic control over 2 years in patients with type 2 diabetes. Diabetes Care. 2005;28(3):544-50. Does not have a drug comparison of interest. [pmid: 15735185].
Tan MH, Johns D, Glazer NB. Pioglitazone reduces atherogenic index of plasma in patients with type 2 diabetes. Clin Chem. 2004;50(7):1184-8. Does not apply. [pmid: 15117857].
Tankova T, Koev D, Dakovska L, Kirilov G. The effect of repaglinide on insulin secretion and oxidative stress in type 2 diabetic patients. Diabetes Res Clin Pract. 2003;59(1):43-9. Does not have a drug comparison of interest. [pmid: 12482641].
Taylor KG, Wright AD, John WG. A prospective study of sulphonylurea therapy and serum HDL-cholesterol in type 2 (insulin independent) diabetics. Diabetologia. 1981;21(5):514-5. Less than 40 subjects with type 2 diabetes.
Taylor R, Isles TE, MacLaren S. Comparison of metabolic profiles in non obese, non insulin dependent diabetics receiving glipizide and glibenclamide. Diabetol Croat. 1983;12(4):279-92. Less than 40 subjects with type 2 diabetes.
Taylor R, Isles TE, McLaren S, Newton RW. A comparison of the metabolic profiles in type 2 diabetics during glipizide and glibenclamide treatment. Diabetologia. 1981;21(3):518. Less than 40 subjects with type 2 diabetes.
Taylor R, Isles TE, McLaren S. A comparison of the metabolic profiles in type 2 (insulin independent) diabetics during glipzide and glibenclamide treatment. Diabetologia. 1981;21(5). Does not have a drug comparison of interest.
Tentolouris N, Matsagura M, Psallas M, et al. Relationship between antidiabetic treatment with QT dispersion during acute coronary syndromes in type 2 diabetes: comparison between patients receiving sulfonylureas and insulin. Exp Clin Endocrinol Diabetes. 2005;113(5):298-301. Does not apply. [pmid: 15926117].
Teranishi T, Ohara T, Maeda K, et al. Effects of pioglitazone and metformin on intracellular lipid content in liver and skeletal muscle of individuals with type 2 diabetes mellitus. Metabolism. 2007;56(10):1418-24. Does not meet the study design criteria. [pmid: 17884455].
Testa MA, Simonson DC. Health economic benefits and quality of life during improved glycemic control in patients with type 2 diabetes mellitus: a randomized, controlled, double-blind trial. JAMA. 1998;280(17):1490-6. Does not have a drug comparison of interest. [pmid: 9809729].
Teupe B, Bergis K. Prospective randomized two-years clinical study comparing additional metformin treatment with reducing diet in type 2 diabetes. Diabete Metab. 1991;17:213-7. Does not have a drug comparison of interest. [pmid: 1936479].
Thai AC, Husband DJ, Gill GV, Alberti KGMM. Management of diabetes during surgery. A retrospective study of 112 cases. Diabete Metabol. 1984;10(2):65-70. Does not apply.
Thayer S, Arondekar B, Harley C, Darkow TE. Adherence to a Fixed-Dose Combination of Rosiglitazone/Glimepiride in Subjects Switching from Monotherapy or Dual Therapy with a Thiazolidinedione and/or a Sulfonylurea(May). Ann Pharmacother. 2010. Does not have a drug comparison of interest.
Tholakanahalli VN, Potti A, Heyworth MF. Glibenclamide-induced cholestasis. West J Med. 1998;168(4):274-7. Does not meet the study design criteria. [pmid: 9584675].
Tildesley HD, Aydin CM, Ignaszewski A, Strelzow JA, Yu E, Bondy G. Sulfonylurea therapy is associated with increased NT-proBNP levels in the treatment of type 2 diabetes. Int J Cardiol. 2007;115(3):312-7. Does not meet the study design criteria. [pmid: 16824633].
Tomioka S, Ogata H, Tamura Y, et al. Clinical characteristics influencing the effectiveness of metformin on Japanese type 2 diabetes receiving sulfonylureas. Endocr J. 2007;54(2):247-53. No comparison group. [pmid: 17303931].
Tong PC, Chow CC, Jorgensen LN, Cockram CS. The contribution of metformin to glycaemic control in patients with Type 2 diabetes mellitus receiving combination therapy with insulin. Diabetes Res Clin Pract. 2002;57(2):93-8. Does not have a drug comparison of interest. [pmid: 12062853].
Tong PCY, Ko GTC, So W-Y, et al. Use of anti-diabetic drugs and glycaemic control in type 2 diabetes-The Hong Kong Diabetes Registry. Diabetes Res Clin Pract. 2008;82(3):346-52. Does not meet the study design criteria. [pmid: 18926583].
Tovi J, Theobald H, Engfeldt P. Effect of metabolic control on 24-h ambulatory blood pressure in elderly non-insulin-dependent diabetic patients. J Hum Hypertens. 1996;10(9):589-94. Less than 40 subjects with type 2 diabetes. [pmid: 8953203].
Trischitta V, Italia S, Mazzarino S, Riddle MC. Addition of insulin or metformin after secondary failure to glyburide. Ann Intern Med. 1992;117(SUPPL 2):46. Less than 40 subjects with type 2 diabetes.
Trischitta V, Italia S, Raimondo M, et al. Efficacy of combined treatments in NIDDM patients with secondary failure to sulphonylureas. Is it predictable. J Endocrinol Invest. 1998;21(11):744-7. Does not have a drug comparison of interest. [pmid: 9972673].
Trovati M, Burzacca S, Mularoni E, et al. A comparison of the predictive power for overall blood glucose control of a ‘good’ fasting level in type 2 diabetic patients on diet alone or with oral agents. Diabet Med. 1992;9(2):134-7. Does not have a drug comparison of interest. [pmid: 1563247].
Tseng CH, Huang TS. Pioglitazone with sulfonylurea: glycemic and lipid effects in Taiwanese type 2 diabetic patients. Diabetes Res Clin Pract. 2005;70(2):193-4. No original data. [pmid: 16188579].
Turner R, Cull C, Holman R. United Kingdom Prospective Diabetes Study 17: a 9-year update of a randomized, controlled trial on the effect of improved metabolic control on complications in non-insulin-dependent diabetes mellitus. Ann Intern Med. 1996;124:136-45. Does not have a drug comparison of interest. [pmid: 8554206].
Turner R, Murchison L, Wright AD, et al. United Kingdom prospective diabetes study 24: A 6-year, randomized, controlled trial comparing sulfonylurea, insulin, and metformin therapy in patients with newly diagnosed type 2 diabetes that could not be controlled with diet therapy. Ann Intern Med. 1998;128(3):165-75. Does not have a drug comparison of interest. [pmid: 9454524].
Turner R, Rachman J, Holman R. UK Prospective Diabetes Study Diabetes Stoffwechsel. 1996;5:77-80. Other reason.
Turner RC, Cull C, Frighi V, Holman R. UK Prospective Diabetes Study (UKPDS) Group, Glycemic control with diet, sulfonylurea, metformin or insulin in patients with type 2 diabetes mellitus. JAMA. 1999:281. Other reason. [pmid: 10422999].
Turner RC, Holman RR, Cull CA, et al. Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). Lancet. 1998;352(9131):837-53. Does not have a drug comparison of interest. [pmid: 9742976].
Turner RC, Holman RR, Stratton IM, et al. Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). Lancet. 1998;352(9131):854-65. Does not have a drug comparison of interest. [pmid: 9742977].
U.K. prospective diabetes study 16. Overview of 6 years’ therapy of type II diabetes: a progressive disease. UK Prospective Diabetes Study Group. Diabetes. 1995;44(11):1249-58. Does not have a drug comparison of interest. [pmid: 7589820].
U.K. prospective diabetes study. II. Reduction in HbA1c with basal insulin supplement, sulfonylurea, or biguanide therapy in maturity-onset diabetes. A multicenter study. Diabetes. 1985;34(8):793-8. Does not have a drug comparison of interest. [pmid: 2862087].
UKPDS Group. UK Prospective Diabetes Study 24: relative efficacy of sulfonylurea, insulin and metformin therapy in newly diagnosed non-insulin dependent diabetes with primary diet failure followed for six years. Ann Intern Med. 1998;128:165-75. Other reason. [pmid: 9454524].
United Kingdom Prospective Diabetes Study (UKPDS). 13: Relative efficacy of randomly allocated diet, sulphonylurea, insulin, or metformin in patients with newly diagnosed non-insulin dependent diabetes followed for three years. BMJ. 1995;310(6972):83-8. Does not have a drug comparison of interest. [pmid: 7833731].
United Kingdom Prospective Diabetes Study 24: a 6-year, randomized, controlled trial comparing sulfonylurea, insulin, and metformin therapy in patients with newly diagnosed type 2 diabetes that could not be controlled with diet therapy. United Kingdom Prospective Diabetes Study Group. Ann Intern Med. 1998;128(3):165-75. Does not have a drug comparison of interest. [pmid: 9454524].
Van de Laar FA, Lucassen PL, Akkermans RP, Van de Lisdonk EH, Rutten GE, Van Weel C. Alpha-glucosidase inhibitors for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2005;(2):CD003639. No original data. [pmid: 15846673].
van de Laar FA, Lucassen PL, Akkermans RP, van de Lisdonk EH, Rutten GE, van Weel C. Alpha-glucosidase inhibitors for patients with type 2 diabetes: results from a Cochrane systematic review and meta-analysis. Diabetes Care. 2005;28(1):154-63. Does not apply. [pmid: 15616251].
Van der Does FE, BLHR. Glycemic control and complications in type II diabetes. Diabetes Care. 1993;16(6):952-3. No original data. [pmid: 8325216].
Van Hooland S, Boey O, Van der Niepen P, Van den Branden C, Verbeelen D. Effect of short-term rosiglitazone therapy in peritoneal dialysis patients. Perit Dial Int. 2009;29(1):108-11. Less than 40 subjects with type 2 diabetes. [pmid: 19164260].
Van Staa T, Abenhaim L, Monette J. Rates of hypoglycemia in users of sulfonylureas. J Clin Epidemiol. 1997;50(6):735-41. Does not have a drug comparison of interest. [pmid: 9250272].
Varghese P, Gleason V, Sorokin R, Senholzi C, Jabbour S, Gottlieb JE. Hypoglycemia in hospitalized patients treated with antihyperglycemic agents. J Hosp Med. 2007;2(4):234-40. Does not meet the study design criteria. [pmid: 17702035].
Variation in diabetes response. Pharm. J. 2003;271(7272):572. No original data.
Vestergaard P, Rejnmark L, Mosekilde L. Relative fracture risk in patients with diabetes mellitus, and the impact of insulin and oral antidiabetic medication on relative fracture risk. Diabetologia. 2005;48(7):1292-9. Does not have a drug comparison of interest. [pmid: 15909154].
Vilsboll T, Zdravkovic M, Le-Thi T, et al. Liraglutide, a long-acting human glucagon-like peptide-1 analog, given as monotherapy significantly improves glycemic control and lowers body weight without risk of hypoglycemia in patients with type 2 diabetes. Diabetes Care. 2007;30(6):1608-10. Does not have a drug comparison of interest. [pmid: 17372153].
Vlckova V, Cornelius V, Kasliwal R, Wilton L, Shakir SA. Hypoglycaemia with oral antidiabetic drugs: results from prescription-event monitoring cohorts of rosiglitazone, pioglitazone, nateglinide and repaglinide. Drug Saf. 2009;32(5):409-18. Does not have a drug comparison of interest. [pmid: 19419235].
Vongthavaravat V, Wajchenberg BL, Waitman JN, et al. An international study of the effects of rosiglitazone plus sulphonylurea in patients with type 2 diabetes. Curr Med Res Opin. 2002;18(8):456-61. Does not have a drug comparison of interest. [pmid: 12564655].
Vray M, Attali JR. Randomized study of glibenclamide versus traditional Chinese treatment in type 2 diabetic patients. Chinese-French Scientific Committee for the Study of Diabetes. Diabete Metab. 1995;21(6):433-9. Does not have a drug comparison of interest. [pmid: 8593925].
Wade R, Pawaskar MD, Quimbo RA, Hou L. Real world clinical effectiveness of sitagliptin therapy for management of type 2 diabetes: A retrospective database analysis. Value Health. 2009;12(7):A401. Other reason.
Wajchenberg BL, Lerario AC, El-Andere W. The insulin receptor and the effect of sulfonylureas in non-insulin dependent diabetes mellitus. Arq Bras Endocrinol Metabol. 1984;28(4):107-10. Does not apply.
Walker AM, Koro CE, Landon J. Coronary heart disease outcomes in patients receiving antidiabetic agents in the PharMetrics database 2000–2007. Pharmacoepidemiol Drug Saf. 2008;17(8):760-8. Does not have a drug comparison of interest. [pmid: 18383443].
Wallace TM, Matthews DR. Assessment of the effects of insulin secretagogues in humans. Diabetes Obes Metab. 2000;2(5):271-83. No original data. [pmid: 11225742].
Wang F, Vergara C, Carabino J, Desilets A, Vasquez R. Continuation of thiazolidinedione therapy in patients without left ventricular dysfunction who developed edema and congestive-heart-failure symptoms. Am J Health Syst Pharm. 2004;61(15):1604-8. Does not meet the study design criteria. [pmid: 15372837].
Warren E, Weatherley-Jones E, Chilcott J, Beverley C. Systematic review and economic evaluation of a long-acting insulin analogue, insulin glargine. Health Technol. Assess. 2004;8(45):iii-41. Does not apply.
Waters AK, Morgan DB, Wales JK. Blood lactate and pyruvate levels in diabetic patients treated with biguanides with and without sulphonylureas. Diabetologia. 1978;14(2):95-8. Study duration less than 3 months. [pmid: 631461].
Wiholm BE, Myrhed M. Metformin-associated lactic acidosis in Sweden 1977–1991. Eur J Clin Pharmacol. 1993;44(6):589-91. No comparison group. [pmid: 8405019].
Wilcox R, Bousser MG, Betteridge DJ, et al. Effects of pioglitazone in patients with type 2 diabetes with or without previous stroke: results from PROactive (PROspective pioglitAzone Clinical Trial In macroVascular Events 04). Stroke. 2007;38(3):865-73. Does not have a drug comparison of interest. [pmid: 17290029].
Wilcox R. An analysis from PROactive on the effects of pioglitazone on myocardial infarction and major adverse cardiovascular events (MACE) in patients with type 2 diabetes. World Congress of Cardiology 2006. 2006. Other reason.
Williams-Herman D, Johnson J, Lunceford J. Initial combination therapy with sitagliptin and metformin provides effective and durable glycemic control over 1 year in patients with type 2 diabetes: a pivotal phase III clinical trial. Diabetologia. 2007;50:52-3. Other reason.
Williams-Herman D, Seck T, Golm G, et al. Long-term efficacy with sitagliptin as monotherapy or add-on therapy to metformin: Improvement in glycaemic control over 2 years in patients with type 2 diabetes. Diabetologia. 2009;52(S1):S296. No original data.
Willms B, Ruge D. Comparison of acarbose and metformin in patients with Type 2 diabetes mellitus insufficiently controlled with diet and sulphonylureas: a randomized, placebo-controlled study. Diabet Med. 1999;16(9):755-61. Does not have a drug comparison of interest. [pmid: 10510952].
Woerle HJ, Neumann C, Zschau S, et al. Impact of fasting and postprandial glycemia on overall glycemic control in type 2 diabetes Importance of postprandial glycemia to achieve target HbA1c levels. Diabetes Res Clin Pract. 2007;77(2):280-5. Does not apply. [pmid: 17240473].
Wolever TM, Chiasson JL, Josse RG, et al. Small weight loss on long-term acarbose therapy with no change in dietary pattern or nutrient intake of individuals with non-insulin-dependent diabetes. Int J Obes Relat Metab Disord. 1997;21(9):756-63. Does not have a drug comparison of interest. [pmid: 9376887].
Wolever TMS, Assiff L, Basu T, et al. Miglitol, an (alpha)-glucosidase inhibitor, prevents the metformin-induced fall in serum folate and vitamin B12 in subjects with type 2 diabetes. Nutr Res. 2000;20(10):1447-56. Does not have a drug comparison of interest.
Wolffenbuttel BH, Gomis R, Squatrito S, Jones NP, Patwardhan RN. Addition of low-dose rosiglitazone to sulphonylurea therapy improves glycaemic control in Type 2 diabetic patients. Diabet Med. 2000;17(1):40-7. Does not have a drug comparison of interest. [pmid: 10691158].
Wright AD, Cull CA, Holman RR, Turner RC. UKPDS 28: A randomized trial of efficacy of early addition of metformin in sulfonylurea-treated type 2 diabetes. Diabetes Care. 1998;21(1):87-92. Does not have a drug comparison of interest. [pmid: 9538975].
Wright JL, Stanford JL. Metformin use and prostate cancer in Caucasian men: results from a population-based case-control study. Cancer Causes Control. 2009;20(9):1617-22. Does not have a drug comparison of interest. [pmid: 19653109].
Wroe CD. 66th Annual Scientific Sessions of the American Diabetes Association: The 66th Annual Scientific Sessions of the American Diabetes Association. Washington DC. 9–13 June 2006. Pract Diabetes Int. 2006;23(9):424-6. No original data.
Wu Y-T, Gau CS. The cardiovascular risk of sulfonylureas on newly diagnosed type ii diabetes mellitus patients. Drug Saf. 2009;32(10):945-6. Other reason.
Wyne KL, Bell DSH, Braunstein S, Drexler AJ, Miller JL, Nuckolls JG. Trends in management of type 2 diabetes: Role of thiazolidinediones. Endocrinologist. i, ii+. 2003;13(SUPPL 1):S1-21. No original data.
Wysham C, Bergenstal R, Yan P, MacConell L, Malloy J, Porter L. DURATION-2: Exenatide once weekly demonstrated superior glycaemic control and weight reduction compared to sitagliptin or pioglitazone after 26 weeks of treatment. Diabetologia: Diabetologia. 2009;52(S1):S290. No original data.
Xu L, Williams-Herman D. Initial combination therapy with sitagliptin,a selective DPP-4 inhibitor, and metformin leads to marked improvement in cell function in patients with type 2 diabetes. Diabetologia. 2007;50(Suppl 1):365. Other reason.
Yamagishi S, Nakamura K, Inoue H. Acarbose is a promising therapeutic strategy for the treatment of patients with nonalcoholic steatohepatitis (NASH). Med Hypotheses. 2005;65(2):377-9. No original data. [pmid: 15922116].
Yanagawa T, Araki A, Sasamoto K, Shirabe S, Yamanouchi T. Effect of antidiabetic medications on microalbuminuria in patients with type 2 diabetes. Metabolism. 2004;53(3):353-7. Does not have a drug comparison of interest. [pmid: 15015149].
Yang JK, et al. Clinical study on rosiglitazone monotherapy of early type 2 diabetes. China Pharmacy. 2002;13(10):608-10. Other reason.
Yang W, et al. Biphasic insulin aspart 30 three times daily is more effective than a twice-daily regimen, without increasing hypoglycemia, in Chinese subjects with type 2 diabetes inadequately controlled on oral antidiabetes drugs. Diabetes Care. 2008;31(5):852-6. Does not have a drug comparison of interest. [pmid: 18268073].
Yang WY, Ji QH, Zhu DL, et al. Thrice-daily biphasic insulin aspart 30 may be another therapeutic option for Chinese patients with type 2 diabetes inadequately controlled with oral antidiabetic agents. Chin Med J (Engl). 2009;122(14):1704-8. Does not have a drug comparison of interest. [pmid: 19719975].
Yaturu S, Bryant B, Jain SK. Thiazolidinedione treatment decreases bone mineral density in type 2 diabetic men. Diabetes Care. 2007;30(6):1574-6. Does not have a drug comparison of interest. [pmid: 17363747].
Yegnanarayan R, Suryavanshi M, Singh M, Desai S. A comparative study of the glycemic control of various antidiabetic agents and the role of homocysteine in the therapy of type 2 diabetes mellitus. J Diabetes Complications. 2008;22(2):104-11. Does not meet the study design criteria. [pmid: 18280440].
Yener S, Comlekci A, Akinci B, et al. Soluble CD40 ligand, plasminogen activator inhibitor-1 and thrombin-activatable fibrinolysis inhibitor-1-antigen in normotensive type 2 diabetic subjects without diabetic complications. Effects of metformin and rosiglitazone. Med Princ Pract. 2009;18(4):266-71. Does not have a drug comparison of interest. [pmid: 19494532].
Yki-Jarvinen H, Kauppila M, Kujansuu E, et al. Comparison of insulin regimens in patients with non-insulin-dependent diabetes mellitus. New Engl J Med. 1992;327(20):1426-33. Does not have a drug comparison of interest. [pmid: 1406860].
Yki-Jarvinen H, Ryysy L, Nikkila K, Tulokas T, Vanamo R, Heikkila M. Comparison of bedtime insulin regimens in patients with type 2 diabetes mellitus. A randomized, controlled trial. Ann Intern Med. 1999;130(5):389-96. Does not have a drug comparison of interest. [pmid: 10068412].
Yki-Jarvinen H, Ryysy L, Nikkila K. Bedtime insulin plus metformin was effective and did not cause weight gain in patients with poorly controlled type 2 diabetes mellitus. Evid.-Based Med. 1999;4(4):108. No original data.
Yki-Jarvinen H. Combination therapies with insulin in type 2 diabetes. Diabetes Care. 2001;24(4):758-67. No original data. [pmid: 11315844].
Yosefy C, Magen E, Kiselevich A, et al. Rosiglitazone improves, while Glibenclamide worsens blood pressure control in treated hypertensive diabetic and dyslipidemic subjects via modulation of insulin resistance and sympathetic activity. J Cardiovasc Pharmacol. 2004;44(2):215-22. Study duration less than 3 months. [pmid: 15243303].
Yu AP, Wu EQ, Birnbaum HG, et al. Short-term economic impact of body weight change among patients with type 2 diabetes treated with antidiabetic agents: Analysis using claims, laboratory, and medical record data. Curr Med Res Opin. 2007;23(9):2157-69. Does not apply. [pmid: 17669232].
Yudkin JS, Freemantle N. PROactive study. Lancet. 2006;367(9504):24-25. author reply 26–27. No original data. [pmid: 16399143].
Yurgin N, Secnik K, Lage MJ. Antidiabetic prescriptions and glycemic control in German patients with type 2 diabetes mellitus: a retrospective database study. Clin Ther. 2007;29(2):316-25. Does not meet the study design criteria. [pmid: 17472823].
Zhao Z, Spanheimer R, Perez A. Effect of pioglitazone and metformin fixed-dose combination on glycaemic control in untreated patients. Diabetologia. 2009;52(S1):S335. Does not meet the study design criteria.
Zhu XX, Pan CY, Li GW, et al. Addition of rosiglitazone to existing sulfonylurea treatment in chinese patients with type 2 diabetes and exposure to hepatitis B or C. Diabetes Technol Ther. 2003;5(1):33-42. Does not have a drug comparison of interest. [pmid: 12725705].
Zinman B, Gerich J, Buse JB, et al. Efficacy and safety of the human glucagon-like peptide-1 analog liraglutide in combination with metformin and thiazolidinedione in patients with type 2 diabetes (LEAD-4 Met + TZD) (Diabetes Care 2009; 32, (1224-1230)). Diabetes Care: Diabetes Care. 2010;33(3):692. No original data.
Ziyadeh N, McAfee AT, Koro C, Landon J, Arnold Chan K. The thiazolidinediones rosiglitazone and pioglitazone and the risk of coronary heart disease: A retrospective cohort study using a US health insurance database. Clin Ther. 2009;31(11):2665-77. Does not apply. [pmid: 20110009].
Zurlinden J. New treatment for adult-onset diabetes. Nurs Spectr (Wash D C). 1997;7(16):8. No original data. [pmid: 9439332].