# Tallies for Comparisons Not Included in Review

Main intervention | Comparator | Number of studies
Metformin | Acarbose | 3
Metformin | Any insulin | 3
Metformin | Placebo or any non-drug intervention | 21
Metformin | Metformin + GLP-1 agonist | 5
Metformin | Metformin + insulin | 3
Thiazolidinedione | Acarbose | 1
Thiazolidinedione | Placebo or any non-drug intervention | 38
Sulfonylurea | Acarbose | 6
Sulfonylurea | Placebo or any non-drug intervention | 18
DPP-4 inhibitor | Placebo or any non-drug intervention | 9
Meglitinides | Placebo or any non-drug intervention | 10
GLP-1agonist | Placebo or any non-drug intervention | 1
Metformin + thiazolidinedione | Thiazolidinedione + DPP-4inhibitor | 3
Metformin + thiazolidinedione | Thiazolidinedione + GLP-1agonist | 1
Metformin + thiazolidinedione | Sulfonylurea + meglitinides | 1
Metformin + sulfonylurea | Thiazolidinedione + basal insulin | 1
Metformin + sulfonylurea | Sulfonylurea + basal insulin | 2
Metformin + GLP-1 agonist | Thiazolidinedione + GLP-1agonist | 1
Metformin + GLP-1 agonist | Sulfonylurea + GLP-1agonist | 1
Metformin + basal insulin | Sulfonylurea + basal insulin | 2
Metformin + premixed insulin | Sulfonylurea + premixed insulin | 1
Metformin + premixed insulin | Meglitinides + premixed insulin | 1

Additionally, our team attempted to tally, but found no studies evaluating the following comparisons:

- metformin versus bromocriptine
- metformin versus colesevalam
- sitagliptin versus acarbose
- meglitinides versus acarbose
- combination of metformin and either thiazolidinediones, meglitinides, sitagliptin, or premixed insulin versus combinations of thiazolidinedione and either sitagliptin, exenatide, basal insulin, or premixed insulin
- combination of metformin and thiazolidinedione versus a combination that contains either a sulfonylurea, meglitinides, or sitagliptin and either a meglitinides, sitagliptin, exenatide, basal insulin, or premixed insulin
- combination of metformin and sulfonylurea versus combinations of thiazolidinedione and either sitagliptin, exenatide, or premixed insulin
- combination of metformin and sulfonylurea versus a combination of sulfonylurea and either meglitinides, sitagliptin, exenatide, or premixed insulin
- combination of metformin and sulfonylurea versus a combination that contains either a meglitinides or sitagliptin and either a sitagliptin, exenatide, or premixed insulin
- combination of metformin and a basal insulin versus a combination of thiazolidinedione and either sitagliptin, exenatide, basal insulin, or premixed insulin
- combination of metformin and basal insulin versus a combination that contains either a meglitinides or sitagliptin and either a sitagliptin, exenatide, or premixed insulin
- combination of thiazolidinedione and either sulfonylurea, meglitinides, sitagliptin, or exenatide versus a combination of thiazolidinediones and either meglitinides, sitagliptin, exenatide, basal insulin, or premixed insulin
- combination of sulfonylurea and either meglitinides, sitagliptin, or exenatide versus a combination of sulfonylureas and either sitagliptin, exenatide, basal insulin, or premixed insulin
- combination of meglitinides and either sitagliptin or exenatide versus a combination of meglitinides and either exenatide, basal insulin, or premixed insulin
- combination of sitagliptin and exenatide versus a combination of sitagliptin and either basal insulin or premixed insulin