# Forms

Diabetes Medications: Relevance to Key Questions Form

Diabetes Medications: Abstract Review Form

Diabetes Medications: Article Review Form

Diabetes Medications: Study Design Form

Diabetes Medications: Intervention Form

Diabetes Medications: Outcomes Form

Diabetes Medications: Quality Form for Trials

Diabetes Medications: Quality Form for Observational Trials