# Hand-Searched Journals

## All Journals Hand Searched

February 2009–September 2009

American Journal of Medicine

Clinical Therapeutics

Diabetic Medicine

Diabetes and Metabolism

Diabetes

Diabetes Care

Diabetes, Obesity & Metabolism

Diabetes Research and Clinical Practice

Diabetologia

Hormone and Metabolic Research

Journal of Clinical Endocrinology and Metabolism

Lancet

Metabolism: Clinical and Experimental

Practical Diabetes International