# Detailed Electronic Database Search Strategies

MEDLINE Strategy

Terms | Returns
(“diabetes mellitus, type 2”[mh] or (diabet*[tiab] and (“non-insulin dependent”[tiab] or type-2[tiab] or “type II”[tiab] or “type 2”[tiab]))) AND (“thiazolidinediones”[mh] or “glipizide”[mh] or “glyburide”[mh] or “metformin”[mh] or “acarbose”[mh] or thiazolidinedione*[tiab] or pioglitazone[tiab] or rosiglitazone[tiab] or sulfonylurea*[tiab] or sulphonylurea*[tiab] or glipizide[tiab] or glyburide[tiab] or glimepiride[tiab] or glibenclamide[tiab] or biguanide*[tiab] or metformin[tiab] or “insulin secretagogues”[tiab] or meglitinide*[tiab] or repaglinide[tiab] or nateglinide[tiab] or “alpha-glucosidase inhibitors”[tiab] or “alpha-glucosidase inhibitor”[tiab] or acarbose[tiab] or “Dipeptidyl-Peptidase IV Inhibitors”[mh] or sitagliptin*[tiab] or saxagliptin*[tiab] or dpp-4[tiab] or dpp-iv[tiab] or bromocriptine[mh] or bromocriptine[tiab] or colesevelam[tiab] or “Glucagon-Like Peptide 1”[mh] or liraglutide[tiab] or exenatide[tiab]) AND English[lang] NOT (animal[mh] NOT human[mh]) NOT (letter[pt] or comment[pt] or editorial[pt]) | 7927

Embase Strategy

(‘non insulin dependent diabetes mellitus’/exp OR ‘non insulin dependent diabetes mellitus’ or (diabet*:ti,ab and (‘non-insulin dependent’:ti,ab or type-2:ti,ab or ‘type II’:ti,ab or ‘type 2’:ti,ab))) AND (‘thiazolidinedione’/exp or ‘rosiglitazone’/exp or ‘pioglitazone’/exp or ‘glipizide’/exp or ‘glyburide’/exp or ‘glimepiride’/exp or ‘metformin’/exp or ‘alpha glucosidase inhibitor’/exp or ‘acarbose’/exp or ‘sitagliptin’/exp or ‘colesevelam”/exp or thiazolidinedione*:ti,ab or pioglitazone:ti,ab or rosiglitazone:ti,ab or sulfonylurea*:ti,ab or sulphonylurea*:ti,ab or glipizide:ti,ab or glyburide:ti,ab or glimepiride:ti,ab or glibenclamide:ti,ab or biguanide*:ti,ab or metformin:ti,ab or ‘insulin secretagogues’:ti,ab or meglitinide*:ti,ab or repaglinide:ti,ab or nateglinide:ti,ab or ‘alpha-glucosidase inhibitors’:ti,ab or ‘alpha-glucosidase inhibitor’:ti,ab or acarbose:ti,ab or ‘Dipeptidyl-Peptidase IV Inhibitor’/exp or saxagliptin/exp or saxagliptin*:ti,ab or sitagliptin/exp or sitagliptin*:ti,ab or dpp-4:ti,ab or dpp-iv:ti,ab or ‘bromocriptine mesilate’/exp or bromocriptine:ti,ab or colesevelam:ti,ab or exenatide/exp or exenatide:ti,ab or liraglutide/exp or liraglutide:ti,ab) AND [english]/lim NOT ([animals]/lim NOT [humans]/lim) NOT (letter:it or comment:it or editorial:it) | 16093

The Cochrane Central Register of Controlled Trials (CENTRAL)

(diabetes near type-2) or (diabet*:ti,ab,kw and (“non-insulin dependent”:ti,ab,kw or type-2:ti,ab,kw or “type II”:ti,ab,kw or “type 2”:ti,ab,kw)) AND (thiazolidinedione*:ti,ab,kw or pioglitazone:ti,ab,kw or rosiglitazone:ti,ab,kw or sulfonylurea*:ti,ab,kw or sulphonylurea*:ti,ab,kw or glipizide:ti,ab,kw or glyburide:ti,ab,kw or glimepiride:ti,ab,kw or glibenclamide:ti,ab,kw or biguanide*:ti,ab,kw or metformin:ti,ab,kw or “insulin secretagogues”:ti,ab,kw or meglitinide*:ti,ab,kw or repaglinide:ti,ab,kw or nateglinide:ti,ab,kw or “alpha-glucosidase inhibitors”:ti,ab,kw or “alpha-glucosidase inhibitor”:ti,ab,kw or acarbose:ti,ab,kw or “Dipeptidyl-Peptidase IV Inhibitors”:ti,ab,kw or saxagliptin*:ti,ab,kw or sitagliptin*:ti,ab,kw or liraglutide:ti,ab,kw or exenatide:ti:ab,kw or bromocriptine:ti,ab,kw or colesevelam:ti,ab,kw) | 6507