# Medication Comparisons

Table 1 Monotherapy comparisons considered for review

| MET | TZD | SU | DPP4 | MEG | AGI | BROMO | COL | any insulin | non-drug | MET/TZD | MET/ZU | MET/DPP4 | MET/MEG | MET/EX | Met/Insulin
MET
TZD
SU
DPP4
MEG
AGI
BROMO
COL

Black boxes indicate comparisons that were included in the review; light gray boxes indicate comparisons that were not included, but tallied; and dark gray boxes indicate comparisons that were excluded from the review.

AGI = alpha-glucosidase inhibitors; BROMO – bromocriptine; COL = colesevalam; DPP4 = dipeptidyl peptidase-4 inhibitors; MEG = meglitinides; MET = metformin; SU = sulfonylurea; TZD = thiazolidinedione

Table 2 Combination comparisons considered for review

| MET + SU | MET + MEG | MET + DPP4 | MET + EX | MET + Basal | MET + premixed | TZD + SU | TZD + MEG | TZD + DPP4 | TZD + EX | TZD + basal | TZD + premixed | SU + MEG | SU + DPP4 | SU + EX | SU + Basal | SU + premixed | MEG + DPP4 | MEG + EX | MEG + Basal | MEG + premixed | DPP4 + EX | DPP4 + basal ins | DPP4 + premixed | EX + basal ins | EX + premixed
MET + TZD
MET + SU
MET + MEG
MET + DPP4
MET + EX
MET + Basal
MET + premixed
TZD + SU
TZD + MEG
TZD + DPP4
TZD + EX
TZD + basal
TZD + premixed
SU + MEG
SU + DPP4
SU + EX
SU + basal
SU + premixed
MEG + DPP4
MEG + EX
MEG + basal
MEG + premixed
DPP4 + EX
DPP4 + basal
DPP4 + premixed
EX + basal

Black boxes indicate comparisons that were included in the review; light gray boxes indicate comparisons that were not included, but tallied; and dark gray boxes indicate comparisons that were excluded from the review.

AGI = alpha-glucosidase inhibitors; basal = basal insulin; BROMO = bromocriptine; COL = colesevalam; DPP4 = dipeptidyl peptidase-4 inhibitors; EX = exenatide; MEG = meglitinides; MET = metformin; premixed = premixed insulin; SU = sulfonylurea; TZD = thiazolidinedione