# Technical Expert Panel

Robin Dea, M.D.

Regional Director, Autism Spectrum Disorder Services

Kaiser Permanente

Redwood City, CA

Bryan King, M.D.

Professor, Psychiatry and Behavioral Sciences

University of Washington

Seattle, WA

Susan Levy, M.D.

Medical Director, Regional Autism Center

The Children’s Hospital of Philadelphia

Philadelphia, PA

Catherine Lord, Ph.D.

Director, Autism and Communication Disorders Center

University of Michigan, Ann Arbor, MI

Doris Lotz, M.D., M.P.H.

Medicaid Medical Director

New Hampshire Department of Health and Human Services

Gary Mesibov, Ph.D.

Professor and Director, Division of TEACCH

UNC School of Medicine

Chapel Hill, NC

Tristram Smith, Ph.D.

Associate Professor, Department of Pediatrics

University of Rochester Medical Center

Rochester, NY

Paul Yoder, Ph.D.

Professor, Special Education

Vanderbilt Kennedy Center

Nashville, TN