# References

1 Prevalence of the Autism Spectrum Disorders (ASDs) in Multiple Areas of the United States, 2004 and 2006. Atlanta. Centers for Disease Control and Prevention. 2009.
2 Shelton JF, Tancredi DJ, Hertz-Picciotto I. Independent and dependent contributions of advanced maternal and paternal ages to autism risk. Autism Res. 02. 2010;3(1):30-39. [pmid: 20143326].
3 Johnson CP, Myers SM. Identification and evaluation of children with autism spectrum disorders. Pediatrics. 11. 2007;120(5):1183-215. [pmid: 17967920].
4 Diagnostic and Statistical Manual of Mental Disorders. IV ed. Washington DC. American Psychiatric Association. 2000.
5 Zwaigenbaum L, Bryson S, Lord C, et al. Clinical assessment and management of toddlers with suspected autism spectrum disorder: insights from studies of high-risk infants. Pediatrics. 05. 2009;123(5):1383-1391. [pmid: 19403506].
6 Myers SM, Johnson CP. Management of children with autism spectrum disorders. Pediatrics. 11. 2007;120(5):1162-1182. [pmid: 17967921].
7 Myers SM. Management of autism spectrum disorders in primary care. Pediatr Ann. 01. 2009;38(1):42-49. [pmid: 19213293].
8 Seida JK, Ospina MB, Karkhaneh M, et al. Systematic reviews of psychosocial interventions for autism: an umbrella review. Dev Med Child Neurol. 02. 2009;51(2):95-104. [pmid: 19191842].
9 Ospina MB, Krebs Seida J, Clark B, et al. Behavioural and developmental interventions for autism spectrum disorder: a clinical systematic review. PLoS One. 2008;3(11):e3755. [pmid: 19015734].
10 Parr J. Autism. Clin Evid (Online). 2008.
11 Bryson SE, Rogers SJ, Fombonne E. Autism spectrum disorders: early detection, intervention, education, and psychopharmacological management. Can J Psychiatry. 09. 2003;48(8):506-516. [pmid: 14574826].
12 Rogers SJ, Vismara LA. Evidence-Based Comprehensive Treatments for Early Autism. Journal of Clinical Child and Adolescent Psychology. 01. 2008;37(1):8-38. [pmid: 18444052].
13 National Research Council. Committee on Educational Interventions for Children with Autism, Educating Children with Autism. Washington DC. 2001.
14 National Standards Report Randolph. MA. National Autism Center. 2009.
15 Howlin P, Magiati I, Charman T. Systematic Review of Early Intensive Behavioral Interventions for Children with Autism. American Journal on Intellectual and Developmental Disabilities. 01. 2009;114(1):23-41. [pmid: 19143460].
16 Baranek GT. Efficacy of sensory and motor interventions for children with autism. J Autism Dev Disord. 10. 2002;32(5):397-422. [pmid: 12463517].
17 Millward C, Ferriter M, Calver S, et al. Gluten- and casein-free diets for autistic spectrum disorder. Cochrane Database Syst Rev. 2008(2):CD003498.
18 Levy S, Kim A-H, Olive ML. Interventions for Young Children with Autism: A Synthesis of the Literature. Focus on Autism and Other Developmental Disabilities. Spr. 2006;21(1):55-62.
19 Levy SE, Hyman SL. Novel treatments for autistic spectrum disorders. Ment Retard Dev Disabil Res Rev. 2005;11(2):131-142. [pmid: 15977319].
20 Aman MG, Langworthy KS. Pharmacotherapy for hyperactivity in children with autism and other pervasive developmental disorders. J Autism Dev Disord. 10. 2000;30(5):451-459. [pmid: 11098883].
21 Lovaas OI. Behavioral treatment and normal educational and intellectual functioning in young autistic children. J Consult Clin Psychol. 02. 1987;55(1):3-9. [pmid: 3571656].
22 DeMyer MK, Hingtgen JN, Jackson RK. Infantile autism reviewed: a decade of research. Schizophr Bull. 1981;7(3):388-451. [pmid: 6116276].
23 Kanner L. Autistic Disturbances of Affective Contact. Nervous Child 2. 1943;1943:217-250.
24 Rutter M. Diagnosis and definition of childhood autism. J Autism Child Schizophr. 06. 1978;8(2):139-161. [pmid: 670129].
25 Chalfant AM, Rapee R, Carroll L. Treating anxiety disorders in children with high functioning autism spectrum disorders: a controlled trial. J Autism Dev Disord. 11. 2007;37(10):1842-1857. [pmid: 17171539].
26 Reaven JA, Blakeley-Smith A, Nichols S, et al. Cognitive-Behavioral Group Treatment for Anxiety Symptoms in Children with High-Functioning Autism Spectrum Disorders: A Pilot Study. Focus on Autism and Other Developmental Disabilities. 2009;24(1):27-37.
27 Reaven J, Hepburn S. Cognitive-behavioral treatment of obsessive-compulsive disorder in a child with Asperger syndrome: a case report. Autism. 06. 2003;7(2):145-164. [pmid: 12846384].
28 Muris P, Steerneman P, Merckelbach H, et al. Comorbid anxiety symptoms in children with pervasive developmental disorders. J Anxiety Disord. 07-08. 1998;12(4):387-393. [pmid: 9699121].
29 Child and adolescent therapy : cognitive-behavioral procedures. Kendall PC, editor. New York. Guildford Press. 2005.
30 Mesibov GSV. The culture of autism: From theoretical understanding to educational practice. University of North Carolina at Chapel Hill. Division TEACCH, Department of Psychiatry. 1998.
31 Carpenter WT, Koenig JI. The evolution of drug development in schizophrenia: past issues and future opportunities. Neuropsychopharmacology. 08. 2008;33(9):2061-2079. [pmid: 18046305].
32 Akam E, Strange PG. Inverse agonist properties of atypical antipsychotic drugs. Biochem Pharmacol. 06. 1. 2004;67(11):2039-2045. [pmid: 15135301].
33 Meltzer HY, Huang M. In vivo actions of atypical antipsychotic drug on serotonergic and dopaminergic systems. Prog Brain Res. 2008;172:177-197. [pmid: 18772033].
34 Kuroki T, Nagao N, Nakahara T. Neuropharmacology of second-generation antipsychotic drugs: a validity of the serotonin-dopamine hypothesis. Prog Brain Res. 2008;172:199-212. [pmid: 18772034].
35 Scherk H, Pajonk FG, Leucht S. Second-generation antipsychotic agents in the treatment of acute mania: a systematic review and meta-analysis of randomized controlled trials. Arch Gen Psychiatry. 04. 2007;64(4):442-455. [pmid: 17404121].
36 Nelson JC, Papakostas GI. Atypical antipsychotic augmentation in major depressive disorder: a meta-analysis of placebo-controlled randomized trials. Am J Psychiatry. 09. 2009;166(9):980-91. [pmid: 19687129].
37 Bloch MH, Landeros-Weisenberger A, Kelmendi B, et al. A systematic review: antipsychotic augmentation with treatment refractory obsessive-compulsive disorder. Mol Psychiatry. 07. 2006;11(7):622-632. [pmid: 16585942].
38 Bloch MH. Emerging treatments for Tourette’s disorder. Curr Psychiatry Rep. 08. 2008;10(4):323-30. [pmid: 18627671].
39 Anderson LT, Campbell M, Adams P, et al. The effects of haloperidol on discrimination learning and behavioral symptoms in autistic children. J Autism Dev Disord. 06. 1989;19(2):227-239. [pmid: 2663834].
40 Tatsumi M, Groshan K, Blakely RD, et al. Pharmacological profile of antidepressants and related compounds at human monoamine transporters. Eur J Pharmacol. 12. 11. 1997;340(2–3):249-258. [pmid: 9537821].
41 Esbensen AJ, Greenberg JS, Seltzer MM, et al. A longitudinal investigation of psychotropic and non-psychotropic medication use among adolescents and adults with autism spectrum disorders. J Autism Dev Disord. 09. 2009;39(9):1339-1349. [pmid: 19434487].
42 Aman MG, Lam KS, Van Bourgondien ME. Medication patterns in patients with autism: temporal, regional, and demographic influences. J Child Adolesc Psychopharmacol. 02. 2005;15(1):116-126. [pmid: 15741793].
43 Aman MG, Lam KS, Collier-Crespin A. Prevalence and patterns of use of psychoactive medicines among individuals with autism in the Autism Society of Ohio. J Autism Dev Disord. 10. 2003;33(5):527-534. [pmid: 14594332].
44 Gordon CT, Rapoport JL, Hamburger SD, et al. Differential response of seven subjects with autistic disorder to clomipramine and desipramine. Am J Psychiatry. 03. 1992;149(3):363-366. [pmid: 1536276].
45 Cook EH Jr, Rowlett R, Jaselskis C, et al. Fluoxetine treatment of children and adults with autistic disorder and mental retardation. J Am Acad Child Adolesc Psychiatry. 07. 1992;31(4):739-745. [pmid: 1644739].
46 Mulder EJ, Anderson GM, Kema IP, et al. Platelet serotonin levels in pervasive developmental disorders and mental retardation: diagnostic group differences, within-group distribution, and behavioral correlates. J Am Acad Child Adolesc Psychiatry. 04. 2004;43(4):491-499. [pmid: 15187810].
47 Gordon CT, State RC, Nelson JE, et al. A double-blind comparison of clomipramine, desipramine, and placebo in the treatment of autistic disorder. Arch Gen Psychiatry. 06. 1993;50(6):441-447. [pmid: 8498878].
48 McDougle CJ, Naylor ST, Cohen DJ, et al. A double-blind, placebo-controlled study of fluvoxamine in adults with autistic disorder. Arch Gen Psychiatry. 11. 1996;53(11):1001-1008. [pmid: 8911223].
49 Kolevzon A, Mathewson KA, Hollander E. Selective serotonin reuptake inhibitors in autism: a review of efficacy and tolerability. J Clin Psychiatry. 03. 2006;67(3):407-414. [pmid: 16649827].
50 Jou RJ, Handen BL, Hardan AY. Retrospective assessment of atomoxetine in children and adolescents with pervasive developmental disorders. J Child Adolesc Psychopharmacol. 04. 2005;15(2):325-330. [pmid: 15910217].
51 Posey DJ, Wiegand RE, Wilkerson J, et al. Open-label atomoxetine for attention-deficit/hyperactivity disorder symptoms associated with high-functioning pervasive developmental disorders. J Child Adolesc Psychopharmacol. 10. 2006;16(5):599-610. [pmid: 17069548].
52 Arnold LE, Aman MG, Cook AM, et al. Atomoxetine for hyperactivity in autism spectrum disorders: placebo-controlled crossover pilot trial. J Am Acad Child Adolesc Psychiatry. 10. 2006;45(10):1196-1205. [pmid: 17003665].
53 Scahill L, Aman MG, McDougle CJ, et al. A prospective open trial of guanfacine in children with pervasive developmental disorders. J Child Adolesc Psychopharmacol. 10. 2006;16(5):589-598. [pmid: 17069547].
54 Handen BL, Sahl R, Hardan AY. Guanfacine in children with autism and/or intellectual disabilities. J Dev Behav Pediatr. 08. 2008;29(4):303-308. [pmid: 18552703].
55 Tulassay Z, Bodnar A, Farkas I, et al. Somatostatin versus secretin in the treatment of actively bleeding gastric erosions. Digestion. 1992;51(4):211-216. [pmid: 1356864].
56 Watanabe Y, Tsumura H, Sasaki H. Effect of continuous intravenous infusion of secretin preparation (secrepan) in patients with hemorrhage from chronic peptic ulcer and acute gastric mucosal lesion (AGML). Gastroenterol Jpn. 07. 1991;26(Suppl 3):86-89. [pmid: 1884969].
57 Charlton CG, Miller RL, Crawley JN, et al. Secretin modulation of behavioral and physiological functions in the rat. Peptides. 09-10. 1983;4(5):739-742. [pmid: 6657519].
58 Fremeau RT Jr, Jensen RT, Charlton CG, et al. Secretin: specific binding to rat brain membranes. J Neurosci. 08. 1983;3(8):1620-1625. [pmid: 6308185].
59 Horvath K, Stefanatos G, Sokolski KN, et al. Improved social and language skills after secretin administration in patients with autistic spectrum disorders. J Assoc Acad Minor Phys. 1998;9(1):9-15. [pmid: 9585670].
60 Cortesi F, Giannotti F, Ivanenko A, et al. Sleep in children with autistic spectrum disorder. Sleep Med. 08. 2010;11(7):659-664. [pmid: 20605110].
61 Zawilska JB, Skene DJ, Arendt J. Physiology and pharmacology of melatonin in relation to biological rhythms. Pharmacol Rep. 05-06. 2009;61(3):383-410. [pmid: 19605939].
62 Dosman CF, Drmic IE, Brian JA, et al. Ferritin as an indicator of suspected iron deficiency in children with autism spectrum disorder: prevalence of low serum ferritin concentration. Dev Med Child Neurol. 12. 2006;48(12):1008-1009. [pmid: 17109795].
63 Schneider CK, Melmed RD, Barstow LE, et al. Oral human immunoglobulin for children with autism and gastrointestinal dysfunction: a prospective, open-label study. J Autism Dev Disord. 11. 2006;36(8):1053-1064. [pmid: 16845577].
64 Handen BL, Melmed RD, Hansen RL, et al. A double-blind, placebo-controlled trial of oral human immunoglobulin for gastrointestinal dysfunction in children with autistic disorder. J Autism Dev Disord. 05. 2009;39(5):796-805. [pmid: 19148734].
65 Nye C, Brice A. Combined vitamin B6-magnesium treatment in autism spectrum disorder. Cochrane Database Syst Rev. 2005(4):CD003497.
66 Gaby AR. Natural approaches to epilepsy. Altern Med Rev. 03. 2007;12(1):9-24. [pmid: 17397265].
67 Pearl PL, Gibson KM. Clinical aspects of the disorders of GABA metabolism in children. Curr Opin Neurol. 04. 2004;17(2):107-113. [pmid: 15021235].
68 Rossignol DA. Novel and emerging treatments for autism spectrum disorders: a systematic review. Ann Clin Psychiatry. 10-12. 2009;21(4):213-236. [pmid: 19917212].
69 Lakhan SE, Vieira KF. Nutritional therapies for mental disorders. Nutr J. 2008;7:2. [pmid: 18208598].
70 Levy R, Cooper P. Ketogenic diet for epilepsy. Cochrane Database Syst Rev. 2003(3):CD001903.
71 Lechin F, van der Dijs B, Pardey-Maldonado B, et al. Effects of amantadine on circulating neurotransmitters in healthy subjects. J Neural Transm. 03. 2010;117(3):293-299. [pmid: 20131070].
72 Farlow MR. Treatment of mild cognitive impairment (MCI). Curr Alzheimer Res. 08. 2009;6(4):362-367. [pmid: 19689235].
73 Calvert JW, Cahill J, Zhang JH. Hyperbaric oxygen and cerebral physiology. Neurol Res. 03. 2007;29(2):132-141. [pmid: 17439697].
74 McDonagh MS, Morgan D, Carson S, et al. Systematic review of hyperbaric oxygen therapy for cerebral palsy: the state of the evidence. Dev Med Child Neurol. 12. 2007;49(12):942-947. [pmid: 18039243].
75 Santoro A, Siviero P, Minicuci N, et al. Effects of donepezil, galantamine and rivastigmine in 938 italian patients with Alzheimer’s disease: a prospective, observational study. CNS Drugs. 02. 1. 2010;24(2):163-176. [pmid: 20088621].
76 Bradberry S, Vale A. Dimercaptosuccinic acid (succimer; DMSA) in inorganic lead poisoning. Clin Toxicol (Phila). 08. 2009;47(7):617-631. [pmid: 19663612].
77 Boscolo M, Antonucci S, Volpe AR, et al. Acute mercury intoxication and use of chelating agents. J Biol Regul Homeost Agents. 10-12. 2009;23(4):217-223. [pmid: 20003760].
78 Kidd PM. Autism, an extreme challenge to integrative medicine. Part 2: medical management. Altern Med Rev. 12. 2002;7(6):472-99. [pmid: 12495373].
79 Gupta S. Immunological treatments for autism. J Autism Dev Disord. 10. 2000;30(5):475-479. [pmid: 11098887].
80 Yoder PJ, Warren SF, Kim K, et al. Facilitating prelinguistic communication skills in young children with developmental delay. II: Systematic replication and extension. J Speech Hear Res. 08. 1994;37(4):841-851. [pmid: 7526042].
81 Warren SF, Yoder PJ, Gazdag GE, et al. Facilitating prelinguistic communication skills in young children with developmental delay. J Speech Hear Res. 02. 1993;36(1):83-97. [pmid: 7680733].
82 Bondy AS, Frost LA. PECS: The Picture Exchange Communication System Training Manual. 1st ed. Cherry Hill, NJ. 1994.
83 Baron-Cohen S, Ashwin E, Ashwin C, et al. Talent in autism: hyper-systemizing, hyper-attention to detail and sensory hypersensitivity. Philos Trans R Soc Lond B Biol Sci. 05. 27. 2009;364(1522):1377-1383. [pmid: 19528020].
84 Rogers SJ, Ozonoff S. Annotation: what do we know about sensory dysfunction in autism? A critical review of the empirical evidence. J Child Psychol Psychiatry. 12. 2005;46(12):1255-1268. [pmid: 16313426].
85 Jean AA. Sensory integration and learning disorders. Los Angeles. Western Psychological Services. 1972.
86 Sinha Y, Silove N, Wheeler D, et al. Auditory integration training and other sound therapies for autism spectrum disorders. Cochrane Database Syst Rev. 2004(1):CD003681.
87 Sinha Y, Silove N, Wheeler D, et al. Auditory integration training and other sound therapies for autism spectrum disorders: a systematic review. Arch Dis Child. 12. 2006;91(12):1018-1022. [pmid: 16887860].
88 Gold C, Wigram T, Elefant C. Music therapy for autistic spectrum disorder. Cochrane Database Syst Rev. 2006(2):CD004381.
89 Kim J, Wigram T, Gold C. Emotional, motivational and interpersonal responsiveness of children with autism in improvisational music therapy. Autism. 07. 2009;13(4):389-409. [pmid: 19535468].
90 Field T, Lasko D, Mundy P, et al. Brief report: autistic children’s attentiveness and responsivity improve after touch therapy. J Autism Dev Disord. 06. 1997;27(3):333-338. [pmid: 9229263].
91 Zwaigenbaum L, Thurm A, Stone W, et al. Studying the Emergence of Autism Spectrum Disorders in High-Risk Infants: Methodological and Practical Issues. Journal of Autism and Developmental Disorders. 03. 2007;37(3):466-480. [pmid: 16897376].
92 American Academy of Pediatrics. The pediatrician’s role in the diagnosis and anagement of autistic spectrum disorder in children. Pediatrics. 05. 2001;107(5):1221-1226. [pmid: 11331713].
93 Carbone PS, Behl DD, Azor V, et al. The medical home for children with autism spectrum disorders: Parent and pediatrician perspectives. Journal of Autism and Developmental Disorders. 03. 2010;40(3):317-324. [pmid: 19768528].
94 Bent S, Bertoglio K, Hendren RL. Omega-3 Fatty Acids for Autistic Spectrum Disorder: A Systematic Review. Journal of Autism and Developmental Disorders. 08. 2009;39(8):1145-1154. [pmid: 19333748].
95 Broadstock M, Doughty C, Eggleston M. Systematic Review of the Effectiveness of Pharmacological Treatments for Adolescents and Adults with Autism Spectrum Disorder. Autism: The International Journal of Research and Practice. 2007;11(4):335-348. [pmid: 17656398].
96 Williams KW, Wray JJ, Wheeler DM. Intravenous secretin for autism spectrum disorder. Cochrane Database Syst Rev. 2005(3):CD003495.
97 Horner RHCE, Halle J, McGee G, Odom S, Wolery M. The use of single subject research to identify evidence-based practice in special education. Except Child. 2005;71:165-179.
98 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. 05. 2010;63(5):502-512. [pmid: 18823754].
99 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 05. 2010;63(5):513-523. [pmid: 19595577].
100 Green J, Charman T, McConachie H, et al. Parent-mediated communication-focused treatment in children with autism (PACT): a randomised controlled trial. Lancet. 2010. 05. 20.
101 Remington B, Hastings RP, Kovshoff H, et al. Early intensive behavioral intervention: outcomes for children with autism and their parents after two years. Am J Ment Retard. 11. 2007;112(6):418-438. [pmid: 17963434].
102 Ben Itzchak E, Lahat E, Burgin R, et al. Cognitive, behavior and intervention outcome in young children with autism. Res Dev Disabil. 09-10. 2008;29(5):447-458. [pmid: 17923388].
103 Reed P, Osborne LA, Corness M. Brief report: relative effectiveness of different home-based behavioral approaches to early teaching intervention. J Autism Dev Disord. 10. 2007;37(9):1815-1821. [pmid: 17180714].
104 Ben-Itzchak E, Zachor DA. The effects of intellectual functioning and autism severity on outcome of early behavioral intervention for children with autism. Res Dev Disabil. 05-06. 2007;28(3):287-303. [pmid: 16730944].
105 Cohen H, Amerine-Dickens M, Smith T. Early intensive behavioral treatment: replication of the UCLA model in a community setting. J Dev Behav Pediatr. 04. 2006;27(2 Suppl):S145-155. [pmid: 16685181].
106 Eldevik S, Eikeseth S, Jahr E, et al. Effects of low-intensity behavioral treatment for children with autism and mental retardation. J Autism Dev Disord. 02. 2006;36(2):211-224. [pmid: 16477514].
107 Beglinger L, Smith T. Concurrent validity of social subtype and IQ after early intensive behavioral intervention in children with autism: a preliminary investigation. J Autism Dev Disord. 06. 2005;35(3):295-303. [pmid: 16119470].
108 Aldred C, Green J, Adams C. A new social communication intervention for children with autism: pilot randomised controlled treatment study suggesting effectiveness. J Child Psychol Psychiatry. 11. 2004;45(8):1420-1430. [pmid: 15482502].
109 Drew A, Baird G, Baron-Cohen S, et al. A pilot randomised control trial of a parent training intervention for pre-school children with autism. Preliminary findings and methodological challenges. Eur Child Adolesc Psychiatry. 12. 2002;11(6):266-272. [pmid: 12541005].
110 Eikeseth S, Smith T, Jahr E, et al. Intensive behavioral treatment at school for 4- to 7-year-old children with autism. A 1-year comparison controlled study. Behav Modif. 01. 2002;26(1):49-68. [pmid: 11799654].
111 Boyd RD, Corley MJ. Outcome survey of early intensive behavioral intervention for young children with autism in a community setting. Autism. 12. 2001;5(4):430-441. [pmid: 11777258].
112 Gabriels RL, Hill DE, Pierce RA, et al. Predictors of treatment outcome in young children with autism: a retrospective study. Autism. 12. 2001;5(4):407-429. [pmid: 11777257].
113 Mudford OC, Martin NT, Eikeseth S, et al. Parent-managed behavioral treatment for preschool children with autism: some characteristics of UK programs. Res Dev Disabil. 05-06. 2001;22(3):173-182. [pmid: 11380057].
114 Smith T, Groen AD, Wynn JW. Randomized trial of intensive early intervention for children with pervasive developmental disorder. Am J Ment Retard. 07. 2000;105(4):269-85. [pmid: 10934569].
115 Harris SL, Handleman JS. Age and IQ at intake as predictors of placement for young children with autism: a four- to six-year follow-up. J Autism Dev Disord. 04. 2000;30(2):137-142. [pmid: 10832778].
116 Anan RM, Warner LJ, McGillivary JE, et al. Group Intensive Family Training (GIFT) for preschoolers with autism spectrum disorders. Behavioral Interventions. 07. 2008;23(3):165-180.
117 Baker-Ericzen MJ, Stahmer AC, Burns A. Child Demographics Associated With Outcomes in a Community-Based Pivotal Response Training Program. Journal of Positive Behavior Interventions. Win. 2007;9(1):52-60.
118 Dillenburger K, Keenan M, Gallagher S, et al. Parent education and home-based behaviour analytic intervention: An examination of parents’ perceptions of outcome. Journal of Intellectual & Developmental Disability. 06. 2004;29(2):119-130.
119 Arick JR, Young HE, Falco RA, et al. Designing an outcome study to monitor the progress of students with autism spectrum disorders. Focus on Autism and Other Developmental Disabilities. Sum. 2003;18(2):75-87.
120 Stahmer AC, Gist K. The effects of an accelerated parent education program on technique mastery and child outcome. Journal of Positive Behavior Interventions. Spr. 2001;3(2):75-82.
121 Luiselli JK, Cannon BOM, Ellis JT, et al. Home-based behavioral interventions for young children with autism/pervasive developmental disorder: A preliminary evaluation of outcome in relation to child age and intensity of service delivery. Autism. 12. 2000;4(4):426-438.
122 Perry A, Cummings A, Geier JD, et al. Effectiveness of Intensive Behavioral Intervention in a Large, Community-Based Program. Research in Autism Spectrum Disorders. 10. 2008;2(4):621-642.
123 Gabriels RL, Ivers BJ, Hill DE, et al. Stability of Adaptive Behaviors in Middle-School Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 10-12. 2007;1(4):291-303.
124 Zachor DA, Ben-Itzchak E, Rabinovich AL, et al. Change in Autism Core Symptoms with Early Intervention: predictors and outcomes. Research in Autism Spectrum Disorders. 2009;3:967-976.
125 Zachor DA, Ben-Itzchak E, Rabinovich AL, et al. Change in autism core symptoms with intervention. Research in Autism Spectrum Disorders. [doi: 10.1016/j.rasd.2006.12.001]. 1(4):304-317.
126 Hayward D, Eikeseth S, Gale C, et al. Assessing progress during treatment for young children with autism receiving intensive behavioural interventions. Autism. 11. 2009;13(6):613-633. [pmid: 19933766].
127 Granpeesheh D, Tarbox J, Dixon DR, et al. Retrospective analysis of clinical records in 38 cases of recovery from autism. Ann Clin Psychiatry. 10-12. 2009;21(4):195-204. [pmid: 19917210].
128 Keen D, Rodger S, Doussin K, et al. A pilot study of the effects of a social-pragmatic intervention on the communication and symbolic play of children with autism. Autism. 01. 2007;11(1):63-71. [pmid: 17175574].
129 Howard JS, Sparkman CR, Cohen HG, et al. A comparison of intensive behavior analytic and eclectic treatments for young children with autism. Res Dev Disabil. 07-08. 2005;26(4):359-83. [pmid: 15766629].
130 Farrell P, Trigonaki N, Webster D. An exploratory evaluation of two early intervention programmes for young children with autism. Educational and Child Psychology. 2005;22(4):29-40.
131 Bibby P, Eikeseth S, Martin NT, et al. Progress. and outcomes for children with autism receiving parent-managed intensive interventions. Res Dev Disabil. 01-02. 2002;23(1):81-104. [pmid: 12071397].
132 Eikeseth S, Hayward D, Gale C, et al. Intensity of Supervision and Outcome for Preschool Aged Children Receiving Early and Intensive Behavioral Interventions: A Preliminary Study. Research in Autism Spectrum Disorders. 01. 2009;3(1):67-73.
133 Eikeseth S, Smith T, Jahr E, et al. Outcome for children with autism who began intensive behavioral treatment between ages 4 and 7: a comparison controlled study. Behav Modif. 05. 2007;31(3):264-278. [pmid: 17438342].
134 Gotham K, Pickles A, Lord C. Standardizing ADOS scores for a measure of severity in autism spectrum disorders. J Autism Dev Disord. 05. 2009;39(5):693-705. [pmid: 19082876].
135 Lopata C, Thomeer ML, Volker MA, et al. Effectiveness of a manualized summer social treatment program for high-functioning children with autism spectrum disorders. J Autism Dev Disord. 05. 2008;38(5):890-904. [pmid: 18058012].
136 Lopata C, Thomeer ML, Volker MA, et al. Effectiveness of a Cognitive-Behavioral Treatment on the Social Behaviors of Children With Asperger Disorder. Focus on Autism and Other Developmental Disabilities. Win. 2006;21(4):237-244.
137 Bauminger N. Brief report: individual social-multi-modal intervention for HFASD. J Autism Dev Disord. 09. 2007;37(8):1593-1604. [pmid: 17072753].
138 Bauminger N. Brief report: group social-multimodal intervention for HFASD. J Autism Dev Disord. 09. 2007;37(8):1605-1615. [pmid: 17072752].
139 Solomon M, Goodlin-Jones BL, Anders TF. A social adjustment enhancement intervention for high functioning autism, Asperger’s syndrome, and pervasive developmental disorder NOS. J Autism Dev Disord. 12. 2004;34(6):649-668. [pmid: 15679185].
140 Cotugno AJ. Social competence and social skills training and intervention for children with Autism Spectrum Disorders. J Autism Dev Disord. 09. 2009;39(9):1268-77. [pmid: 19365716].
141 Frankel F, Myatt R, Sugar C, et al. A Randomized Controlled Study of Parent-assisted Children’s Friendship Training with Children having Autism Spectrum Disorders. J Autism Dev Disord. 2010. 01. 8.
142 Tyminski RF, Moore PJ. The impact of group psychotherapy on social development in children with pervasive development disorders. International Journal of Group Psychotherapy. 07. 2008;58(3):363-379. [pmid: 18573027].
143 Owens G, Granader Y, Humphrey A, et al. LEGO therapy and the social use of language programme: an evaluation of two social skills interventions for children with high functioning autism and Asperger Syndrome. J Autism Dev Disord. 11. 2008;38(10):1944-1957. [pmid: 18566882].
144 Gevers C, Clifford P, Mager M, et al. Brief report: A theory-of-mind-based social-cognition training program for school-aged children with pervasive developmental disorders: an open study of its effectiveness. J Autism Dev Disord. 05. 2006;36(4):567-571. [pmid: 16586154].
145 Quirmbach LM, Lincoln AJ, Feinberg-Gizzo MJ, et al. Social stories: mechanisms of effectiveness in increasing game play skills in children diagnosed with autism spectrum disorder using a pretest posttest repeated measures randomized control group design. J Autism Dev Disord. 02. 2009;39(2):299-321. [pmid: 18704672].
146 Beaumont R, Sofronoff K. A multi-component social skills intervention for children with Asperger syndrome: the Junior Detective Training Program. J Child Psychol Psychiatry. 07. 2008;49(7):743-753. [pmid: 18503531].
147 Whitaker P. Fostering Communication and Shared Play between Mainstream Peers and Children with Autism: Approaches, Outcomes and Experiences. British Journal of Special Education. 12. 2004;31(4):215-222.
148 Legoff DB, Sherman M. Long-Term Outcome of Social Skills Intervention Based on Interactive LEGO[C] Play. Autism: The International Journal of Research & Practice. 2006;10(4):317-329. [pmid: 16908476].
149 Kroeger KA, Schultz JR, Newsom C. A Comparison of Two Group-Delivered Social Skills Programs for Young Children with Autism. Journal of Autism and Developmental Disorders. 05. 2007;37(5):808-817. [pmid: 16927011].
150 McGinnis E, Goldsten A. Skillstreaming the Elementary School Child: New Strategies and Perspectives for Teaching Prosocial Skills. Champaign, IL. Research Press. 1997.
151 Gray C, Garand J. Social Stories: Improving Responses of Students with Autism with Accurate Social Information. Focus on Autistic Behavior. 1993;8:1-10.
152 Golan O, Ashwin E, Granader Y, et al. Enhancing Emotion Recognition in Children with Autism Spectrum Conditions: An Intervention Using Animated Vehicles with Real Emotional Faces. Journal of Autism and Developmental Disorders. 03. 2010;40(3):269-279. [pmid: 19763807].
153 Whittingham K, Sofronoff K, Sheffield J, et al. Stepping Stones Triple P: An RCT of a Parenting Program with Parents of a Child Diagnosed with an Autism Spectrum Disorder. Journal of Abnormal Child Psychology. 05. 2009;37(4):469-480. [pmid: 19023654].
154 Whittingham K, Sofronoff K, Sheffield J, et al. Do Parental Attributions Affect Treatment Outcome in a Parenting Program? An Exploration of the Effects of Parental Attributions in an RCT of Stepping Stones Triple P for the ASD Population. Research in Autism Spectrum Disorders. 01. 2009;3(1):129-144.
155 Kasari C, Paparella T, Freeman S, et al. Language outcome in autism: randomized comparison of joint attention and play interventions. J Consult Clin Psychol. 02. 2008;76(1):125-137. [pmid: 18229990].
156 Kasari C, Freeman S, Paparella T. Joint attention and symbolic play in young children with autism: a randomized controlled intervention study. J Child Psychol Psychiatry. 06. 2006;47(6):611-620. [pmid: 16712638].
157 Gulsrud AC, Kasari C, Freeman S, et al. Children with autism’s response to novel stimuli while participating in interventions targeting joint attention or symbolic play skills. Autism. 11. 2007;11(6):535-546. [pmid: 17947289].
158 Wong CS, Kasari C, Freeman S, et al. The Acquisition and Generalization of Joint Attention and Symbolic Play Skills in Young Children with Autism. Research and Practice for Persons with Severe Disabilities (RPSD). Sum. 2007;32(2):101-109.
159 Gutstein SE, Burgess AF, Montfort K. Evaluation of the relationship development intervention program. Autism. 09. 2007;11(5):397-411. [pmid: 17942454].
160 Solomon R, Necheles J, Ferch C, et al. Pilot Study of a Parent Training Program for Young Children with Autism: The PLAY Project Home Consultation Program. Autism: The International Journal of Research and Practice. 2007;11(3):205-224. [pmid: 17478575].
161 Solomon M, Ono M, Timmer S, et al. The effectiveness of parent-child interaction therapy for families of children on the autism spectrum. J Autism Dev Disord. 10. 2008;38(9):1767-1776. [pmid: 18401693].
162 Vorgraft Y, Farbstein I, Spiegel R, et al. Retrospective evaluation of an intensive method of treatment for children with pervasive developmental disorder. Autism. 09. 2007;11(5):413-424. [pmid: 17942455].
163 Field T, Sanders C, Nadel J. Children with autism display more social behaviors after repeated imitation sessions. Autism. 09. 2001;5(3):317-323. [pmid: 11708590].
164 Heimann M, Laberg KE, Nordoen B. Imitative Interaction Increases Social Interest and Elicited Imitation in Non-verbal Children with Autism. Infant and Child Development. Special Issue: Imitation and Socio-Emotional Processes: Implications for Communicative Development and Interventions. 05-06. 2006;15(3):297-309.
165 Escalona A, Field T, Nadel J, et al. Brief report: Imitation effects on children with autism. Journal of Autism and Developmental Disorders. 04. 2002;32(2):141-144. [pmid: 12058842].
166 Mahoney G, Perales F. Relationship-focused early intervention with children with pervasive developmental disorders and other disabilities: a comparative study. J Dev Behav Pediatr. 04. 2005;26(2):77-85. [pmid: 15827458].
167 Gulsrud AC, Jahromi LB, Kasari C. The Co-Regulation of Emotions between Mothers and Their Children with Autism. Journal of Autism and Developmental Disorders. 02. 2010;40(2):227-237. [pmid: 19714458].
168 Sofronoff K, Attwood T, Hinton S, et al. A randomized controlled trial of a cognitive behavioural intervention for anger management in children diagnosed with Asperger syndrome. J Autism Dev Disord. 08. 2007;37(7):1203-1214. [pmid: 17082978].
169 Sofronoff K, Attwood T, Hinton S. A randomised controlled trial of a CBT intervention for anxiety in children with Asperger syndrome. J Child Psychol Psychiatry. 11. 2005;46(11):1152-1160. [pmid: 16238662].
170 Wood JJ, Drahota A, Sze K, et al. Cognitive Behavioral Therapy for Anxiety in Children with Autism Spectrum Disorders: A Randomized, Controlled Trial. Journal of Child Psychology and Psychiatry. 03. 2009;50(3):224-234. [pmid: 19309326].
171 Wood JJ, Drahota A, Sze K, et al. Brief Report: Effects of Cognitive Behavioral Therapy on Parent-Reported Autism Symptoms in School-Age Children with High-Functioning Autism. Journal of Autism and Developmental Disorders. 11. 2009;39(11):1608-1612. [pmid: 19562475].
172 Parent training for children with pervasive developmental disorders: A multi-site feasibility trial. Behavioral Interventions. 07. 2007;22(3):179-199.
173 Grey IM, Honan R, McClean B, et al. Evaluating the effectiveness of teacher training in Applied Behaviour Analysis. J Intellect Disabil. 09. 2005;9(3):209-227. [pmid: 16144826].
174 Sofronoff K, Leslie A, Brown W. Parent management training and Asperger syndrome: a randomized controlled trial to evaluate a parent based intervention. Autism. 09. 2004;8(3):301-317. [pmid: 15358872].
175 Sofronoff K, Farbotko M. The effectiveness of parent management training to increase self-efficacy in parents of children with Asperger syndrome. Autism. 09. 2002;6(3):271-286. [pmid: 12212918].
176 Sofronoff K. A Cognitive Behaviour Therapy intervention for anxiety in children with Asperger’s syndrome. Good Autism Practice. 2003;4:2-8.
177 Aman MG, McDougle CJ, Scahill L, et al. Medication and Parent Training in Children With Pervasive Developmental Disorders and Serious Behavior Problems: Results From a Randomized Clinical Trial. J Am Acad Child Adolesc Psychiatry. 2009. 10. 23.
178 Vismara LA, Young GS, Stahmer AC, et al. Dissemination of Evidence-Based Practice: Can We Train Therapists from a Distance?. Journal of Autism and Developmental Disorders. 12. 2009;39(12):1636-1651.
179 Heinrich H, Gevensleben H, Strehl U. Annotation: neurofeedback - train your brain to train behaviour. J Child Psychol Psychiatry. 01. 2007;48(1):3-16. [pmid: 17244266].
180 Wiggs L, France K. Behavioural treatments for sleep problems in children and adolescents with physical illness, psychological problems or intellectual disabilities. Sleep Med Rev. 06. 2000;4(3):299-314. [pmid: 12531171].
181 Jarusiewicz B. Efficacy of Neurofeedback for Children in the Autistic Spectrum: A Pilot Study. Journal of Neurotherapy. 2002;6(4):39-49.
182 Coben R, Padolsky I. Assessment-guided neurofeedback for autistic spectrum disorder. Journal of Neurotherapy. 2007;11(1):5-23.
183 Reed HE, McGrew SG, Artibee K, et al. Parent-based sleep education workshops in autism. J Child Neurol. 08. 2009;24(8):936-945. [pmid: 19491110].
184 Mesibov GB, Shea V. The TEACCH program in the era of evidence-based practice. J Autism Dev Disord. 05. 2010;40(5):570-9. [pmid: 19937103].
185 Panerai S, Zingale M, Trubia G, et al. Special education versus inclusive education: the role of the TEACCH program. J Autism Dev Disord. 06. 2009;39(6):874-882. [pmid: 19205860].
186 Probst P, Leppert T. Brief report: outcomes of a teacher training program for autism spectrum disorders. J Autism Dev Disord. 10. 2008;38(9):1791-1796. [pmid: 18369717].
187 Tsang SK, Shek DT, Lam LL, et al. Brief report: application of the TEACCH program on Chinese pre-school children with autism--Does culture make a difference?. J Autism Dev Disord. 02. 2007;37(2):390-6. [pmid: 16906461].
188 Mukaddes NM, Kaynak FN, Kinali G, et al. Psychoeducational treatment of children with autism and reactive attachment disorder. Autism. 03. 2004;8(1):101-109. [pmid: 15070550].
189 Moore M, Calvert S. Brief report: vocabulary acquisition for children with autism: teacher or computer instruction. J Autism Dev Disord. 08. 2000;30(4):359-362. [pmid: 11039862].
190 Tjus T, Heimann M, Nelson KE. Interaction patterns between children and their teachers when using a specific multimedia and communication strategy: observations from children with autism and mixed intellectual disabilities. Autism. 06. 2001;5(2):175-187. [pmid: 11706865].
191 Greenberg JH, Martinez RC. Starting Off on the Right Foot: One Year of Behavior Analysis in Practice and Relative Cost. International Journal of Behavioral Consultation and Therapy. 2008;4(2):212-226.
192 Reed P, Osborne LA, Corness M. The Real-World Effectiveness of Early Teaching Interventions for Children with Autism Spectrum Disorder. Exceptional Children. Sum. 2007;73(4):417-433.
193 Stahmer AC, Ingersoll B. Inclusive Programming for Toddlers with Autism Spectrum Disorders: Outcomes from the Children’s Toddler School. Journal of Positive Behavior Interventions. 2004;6(2):67-82.
194 Rickards AL, Walstab JE, Wright-Rossi RA, et al. A randomized, controlled trial of a home-based intervention program for children with autism and developmental delay. J Dev Behav Pediatr. 08. 2007;28(4):308-316. [pmid: 17700083].
195 Magiati I, Charman T, Howlin P. A two-year prospective follow-up study of community-based early intensive behavioural intervention and specialist nursery provision for children with autism spectrum disorders. J Child Psychol Psychiatry. 08. 2007;48(8):803-812. [pmid: 17683452].
196 Osborne LA, McHugh L, Saunders J, et al. Parenting stress reduces the effectiveness of early teaching interventions for autistic spectrum disorders. J Autism Dev Disord. 07. 2008;38(6):1092-1103. [pmid: 18027079].
197 Salt J, Shemilt J, Sellars V, et al. The Scottish Centre for autism preschool treatment programme. II: The results of a controlled treatment outcome study. Autism. 03. 2002;6(1):33-46. [pmid: 11918108].
198 Rickards AL, Walstab JE, Wright-Rossi RA, et al. One-year follow-up of the outcome of a randomized controlled trial of a home-based intervention programme for children with autism and developmental delay and their families. Child Care Health Dev. 09. 2009;35(5):593-602. [pmid: 19508318].
199 Reed P, Osborne LA, Corness M. Effectiveness of Special Nursery Provision for Children with Autism Spectrum Disorders. Autism: The International Journal of Research and Practice. 2010;14(1):67-82. [pmid: 20124504].
200 Whalen C, Moss D, Ilan AB, et al. Efficacy of TeachTown: Basics computer-assisted intervention for the Intensive Comprehensive Autism Program in Los Angeles Unified School District. Autism. 05. 2010;14(3):179-97. [pmid: 20484002].
201 Aman MG, Hollway JA, McDougle CJ, et al. Cognitive effects of risperidone in children with autism and irritable behavior. J Child Adolesc Psychopharmacol. 06. 2008;18(3):227-236. [pmid: 18582177].
202 Aman MG, Arnold LE, McDougle CJ, et al. Acute and long-term safety and tolerability of risperidone in children with autism. J Child Adolesc Psychopharmacol. 12. 2005;15(6):869-884. [pmid: 16379507].
203 Risperidone treatment of autistic disorder: longer-term benefits and blinded discontinuation after 6 months. Am J Psychiatry. 07. 2005;162(7):1361-1369. [pmid: 15994720].
204 McDougle CJ, Scahill L, Aman MG, et al. Risperidone for the core symptom domains of autism: results from the study by the autism network of the research units on pediatric psychopharmacology. Am J Psychiatry. 06. 2005;162(6):1142-1148. [pmid: 15930063].
205 Martin A, Scahill L, Anderson GM, et al. Weight and leptin changes among risperidone-treated youths with autism: 6-month prospective data. Am J Psychiatry. 06. 2004;161(6):1125-1127. [pmid: 15169706].
206 McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med. 08. 1. 2002;347(5):314-321. [pmid: 12151468].
207 Arnold LE, Vitiello B, McDougle C, et al. Parent-defined target symptoms respond to risperidone in RUPP autism study: customer approach to clinical trials. J Am Acad Child Adolesc Psychiatry. 12. 2003;42(12):1443-1450. [pmid: 14627879].
208 Williams SK, Scahill L, Vitiello B, et al. Risperidone and adaptive behavior in children with autism. J Am Acad Child Adolesc Psychiatry. 04. 2006;45(4):431-439. [pmid: 16601648].
209 Anderson GM, Scahill L, McCracken JT, et al. Effects of short- and long-term risperidone treatment on prolactin levels in children with autism. Biol Psychiatry. 02. 15. 2007;61(4):545-550. [pmid: 16730335].
210 Pandina GJ, Bossie CA, Youssef E, et al. Risperidone improves behavioral symptoms in children with autism in a randomized, double-blind, placebo-controlled trial. J Autism Dev Disord. 02. 2007;37(2):367-373. [pmid: 17019624].
211 Shea S, Turgay A, Carroll A, et al. Risperidone in the treatment of disruptive behavioral symptoms in children with autistic and other pervasive developmental disorders. Pediatrics. 11. 2004;114(5):e634-41. [pmid: 15492353].
212 Nagaraj R, Singhi P, Malhi P. Risperidone in children with autism: randomized, placebo-controlled, double-blind study. J Child Neurol. 06. 2006;21(6):450-5. [pmid: 16948927].
213 Masi G, Cosenza A, Mucci M, et al. A 3-year naturalistic study of 53 preschool children with pervasive developmental disorders treated with risperidone. J Clin Psychiatry. 09. 2003;64(9):1039-1047. [pmid: 14628979].
214 Correia CT, Almeida JP, Santos PE, et al. Pharmacogenetics of risperidone therapy in autism: association analysis of eight candidate genes with drug efficacy and adverse drug reactions. Pharmacogenomics J. 2009. 12. 8.
215 Marcus RN, Owen R, Kamen L, et al. A placebo-controlled, fixed-dose study of aripiprazole in children and adolescents with irritability associated with autistic disorder. J Am Acad Child Adolesc Psychiatry. 11. 2009;48(11):1110-1109. [pmid: 19797985].
216 Owen R, Sikich L, Marcus RN, et al. Aripiprazole in the treatment of irritability in children and adolescents with autistic disorder. Pediatrics. 12. 2009;124(6):1533-1540. [pmid: 19948625].
217 Akhondzadeh S, Erfani S, Mohammadi MR, et al. Cyproheptadine in the treatment of autistic disorder: a double-blind placebo-controlled trial. J Clin Pharm Ther. 04. 2004;29(2):145-50. [pmid: 15068403].
218 Scahill L, McDougle CJ, Williams SK, et al. Children’s Yale-Brown Obsessive Compulsive Scale modified for pervasive developmental disorders. J Am Acad Child Adolesc Psychiatry. 09. 2006;45(9):1114-1123. [pmid: 16926619].
219 Anderson LT, Campbell M, Grega DM, et al. Haloperidol in the treatment of infantile autism: effects on learning and behavioral symptoms. Am J Psychiatry. 10. 1984;141(10):1195-1202. [pmid: 6385731].
220 Hollander E, Phillips A, Chaplin W, et al. A placebo controlled crossover trial of liquid fluoxetine on repetitive behaviors in childhood and adolescent autism. Neuropsychopharmacology. 03. 2005;30(3):582-589. [pmid: 15602505].
221 DeLong GR, Ritch CR, Burch S. Fluoxetine response in children with autistic spectrum disorders: correlation with familial major affective disorder and intellectual achievement. Dev Med Child Neurol. 10. 2002;44(10):652-659. [pmid: 12418789].
222 King BH, Hollander E, Sikich L, et al. Lack of efficacy of citalopram in children with autism spectrum disorders and high levels of repetitive behavior: citalopram ineffective in children with autism. Arch Gen Psychiatry. 06. 2009;66(6):583-590. [pmid: 19487623].
223 Owley T, Brune CW, Salt J, et al. A pharmacogenetic study of escitalopram in autism spectrum disorders. Autism Res. 02. 2010;3(1):1-7. [pmid: 20020537].
224 Henry CA, Steingard R, Venter J, et al. Treatment outcome and outcome associations in children with pervasive developmental disorders treated with selective serotonin reuptake inhibitors: a chart review. J Child Adolesc Psychopharmacol. 02-04. 2006;16(1–2):187-195. [pmid: 16553539].
225 Geller DA, Biederman J, Stewart SE, et al. Which SSRI? A meta-analysis of pharmacotherapy trials in pediatric obsessive-compulsive disorder. Am J Psychiatry. 11. 2003;160(11):1919-1928. [pmid: 14594734].
226 March JS, Biederman J, Wolkow R, et al. Sertraline in children and adolescents with obsessive-compulsive disorder: a multicenter randomized controlled trial. JAMA. 11. 25. 1998;280(20):1752-176. [pmid: 9842950].
227 Owley T, Walton L, Salt J, et al. An open-label trial of escitalopram in pervasive developmental disorders. J Am Acad Child Adolesc Psychiatry. 04. 2005;44(4):343-348. [pmid: 15782081].
228 Randomized, controlled, crossover trial of methylphenidate in pervasive developmental disorders with hyperactivity. Arch Gen Psychiatry. 11. 2005;62(11):1266-1274. [pmid: 16275814].
229 Posey DJ, Aman MG, McCracken JT, et al. Positive effects of methylphenidate on inattention and hyperactivity in pervasive developmental disorders: an analysis of secondary measures. Biol Psychiatry. 02. 15. 2007;61(4):538-544. [pmid: 17276750].
230 Jahromi LB, Kasari CL, McCracken JT, et al. Positive Effects of Methylphenidate on Social Communication and Self-Regulation in Children with Pervasive Developmental Disorders and Hyperactivity. Journal of Autism and Developmental Disorders. 03. 2009;39(3):395-404. [pmid: 18752063].
231 Nickels K, Katusic SK, Colligan RC, et al. Stimulant medication treatment of target behaviors in children with autism: a population-based study. J Dev Behav Pediatr. 04. 2008;29(2):75-81. [pmid: 18478626].
232 Posey DJ, Puntney JI, Sasher TM, et al. Guanfacine treatment of hyperactivity and inattention in pervasive developmental disorders: a retrospective analysis of 80 cases. J Child Adolesc Psychopharmacol. Summer. 2004;14(2):233-241. [pmid: 15319020].
233 Stigler KA, Desmond LA, Posey DJ, et al. A naturalistic retrospective analysis of psychostimulants in pervasive developmental disorders. J Child Adolesc Psychopharmacol. Spring. 2004;14(1):49-56. [pmid: 15142391].
234 Levy SE, Souders MC, Wray J, et al. Children with autistic spectrum disorders. I: comparison of placebo and single dose of human synthetic secretin. Arch Dis Child. 08. 2003;88(8):731-736. [pmid: 12876177].
235 Molloy CA, Manning-Courtney P, Swayne S, et al. Lack of benefit of intravenous synthetic human secretin in the treatment of autism. J Autism Dev Disord. 12. 2002;32(6):545-551. [pmid: 12553591].
236 Unis AS, Munson JA, Rogers SJ, et al. A randomized, double-blind, placebo-controlled trial of porcine versus synthetic secretin for reducing symptoms of autism. J Am Acad Child Adolesc Psychiatry. 11. 2002;41(11):1315-1321. [pmid: 12410073].
237 Owley T, McMahon W, Cook EH, et al. Multisite, double-blind, placebo-controlled trial of porcine secretin in autism. J Am Acad Child Adolesc Psychiatry. 11. 2001;40(11):1293-1299. [pmid: 11699803].
238 Roberts W, Weaver L, Brian J, et al. Repeated doses of porcine secretin in the treatment of autism: a randomized, placebo-controlled trial. Pediatrics. 05. 2001;107(5):E71. [pmid: 11331721].
239 Coniglio SJ, Lewis JD, Lang C, et al. A randomized, double-blind, placebo-controlled trial of single-dose intravenous secretin as treatment for children with autism. J Pediatr. 05. 2001;138(5):649-655. [pmid: 11343038].
240 Dunn-Geier J, Ho HH, Auersperg E, et al. Effect of secretin on children with autism: a randomized controlled trial. Dev Med Child Neurol. 12. 2000;42(12):796-802. [pmid: 11132252].
241 Chez MG, Buchanan CP, Bagan BT, et al. Secretin and autism: a two-part clinical investigation. J Autism Dev Disord. 04. 2000;30(2):87-94. [pmid: 10832772].
242 Dosman CF, Brian JA, Drmic IE, et al. Children with autism: effect of iron supplementation on sleep and ferritin. Pediatr Neurol. 03. 2007;36(3):152-158. [pmid: 17352947].
243 Mousain-Bosc M, Roche M, Polge A, et al. Improvement of neurobehavioral disorders in children supplemented with magnesium-vitamin B6. II. Pervasive developmental disorder-autism. Magnes Res. 03. 2006;19(1):53-62. [pmid: 16846101].
244 Andersen IM, Kaczmarska J, McGrew SG, et al. Melatonin for insomnia in children with autism spectrum disorders. J Child Neurol. 05. 2008;23(5):482-485. [pmid: 18182647].
245 Evangeliou A, Vlachonikolis I, Mihailidou H, et al. Application of a ketogenic diet in children with autistic behavior: pilot study. J Child Neurol. 02. 2003;18(2):113-118. [pmid: 12693778].
246 Meguid NA, Atta HM, Gouda AS, et al. Role of polyunsaturated fatty acids in the management of Egyptian children with autism. Clin Biochem. 09. 2008;41(13):1044-8. [pmid: 18582451].
247 Chez MG, Buchanan CP, Aimonovitch MC, et al. Double-blind, placebo-controlled study of L-carnosine supplementation in children with autistic spectrum disorders. J Child Neurol. 11. 2002;17(11):833-837. [pmid: 12585724].
248 Kern JK, Miller VS, Cauller PL, et al. Effectiveness of N, N-dimethylglycine in autism and pervasive developmental disorder. J Child Neurol. 03. 2001;16(3):169-173. [pmid: 11305684].
249 Munasinghe SA, Oliff C, Finn J, et al. Digestive Enzyme Supplementation for Autism Spectrum Disorders: A Double-Blind Randomized Controlled Trial. J Autism Dev Disord. 2010. 03. 5.
250 Adams JB, Baral M, Geis E, et al. Safety and efficacy of oral DMSA therapy for children with autism spectrum disorders: part A--medical results. BMC Clin Pharmacol. 2009;9:16. [pmid: 19852789].
251 King BH, Wright DM, Handen BL, et al. Double-blind, placebo-controlled study of amantadine hydrochloride in the treatment of children with autistic disorder. J Am Acad Child Adolesc Psychiatry. 06. 2001;40(6):658-665. [pmid: 11392343].
252 Akhondzadeh S, Tajdar H, Mohammadi MR, et al. A double-blind placebo controlled trial of piracetam added to risperidone in patients with autistic disorder. Child Psychiatry Hum Dev. 09. 2008;39(3):237-245. [pmid: 17929164].
253 Akhondzadeh S, Fallah J, Mohammadi M-R, et al. Double-blind placebo-controlled trial of pentoxifylline added to risperidone: Effects on aberrant behavior in children with autism. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 02. 2010;34(1):32-36. [pmid: 19772883].
254 Rossignol DA, Rossignol LW, Smith S, et al. Hyperbaric treatment for children with autism: a multicenter, randomized, double-blind, controlled trial. BMC Pediatr. 2009;9:21. [pmid: 19284641].
255 Adams JB, Baral M, Geis E, et al. Safety and efficacy of oral DMSA therapy for children with autism spectrum disorders: part B - behavioral results. BMC Clin Pharmacol. 2009;9:17. [pmid: 19852790].
256 Chez MG, Aimonovitch M, Buchanan T, et al. Treating autistic spectrum disorders in children: utility of the cholinesterase inhibitor rivastigmine tartrate. J Child Neurol. 03. 2004;19(3):165-169. [pmid: 15119476].
257 Chez MG, Buchanan TM, Becker M, et al. Donepezil hydrochloride: A double-blind study in autistic children. Journal of Pediatric Neurology. 10-12. 2003;1(2):83-88.
258 Yoder PJ. Predicting lexical density growth rate in young children with autism spectrum disorders. Am J Speech Lang Pathol. 11. 2006;15(4):378-388. [pmid: 17102148].
259 Yoder P, Stone WL. A randomized comparison of the effect of two prelinguistic communication interventions on the acquisition of spoken communication in preschoolers with ASD. J Speech Lang Hear Res. 08. 2006;49(4):698-711. [pmid: 16908870].
260 Yoder P, Stone WL. Randomized comparison of two communication interventions for preschoolers with autism spectrum disorders. J Consult Clin Psychol. 06. 2006;74(3):426-435. [pmid: 16822100].
261 Yoder PJ, Lieberman RG. Brief Report: Randomized Test of the Efficacy of Picture Exchange Communication System on Highly Generalized Picture Exchanges in Children with ASD. J Autism Dev Disord. 2009. 11. 11.
262 Carr D, Felce J. The effects of PECS teaching to Phase III on the communicative interactions between children with autism and their teachers. J Autism Dev Disord. 04. 2007;37(4):724-737. [pmid: 17006780].
263 Howlin P, Gordon RK, Pasco G, et al. The effectiveness of Picture Exchange Communication System (PECS) training for teachers of children with autism: a pragmatic, group randomised controlled trial. J Child Psychol Psychiatry. 05. 2007;48(5):473-481. [pmid: 17501728].
264 Magiati I, Howlin P. A pilot evaluation study of the Picture Exchange Communication System (PECS) for children with autistic spectrum disorders. Autism. 09. 2003;7(3):297-320. [pmid: 14516062].
265 Carr D, Felce J. Teaching picture-to-object relations in picture-based requesting by children with autism: a comparison between error prevention and error correction teaching procedures. J Intellect Disabil Res. 04. 2008;52(Pt 4):309-317. [pmid: 18339093].
266 Fazlioglu Y, Baran G. A sensory integration therapy program on sensory problems for children with autism. Percept Mot Skills. 04. 2008;106(2):415-422. [pmid: 18556898].
267 Jung KE, Lee HJ, Lee YS, et al. Efficacy of sensory integration treatment based on virtual reality - Tangible interaction for children with autism. Annual Review of CyberTherapy and Telemedicine. 2006;4:45-49.
268 Jung K-E, Lee H-J, Lee Y-S, et al. The Application of a Sensory Integration Treatment Based on Virtual Reality-Tangible Interaction for Children with Autistic Spectrum Disorder. PsychNology Journal. Special Issue: Emerging Trends in Cybertherapy. 2006;4(2):145-159.
269 Mudford OC, Cross BA, Breen S, et al. Auditory integration training for children with autism: no behavioral benefits detected. Am J Ment Retard. 03. 2000;105(2):118-129. [pmid: 10755175].
270 Corbett BA, Shickman K, Ferrer E. Brief report: the effects of Tomatis sound therapy on language in children with autism. J Autism Dev Disord. 03. 2008;38(3):562-566. [pmid: 17610057].
271 Kim J, Wigram T, Gold C. The effects of improvisational music therapy on joint attention behaviors in autistic children: a randomized controlled study. J Autism Dev Disord. 10. 2008;38(9):1758-1766. [pmid: 18592368].
272 Sams MJ, Fortney EV, Willenbring S. Occupational therapy incorporating animals for children with autism: A pilot investigation. Am J Occup Ther. 05-06. 2006;60(3):268-274. [pmid: 16776394].
273 Carmody DP, Kaplan M, Gaydos AM. Spatial orientation adjustments in children with autism in Hong Kong. Child Psychiatry Hum Dev. Spring. 2001;31(3):233-247. [pmid: 11196013].
274 Hartshorn K, Olds L, Field T, et al. Creative movement therapy benefits children with autism. Early Child Development and Care. 2001;166:1-5.
275 Ludlow AK, Wilkins AJ, Heaton P. Colored Overlays Enhance Visual Perceptual Performance in Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 07-09. 2008;2(3):498-515.
276 Bass MM, Duchowny CA, Llabre MM. The effect of therapeutic horseback riding on social functioning in children with autism. J Autism Dev Disord. 09. 2009;39(9):1261-1267. [pmid: 19350376].
277 Ludlow AK, Wilkins AJ, Heaton P. The effect of coloured overlays on reading ability in children with autism. J Autism Dev Disord. 05. 2006;36(4):507-516. [pmid: 16598434].
278 Laud RB, Girolami PA, Boscoe JH, et al. Treatment outcomes for severe feeding problems in children with autism spectrum disorder. Behav Modif. 09. 2009;33(5):520-536. [pmid: 19748900].
279 Pan CY. Effects of water exercise swimming program on aquatic skills and social behaviors in children with autism spectrum disorders. Autism. 01. 2010;14(1):9-28. [pmid: 20124502].
280 Allam H, ElDine NG, Helmy G. Scalp acupuncture effect on language development in children with autism: a pilot study. J Altern Complement Med. 03. 2008;14(2):109-114. [pmid: 18315511].
281 Chan AS, Cheung MC, Sze SL, et al. Seven-star needle stimulation improves language and social interaction of children with autistic spectrum disorders. Am J Chin Med. 2009;37(3):495-504. [pmid: 19606510].
282 Silva LM, Ayres R, Schalock M. Outcomes of a pilot training program in a qigong massage intervention for young children with autism. Am J Occup Ther. 09-10. 2008;62(5):538-546. [pmid: 18826014].
283 Silva LM, Cignolini A, Warren R, et al. Improvement in sensory impairment and social interaction in young children with autism following treatment with an original Qigong massage methodology. Am J Chin Med. 2007;35(3):393-406. [pmid: 17597498].
284 Escalona A, Field T, Singer-Strunck R, et al. Brief report: improvements in the behavior of children with autism following massage therapy. J Autism Dev Disord. 10. 2001;31(5):513-516. [pmid: 11794416].
285 Silva LM, Schalock M, Ayres R, et al. Qigong massage treatment for sensory and self-regulation problems in young children with autism: a randomized controlled trial. Am J Occup Ther. 07-08. 2009;63(4):423-432. [pmid: 19708471].
286 Piravej K, Tangtrongchitr P, Chandarasiri P, et al. Effects of Thai traditional massage on autistic children’s behavior. J Altern Complement Med. 12. 2009;15(12):1355-1361. [pmid: 20001837].
287 Sallows GO, Graupner TD. Intensive behavioral treatment for children with autism: four-year outcome and predictors. Am J Ment Retard. 11. 2005;110(6):417-438. [pmid: 16212446].
288 Bryson SE, Zwaigenbaum L, Brian J, et al. A prospective case series of high-risk infants who developed autism. J Autism Dev Disord. 01. 2007;37(1):12-24. [pmid: 17211728].
289 Cross S, Kim SJ, Weiss LA, et al. Molecular genetics of the platelet serotonin system in first-degree relatives of patients with autism. Neuropsychopharmacology. 01. 2008;33(2):353-360. [pmid: 17406648].
290 Dawson G, Rogers S, Munson J, et al. Randomized, Controlled Trial of an Intervention for Toddlers With Autism: The Early Start Denver Model. Pediatrics. 2009. 11. 30.
291 Filipek PA, Accardo PJ, Ashwal S, et al. Practice parameter: screening and diagnosis of autism: report of the Quality Standards Subcommittee of the American Academy of Neurology and the Child Neurology Society. Neurology. 08. 22. 2000;55(4):468-479. [pmid: 10953176].
292 Filipek PA, Accardo PJ, Baranek GT, et al. The screening and diagnosis of autistic spectrum disorders. J Autism Dev Disord. 12. 1999;29(6):439-484. [pmid: 10638459].
293 Stone WL, Lee EB, Ashford L, et al. Can autism be diagnosed accurately in children under 3 years?. J Child Psychol Psychiatry. 02. 1999;40(2):219-226. [pmid: 10188704].
294 Wetherby AM, Woods JJ. Early Social Interaction Project for Children with Autism Spectrum Disorders Beginning in the Second Year of Life: A Preliminary Study. Topics in Early Childhood Special Education. Sum. 2006;26(2):67-82.
295 McConachie H, Randle V, Hammal D, et al. A controlled trial of a training course for parents of children with suspected autism spectrum disorder. J Pediatr. 09. 2005;147(3):335-340. [pmid: 16182672].
296 Spreckley M, Boyd R. Efficacy of Applied Behavioral Intervention in Preschool Children with Autism for Improving Cognitive, Language, and Adaptive Behavior: A Systematic Review and Meta-analysis. J Pediatr. 2008. 10. 22.
297 Special report: early intensive behavioral intervention based on applied behavior analysis among children with autism spectrum disorders. Technol Eval Cent Asses Program Exec Summ. 02. 2009;23(9):1-5.
298 Reichow B, Wolery M. Comprehensive Synthesis of Early Intensive Behavioral Interventions for Young Children with Autism Based on the UCLA Young Autism Project Model. Journal of Autism and Developmental Disorders. 01. 2009;39(1):23-41. [pmid: 18535894].
299 Eldevik S, Hastings RP, Hughes JC, et al. Meta-analysis of Early Intensive Behavioral Intervention for children with autism. J Clin Child Adolesc Psychol. 05. 2009;38(3):439-450. [pmid: 19437303].
300 Mulloy A, Lang R, O’Reilly M, et al. Gluten-Free and Casein-Free Diets in the Treatment of Autism Spectrum Disorders: A Systematic Review. Research in Autism Spectrum Disorders. 07-09. 2010;4(3):328-339.
301 Schlosser RW, Wendt O. Effects of augmentative and alternative communication intervention on speech production in children with autism: a systematic review. Am J Speech Lang Pathol. 08. 2008;17(3):212-230. [pmid: 18663107].
302 Flippin M, Reszka S, Watson LR. Effectiveness of the Picture Exchange Communication System (PECS) on communication and speech for children with autism spectrum disorders: a meta-analysis. Am J Speech Lang Pathol. 05. 2010;19(2):178-195. [pmid: 20181849].
303 Russo NM, Skoe E, Trommer B, et al. Deficient brainstem encoding of pitch in children with Autism Spectrum Disorders. Clin Neurophysiol. 08. 2008;119(8):1720-1731. [pmid: 18558508].
304 Posey DJ, Erickson CA, Stigler KA, et al. The use of selective serotonin reuptake inhibitors in autism and related disorders. J Child Adolesc Psychopharmacol. 02-04. 2006;16(1–2):181-186. [pmid: 16553538].
305 Levy SE, Hyman SL. Use of complementary and alternative treatments for children with autistic spectrum disorders is increasing. Pediatr Ann. 10. 2003;32(10):685-691. [pmid: 14606219].
306 Cognitive-behavior therapy, sertraline, and their combination for children and adolescents with obsessive-compulsive disorder: the Pediatric OCD Treatment Study (POTS) randomized controlled trial. JAMA. 10. 27. 2004;292(16):1969-1976. [pmid: 15507582].
307 March J, Silva S, Petrycki S, et al. Fluoxetine, cognitive-behavioral therapy, and their combination for adolescents with depression: Treatment for Adolescents With Depression Study (TADS) randomized controlled trial. JAMA. 08. 18. 2004;292(7):807-820. [pmid: 15315995].
308 Walkup JT, Albano AM, Piacentini J, et al. Cognitive behavioral therapy, sertraline, or a combination in childhood anxiety. N Engl J Med. 12. 25. 2008;359(26):2753-2766. [pmid: 18974308].
309 Davis M, Ressler K, Rothbaum BO, et al. Effects of D-cycloserine on extinction: translation from preclinical to clinical work. Biol Psychiatry. 08. 15. 2006;60(4):369-375. [pmid: 16919524].