# Executive Summary

## Background

Autism spectrum disorders (ASDs) have an estimated prevalence of 1 in 110 children in the United States.1 Disorders within the spectrum include Autistic Disorder, Asperger Syndrome, and Pervasive Developmental Disorder, Not Otherwise Specified (PDD-NOS).

Individuals with ASDs have impaired social interaction, behavior, and communication2 including lack of reciprocal social interaction and joint attention (i.e., the ability to use nonverbal means such as pointing to direct others’ attention to something in which the child is interested); dysfunctional or absent communication and language skills; lack of spontaneous or pretend play; intense preoccupation with particular concepts or things; and repetitive behaviors or movements.3–5 Children with ASDs may also have impaired cognitive skills and sensory perception.1,2

Treatment for ASDs focuses on improving core deficits in social communication, as well as addressing challenging behaviors to improve functional engagement in developmentally appropriate activities.4 In addition to addressing core deficits, treatments are provided for difficulties associated with the disorder (anxiety, attention difficulties, sensory difficulties, etc.). Individual goals for treatment vary for different children and may include combinations of therapies.4

## Objectives

Population. We focused this review on children ages 2–12 with ASDs for Key Questions (KQs) 1–6 and children under age 2 at risk of ASD for KQ7.

Interventions. Treatments included behavioral, educational, medical, allied health, and complementary and alternative medicine (CAM) interventions (Table A).

Table A Description of interventions

Intervention category | Brief description
Behavioral | - Interventions in the early intensive behavioral and developmental category have their basis in or draw from principles of applied behavior analysis (ABA), with differences in methods and setting. We included in this category two intensive interventions with published treatment manuals (manualized interventions): the University of California, Los Angeles/Lovaas model and the Early Start Denver Model (ESDM). We also included in this category interventions utilizing intensive ABA principles in a similar fashion to the UCLA/Lovaas model. Frequently these approaches included variations of the UCLA/Lovaas model, but we review this literature together because of overall similarities. An additional set of interventions included in this category use ABA principles to focus on teaching pivotal behaviors to parents rather than on directed intensive intervention.; - Social skills interventions focus on facilitating social interactions and may include peer training and social stories.; - Play- or interaction-focused interventions use interactions between children and parents or researchers to affect outcomes, including imitation, joint attention skills, or children’s ability to engage in symbolic play.; - Interventions focused on commonly associated behaviors attempt to ameliorate symptoms such as anxiety, often present in ASDs, using techniques including cognitive behavioral therapy (CBT) and parent training focused on challenging behaviors.; - Additional interventions include techniques such as sleep workshops and neurofeedback.
Educational | - Educational interventions focus on improving educational and cognitive skills. They are intended to be administered primarily in educational settings and also include studies for which the educational arm was most clearly categorized.; - Some interventions in educational settings are based on principles of ABA and may be intensive, but no interventions in this category used the UCLA/Lovaas or ESDM manualized treatments.
Medical and related interventions | - Medical and related interventions are those that include the administration of external substances to the body to treat symptoms of ASDs.; - Medical treatments for ASD symptoms comprise a variety of pharmacologic agents, including antipsychotics, psychostimulants, and serotonin reuptake inhibitors (SRIs), and modalities such as therapeutic diets, supplements, hormonal supplements, immunoglobulin, hyperbaric oxygen, and chelating agents.
Allied health | - Allied health interventions include therapies typically provided by speech/language, occupational, and physical therapists, including auditory and sensory integration, music therapy, and language therapies (e.g., Picture Exchange Communication System [PECS]).
CAM | - CAM interventions include acupuncture and massage.

Note: ABA = applied behavior analysis; ASDs = autism spectrum disorders; CAM = complementary and alternative medicine; CBT = cognitive behavioral therapy; ESDM = Early Start Denver Model; PECS = Picture Exchange Communication System; SRI = serotonin reuptake inhibitor; UCLA = University of California, Los Angeles

Comparators. Comparators included no treatment, placebo, and comparative interventions or combinations of interventions.

Outcomes. Outcomes included changes in core ASD symptoms and in commonly associated symptoms (Figure A).

## Key Questions

Key questions were:

KQ1. Among children ages 2–12 with ASDs, what are the short- and long-term effects of available behavioral, educational, family, medical, allied health, or CAM treatment approaches? Specifically,

KQ1a What are the effects on core symptoms (e.g., social deficits, communication deficits, and repetitive behaviors) in the short term (≤6 months)?
KQ1b What are the effects on commonly associated symptoms (e.g., motor, sensory, medical, mood/anxiety, irritability, and hyperactivity) in the short term (≤6 months)?
KQ1c What are the longer term effects (>6 months) on core symptoms (e.g., social deficits, communication deficits, and repetitive behaviors)?
KQ1d What are the longer term effects (>6 months) on commonly associated symptoms (e.g., motor, sensory, medical, mood/anxiety, irritability, and hyperactivity)?

KQ2. Among children ages 2–12, what are the modifiers of outcome for different treatments or approaches?

KQ2a Is the effectiveness of the therapies reviewed affected by the frequency, duration, and intensity of the intervention?
KQ2b Is the effectiveness of the therapies reviewed affected by the training and/or experience of the individual providing the therapy?
KQ2c What characteristics, if any, of the child modify the effectiveness of the therapies reviewed?
KQ2d What characteristics, if any, of the family modify the effectiveness of the therapies reviewed?

KQ3. Are there any identifiable changes early in the treatment phase that predict treatment outcomes?

KQ4. What is the evidence that effects measured at the end of the treatment phase predict long-term functional outcomes?

KQ5. What is the evidence that specific intervention effects measured in the treatment context generalize to other contexts (e.g., people, places, materials)?

KQ6. What evidence supports specific components of treatment as driving outcomes, either within a single treatment or across treatments?

KQ7. What evidence supports the use of a specific treatment approach in children under the age of 2 who are at high risk of developing autism based upon behavioral, medical, or genetic risk factors?

## Analytic Framework

Figure A Analytic framework for therapies for children with ASDs

Figure A is the analytic framework to guide the literature review of autism spectrum disorders (ASDs). It summarizes the process by which families of children with ASDs make and modify treatment choices. Circled numbers indicate the Key Questions (KQs), and their placement indicates the points in the treatment process where they are likely to arise. Treatments for ASD include behavioral, educational, medical, allied health, and complementary and alternative medicine interventions (KQ1). The populations of interest are patients 2–12 years diagnosed with ASD (for KQs 1–6) and patients under 2 at risk for diagnosis of ASD (KQ7). Therapeutic modalities are chosen (KQ6). KQ3 involves identifiable changes early in the treatment process. KQ4 involves the relationship between targeted outcomes in the treatment setting and functional outcomes outside the treatment setting. KQ5 involves generalization of interventions to other contexts. KQ2, modifiers of outcome, is related to individual and therapeutic characteristics. Target outcomes in the treatment setting are language communication, academic skill development, maladaptive behaviors, distress, adaptive skills development, and social skills/interaction. Functional outcomes outside the treatment setting are adaptive independence, academic engagement/attainment, psychological well-being, and psychosocial adaptation. Long-term outcomes include quality of life, social integration, and appropriate level of independence. Harms are also considered.

The analytic framework (Figure A) summarizes the process by which families of children with ASDs make and modify treatment choices. Treatment choices are affected by many factors that relate to the care available. Treatment effectiveness may also be affected by factors related to the child (e.g., age, IQ) or the context of care. Ideally, treatment effects are seen both in the short term in clinical changes and in longer term or functional outcomes. Eventual outcomes of interest include adaptive independence appropriate to the abilities of the specific child, psychological well-being, appropriate academic engagement, and psychosocial adaptation. The circled numbers represent the report’s key questions; their placement indicates the points in the treatment process in which they are likely to arise.

## Methods

### Input From Stakeholders

The topic was nominated in a public process. With key informant input, we drafted initial key questions and, after approval from the Agency for Healthcare Research and Quality (AHRQ), they were posted to a public Web site for public comment. Using public input, we drafted final key questions, which were approved by AHRQ. We convened a Technical Expert Panel to provide input during the project on issues such as setting inclusion/exclusion criteria and assessing study quality. In addition, the draft report was peer reviewed and made available for public comment.

### Data Sources and Selection

We searched three databases: MEDLINE^®^ via the PubMed interface, PsycINFO, and the Education Resources Information Center (ERIC) database. We hand-searched reference lists of included articles and recent reviews for additional studies. We excluded studies that:

- Were not published in English.
- Did not report information pertinent to the key questions.
- Were published prior to the year 2000, the time of the revision of the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV)2 and widespread implementation of gold standard assessment tools, including the Autism Diagnostic Observation Schedule (ADOS)6 and the Autism Diagnostic Interview – Revised (ADI-R).7
- Were not original research.
- Did not present aggregated results (i.e., only presented data for each individual participant) or presented graphical data only.

We also excluded studies with fewer than 10 total participants for studies of behavioral, educational, allied health, or CAM interventions; or fewer than 30 total participants for medical studies. We believed that, given the greater risk associated with the use of medical interventions, it was appropriate to require a larger sample size to accrue adequate data on safety and tolerability as well as efficacy. In addition, most studies of medical interventions for ASDs with fewer than 30 subjects report preliminary results that are replaced by later, larger studies.

We accepted any study designs except individual case reports. Our approach to categorizing study designs is presented in Appendix F of the full report.

Two reviewers separately evaluated each abstract. If one reviewer concluded that the article could be eligible, we retained it. Two reviewers independently read the full text of each included article to determine eligibility, with disagreements resolved via third-party adjudication.

### Data Extraction and Quality Assessment

Data extraction. All team members entered information into the evidence table. After initial data extraction, a second team member edited entries for accuracy, completeness, and consistency. In addition to outcomes for treatment effectiveness, we extracted data on harms/adverse effects.

Quality assessment. Two reviewers independently assessed quality (study design, diagnostic approach, participant ascertainment, intervention characteristics, outcomes measurement, and statistical analysis), with differences resolved though discussion, review of the publications, and consensus with the team. We rated studies as good, fair, or poor quality and retained poor studies as part of the evidence base discussed in this review. More information about our quality assessment methods is in the full report.

### Data Synthesis and Analysis

Evidence synthesis. We used summary tables to synthesize studies that included comparison groups and summarized the results qualitatively.

Strength of evidence. The degree of confidence that the observed effect of an intervention is unlikely to change is presented as strength of evidence, and it can be regarded as insufficient, low, moderate, or high. Strength of evidence describes the adequacy of the current research, in quantity and quality, and the degree to which the entire body of current research provides a consistent and precise estimate of effect. We established methods for assessing the strength of evidence based on the Evidence-based Practice Centers Methods Guide for Effectiveness and Comparative Effectiveness Reviews.8 Details of our strength-of-evidence methods are in Chapter 2 of the full report.

## Results

Our searches retrieved 4,120 nonduplicate citations. We included 183 articles, representing 159 unique studies, in the review (Figure B). The full report details reasons for exclusion.

Figure B Disposition of articles addressing therapies for children with ASDs

a The total number of articles in the exclusion categories exceeds the number of articles excluded because most of the articles fit into multiple exclusion categories.

Note: KQ = key question.

Searches retrieved 4.120 nonduplicate citations (3,779 from the literature search and 341 from the hand search/gray literature search). Of these, 3,406 articles were excluded for various reasons. Of the 714 full-text articles reviewed, 531 were excluded. The reasons for exclusion were: participants not in age range (293), not original research (135), ineligible study size (406), not relevent to Key Questions (KQs) (285), unable to abstract data (16). The total number of articles in the exclusion categories exceeds the number of articles excluded because most of the articles fit into multiple exclusion categories. The 183 unique full-text articles included in the review comprised 159 unique studies. The numbers of articles pertaining to each KQ are: KQ1, 154; KQ2, 38; KQ3, 4; KQ4, 01; KQ5, 17; KQ6, 0; KQ7, 4.

### KQ1 Outcomes of Therapies for ASDs in Children Ages 2–12

Behavioral interventions. We identified 78 unique behavioral studies.9–92 Early intensive behavioral and developmental intervention may improve core areas of deficit for individuals with ASDs; however, few randomized controlled trials (RCTs) of sufficient quality have been conducted, no studies directly compare effects of different treatment approaches, and little evidence of practical effectiveness or feasibility exists.

Within this category, studies of UCLA/Lovaas-based interventions report greater improvements in cognitive performance, language skills, and adaptive behavior skills than broadly defined eclectic treatments available in the community.11,13,19,23,35,36,40 However, strength of evidence is currently low. Further, not all children receiving intensive intervention demonstrate rapid gains, and many children continue to display substantial impairment.23 Although positive results are reported for the effects of intensive interventions that use a developmental framework, such as the Early Start Denver Model (ESDM),37 evidence for this type of intervention is currently insufficient because few studies have been published to date.

Less intensive interventions focusing on providing parent training for bolstering social communication skills and managing challenging behaviors have been associated in individual studies with short-term gains in social communication and language use.17,18,46 The current evidence base for such treatment remains insufficient, with current research lacking consistency in interventions and outcomes assessed.

Although all of the studies of social skills interventions reported some positive results,47–62 most have not included objective observations of the extent to which improvements in social skills generalize and are maintained within everyday peer interactions. Strength of evidence is insufficient to assess effects of social skills training on core autism outcomes for older children or play- and interaction-based approaches for younger children.

Several studies suggest that interventions based on cognitive behavioral therapy are effective in reducing anxiety symptoms.79–82 Strength of evidence for these interventions, however, is insufficient pending further replication.

Educational interventions. We identified 15 unique studies of educational interventions meeting our inclusion criteria.93–108 Most research on the Treatment and Education of Autistic and Communication related handicapped CHildren (TEACCH) program was conducted prior to the date cutoff for our review. Newer studies continue to report improvements among children in motor, eye-hand coordination, and cognitive measures.94,96 The strength of evidence for TEACCH, as well as broad-based and computer-based educational approaches included in this category,106–108 to affect any individual outcomes is insufficient because there are too few studies and they are inconsistent in outcomes measured.

Medical and related interventions. We identified 42 unique studies in the medical literature,109–115,116,117–161 of which 27 were RCTs.109–120,122–124,126,128,131–133,137–143,145–152,159–161 Although no current medical interventions demonstrate clear benefit for social or communication symptoms, a few medications show benefit for repetitive behaviors or associated symptoms.

The clearest evidence favors the use of medications to address challenging behaviors. The antipsychotics risperidone and aripiprazole each have at least two RCTs demonstrating improvement in a parent-reported measure of challenging behavior.109–120,122,123 A parent-reported hyperactivity and noncompliance measure also showed significant improvement. In addition, repetitive behavior showed improvement with both risperidone and aripiprazole. Both medications also cause significant side effects, however, including marked weight gain, sedation, and risk of extrapyramidal symptoms (side effects, including muscle stiffness or tremor, that occur in individuals taking antipsychotic medications). These side effects limit use of these drugs to patients with severe impairment or risk of injury.

We rated the strength of evidence as high for the adverse effects of both medications, moderate for the ability of risperidone to affect challenging behaviors, and high for aripiprazole’s effects on challenging behaviors.

Allied health. The allied health interventions reviewed here were varied and reported in 17 unique studies.162–184 The research provided little support for their use. Specifically, all studies of sensory integration and music therapy were of poor quality, and two fair-quality studies of auditory integration showed no improvement associated with treatment.173,174 Language and communication interventions (Picture Exchange Communication System [PECS] and Responsive Education and Prelinguistic Milieu Training [RPMT]) demonstrated short-term improvement in word acquisition without effect durability, and should be studied further.162–165 No other allied health interventions had adequate research to assess the strength of evidence.

CAM. Evidence for CAM interventions is insufficient for assessing outcomes.185–191

### KQ2 Modifiers of Treatment Outcomes

With rare exceptions, 163, 164, 192 few studies are designed or powered to identify modifiers of treatment effect. Although we sought studies of treatment modifiers, only one included study actually demonstrated true treatment modifiers based on appropriate study design and statistical analysis.163, 164 One other study 192 was designed to examine the role of provider on outcomes but showed no difference, possibly because it was underpowered to do so.

This first study163 included an analysis of initial characteristics of the children, demonstrating that children who were low in initial object exploration benefited more from RPMT, which explicitly teaches play with objects, while children who were relatively high in initial object exploration demonstrated more benefit from PECS. An additional analysis164 showed greater increases in generalized turn-taking and initiating joint attention in the RPMT group than in PECS. The increased benefit in joint attention for RPMT was seen only in children who began the study with at least seven acts of joint attention.

One study^192^ explicitly sought to examine the impact of provider (parent vs. professional) using similar interventions in an RCT. The study did not show a difference in outcomes for children receiving the UCLA/Lovaas protocol-based intervention in a clinical setting vs. at home from highly trained parents.

Other studies identified potential correlates that warrant further study. Modifiers with potential for further investigation but with currently conflicting data included pretreatment IQ and language skills, and age of initiation of treatment (with earlier age potentially associated with better outcomes). Social responsiveness and imitation skills have been suggested as skills that may correlate with improved treatment response in UCLA/Lovaas treatment,^192^ whereas “aloof” subtypes of ASDs may be associated with less robust changes in IQ.16 Other studies have seen specific improvement in children with PDD-NOS vs. Autistic Disorder diagnoses,23 which may be indicative of baseline symptom differences. However, many other studies have failed to find a relationship between autism symptoms and treatment response.

### KQ3 Early Results in the Treatment Phase That Predict Outcomes

The literature offers almost no information about specific observations of children that might be made early in treatment to predict long-term outcomes. Some evidence suggests that changes in IQ over the first year of either UCLA/Lovaas-based or ESDM intervention predicts, or accounts for, longer term change in IQ.37,^192^ However, findings also suggest that although gains in the cognitive domain might be identified primarily within the first year of treatment, changes in adaptive behavior in response to these same interventions may occur over a longer timeframe,19,37,45,^192^ if they occur at all.13

### KQ4 End-of-Treatment Effects That Predict Outcomes

One study specifically addressed end-of-treatment effects to predict longer range outcomes. The feasibility of such studies was established in this language study, which reported outcomes 12 months postintervention.65,66

### KQ5 Generalization of Treatment Effects

Few studies measured generalization of effects seen in treatment conditions to either different conditions or different locations. Among behavioral studies, those of treatments for commonly associated conditions, such as anxiety, employed outcomes assessment outside the therapeutic environment, with positive results observed. However, in most cases, outcomes are parent reported and not confirmed by direct observation.

For medical studies, data across classes of medications are likely to be transferable outside of the clinic setting, primarily because the outcome measures used in these studies rely on parent report of the subjects’ behavior in the home or other settings and are augmented in some studies by teacher report.

### KQ6 Drivers of Treatment Effects

No studies were identified to answer this question.

### KQ7 Treatment Approaches in Children Under Age 2 at Risk for ASDs

Research on very young children is preliminary, with four studies identified.15,34,37,42 One good-quality RCT suggested benefit from the use of ESDM in young children,37 with improvements in adaptive behavior, language, and cognitive outcomes. Diagnostic shifts within the autism spectrum were reported in close to 30 percent of children but were not associated with clinically significant improvements in ADOS severity scores or other measures.

## Discussion

### Key Findings

In the behavioral literature, some evidence supports early and intensive behavioral and developmental intervention, including intensive approaches (provided >30 hours per week) and comprehensive approaches (addressing numerous areas of functioning). These included a UCLA/Lovaas-focused approach and developmentally focused ESDM approach.23,37 Both approaches were associated with greater improvements in cognitive performance, language skills, and adaptive behavior skills compared with broadly defined eclectic treatments in subgroups of children, although the strength of evidence (confidence in the estimate) is low pending replication of the available studies.

Not all children receiving such interventions demonstrate rapid gains. Some data suggest that many children continue to display prominent areas of impairment and that subgroups may account for a majority of the change within certain samples.23 No studies directly compare effects of different treatment approaches (for example, there are no direct comparisons of UCLA/Lovaas and ESDM) and little evidence of practical effectiveness or feasibility beyond research studies exists, so questions remain about whether reported findings would be observed on a larger scale within communities. Furthermore, existing studies have used small samples, different treatment approaches and duration, and different outcome measurements. Nonetheless, improvements occur in some aspects of language, cognitive ability, adaptive behavior, challenging behaviors, and potentially, educational attainment, for some children.

Strength of evidence is insufficient for the effects of social skills training for older children and for play- and interaction-based approaches for younger children. Cognitive behavioral therapy (CBT) for associated conditions such as anxiety also has insufficient strength of evidence supporting positive outcomes.

The strength of evidence is insufficient to provide confidence in observed improvements in cognitive outcomes with educational interventions, including the TEACCH intervention, and there is insufficient evidence for broad-based educational approaches, often based on applied behavior analysis (ABA) principles and computer-based approaches.

A few medications show benefit for repetitive behaviors or associated symptoms, with the clearest evidence favoring risperidone and aripiprazole, both studied in RCTs and showing evidence of improvement in problem and repetitive behavior. Significant side effect profiles, however, make it clear that although these drugs are efficacious, caution is warranted regarding their use in patients without severe impairments or risk of injury.

A few other medical interventions show some promise for future research, including serotonin reuptake inhibitors (SRIs),128–130 methylphenidate,131–134,136 omega 3 fatty acids,154 and melatonin.153 Others, including secretin,137–144 are clearly not efficacious and warrant no further study.

Evidence is insufficient at this time to support the use of sensory or auditory integration, insufficient for speech and language interventions, and insufficient for CAM approaches.

### Applicability of Evidence

By definition, ASDs are heterogeneous. Characterizing a “typical” child with an ASD is not possible, although certain symptoms are central to the range of children within the autism spectrum. Individual therapies are developed and tested to ameliorate specific symptoms or groups of symptoms, often in a fairly circumscribed subset of children.

Behavioral interventions. Studies of early intensive behavioral and developmental interventions were conducted primarily in preschool and young children (typically children initially ages 2–7 years). Questions remain about how these approaches apply to and benefit younger children (under 2) at risk for ASD. The cognitive, language, and adaptive behavior profiles of participants included in these studies were generally in line with those typically seen in young children with ASD. Participants typically had substantial impairment or delay, but some children had less early cognitive/language impairment.

The range of approaches studied may not always match what is available in practice—that is, either the studies were often conducted in highly controlled environments (e.g., university-supported intervention trials) or the actual methodology was not well described (i.e., approaches lacking treatment manuals). Thus, individuals wishing to infer the potential results of clinical practice based on the available research need to assess carefully the degree to which the study methods matched those available and used in practice.

Most studies of social skills interventions targeted children of elementary school age (6–13 years old). Most also excluded children with IQs below 60. Therefore, evidence on social skills interventions is likely applicable only to older, higher functioning children. Similarly, CBT for commonly associated conditions was targeted toward older children who were higher functioning. The effectiveness of both of these types of interventions in other groups of children with ASDs is currently unknown.

Medical and related interventions. In the medical literature, study participants were generally recruited from non-primary-care populations. Such individuals’ parents may be seeking a higher level of care than is the case for the broader population of children with ASDs, based on more severe or acute symptoms, including aggression or other challenging behaviors. Most studies of medical interventions targeted elementary-school-age and older children with autism, with little data on the treatment of younger children. Some studies also expanded their inclusion criteria to include children with Asperger syndrome or PDD-NOS.

### Gaps in the Evidence and Methodologic Concerns

Roughly 40 percent of studies in this review failed to use a comparison group. This lack of comparison groups presents substantial challenges for assessing effectiveness at a population level or for conducting comparative effectiveness research.

Studies without a comparison group with at least 10 children with ASDs were included in the review. Single-subject design studies were not excluded on the basis of their design; however, the majority of these studies do not include at least 10 participants and are therefore not represented in the review. Single-subject design studies can be helpful in assessing response to treatment in very short timeframes and under very tightly controlled circumstances, but they typically do not provide information on longer term or functional outcomes. They are useful in serving as demonstration projects, yielding initial evidence that an intervention merits further study, and in the clinical environment, they can be useful in identifying whether a particular approach to treatment is likely to be helpful for a specific child. Our goal was to identify and review the best evidence for assessing the effectiveness of therapies for children with ASDs, with an eye toward utility in the clinical setting and for the larger population of children with ASDs. By definition, “populations” in single-subject design studies are likely to be idiosyncratic and therefore unlikely to provide information that is generalizable.

Even in studies with a comparison group, sample size is frequently insufficient to draw conclusions. Larger multisite trials are needed across all treatment types. A few studies used comparison groups that were inappropriate for observing group differences in treatment effect (e.g., comparing treatment effects in children with autism to the effects of the treatment in typically developing peers or to children with a different developmental disorder). For those studies we could use only the pre-post case series data available in the group with autism, limiting the ability to comment on effectiveness.

We encourage investigators to provide adequate detail as they describe their interventions to allow for replicable research. Ideally, investigators publish the treatment manuals they develop, which are then referenced in later research, but many studies made general references to their use of an underlying approach (e.g., ABA) without specifying the ways in which they used or modified the technique. Lack of detail about the intervention makes it difficult to assess the applicability of individual studies, to synthesize groups of studies, or to replicate studies.

Characterization of the study population was often inadequate, with 125 of 159 studies failing to use or report gold standard diagnostic measures (clinical DSM-IV-based diagnosis plus ADI and/or ADOS). Because ASDs are spectrum disorders, it is difficult to assess the applicability of interventions when the population in which they were studied is poorly defined or described.

We identified more than 100 distinct outcome measures used in this literature base, not accounting for subscales of many. The use of so many and such disparate outcome measures makes it nearly impossible to synthesize the effectiveness of the interventions. We recommend a consistent set of rigorously evaluated outcome measures specific to each intended target of treatment to move comparative effectiveness research forward and to provide a sense of expected outcomes of the interventions. At the same time, the means for assessing outcomes should include increased focus on use of observers masked to the intervention status of the participant. When some outcomes are measured in a masked fashion but others not, evaluators should place more emphasis on those that are masked.

We noted a strong tendency for authors to present data on numerous outcomes without adjusting for multiple comparisons. Investigators also failed to report the outcome that was the primary outcome of a priori interest and on which, presumably, they based sample-size calculations (when these calculations were present). This may suggest the presence of selective reporting. We attempted to identify a primary intended outcome in the papers, but in almost all cases we were unable to do so.

Duration of treatment and followup was generally short. Few studies provided data on long-term outcomes after cessation of treatment. Future studies should extend the followup period and assess the degree to which outcomes are durable. Few studies adequately accounted for concomitant interventions that might confound observed effectiveness. Accounting for concomitant interventions should be standardized in future research.

### Areas for Future Research

A critical area for further research is identifying which children are likely to benefit from particular interventions. To date, studies have failed to characterize adequately the subpopulation of children who experience positive response to intervention, although it is clear that positive outcomes are more prominent in some children than in others. One powerfully replicated finding in the available behavioral literature is that not all children receiving early intensive intervention demonstrate robust gains, and many children continue to display prominent areas of impairment. Dramatic improvements are observed in a subset of children, and mild improvements in terms of standardized outcomes are seen in others. This fact may translate into meaningful improvements in quality of life for some children and family members, suggesting that early intensive approaches have significant potential but require further research.

Behavioral interventions by their nature often employ multiple components, and data on whether specific functional components of the interventions drive effectiveness are currently unavailable. Component analyses in this field would be productive for refining intervention approaches and for assessing applicability and generalizability of the results.

Health services research on feasibility and accessibility is currently lacking, and given the growing number of children diagnosed with an autism spectrum disorder, it is needed. A few studies in this literature made preliminary strides in addressing these issues, but studies that specifically measure the role of setting, provider, and other factors would strongly benefit our ability to inform implementation practices. In line with this need, we recommend future consideration of the ways in which the cultural context of the child and family may affect the applicability or effectiveness of specific interventions.

The medical literature lacks properly designed, appropriately powered RCTs of a number of interventions that have been inadequately studied to date. Some of the strongest studies to support the use of medical interventions have been funded by pharmaceutical companies or device manufacturers that profit from the treatment. Certainly, the NIH (National Institutes of Health) has funded some large-scale studies of a few medical interventions, but publicly funded studies of medications for ASDs are few and more are warranted.

Also lacking in the literature are comparisons of medical interventions with behavioral interventions and combinations of the two, despite the fact that most children are undergoing multiple concurrent treatments. Harms data are also typically not reported in nonmedical studies, although potential harms of behavioral and other interventions should not be discounted.

In sum, while some therapies hold promise and warrant further study, substantial needs exist for continuing improvements in methodologic rigor in the field and for larger, potentially multisite studies of existing interventions. New studies should better characterize children, both phenotypically and genotypically, to move toward personalization of treatments for improved outcomes.

## References

1 Prevalence of the Autism Spectrum Disorders (ASDs) in Multiple Areas of the United States, 2004 and 2006. Atlanta. Centers for Disease Control and Prevention. 2009.
2 Diagnostic and Statistical Manual of Mental Disorders. IV ed. Washington DC. American Psychiatric Association. 2000.
3 Zwaigenbaum L, Bryson S, Lord C, et al. Clinical assessment and management of toddlers with suspected autism spectrum disorder: insights from studies of high-risk infants. Pediatrics. 05. 2009;123(5):1383-1391. [pmid: 19403506].
4 Myers SM, Johnson CP. Management of children with autism spectrum disorders. Pediatrics. 11. 2007;120(5):1162-1182. [pmid: 17967921].
5 Myers SM. Management of autism spectrum disorders in primary care. Pediatr Ann. 01. 2009;38(1):42-49. [pmid: 19213293].
6 Lord C, Risi S, Lambrecht L, et al. The autism diagnostic observation schedule-generic: a standard measure of social and communication deficits associated with the spectrum of autism. J Autism Dev Disord. 06. 2000;30(3):205-223. [pmid: 11055457].
7 Lord C, Rutter M, Le Couteur A. Autism Diagnostic Interview-Revised: a revised version of a diagnostic interview for caregivers of individuals with possible pervasive developmental disorders. J Autism Dev Disord. 10. 1994;24(5):659-685. [pmid: 7814313].
8 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions–Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 05. 2010;63(5):513-523. [pmid: 19595577].
9 Remington B, Hastings RP, Kovshoff H, et al. Early intensive behavioral intervention: outcomes for children with autism and their parents after two years. Am J Ment Retard. 11. 2007;112(6):418-438. [pmid: 17963434].
10 Ben Itzchak E, Lahat E, Burgin R, et al. Cognitive, behavior and intervention outcome in young children with autism. Res Dev Disabil. 09-10. 2008;29(5):447-458. [pmid: 17923388].
11 Reed P, Osborne LA, Corness M. Brief report: relative effectiveness of different home-based behavioral approaches to early teaching intervention. J Autism Dev Disord. 10. 2007;37(9):1815-1821. [pmid: 17180714].
12 Ben-Itzchak E, Zachor DA. The effects of intellectual functioning and autism severity on outcome of early behavioral intervention for children with autism. Res Dev Disabil. 05-06. 2007;28(3):287-303. [pmid: 16730944].
13 Cohen H, Amerine-Dickens M, Smith T. Early intensive behavioral treatment: replication of the UCLA model in a community setting. J Dev Behav Pediatr. 04. 2006;27(2 Suppl):S145-155. [pmid: 16685181].
14 Eldevik S, Eikeseth S, Jahr E, et al. Effects of low-intensity behavioral treatment for children with autism and mental retardation. J Autism Dev Disord. 02. 2006;36(2):211-224. [pmid: 16477514].
15 McConachie H, Randle V, Hammal D, et al. A controlled trial of a training course for parents of children with suspected autism spectrum disorder. J Pediatr. 09. 2005;147(3):335-340. [pmid: 16182672].
16 Beglinger L, Smith T. Concurrent validity of social subtype and IQ after early intensive behavioral intervention in children with autism: a preliminary investigation. J Autism Dev Disord. 06. 2005;35(3):295-303. [pmid: 16119470].
17 Aldred C, Green J, Adams C. A new social communication intervention for children with autism: pilot randomised controlled treatment study suggesting effectiveness. J Child Psychol Psychiatry. 11. 2004;45(8):1420-1430. [pmid: 15482502].
18 Drew A, Baird G, Baron-Cohen S, et al. A pilot randomised control trial of a parent training intervention for pre-school children with autism. Preliminary findings and methodological challenges. Eur Child Adolesc Psychiatry. 12. 2002;11(6):266-272. [pmid: 12541005].
19 Eikeseth S, Smith T, Jahr E, et al. Intensive behavioral treatment at school for 4- to 7-year-old children with autism. A 1-year comparison controlled study. Behav Modif. 01. 2002;26(1):49-68. [pmid: 11799654].
20 Boyd RD, Corley MJ. Outcome survey of early intensive behavioral intervention for young children with autism in a community setting. Autism. 12. 2001;5(4):430-441. [pmid: 11777258].
21 Gabriels RL, Hill DE, Pierce RA, et al. Predictors of treatment outcome in young children with autism: a retrospective study. Autism. 12. 2001;5(4):407-429. [pmid: 11777257].
22 Mudford OC, Martin NT, Eikeseth S, et al. Parent-managed behavioral treatment for preschool children with autism: some characteristics of UK programs. Res Dev Disabil. 05-06. 2001;22(3):173-182. [pmid: 11380057].
23 Smith T, Groen AD, Wynn JW. Randomized trial of intensive early intervention for children with pervasive developmental disorder. Am J Ment Retard. 07. 2000;105(4):269-285. [pmid: 10934569].
24 Harris SL, Handleman JS. Age and IQ at intake as predictors of placement for young children with autism: a four- to six-year follow-up. J Autism Dev Disord. 04. 2000;30(2):137-142. [pmid: 10832778].
25 Anan RM, Warner LJ, McGillivary JE, et al. Group Intensive Family Training (GIFT) for preschoolers with autism spectrum disorders. Behavioral Interventions. 07. 2008;23(3):165-180.
26 Baker-Ericzen MJ, Stahmer AC, Burns A. Child demographics associated with outcomes in a community-based pivotal response training program. Journal of Positive Behavior Interventions. Win. 2007;9(1):52-60.
27 Dillenburger K, Keenan M, Gallagher S, et al. Parent education and home-based behaviour analytic intervention: An examination of parents’ perceptions of outcome. J Intellect Dev Disabil. 06. 2004;29(2):119-130.
28 Arick JR, Young HE, Falco RA, et al. Designing an outcome study to monitor the progress of students with autism spectrum disorders. Focus Autism Other Devel Disabil. Sum. 2003;18(2):75-87.
29 Stahmer AC, Gist K. The effects of an accelerated parent education program on technique mastery and child outcome. Journal of Positive Behavior Interventions. Spr. 2001;3(2):75-82.
30 Luiselli JK, Cannon BOM, Ellis JT, et al. Home-based behavioral interventions for young children with autism/pervasive developmental disorder: A preliminary evaluation of outcome in relation to child age and intensity of service delivery. Autism. 12. 2000;4(4):426-438.
31 Perry A, Cummings A, Geier JD, et al. Effectiveness of intensive behavioral intervention in a large, community-based program. Res Autism Spectr Disord. 10. 2008;2(4):621-642.
32 Gabriels RL, Ivers BJ, Hill DE, et al. Stability of adaptive behaviors in middle-school children with autism spectrum disorders. Res Autism Spectr Disord. 10-12. 2007;1(4):291-303.
33 Zachor DA, Ben-Itzchak E, Rabinovich AL, et al. Change in Autism core symptoms with early intervention: predictors and outcomes. Res Autism Spectr Disord. 2009;3:967-976.
34 Wetherby AM, Woods JJ. Early social interaction project for children with autism spectrum disorders beginning in the second year of life: a preliminary study. Topics in Early Childhood Special Education. Sum. 2006;26(2):67-82.
35 Zachor DA, Ben-Itzchak E, Rabinovich AL, et al. Change in autism core symptoms with intervention. Res Autism Spectr Disord. 10-12. 2007;1(4):304-317.
36 Hayward D, Eikeseth S, Gale C, et al. Assessing progress during treatment for young children with autism receiving intensive behavioural interventions. Autism. 11. 2009;13(6):613-633. [pmid: 19933766].
37 Dawson G, Rogers S, Munson J, et al. Randomized, controlled trial of an intervention for toddlers with autism: the Early Start Denver Model. Pediatrics. 01. 2010;125(1):e17-23. [pmid: 19948568].
38 Granpeesheh D, Tarbox J, Dixon DR, et al. Retrospective analysis of clinical records in 38 cases of recovery from autism. Ann Clin Psychiatry. 10-12. 2009;21(4):195-204. [pmid: 19917210].
39 Keen D, Rodger S, Doussin K, et al. A pilot study of the effects of a social-pragmatic intervention on the communication and symbolic play of children with autism. Autism. 01. 2007;11(1):63-71. [pmid: 17175574].
40 Howard JS, Sparkman CR, Cohen HG, et al. A comparison of intensive behavior analytic and eclectic treatments for young children with autism. Res Dev Disabil. 07-08. 2005;26(4):359-383. [pmid: 15766629].
41 Farrell P, Trigonaki N, Webster D. An exploratory evaluation of two early intervention programmes for young children with autism. Educational and Child Psychology. 2005;22(4):29-40.
42 Vismara LA, Young GS, Stahmer AC, et al. Dissemination of Evidence-based practice: can we train therapists from a distance?. J Autism Devel Disord. 12. 2009;39(12):1636-1651.
43 Bibby P, Eikeseth S, Martin NT, et al. Progress. and outcomes for children with autism receiving parent-managed intensive interventions. Res Dev Disabil. 01-02. 2002;23(1):81-104. [pmid: 12071397].
44 Eikeseth S, Hayward D, Gale C, et al. Intensity of supervision and outcome for preschool aged children receiving early and intensive behavioral interventions: a preliminary study. Res Autism Spectr Disord. 01. 2009;3(1):67-73.
45 Eikeseth S, Smith T, Jahr E, et al. Outcome for children with autism who began intensive behavioral treatment between ages 4 and 7: a comparison controlled study. Behav Modif. 05. 2007;31(3):264-278. [pmid: 17438342].
46 Green J, Charman T, McConachie H, et al. Parent-mediated communication-focused treatment in children with autism (PACT): a randomised controlled trial. Lancet. 2010. 05. 20.
47 Owens G, Granader Y, Humphrey A, et al. LEGO therapy and the social use of language programme: an evaluation of two social skills interventions for children with high functioning autism and Asperger Syndrome. J Autism Dev Disord. 11. 2008;38(10):1944-1957. [pmid: 18566882].
48 Cotugno AJ. Social competence and social skills training and intervention for children with Autism Spectrum Disorders. J Autism Dev Disord. 09. 2009;39(9):1268-1277. [pmid: 19365716].
49 Quirmbach LM, Lincoln AJ, Feinberg-Gizzo MJ, et al. Social stories: mechanisms of effectiveness in increasing game play skills in children diagnosed with autism spectrum disorder using a pretest posttest repeated measures randomized control group design. J Autism Dev Disord. 02. 2009;39(2):299-321. [pmid: 18704672].
50 Beaumont R, Sofronoff K. A multi-component social skills intervention for children with Asperger syndrome: the Junior Detective Training Program. J Child Psychol Psychiatry. 07. 2008;49(7):743-753. [pmid: 18503531].
51 Lopata C, Thomeer ML, Volker MA, et al. Effectiveness of a manualized summer social treatment program for high-functioning children with autism spectrum disorders. J Autism Dev Disord. 05. 2008;38(5):890-904. [pmid: 18058012].
52 Solomon M, Goodlin-Jones BL, Anders TF. A social adjustment enhancement intervention for high functioning autism, Asperger’s syndrome, and pervasive developmental disorder NOS. J Autism Dev Disord. 12. 2004;34(6):649-668. [pmid: 15679185].
53 Kroeger KA, Schultz JR, Newsom C. A Comparison of Two Group-Delivered Social Skills Programs for Young Children with Autism. J Autism Dev Disord. 05. 2007;37(5):808-817. [pmid: 16927011].
54 Frankel F, Myatt R, Sugar C, et al. A Randomized Controlled Study of Parent-assisted Children’s Friendship Training with Children having Autism Spectrum Disorders. J Autism Dev Disord. 2010. 01. 8.
55 Bauminger N. Brief report: individual social-multi-modal intervention for HFASD. J Autism Dev Disord. 09. 2007;37(8):1593-1604. [pmid: 17072753].
56 Bauminger N. Brief report: group social-multimodal intervention for HFASD. J Autism Dev Disord. 09. 2007;37(8):1605-1615. [pmid: 17072752].
57 Gevers C, Clifford P, Mager M, et al. Brief report: A theory-of-mind-based social-cognition training program for school-aged children with pervasive developmental disorders: an open study of its effectiveness. J Autism Dev Disord. 05. 2006;36(4):567-571. [pmid: 16586154].
58 Tyminski RF, Moore PJ. The impact of group psychotherapy on social development in children with pervasive development disorders. I J Group Psychother. 07. 2008;58(3):363-379.
59 Lopata C, Thomeer ML, Volker MA, et al. Effectiveness of a cognitive-behavioral treatment on the social behaviors of children with Asperger Disorder. Focus Autism Other Dev Disabil. Win. 2006;21(4):237-244.
60 Whitaker P. Fostering communication and shared play between mainstream peers and children with autism: approaches, outcomes and experiences. British Journal of Special Education. 12. 2004;31(4):215-222.
61 Legoff DB, Sherman M. Long-term outcome of social skills intervention based on interactive LEGO© play. Autism: The International Journal of Research & Practice. 2006;10(4):317-329. [pmid: 16908476].
62 Golan O, Ashwin E, Granader Y, et al. Enhancing Emotion Recognition in Children with Autism Spectrum Conditions: An Intervention Using Animated Vehicles with Real Emotional Faces. J Autism Dev Disord. 03. 2010;40(3):269-279. [pmid: 19763807].
63 Whittingham K, Sofronoff K, Sheffield J, et al. Stepping Stones Triple P: n RCT of a parenting program with parents of a child diagnosed with an autism spectrum disorder. Journal of Abnormal Child Psychology. 05. 2009;37(4):469-480. [pmid: 19023654].
64 Whittingham K, Sofronoff K, Sheffield J, et al. Do parental attributions affect treatment outcome in a parenting program? an exploration of the effects of parental attributions in an RCT of Stepping Stones Triple P for the ASD population. Res Autism Spectr Disord. 01. 2009;3(1):129-144.
65 Kasari C, Paparella T, Freeman S, et al. Language outcome in autism: randomized comparison of joint attention and play interventions. J Consult Clin Psychol. 02. 2008;76(1):125-137. [pmid: 18229990].
66 Kasari C, Freeman S, Paparella T. Joint attention and symbolic play in young children with autism: a randomized controlled intervention study. J Child Psychol Psychiatry. 06. 2006;47(6):611-620. [pmid: 16712638].
67 Gulsrud AC, Kasari C, Freeman S, et al. Children with autism’s response to novel stimuli while participating in interventions targeting joint attention or symbolic play skills. Autism. 11. 2007;11(6):535-546. [pmid: 17947289].
68 Wong CS, Kasari C, Freeman S, et al. The acquisition and generalization of joint attention and symbolic play skills in young children with autism. Research and Practice for Persons with Severe Disabilities (RPSD). Sum. 2007;32(2):101-109.
69 Gutstein SE, Burgess AF, Montfort K. Evaluation of the relationship development intervention program. Autism. 09. 2007;11(5):397-411. [pmid: 17942454].
70 Solomon R, Necheles J, Ferch C, et al. Pilot Study of a parent training program for young children with autism: The PLAY Project Home Consultation Program. Autism: The International Journal of Research and Practice. 2007;11(3):205-224. [pmid: 17478575].
71 Solomon M, Ono M, Timmer S, et al. The effectiveness of parent-child interaction therapy for families of children on the autism spectrum. J Autism Dev Disord. 10. 2008;38(9):1767-1776. [pmid: 18401693].
72 Vorgraft Y, Farbstein I, Spiegel R, et al. Retrospective evaluation of an intensive method of treatment for children with pervasive developmental disorder. Autism. 09. 2007;11(5):413-424. [pmid: 17942455].
73 Field T, Sanders C, Nadel J. Children with autism display more social behaviors after repeated imitation sessions. Autism. 09. 2001;5(3):317-323. [pmid: 11708590].
74 Heimann M, Laberg KE, Nordoen B. Imitative interaction increases social interest and elicited imitation in non-verbal children with autism. Infant and Child Development. Special Issue: Imitation and Socio-Emotional Processes: Implications for Communicative Development and Interventions. 05-06. 2006;15(3):297-309.
75 Escalona A, Field T, Nadel J, et al. Brief report: Imitation effects on children with autism. J Autism Dev Disord. 04. 2002;32(2):141-144. [pmid: 12058842].
76 Mahoney G, Perales F. Relationship-focused early intervention with children with pervasive developmental disorders and other disabilities: a comparative study. J Dev Behav Pediatr. 04. 2005;26(2):77-85. [pmid: 15827458].
77 Gulsrud AC, Jahromi LB, Kasari C. The co-regulation of emotions between mothers and their children with autism. J Autism Dev Disord. 02. 2010;40(2):227-237. [pmid: 19714458].
78 Sofronoff K, Attwood T, Hinton S, et al. A randomized controlled trial of a cognitive behavioural intervention for anger management in children diagnosed with Asperger syndrome. J Autism Dev Disord. 08. 2007;37(7):1203-1214. [pmid: 17082978].
79 Sofronoff K, Attwood T, Hinton S. A randomised controlled trial of a CBT intervention for anxiety in children with Asperger syndrome. J Child Psychol Psychiatry. 11. 2005;46(11):1152-1160. [pmid: 16238662].
80 Wood JJ, Drahota A, Sze K, et al. Cognitive Behavioral therapy for anxiety in children with autism spectrum disorders: a randomized, controlled trial. J Child Psychol and Psychiatry. 03. 2009;50(3):224-234. [pmid: 19309326].
81 Wood JJ, Drahota A, Sze K, et al. Brief Report: Effects of Cognitive Behavioral Therapy on Parent-Reported Autism Symptoms in School-Age Children with High-Functioning Autism. J Autism Dev Disord. 11. 2009;39(11):1608-1612. [pmid: 19562475].
82 Reaven JA, Blakeley-Smith A, Nichols S, et al. Cognitive-behavioral group treatment for anxiety symptoms in children with high-functioning autism spectrum disorders: a pilot study. Focus on Autism and Other Developmental Disabilities. 2009;24(1):27-37.
83 Research Units on Pediatric Psychopharmocology (RUPP). Parent training for children with pervasive developmental disorders: A multi-site feasibility trial. Behavioral Interventions. 07. 2007;22(3):179-199.
84 Chalfant AM, Rapee R, Carroll L. Treating anxiety disorders in children with high functioning autism spectrum disorders: a controlled trial. J Autism Dev Disord. 11. 2007;37(10):1842-1857. [pmid: 17171539].
85 Grey IM, Honan R, McClean B, et al. Evaluating the effectiveness of teacher training in Applied Behaviour Analysis. J Intellect Disabil. 09. 2005;9(3):209-227. [pmid: 16144826].
86 Sofronoff K, Leslie A, Brown W. Parent management training and Asperger syndrome: a randomized controlled trial to evaluate a parent based intervention. Autism. 09. 2004;8(3):301-317. [pmid: 15358872].
87 Sofronoff K, Farbotko M. The effectiveness of parent management training to increase self-efficacy in parents of children with Asperger syndrome. Autism. 09. 2002;6(3):271-286. [pmid: 12212918].
88 Sofronoff K. A Cognitive Behaviour Therapy intervention for anxiety in children with Asperger’s syndrome. Good Autism Practice. 2003;4:2-8.
89 Aman MG, McDougle CJ, Scahill L, et al. Medication and parent training in children with pervasive developmental disorders and serious behavior problems: results from a randomized clinical trial. J Am Acad Child Adolesc Psychiatry. 2009. 10. 23.
90 Jarusiewicz B. Efficacy of neurofeedback for children in the autistic spectrum: a pilot study. Journal of Neurotherapy. 2002;6(4):39-49.
91 Coben R, Padolsky I. Assessment-guided neurofeedback for autistic spectrum disorder. Journal of Neurotherapy. 2007;11(1):5-23.
92 Reed HE, McGrew SG, Artibee K, et al. Parent-based sleep education workshops in autism. J Child Neurol. 08. 2009;24(8):936-945. [pmid: 19491110].
93 Probst P, Leppert T. Brief report: outcomes of a teacher training program for autism spectrum disorders. J Autism Dev Disord. 10. 2008;38(9):1791-1796. [pmid: 18369717].
94 Tsang SK, Shek DT, Lam LL, et al. Brief report: application of the TEACCH program on Chinese pre-school children with autism–does culture make a difference?. J Autism Dev Disord. 02. 2007;37(2):390-396. [pmid: 16906461].
95 Mukaddes NM, Kaynak FN, Kinali G, et al. Psychoeducational treatment of children with autism and reactive attachment disorder. Autism. 03. 2004;8(1):101-109. [pmid: 15070550].
96 Panerai S, Zingale M, Trubia G, et al. Special education versus inclusive education: the role of the TEACCH program. J Autism Dev Disord. 06. 2009;39(6):874-882. [pmid: 19205860].
97 Rickards AL, Walstab JE, Wright-Rossi RA, et al. A randomized, controlled trial of a home-based intervention program for children with autism and developmental delay. J Dev Behav Pediatr. 08. 2007;28(4):308-316. [pmid: 17700083].
98 Salt J, Shemilt J, Sellars V, et al. The Scottish Centre for Autism preschool treatment programme. II: The results of a controlled treatment outcome study. Autism. 03. 2002;6(1):33-46. [pmid: 11918108].
99 Osborne LA, McHugh L, Saunders J, et al. Parenting stress reduces the effectiveness of early teaching interventions for autistic spectrum disorders. J Autism Dev Disord. 07. 2008;38(6):1092-1103. [pmid: 18027079].
100 Magiati I, Charman T, Howlin P. A two-year prospective follow-up study of community-based early intensive behavioural intervention and specialist nursery provision for children with autism spectrum disorders. J Child Psychol Psychiatry. 08. 2007;48(8):803-812. [pmid: 17683452].
101 Reed P, Osborne LA, Corness M. The real-world effectiveness of early teaching interventions for children with autism spectrum disorder. Exceptional Children. Sum. 2007;73(4):417-433.
102 Stahmer AC, Ingersoll B. Inclusive programming for toddlers with autism spectrum disorders: outcomes from the children’s toddler school. Journal of Positive Behavior Interventions. 2004;6(2):67-82.
103 Reed P, Osborne LA, Corness M. Effectiveness of special nursery provision for children with autism spectrum disorders. Autism: The International Journal of Research and Practice. 2010;14(1):67-82. [pmid: 20124504].
104 Greenberg JH, Martinez RC. Starting off on the right foot: one year of behavior analysis in practice and relative cost. International Journal of Behavioral Consultation and Therapy. 2008;4(2):212-226.
105 Moore M, Calvert S. Brief report: vocabulary acquisition for children with autism: teacher or computer instruction. J Autism Dev Disord. 08. 2000;30(4):359-362. [pmid: 11039862].
106 Whalen C, Moss D, Ilan AB, et al. Efficacy of TeachTown: Basics computer-assisted intervention for the Intensive Comprehensive Autism Program in Los Angeles Unified School District. Autism. 05. 2010;14(3):179-197. [pmid: 20484002].
107 Tjus T, Heimann M, Nelson KE. Interaction patterns between children and their teachers when using a specific multimedia and communication strategy: observations from children with autism and mixed intellectual disabilities. Autism. 06. 2001;5(2):175-187. [pmid: 11706865].
108 Aman MG, Hollway JA, McDougle CJ, et al. Cognitive effects of risperidone in children with autism and irritable behavior. J Child Adolesc Psychopharmacol. 06. 2008;18(3):227-236. [pmid: 18582177].
109 Aman MG, Arnold LE, McDougle CJ, et al. Acute and long-term safety and tolerability of risperidone in children with autism. J Child Adolesc Psychopharmacol. 12. 2005;15(6):869-884. [pmid: 16379507].
110 Research Units on Pediatric Psychopharmacology Autism Network. Risperidone treatment of autistic disorder: longer-term benefits and blinded discontinuation after 6 months. Am J Psychiatry. 07. 2005;162(7):1361-1369. [pmid: 15994720].
111 McDougle CJ, Scahill L, Aman MG, et al. Risperidone for the core symptom domains of autism: results from the study by the autism network of the research units on pediatric psychopharmacology. Am J Psychiatry. 06. 2005;162(6):1142-1148. [pmid: 15930063].
112 Martin A, Scahill L, Anderson GM, et al. Weight and leptin changes among risperidone-treated youths with autism: 6-month prospective data. Am J Psychiatry. 06. 2004;161(6):1125-1127. [pmid: 15169706].
113 McCracken JT, McGough J, Shah B, et al. Risperidone in children with autism and serious behavioral problems. N Engl J Med. 08. 1. 2002;347(5):314-321. [pmid: 12151468].
114 Arnold LE, Vitiello B, McDougle C, et al. Parent-defined target symptoms respond to risperidone in RUPP autism study: customer approach to clinical trials. J Am Acad Child Adolesc Psychiatry. 12. 2003;42(12):1443-1450. [pmid: 14627879].
115 Williams SK, Scahill L, Vitiello B, et al. Risperidone and adaptive behavior in children with autism. J Am Acad Child Adolesc Psychiatry. 04. 2006;45(4):431-439. [pmid: 16601648].
116 Anderson GM, Scahill L, McCracken JT, et al. Effects of short- and long-term risperidone treatment on prolactin levels in children with autism. Biol Psychiatry. 02. 15. 2007;61(4):545-550. [pmid: 16730335].
117 Pandina GJ, Bossie CA, Youssef E, et al. Risperidone improves behavioral symptoms in children with autism in a randomized, double-blind, placebo-controlled trial. J Autism Dev Disord. 02. 2007;37(2):367-373. [pmid: 17019624].
118 Shea S, Turgay A, Carroll A, et al. Risperidone in the treatment of disruptive behavioral symptoms in children with autistic and other pervasive developmental disorders. Pediatrics. 11. 2004;114(5):e634-641. [pmid: 15492353].
119 Nagaraj R, Singhi P, Malhi P. Risperidone in children with autism: randomized, placebo-controlled, double-blind study. J Child Neurol. 06. 2006;21(6):450-455. [pmid: 16948927].
120 Masi G, Cosenza A, Mucci M, et al. A 3-year naturalistic study of 53 preschool children with pervasive developmental disorders treated with risperidone. J Clin Psychiatry. 09. 2003;64(9):1039-1047. [pmid: 14628979].
121 Marcus RN, Owen R, Kamen L, et al. A placebo-controlled, fixed-dose study of aripiprazole in children and adolescents with irritability associated with autistic disorder. J Am Acad Child Adolesc Psychiatry. 11. 2009;48(11):1110-1119. [pmid: 19797985].
122 Owen R, Sikich L, Marcus RN, et al. Aripiprazole in the treatment of irritability in children and adolescents with autistic disorder. Pediatrics. 12. 2009;124(6):1533-1540. [pmid: 19948625].
123 Akhondzadeh S, Erfani S, Mohammadi MR, et al. Cyproheptadine in the treatment of autistic disorder: a double-blind placebo-controlled trial. J Clin Pharm Ther. 04. 2004;29(2):145-150. [pmid: 15068403].
124 Correia CT, Almeida JP, Santos PE, et al. Pharmacogenetics of risperidone therapy in autism: association analysis of eight candidate genes with drug efficacy and adverse drug reactions. Pharmacogenomics J. 2010;10(5):418-430. [pmid: 19997080].
125 Hollander E, Phillips A, Chaplin W, et al. A placebo controlled crossover trial of liquid fluoxetine on repetitive behaviors in childhood and adolescent autism. Neuropsychopharmacology. 03. 2005;30(3):582-589. [pmid: 15602505].
126 DeLong GR, Ritch CR, Burch S. Fluoxetine response in children with autistic spectrum disorders: correlation with familial major affective disorder and intellectual achievement. Dev Med Child Neurol. 10. 2002;44(10):652-659. [pmid: 12418789].
127 King BH, Hollander E, Sikich L, et al. Lack of efficacy of citalopram in children with autism spectrum disorders and high levels of repetitive behavior: citalopram ineffective in children with autism. Arch Gen Psychiatry. 06. 2009;66(6):583-590. [pmid: 19487623].
128 Owley T, Brune CW, Salt J, et al. A pharmacogenetic study of escitalopram in autism spectrum disorders. Autism Res. 02. 2010;3(1):1-7. [pmid: 20020537].
129 Henry CA, Steingard R, Venter J, et al. Treatment outcome and outcome associations in children with pervasive developmental disorders treated with selective serotonin reuptake inhibitors: a chart review. J Child Adolesc Psychopharmacol. 02-04. 2006;16(1–2):187-195. [pmid: 16553539].
130 Randomized controlled crossover trial of methylphenidate in pervasive developmental disorders with hyperactivity. Arch Gen Psychiatry. 11. 2005;62(11):1266-1274. [pmid: 16275814].
131 Posey DJ, Aman MG, McCracken JT, et al. Positive effects of methylphenidate on inattention and hyperactivity in pervasive developmental disorders: an analysis of secondary measures. Biol Psychiatry. 02. 15. 2007;61(4):538-544. [pmid: 17276750].
132 Jahromi LB, Kasari CL, McCracken JT, et al. Positive effects of methylphenidate on social communication and self-regulation in children with pervasive developmental disorders and hyperactivity. J Autism Dev Disord. 03. 2009;39(3):395-404. [pmid: 18752063].
133 Nickels K, Katusic SK, Colligan RC, et al. Stimulant medication treatment of target behaviors in children with autism: a population-based study. J Dev Behav Pediatr. 04. 2008;29(2):75-81. [pmid: 18478626].
134 Posey DJ, Puntney JI, Sasher TM, et al. Guanfacine treatment of hyperactivity and inattention in pervasive developmental disorders: a retrospective analysis of 80 cases. J Child Adolesc Psychopharmacol. Summer. 2004;14(2):233-241. [pmid: 15319020].
135 Stigler KA, Desmond LA, Posey DJ, et al. A naturalistic retrospective analysis of psychostimulants in pervasive developmental disorders. J Child Adolesc Psychopharmacol. Spring. 2004;14(1):49-56. [pmid: 15142391].
136 Levy SE, Souders MC, Wray J, et al. Children with autistic spectrum disorders. I: comparison of placebo and single dose of human synthetic secretin. Arch Dis Child. 08. 2003;88(8):731-736. [pmid: 12876177].
137 Molloy CA, Manning-Courtney P, Swayne S, et al. Lack of benefit of intravenous synthetic human secretin in the treatment of autism. J Autism Dev Disord. 12. 2002;32(6):545-551. [pmid: 12553591].
138 Unis AS, Munson JA, Rogers SJ, et al. A randomized, double-blind, placebo-controlled trial of porcine versus synthetic secretin for reducing symptoms of autism. J Am Acad Child Adolesc Psychiatry. 11. 2002;41(11):1315-1321. [pmid: 12410073].
139 Owley T, McMahon W, Cook EH, et al. Multisite, double-blind, placebo-controlled trial of porcine secretin in autism. J Am Acad Child Adolesc Psychiatry. 11. 2001;40(11):1293-1299. [pmid: 11699803].
140 Roberts W, Weaver L, Brian J, et al. Repeated doses of porcine secretin in the treatment of autism: a randomized, placebo-controlled trial. Pediatrics. 05. 2001;107(5):E71. [pmid: 11331721].
141 Coniglio SJ, Lewis JD, Lang C, et al. A randomized, double-blind, placebo-controlled trial of single-dose intravenous secretin as treatment for children with autism. J Pediatr. 05. 2001;138(5):649-655. [pmid: 11343038].
142 Dunn-Geier J, Ho HH, Auersperg E, et al. Effect of secretin on children with autism: a randomized controlled trial. Dev Med Child Neurol. 12. 2000;42(12):796-802. [pmid: 11132252].
143 Chez MG, Buchanan CP, Bagan BT, et al. Secretin and autism: a two-part clinical investigation. J Autism Dev Disord. 04. 2000;30(2):87-94. [pmid: 10832772].
144 Akhondzadeh S, Tajdar H, Mohammadi MR, et al. A double-blind placebo controlled trial of piracetam added to risperidone in patients with autistic disorder. Child Psychiatry Hum Dev. 09. 2008;39(3):237-245. [pmid: 17929164].
145 Chez MG, Buchanan CP, Aimonovitch MC, et al. Double-blind, placebo-controlled study of L-carnosine supplementation in children with autistic spectrum disorders. J Child Neurol. 11. 2002;17(11):833-837. [pmid: 12585724].
146 King BH, Wright DM, Handen BL, et al. Double-blind, placebo-controlled study of amantadine hydrochloride in the treatment of children with autistic disorder. J Am Acad Child Adolesc Psychiatry. 06. 2001;40(6):658-665. [pmid: 11392343].
147 Kern JK, Miller VS, Cauller PL, et al. Effectiveness of N, N-dimethylglycine in autism and pervasive developmental disorder. J Child Neurol. 03. 2001;16(3):169-173. [pmid: 11305684].
148 Chez MG, Buchanan TM, Becker M, et al. Donepezil hydrochloride: A double-blind study in autistic children. Journal of Pediatric Neurology. 10-12. 2003;1(2):83-88.
149 Rossignol DA, Rossignol LW, Smith S, et al. Hyperbaric treatment for children with autism: a multicenter, randomized, double-blind, controlled trial. BMC Pediatr. 2009;9:21. [pmid: 19284641].
150 Handen BL, Melmed RD, Hansen RL, et al. A double-blind, placebo-controlled trial of oral human immunoglobulin for gastrointestinal dysfunction in children with autistic disorder. J Autism Dev Disord. 05. 2009;39(5):796-805. [pmid: 19148734].
151 Adams JB, Baral M, Geis E, et al. Safety and efficacy of oral DMSA therapy for children with autism spectrum disorders: part A—medical results. BMC Clin Pharmacol. 2009;9:16. [pmid: 19852789].
152 Andersen IM, Kaczmarska J, McGrew SG, et al. Melatonin for insomnia in children with autism spectrum disorders. J Child Neurol. 05. 2008;23(5):482-485. [pmid: 18182647].
153 Meguid NA, Atta HM, Gouda AS, et al. Role of polyunsaturated fatty acids in the management of Egyptian children with autism. Clin Biochem. 09. 2008;41(13):1044-1048. [pmid: 18582451].
154 Dosman CF, Brian JA, Drmic IE, et al. Children with autism: effect of iron supplementation on sleep and ferritin. Pediatr Neurol. 03. 2007;36(3):152-158. [pmid: 17352947].
155 Mousain-Bosc M, Roche M, Polge A, et al. Improvement of neurobehavioral disorders in children supplemented with magnesium-vitamin B6. II. Pervasive developmental disorder-autism. Magnes Res. 03. 2006;19(1):53-62. [pmid: 16846101].
156 Chez MG, Aimonovitch M, Buchanan T, et al. Treating autistic spectrum disorders in children: utility of the cholinesterase inhibitor rivastigmine tartrate. J Child Neurol. 03. 2004;19(3):165-169. [pmid: 15119476].
157 Evangeliou A, Vlachonikolis I, Mihailidou H, et al. Application of a ketogenic diet in children with autistic behavior: pilot study. J Child Neurol. 02. 2003;18(2):113-118. [pmid: 12693778].
158 Adams JB, Baral M, Geis E, et al. Safety and efficacy of oral DMSA therapy for children with autism spectrum disorders: part B—behavioral results. BMC Clin Pharmacol. 2009;9:17. [pmid: 19852790].
159 Munasinghe SA, Oliff C, Finn J, et al. Digestive enzyme supplementation for autism spectrum disorders: a double-blind randomized controlled trial. J Autism Dev Disord. 09. 2010;40(9):1131-1138. [pmid: 20204691].
160 Akhondzadeh S, Fallah J, Mohammadi M-R, et al. Double-blind placebo-controlled trial of pentoxifylline added to risperidone: Effects on aberrant behavior in children with autism. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 02. 2010;34(1):32-36. [pmid: 19772883].
161 Yoder PJ. Predicting lexical density growth rate in young children with autism spectrum disorders. Am J Speech Lang Pathol. 11. 2006;15(4):378-388. [pmid: 17102148].
162 Yoder P, Stone WL. A randomized comparison of the effect of two prelinguistic communication interventions on the acquisition of spoken communication in preschoolers with ASD. J Speech Lang Hear Res. 08. 2006;49(4):698-711. [pmid: 16908870].
163 Yoder P, Stone WL. Randomized comparison of two communication interventions for preschoolers with autism spectrum disorders. J Consult Clin Psychol. 06. 2006;74(3):426-435. [pmid: 16822100].
164 Yoder PJ, Lieberman RG. Brief Report: randomized test of the efficacy of Picture Exchange Communication System on highly generalized picture exchanges in children with ASD. J Autism Dev Disord. 05. 2010;40(5):629-632. [pmid: 19904596].
165 Carr D, Felce J. The effects of PECS teaching to Phase III on the communicative interactions between children with autism and their teachers. J Autism Dev Disord. 04. 2007;37(4):724-737. [pmid: 17006780].
166 Howlin P, Gordon RK, Pasco G, et al. The effectiveness of Picture Exchange Communication System (PECS) training for teachers of children with autism: a pragmatic, group randomised controlled trial. J Child Psychol Psychiatry. 05. 2007;48(5):473-481. [pmid: 17501728].
167 Magiati I, Howlin P. A pilot evaluation study of the Picture Exchange Communication System (PECS) for children with autistic spectrum disorders. Autism. 09. 2003;7(3):297-320. [pmid: 14516062].
168 Carr D, Felce J. Teaching picture-to-object relations in picture-based requesting by children with autism: a comparison between error prevention and error correction teaching procedures. J Intellect Disabil Res. 04. 2008;52(Pt 4):309-317. [pmid: 18339093].
169 Fazlioglu Y, Baran G. A sensory integration therapy program on sensory problems for children with autism. Percept Mot Skills. 04. 2008;106(2):415-422. [pmid: 18556898].
170 Jung KE, Lee HJ, Lee YS, et al. Efficacy of sensory integration treatment based on virtual reality—tangible interaction for children with autism. Annual Review of CyberTherapy and Telemedicine. 2006;4:45-49.
171 Jung K-E, Lee H-J, Lee Y-S, et al. The application of a sensory integration treatment based on virtual reality—tangible interaction for children with autistic spectrum disorder. PsychNology Journal. Special Issue: Emerging Trends in Cybertherapy. 2006;4(2):145-159.
172 Mudford OC, Cross BA, Breen S, et al. Auditory integration training for children with autism: no behavioral benefits detected. Am J Ment Retard. 03. 2000;105(2):118-129. [pmid: 10755175].
173 Corbett BA, Shickman K, Ferrer E. Brief report: the effects of Tomatis sound therapy on language in children with autism. J Autism Dev Disord. 03. 2008;38(3):562-566. [pmid: 17610057].
174 Kim J, Wigram T, Gold C. The effects of improvisational music therapy on joint attention behaviors in autistic children: a randomized controlled study. J Autism Dev Disord. 10. 2008;38(9):1758-1766. [pmid: 18592368].
175 Kim J, Wigram T, Gold C. Emotional, motivational and interpersonal responsiveness of children with autism in improvisational music therapy. Autism. 07. 2009;13(4):389-409. [pmid: 19535468].
176 Sams MJ, Fortney EV, Willenbring S. Occupational therapy incorporating animals for children with autism: A pilot investigation. Am J Occup Ther. 05-06. 2006;60(3):268-274. [pmid: 16776394].
177 Carmody DP, Kaplan M, Gaydos AM. Spatial orientation adjustments in children with autism in Hong Kong. Child Psychiatry Hum Dev. Spring. 2001;31(3):233-247. [pmid: 11196013].
178 Hartshorn K, Olds L, Field T, et al. Creative movement therapy benefits children with autism. Early Child Development and Care. 2001;166:1-5.
179 Ludlow AK, Wilkins AJ, Heaton P. Colored Overlays Enhance Visual Perceptual Performance in Children with Autism Spectrum Disorders. Res Autism Spectr Disord. 07-09. 2008;2(3):498-515.
180 Bass MM, Duchowny CA, Llabre MM. The effect of therapeutic horseback riding on social functioning in children with autism. J Autism Dev Disord. 09. 2009;39(9):1261-1267. [pmid: 19350376].
181 Ludlow AK, Wilkins AJ, Heaton P. The effect of coloured overlays on reading ability in children with autism. J Autism Dev Disord. 05. 2006;36(4):507-516. [pmid: 16598434].
182 Laud RB, Girolami PA, Boscoe JH, et al. Treatment outcomes for severe feeding problems in children with autism spectrum disorder. Behav Modif. 09. 2009;33(5):520-536. [pmid: 19748900].
183 Pan CY. Effects of water exercise swimming program on aquatic skills and social behaviors in children with autism spectrum disorders. Autism. 01. 2010;14(1):9-28. [pmid: 20124502].
184 Piravej K, Tangtrongchitr P, Chandarasiri P, et al. Effects of Thai traditional massage on autistic children’s behavior. J Altern Complement Med. 12. 2009;15(12):1355-1361. [pmid: 20001837].
185 Allam H, El Dine NG, Helmy G. Scalp acupuncture effect on language development in children with autism: a pilot study. J Altern Complement Med. 03. 2008;14(2):109-114. [pmid: 18315511].
186 Chan AS, Cheung MC, Sze SL, et al. Seven-star needle stimulation improves language and social interaction of children with autistic spectrum disorders. Am J Chin Med. 2009;37(3):495-504. [pmid: 19606510].
187 Silva LM, Ayres R, Schalock M. Outcomes of a pilot training program in a qigong massage intervention for young children with autism. Am J Occup Ther. 09-10. 2008;62(5):538-546. [pmid: 18826014].
188 Silva LM, Cignolini A, Warren R, et al. Improvement in sensory impairment and social interaction in young children with autism following treatment with an original Qigong massage methodology. Am J Chin Med. 2007;35(3):393-406. [pmid: 17597498].
189 Escalona A, Field T, Singer-Strunck R, et al. Brief report: improvements in the behavior of children with autism following massage therapy. J Autism Dev Disord. 10. 2001;31(5):513-516. [pmid: 11794416].
190 Silva LM, Schalock M, Ayres R, et al. Qigong massage treatment for sensory and self-regulation problems in young children with autism: a randomized controlled trial. Am J Occup Ther. 07-08. 2009;63(4):423-432. [pmid: 19708471].
191 Sallows GO, Graupner TD. Intensive behavioral treatment for children with autism: four-year outcome and predictors. Am J Ment Retard. 11. 2005;110(6):417-438. [pmid: 16212446].