# Discussion

In this chapter, we summarize our findings about therapies for children with autism spectrum disorders (ASDs). We provide an overview of the state of the literature by intervention type, detail the strength of evidence for the impact of each major intervention on relevant outcomes, and describe major issues and gaps in the current body of evidence.

The organization of interventions into categories followed in this report is one of many possible approaches, none of which is uniformly accepted in the field. In developing a comparative effectiveness review for the Effective Healthcare Program, our primary intent is to provide information to end users making treatment choices, rather than to academic researchers who might choose to organize the report differently, for example by underlying philosophy or approach. Therefore, in selecting the categories of interventions reflected here, we attempted to incorporate both treatment approach and treatment setting, as these two elements would be considered in a treatment decision. This consideration means that some categorical divisions of similar approaches are reviewed in different sections. For example, studies employing early intensive intervention approaches are included in the early intensive behavioral and developmental studies section and in the educational section. We considered whether alternate organizations would have changed our conclusions in any area and determined that neither our assessment of the literature nor our strength of the evidence determinations would have changed.

Our summary begins with results of the literature search on behavioral interventions, which we have organized into five major categories: early intensive behavioral and developmental approaches; social skills training; play and interaction-based interventions; behavioral interventions for associated conditions; and additional interventions. We subsequently review educational interventions, which we defined as those interventions intended primarily to be administered in educational settings, or studies for which the educational arm was most clearly categorized. This section includes TEACCH (Treatment and Education of Autistic and Communication related handicapped CHildren) and other treatments implemented primarily in the educational setting. Some of the interventions implemented in educational settings are based on principles of ABA and may be intensive in nature, but none of these interventions used the UCLA/Lovaas or Early Start denver Model (ESDM) manualized (i.e., have published treatment manuals to facilitate replication) treatments.

Finally, we discuss medical and related interventions, allied health interventions, and then remaining complementary and alternative medicine (CAM) interventions not fitting the above categories.

The assessment of the literature is done by considering both the observed effectiveness of interventions and the confidence that we have in the stability of those effects in the face of future research. The degree of confidence that the observed effect of an intervention is unlikely to change is presented as strength of evidence, and can be insufficient, low, moderate or high. Strength of evidence describes the adequacy of the current research, both quantity and quality, and whether the entire body of current research provides a consistent and precise estimate of effect. Interventions that have shown significant benefit in a small number of studies but have not yet been replicated using rigorous study designs will have insufficient or low strength of evidence, despite potentially offering clinically important benefits. Future research may find that the intervention is either effective or ineffective.

Methods for applying strength of evidence assessments are established in the Evidence-based Practice Centers’ Methods Guide for Effectiveness and Comparative Effectiveness Reviews99 and are based on consideration of four domains: risk of bias, consistency in direction of the effect, directness in measuring intended outcomes, and precision of effect. For determining the strength of evidence for effectiveness outcomes, we only assessed the body of literature deriving from studies that included comparison groups. We required at least 3 fair studies to be available to assign a low strength of evidence rather than considering it to be insufficient. We required at least one good study for moderate strength of evidence and two good studies for high strength of evidence. In addition, to be considered “moderate” or higher, intervention-outcome pairs needed a positive response on two out of the three domains other than risk of bias. For determining the strength of evidence related to harms, we also considered data from case series.

Once we established the maximum strength of evidence possible based upon these criteria, we assessed the number of studies and range of study designs for a given intervention-outcome pair, and downgraded the strength of evidence rating when the cumulative evidence was not sufficient to justify the higher rating. As could be expected in a field that is testing a broad array of interventions, most intervention-outcome pairs had insufficient strength of evidence to establish confidence in the stability of observed effects.

Tables 27 through 35 provide summaries of results, including strength of evidence, for each category of intervention (behavioral, educational, medical, allied health, and CAM). Table 36 documents the strength of evidence for each domain of the major intervention-outcome combinations for which the strength of evidence was not insufficient. Table 37 presents those interventions-outcomes pairs for which the strength of evidence is insufficient.

Table 27 Summary of results of studies of early intensive behavioral and developmental approaches

Intervention | Study design/Quality | Study results and overall strength of evidence
UCLA/Lovaas-based interventions | 1 RCT/1 fair114 3 Nonrandomized trials/3 fair,103,110,126 5 Prospective cohorts/3 fair,105,125,129 2 poor101,124 2 Retrospective cohorts/2 poor106,130 6 Prospective case series102,104,107,112,115,119 6 Retrospective case series111,113,118,121,122,127,131 | - Young children receiving high intensity interventions (>30 hours a week for 1–3 years by well trained therapists) display improvements in areas of cognitive, language, adaptive functioning.; - Subgroups of children display a positive response to this intervention, but the subgroup with a positive response is not well characterized.; - Strength of evidence for UCLA/Lovaas-based intervention in affecting language, cognitive, educational, and adaptive outcomes and ASD symptom severity is low.
Early Start Denver Model | 1 RCT/1 good290 1 Prospective case series178 | - Improvements in cognitive, language, and adaptive behavior skills are seen over 2 years in one RCT of ESDM intervention for young children with ASDs.; - ESDM findings are not yet replicated and it is unclear how core ASDs symptoms change in response to treatment.; - Strength of evidence for ESDM-based intervention in affecting cognitive, language, and adaptive outcomes currently is insufficient.
Intensive parent training | 3 RCTs/3 fair100,108,109 1 Nonrandomized controlled trial/1 poor120 3 Prospective case series116,117,128 | - Some indication of short-term improvements in language, social, and adaptive skills for children whose parents receive training in these areas but studies vary in interventions and outcomes studied.; - Data do not yet demonstrate long-term functional improvements across domains for any specific form of training.; - Strength of evidence for changing core ASDs deficit areas is insufficient as studies vary in interventions and outcomes reported.

ASDs=autism spectrum disorders; ESDM=Early Start Denver Model; RCT=randomized controlled trial; UCLA=University of California, Los Angeles

Table 28 Summary of results of social skills interventions

Intervention | Study design/Quality | Study results and overall strength of evidence
Group-format | 6 RCTs/3 fair135,139,141, 3 poor143,146,149 1 Retrospective cohort/1 poor148 5 Prospective case series136,138,140,142,144 | - High functioning children with ASDs improved on various social outcomes in individual studies, however the specific social skills in which benefits were observed and reported (such as emotion recognition, theory of mind, and observed peer interactions) varied depending on the study.; - Strength of evidence on social outcomes is insufficient given variations in the interventions and outcomes assessed.
Individual-format | 2 RCTs/1 fair,145 1 poor152 2 Prospective case series137,147 | - Improvements were seen in targeted social skills for treated participants but interventions and outcomes varied substantially across studies.; - Strength of evidence for social outcomes is insufficient given variations in the interventions assessed.

ASDs=autism spectrum disorders; RCT=randomized controlled trial

Table 29 Summary of results of studies of play-/interaction-based interventions

Intervention | Study design/Quality | Study results and overall strength of evidence
Parent-focused tderapies | 2 RCTs/1 fair,161 1 poor153,154 | - Problem behavior declined for the treated group in both studies.; - Adaptive behavior skills increased for the treated group in one RCT.; - Parent reports indicated that the treated group appeared more typical following intervention in one study.; - Strength of evidence for effectiveness in affecting challenging behavior is insufficient.
Imitation | 3 RCTs/3 poor163–165 | - Children in imitation treatment groups showed more interaction with adults compared with those in contingent response groups in all three studies.; - Strength of evidence for the effect on social behavior is insufficient.
Joint attention and symbolic play | 2 RCTs/1 fair155,156, 1 poor157 2 Prospective case series158,167 | - Joint attention and symbolic play were both effective in improving responsive joint attention or expressive language in the short and long term in one RCT.; - Greater improvement in outcomes predicated on increased joint attention in the joint attention groups in one RCT.; - Mother-mediated joint attention intervention yielded increases in joint engagement in one study.; - Strength of evidence for effectiveness of joint attention intervention in affecting joint attention outcomes is insufficient.
Relationship- focused interventions | 2 Prospective case series160,166 2 Retrospective case series 159,162 | - Positive behavioral outcomes noted in all series, but no comparison groups.; - Insufficient evidence to determine effectiveness.

RCT=randomized controlled trial

Table 30 Summary of results of studies targeting behaviors commonly associated with ASDs

Intervention | Study design/Quality | Study results and strength of evidence
CBT for anxiety | 4 RCTs/2 fair,169–171 2 poor25,176 1 Nonrandomized trial/1 fair26 | - Decrease in anxiety symptoms in treated groups in individual studies.; - Participants meeting criteria for anxiety disorders decreased in one study.; - Improvement in social skills in treated children.; - Strength of evidence for a positive effect on comorbid symptoms was insufficient based on variation in the interventions assessed.
CBT for anger management | 1 RCT/1 fair168 | - Reduction in parent-reported instances of anger in the treated group of one RCT.; - Strength of evidence for a positive effect on comorbid symptoms was insufficient, based on only on RCT of fair quality.
Parent and teacher training focused on commonly associated behaviors | 1 RCT/1 fair177 2 prospective cohorts/2 poor174,175 2 prospective case series172,173 | - Less severe challenging behaviors were observed in children taking risperidone whose parents participated in parent training in one RCT; - Parent training in individual sessions was more effective than in a workshop setting in one study.; - Strength of evidence for a positive effect on comorbid symptoms was insufficient, based on variation in the interventions and outcomes assessed.

CBT=cognitive behavioral therapy; RCT=randomized controlled trial

Table 31 Summary of results of studies of other behavioral interventions

Intervention | Study design/Quality | Study results and overall strength of evidence
Neurofeedback | 2 RCTs/2 poor181,182 | - Insufficient strength of the evidence based on few, poor studies.
Sleep workshops | 1 Prospective case series 183 | - Insufficient strength of the evidence.

ASDs=autism spectrum disorders; RCT=randomized controlled trial

Table 32 Summary of results of educational interventions

Intervention | Study design/Quality | Study results and overall strength of evidence
TEACCH | 2 Prospective cohorts/1 good, 185 1 fair187 2 Prospective case series 186,188 | - In prospective cohorts, all treated groups improved in gross motor skills and cognitive performance.; - Inconclusive outcomes for fine motor skills, perception, daily living skills, imitation, and socialization.; - Strength of evidence for effect on cognitive outcomes is insufficient, based upon too few studies.
Broad-based approaches | 1 RCT/1 fair194,198 1 Nonrandomized trial/1 poor197 3 Prospective cohorts/3 fair192,195,196 1 Prospective case series193 1 Retrospective cohort/1 fair199 1 Retrospective case series 191 | - Combination of home- and center-based program compared with a center-based program alone improved IQ and behavior in one study.; - ABA and a nursery program showed higher gains compared with the portage program in educational functioning and adaptive behavior in one study.; - Special nursery placement, both ASD-specific and general specialized nursery, was associated with greater gains in adaptive behavior in one study.; - Strength of evidence for effect on communication and social skills is insufficient because studies differed in interventions and outcomes assessed, and were of too low quality.
Computer-based approaches | 2 RCT/2 poor189,200 1 Prospective case series 190 | - Insufficient strength of the evidence for the effects of computer-based programs on language skills because studies differed in the interventions assessed and were poor quality.

ABA=applied behavior analysis; IQ=intelligence quotient; RCT=randomized controlled trial; TEACCH= Treatment and Education of Autistic and Communication related handicapped CHildren

Table 33 Summary of results of medical studies

Intervention | Study design/Quality | Study results and overall strength of evidence
Antipsychotics
Risperidone vs. placebo | 4 RCT/1 good,201,202,204–209 3 fair203,210–212 2 prospective case series213,214 | - Improvements in challenging behavior and repetitive behavior.; - Adverse effects, including weight gain, sedation and extrapyramidal effects.; - Strength of evidence for reducing challenging behavior and repetitive behavior is moderate.; - Strength of evidence for adverse events is high based on RCTs and case series; common side effects include weight gain, sedation, and extra- pyramidal effects.
Aripiprazole vs. placebo | 2 RCT/2 good215,216 | - Improvements in challenging behavior and repetitive behavior.; - Adverse effects, including weight gain, sedation and extrapyramidal side effects.; - Strength of evidence for reducing challenging behavior and repetitive behavior is high.; - Strength of evidence for adverse events is high; common side effects include weight gain, sedation, and extra-pyramidal effects.
Cyproheptadine added to haloperidol vs. haloperidol and placebo | 1 RCT/1 fair217 | - Behavioral improvement reported but without indicating specific domains in one study.; - Strength of evidence for reducing challenging behavior and repetitive behavior is insufficient.
Fluoxetine vs. placebo | 1 RCT/1 fair220 1 Retrospective case series 221 | - Greater change in repetitive behavior with fluoxetine compared with placebo.; - Strength of evidence for SRIs to decrease repetitive behavior is insufficient.; - Strength of evidence for adverse events is insufficient with only one RCT of fair quality.
Citalopram vs. placebo | 1 RCT/1 good222 1 Prospective case series 223 | - No significant difference between the groups on repetitive behavior in one study.; - Significant but clinically small reduction in challenging behavior in the treatment group compared with placebo.; - Genotype effect on improvement in challenging behavior.; - Strength of evidence for effect of SRIs to reduce repetitive behavior is insufficient.; - Strength of evidence for adverse events is insufficient.
Various SRIs (including sertraline, citalopram, paroxetine, fluvoxamine) | 1 Retrospective case series224 | - 40/89 subjects ranked as “much improved.”; - Strength of evidence for effect of SRIs to reduce repetitive behavior is insufficient.; - Strength of evidence for adverse events is low when SRIs are considered as a class.
Stimulants and other medications to treat hyperactivity
Stimulants | 1 RCT/1 good228–230 2 Retrospective case series231,233 | - Improvement in hyperactivity and non-compliance in one study.; - Adverse events, including increases in challenging behavior and loss of appetite.; - Strength of evidence for effectiveness in affecting hyperactivity is insufficient.; - Strength of evidence around adverse events is also insufficient.
Guanfacine | 1 Retrospective case series 232 | - Symptom improvement observed for hyperactivity, inattention, insomnia, and tics.; - Strength of evidence for effectiveness on hyperactivity and inattention is insufficient.
Secretin
Secretin vs. placebo | 7 RCTs/2 good,237,238 5 fair234–236,239,240 1 Prospective case series 241 | - No studies showed significantly greater improvements in the secretin group;; - No difference for porcine or synthetic secretin.; - Strength of evidence is high for lack of effectiveness in affecting language, cognition, behavior, communication, autism symptom severity, and socialization.
Dietary interventions
Dietary interventions and supplements | 1 RCT/1 fair249 4 Prospective case series242,243,245,246 | - Some studies showed improvements with iron supplementation, magnesium and vitamins, fish oil, evening primrose oil and ketogenic diet.; - Some lessening of food selectivity behaviors in study of dietary enzyme supplementation.; - Few studies had comparison groups and most were poor.; - Insufficient evidence to determine effectiveness.
Other interventions
Various medical Interventions | 9 RCTs/2 good,64,254 6 fair,247,248,251–253,^257^1 poor250,255 1 Prospective case series256 1 Retrospective case series 244 | - Early promise for omega 3 fatty acids, melatonin, L-carnosine, and piracetam.; - 85% of parents reported decrease in or resolution of sleep problems with melatonin; problems returned in some children.; - One good RCT of hyperbaric oxygen showed benefit on general ratings and social and challenging behaviors.; - Fair RCT of pentoxifylline added to risperidone compared with risperidone+ placebo showed significant improvements in irritability, lethargy/social withdrawal, stereotypic behavior, hyperactivity, and inappropriate speech for the pentoxifylline group.; - No effect for cholinesterase inhibitors (donepezil) on language or behavior.; - Amantadine, oral immunoglobulin, and the chelating agent DMSA showed no benefit in single RCTs.; - Insufficient evidence to determine strength of the evidence for any one of the various medical interventions.; - Insufficient evidence in any one category.

DMSA=dimercaptosuccinic acid; RCT=randomized controlled trial; SRI=serotonin reuptake inhibitor

Table 34 Summary of results of allied health studies

Intervention | Study design/Quality | Study results and overall strength of evidence
Language and speech interventions
PECS, RPMT | 2 RCTs/1 good,258–261 1 poor263 1 Nonrandomized controlled trial/1 poor262,265 1 Prospective case series264 | - Mixed results for language acquisition.; - Observed increases in language have not been maintained long-term or after treatment discontinuation.; - Children most likely to benefit from RPMT in increasing joint attention had demonstrated at least 7 acts of joint attention in the pre-intervention assessment.; - Strength of evidence for language interventions (PECS and RPMT) is insufficient.
Sensory/auditory interventions
Sensory integration interventions | 1 RCT/1 poor266 1 Prospective case series267,268 | - Some improvements in sensory problems in treatment groups; however, poor quality studies limit conclusions.; - Strength of evidence for effect is insufficient.
Auditory integration interventions | 2 RCTs/2 fair269,270 | - Receptive or expressive language, cognitive skills, problem or adaptive behaviors did not improve significantly in the treatment groups.; - Insufficient evidence to determine effects on language, adaptive behavior, and challenging behaviors.
Music and play therapy interventions | 1 RCT/1 poor89,271 | - Insufficient evidence to determine effects on social skills outcomes.
Other allied health interventions
Varied allied health interventions | 1 RCT/1 poor276 1 Nonrandomized controlled trial/1 poor274 6 Prospective case series272,273,275,277–279 | - Small, short-term studies of disparate interventions.; - Insufficient evidence to determine effectiveness for any outcome.

PECS=Picture Exchange Communication System; RCT=randomized controlled trial; RPMT= Responsive Education and Prelinguistic Milieu Training

Table 35 Summary of results of CAM studies

Intervention | Study design/Quality | Study results and overall strength of evidence
Massage | 4 RCTs/1fair,283 3 poor284–286 1 Prospective case series282 | - Some improvements in sensory, adaptive behaviors, social skills, and language measures.; - Short-term, small studies (mean 25 participants/study), largely employing parent reported outcome measures.; - Insufficient evidence to determine effectiveness.
Acupuncture | 2 RCTs/1 fair,280 1 poor281 | - Small effects on language measured with unvalidated tools.; - Adverse effects not addressed.; - Insufficient evidence to determine effectiveness.

RCT=randomized controlled trial

Table 36 Intervention, strength of evidence domains, and strength of evidence for key outcomes

Intervention | Domains pertaining to Strength of Evidence (SOE): | | | | SOE
Intervention | Risk of Bias | Consistency | Directness | Precision | SOE
Adaptive behavior
Behavioral, UCLA/Lovaas | Medium | Consistent | Direct | Imprecise | Low
Adverse events/harms
Medical, Antipsychotics (Aripiprazole) | Low | Consistent | Direct | Precise | High
Medical, Antipsychotics (Risperidone) | Low | Consistent | Direct | Precise | High
ASDs symptom severity
Behavioral, UCLA/Lovaas | Medium | Inconsistent | Direct | Precise | Low
Medical, Secretin | Low | Consistent | Direct | Precise | High (lack of effectiveness)
Challenging behavior
Medical, Antipsychotics (Aripiprazole) | Low | Consistent | Direct | Precise | High
Medical, Antipsychotics (Risperidone) | Low | Consistent | Direct | Precise | Moderate
IQ/cognitive
Behavioral, UCLA/Lovaas | Medium | Consistent | Direct | Precise | Low
Medical, Secretin | Low | Consistent | Direct | Precise | High (lack of effectiveness)
Language/communication
Behavioral, UCLA/Lovaas | Medium | Consistent | Direct | Precise | Low
Medical, Secretin | Low | Consistent | Direct | Precise | High (lack of effectiveness)
Repetitive behavior
Medical, Antipsychotics (Aripiprazole) | Low | Consistent | Direct | Precise | High
Medical, Antipsychotics (Risperidone) | Low | Consistent | Direct | Precise | Moderate
Social skills/social behaviors
Medical, Secretin | Low | Consistent | Direct | Precise | High (lack of effectiveness)

ASDs=Autism Spectrum Disorders; SOE=strength of evidence; SRIs-selective serotonin reuptake inhibitors; UCLA=University of California, Los Angeles

Table 37 Interventions/outcomes with insufficient strength of evidence by outcomes assessed

Intervention | Adaptive behavior | Adverse events/harms | Anger | Anxiety | ASDs symptom severity | Challenging behavior | Hyperactivity/inattention | IQ/cognitive | Joint attention | Language/communication | Motor/sensory | Repetitive behavior | Sleep | Social skills/social behaviors
Allied health, Auditory integration | ✓ | | | | | ✓ | | ✓ | | ✓
Allied health, Music therapy | | | | | | | | | | | | | | ✓
Allied health, PECS/RPMT | | | | | | | | | | ✓
Allied health, Sensory integration | | | | | | | | | | | ✓
Allied health, Other | ✓ | | | | | | | | | ✓ | ✓ | | | ✓
Behavioral, CBT (commonly associated conditions) | | | ✓ | ✓ | | | | | | ✓
Behavioral, ESDM | ✓ | | | | ✓ | | | ✓ | | ✓
Behavioral, Imitation (play-/interaction-based) | | | | | | | | | | | | | | ✓
Behavioral, Joint attention/symbolic play (play-/interaction-based) | | | | | | | | | ✓
Behavioral, Other— Neurofeedback | | | | | ✓
Behavioral, Other— Sleep | | | | | | ✓ | | | | | | ✓ | ✓
Behavioral, Parent & teacher training (commonly associated conditions) | | | ✓ | ✓ | | ✓
Behavioral, Parent training (early intensive behavioral) | | | | | | | | | | ✓ | | ✓ | | ✓
Behavioral, Parent-focused (play-/interaction-based) | | | | | | ✓
Behavioral, Relationship-focused (play-/interaction-based) | | | | | | | | | | | | | | ✓
Behavioral, Social skills | | | | | | | | | | | | | | ✓
CAM, Acupuncture | | | | | | | | | | ✓ | | | | ✓
CAM, Massage | ✓ | | | | | | | | | | ✓ | | ✓
Educational, Broad-based | | | | | | | | ✓ | | ✓ | | | | ✓
Educational, Computer-based | | | | | | | | | | ✓
Educational, TEACCH | | | | | | | | ✓ | | ✓
Medical, Antipsychotics (Cyproheptadine+Haloperidol) | | | | | | ✓ | | | | | | ✓
Medical, Dietary & other | | | | | ✓ | ✓ | | | | ✓ | | | ✓
Medical, Guanfacine | | ✓ | | | | | ✓
Medical, SRIs (all) | | ✓ | | | | ✓ | | | | | | ✓
Medical, Stimulants | | ✓ | | | | | ✓

CAM=complementary and alternative medicine; CBT=cognitive behavioral therapy; ESDM=Early Start Denver Model; PECS=Picture Exchange Communication System; RPMT= Responsive Education and Prelinguistic Milieu Teaching SRI=serotonin reuptake inhibitor; TEACCH=Treatment and Education of Autistic and Communication related handicapped CHildren

## Outcomes and Strength of Evidence of Therapies

### Effectiveness of Behavioral Interventions

Categories of behavioral intervention studies included early intensive behavioral and developmental intervention studies, social skills approaches, play- and interaction-based approaches, interventions focused on commonly associated conditions, and studies of additional behavioral interventions. Tables 27 through 31 summarize effectiveness findings for studies of behavioral approaches.

Early intensive behavioral and developmental interventions. We adopted a similar approach to the operationalization of this category as Rogers and Vismara12 in their review of “comprehensive” evidence-based treatments for early ASDs. Interventions in this category have their basis in or draw from principles of applied behavior analysis (ABA), with differences in methods and setting. ABA is an umbrella term describing principles and techniques used in the assessment, treatment and prevention of challenging behaviors and the promotion of new desired behaviors. The goal of ABA is to teach new skills, promote generalization of these skills, and reduce challenging behaviors with systematic reinforcement. The principles and techniques of ABA existed for decades prior to specific application and study within ASDs.

We first discuss two intensive manualized interventions: the UCLA/Lovaas model and the ESDM. These two interventions have several key differences in their theoretical frameworks and implementation, but are similar in the frequent use of high intensity (many hours per week, one-on-one) instruction utilizing ABA techniques. They are described together here because of these similarities. The UCLA/Lovaas method relies heavily on one-on-one therapy sessions during which a trained therapist uses discrete trial teaching with a child to practice target skills, while the Early Start Denver Model (ESDM) blends ABA principles with developmental and relationship-based approaches for young children.

The other treatment approaches in this section also incorporate ABA principles, and may be intensive in nature, but often have not been manualized. We have classified these approaches broadly as UCLA/Lovaas-based given their similarity in approach to the Lovaas model. A third set of interventions included here use the principles of ABA to focus on key pivotal behaviors rather than global improvements. These approaches emphasize parent training (e.g., Pivotal Response Training, Hanen More than Words, social pragmatic intervention, etc.) and may focus on specific behaviors such as initiating or organizing activity or on core social communication skills. Because they emphasize early training of parents of young children, they are reviewed here.

Summary. We located 38 papers100–133,178,290,294,295 comprising 34 unique studies addressing early intensive behavioral and developmental interventions. Individual studies using UCLA/Lovaas-based interventions or ESDM report improvements in outcomes for some preschool and early school-aged children. Improvements are most often seen in cognitive abilities and educational attainment, and less consistently in adaptive, social, and challenging behaviors. Of note, however, even children who have meaningful improvement in specific areas (most commonly in cognitive skills) often continue to have substantial impairment in adaptive, social, and behavioral functioning. This sustained level of impairment, along with a lack of longer-term outcomes data, makes it difficult to assess whether treatment-related changes can modify long-term functional and developmentally appropriate adaptive independence.

To date, studies have failed to characterize adequately the subpopulation of children who experience positive response to intervention, although it is clear that positive outcomes are more prominent in some children but not others. One powerfully replicated finding is that not all children receiving early intensive intervention demonstrate robust gains, and many children continue to display prominent areas of impairment. Nonetheless, dramatic improvements are observed in a subset of children and even small improvements in standardized outcomes may translate into meaningful improvements in quality of life. Early intensive behavioral and developmental approaches have significant potential, yet require further research.

Unfortunately, there have been to date very few well-controlled trials and those conducted have used small samples; different treatment approaches (i.e., developmental to intensive behavioral); intensity (12 hours over 3 months vs. 30 hours over 1 week); and duration (weeks to years); varied inclusion and baseline assessment criteria; children of varying ages (intake age ranging from 18 months to 7 years); and different outcome measurements over different periods of time (weeks to years).

Observational and noncontrolled studies also have reported improvement for children receiving early intensive treatments when compared with eclectic treatments. Positive outcomes have been most common when early intensive behavioral and developmental interventions are systematically delivered by expert providers, including well-supervised and trained parents, over fairly lengthy intervals of time (> 1 year). A challenge to interpreting the observational literature, however, is that although authors assert that they used early intensive behavioral and developmental interventions, many of the studies are inadequately described, fail to include fidelity and treatment adherence measurements and procedures, and may in fact be delivering very different interventions. As a result, the body of observational literature categorized in this report as “early intensive behavioral” is so disparate that conclusions cannot easily be drawn.

Few studies directly comparing the effects of different treatment approaches are available (for example, direct comparison of UCLA/Lovaas and ESDM), and few data on practical effectiveness or feasibility beyond research studies exist, so questions remain about whether reported findings would be observed on a larger scale within communities. Similarly, no studies in this category reported harms of intervention.

Less intensive interventions to provide parent training for bolstering social communication skills and managing challenging behaviors may be useful for younger children with ASDs, particularly to improve social communication, language use, and potentially symptom severity and family functioning.108,109,120,295 However, while parent training programs can modify parenting behaviors during interactions, data are limited about their contribution to specific child improvements in the short- and long-term beyond simple language gains for some children.

Strength of evidence. In general, there are too few studies of either UCLA/Lovaas-based approaches, ESDM, or intensive parent training approaches to assert that observed estimates of effect for either approach are unlikely to change with future research. With a relatively larger (albeit still inadequate) body of literature, the UCLA/Lovaas studies report positive shifts in language, adaptive, cognitive and educational outcomes, but our confidence (strength of evidence) in that effect is low, based on the need for additional, confirmatory research (Table 27). With only one RCT, we can only judge the literature on ESDM to be insufficient; although results in this one study were positive and the study warrants replication. On balance, however, the combined research on UCLA/Lovaas and ESDM suggests a benefit of early intensive approaches for some children that should continue to be studied. The evidence for parent training interventions was insufficient; the few available studies used interventions that varied from study to study. Furthermore, outcomes assessed in these studies were frequently short-term, indirect (intermediate) measures.

#### Social Skills Training

Summary. We located 16 papers addressing interventions targeting social skills.135–149,152 Although all of the studies of social skills interventions reported some encouraging results, most have not included objective observations of the extent to which social skills improvements are maintained within everyday peer interactions. In addition, the current research focuses almost exclusively on children considered high functioning based on IQ and language skills, excluding the majority of children diagnosed with an ASD. The quality of the studies was poor to fair, although some results may suggest benefit for a subgroup of particularly high functioning children. No two studies evaluated the same intervention, making it impossible to know whether observed results are likely to be consistently observed. No studies reported harms of intervention.

Strength of evidence. The strength of evidence for the effect of social skills interventions on social outcomes is insufficient (Table 28). Of 8 RCTs, four were fair in quality and none was good. All studies did demonstrate benefit on at least one outcome measure but a lack of consistency in the interventions or outcome measures makes it impossible to assess consistency or precision. Most studies relied on report of intermediate outcomes.

#### Play- and Interaction-Based Interventions

Summary. Fifteen papers (13 unique study populations) assessed play-/interaction-based approaches.153–167 Parent training in play-based interventions shows some promise for reducing challenging behavior and encouraging early social communication skills (e.g., joint attention and symbolic play). Joint attention and symbolic play interventions also promoted expressive language growth.155,156 No studies reported harms of intervention.

Strength of evidence. Although there were at least two RCTs available for most categories of play interventions (parent-focused, relationship-based, imitation, joint attention and symbolic play), none was of good quality and the diversity of specific interventions and outcomes prohibits drawing conclusions about specific approaches (Table 29).

#### Behavioral Interventions for Commonly Associated Conditions

Summary. We identified 11 studies reported in 12 papers 25,26,168–177 that addressed behavioral interventions focused on symptoms commonly associated with ASDs. Most studies of behavioral interventions to address commonly associated conditions are limited to high-functioning children (based on IQ) with ASDs who are at least school age. These studies evaluated behavioral treatments for commonly occurring comorbid symptoms in ASDs, including anxiety, anger management difficulties, and challenging behaviors. All report promising results, with caveats concerning study quality.

Interventions included cognitive behavioral therapy in individual and group formats, parent training, and teacher training to address target symptoms. Cognitive behavioral therapy (CBT)-based treatments varied across studies and were generally adapted from existing manuals to be more amenable for use in children with ASDs. Several studies suggested that CBT-based interventions were effective in reducing anxiety symptoms.26,170,171

This category of intervention also included various parent training approaches to decrease challenging behaviors. Results of two studies combining parent training with risperidone treatment suggested that adding parent training to medication increased adaptive behavior and decreased noncompliance and irritability/aggression in children with ASDs.172,177 Another set of parent training studies suggested that training parents improved both the frequency and intensity of a child’s challenging behaviors.174,175

While individual studies of CBT and parent training for decreasing comorbid anxiety, anger management, and externalizing symptoms reported positive results, results should be interpreted cautiously. The small number of studies overall use disparate intervention approaches and different outcome measures. Additionally, in some of these studies, parents were involved in delivering the interventions and completed the majority of questionnaires to assess symptoms before and after treatment. No studies reported harms of intervention.

Strength of evidence. Current strength of evidence for CBT- based, parent-training, and teacher-training interventions on comorbid symptoms is insufficient. Consistent positive findings of improvement in anxiety, anger, and challenging behavior levels are offset by variation among the interventions and outcomes assessed (Table 30).

#### Additional Behavioral Interventions

Summary. Three studies181–183 of additional behavioral interventions (neurofeedback, sleep workshops) met our inclusion criteria. These intervention studies were limited by small sample sizes, short-term followup and largely parent-reported outcomes. No studies reported harms of intervention.

Strength of evidence. With few studies of additional behavioral interventions, all of poor quality, there is insufficient evidence to evaluate the relative effect of other behavioral interventions on targeted outcomes including ASDs symptom severity, problem behaviors, and sleep concerns (Table 31).

### Effectiveness of Educational Interventions

Studies of educational interventions. Interventions intended primarily to be administered in educational settings, or studies for which the educational arm was most clearly categorized, were included in this category. This included studies of the Treatment and Education of Autistic and Communication related handicapped CHildren (TEACCH) program, computer-based educational intervention studies, as well as studies implemented in educational settings based on principles of ABA that were intensive in nature (broad-based studies).

This third group of studies is included in this section because they were implemented in an educational setting and they did not utilize a specific treatment manual (e.g., UCLA/Lovaas, ESDM). We note that these studies make use of intensive behavioral approaches as comparators. They are included here because the educational arms of the studies are more clearly characterized than the ABA arms. Our conclusions would not have changed had these studies been included in the early intensive behavioral and developmental section of the report.

Summary. The TEACCH program has historically been the most widely studied educational intervention, but the majority of research on it took place prior to the date cutoff for our review. Thus, only four studies met our criteria for inclusion.185–188 This newer research continues to report some improvements in motor and cognitive measures.

Among the studies of broad-based interventions evaluating the setting and the type of instructional strategy, one study195 found that children in both a home-based early intensive behavioral intervention and an autism-based nursery program improved at similar rates, and that child characteristics including IQ and receptive language at baseline were strong predictors of progress. An additional study192 suggested that home-based ABA teaching interventions were more effective than those in a school-based intervention borrowing from TEACCH, and a home-based portage program, in which parents were provided training to conduct the intervention at home. Few studies of computer-based interventions met our criteria, and those that did employed varied approaches. No studies of educational interventions included here reported harms.

Strength of evidence. The strength of evidence for positive outcomes observed for educational interventions on all outcomes measured (cognitive, socialization, communication) was insufficient based on too few studies measuring the same outcomes (Table 32).

### Effectiveness of Medical and Related Interventions

#### Medical and Related Interventions

Summary. Although no current medical interventions demonstrate clear benefit for social or communication symptoms in ASDs, a few medications show benefit for repetitive behaviors or associated symptoms. Given that many children with ASDs are currently treated with medical interventions,41–43 strikingly little evidence exists to support clear benefit for most medical interventions, especially in the realm of interventions such as restrictive diets and supplements.

We located 17 papers from nine studies addressing antipsychotic medications;201–207,208,209–217 five studies addressing serotonin reuptake inhibitors (SRIs);220–224 six publications228–233 from four studies evaluating stimulants and other medications for hyperactivity; eight studies addressing secretin;234–241 and 17 papers (16 unique studies) addressing dietary and other medical interventions.64,242–257

The clearest evidence favors the use of medications to address challenging behaviors (Table 33). Risperidone and aripiprazole are the two best-studied medications in ASDs, with the corresponding pharmaceutical companies funding at least one RCT for each. Each medication now has at least two RCTs demonstrating improvement in a parent-reported measure of challenging behavior that includes emotional distress, aggression, and self-injury. A parent-reported hyperactivity and noncompliance measure also showed significant improvement. Although it was not the primary target behavior addressed in these studies, repetitive behavior also showed improvement with both risperidone and aripiprazole. Both medications also cause significant side effects, including marked weight gain, sedation, and risk of extrapyramidal symptoms. When considered in aggregate, risperidone and aripiprazole are efficacious but are associated with significant side effects that limit their use to patients with severe impairment or risk of injury (Table 33).

Secretin has been exhaustively studied in multiple RCTs with clear evidence that it lacks benefit in ASDs. Amantadine, N-dimethylglycine, oral immunoglobulin, and the chelating agent dimercaptosuccinic acid (DMSA) showed no benefit in single RCTs. Methylphenidate improved hyperactivity in the ASDs population in an RCT, and a followup analysis suggested possible improvements in a measure of social communication. An RCT of hyperbaric oxygen treatment showed benefit on general ratings of improvement. The SRI fluoxetine showed benefit for repetitive behavior in a single cross-over RCT; although this effect was driven by only one arm of the study.220 An RCT of the SRI citalopram222 showed no benefit for repetitive behavior but possible improvement in irritability/problem behavior.

Strength of evidence. We rated the strength of evidence for the effect of atypical antipsychotic medications on challenging behavior and repetitive behavior to be moderate for risperidone and high for aripiprazole (Table 33). There were a total of six RCTs in this area, three of which had good quality and the other three fair. They produced consistent and precise estimates of effect. Strength of evidence around adverse events is high for both aripiprazole and risperidone, based on RCTs and case series. Common side effects included weight gain, sedation and extra-pyramidal effects.

It is clear from existing research that secretin is not effective in affecting language, cognition, behavior, communication, autism symptom severity, and socialization skills, and the strength of evidence for this lack of effectiveness is high. With seven RCTs with fair to good quality scores and one case series contributing to this evidence base, future studies are unlikely to change the estimate of effect for this treatment.

With only one good quality RCT available, and an additional RCT of fair quality, we consider the strength of evidence for the ability of SRIs to reduce repetitive behavior to be insufficient. SRIs were also studied for their effect on irritability/problem behavior, but the one good RCT on SRIs did not focus primarily on this outcome. The direction of the effect was inconsistent given that worsening of behavior can be an adverse effect of the treatment, and we assessed the strength of evidence for this relationship to be insufficient. Evidence of adverse effects with SRIs (decreased sleep and increased energy) had insufficient strength of evidence (two RCTs, one of which was good) with variability in how the outcomes were measured. The strength of evidence for the effects of both stimulants and guanfacine on hyperactivity was insufficient. Evidence was also insufficient for assessing the strength of evidence of varied medical and dietary interventions including hyperbaric oxygen, ketogenic diet, omega 3 fatty acids, and cholinesterase inhibitors (Table 33).

### Effectiveness of Allied Health Interventions

#### Language and Speech

Summary. Our search identified eight publications focused on speech and language interventions (Picture Exchange Communication System [PECS] and Responsive Education and Prelinguistic Milieu Teaching [RPMT]),258–265 representing four distinct study populations. Both interventions were effective at increasing the number of words used by children early after intervention (up to 3 months) but neither showed maintenance of improvements over the longer term. No studies reported harms of intervention.

While ultimate benefit of these reviewed speech and language interventions in terms of advancing core language skills over time is limited given the existing research, an emerging strength of this reviewed literature has been direct comparison of specific intervention techniques (e.g., PECS vs. RPMT) as well as appropriate analysis of the factors that moderate treatment impact. Specifically, this emerging literature has demonstrated in preliminary fashion that certain children respond to certain interventions differently based on their clinical profile.258–261 Such a study demonstrates that this underlying assumption of differential response to treatment is a reality for some children with autism related to language intervention.

Strength of evidence. Data from studies in this review were insufficient at this time to rate the strength of evidence for language-focused interventions.

##### Sensory and Auditory Integration

Summary. We located seven papers,89,266–271 comprising five unique studies addressing sensory or auditory integration. One study reported harms of intervention.269

Strength of evidence. Data from studies in this review were insufficient to rate the strength of evidence related to sensory and auditory integration training for improving language skills, challenging behaviors, or cognitive ability in low functioning children with autism (Table 34). While earlier studies (reviewed in Baranek, 2002^16^) suggested some positive outcomes associated with auditory integration, newer, well-designed studies described here contradict older findings in showing no improvements in the treatment groups.

#### Allied Health Additional Studies

Summary. We found eight studies272–279 addressing disparate additional allied health interventions. No studies reported harms of intervention.

Strength of evidence. Insufficient evidence is available to assess these interventions, including animal-assisted occupational therapy, prism lenses, and systematic feeding training. In sum, there have been few studies in the past decade examining the effectiveness of allied health interventions with sufficient sample size to consider closely (Table 34), although these approaches are often pursued by parents of children with autism. It will be important for future research to prioritize studying these treatments using rigorous methodologies to clarify whether (or for what outcomes) these treatments may be effective.

### Effectiveness of CAM Interventions

#### Complementary and Alternative Medicine (CAM)

Summary. Much of the CAM research (seven studies280–286) meeting our inclusion criteria is preliminary (Table 35). Brief trials of massage therapy284,286 suggest a potential role for massage in promoting sleep and behavioral improvement in children with ASDs. Pilot studies of acupuncture provided insufficient evidence based on small sample sizes and treatment duration.280,281 Studies included here did not report harms of intervention.

Strength of evidence. We found very few studies of complementary and alternative medicine, so evidence in this area also is insufficient to evaluate effects on outcomes assessed including sleep, language, social skills, sensory difficulties, and adaptive behavior (Table 35).

### Assessment of Domains for Strength of Evidence

Table 36 illustrates assessments for each domain (risk of bias, consistency, directness, and precision) pertaining to strength of evidence for each of the major intervention-outcome combinations in this review that received a strength of evidence rating of low or high. As noted in the Evidence-based Practice Centers’ Methods Guide for Effectiveness and Comparative Effectiveness Reviews,99 risk of bias reflects issues in study design and conduct that could result in biased estimates of effect. Consistency reflects similarity of effect sizes seen across studies. Consistency cannot be assessed when only one study is available. Directness is a reflection of the relationship between the intervention and the ultimate health outcome of interest. Precision is an assessment of certainty around the effect observed.

Most intervention-outcome combinations have insufficient strength of evidence at this time, often because studies were either too diverse in interventions and outcomes studied to summarize, or because the field is early in its development (Table 37).

## KQ2 Modifiers of Treatment Outcomes

Understanding the degree to which child characteristics (i.e., specific ASDs related difficulties and skills), treatment factors (e.g., type, duration, intensity), and systems (e.g., family, community) influence response to treatments could improve targeting of treatments to the appropriate children and circumstances. However, with rare exceptions,259,260,287 few studies are designed or powered to allow analysis of heterogeneous effects. Although we sought studies of treatment modifiers, only one included study259,260 actually demonstrated true treatment modifiers based upon appropriate study design and statistical analysis. One other study287 was designed to examine the role of provider on outcomes, but showed no difference, possibly because it was underpowered to do so.

This first study259 included an analysis of initial characteristics of the children demonstrating that children who were low in initial object exploration benefitted more from RPMT, which explicitly teaches play with objects, while children who were relatively high in initial object exploration demonstrated more benefit from PECS. These results were maintained at 6 months. An additional analysis based on this study260 showed greater increases in generalized turn taking and initiating joint attention in the RPMT group than in PECS. The increased benefit for RPMT in join attention was only seen, however, in children who began the study with at least some initiation of joint attention. Specifically, children most likely to benefit from RPMT in increasing joint attention had demonstrated at least seven acts of joint attention in the pre-intervention assessment. RPMT was also superior in this analysis in increasing object exchange turns.

One study287 explicitly sought to examine the impact of provider choice (parent versus professional) using similar interventions in an RCT. The study did not show a difference in outcomes for children receiving UCLA/Lovaas protocol-based intervention in a clinical setting versus at home from highly trained parents. Both clinic and parent groups received over 30 hours of intervention weekly and no group differences related to IQ, language, adaptive behavior, or other outcomes were seen. Children in both groups demonstrated substantial gains in a number of areas. Nonetheless, the results do provide further evidence of response to treatments anchored in the UCLA/Lovaas method, with some children demonstrating rapid acquisitions of new skills and change in IQ. Other studies not specifically designed to examine modifiers have also compared parent to clinic-based interventions126,132,288 and demonstrated equivalent group change when delivered in the same intensity.

Other studies in this section are those in which potential correlates were identified that may be moderators, but have not been studied as such. These potential moderators should be assessed in properly designed and powered studies for this purpose.

In terms of correlates with positive outcomes, several investigations have noted that pretreatment IQ and language predicts IQ at followup in early intensive behavioral and developmental studies.101,104,115,124,287 However, other studies have suggested having a lower IQ at initiation of treatment is related to increased change in IQ over time 127 or failed to find a relationship between IQ and change in response to intervention.102,126,132 IQ and verbal ability also predict treatment outcomes in educational interventions. Baseline language/communication skills may also correlate with treatment success, with studies generally suggesting a benefit for communication skills, including changes in ASDs classification associated with baseline language skills in an UCLA/Lovaas-based approach.102,124 Similarly, social skills studies have found verbal skills, either verbal comprehension (using the Verbal Comprehension Index) or expressive communication skills to be associated with greater improvements in social skills.

Data on the degree to which earlier age of treatment initiation is associated with better outcomes with early intensive behavioral and developmental intervention is conflicting. Studies suggesting a preference for early intervention may be confounded by characteristics of treatment.129

Finally, some studies suggest that specific constellations of symptoms related to ASDs may be important in understanding response to treatment. Social responsiveness and imitation skills have been suggested as skills that may predict improved treatment response in UCLA/Lovaas treatment,287 whereas “aloof” subtypes of ASDs have been suggested to be associated with less robust changes in IQ,107 and lower baseline symptom tallies have also been related to specific gains.104 Other studies have seen specific improvement in early intensive intervention for children with PDD-NOS vs. Autistic Disorder diagnoses,114 which may be indicative of baseline symptom differences. However, many other studies have failed to find a relationship between autism symptoms and treatment response.

In the medical literature, some characteristics of the family and child were found to be associated with treatment success, including a history of psychiatric diagnoses in the family and early verbal skills in the child correlating with treatment response to fluoxetine in a case series.224 One pharmacogenetic study assessed variation in the serotonin transporter gene for predicting lack of treatment response to escitalopram; although replication will be required to confirm the initial findings.223 Several studies of stimulant use highlighted differences in effectiveness by diagnosis type228–230,232,233 finding that children with Asperger syndrome were typically more responsive to psychostimulant treatment than those with autistic disorder. The presence of co-morbid intellectual disability was associated with lower response to psychostimulant treatment in one study.232

## KQ3 Early Results in the Treatment Phase That Predict Outcomes

Information about early response to treatment, or lack thereof, could guide treatment selection, implementation, and modification. The reviewed literature offers almost no information about what specific observations of children might be made early in treatment to predict long-term outcome and response. Some evidence suggests that changes in IQ over the first year of treatment with UCLA/Lovaas-based approaches and ESDM predicts, or accounts for, longer-term change in IQ.287,290 However, findings also suggest that while gains in the cognitive domain might be accounted for primarily within the first year of treatment, changes in adaptive behavior in response to these same interventions may occur over a longer time frame110,133,287,290 if they occur at all.105

## KQ4 End of Treatment Effects That Predict Outcomes

Few studies assess end of treatment effects that may predict outcomes; however, this type of research is feasible as exemplified in one study which assessed language development and joint attention and play skills in 3 to 4 year old children with ASDs.155,156 Children in the symbolic play and joint attention intervention groups showed significantly greater growth in expressive language, initiation of joint attention, and duration of child-initiated joint attention over time than did participants in the control group (p<.01 to <.05, moderate to large effect sizes). Growth in receptive language was not significantly affected by the intervention from pre-intervention to 12 months post-intervention. Children in the symbolic play group also showed significantly more growth in play level than did children in either the joint attention (p<.01) or control (p<.001) groups.

The investigators also assessed differences in the amount (total hours) of intervention services (speech and overall) children in the three groups received post-intervention, with children in the control group receiving significantly more hours of overall services than either the joint attention or symbolic play groups (p<.05 and <.01, respectively); differences in hours of speech interventions received were not significant. Only the duration of child-initiated joint attention episodes was related to hours of intervention received post-treatment, with children with fewer hours of overall services showing greater growth in child-initiated joint attention episodes.155 Hours of speech interventions received did not affect growth in skills.

## KQ5 Generalization of Treatment Effects

Few studies included in this review explicitly measured generalization of effects seen in treatment conditions to either different conditions or locations. The majority of studies in the behavioral interventions targeting associated conditions did not measure outcomes in the treatment context (i.e., within therapy sessions or groups). Outcomes were primarily assessed using parent, self, and/or teacher report of targeted symptoms (e.g., anxiety, externalizing behaviors) at home, at school, and in the community, suggesting that those interventions conducted in a clinical setting for which measured outcomes were positive may generalize in the sense that they achieve outcomes in the daily context/life of the child. On the other hand, in most cases, these outcomes are parent reported and not confirmed with direct observation. Behavioral intervention studies rarely measured outcomes beyond the intervention period, and therefore, we cannot assume that effects are maintained over time.

In medical studies, although the treatment is prescribed in a clinical setting, it is generally administered at home, and one would expect effects of medications to be observed in terms of behavior in the home and other settings. However, medical studies may be good sources of information on the duration of perceived effects. Unfortunately, other than case series data for risperidone177,203,204,206,213 demonstrating continued effects and side effects beyond six months. Few data are available on longer term outcomes of medical treatment.

## KQ6 Drivers of Treatment Effects

We identified no studies answering this question.

## KQ7 Treatment Approaches in Children Under Age Two at Risk for ASDs

Research on very young children is preliminary but promising, with only four studies identified in our review.178,290,294,295 One was a good quality RCT290 that suggested benefit for the use of ESDM in young children with improvements in adaptive behavior, language, and cognitive outcomes. Diagnostic shifts were also seen in close to 30 percent of children (but still on the autism spectrum). The observed diagnostic shifts, however, were not associated with clinically significant improvements in terms of ADOS severity scores or other measures. Developing interventions directed to toddlers that take into account the diagnostic uncertainty at this age is a critical need. Therefore, we considered the strength of evidence in this area currently insufficient, pending additional data.

## Quality Considerations

To better understand methodological challenges in the autism literature, we calculated the distribution of quality scores for the medical and behavioral (including educational studies). Medical studies had a higher threshold for subject number (30) to be included in the review in comparison to behavioral studies (10). This may have resulted in a different pattern of study types in the two literatures. Studies in other intervention categories were too few in number to examine in this way.

Just over half (58 percent behavioral; 64 percent medical) did employ a group design (i.e., included a comparison group); of the studies with comparison groups, 64 percent of behavioral and 100 percent of medical studies were randomized. Although almost all (87 percent behavioral; 100 percent medical) adequately described their intervention by our criteria, few (32 percent behavioral; 38 percent medical) provided any measure of fidelity or adherence. Only 22 percent of behavioral studies reported differences in or held steady concomitant interventions that might have served as confounders of the observed effect. Sixty seven percent of medical studies did so. Outcome measures were almost always considered valid (94 percent behavioral; 93 percent medical); 26 percent of behavioral studies reported outcomes coded by individuals blinded to the intervention status, compared with 64 percent of medical studies.

Of particular note in the quality assessment is lack of adequate characterization of participant populations. Twenty-one percent of behavioral studies and only 33 percent of medical studies reported using a combination of clinical Diagnostic and Statistical Manual of Mental Disorders-Fourth Edition (DSM-IV) with the ADOS and/or Autism Diagnostic Interview-Revised (ADI-R) to diagnose or confirm diagnoses of ASDs. More than 35 percent of behavioral studies either did not use or did not report use of the DSM-IV or ADOS. Analytic approaches were problematic with 56 percent of behavioral and 67 percent of medical studies conducting using appropriate statistical approaches. Quality scores for each study in this report are presented in Appendix H.

## Applicability

By definition, autism spectrum disorders are heterogeneous. Characterizing a “typical“ child with an ASD is not possible, although certain symptoms are central to the range of children within the autism spectrum. Individual therapies are developed and tested to ameliorate specific symptoms or groups of symptoms, often in a fairly circumscribed subset of children. Ideally, research on therapies for ASD should target children most likely to benefit from a particular focus; thus details on the population, intervention, comparator, outcomes, and setting (PICOS) for each intervention category are provided in Appendix I to support translation of our findings and assessment of the applicability of each for differing circumstances and children.

Furthermore, although interim, clinically based improvement is important, longer term functional outcomes are the goal for autism interventions. In terms of followup for assessing durability of effects, most studies report on outcomes collected immediately post-treatment or within 3 months of treatment (76 percent of studies in the behavioral literature, 86 percent in the medical literature). Additional research is needed on the degree to which changes observed during treatment translate to functional outcomes over time should treatment be discontinued.

Behavioral interventions. Studies of early intensive behavioral and developmental interventions were conducted primarily in preschool and young children (i.e., typically children initially ages 2–7) and as such questions remain about how these approaches apply to and benefit younger children with (≤ 2) at-risk for ASD. The cognitive, language, and adaptive behavior profiles of participants included in these studies were generally in line with those seen in the community (i.e., typically marked by substantial impairment/delay, but with some children with more intact early cognitive/language profiles).

The range of approaches studied may not always match what is available in practice. That is, the studies were often either conducted in highly controlled environments (e.g., university supported intervention trials) or the methodology was not well-described (i.e., non-manualized approaches). Thus, individuals wishing to infer the potential results of clinical practice based on the available research need to assess carefully the degree to which the study methods matched those available and used in practice. Two of the primary intensive behavioral intervention programs (UCLA/Lovaas and ESDM) publish and/or employ manuals for intervention, but implementing them requires sophisticated training and oversight that will continue to make translation to common practice difficult.

Studies of parent training interventions for preschool children, often emphasizing principles of ABA, aligned with current practice and the target populations that are typically referred for these services. Training programs often included components to improve social communication skills such as joint attention, play-based interactions, and pragmatic language approaches; interventions were conducted for approximately 1–4 hours/week with parents asked to introduce learned techniques within natural settings. Several programs offer manualized versions of training that can be adopted in other settings with appropriate training.

Most studies of social skills interventions targeted elementary school aged children (between 6 and 13 years old). Only one study targeted younger children (4 to 6 years old); although such interventions may be important in this younger age group. Most also excluded children with IQs below 60 and 6 of the studies specifically targeted children with high functioning ASD or who were diagnosed with Asperger disorder only. Therefore, evidence on social skills interventions is likely applicable to older, higher functioning children only. Similarly, CBT for commonly associated conditions was targeted toward older children who were high-functioning, some with Asperger disorder only, or excluded those with intellectual disabilities. The effectiveness of both of these types of interventions in other groups of children with ASD is currently unknown.

Studies of play-based interventions were generally conducted in clinic settings with children whose ages ranged from 3 to 12 years. Further research is needed to assess the utility of these approaches outside of the clinic.

Medical and related interventions. In the medical literature, study participants were generally recruited from non-primary care populations. As such, families of these children may be seeking a higher level of care than those of the broader population of children with ASDs based upon more severe or acute symptoms, including aggression or other challenging behaviors. Most studies of medical interventions targeted elementary school aged and older children with autism, with little data on the treatment of younger children. Some studies also expanded their inclusion criteria to include children with Asperger syndrome or PDD-NOS.

For some medications, age could be an important modifier of treatment, which should be considered in future studies. As one example, SRIs were reported to be helpful for repetitive behaviors in adults in a previous RCT, but more recent data in children shows less clear evidence for benefit.

In addition to the limitations of the actual populations studied, some characteristics of the family and child were found to be correlated with treatment success within individual studies as noted in the discussion on modifiers. Most of these correlates are difficult to interpret in the absence of studies that directly assess modifiers. Further research will be necessary to evaluate whether family history, cognitive profile,224 or diagnosis within the autism spectrum could be a modifier.

## Review of Systematic Reviews

Because we limited our review to studies published after the year 2000, we reviewed existing systematic review literature so as not to lose important information published previously. Our findings in the current review concur with findings in the previously available reviews in that some evidence supports effectiveness of early intervention approaches and interventions such as CBT.

Most of the reviews generally concluded that the evidence base for early intensive behavioral and developmental intervention is inadequate, noting variability in treatment and intervention, limited followup, lack of comparative studies, need for replication, and unclear inclusion and exclusion criteria.12,296,297 Meta-analyses from Reichow298 and Eldevik,299 reported more positive results, noting strong evidence for intensive ABA-based intervention effects in some children.298,299 Eldevik’s meta analysis of nine studies found an average large effect size for IQ change (1.103, 95 percent CI [CI=.871, 1.335]) and medium effect size for change on the VABS composite score (.660, 95 percent CI [CI=.41, .90]). The meta-analysis from Reichow and Wolery,298 including studies exclusively based on Lovaas’ treatment manuals or replicating the UCLA/Lovaas model and computing mean effect size based on change in the Lovaas group only, also reported a large effect size of .69 for IQ change and mean difference effect sizes suggesting greater gains for children receiving Lovaas-based intervention compared with those receiving minimal behavioral intervention, usual treatment, or eclectic treatment. Additionally, it is a subtle but important weakness concerning the review that evaluations of pre-post change as units of analysis are not sufficient for estimating treatment effects. More specifically, changes observed during the treatment phase may not be entirely accounted for as change because of a treatment.

Each of these reviews also notes significant concerns about the included studies, such as limited accounting for the effects of maturity, lack of equivalent groups, uncertain treatment fidelity, and small sample sizes. Several authors also noted the need for studies comparing intensive behavioral approaches to other approaches that have been similarly empirically tested.

Across all the reviews, areas noted for improvement in the literature included the need for more RCTs, though investigators acknowledge the difficulty of conducting RCTs with interventions of such complexity and ethical issues of withholding treatment for comparison purposes. Additional areas for improvement noted in reviews included the need for larger sample sizes; longer followup to allow for evaluation of the durability of effects; greater treatment fidelity; improved reporting of methodological and participant characteristics; and greater consistency in treatment approaches and outcomes measurement.

In terms of the quality of the reviews themselves, we assessed the reviews to be of generally good quality, though some elements of reporting were inconsistent across reviews. For example, few reviews12,17,296,300 explicitly reported author conflicts of interest, though, for example, investigators in one meta-analysis were authors of papers included in the analysis. Use of an a priori design was not always clearly stated though generally implied, and we considered review designs a priori if the review appeared to employ a standardized approach. Similarly, methods for reviewing abstracts and the full papers of studies were not always clearly described (e.g., use of dual reviewers), and six out of 10 reviews provided a complete (ample enough to likely permit replication) description of search terminology.17,296,297,300–302 Appendix G presents more information on our assessment of recent reviews.

## Future Research

### State of the Literature

Research on treatment approaches for autism has emerged primarily in the past two decades, and we focused our review on the last decade. Like any young research field, the body of evidence on therapies to treat core and concomitant symptoms of autism is characterized by a predominance of small studies with no comparison groups, a smaller set of nonrandomized cohort studies, and a very small set of RCTs. Only 13 of 159 of the studies were rated as good, although we see a clear evolution in the field toward greater rigor. Within our review, studies of medical interventions were more likely to be rated of higher quality. Several factors could account for this, including the higher minimum sample size that we set for medical interventions.

We felt that the higher risk involved in a child with an ASD taking a medication, pursuing a restricted diet, or participating in another medical intervention warranted a more rigorous standard for studies supporting possible benefit.

### Gaps in Areas of Research

Several treatment approaches show promise in early research, but remain understudied in rigorous designs. In the behavioral literature, these include early intensive behavioral and developmental interventions103,105,114,126,132,133,287,303 (e.g., UCLA/Lovaas model and variants), the ESDM approach,290, and parent training approaches (e.g., Pivotal Response Training, More than Words,295 Early Social Interaction294). In the medical literature, these include SRIs,222–224 methylphenidate,228–231,233 omega 3 fatty acids,246 and melatonin.244

A critical area for further research is understanding which children are likely to benefit from particular interventions. To date, studies have failed to adequately characterize the subpopulation of children who experience positive response, although positive outcomes are most prominent in some children but not others. One powerfully replicated finding is that not all children receiving early intensive intervention demonstrate robust gains, and many children continue to display prominent areas of impairment. Dramatic improvements are observed in a subset of children and mild improvements in terms of standardized outcomes may translate into meaningful improvements in quality of life. Early intensive behavioral and developmental approaches therefore have significant potential, yet require further research.

Data on modifiers of effectiveness is an important area for future study, and preliminary data suggest that some interventions, including intensive behavioral interventions, are likely to be most effective when targeted to yet undefined subgroups of children. Early research suggests child characteristics, such as baseline cognitive, language, and adaptive skill, correlate with treatment outcome; however, such correlational data provides limited information in making predictions of what treatments will work best for individual children. Additionally, the emergence of biomarkers and susceptibility genes may allow researchers to focus on additional characteristics beyond symptom profile that might be useful in personalizing treatment approaches, but research in this area is just emerging.

Behavioral interventions are by their nature often multi-component, and data on whether specific functional components of the interventions drive effectiveness are currently unavailable. Component analyses in this field would be productive to refine intervention approaches and assess applicability and generalizability of the results.

Along those lines, we found few studies providing specific evidence of the generalization of interventions (the maintenance of effects when factors such as the setting, individual providing the intervention, or situational factors are changed). It is essential for families of children with autism to understand the degree to which intervention effects observed during treatment are likely to translate to functional behavior changes in their child at home or in school.

Further, as proposed treatments methods often rely heavily upon parents as coordinating influences and/or primary interventionists, examination of the characteristics of families that modify treatment appears another area for potential examination.

In the social skills literature, we identified several studies139,140,144,146,147,149 that were the first report of the particular intervention. These approaches are candidates for replication. Most focused on group interventions and more consideration of the potential for family-oriented or individual intervention is warranted. This literature overall focuses almost entirely on high functioning children with ASDs, and it would be helpful to consider whether social skill interventions have potential for a broader range of individuals. There was also a tendency in this area to focus on intermediate outcomes (e.g., recognition of facial expressions) with little information on whether these translate to longer term functional outcomes.

Because the treatment process for ASD is typically intensive, questions of feasibility and accessibility are germane, but understudied. A few studies in this literature made preliminary strides in addressing these issues, but studies that specifically measure the role of setting, provider and other factors would benefit our ability to inform implementation. We also recommend future consideration of the ways in which the cultural context of the child and family may affect applicability or effectiveness of specific interventions.

Almost no studies in the behavioral, educational, allied health or CAM literature reported harms. While adverse effects may appear less likely with some of these types of interventions, assessment of potential harms is warranted.

The medical literature lacks properly designed, appropriately powered randomized, controlled trials of a number of interventions that have been inadequately studied to date. Some of the strongest studies to support the use of medical interventions have been funded by pharmaceutical companies or device manufacturers that profit from the treatment. Certainly, the National Institutes of Health has funded some large-scale studies of a few medical interventions, but publicly funded studies of medications for ASDs are few and more are warranted.

Importantly, the marked improvements in challenging behaviors seen with risperidone and aripiprazole support the study of other atypical antipsychotic medications that do not cause as much weight gain or liability to metabolic disorders. Additionally, medications for hyperactivity and inattention symptoms deserve further scrutiny in autism. Dosing information remains inadequate in the stimulant literature and is particularly important for balancing positive outcomes with potential harms. The data on serotonin reuptake inhibitors are scattered and contradictory, with a particular need to consider modifiers such as age (childhood versus adult, see Posey et al.304 and pharmacogenetics.223 The largest published trial of an SRI, citalopram, found no effect at all on repetitive or compulsive behavior but found a possible effect on challenging behavior (ABC-C-Irritability) that warrants follow up in a study with challenging behavior as a focus.222 A number of other medical interventions are worthy of further study, including hyperbaric oxygen,254 which was studied in a single RCT by providers with a conflict of interest.

In addition to the need for further study of interventions with some existing research, the need for research on medical interventions with no existing research is tremendous.305 Clinicians who employ medical interventions without an existing research base should publish case series data to allow researchers to evaluate which treatments are worth studying in RCTs. Given that behavioral interventions are the mainstays of autism treatment, studies examining the effects of coupling medical and behavioral interventions are crucial to match the typical experience of most children with ASDs. Emerging data in other areas, including anxiety and mood disorders, suggest that medications and behavioral treatments may act in synergy to produce benefit, including studies on SRIs and cognitive-behavioral therapy,306–308 as well as recent studies on the use of cognitive enhancers to potentiate cognitive behavioral therapy.309

Finally, this literature lacks comparisons of medical interventions with behavioral interventions and combinations of the two, despite the fact that most children are undergoing multiple concurrent treatments. This approach has proven crucial in studies of obsessive compulsive disorder, depression, and anxiety,306–308 but only two studies of adequate size have considered combination treatment with risperidone and behavioral treatment, and these studies lacked an arm that considered behavioral treatment alone, in addition to lacking a placebo control.

### Methodologic Issues

A high proportion of studies in this review (36 percent) fail to use a comparison group, and while substantial strides have been made in the analysis of single-subject designs, these are not ideal for assessing effectiveness at a population level, nor are they appropriate for comparative effectiveness research. They are, however, used frequently in the behavioral literature, and so we address our decisions regarding them here. Because there is no separate comparison group in these studies they would be considered case reports (if only one child included) or case series (multiple children) under the rubric of the EPC study designs. Case reports and case series can have rigorous evaluation of pre- and post- measures, as well as strong characterization of the study participants.

Studies using this design that included at least 10 children were included in the review. Studies of this type can be helpful in assessing response to treatment in very short time frames and under very tightly controlled circumstances, but they typically do not provide information on longer term or functional outcomes. They are useful in serving as demonstration projects, yielding initial evidence that an intervention merits further study, and, in the clinical environment, they can be useful in identifying whether a particular approach to treatment is likely to be helpful for a specific child. Our goal was to identify and review the best evidence for assessing the efficacy and effectiveness of therapies for children with ASD, with an eye toward their utility in the clinical setting, and for the larger population of children with ASD. By definition, “populations“ in single-subject design studies are likely to be idiosyncratic and therefore not to provide information that is generalizable.

Nonetheless, even in studies with a comparison group, sample size is frequently insufficient to draw conclusions, and larger, multisite trials are needed across all treatment types. Furthermore, the choice of comparison groups in the studies that employed a group design was uneven. A number of studies used comparison groups that were inappropriate for observing group differences in treatment effect (e.g., comparing treatment in children with autism to the effects of the treatment in typically developing peers or to children with a different developmental disorder), and for those studies we could only use the pre-post case series data available in the group with autism, limiting the ability to comment on effectiveness.

We encourage investigators to provide adequate detail as they describe their interventions to allow for replicable research. In ideal circumstances, investigators publish and reference treatment manuals, but many studies made general references to their use of an underlying approach (e.g., ABA) without specifying the ways in which they used the technique or modifications they made to the original, published use of it. Lack of detail about the intervention makes it difficult to assess the applicability of individual studies, to synthesize groups of studies or to replicate studies.

Characterization of the study population was often inadequate, with 125 of 159 studies failing to use or report “gold standard“ diagnostic measures (clinical DSM-IV-based diagnosis plus ADI-R and/or ADOS) for the participants. Because ASDs are spectrum disorders, it is difficult to assess the applicability of interventions when the population in which they were studied is poorly defined or described. Authors often do not consider diagnostic criteria in selecting participants for their studies; nor do they fully describe the children who do participate. We recommend that investigators fully describe participants in their study, both diagnostically and otherwise. In addition, because the myriad causes of ASDs are unknown, even children with the same diagnosis may have distinct genetic or other “causes“ that could affect treatment effectiveness. Ideally, future research will better characterize participants genotypically and phenotypically.

We identified more than 100 distinct outcome measures used in this literature base, not accounting for subscales. The use of so many and such disparate outcome measures makes it nearly impossible to synthesize the effectiveness of the interventions, and we recommend a consistent set of rigorously evaluated outcome measures specific to each intended target of treatment to move comparative effectiveness research forward and to provide a sense of expected outcomes of the interventions. At the same time, the means for assessing outcomes should include increased focus on use of observers or reporters masked to the intervention status of the participant, and where some outcomes are measured in a masked fashion but others not, more emphasis should be placed on those that are.

In addition, many studies use changes in measures of IQ as outcomes, on the basis that IQ deficits are a powerfully impairing co-occurring index of ASD impairment and are therefore an important outcome, particularly in combination with social communication measures. However, IQ assessment for young children with ASDs is challenging as it is dependent not only on nonverbal cognition and receptive and expressive language, but also on a child’s ability to focus in an academic setting and to interact with the person administering the exam. Measures of IQ thus may not be the optimal tool for effectively measuring changes related to core ASD symptoms.

There also was a strong tendency for authors to present data on numerous outcomes without adjusting for multiple comparisons, and to fail to report the outcome that was the primary outcome of a priori interest and on which sample size calculations were based (when they were present). This may suggest a level of selective reporting bias in which results are published on a select group of outcomes that show the most effect. We attempted, but were unable, to identify a clear primary intended outcome in almost all of the papers.

Duration of treatment and follow up was generally short, with few studies providing data on long-term outcomes after cessation of treatment. Future studies should extend the follow up period and assess the degree to which outcomes are durable. Few studies adequately accounted for concomitant interventions that might confound observed effectiveness and this should be standardized in future research.

## Conclusions

The literature regarding therapies for children with autism spectrum disorders is of highly variable quality and in most specific areas limited and inconclusive. A few conclusions can be drawn, however.

In the behavioral literature, some evidence supports early and intensive behavioral and developmental intervention, including two randomized studies of intensive (i.e., interventions provided >30 hours per week) and comprehensive (i.e., addressing numerous areas of functioning) approaches. These included one UCLA/Lovaas focused approach and one developmentally focused ESDM approach.114,290 Both approaches demonstrated greater improvements in cognitive performance, language skills, and adaptive behavior skills when compared with broadly defined eclectic treatments in subgroups of children, although the strength of evidence (confidence in the estimate) is low pending replication of the available studies.

Not all children receiving such interventions demonstrate rapid gains, with some data suggesting that many children continue to display prominent areas of impairment114 and that subgroups may account for a majority of change within certain samples. It seems likely based on preliminary evidence that subgroups of children are more amenable to many of the interventions available. These could potentially include groups defined by initial IQ, language and verbal skills as well as severity of ASDs, but there may also be underlying skill differences that may better account for variability. Current evidence is insufficient, however, to adequately identify and target children most likely to benefit from specific interventions.

No studies directly compare effects of different treatment approaches (for example, there are no direct comparisons of UCLA/Lovaas and ESDM) and there is little evidence of practical effectiveness or feasibility beyond research studies, so questions remain about whether reported findings would be observed on a larger scale within communities. Furthermore, the studies conducted have used small samples, drastically different treatment approaches and duration and different outcome measurements. Nonetheless, improvements occur in some aspects of language, cognitive ability, adaptive behavior, challenging behaviors and potentially improved educational attainment for some children.

While some previous reports13,296,297 have suggested that it may be unethical to conduct randomized studies of early intensive interventions in the presence of evidence of benefit, the low strength of this evidence suggests that more rigorous trials or well conducted prospective cohort studies are needed.

Strength of evidence is insufficient for the effects of social skills training for older children and for play and interaction based approaches for younger children. Cognitive behavioral therapy for associated conditions such as anxiety also has insufficient strength of evidence supporting positive outcomes.

There is insufficient strength of evidence for improvements in cognitive outcomes with educational interventions, including the TEACCH intervention, and insufficient strength of evidence for broad-based approaches often based on ABA principles.

A few medications show benefit for repetitive behaviors or associated symptoms, with the clearest evidence favoring risperidone and aripiprazole, both studied in RCTs and showing evidence of improvement in problem and repetitive behavior. Significant side effects, however, make it clear that although these drugs are efficacious, caution is warranted regarding their use in patients without severe impairments or risk of injury.

A few other medical interventions show some promise for future research, including SRIs,222–224 methylphenidate,228–231,233 omega 3 fatty acids,246 and melatonin.244 Others are clearly not efficacious and warrant no further study, including secretin.

Evidence was insufficient at this time to support the use of sensory or auditory integration, insufficient for speech and language interventions, and insufficient for complementary and alternative medicine approaches.

Importantly, the literature lacks comparisons of medical interventions with behavioral interventions and combinations of the two, despite the fact that most children are undergoing multiple concurrent treatments. This approach has proven crucial in studies of obsessive compulsive disorder, depression, and anxiety,306–308 but few studies of adequate size have considered combination treatment with risperidone and behavioral treatment,172,177 and these studies lacked an arm that considered behavioral treatment alone, in addition to lacking a placebo control.

In sum, some therapies for ASD do hold promise and warrant further study. Continuing improvements in methodologic rigor are needed, as are larger, potentially multisite, studies of existing interventions in which children are well characterized, both phenotypically and genotypically.