# Applicability Summary Tables

## Behavioral

Early intensive behavioral and developmental interventions: UCLA/Lovaas-based interventions

Domain | Description of applicability of evidence
Population | Studies typically included preschool children (i.e. children from 2–7), baseline cognitive/language and adaptive behavior scores typically falling within the impaired range, but often included children with more intact early cognitive/language skills. Populations generally reflect IQ, language, and adaptive behavior characteristics of preschool children with ASD in the community.
Intervention | Early intensive behavioral intervention (EIBI) approaches ranged in terms scope [i.e., applied behavioral analysis-based (ABA) methods/techniques included] as well as intensity (i.e., from 10–40 hours).
Comparators | Comparators included eclectic interventions, parent-directed EIBI, and varying levels of intensity (e.g. hours of treatment, intensity of supervision of treatment given by parents or treatment given in clinic); comparative interventions were often heterogeneous and may not have employed standardized manuals/protocols.
Outcomes | Studies commonly assessed IQ, language, and adaptive behavior outcomes after approximately 9-months to three years of intervention. Follow-up over the course of years and inclusion of broader adaptive indices for evaluation (i.e., school functioning/placement) suggests that certain cognitive/language and educational gains may be durable. It is less clear that adaptive behavior skills see similar patterns of improvement. Participant groups in many studies included children with ranges of skills which makes group based differences difficult to interpret, particularly as early IQ was found to potentially be a greater predictor of response to intervention.
Setting | Studies were conducted in the US, UK, Norway, and Israel in clinic, school/community, and home settings. Participants were often allocated to early intervention treatment vs. eclectic/community-available treatments based on geography (i.e. location relative to clinic), availability of service, or combined parent and educational system choice.

Early intensive behavioral and developmental interventions: Parent training in social communication

Domain | Description of applicability of evidence compared to question
Population | Studies included preschool-aged children.
Intervention | Parent training interventions included components aimed at social communication including joint attention behaviors, play-based interactions, and pragmatic language approaches; interventions were conducted for approximately 1–4 hours/week with parents asked to introduce learned techniques within natural settings. This approach aligns with several current approaches to ASD treatment.
Comparators | Comparative interventions included eclectic/community-available approaches which may not have employed standardized manuals/protocols.
Outcomes | Studies assessed language and social outcomes after 12 months of intervention. While some language/communication skills improved with intervention, with lower functioning children at baseline generally showing greater improvement.
Setting | Studies were conducted in clinics in the UK. Participants were recruited from the community and randomly allocated to parent training or locally/community-available treatment.

Early intensive behavioral and developmental interventions: ESDM

Domain | Description of applicability of evidence
Population | Limited studies of Early Start Denver Model (ESDM) have been published to date (i.e., one RCT, one case series). These studies have focused on younger preschool aged children (i.e. mean of 2 years of age), Baseline cognitive/language and adaptive behavior scores fell within the impaired range and are generally reflective of characteristics of preschool children with ASD in the community.
Intervention | The ESDM approach focused on delivering approximately 15 hours of service per week with parents providing substantial intervention at other times. The intervention involves supplying ABA-based intervention within developmentally appropriate patterns of activity for young children.
Comparators | Comparators included eclectic community intervention and intensity/type of supervision provided.
Outcomes | Children demonstrated cognitive, language, and adaptive behavior improvements relative to comparison group over two-years, although adaptive behavior skill improvement appears less robust. The impact of such intervention on core autism symptoms also appears unclear.
Setting | Studies were conducted in the US in home and center/school settings.

Social skills

Domain | Description of applicability of evidence
Population | Most studies of social skills interventions targeted elementary school aged children (between 6 and 13 years old). Only one study targeted younger children (4 to 6 years old). Most of the studies of social skills interventions also excluded children with IQs below 60 (reported mean IQs for these studies ranged from 95 to 119), and 6 of the studies targeted children with high functioning ASD or who were diagnosed with Asperger disorder. Therefore this evidence may not be applicable to children below 6 years old or children with very low cognitive functioning.
Intervention | Interventions in this category were mostly implemented in a small group format. 4 studies looked at interventions that ran concurrent parent training in addition to the small groups for the children. Only 3 studies assessed interventions implemented at an individual level. Very few studies followed a manualized intervention or reported fidelity data.
Comparators | The most common comparison group used was a wait-list control group, however almost half the studies in this category did not have a comparison group.
Outcomes | The most common outcomes used were parental reports of children’s social behaviors. Few studies included direct observation measures of peer interactions in naturalistic settings.
Setting | Most of the social skills interventions were implemented in a clinic setting. Three studies were conducted with interventions in school setting.

Interventions targeting commonly associated conditions

Domain | Description of applicability of evidence
Population | As a whole, studies of interventions targeting commonly associated conditions typically targeted older and higher functioning children, with mean ages ranging from 7–9 in studies of parent training and from 9–11 in studies of cognitive behavioral therapy-based (CBT) interventions; several studies only accepted children with Asperger Disorder and/or excluded for intellectual disabilities.
Intervention | Interventions in this category included individual-based and group-based cognitive behavioral therapy, parent trainings, and teacher trainings, targeting commonly associated conditions including anxiety, anger management, and problem behaviors.
Comparators | Comparison groups in studies of interventions targeting commonly associated conditions most often were waiting list control groups; in the case of parent trainings, several studies compared the same training material presented in multiple formats to each other, as well as to a waiting list control.
Outcomes | Studies of interventions targeting commonly associated conditions measured outcomes including anxiety symptoms, problem behaviors, and anger management, most often using parent and/or teacher report rather than direct assessment or observation.
Setting | Most interventions took place in the clinic setting, with two in the school setting; no studies took place in the home.

Play-/interaction-based - Joint Attention

Domain | Description of applicability of evidence
Population | The majority of the children in these studies was 3–4 years old and diagnosed with autism.
Intervention | The majority of these interventions consisted of a combination of adult-directed behavioral drill (i.e., discrete trial training) and child-directed milieu teaching approach. The child-directed training incorporated ABA and developmental procedures of responsive and interactive methods in a tabletop structured context. One study also included a generalization test of joint attention skills to novel stimuli. These approaches align with several current approaches to ASD treatment.
Comparators | All of these studies compared joint attention interventions to symbolic play interventions, and one included a control group.
Outcomes | The most frequently reported outcomes were those related to joint attention and symbolic play skills. These were most often assessed pre- and post-intervention but one study also included a 6- and 12-month follow up.
Setting | These studies all took place in center-based early intervention programs in the US and likely reflect

Play-/interaction-based - Imitation

Domain | Description of applicability of evidence
Population | The majority of the children included were ages 3 through 6, all of whom were nonverbal and diagnosed with autism or ASD.
Intervention | The primary intervention was adult imitation of the child’s behavior. This approach aligns with current approaches to ASD treatment.
Comparators | All of these studies used contingent responsiveness as the comparison treatment. Contingently responsive behavior refers to the adult responding to the child’s initiations by either commenting back or gesturing within the play context.
Outcomes | The outcomes most frequently assessed were social behaviors (e.g, proximity to adult, looking at adult, touching adult). These outcomes were assessed pre- and post- intervention only.
Setting | These studies were conducted in clinics located in the US and Norway.

Play-/interaction-based - Parent-focused

Domain | Description of applicability of evidence
Population | Children in these studies were diagnosed with ASD and had behavior problems; participants were between the ages of 2 and 12.
Intervention | These interventions generally consisted of ABA-based behavior management strategies taught to and led by parents; these approaches align with several approaches currently used to treat ASD in children.
Comparators | The comparison group was a wait-list control group for both studies.
Outcomes | The most frequent outcome assessed was problem behavior. Both studies included a pre- and post-intervention assessment, and one also conducted a 6-month follow-up.
Setting | These interventions were conducted in clinics in the US and Australia.

## Educational

Broad-based approaches

Domain | Description of applicability of evidence
Population | Studies typically included younger preschool children (i.e. children from 2–6), with baseline cognitive/language and autism severity scores typically falling within the impaired range. Populations generally reflect IQ, language, and adaptive behavior characteristics of preschool children with ASD in the community.
Intervention | Approaches included variants of early intensive behavioral and developmental intervention approaches ranging in terms of scope (i.e., applied behavioral analysis- based (ABA) methods/techniques included) as well as intensity (i.e., hours of intervention/week) and eclectic, school- or center-based approaches which employed elements of special nursery, special education, parent training, portage, etc.
Comparators | Comparators included ABA-based approaches compared to eclectic interventions and varying levels of intensity or combinations of center- and home-based treatment; comparative interventions were often heterogeneous and may not have employed standardized manuals/protocols.
Outcomes | Studies commonly assessed developmental functioning, language, ASD severity, and adaptive behavior outcomes with some improvements noted across groups. Few studies assessed longer term outcomes. On study with follow-up at 12 months post-intervention suggests that cognitive gains were sustained while behavioral improvements were not.
Setting | Studies were conducted in the US, UK, and Australia in school/center and home settings. Some participants were allocated to early intervention treatment vs. eclectic/community- available treatments based on geography (i.e. location relative to clinic), availability of service, or combined parent and educational system choice.