# Quality of the Literature

Study | Group design | Random assignment | Appropriate comparison | RCT: Correct randomization | DSM-IV + ADI-R + ADOS | DSM-IV + ADOS or ADI-R | [DSM-IV + other] or [ADOS + other] | Only DSM-IV or only ADOS | Neither DSM-IV nor ADOS | Sample clearly characterized | Inclusion/Exclusion criteria stated | Reported attrition | Drop-out evaluated for differences | Intervention fully described | Treatment fidelity monitored | Reported adherence | Held steady concomitant interventions | Reliability & validity of measures | Prim. & sec. measures specified | Data collected from approp. sources | Coded by blinded individuals | Appropriate statistical analysis | Intent-to-treat analysis | Power calculation provided | Corrected for multiple testing | Confounders & modifiers captured | Confounders & modifiers handled | Outcomes measured outside tx setting | Outcomes measured in natural environ. | Follow-up at least 3 mos post-tx | Final Score
Adams 2009{, #5813;, #5727} | + | − | + | N | − | − | − | − | + | − | + | + | − | + | − | − | − | + | + | + | + | + | N | N | + | + | + | + | + | − | P
Akhondzad eh 2004{, #857} | + | + | + | + | − | − | − | + | − | + | + | + | N | + | N | − | − | + | + | + | + | + | + | N | − | N | N | + | + | − | F
Akhondzad eh 2008{, #250} | + | + | + | + | − | − | − | + | − | − | + | + | N | + | N | − | + | + | + | + | + | + | + | + | N | N | N | − | − | − | F
Akhondzad eh 2010{, #5879} | + | + | + | + | − | − | − | + | − | − | + | N | N | + | N | − | − | + | + | + | + | + | + | N | − | N | N | + | − | − | F
Aldred 2004{, #803} | + | + | + | + | − | − | + | − | − | + | + | + | N | + | − | − | − | + | + | + | + | + | + | N | − | N | N | + | + | − | F
Allam 2008{, #170} | + | + | + | + | − | + | − | − | − | − | + | + | N | + | − | − | + | + | + | + | + | + | + | N | − | N | N | − | − | − | F
Aman 2009{, #5657} | + | + | + | − | − | + | − | − | − | + | + | + | − | + | + | + | + | + | + | + | − | + | + | N | − | N | N | + | + | − | F
Anan 2008{, #2542} | − | − | − | N | − | − | − | + | − | + | + | + | − | + | − | − | − | + | + | + | − | − | N | N | − | − | N | + | + | − | P
Andersen 2008{, #192} | − | − | − | N | − | − | − | + | − | − | + | + | N | + | N | − | + | − | + | + | − | + | N | N | N | + | + | + | + | + | P
Arick 2003{, #2853} | − | − | − | N | − | − | − | − | + | + | + | − | N | − | + | − | − | + | + | + | − | + | N | N | − | − | N | + | + | − | P
Baker-Ericzen 2007{, #2629} | − | − | − | N | − | − | − | + | − | − | − | + | + | + | − | − | − | + | + | + | − | + | N | N | + | + | + | + | + | − | P
Bass 2009{, #5609} | + | + | + | − | − | − | − | + | − | + | − | + | − | + | − | − | − | + | + | + | − | − | − | N | − | N | N | + | + | − | P
Bauminger 2006{, #422} | − | N | − | N | − | + | − | − | − | + | + | + | + | + | − | − | − | + | + | + | + | + | N | N | − | N | N | − | + | − | F
Bauminger 2006{, #423} | − | N | − | N | − | + | − | − | − | + | + | + | N | + | − | − | − | + | + | + | + | + | N | N | − | N | N | − | + | − | F
Beaumont 2008{, #125} | + | + | + | − | − | − | + | − | − | + | + | + | N | + | + | − | − | + | + | + | − | − | − | N | − | N | N | + | + | + | P
Beglinger 2005{, #670} | − | − | − | N | − | + | − | − | − | + | + | + | + | + | − | − | − | + | + | + | − | + | N | N | − | N | N | + | + | − | F
Ben-Itzchak 2007{, #538} | − | − | − | N | + | − | − | − | − | + | + | + | N | − | − | − | − | + | + | + | − | + | N | N | − | N | N | − | + | − | P
Bibby 2002{, #1065} | − | − | − | N | − | − | − | − | + | + | + | + | − | + | − | − | + | + | + | + | − | − | N | N | − | + | + | + | + | + | P
Boyd 2001{, #1121} | − | − | − | N | − | − | − | + | − | + | + | + | − | + | − | − | − | + | + | + | − | − | N | N | N | − | N | + | + | − | P
Carmody 2001{, #1226} | − | − | − | N | − | − | − | − | + | − | − | N | N | + | − | + | − | + | + | + | − | − | N | N | − | − | − | − | − | − | P
Carr 2008, 2007{, #165;, #462} | + | + | + | − | − | − | − | − | + | + | + | + | N | + | − | − | − | + | + | + | − | + | + | N | N | N | N | − | + | − | P
Chalfant 2006{, #387} | + | + | + | − | − | − | − | − | + | + | + | + | + | + | − | − | − | + | + | + | − | − | − | N | − | N | N | + | + | − | P
Chan 2009{, #5606} | + | + | + | − | − | − | − | − | + | + | − | + | N | + | − | + | − | − | + | + | − | − | − | N | − | N | N | + | + | − | P
Chez 2000{, #1271} | − | − | − | N | − | − | − | + | − | + | − | + | N | + | N | + | + | + | + | + | − | − | N | N | + | − | N | + | + | − | P
Chez 2002{, #988} | + | + | + | + | − | − | − | + | − | + | + | + | N | + | N | − | − | + | + | + | + | + | + | N | + | N | N | + | + | − | F
Chez 2003{, #2844} | + | + | + | − | − | − | − | + | − | + | + | + | + | + | N | − | + | + | + | + | + | − | − | N | − | N | N | + | + | − | F
Chez 2004{, #850} | − | − | − | − | − | − | − | + | − | + | − | + | N | + | N | − | + | + | + | + | − | + | − | N | − | N | N | + | + | − | P
Coben 2007{, #2636} | + | − | + | N | − | − | − | − | + | − | − | + | N | + | − | − | + | + | + | + | − | + | N | N | + | + | + | + | + | − | P
Cohen 2006{, #546} | + | − | + | N | − | − | + | − | − | + | + | + | + | + | − | − | − | + | + | + | − | + | N | N | − | N | N | − | + | + | F
Coniglio 2001{, #1201} | + | + | + | − | − | − | − | + | − | + | + | + | + | + | N | + | + | + | + | + | + | − | − | − | − | N | N | + | + | − | F
Corbett 2007{, #297} | + | + | + | − | − | + | − | − | − | + | + | − | N | + | − | − | − | + | + | + | + | − | N | − | N | N | N | − | − | − | F
Correia 2009{, #6120} | − | N | − | N | − | − | + | − | − | + | + | + | − | + | N | − | − | + | + | + | − | − | N | N | − | + | + | + | + | − | P
Cotugno 2009{, #5071} | + | − | − | N | − | − | − | + | − | + | + | + | N | + | − | − | − | + | + | + | − | − | N | N | − | + | + | + | + | − | F
Dawson 2010{, #5715} | + | + | + | + | + | − | − | − | − | + | + | + | − | + | + | + | + | + | + | + | − | − | − | N | − | N | N | + | + | − | G
Delong 2002{, #1020} | − | − | − | N | − | − | + | − | − | − | + | + | N | + | N | − | − | − | − | + | − | − | N | N | − | − | N | − | − | − | P
Dillenburge r 2004{, #2797} | − | − | − | N | − | − | − | − | + | − | − | + | − | − | − | − | − | − | + | + | − | − | N | N | N | − | N | + | + | − | P
Dosman 2007{, #347} | − | N | − | N | − | − | + | − | − | − | + | + | − | + | − | + | − | + | + | + | − | + | N | N | N | + | + | + | + | − | P
Drew 2002{, #997} | + | + | + | + | − | − | − | − | + | + | + | + | N | + | − | − | + | + | + | + | − | + | + | N | − | N | N | + | + | − | F
Dunn-Geier 2000{, #1232} | + | + | + | + | − | − | + | − | − | + | + | + | N | + | N | + | + | + | + | + | + | − | + | + | − | N | N | + | + | − | F
Eikeseth 2002, 2007{, #1117;, #328} | + | − | + | N | − | − | − | − | + | + | + | + | − | + | − | + | − | + | + | + | + | + | N | N | − | N | N | + | + | + | F
Eikeseth 2009 & Hayward 2009{, #5680;, #3630} | + | − | − | N | − | − | − | − | + | + | + | + | + | + | + | + | − | + | + | + | + | + | N | N | − | + | + | + | + | − | F
Eldevik 2006{, #588} | + | − | + | N | − | − | − | − | + | + | + | + | − | + | − | − | − | + | + | + | − | − | N | N | − | − | N | + | + | + | P
Escalona 2001{, #1120} | + | + | + | − | − | − | − | − | + | + | − | + | N | + | N | − | − | + | + | + | − | + | + | N | − | N | N | + | + | − | P
Escalona 2002{, #4810} | + | + | + | − | − | − | − | + | − | + | − | + | N | + | + | − | − | + | + | + | − | + | + | N | − | N | N | − | − | − | P
Evangeliou 2003{, #970} | − | − | − | N | − | − | − | − | + | − | − | + | − | + | − | − | + | + | + | + | − | + | N | N | N | N | N | − | − | + | P
Farrell 2005{, #4808} | + | − | + | N | − | − | − | − | + | − | − | + | − | + | − | − | − | + | + | + | − | − | N | N | − | − | N | + | + | − | P
Fazlioglu 2008{, #118} | + | + | + | + | − | − | − | + | − | − | + | + | N | + | − | − | − | + | + | + | − | + | + | N | N | N | N | − | − | − | P
Field 2001{, #1135} | + | + | + | − | − | − | − | + | − | + | − | + | N | + | − | − | − | + | + | + | − | + | + | N | − | N | N | − | − | − | P
Frankel 2010{, #5826} | + | + | + | + | − | − | + | − | − | + | + | + | − | + | + | − | − | + | + | + | − | − | − | N | − | N | N | + | + | − | F
Gabriels 2001{, #1122;, #3842} | − | − | − | N | − | + | − | − | − | + | + | + | − | − | − | − | + | + | + | + | − | + | N | + | − | + | + | + | + | + | P
Gevers 2006{, #569} | − | − | − | N | − | − | − | + | − | − | − | N | N | − | − | − | − | + | + | + | − | − | N | N | − | − | N | + | + | − | P
Golan 2010{, #5892} | + | + | + | − | − | − | − | − | + | + | + | + | − | + | + | + | − | + | + | + | − | − | − | N | + | N | N | + | + | − | P
Granpeesh eh 2009{, #5717} | − | N | − | N | − | − | − | − | + | + | + | N | N | + | − | − | − | + | + | + | − | − | N | N | N | − | N | − | − | − | P
Green 2010{, #6090} | + | + | + | + | − | − | + | − | − | + | + | + | + | + | + | + | + | + | + | + | + | − | + | N | − | N | N | + | + | − | F
Greenberg 2008{, #3784} | − | N | − | N | − | − | − | − | + | − | − | N | N | + | + | − | − | + | + | + | − | − | N | N | N | − | N | + | + | − | P
Grey 2005{, #664} | − | − | − | N | − | − | − | − | + | − | − | + | N | − | − | − | − | − | + | + | − | + | N | N | − | N | N | + | + | − | P
Gulsrud 2007{, #2578} | + | + | + | − | − | − | + | − | − | + | + | + | + | + | + | − | − | + | + | + | − | − | − | N | − | N | N | − | + | − | P
Gulsrud 2010{, #5893} | − | − | − | N | − | − | + | − | − | + | + | + | − | + | − | − | − | + | + | + | + | + | N | N | + | + | + | + | − | − | F
Gutstein 2007{, #246} | − | N | − | N | − | − | + | − | − | + | + | N | − | + | − | − | + | + | + | + | − | + | N | N | − | + | + | + | + | + | P
Handen 2009{, #4350} | + | + | + | + | − | + | − | − | − | − | + | + | − | + | N | + | + | + | + | + | + | + | + | + | − | N | N | + | + | − | G
Harris 2000{, #1270} | − | − | − | N | − | − | − | − | + | + | + | + | N | + | − | − | − | + | − | + | − | + | N | N | N | + | + | + | + | + | P
Hartshorn 2001{, #3016} | + | − | + | N | − | − | − | − | + | − | − | + | N | + | − | − | − | + | + | + | − | + | N | N | − | N | N | − | + | − | P
Heimann 2006{, #2677} | + | + | + | − | − | − | − | − | + | + | − | + | N | + | − | − | − | + | + | + | − | + | + | N | − | N | N | − | − | − | P
Henry 2006{, #578} | − | − | − | N | − | − | − | + | − | − | + | N | N | + | N | − | − | + | + | + | − | + | N | N | N | N | N | − | − | − | P
Hollander 2005{, #777} | + | + | + | − | + | − | − | − | − | + | + | + | − | + | N | − | + | + | + | + | + | + | + | N | − | N | N | + | + | − | F
Howard 2005{, #734} | + | − | + | N | − | − | − | + | − | + | + | + | − | + | − | − | − | + | + | + | − | + | N | N | − | + | + | − | + | − | F
Howlin 2007{, #312} | + | + | + | + | − | − | − | + | − | − | + | + | − | + | − | − | − | + | + | + | − | + | + | + | − | N | N | − | + | − | P
Itzchak 2008{, #252} | + | − | − | − | + | − | − | − | − | + | − | + | − | − | − | − | − | + | + | + | − | − | N | N | N | − | N | − | − | − | P
Itzchak 2009{, #3844} | − | N | − | N | + | − | − | − | − | + | − | + | N | + | − | − | − | + | + | + | − | + | N | N | − | + | + | + | + | − | P
Jarusiewic z 2002{, #2953} | + | + | + | N | − | − | − | − | + | − | − | + | − | + | N | − | − | + | + | + | − | + | − | N | − | N | N | + | + | − | P
Jung 2006{, #2698;, #4951} | + | − | − | N | − | − | − | + | − | + | − | + | N | + | − | − | − | + | + | + | − | − | N | N | − | − | N | − | − | − | P
Kasari 2006, 2008{, #540;, #184} | + | + | + | − | − | − | + | − | − | + | + | + | − | + | + | + | + | + | + | + | + | − | − | N | − | N | N | + | + | + | F
Keen 2007{, #383} | − | N | − | N | − | − | − | + | − | − | − | + | N | − | − | − | − | − | + | + | − | + | N | N | − | N | N | − | + | − | P
Kern 2001{, #1208} | + | + | + | − | − | − | − | + | − | + | + | + | − | + | N | − | + | + | + | + | + | − | − | − | − | N | N | + | + | − | F
Kim 2008, 2009{, #106;, #4314} | + | + | + | − | − | − | + | − | − | − | − | + | − | + | − | − | − | + | + | + | + | − | − | N | − | N | N | + | + | − | P
King 2001{, #1192} | + | + | + | − | + | − | − | − | − | + | + | + | N | + | N | − | + | + | + | + | + | + | + | N | − | N | N | + | + | − | F
King 2009{, #4321} | + | + | + | + | + | − | − | − | − | + | + | + | − | + | N | + | + | + | + | + | + | + | + | + | − | N | N | + | − | − | G
Kroeger 2007{, #3901} | + | − | + | − | − | − | − | − | + | + | + | + | − | + | − | − | − | + | + | + | + | − | − | N | − | N | N | − | − | − | P
Laud 2009{, #5744} | − | N | − | N | − | − | − | − | + | − | + | + | − | + | − | − | − | + | + | + | − | − | N | N | − | − | N | + | + | + | P
Legoff 2006{, #5558} | + | − | + | N | − | − | − | − | + | + | + | N | N | − | − | − | + | + | + | + | − | + | N | N | − | + | + | + | + | − | P
Levy 2003{, #942} | + | + | + | + | − | − | − | − | + | + | + | + | + | + | N | + | − | + | + | + | + | − | − | − | − | N | N | + | + | − | F
Lopata 2006{, #2697;, #216} | − | − | − | N | − | − | − | − | + | − | + | + | N | + | + | + | − | + | + | + | − | − | N | N | − | − | N | + | + | − | P
Lopata 2008{, #216;, #2697} | + | + | + | − | − | − | − | + | − | + | + | + | N | + | + | − | − | + | + | + | + | + | + | N | − | N | N | + | + | − | F
Ludlow 2006{, #5711} | − | − | − | N | − | − | − | − | + | + | − | + | N | + | − | − | − | + | + | + | − | + | N | N | − | + | + | − | − | − | P
Ludlow 2008{, #3710} | − | N | − | N | − | − | − | − | + | − | − | + | N | + | − | − | − | + | + | + | − | − | N | N | − | − | N | − | + | − | P
Luiselli 2000{, #3024} | − | − | − | N | − | − | − | − | + | − | − | | N | + | − | − | − | + | + | + | − | + | N | N | + | + | + | − | + | − | P
Magiati 2003{, #916} | − | − | − | N | − | − | − | − | + | + | + | − | N | + | − | − | + | + | + | + | − | + | N | N | + | N | N | − | + | − | P
Magiati 2007{, #288} | + | − | + | N | − | − | − | − | + | + | + | + | N | + | − | − | + | + | + | + | − | + | N | − | − | + | + | − | + | + | F
Mahoney 2005{, #719} | − | − | − | N | − | − | − | + | − | + | − | + | N | + | − | + | − | + | + | + | − | + | N | N | − | N | N | − | + | − | P
Marcus 2009{, #5687} | + | + | + | + | − | + | − | − | − | − | + | + | − | + | N | + | + | + | + | + | + | + | + | N | − | N | N | + | + | − | G
Masi 2003{, #891} | − | − | − | N | − | − | + | − | − | + | + | + | − | + | N | − | − | + | + | + | − | + | N | N | + | N | N | + | − | − | P
McConachie 2005{, #651} | + | − | + | N | − | − | + | − | − | + | + | + | N | + | + | + | + | + | + | + | + | + | N | N | − | N | N | − | + | + | F
Meguid 2008{, #107} | + | − | − | N | − | − | + | − | − | − | + | + | N | + | − | − | + | + | + | + | − | + | N | N | − | N | N | + | + | − | P
Molloy 2002{, #995} | + | + | + | − | − | − | − | + | − | + | + | + | − | + | N | − | − | + | + | + | + | + | + | + | − | N | N | + | + | − | F
Moore 2000{, #1253} | + | + | + | − | − | − | − | − | + | − | − | + | N | + | + | + | − | + | + | + | − | + | + | N | N | N | N | − | + | − | P
Mousain-Bosc 2006{, #508} | − | − | − | N | − | − | − | + | − | − | − | + | N | + | N | − | + | + | + | + | − | + | N | N | − | N | N | − | − | − | P
Mudford 2000{, #1228} | + | − | − | N | − | − | + | − | − | + | − | + | − | + | − | − | − | + | + | + | + | + | N | N | − | N | N | + | + | + | F
Mukaddes 2004{, #855} | − | − | − | N | − | − | − | + | − | − | − | + | N | + | − | − | − | + | + | + | − | + | N | N | − | N | N | − | + | − | P
Munasingh e 2010{, #5843} | + | + | + | + | − | − | − | + | − | − | + | + | − | + | N | + | + | + | + | + | + | − | − | + | − | N | N | + | + | − | F
Nagaraj 2006{, #475} | + | + | + | + | − | − | − | + | − | + | + | + | − | + | N | − | + | + | + | + | + | − | − | N | − | N | N | + | + | − | F
Nickels 2008{, #130} | − | N | − | N | − | − | − | + | − | − | + | N | N | + | − | − | − | − | + | + | − | + | N | N | N | + | + | + | + | N | P
Osborne 2008{, #224} | + | − | + | N | − | − | − | − | + | + | + | + | N | + | − | − | − | + | + | + | + | + | N | N | − | + | + | − | + | − | F
Owen 2009{, #5714} | + | + | + | + | − | + | − | − | − | − | + | + | − | + | N | + | + | + | + | + | + | + | + | N | − | N | N | + | + | − | G
Owens 2008{, #116} | + | + | + | − | − | − | − | − | + | + | + | + | − | + | − | − | + | + | + | + | − | − | − | N | − | N | N | + | + | − | P
Owley 2001{, #1142} | + | + | + | + | + | − | − | − | − | + | + | + | N | + | N | + | + | + | + | + | + | + | + | + | − | N | N | + | + | − | G
Owley 2010{, #5841} | − | − | − | N | + | − | − | − | − | + | + | + | − | + | N | − | + | + | + | + | − | + | N | N | N | + | + | + | + | − | F
Pan 2010{, #6030} | − | N | − | N | − | − | − | + | − | − | + | N | N | + | − | + | + | + | + | + | − | − | N | N | + | − | N | + | + | − | P
Panerai 2009{, #4343} | + | − | + | N | − | + | − | − | − | + | + | + | N | + | − | − | − | + | + | + | + | − | N | N | − | − | N | + | + | − | G
Perry 2008{, #3668} | − | N | − | N | − | − | − | + | − | + | + | N | N | + | − | − | − | + | + | + | − | + | N | N | − | + | + | + | + | − | P
Piravej 2009{, #6031} | + | + | + | + | − | − | − | + | − | − | + | − | − | + | − | + | − | + | + | + | − | − | − | N | − | N | N | + | + | − | P
Posey 2004{, #821} | − | − | − | N | − | − | − | + | − | + | + | N | N | + | N | + | + | + | + | + | − | − | N | N | − | − | N | + | + | N | P
Probst 2008{, #158} | − | − | − | N | − | − | − | + | − | + | + | + | N | + | − | − | − | + | + | + | − | − | N | N | − | − | N | − | + | − | P
Quirmbach 2009{, #84} | + | + | + | − | − | − | − | + | − | + | + | + | N | + | − | − | − | + | + | + | + | + | + | N | − | N | N | + | + | − | F
Reaven 2009{, #3650} | + | − | + | N | − | − | − | + | − | + | + | + | − | + | + | + | + | + | + | + | − | − | N | N | − | N | N | + | + | − | F
Reed 2006{, #381} | + | − | + | N | − | − | − | − | + | + | + | + | N | + | − | − | + | + | + | + | + | − | N | N | − | − | N | − | + | − | F
Reed 2007{, #3887} | + | − | + | N | − | − | − | − | + | + | + | + | − | + | − | − | − | + | + | + | − | + | N | N | − | + | + | + | + | − | F
Reed 2009{, #5066} | − | N | − | N | − | − | − | + | − | + | + | + | − | + | − | − | + | + | + | + | − | − | N | N | − | − | N | + | + | − | P
Reed 2010{, #5899} | + | − | + | N | − | − | − | − | + | + | + | + | N | + | − | + | + | + | + | + | − | + | N | N | − | + | + | + | + | − | F
Remington 2007{, #240} | + | − | + | N | − | − | − | − | + | + | + | − | N | − | − | − | − | + | + | + | − | − | N | N | − | + | + | − | + | − | P
Rickards 2001{, #278} | + | + | + | + | + | − | − | − | − | + | + | + | − | + | − | − | − | + | + | + | + | − | − | N | − | N | N | − | − | + | G
Roberts 2001{, #1199} | + | + | + | + | + | − | − | − | − | + | + | + | − | + | N | + | + | + | + | + | + | − | − | − | + | N | N | + | + | − | G
Rossignol 2009{, #4} | + | + | + | + | + | − | − | − | − | + | + | + | + | + | + | − | + | + | + | + | + | + | + | N | − | N | N | + | + | − | G
RUPP 2002{, #1051;, #610;, #704;, #892;, #564;, #539;, #108;, #838;, #691} | + | + | + | + | − | + | − | − | − | + | + | + | + | + | + | + | + | + | + | + | + | + | + | N | − | N | N | − | − | − | G
RUPP 2005; Posey 2007; Jahromi 2009{, #635;, #363;, #3615} | + | + | + | + | − | + | − | − | − | + | + | + | − | + | N | − | + | + | + | + | + | + | + | N | − | N | N | + | + | − | F
RUPP 2005{, #5725} | − | N | − | N | − | + | − | − | − | + | + | + | − | + | + | + | + | + | + | + | + | − | N | N | − | − | N | + | + | − | G
Sallows 2005{, #647} | + | + | + | + | − | + | − | − | − | + | + | + | − | + | + | + | + | + | + | + | + | − | − | N | − | N | N | + | + | + | G
Salt 2002{, #1094} | + | − | + | N | − | − | − | − | + | + | − | + | − | + | − | + | − | + | + | + | − | − | N | N | − | − | N | + | + | − | P
Sams 2006{, #532} | + | − | − | N | − | − | − | − | + | − | − | + | N | + | − | − | − | + | + | + | − | − | N | N | N | − | N | − | + | − | P
Shea 2004; Pandina 2007{, #799;, #458} | + | + | + | − | − | − | + | − | − | + | + | + | − | + | N | + | + | + | + | + | + | + | + | N | − | N | N | + | + | − | F
Silva 2007{, #302} | + | + | + | − | − | − | − | + | − | + | + | + | − | + | − | − | + | + | + | + | + | − | − | N | − | N | N | − | + | − | F
Silva 2008{, #58} | − | N | − | N | − | − | − | − | + | − | + | + | N | + | + | + | − | + | + | + | − | − | N | N | − | − | N | − | + | − | P
Silva 2009{, #5051} | + | + | + | − | − | − | − | − | + | − | − | + | − | + | + | − | + | + | + | + | − | − | − | N | + | N | N | + | + | + | P
Smith 2000{, #1264} | + | + | + | − | − | − | − | − | + | + | + | + | N | + | + | + | − | + | + | + | + | + | + | N | + | N | N | + | + | − | F
Sofronoff 2002{, #1039} | + | − | + | N | − | − | − | + | − | − | − | − | N | + | − | − | − | + | + | + | − | − | N | N | + | − | N | + | + | − | P
Sofronoff 2003{, #5832} | + | + | + | − | − | − | − | − | + | − | − | + | N | + | + | − | − | − | + | + | − | + | + | N | N | N | N | + | + | − | P
Sofronoff 2004{, #814} | + | + | + | − | − | − | − | − | + | − | − | + | N | + | − | − | − | − | + | + | − | + | + | N | − | N | N | + | + | − | P
Sofronoff 2005{, #644} | + | + | + | − | − | − | + | − | − | + | + | + | + | + | + | − | − | + | + | + | + | − | − | N | + | N | N | + | + | − | F
Sofronoff 2007{, #417} | + | + | + | − | − | − | + | − | − | + | + | + | N | + | + | + | − | + | + | + | − | + | + | N | − | N | N | + | + | − | F
Solomon 2004{, #756} | + | + | + | − | + | − | − | − | − | + | + | + | N | + | − | − | − | + | + | + | − | + | + | N | − | N | N | + | + | − | F
Solomon 2007{, #3950} | − | N | − | N | − | − | − | + | − | − | + | + | − | + | + | − | − | + | + | + | + | − | N | N | − | − | N | + | + | − | P
Solomon 2008{, #150} | + | + | + | − | + | − | − | − | − | + | + | + | N | + | + | + | − | + | + | + | − | + | N | N | − | N | N | + | + | − | F
Stahmer 2001{, #2999} | + | − | + | N | − | − | − | − | + | + | − | + | N | + | − | + | − | + | + | + | + | + | N | N | − | − | N | + | + | − | P
Stahmer 2004{, #4234} | − | N | − | N | − | − | + | − | − | + | + | + | N | + | − | − | + | + | + | + | − | − | N | N | − | − | N | + | + | − | P
Stigler 2004{, #845} | − | − | − | N | − | − | − | + | − | − | + | N | N | + | N | − | − | + | + | + | − | + | N | N | − | N | N | + | + | − | P
Tjus 2001{, #1141} | − | − | − | N | − | − | − | − | + | + | − | + | N | + | − | + | − | + | + | + | − | + | N | N | − | + | + | − | + | − | P
Tsang 2006{, #491} | + | − | − | N | − | − | − | + | − | + | + | + | N | + | − | − | − | − | + | + | − | + | N | N | − | N | N | − | + | − | F
Tyminski 2008{, #2539} | − | − | − | N | − | − | − | + | − | − | + | + | − | + | − | + | − | + | + | + | − | + | N | N | − | + | + | + | + | − | P
Unis 2002{, #1024} | + | + | + | − | − | + | − | − | − | + | + | + | − | + | N | − | − | + | + | + | + | − | − | − | − | N | N | + | + | − | F
Vismara 2009{, #5767} | − | N | − | N | − | + | − | − | − | + | + | + | − | + | + | + | − | + | + | + | − | − | N | N | − | − | N | + | + | − | P
Vorgraft 2007{, #245} | − | − | − | N | − | − | − | + | − | − | + | N | N | + | − | − | − | + | + | + | − | − | N | N | + | − | N | + | + | − | P
Wetherby 2006{, #4027} | − | N | − | N | − | + | − | − | − | + | + | + | N | + | + | − | − | + | + | + | − | − | N | N | − | − | N | + | + | − | P
Whalen 2010{, #6122} | + | + | + | − | − | − | − | − | + | + | + | + | N | + | − | − | − | + | + | + | − | − | + | N | − | N | N | − | + | − | P
Whitaker 2004{, #4176} | − | N | − | N | − | − | − | − | + | + | − | + | N | + | − | − | − | + | + | + | − | − | N | N | N | − | N | − | + | − | P
Whittingha m 2009{, #3592;, #3631} | + | + | + | + | − | − | − | + | − | + | − | + | − | + | − | − | − | + | + | + | − | + | + | N | + | N | N | + | + | + | P
Wong 2007{, #3875} | − | − | − | N | − | − | − | + | − | + | + | + | N | + | + | − | − | + | + | + | − | + | N | N | − | + | + | − | + | − | P
Wood 2009{, #3618;, #5523} | + | + | + | + | − | − | + | − | − | + | + | + | − | + | − | − | + | + | + | + | + | + | + | N | − | N | N | + | + | + | F
Yoder 2006, 2009{, #516;, #487;, #5719;, #408} | + | + | + | + | + | − | − | − | − | + | + | + | N | + | + | + | − | + | + | + | + | + | + | N | − | N | N | + | + | − | G
Zachor 2007{, #5652} | + | − | + | N | − | + | − | − | − | + | − | + | N | + | − | − | − | + | + | + | − | + | N | N | − | + | + | − | − | − | F

+ = Yes, − = No or Not Reported, and N = Not applicable

G = Good, F = Fair, and P = Poor