# Discussion of Recent Systematic Reviews of Therapies for Children with ASDs

We conducted a scan of recent (2008–2010) systematic reviews addressing therapies for children with ASD in order to inform the present review. We considered systematic reviews as those literature reviews that employed reproducible, explicit methods to locate and summarize a body of literature; we required that systematic reviews included in our assessment:

- Include a focused question or topic area to be assessed in the review
- Include explicit inclusion/exclusion criteria for studies included in the review
- Include only studies of therapies for children (defined as participants ≤ 18 years of age for this examination of reviews) with ASD
- Articulate approaches used to locate studies including the resources searched; search strategies used; and time frame for searches
- Articulate approaches used to assess the relevance of studies included in the review
- Provide an accounting of included and excluded studies
- Summarize the characteristics of included studies
- Assess the quality of included studies
- Synthesize results of studies using statistical approaches where appropriate and possible

Methods. We searched the MEDLINE, ERIC, and PsycInfo databases using the autism search string employed to locate studies for the full review with the addition of terms to limit retrieval to reviews (systematic review, meta-analysis, review); we also limited searches to the years 2008 to 2010 and reviews published in English only given that the team lacked translators for potentially relevant non-English studies. We assessed the titles and abstracts of reviews for relevance to the inclusion/exclusion criteria and subsequently assessed the full text of included studies using a standard form developed by the Vanderbilt EPC (Appendix B). We abstracted descriptive data about the reviews including publication characteristics (author, year of publication, last update date/search date), study and methodological characteristics (number of studies included, study designs included, search parameters, quality measures employed) and primary results into a spreadsheet.

Content of the literature. Of 218 reviews retrieved in our searches, ten{, #4988;, #3640;, #3763;, #4990;, #3;, #4991;, #4994;, #4992;, #6084;, #6085} were eligible for inclusion. The bulk of excluded reviews either did not focus on ASD in children, were narrative or descriptive reviews, and/or included studies of both children and adults (defined as ≥ 18 years old). Five systematic reviews addressed early behavioral intervention approaches, {, #4990;, #4988;, #3640;, #3763;, #3}. The remaining reviews addressed augmentative and alternative communication interventions (AAC) including the Picture Exchange Communication System (PECS),{, #4991;, #6085} gluten free-casein free (GFCF) diets,{, #4994;, #6084} and drug and non-drug interventions in general.{, #4992} Six reviews were published by investigators in the US,{, #3763;, #3640;, #3;, #4991;, #6084;, #6085} two from the UK,{, #4992;, #4994} and one each from Norway{, #4988} and Australia.{, #4990}

Databases commonly noted as searched for the reviews included MEDLINE, PsycInfo, EMBASE, ERIC, the Cochrane database and trial registry, and CINAHL, and years searched for each review varied from the 1960s to 2006–2008,{, #4988;, #3;, #4994} to the 1980s or 1990s to 2006–2009.{, #4990;, #4992;, #6085} Four reviews explicitly noted the date of their last search update,{, #4992;, #4994;, #3;, #6085} while six provided a complete description of search terms used.{, #4990;, #3;, #4991;, #4994;, #6085;, #6084} Most of the reviews described other resources searched in addition to bibliographic databases; such resources included reviewing the reference lists of studies in the review and existing reviews, contacting experts in the area, and scanning relevant websites such as the Food and Drug Administration.{, #6085;, #6084;, #3640;, #3763;, #3;, #4991;, #4994;, #4992} All of the reviews appeared to employ an a priori design, though this was not always explicitly stated. Most investigators also noted dual review of included studies.{, #4988;, #3640;, #4990;, #3;, #4991;, #4994;, #6085;, #6084}

Six reviews included group design studies employing experimental or quasi-experimental designs with either control or comparison groups,{, #4988;, #4990;, #4994;, #4992;, #6084;, #6085} and four also included multiple baseline studies.{, #3763;, #4991;, #6085;, #6084} Reichow and colleagues’ review of studies of interventions based on the UCLA/Lovaas model{, #3640} and the Blue Cross Blue Shield Association’s review of EIBI interventions{, #3} included one group pre-post designs as well as comparative studies, while Millward and colleagues’ review of GFCF diets included only RCTs.{, #4994} The number of studies included in the reviews ranged from two (in Millward’s{, #4994} review of RCTs) to 22 in Rogers and colleagues’ review of early intensive behavioral interventions.{, #3763} Several reviews included only papers with study populations in the preschool age range.{, #4988;, #3640;, #3763;, #4990;, #3} Reviews of GFCF diets{, #4994;, #6084}, a meta-analysis of PECS{Flippin, 2010 #6085}, and an overarching review of therapies for children with ASD{, #4992} included both younger children and adolescents. The number of participants in studies in the reviews ranged from 35 in the Cochrane review of GFCF diets{, #4994} to over 600 in Parr’s comprehensive review of interventions.{, #4992} Four reviews also reported meta-analyses.{, #4988;, #3640;, #4990;, #6085} Table G1 provides additional data on parameters of each review.

Table G1 Characteristics of recent systematic reviews

Author, year Country COI noted | Interventions assessed | N studies | N participants | Quality assessment | Publication bias assessed
Flippin (2010) US Not stated | PECS | 10 | 178 | Horner et al. (2005), Wolf (1978), Gersten et al. (2005) | Not stated
Mulloy (2010) US Yes—no disclosures to make | Gluten Free Casein Free diets | 14 | 188 | Simeonsson and Bailey (1991) | Not stated
Eldevik (2009) Norway Not stated | EIBI intervention as described by Green et al. (2002) | 9 | 153 in EIBI groups; 105 in control groups ; 39 in comparison groups | Nathan and Gorman (2002 ) | Yes
Parr (2009) UK Not stated | Early intensive multidisciplinary approaches, dietary interventions, drug treatments, allied health, CAM | 14 | 612 | GRADE | Not stated
Reichow (2009) US Not stated | Interventions replicating UCLA Young Autism Program | 14 | 373 | Assessed elements of research design, tx fidelity | Yes
Rogers (2008) US Yes—no disclosures to make | Behavioral/psycho-social interventions; Lovaas replications | 22 | 431 | Nathan and Gorman (2002); Chambless, criteria | Not stated
Spreckley (2008) Australia Yes—no disclosures to make | Applied behavioral intervention approaches to behavioral management | 13 | 101 included in the 4 studies used in meta- analysis | Physiotherapy Evidence Database (PEDro) scale of quality assessment | Not stated
TEC report (2009) US Not stated | EIBI approaches | 16 | ~518 | US Preventive Service Task Force, Carey and Boden (2003 ) | Not stated
Schlosser (2008) US Not stated | AAC interventions as defined by the American Speech Language Hearing Association, 2002 (e.g., PECS, RPMT, speech generating devices) | 11 | 27 (single subject); 98 (group) | Simeonsson and Bailey (1991) | Not stated
Millward (2008) UK Yes—one author noted as parent of child with ASD | Gluten Free- Casein Free diets | 2 | 35 | Cochrane methods | Not stated

AAC- augmentative and alternative communication; ASD-autism spectrum disorders; EIBI-early intensive behavioral intervention; PECS-Picture Exchange Communication System; RPMT- Responsive Education and Prelinguistic Milieu Teaching; tx-treatment

Summary of recent systematic reviews of therapies for ASD. Millward et al.{, #4994} reviewed RCTs of GFCF diets for ASD, locating two studies comprising three papers published in 2002, 2003, and 2006 and including 35 participants with ASD. The age range of the 20 participants in one single blind study conducted over one year was 59 to 127 months;{Knivsberg, 2002 #1047;Knivsberg, 2003 #4445} the age range of the 15 participants in the second, double blind, 18 week crossover study was 2 to 16 years.{Harrison Elder, 2006 #2689} The studies assessed various outcomes: autistic traits and severity, linguistic age, motor skills, cognitive level, urinary peptide levels, and language and communication outcomes; different outcome measures were used in each study. A beneficial treatment effect was shown in reduction in autistic traits in the Knivsberg study; however, the Elder study showed no significant difference on the Childhood Autism Rating Scale (CARS) scores between the diet and control groups. The review reports that much of the data in both studies was skewed, which obviated review investigators’ calculation of treatment effect sizes for all measures assessed. Though not reporting a washout period, the Elder trial was described as well-designed, with blinding and adequate concealment of allocation.

Mulloy and colleagues review of gluten free and/or casein free diets{, #6084} included 14 studies (including the Elder and Knivsberg trials) collectively including 188 participants ranging from 2 to 17 years of age. Most participants (93 percent) were diagnosed with autism or Asperger syndrome. Twelve studies examined GFCF diets while one assessed a gluten free and one a casein free regime. Diets were followed across studies for a mean of 10 months (range 4 days to 4 years), and four studies also included additional interventions such as vitamin supplementation, chelation, and behavior modification. Review investigators characterized the certainty of evidence of studies based on study design and methodological rigor, rating studies as suggestive, preponderant, or conclusive in line with classifications developed by Simeonsson and Bailey{, #6011} and Smith; 11 studies were rated as suggestive. Methodological concerns included use of measurements subject to bias, lack of blinding and control groups, use of only post-treatment measures, short intervention durations, and failure to control for the effects of maturation. Investigators considered 3 studies as providing a level of certainty of evidence for the lack of effectiveness of GFCF diets. Overall, the review authors conclude that the evidence supporting GFCF diets in ASD is limited and weak.

Schlosser and colleagues’ review of AAC interventions on speech production{, #4991} included nine single subject design studies with 27 total participants and two group design studies with 98 total participants; all studies were published between 1988 and 2007. Single subject studies included between 1 and 6 participants (mean age 81 months, range 37–144). All but one participant lacked functional speech, and interventions evaluated were PECS, manual signing, speech generating devices, and enhanced milieu teaching. Speech measurement techniques varied across studies and ranged from mean length of utterance to word approximations to word elicitation. The mean age of participants in group design studies was 60 months and 33 months; participants appeared to possess some spoken speech at baseline. Interventions represented were PECS, manual signing and speech training, and RPMT, and both studies assessed child-initiated spoken words. Overall, no studies included in the review reported a decline in speech production, and most participants in most of the studies showed modest gains in speech. One study comparing PECS to RPMT{Yoder, 2006 #487}demonstrated more nonimitative spoken communication acts and different nonimitative words in children receiving PECS.

The review judged quality by evaluating design and implementation, interobserver agreement, and treatment integrity, appraising the evidence as conclusive, preponderant, suggestive, or inconclusive based on Simeonsson and Bailey’s taxonomy.{, #6011} The review investigators rated one single subject study of PECS as conclusive, two (1 of PECS, 1 of speech generating devices) as preponderant, and four (2 of PECS and 2 of speech-generating devices) as suggestive; two studies were not rated. Group design studies were rated as conclusive (PECS/RPMT) and suggestive (speech and signing methods).

A meta-analysis from Flippin et al.{, #6085} included 10 studies (7 single subject and 3 group design studies) and a total of 178 participants. Five studies reported a measurement of treatment fidelity, and most assessed changes in the numbers of PECS exchanges and initiations of communication. Meta-analysis showed small to moderate effects of the efficacy of PECS on communication-related outcomes in the short term. Evidence for maintenance and generalization of effects was limited. Results related to speech outcomes were variable across group and single subject studies. The review assessed the quality of studies using scales adapted from guidelines from Horner{, #6087} and Wolf{, #6088} for single subject studies and Gersten{, #6086} for group designs. Four studies received a quality rating of strong, 4 of adequate, and 2 of inadequate. Studies were typically limited by their measurement and reporting of treatment fidelity, generalization, and social validity.

Parr’s review of medical and behavioral treatments{, #4992} included studies with at least 20 participants with ASD and reports benefits, harms, and a brief assessment of a study’s quality by intervention. Based on “very low quality evidence,” EIBI was reported as potentially improving IQ and adaptive behavior; the More than Words training was reported as potentially yielding improved communication outcomes compared to participants with delayed access to the training; TEACCH was reported as potentially improving psycho-educational scores compared to usual care. PECS was reported as of unknown effectiveness compared to other or no treatment at increasing speech frequency or communication scores, but the review notes consensus surrounding its benefit in children with ASD based on very low quality evidence.

Based on “low quality evidence,” GFCF diets were reported to potentially improve autistic trait scores compared to no dietary advice and MPH was seen as modestly reducing hyperactivity compared to placebo. Based on “moderate quality” evidence, Child’s Talk was reported as potentially yielding gains in social interactions and language outcomes compared to existing care alone; risperidone was reported as more effective in reducing problem behaviors compared to placebo and secretin as apparently not more effective in treating autism symptoms compared to placebo.

Interventions for which no “clinically important results from RCTs, quasi-randomised trials, or cohort studies” were found included the Autism Preschool Program, CBT, the Earlybird Program, DIR/Floortime, portage, RDI, social skills training, social stories, the Son-Rise program, music therapy, facilitated communication, digestive enzymes, omega-3 fish oil, probiotics, vitamin A, vitamin B6 plus magnesium, vitamin C, melatonin, immunoglobulins, memantine, SSRIs, olanzapine, auditory or sensory integration, and chelation. Harms noted by the review included appetite and weight changes; sleep difficulties, including drowsiness and trouble sleeping; tremors; and prolactin elevation. The review also reports that chelation is under careful review given deaths of some children receiving edetate disodium. The review evaluated quality of studies using the GRADE system; overall, four studies were considered very low quality, two were considered low quality, and three were considered moderate quality.

Reviews assessing early behavioral interventions included between 9 and 22 studies and including participants ranging in age from 30 months to four to five years. Among included studies, the Cohen et al. non-randomized controlled trial{, #546} and the Smith et al. RCT{, #1264} were addressed in all the reviews; the Sallows et al. RCT{, #647} and Eikeseth and colleagues’ 2002 RCT{, #1117} were included in 4 reviews. Studies addressed in three reviews included Magiati’s 2007 study,{, #288} Sheinkopf’s 1998 retrospective study,{, #1378}, Bibby and colleagues 2002 study,{, #1065} Eikeseth’s 2007 study,{, #328} and Howard’s 2005 study.{, #734} Nine studies were reported in two reviews, and 15 studies were reported in at least one review.

The review from Rogers and Vismara{, #3763}included early intervention studies published between 1998 and 2006 and employing either group design or single subject design with more than three subjects. The investigators assessed the quality of the 22 studies meeting their inclusion criteria using the Nathan and Gorman{, #6012}and Chambless et al.{, #6013} classifications and categorized 4 studies as Type 1, with a randomized design, clear reporting of methods, state-of–the-art diagnosis, and treatment fidelity measures. Six studies met criteria as Type 2, comparative studies without “critical design flaws,” and eleven were considered Type 3, studies with significant methodological flaws including lacking a control groups or retrospective design. The investigators categorized one study designed as an RCT but which presented no outcome data as Type 6, defined as case reports. The investigators also described potential mediators and moderators of outcomes, noting that studies addressed pretreatment IQ, intake age, treatment intensity, family characteristics, social variables including social avoidance, and biological variables including physical anomalies and head circumference, among others. Overall the review notes that existing studies, though flawed, suggest that early intervention, particularly at younger ages, may yield gains in language and communication and increases in IQ.

The evidence report from the Blue Cross Blue Shield Association Technology Evaluation Center (TEC){, #3} drew similar conclusions about the weak quality and consistency of the 16 early intervention studies included. The review included group and single arm studies but excluded single subject designs and those reporting on interventions delivered for less than 20 hours/week. The review reports insufficient evidence to judge the effectiveness of EIBI approaches compared to other alternatives. The investigators also examined potential predictors of treatment success, finding that age and cognitive functioning had been examined as predictors in four studies; results were variable with three of four studies reporting that cognitive functioning at intake significantly predicted outcomes, and some studies finding that younger intake age predicted better outcomes. Investigations of the effects of treatment intensity were similarly mixed.

A review and meta-analysis from Spreckley et al.{, #4990} included 13 group design studies, of which only six were considered were considered higher quality according to the Physiotherapy Evidence Database (PEDro) Scale and only four contained data adequate for meta-analysis. The analysis pooled cognitive, expressive and receptive language, and adaptive results and noted no significant improvement for early intervention approaches compared to standard care across these outcomes. Meta-analyses from Reichow and Wolery{, #3640} and Eldevik et al.{, #4988}included 14 and 9 studies, respectively, and noted significant effects for early intervention on cognitive outcomes. Reichow{, #3640} also assessed methodological quality and group assignment as moderators of IQ effects but found no statistically significant relation. Among treatment and participant variables (e.g. intensity, provider characteristics, intake IQ, etc.) examined as moderators of effects, only provider/supervisor training showed a significant relationship to IQ change (p=0.01). The investigators also reported the possibility of publication bias, with funnel plots suggesting the absence of two studies which, if included, would reduce mean effect size. Eldevik{, #4988} aimed to replicate and extend the Reichow analysis and included only studies with comparison or control groups and full scale measures of intelligence, noting significant effects on IQ and adaptive behavior. No publication bias was found.

Most of the reviews generally concluded that the evidence base for EIBI is inadequate, noting variability in treatment and intervention, limited follow-up, lack of comparative studies, need for replication, and unclear inclusion and exclusion criteria.{, #4990;, #3;, #3763} Meta-analyses from Reichow{, #3640} and Eldevik,{, #4988} reported more positive results, noting strong evidence for EIBI’s effects in some children.{, #4988;, #3640} Eldevik’s meta analysis of 9 studies found an average large effect size for IQ change (1.103, 95 percent CI [CI=.871, 1.335]) and medium effect size for change on the VABS composite score (.660, 95 percent CI [CI=.41, .90]). The meta-analysis from Reichow and Wolery,{, #3640} including studies exclusively based on Lovaas’ treatment manuals or replicating the UCLA/Lovaas model and computing mean effect size based on change in the EIBI group only, also reported a large effect size of .69 for IQ change and mean difference effect sizes suggesting greater gains for children receiving EIBI compared to those receiving minimal behavioral intervention, usual treatment, or eclectic treatment. Each of these reviews, however, notes significant concerns about the included studies, such as limited accounting for the effects of maturity, lack of equivalent groups, uncertain treatment fidelity, and small sample sizes. Several authors also noted the need for studies comparing EIBI to other approaches that have been similarly empirically tested.

Across all the reviews, areas noted for improvement in the literature included the need for more RCTs, though investigators acknowledge the difficulty of conducting RCTs with interventions of such complexity and ethical issues of withholding treatment for comparison purposes. Other areas for improvement noted included a need for larger sample sizes; longer follow-up to allow for evaluation of the durability of effects; greater treatment fidelity; improved reporting of methodological and participant characteristics; and greater consistency in treatment approaches and outcomes measurement.

In terms of the quality of the reviews themselves, we considered the reviews described here to be of generally good quality, though some elements of reporting were spotty across reviews. For example, only two reviews{, #4994;, #4990} explicitly reported author conflicts of interest, though, for example, investigators in one meta-analysis were authors of papers included in the analysis. Use of an a priori design was not always clearly stated though generally implied, and we considered review designs a priori if a standardized approach appeared to be employed. Similarly, methods for reviewing abstracts and the full papers of studies were not always clearly described (e.g. use of dual reviewers), and six out of 10 reviews provided a complete (ample enough to likely permit replication) description of search terminology.{, #4990;, #4991;, #4994;, #6084;, #6085;, #3} The reviews typically fully described inclusion/exclusion criteria and characteristics of studies included. Reviews generally stated elements used to evaluate study quality and/or cited quality instruments and, overall, seem to make conclusions warranted by the evidence. Meta-analyses appear to be appropriately conducted; however, they are limited by the heterogeneity of interventions and outcomes assessed in the included studies.

Our discussion of recent reviews is limited by our exclusion of reviews including studies with participants over age 18; several comprehensive and rigorously conducted reviews, such as the National Autism Center’s 2009 National Standards report,{Center, 2009 #5988} Ospina and colleagues review of behavioral and developmental interventions{, #4993} and Seida and colleagues umbrella review of psychosocial interventions{, #4987} are not addressed here.

Our findings in the current review are largely in line with the findings of reviews included here; some evidence points to the effectiveness of early intervention approaches and communication interventions such as PECS, but evidence is lacking for many approaches.