# Approach to Categorizing Study Designs

- Cohort, prospective: studies in which subjects receive more than one type of treatment or exposure (e.g. ABA therapy or DIR/floortime compared to another treatment or no treatment) in order to make comparisons of the outcomes of treatment, in which the investigator(s) does not assign the treatment or non-treatment states for the purposes of comparing them. For the purpose of this review, we termed studies with more than one “exposure” group prospective cohorts to distinguish them from case series. Analysis is focused on estimating the risk or odds of the outcome(s) based on the participants’ exposure (treatment group status). These would include comparative studies in which the treatment is set based on “happenstance” conditions such as availability of a therapist, or parental choice. These types of studies can also be described as employing a non-randomized pre-post group comparison design.
- Cohort, retrospective: studies in which subjects having more than one type of treatment (more than one “exposure”) are identified after having had intervention (e.g., chart review of children with ASD receiving either risperidone or olanzapine). Studies that have some component of follow-up should be classified as retrospective if the intent to follow-up the cohort was not designed and future data collection planned prior to the time of the treatment under investigation. Analysis estimates the risk or odds of the outcome(s) based on the participants’ exposure (treatment group status).
- Randomized clinical trials: special instances of prospective cohorts in which the “exposure” or treatment group is assigned by the investigator through use of an allocation method; treatment and non-treatment are assigned by study investigators using an a priori protocol.
- Controlled trials (nonrandomized): special instances of prospective cohorts in which the exposure or treatment group is assigned by the investigator but without using a randomization scheme.
- Case-control studies: studies that identify cases based on the outcome under study. A control, comparison population is identified that is intended to be a representative sample of similar children. In order to assure similar characteristics overall with respect to covariates not being studied, matching is often used, such as matching on age or race to assure a similar distribution of these potential confounders. Analysis is technically estimating the odds of having had a particular exposure or characteristic given known presence or absence of the outcome.
- Case series, prospective: studies in which subjects (ideally consecutive participants) having the same type of treatment for symptoms of ASD are identified prior to treatment and consented to participate (i.e., all participants receive the same treatment). The components of the study and outcome follow-up are designed before the participants are enrolled. Data analysis is descriptive including the full range of potential outcome measures such as reduction in problem behaviors, changes in IQ, etc. Analysis may include construction of predictive models that seek to examine influences on outcomes, such as IQ at intake, etc. Studies may also present data for groups of participants (e.g., males vs. females) though all participants received the same treatment. Case series might include experimental approaches or analyses such as multiple baseline, reversal, ABAB, alternating treatments, or changing criterion studies in this literature. Group designed studies from which we could only collect data from one arm (e.g., studies that inappropriately compared the effects of an intervention in children with ASD to normally developing children) were considered case series.
- Case series, retrospective: studies in which investigators obtain permission to review existing clinical records in order to summarize the outcomes from a sequence (ideally consecutive patients) receiving the same treatment. Follow-up of the members of a case series identified from medical records or databases using methods such as surveys should still be counted as “retrospective” if the design of the study and future data collection were not established prior to the time of the treatment under study. Analysis is descriptive.