# List of Peer Reviewers

Geraldine Dawson, Ph.D. *

* also served on Technical Expert Panel (TEP)

Research Professor, Department of Psychiatry

UNC-Chapel Hill

Lynn Koegel, Ph.D.

Director, Autism Services, Autism Research Center

University of California, Santa Barbara

Catherine Lord, Ph.D. *

Director, Autism and Communication Disorders Center

University of Michigan

Christina Nicolaidis, M.D., M.P.H.

Associate Professor, Medicine

Oregon Health & Science University

Tristram Smith, Ph.D. *

Associate Professor, Department of Pediatrics

University of Rochester Medical Center

Glenn Tripp, M.D.

Medical Director of Developmental Services

Mary Bridge Children’s Hospital, Tacoma, WA

Paul Yoder, Ph.D. *

Professor, Special Education

Vanderbilt University Kennedy Center